# Key Question 4 Evidence Set

Table K-1 Studies evaluating incremental value of BNP to predict the outcome of all-cause mortality in decompensated heart failure patients for all time points

Table K-2 Studies evaluating incremental value of BNP to predict the outcome of cardiovascular mortality in patients with decompensated heart failure for all time points

Table K-3 Studies evaluating incremental value of NT-proBNP to predict the outcomes of mortality in patients with decompensated heart failure for all time points

Table K-4 Risk of bias for studies using the Hayden criteria assessing BNP and NT-proBNP for decompensated heart failure population

Table K-5 Studies evaluating incremental value of NT-proBNP to predict the outcome of all-cause mortality in patients with stable heart failure

Table K-6 Studies evaluating incremental value of NT-proBNP to predict the outcome of cardiovascular mortality in patients with stable heart failure

Table K-7 Studies evaluating incremental value of NT-proBNP to predict the outcome of morbidity in patients with stable heart failure

Table K-8 Studies evaluating incremental value of NT-proBNP to predict composite outcomes in stable heart failure patients

Table K-9 Risk of bias for studies using the Hayden criteria assessing BNP and NT-proBNP for stable heart failure population

## Appendix K Reference List

1 Maisel A, Mueller C, Nowak R, et al. Mid-region pro-hormone markers for diagnosis and prognosis in acute dyspnea: Results from the BACH (Biomarkers in Acute Heart Failure) trial. J Am Coll Cardiol. 2010;55(19):2062-76. [pmid: 20447528].
2 Nunez J, Sanchis J, Bodi V, et al. Improvement in risk stratification with the combination of the tumour marker antigen carbohydrate 125 and brain natriuretic peptide in patients with acute heart failure. Eur Heart J. 2010;31(14):1752-63. [pmid: 20501480].
3 Nunez J, Nunez E, Robles R, et al. Prognostic value of brain natriuretic peptide in acute heart failure: Mortality and hospital readmission. Rev Esp Cardiol. 2008;61(12):1332-7. [pmid: 19080974].
4 Dunlay SM, Gerber Y, Weston SA, et al. Prognostic value of biomarkers in heart failure: Application of novel methods in the community. Circulation. 2009;2(5):393-400. [pmid: 19808368].
5 Zairis MN, Tsiaousis GZ, Georgilas AT, et al. Multimarker strategy for the prediction of 31 days cardiac death in patients with acutely decompensated chronic heart failure. Int J Cardiol. 2010;141(3):284-90. [pmid: 19157603].
6 Pascual-Figal DA, Manzano-Fernandez S, Boronat M, et al. Soluble ST2, high-sensitivity troponin T- and N-terminal pro-B-type natriuretic peptide: complementary role for risk stratification in acutely decompensated heart failure. Eur J Heart Fail. 2011;13(7):718-25. [pmid: 21551163].
7 Harutyunyan M, Christiansen M, Johansen JS, et al. The inflammatory biomarker YKL-40 as a new prognostic marker for all-cause mortality in patients with heart failure. Immunobiology. 2012;217(6):652-6. [pmid: 22209156].
8 von Haehling S, Filippatos GS, Papassotiriou J, et al. Mid-regional pro-adrenomedullin as a novel predictor of mortality in patients with chronic heart failure. Eur J Heart Fail. 2010;12(5):484-91. [pmid: 20215339].
9 Dini FL, Fontanive P, Panicucci E, et al. Prognostic significance of tricuspid annular motion and plasma NT-proBNP in patients with heart failure and moderate-to-severe functional mitral regurgitation. Eur J Heart Fail. 2008;10(6):573-80. [pmid: 18457990].
10 Masson S, Latini R, Anand IS, et al. Direct comparison of B-type natriuretic peptide (BNP) and amino-terminal proBNP in a large population of patients with chronic and symptomatic heart failure: The Valsartan Heart Failure (Val-HeFT) data. Clin Chem. 2006;52(8):1528-38. [pmid: 16777915].
11 Cleland JG, McMurray JJ, Kjekshus J, et al. Plasma concentration of amino-terminal pro-brain natriuretic peptide in chronic heart failure: Prediction of cardiovascular events and interaction with the effects of rosuvastatin: A report from CORONA (Controlled Rosuvastatin Multinational Trial in Heart Failure). J Am Coll Cardiol. 2009;54(20):1850-9. [pmid: 19892235].
12 Schou M, Gustafsson F, Kistorp CN, et al. Prognostic usefulness of anemia and N-terminal pro-brain natriuretic peptide in outpatients with systolic heart failure. Am J Cardiol. 2007;100(10):1571-6. [pmid: 17996522].
13 Christensen HM, Frystyk J, Faber J, et al. alpha-Defensins and outcome in patients with chronic heart failure. Eur J Heart Fail. 2012;14(4):387-94. [pmid: 22357441].
14 Wedel H, McMurray JJ, Lindberg M, et al. Predictors of fatal and non-fatal outcomes in the Controlled Rosuvastatin Multinational Trial in Heart Failure (CORONA): Incremental value of apolipoprotein A-1, high-sensitivity C-reactive peptide and N-terminal pro B-type natriuretic peptide. Eur J Heart Fail. 2009;11(3):281-91. [pmid: 19168876].
15 Bayes-Genis A, de Antonio M, Galan A, et al. Combined use of high-sensitivity ST2 and NTproBNP to improve the prediction of death in heart failure. Eur J Heart Fail. 2012;14(1):32-8. [pmid: 22179033].
16 de Antonio M, Lupon J, Galan A, et al. Combined use of high-sensitivity cardiac troponin T and N-terminal pro-B type natriuretic peptide improves measurements of performance over established mortality risk factors in chronic heart failure. Am Heart J. 2012;163(5):821-8. [pmid: 22607860].
17 Jankowska EA, Filippatos GS, von Haehling S, et al. Identification of chronic heart failure patients with a high 12-month mortality risk using biomarkers including plasma C-terminal pro-endothelin-1. PLoS ONE. 2011;6(1):e14506. [pmid: 21264211].
18 Dini FL, Rosa GM, Fontanive P, et al. Combining blood flow and tissue Doppler imaging with N-terminal pro-type B natriuretic peptide for risk stratification of clinically stable patients with systolic heart failure. Eur J Echocardiogr. 2010;11(4):333-40. [pmid: 20051423].
19 Mikkelsen KV, Moller JE, Bie P, et al. Tei index and neurohormonal activation in patients with incident heart failure: Serial changes and prognostic value. Eur J Heart Fail. 2006;8(6):599-608. [pmid: 16469536].
20 Dini FL, Conti U, Fontanive P, et al. Prognostic value of N-terminal pro-type-B natriuretic peptide and Doppler left ventricular diastolic variables in patients with chronic systolic heart failure stabilized by therapy. Am J Cardiol. 2008;102(4):463-8. [pmid: 18678307].
21 Dini FL, Fontanive P, Buralli S, et al. N-terminal protype-B natriuretic peptide and Doppler diastolic variables are incremental for risk stratification of patients with NYHA class I-II systolic heart failure. Int J Cardiol. 2009;136(2):144-50. [pmid: 18649955].
22 Bajraktari GD. Independent and incremental prognostic value of Doppler-derived left ventricular total isovolumic time in patients with systolic heart failure. Int J Cardiol. 2011;148(3):271-5. [pmid: 19948365].