# Key Question 3 Evidence Set

Table J-1 Risk of bias for prognostic studies using the Hayden Criteria for decompensated population assessing BNP

Table J-2 Studies evaluating independent predictive value of BNP for the outcome of all-cause mortality (up to 31 days)

Table J-3 Studies evaluating independent predictive value of BNP for the outcome of all-cause mortality (2 to 3 months)

Table J-4 Studies evaluating independent predictive value of BNP for the outcome of all-cause mortality (6 to 11 months)

Table J-5 Studies evaluating independent predictive value of BNP for the outcome of all-cause mortality (12 to 23 months)

Table J-6 Studies evaluating independent predictive value of BNP for the outcome of all-cause mortality (24 months and greater)

Table J-7 Studies evaluating independent predictive value of BNP for the outcome cardiovascular mortality

Table J-8 Studies evaluating independent predictive value of BNP for the outcome of morbidity

Table J-9 Studies evaluating independent predictive value of BNP for the composite outcome of all-cause mortality and morbidity

Table J-10 Studies evaluating independent predictive value of BNP for the composite outcome of all-cause mortality and cardiovascular morbidity

Table J-11 Studies evaluating independent predictive value of BNP for the composite outcome of cardiovascular mortality and morbidity

Table J-12 Risk of bias for prognostic studies using the Hayden Criteria for decompensated population assessing NT-proBNP

Table J-13 Studies evaluating independent predictive value of NT-proBNP for the outcome of all-cause mortality - admission and discharge (up to 31 days) in patients with decompensated heart failure

Table J-14 Studies evaluating independent predictive value of NT-proBNP for the outcome of all-cause mortality - admission and discharge (from 2 to 3 months) in patients with decompensated heart failure

Table J-15 Studies evaluating independent predictive value of NT-proBNP for the outcome of all-cause mortality - admission and discharge (from 6 to 11 months) in patients with decompensated HF

Table J-16 Studies evaluating independent predictive value of NT-proBNP for the outcome of all-cause mortality - admission and discharge (from 12 to 23 months) in patients with decompensated heart failure

Table J-17 Studies evaluating independent predictive value of NT-proBNP for the outcome of all-cause mortality - admission and discharge (from 24 months to 7 years) in patients with decompensated heart failure

Table J-18 Studies evaluating independent predictive value of NT-proBNP for the outcome of cardiovascular mortality – admission and discharge (up to 31 days) in patients with decompensated heart failure

Table J-19 Studies evaluating independent predictive value of NT-proBNP for the outcome of cardiovascular mortality - admission and discharge (all time periods) in patients with decompensated heart failure

Table J-20 Studies evaluating independent predictive value of NT-proBNP for the outcome of morbidity - admission, discharge, and change levels (all time periods) in patients with decompensated heart failure

Table J-21 Studies evaluating independent predictive value of NT-proBNP for the composite outcome of all-cause mortality and morbidity – admission and discharge (all time periods) in patients with decompensated heart failure

Table J-22 Studies evaluating independent predictive value of NT-proBNP for the composite outcome of all-cause mortality and cardiovascular morbidity—admission and discharge (all time periods) in patients with decompensated heart failure

Table J-23 Studies evaluating independent predictive value of NT-proBNP for the composite outcome of cardiovascular mortality and morbidity - admission and discharge (all time periods) in patients with decompensated heart failure

Table J-24 Studies evaluating independent predictive value of both BNP and NT-proBNP for the outcome of all-cause mortality in patients with decompensated heart failure

Table J-25 Risk of bias for prognostic studies using the Hayden Criteria for stable population assessing BNP

Table J-26 Studies evaluating independent predictive value of BNP for the outcome of all-cause mortality in patients with stable heart failure

Table J-27 Studies evaluating independent predictive value of BNP for the outcome of cardiovascular mortality in patients with stable heart failure

Table J-28 Studies evaluating independent predictive value of BNP for the outcome of cardiovascular morbidity in patients with stable heart failure

Table J-29 Studies evaluating independent predictive value of BNP for the outcome of composite of cardiovascular mortality and cardiovascular morbidity in patients with stable heart failure

Table J-30 Studies evaluating independent predictive value of BNP for the outcome of composite of all-cause mortality and cardiovascular morbidity in patients with stable heart failure

Table J-31 Studies evaluating independent predictive value of BNP for the outcome of composite of all-cause mortality and all-cause morbidity in patients with stable heart failure

Table J-32 Risk of bias for prognostic studies using the Hayden Criteria for stable population assessing NT-proBNP

Table J-33 Studies evaluating independent predictive value of NT-proBNP for the outcome of all-cause mortality in patients with stable heart failure

Table J-34 Studies evaluating independent predictive value of NT-proBNP for the outcome of cardiovascular mortality in patients with stable heart failure

Table J-35 Studies evaluating independent predictive value of NT-proBNP for the outcome of all-cause morbidity in patients with stable heart failure

Table J-36 Studies evaluating independent predictive value of NT-proBNP for the outcome of cardiovascular morbidity in patients with stable heart failure

Table J-37 Studies evaluating independent predictive value of NT-proBNP for the outcome of composite of all-cause mortality and all-cause morbidity in patients with stable heart failure

Table J-38 Studies evaluating independent predictive value of NT-proBNP for the outcome of composite of cardiovascular mortality and cardiovascular morbidity in patients with stable heart failure

Table J-39 Studies evaluating independent predictive value of NT-proBNP for the outcome of composite of all-cause mortality and cardiovascular morbidity in patients with stable heart failure

Table J-40 Studies evaluating independent predictive value of NT-proBNP for the outcome of composite of cardiovascular mortality and all-cause morbidity in patients with stable heart failure

Table J-41 Risk of bias for prognostic surgical studies using the Hayden Criteria assessing BNP

Table J-42 Surgical studies evaluating independent predictive value of BNP for the outcome of mortality

Table J-43 Risk of bias for prognostic surgical studies using the Hayden Criteria assessing NT-proBNP

Table J-44 Surgical studies evaluating independent predictive value of NT-proBNP for the outcome of mortality

Table J-45 Risk of bias for prognostic studies using the Hayden Criteria for both stable and decompensated population assessing NT-proBNP

Table J-46 Studies evaluating independent predictive value of NT-proBNP in both decompensated and stable population

## Appendix J Reference List

1 Maisel A, Hollander JE, Guss D, et al. Primary results of the Rapid Emergency Department Heart Failure Outpatient Trial (REDHOT). A multicenter study of B-type natriuretic peptide levels, emergency department decision making, and outcomes in patients presenting with shortness of breath. J Am Coll Cardiol. 2004;44(6):1328-33. [pmid: 15364340].
2 Logeart D, Thabut G, Jourdain P, et al. Predischarge B-type natriuretic peptide assay for identifying patients at high risk of re-admission after decompensated heart failure. J Am Coll Cardiol. 2004;43(4):635-41. [pmid: 14975475].
3 Aspromonte N, Feola M, Milli M, et al. Prognostic role of B-type natriuretic peptide in patients with diabetes and acute decompensated heart failure. Diabet Med. 2007;24(2):124-30. [pmid: 17257273].
4 Stoiser B, Mortl D, Hulsmann M, et al. Copeptin, a fragment of the vasopressin precursor, as a novel predictor of outcome in heart failure. Eur J Clin Invest. 2006;36(11):771-8. [pmid: 17032344].
5 Cournot M, Leprince P, Destrac S, et al. Usefulness of in-hospital change in B-type natriuretic peptide levels in predicting long-term outcome in elderly patients admitted for decompensated heart failure. Am J Geriatr Cardiol. 2007;16(1):8-14. [pmid: 17215637].
6 Sun T, Wang L, Zhang Y. Prognostic value of B-type natriuretic peptide in patients with chronic and advanced heart failure. Intern Med J. 2007;37(3):168-71. [pmid: 17316335].
7 Gegenhuber A, Struck J, Dieplinger B, et al. Comparative evaluation of B-type natriuretic peptide, mid-regional pro-A-type natriuretic peptide, mid-regional pro-adrenomedullin, and Copeptin to predict 1-year mortality in patients with acute destabilized heart failure. J Card Fail. 2007;13(1):42-9. [pmid: 17339002].
8 Kellett J. Prediction of mortality of patients with suspected heart failure by brain natriuretic peptide concentrations > 100 pg/ml: Comparison of a clinical model with brain natriuretic peptide concentrations. Heart. 2006;92(10):1512-3. [pmid: 16973805].
9 Valle R, Aspromonte N, Feola M, et al. B-type natriuretic peptide can predict the medium-term risk in patients with acute heart failure and preserved systolic function. J Card Fail. 2005;11(7):498-503. [pmid: 16198244].
10 Dokainish H, Zoghbi WA, Lakkis NM, et al. Incremental predictive power of B-type natriuretic peptide and tissue Doppler echocardiography in the prognosis of patients with congestive heart failure. J Am Coll Cardiol. 2005;45(8):1223-6. [pmid: 15837253].
11 Di Somma S, Magrini L, Pittoni V, et al. In-hospital percentage BNP reduction is highly predictive for adverse events in patients admitted for acute heart failure: The Italian RED Study. Crit Care. 2010;14(3):R116. [pmid: 20550660].
12 Zairis MN, Tsiaousis GZ, Georgilas AT, et al. Multimarker strategy for the prediction of 31 days cardiac death in patients with acutely decompensated chronic heart failure. Int J Cardiol. 2010;141(3):284-90. [pmid: 19157603].
13 Reichlin T, Socrates T, Egli P, et al. Use of myeloperoxidase for risk stratification in acute heart failure. Clin Chem. 2010;56(6):944-51. [pmid: 20413430].
14 Faggiano P, Valle R, Aspromonte N, et al. How often we need to measure brain natriuretic peptide (BNP) blood levels in patients admitted to the hospital for acute severe heart failure? Role of serial measurements to improve short-term prognostic stratification. Int J Cardiol. 2010;140(1):88-94. [pmid: 19321212].
15 Farmakis D, Parissis JT, Bistola V, et al. Plasma B-type natriuretic peptide reduction predicts long-term response to levosimendan therapy in acutely decompensated chronic heart failure. Int J Cardiol. 2010;139(1):75-9. [pmid: 18973957].
16 Dunlay SM, Gerber Y, Weston SA, et al. Prognostic value of biomarkers in heart failure: Application of novel methods in the community. Circulation. 2009;2(5):393-400. [pmid: 19808368].
17 Singer AJ, Birkhahn RH, Guss D, et al. Rapid Emergency Department Heart Failure Outpatients Trial (REDHOT II): A randomized controlled trial of the effect of serial B-type natriuretic peptide testing on patient management. Circulation. 2009;2(4):287-93. [pmid: 19808351].
18 Parissis JT, Farmakis D, Nikolaou M, et al. Plasma B-type natriuretic peptide and anti-inflammatory cytokine interleukin-10 levels predict adverse clinical outcome in chronic heart failure patients with depressive symptoms: A 1-year follow-up study. Eur J Heart Fail. 2009;11(10):967-72. [pmid: 19789400].
19 Cohen-Solal A, Logeart D, Huang B, et al. Lowered B-type natriuretic peptide in response to levosimendan or dobutamine treatment is associated with improved survival in patients with severe acutely decompensated heart failure. J Am Coll Cardiol. 2009;53(25):2343-8. [pmid: 19539144].
20 Dhaliwal AS, Deswal A, Pritchett A, et al. Reduction in BNP levels with treatment of decompensated heart failure and future clinical events. J Card Fail. 2009;15(4):293-9. [pmid: 19398076].
21 Nunez J, Nunez E, Robles R, et al. Prognostic value of brain natriuretic peptide in acute heart failure: Mortality and hospital readmission. Rev Esp Cardiol. 2008;61(12):1332-7. [pmid: 19080974].
22 Feola M, Aspromonte N, Milani L, et al. Plasma brain natriuretic peptide predicts short-term clinical outcome in heart failure patients with restrictive filling pattern. J Card Fail. 2008;14(5):420-5. [pmid: 18514935].
23 Cournot M, Mourre F, Castel F, et al. Optimization of the use of B-type natriuretic peptide levels for risk stratification at discharge in elderly patients with decompensated heart failure. Am Heart J. 2008;155(6):986-91. [pmid: 18513508].
24 Valle R, Aspromonte N, Carbonieri E, et al. Fall in readmission rate for heart failure after implementation of B-type natriuretic peptide testing for discharge decision: A retrospective study. Int J Cardiol. 2008;126(3):400-6. [pmid: 17804095].
25 Parissis JT, Nikolaou M, Farmakis D, et al. Clinical and prognostic implications of self-rating depression scales and plasma B-type natriuretic peptide in hospitalised patients with chronic heart failure. Heart. 2008;94(5):585-9. [pmid: 17761502].
26 Valle R, Aspromonte N, Giovinazzo P, et al. B-type natriuretic Peptide-guided treatment for predicting outcome in patients hospitalized in sub-intensive care unit with acute heart failure. J Card Fail. 2008;14(3):219-24. [pmid: 18381185].
27 Dieplinger B, Gegenhuber A, Poelz W, et al. Prognostic value of increased adiponectin plasma concentrations in patients with acute destabilized heart failure. Clin Biochem. 2009;42(10-11):1190-3. [pmid: 19272369].
28 Nunez J, Sanchis J, Bodi V, et al. Improvement in risk stratification with the combination of the tumour marker antigen carbohydrate 125 and brain natriuretic peptide in patients with acute heart failure. Eur Heart J. 2010;31(14):1752-63. [pmid: 20501480].
29 Pimenta J, Paulo C, Mascarenhas J, et al. BNP at discharge in acute heart failure patients: Is it all about volemia? A study using impedance cardiography to assess fluid and hemodynamic status. Int J Cardiol. 2010;145(2):209-14. [pmid: 19729213].
30 Xue Y, Clopton P, Peacock WF, et al. Serial changes in high-sensitive troponin I predict outcome in patients with decompensated heart failure. Eur J Heart Fail. 2011;13(1):37-42. [pmid: 21149316].
31 Nahum J, Bensaid A, Dussault C, et al. Impact of longitudinal myocardial deformation on the prognosis of chronic heart failure patients. Circulation. 2010;3(3):249-56. [pmid: 20233858].
32 Rychli K, Richter B, Hohensinner PJ, et al. Hepatocyte growth factor is a strong predictor of mortality in patients with advanced heart failure. Heart. 2011;97(14):1158-63. [pmid: 21572126].
33 Arques S, Roux. Usefulness of serum albumin and serum total cholesterol in the prediction of hospital death in older patients with severe, acute heart failure. Arch Cardiovasc Dis. 2011;104(10):502-8. [pmid: 22044702].
34 Allen LA, Gheorghiade M, Reid KJ, et al. Identifying patients hospitalized with heart failure at risk for unfavorable future quality of life. Circ Cardiovasc Qual Outcomes. 2011;4(4):389-98. [pmid: 21693723].
35 Coyne JCJ. Lack of prognostic value of type D personality for mortality in a large sample of heart failure patients. Psychosom Med. 2011;73(7):557-62. [pmid: 21862826].
36 Maisel AS, Mueller C, Fitzgerald R, et al. Prognostic utility of plasma neutrophil gelatinase-associated lipocalin in patients with acute heart failure: The NGAL EvaLuation Along with B-type NaTriuretic Peptide in acutely decompensated heart failure (GALLANT) trial. Eur J Heart Fail. 2011;13(8):846-51. [pmid: 21791540].
37 Arenja N, Reichlin T, Drexler B, et al. Sensitive cardiac troponin in the diagnosis and risk stratification of acute heart failure. J Intern Med. 2012;271(6):598-607. [pmid: 21988283].
38 Neuhold S, Huelsmann M, Strunk G, et al. Prognostic value of emerging neurohormones in chronic heart failure during optimization of heart failure-specific therapy. Clin Chem. 2010;56(1):121-6. [pmid: 19884490].
39 Sakhuja R, Green S, Oestreicher EM, et al. Amino-terminal pro-brain natriuretic peptide, brain natriuretic peptide, and troponin T for prediction of mortality in acute heart failure. Clin Chem. 2007;53(3):412-20. [pmid: 17259237].
40 Maisel A, Mueller C, Nowak R, et al. Mid-region pro-hormone markers for diagnosis and prognosis in acute dyspnea: Results from the BACH (Biomarkers in Acute Heart Failure) trial. J Am Coll Cardiol. 2010;55(19):2062-76. [pmid: 20447528].
41 Boisot S, Beede J, Isakson S, et al. Serial sampling of ST2 predicts 90-day mortality following destabilized heart failure. J Card Fail. 2008;14(9):732-8. [pmid: 18995177].
42 Noveanu M, Breidthardt T, Potocki M, et al. Direct comparison of serial B-type natriuretic peptide and NT-proBNP levels for prediction of short- and long-term outcome in acute decompensated heart failure. Crit Care. 2011;15(1):R1. [pmid: 21208408].
43 Rehman SU, Mueller T, Januzzi J. Characteristics of the novel interleukin family biomarker ST2 in patients with acute heart failure. J Am Coll Cardiol. 2008;52(18):1458-65. [pmid: 19017513].
44 Peacock WF, Nowak R, Christenson R, et al. Short-term mortality risk in emergency department acute heart failure. Acad Emerg Med. 2011;18(9):947-58. [pmid: 21906204].
45 Bettencourt P, Azevedo A, Pimenta J, et al. N-terminal-pro-brain natriuretic peptide predicts outcome after hospital discharge in heart failure patients. Circ Cardiovasc Qual Outcomes. 2004;110(15):2168-74.
46 Baggish AL, van Kimmenade R, Bayes-Genis A, et al. Hemoglobin and N-terminal pro-brain natriuretic peptide: Independent and synergistic predictors of mortality in patients with acute heart failure results from the International Collaborative of NT-proBNP (ICON) Study. Clin Chim Acta. 2007;381(2):145-50. [pmid: 17445789].
47 Bettencourt P, Azevedo A, Fonseca L, et al. Prognosis of decompensated heart failure patients with preserved systolic function is predicted by NT-proBNP variations during hospitalization. Int J Cardiol. 2007;117(1):75-9. [pmid: 16843555].
48 Perna ER, Macin SM, Cimbaro Canella JP, et al. Importance of early combined N-terminal pro-brain natriuretic peptide and cardiac troponin T measurements for long-term risk stratification of patients with decompensated heart failure. J Heart Lung Transplant. 2006;25(10):1230-40. [pmid: 17045936].
49 van Kimmenade RR, Januzzi JL Jr., Baggish AL, et al. Amino-terminal pro-brain natriuretic Peptide, renal function, and outcomes in acute heart failure: Redefining the cardiorenal interaction?. J Am Coll Cardiol. 2006;48(8):1621-7. [pmid: 17045898].
50 van Kimmenade RR, Januzzi JL Jr., Ellinor PT, et al. Utility of amino-terminal pro-brain natriuretic peptide, galectin-3, and apelin for the evaluation of patients with acute heart failure. J Am Coll Cardiol. 2006;48(6):1217-24. [pmid: 16979009].
51 Marcucci R, Gori AM, Giannotti F, et al. Markers of hypercoagulability and inflammation predict mortality in patients with heart failure. J Thromb Haemostasis. 2006;4(5):1017-22. [pmid: 16689753].
52 Januzzi JL, van Kimmenade R, Lainchbury J, et al. NT-proBNP testing for diagnosis and short-term prognosis in acute destabilized heart failure: An international pooled analysis of 1256 patients: The International Collaborative of NT-proBNP Study. Eur Heart J. 2006;27(3):330-7. [pmid: 16293638].
53 Bayes-Genis A, Lopez L, Zapico E, et al. NT-ProBNP reduction percentage during admission for acutely decompensated heart failure predicts long-term cardiovascular mortality. J Card Fail. 2005;11(5 Suppl):S3-8. [pmid: 15948093].
54 Bayes-Genis A, Pascual-Figal D, Fabregat J, et al. Serial NT-proBNP monitoring and outcomes in outpatients with decompensation of heart failure. Int J Cardiol. 2007;120(3):338-43. [pmid: 17174423].
55 Ferreira SAMP, Almeida R, Guerrero H, et al. Prognosis of decompensated heart failure: Role of NT-proBNP. Rev Port Cardiol. 2007;26(5):535-45. [pmid: 17691279].
56 Pimenta JM, Almeida R, Araujo JP, et al. Amino terminal B-type natriuretic peptide, renal function, and prognosis in acute heart failure: A Hospital Cohort Study. J Card Fail. 2007;13(4):275-80. [pmid: 17517347].
57 Siswanto BB, Sunanto, Munawar M, et al. Predictor of mortality and rehospitalization of acute decompensated heart failure at six months follow up. Critical Care & Shock. 2006;9(3):61-7.
58 Park HS, Kim H, Sohn JH, et al. Combination of uric acid and NT-ProBNP: A more useful prognostic marker for short-term clinical outcomes in patients with acute heart failure. Korean Journal of Internal Medicine. 2010;25(3):253-9. [pmid: 20830221].
59 Davutoglu V, Yildirim C, Kucukaslan H, et al. Prognostic value of pleural effusion, CA-125 and NT-proBNP in patients with acute decompensated heart failure. Kardiol Pol. 2010;68(7):771-8. [pmid: 20648434].
60 Dini FL, Buralli S, Bajraktari G, et al. Plasma matrix metalloproteinase-9 better predicts outcome than N-terminal protype-B natriuretic peptide in patients with systolic heart failure and a high prevalence of coronary artery disease. Biomed Pharmacother. 2010;64(5):339-42. [pmid: 19944559].
61 Mohammed AA, van Kimmenade RR, Richards M, et al. Hyponatremia, natriuretic peptides, and outcomes in acutely decompensated heart failure: Results from the International Collaborative of NT-proBNP Study. Circulation. 2010;3(3):354-61. [pmid: 20332419].
62 Baggish AL, van Kimmenade RR, Pinto Y, et al. New York Heart Association class versus amino-terminal pro-B type natriuretic peptide for acute heart failure prognosis. Biomarkers. 2010;15(4):307-14. [pmid: 20370326].
63 Lourenco P, Azevedo A, Araujo JP, et al. Natriuretic peptide system is not exhausted in severe heart failure. J Cardiovasc Med. 2009;10(1):39-43. [pmid: 19708225].
64 Manzano-Fernandez S, Boronat-Garcia M, Albaladejo-Oton MD, et al. Complementary prognostic value of cystatin C, N-terminal pro-B-type natriuretic Peptide and cardiac troponin T in patients with acute heart failure. Am J Cardiol. 2009;103(12):1753-9. [pmid: 19539088].
65 Kubler P, Jankowska EA, Majda J, et al. Lack of decrease in plasma N-terminal pro-brain natriuretic peptide identifies acute heart failure patients with very poor outcome. Int J Cardiol. 2008;129(3):373-8. [pmid: 18054808].
66 Paul B, Soon KH, Dunne J, et al. Diagnostic and prognostic significance of plasma N-terminal-pro-brain natriuretic peptide in decompensated heart failure with preserved ejection fraction. Heart Lung Circ. 2008;17(6):497-501. [pmid: 18722158].
67 Verdiani V, Ognibene A, Rutili MS, et al. NT-ProBNP reduction percentage during hospital stay predicts long-term mortality and readmission in heart failure patients. J Cardiovasc Med. 2008;9(7):694-9. [pmid: 18545069].
68 Andersson SE, Edvinsson ML, Bjork J, et al. High NT-proBNP is a strong predictor of outcome in elderly heart failure patients. Am J Geriatr Cardiol. 2008;17(1):13-20. [pmid: 18174755].
69 Petretta M, Scopacasa F, Fontanella L, et al. Prognostic value of reduced kidney function and anemia in patients with chronic heart failure. J Cardiovasc Med. 2007;8(11):909-16. [pmid: 17906476].
70 Metra M, Nodari S, Parrinello G, et al. The role of plasma biomarkers in acute heart failure. Serial changes and independent prognostic value of NT-proBNP and cardiac troponin-T. Eur J Heart Fail. 2007;9(8):776-86. [pmid: 17573240].
71 Lassus J, Harjola VP, Sund R, et al. Prognostic value of cystatin C in acute heart failure in relation to other markers of renal function and NT-proBNP. Eur Heart J. 2007;28(15):1841-7. [pmid: 17289743].
72 Luers C, Schmidt A, Wachter R, et al. Serial NT-proBNP measurements for risk stratification of patients with decompensated heart failure. Herz. 2010;35(7):488-96. [pmid: 20927502].
73 Carrasco-Sanchez FJ, Galisteo-Almeda L, Paez-Rubio I, et al. Prognostic value of cystatin C on admission in heart failure with preserved ejection fraction. J Card Fail. 2011;17(1):31-8. [pmid: 21187262].
74 Pascual-Figal DA, Manzano-Fernandez S, Boronat M, et al. Soluble ST2, high-sensitivity troponin T- and N-terminal pro-B-type natriuretic peptide: complementary role for risk stratification in acutely decompensated heart failure. Eur J Heart Fail. 2011;13(7):718-25. [pmid: 21551163].
75 Ho SJ, Feng AN, Lee LN, et al. Predictive value of predischarge spectral tissue doppler echocardiography and n-terminal pro-B-type natriuretic peptide in patients hospitalized with acute heart failure. Echocardiograph. 2011;28(3):303-10.
76 Michtalik HJ, Yeh HC, Campbell CY, et al. Acute changes in N-terminal pro-B-type natriuretic peptide during hospitalization and risk of readmission and mortality in patients with heart failure. Am J Cardiol. 2011;107(8):1191-5. [pmid: 21296322].
77 Korewicki J, Leszek P, Zielinski T, et al. Severe chronic heart failure in patients considered for heart transplantation in Poland. Cardiol J. 2012;19(1):36-44. [pmid: 22298166].
78 Krackhardt F, Dungen HD, Trippel TD, et al. N-terminal pro-B-type natriuretic peptide and long-term mortality in non-ischaemic cardiomyopathy. Wiener Klinische Wochenschrift. 2011;123(23-24):738-42. [pmid: 22105112].
79 Harutyunyan M, Christiansen M, Johansen JS, et al. The inflammatory biomarker YKL-40 as a new prognostic marker for all-cause mortality in patients with heart failure. Immunobiology. 2012;217(6):652-6. [pmid: 22209156].
80 Vrtovec B, Delgado R, Zewail A, et al. Prolonged QTc interval and high B-type natriuretic peptide levels together predict mortality in patients with advanced heart failure. Circ Cardiovasc Qual Outcomes. 2003;107(13):1764-9.
81 Horwich TB, Hamilton MA, Fonarow GC. B-type natriuretic peptide levels in obese patients with advanced heart failure. J Am Coll Cardiol. 2006;47(1):85-90. [pmid: 16386669].
82 Ralli S, Horwich TB, Fonarow GC. Relationship between anemia, cardiac troponin I, and B-type natriuretic peptide levels and mortality in patients with advanced heart failure. Am Heart J. 2005;150(6):1220-7. [pmid: 16338262].
83 Boffa GM, Zaninotto M, Sartor R, et al. Interleukin-6 and tumor necrosis factor-alpha as biochemical markers of heart failure: A head-to-head clinical comparison with B-type natriuretic peptide. J Cardiovasc Med. 2009;10(10):758-64. [pmid: 19553828].
84 Adlbrecht C, Hulsmann M, Strunk G, et al. Prognostic value of plasma midregional pro-adrenomedullin and C-terminal-pro-endothelin-1 in chronic heart failure outpatients. Eur J Heart Fail. 2009;11(4):361-6. [pmid: 19190023].
85 Scardovi AB, De Maria R, Celestini A, et al. Prognostic value of brain natriuretic peptide and enhanced ventilatory response to exercise in patients with chronic heart failure. Intern Emerg Med. 2008;3(4):331-7. [pmid: 18560771].
86 Vrtovec B, Okrajsek R, Golicnik A, et al. Atorvastatin therapy may reduce the incidence of sudden cardiac death in patients with advanced chronic heart failure. J Card Fail. 2008;14(2):140-4. [pmid: 18325461].
87 Bermingham MO. Are beta2-agonists responsible for increased mortality in heart failure?. Eur J Heart Fail. 2011;13(8):885-91. [pmid: 21791542].
88 Kruger S, Graf J, Merx MW, et al. The value of cardiopulmonary exercise testing and brain natriuretic peptide plasma levels in predicting the prognosis of patients with chronic heart failure. European Journal of Internal Medicine. 2006;17(2):96-101. [pmid: 16490685].
89 Kozdag G, Ertas G, Kilic T, et al. Triiodothyronine and brain natriuretic peptide: Similar long-term prognostic values for chronic heart failure. Tex Heart Inst J. 2010;37(5):538-46. [pmid: 20978564].
90 Dries DL, Ky B, Wu AH, et al. Simultaneous assessment of unprocessed ProBNP1-108 in addition to processed BNP32 improves identification of high-risk ambulatory patients with heart failure. Circulation. 2010;3(2):220-7. [pmid: 20107190].
91 Popescu BA, Popescu AC, Antonini-Canterin F, et al. Prognostic role of left atrial volume in elderly patients with symptomatic stable chronic heart failure: Comparison with left ventricular diastolic dysfunction and B-type natriuretic peptide. Echocardiograph. 2007;24(10):1035-43. [pmid: 18001356].
92 Scardovi AB, De Maria R, Coletta C, et al. Multiparametric risk stratification in patients with mild to moderate chronic heart failure. J Card Fail. 2007;13(6):445-51. [pmid: 17675058].
93 Moertl D, Berger R, Struck J, et al. Comparison of midregional pro-atrial and B-type natriuretic peptides in chronic heart failure: Influencing factors, detection of left ventricular systolic dysfunction, and prediction of death. J Am Coll Cardiol. 2009;53(19):1783-90. [pmid: 19422985].
94 Meyer B, Mortl D, Strecker K, et al. Flow-mediated vasodilation predicts outcome in patients with chronic heart failure: Comparison with B-type natriuretic peptide. J Am Coll Cardiol. 2005;46(6):1011-8. [pmid: 16168284].
95 Neuhold S, Huelsmann M, Strunk G, et al. Comparison of copeptin, B-type natriuretic peptide, and amino-terminal pro-B-type natriuretic peptide in patients with chronic heart failure: Prediction of death at different stages of the disease. J Am Coll Cardiol. 2008;52(4):266-72. [pmid: 18634981].
96 Rothenburger M, Wichter T, Schmid C, et al. Aminoterminal pro type B natriuretic peptide as a predictive and prognostic marker in patients with chronic heart failure. J Heart Lung Transplant. 2004;23(10):1189-97. [pmid: 15477114].
97 Gardner RS, Ozalp F, Murday AJ, et al. N-terminal pro-brain natriuretic peptide. A new gold standard in predicting mortality in patients with advanced heart failure. Eur Heart J. 2003;24(19):1735-43. [pmid: 14522568].
98 Gardner RS, Chong V, Morton I, et al. N-terminal brain natriuretic peptide is a more powerful predictor of mortality than endothelin-1, adrenomedullin and tumour necrosis factor-alpha in patients referred for consideration of cardiac transplantation. Eur J Heart Fail. 2005;7(2):253-60. [pmid: 15701475].
99 Hartmann F, Packer M, Coats AJ, et al. Prognostic impact of plasma N-terminal pro-brain natriuretic peptide in severe chronic congestive heart failure: A substudy of the Carvedilol Prospective Randomized Cumulative Survival (COPERNICUS) trial. Circ Cardiovasc Qual Outcomes. 2004;110(13):1780-6.
100 Corell P, Gustafsson F, Kistorp C, et al. Effect of atrial fibrillation on plasma NT-proBNP in chronic heart failure. Int J Cardiol. 2007;117(3):395-402. [pmid: 16919342].
101 Schou M, Gustafsson F, Corell P, et al. The relationship between N-terminal pro-brain natriuretic peptide and risk for hospitalization and mortality is curvilinear in patients with chronic heart failure. Am Heart J. 2007;154(1):123-9. [pmid: 17584564].
102 Guder G, Bauersachs J, Frantz S, et al. Complementary and incremental mortality risk prediction by cortisol and aldosterone in chronic heart failure. Circulation. 2007;115(13):1754-61. [pmid: 17372171].
103 Mikkelsen KV, Moller JE, Bie P, et al. Tei index and neurohormonal activation in patients with incident heart failure: Serial changes and prognostic value. Eur J Heart Fail. 2006;8(6):599-608. [pmid: 16469536].
104 Jankowska EA, Biel B, Majda J, et al. Anabolic deficiency in men with chronic heart failure: Prevalence and detrimental impact on survival. Circ Cardiovasc Qual Outcomes. 2006;114(17):1829-37.
105 Bruch C, Reinecke H, Stypmann J, et al. N-terminal pro-brain natriuretic peptide, kidney disease and outcome in patients with chronic heart failure. J Heart Lung Transplant. 2006;25(9):1135-41. [pmid: 16962477].
106 Masson S, Latini R, Anand IS, et al. Direct comparison of B-type natriuretic peptide (BNP) and amino-terminal proBNP in a large population of patients with chronic and symptomatic heart failure: The Valsartan Heart Failure (Val-HeFT) data. Clin Chem. 2006;52(8):1528-38. [pmid: 16777915].
107 Bruch C, Rothenburger M, Gotzmann M, et al. Risk stratification in chronic heart failure: Independent and incremental prognostic value of echocardiography and brain natriuretic peptide and its N-terminal fragment. J Am Soc Echocardiogr. 2006;19(5):522-8. [pmid: 16644435].
108 Kistorp C, Faber J, Galatius S, et al. Plasma adiponectin, body mass index, and mortality in patients with chronic heart failure. Circ Cardiovasc Qual Outcomes. 2005;112(12):1756-62.
109 George J, Patal S, Wexler D, et al. Circulating matrix metalloproteinase-2 but not matrix metalloproteinase-3, matrix metalloproteinase-9, or tissue inhibitor of metalloproteinase-1 predicts outcome in patients with congestive heart failure. Am Heart J. 2005;150(3):484-7. [pmid: 16169329].
110 George J, Patal S, Wexler D, et al. Circulating erythropoietin levels and prognosis in patients with congestive heart failure: Comparison with neurohormonal and inflammatory markers. Arch Intern Med. 2005;165(11):1304-9. [pmid: 15956012].
111 Gardner RS, Chong KS, Morton JJ, et al. N-terminal brain natriuretic peptide, but not anemia, is a powerful predictor of mortality in advanced heart failure. J Card Fail. 2005;11(5 Suppl):S47-53. [pmid: 15948101].
112 Gardner RS, Henderson G, McDonagh TA. The prognostic use of right heart catheterization data in patients with advanced heart failure: How relevant are invasive procedures in the risk stratification of advanced heart failure in the era of neurohormones?. J Heart Lung Transplant. 2005;24(3):303-9. [pmid: 15737757].
113 Sherwood A, Blumenthal JA, Trivedi R, et al. Relationship of depression to death or hospitalization in patients with heart failure. Arch Intern Med. 2007;167(4):367-73. [pmid: 17325298].
114 Jankowska EA, Drohomirecka A, Ponikowska B, et al. Deficiencies in circulating testosterone and dehydroepiandrosterone sulphate, and depression in men with systolic chronic heart failure. Eur J Heart Fail. 2010;12(9):966-73. [pmid: 20595194].
115 Codognotto M, Piccoli A, Zaninotto M, et al. Effect of a dialysis session on the prognostic values of NT-proBNP, troponins, endothelial damage and inflammation biomarkers. J Nephrol. 2010;23(4):465-71. [pmid: 20540041].
116 Dini FL, Gabutti A, Passino C, et al. Atrial fibrillation and amino-terminal pro-brain natriuretic peptide as independent predictors of prognosis in systolic heart failure. Int J Cardiol. 2010;140(3):344-50. [pmid: 19128846].
117 Berger R, Moertl D, Peter S, et al. N-terminal pro-B-type natriuretic peptide-guided, intensive patient management in addition to multidisciplinary care in chronic heart failure a 3-arm, prospective, randomized pilot study. J Am Coll Cardiol. 2010;55(7):645-53. [pmid: 20170790].
118 Tsutamoto T, Kawahara C, Nishiyama K, et al. Prognostic role of highly sensitive cardiac troponin I in patients with systolic heart failure. Am Heart J. 2010;159(1):63-7. [pmid: 20102868].
119 Nishiyama K, Tsutamoto T, Yamaji M, et al. Dose-dependent prognostic effect of carvedilol in patients with chronic heart failure--special reference to transcardiac gradient of norepinephrine. Circ J. 2009;73(12):2270-5. [pmid: 19838002].
120 Al Najjar Y, Goode KM, Zhang J, et al. Red cell distribution width: an inexpensive and powerful prognostic marker in heart failure. Eur J Heart Fail. 2009;11(12):1155-62. [pmid: 19926599].
121 Frankenstein L, Zugck C, Nelles M, et al. The obesity paradox in stable chronic heart failure does not persist after matching for indicators of disease severity and confounders. Eur J Heart Fail. 2009;11(12):1189-94. [pmid: 19887494].
122 Cleland JG, McMurray JJ, Kjekshus J, et al. Plasma concentration of amino-terminal pro-brain natriuretic peptide in chronic heart failure: Prediction of cardiovascular events and interaction with the effects of rosuvastatin: A report from CORONA (Controlled Rosuvastatin Multinational Trial in Heart Failure). J Am Coll Cardiol. 2009;54(20):1850-9. [pmid: 19892235].
123 Charach G, George J, Afek A, et al. Antibodies to oxidized LDL as predictors of morbidity and mortality in patients with chronic heart failure. J Card Fail. 2009;15(9):770-4. [pmid: 19879463].
124 Zielinski T, Browarek A, Zembala M, et al. Risk stratification of patients with severe heart failure awaiting heart transplantation-Prospective national registry POLKARD HF. Transplant Proc. 2009;41(8):3161-5. [pmid: 19857702].
125 Poletti R, Passino C, Giannoni A, et al. Risk factors and prognostic value of daytime Cheyne-Stokes respiration in chronic heart failure patients. Int J Cardiol. 2009;137(1):47-53. [pmid: 18691782].
126 Epelman S, Shrestha K, Troughton RW, et al. Soluble angiotensin-converting enzyme 2 in human heart failure: Relation with myocardial function and clinical outcomes. J Card Fail. 2009;15(7):565-71. [pmid: 19700132].
127 Dini FL, Fontanive P, Buralli S, et al. N-terminal protype-B natriuretic peptide and Doppler diastolic variables are incremental for risk stratification of patients with NYHA class I-II systolic heart failure. Int J Cardiol. 2009;136(2):144-50. [pmid: 18649955].
128 Vazquez R, Bayes-Genis A, Cygankiewicz I, et al. The MUSIC Risk score: A simple method for predicting mortality in ambulatory patients with chronic heart failure. Eur Heart J. 2009;30(9):1088-96. [pmid: 19240065].
129 Frankenstein L, Clark AL, Goode K, et al. The prognostic value of individual NT-proBNP values in chronic heart failure does not change with advancing age. Heart. 2009;95(10):825-9. [pmid: 19147626].
130 Kubanek M, Goode KM, Lanska V, et al. The prognostic value of repeated measurement of N-terminal pro-B-type natriuretic peptide in patients with chronic heart failure due to left ventricular systolic dysfunction. Eur J Heart Fail. 2009;11(4):367-77. [pmid: 19179406].
131 Wedel H, McMurray JJ, Lindberg M, et al. Predictors of fatal and non-fatal outcomes in the Controlled Rosuvastatin Multinational Trial in Heart Failure (CORONA): Incremental value of apolipoprotein A-1, high-sensitivity C-reactive peptide and N-terminal pro B-type natriuretic peptide. Eur J Heart Fail. 2009;11(3):281-91. [pmid: 19168876].
132 Pfisterer M, Buser P, Rickli H, et al. BNP-guided vs symptom-guided heart failure therapy: the Trial of Intensified vs Standard Medical Therapy in Elderly Patients With Congestive Heart Failure (TIME-CHF) randomized trial. JAMA. 2009;301(4):383-92. [pmid: 19176440].
133 Koc M, Bozkurt A, Yildiray-Sahin D, et al. Cutoff values of NT-proBNP for the prediction of low functional capacity, decreased ejection fraction and cardiovascular events in patients with heart failure. Cardiol J. 2009;16(1):43-9. [pmid: 19130415].
134 Michowitz Y, Kisil S, Guzner-Gur H, et al. Usefulness of serum myeloperoxidase in prediction of mortality in patients with severe heart failure. Isr Med Assoc J. 2008;10(12):884-8. [pmid: 19160948].
135 Honold J, Geiger L, Assmus B, et al. The initial slope of the VCO2/VO2-curve (s1) in cardiopulmonary exercise testing is a strong and independent predictor of outcome in patients with previous myocardial infarction. Clin Res Cardiol. 2008;97(12):882-90. [pmid: 18696021].
136 Tsutamoto T, Nishiyama K, Sakai H, et al. Transcardiac increase in norepinephrine and prognosis in patients with chronic heart failure. Eur J Heart Fail. 2008;10(12):1208-14. [pmid: 18977693].
137 Hinderliter AL, Blumenthal JA, O'Conner C, et al. Independent prognostic value of echocardiography and N-terminal pro-B-type natriuretic peptide in patients with heart failure. Am Heart J. 2008;156(6):1191-5. [pmid: 19033018].
138 Frankenstein L, Remppis A, Nelles M, et al. Relation of N-terminal pro-brain natriuretic peptide levels and their prognostic power in chronic stable heart failure to obesity status. Eur Heart J. 2008;29(21):2634-40. [pmid: 18765456].
139 Kallistratos MS, Dritsas A, Laoutaris ID, et al. Incremental value of N-terminal pro-brain natriuretic peptide over left ventricle ejection fraction and aerobic capacity for estimating prognosis in heart failure patients. J Heart Lung Transplant. 2008;27(11):1251-6. [pmid: 18971099].
140 Masson S, Latini R, Anand IS, et al. Prognostic value of changes in N-terminal pro-brain natriuretic peptide in Val-HeFT (Valsartan Heart Failure Trial). J Am Coll Cardiol. 2008;52(12):997-1003. [pmid: 18786480].
141 Grewal J, McKelvie RS, Persson H, et al. Usefulness of N-terminal pro-brain natriuretic peptide and brain natriuretic peptide to predict cardiovascular outcomes in patients with heart failure and preserved left ventricular ejection fraction. Am J Cardiol. 2008;102(6):733-7. [pmid: 18773998].
142 Bruch C, Fischer C, Sindermann J, et al. Comparison of the prognostic usefulness of N-terminal pro-brain natriuretic peptide in patients with heart failure with versus without chronic kidney disease. Am J Cardiol. 2008;102(4):469-74. [pmid: 18678308].
143 Dini FL, Fontanive P, Panicucci E, et al. Prognostic significance of tricuspid annular motion and plasma NT-proBNP in patients with heart failure and moderate-to-severe functional mitral regurgitation. Eur J Heart Fail. 2008;10(6):573-80. [pmid: 18457990].
144 Amir O, Paz H, Ammar R, et al. Usefulness and predictive value of circulating NT-proBNP levels to stratify patients for referral and priority treatment in a specialized outpatient heart failure center. Isr Med Assoc J. 2008;10(2):109-12. [pmid: 18432021].
145 Pascual-Figal DA, Domingo M, Casas T, et al. Usefulness of clinical and NT-proBNP monitoring for prognostic guidance in destabilized heart failure outpatients. Eur Heart J. 2008;29(8):1011-8. [pmid: 18263871].
146 Moertl D, Hammer A, Huelsmann M, et al. Prognostic value of sequential measurements of amino-terminal prohormone of B-type natriuretic peptide in ambulatory heart failure patients. Eur J Heart Fail. 2008;10(4):404-11. [pmid: 18358775].
147 Koc M, Bozkurt A, Acarturk E, et al. Usefulness of N-terminal pro-B-type natriuretic peptide increase with exercise for predicting cardiovascular mortality in patients with heart failure. Am J Cardiol. 2008;101(8):1157-62. [pmid: 18394451].
148 Pfister R, Diedrichs H, Schiedermair A, et al. Prognostic impact of NT-proBNP and renal function in comparison to contemporary multi-marker risk scores in heart failure patients. Eur J Heart Fail. 2008;10(3):315-20. [pmid: 18304872].
149 Gardner RS, Chong KS, O'Meara E, et al. Renal dysfunction, as measured by the modification of diet in renal disease equations, and outcome in patients with advanced heart failure. Eur Heart J. 2007;28(24):3027-33. [pmid: 17967819].
150 Tsutamoto T, Sakai H, Nishiyama K, et al. Direct comparison of transcardiac increase in brain natriuretic peptide (BNP) and N-terminal proBNP and prognosis in patients with chronic heart failure. Circ J. 2007;71(12):1873-8. [pmid: 18037739].
151 von Haehling S, Jankowska EA, Morgenthaler NG, et al. Comparison of midregional pro-atrial natriuretic peptide with N-terminal pro-B-type natriuretic peptide in predicting survival in patients with chronic heart failure. J Am Coll Cardiol. 2007;50(20):1973-80. [pmid: 17996563].
152 Schou M, Gustafsson F, Kistorp CN, et al. Prognostic usefulness of anemia and N-terminal pro-brain natriuretic peptide in outpatients with systolic heart failure. Am J Cardiol. 2007;100(10):1571-6. [pmid: 17996522].
153 Frankenstein L, Nelles M, Slavutsky M, et al. Beta-blockers influence the short-term and long-term prognostic information of natriuretic peptides and catecholamines in chronic heart failure independent from specific agents. J Heart Lung Transplant. 2007;26(10):1033-9. [pmid: 17919624].
154 Kempf T, von Haehling S, Peter T, et al. Prognostic utility of growth differentiation factor-15 in patients with chronic heart failure. J Am Coll Cardiol. 2007;50(11):1054-60. [pmid: 17825714].
155 Michowitz Y, Goldstein E, Wexler D, et al. Circulating endothelial progenitor cells and clinical outcome in patients with congestive heart failure. Heart. 2007;93(9):1046-50. [pmid: 17277352].
156 Bayes-Genis A, Vazquez R, Puig T, et al. Left atrial enlargement and NT-proBNP as predictors of sudden cardiac death in patients with heart failure. Eur J Heart Fail. 2007;9(8):802-7. [pmid: 17569580].
157 Yin WH, Chen JW, Feng AN, et al. Multimarker approach to risk stratification among patients with advanced chronic heart failure. Clin Cardiol. 2007;30(8):397-402. [pmid: 17680620].
158 Petretta M, Colao A, Sardu C, et al. NT-proBNP, IGF-I and survival in patients with chronic heart failure. Growth Hormone IGF Res. 2007;17(4):288-96. [pmid: 17383209].
159 Tsutamoto T, Tanaka T, Sakai H, et al. Total and high molecular weight adiponectin, haemodynamics, and mortality in patients with chronic heart failure. Eur Heart J. 2007;28(14):1723-30. [pmid: 17507366].
160 MacGowan GA, Neely D, Peaston R, et al. Evaluation of NT-proBNP to predict outcomes in advanced heart failure. INT J CLIN PRACT. 2010;64(7):892-9. [pmid: 20584222].
161 Song EK, Moser DK, Frazier SK, et al. Depressive symptoms affect the relationship of N-terminal pro B-type natriuretic peptide to cardiac event-free survival in patients with heart failure. J Card Fail. 2010;16(7):572-8. [pmid: 20610233].
162 Jankowska EA, Rozentryt P, Witkowska A, et al. Iron deficiency: An ominous sign in patients with systolic chronic heart failure. Eur Heart J. 2010;31(15):1872-80. [pmid: 20570952].
163 Jankowska EA, Filippatos GS, von Haehling S, et al. Identification of chronic heart failure patients with a high 12-month mortality risk using biomarkers including plasma C-terminal pro-endothelin-1. PLoS ONE. 2011;6(1):e14506. [pmid: 21264211].
164 Tang WH, Shrestha K, Troughton RW, et al. Integrating plasma high-sensitivity C-reactive protein and myeloperoxidase for risk prediction in chronic systolic heart failure. Congest Heart Fail. 2011;17(3):105-9. [pmid: 21609382].
165 Schierbeck LL, Jensen TS, Bang U, et al. Parathyroid hormone and vitamin D--Markers for cardiovascular and all cause mortality in heart failure. Eur J Heart Fail. 2011;13(6):626-32. [pmid: 21415099].
166 Raposeiras-Roubin S, Rodino-Janeiro BK, Grigorian-Shamagian L, et al. Relation of soluble receptor for advanced glycation end products to predict mortality in patients with chronic heart failure independently of Seattle Heart Failure Score. Am J Cardiol. 2011;107(6):938-44. [pmid: 21247530].
167 von Haehling S, Filippatos GS, Papassotiriou J, et al. Mid-regional pro-adrenomedullin as a novel predictor of mortality in patients with chronic heart failure. Eur J Heart Fail. 2010;12(5):484-91. [pmid: 20215339].
168 Van Den Broek KC, deFilippi CR, Christenson RH, et al. Predictive value of depressive symptoms and B-type natriuretic peptide for new-onset heart failure and mortality. Am J Cardiol. 2011;107(5):723-9. [pmid: 21316507].
169 Kawahara CT. Prognostic value of serial measurements of highly sensitive cardiac troponin i in stable outpatients with nonischemic chronic heart failure. Am Heart J. 2011;162(4):639-45. [pmid: 21982655].
170 Pfister RM-E. NT-pro-BNP predicts worsening renal function in patients with chronic systolic heart failure. Intern Med J. 2011;41(6):467-72. [pmid: 20214692].
171 Frankenstein L, Goode K, Ingle L, et al. Derivation and validation of a simple clinical risk-model in heart failure based on 6 minute walk test performance and NT-proBNP status - Do we need specificity for sex and beta-blockers?. Int J Cardiol. 2011;147(1):74-8. [pmid: 19765836].
172 Bajraktari GD. Independent and incremental prognostic value of Doppler-derived left ventricular total isovolumic time in patients with systolic heart failure. Int J Cardiol. 2011;148(3):271-5. [pmid: 19948365].
173 Carlsen CM, Bay M, Kirk V, et al. Prevalence and prognosis of heart failure with preserved ejection fraction and elevated N-terminal pro brain natriuretic peptide: A 10-year analysis from the Copenhagen Hospital Heart Failure Study. Eur J Heart Fail. 2012;14(3):240-7. [pmid: 22315457].
174 Broch K, Ueland T, Nymo SH, et al. Soluble ST2 is associated with adverse outcome in patients with heart failure of ischaemic aetiology. Eur J Heart Fail. 2012;14(3):268-77. [pmid: 22302661].
175 Tziakas DN, Chalikias GK, Stakos D, et al. Independent and additive prognostic ability of serum carboxy-terminal telopeptide of collagen type-I in heart failure patients: A multi-marker approach with high-negative predictive value to rule out long-term adverse events. European Journal of Preventive Cardiology. 2012;19(1):62-71. [pmid: 20479644].
176 Bayes-Genis A, de Antonio M, Galan A, et al. Combined use of high-sensitivity ST2 and NTproBNP to improve the prediction of death in heart failure. Eur J Heart Fail. 2012;14(1):32-8. [pmid: 22179033].
177 Franke J, Frankenstein L, Schellberg D, et al. Is there an additional benefit of serial NT-proBNP measurements in patients with stable chronic heart failure receiving individually optimized therapy?. Clin Res Cardiol. 2011;100(12):1059-67. [pmid: 21779816].
178 Jungbauer CG, Riedlinger J, Buchner S, et al. High-sensitive troponin T in chronic heart failure correlates with severity of symptoms, left ventricular dysfunction and prognosis independently from N-terminal pro-b-type natriuretic peptide. Clin Chem Lab Med. 2011;49(11):1899-906. [pmid: 21892905].
179 Anand IS, Rector TS, Cleland JG, et al. Prognostic value of baseline plasma amino-terminal pro-brain natriuretic peptide and its interactions with irbesartan treatment effects in patients with heart failure and preserved ejection fraction: Findings from the I-PRESERVE trial. Circulation. 2011;4(5):569-77. [pmid: 21715583].
180 de Antonio M, Lupon J, Galan A, et al. Combined use of high-sensitivity cardiac troponin T and N-terminal pro-B type natriuretic peptide improves measurements of performance over established mortality risk factors in chronic heart failure. Am Heart J. 2012;163(5):821-8. [pmid: 22607860].
181 Balling L, Kistorp C, Schou M, et al. Plasma copeptin levels and prediction of outcome in heart failure outpatients: Relation to hyponatremia and loop diuretic doses. J Card Fail. 2012;18(5):351-8. [pmid: 22555263].
182 Al-Najjar Y, Witte KK, Clark AL. Chronotropic incompetence and survival in chronic heart failure. Int J Cardiol. 2012;157(1):48-52. [pmid: 21185094].
183 Christensen HM, Frystyk J, Faber J, et al. alpha-Defensins and outcome in patients with chronic heart failure. Eur J Heart Fail. 2012;14(4):387-94. [pmid: 22357441].
184 Lellouche N, De Diego C, Cesario DA, et al. Usefulness of preimplantation B-type natriuretic peptide level for predicting response to cardiac resynchronization therapy. Am J Cardiol. 2007;99(2):242-6. [pmid: 17223426].
185 Glick A, Michowitz Y, Keren G, et al. Neurohormonal and inflammatory markers as predictors of short-term outcome in patients with heart failure and cardiac resynchronization therapy. Isr Med Assoc J. 2006;8(6):391-5. [pmid: 16833167].
186 El Saed A, Voigt A, Shalaby A. Usefulness of brain natriuretic peptide level at implant in predicting mortality in patients with advanced but stable heart failure receiving cardiac resynchronization therapy. Clin Cardiol. 2009;32(11):E33-8. [pmid: 19816874].
187 Leibowitz D, Planer D, Rott D, et al. Brain natriuretic peptide levels predict perioperative events in cardiac patients undergoing noncardiac surgery: A prospective study. Cardiol. 2008;110(4):266-70. [pmid: 18073483].
188 Pitzalis MV, Iacoviello M, Di Serio F, et al. Prognostic value of brain natriuretic peptide in the management of patients receiving cardiac resynchronization therapy. Eur J Heart Fail. 2006;8(5):509-14. [pmid: 16503416].
189 Koch M, Haastert B, Kohnle M, et al. Peritoneal dialysis relieves clinical symptoms and is well tolerated in patients with refractory heart failure and chronic kidney disease. Eur J Heart Fail. 2012;14(5):530-9. [pmid: 22447950].
190 Assmus B, Fischer-Rasokat U, Honold J, et al. Transcoronary transplantation of functionally competent BMCs is associated with a decrease in natriuretic peptide serum levels and improved survival of patients with chronic postinfarction heart failure: Results of the TOPCARE-CHD Registry. Circ Res. 2007;100(8):1234-41. [pmid: 17379833].
191 Berger R, Shankar A, Fruhwald F, et al. Relationships between cardiac resynchronization therapy and N-terminal pro-brain natriuretic peptide in patients with heart failure and markers of cardiac dyssynchrony: An analysis from the Cardiac Resynchronization in Heart Failure (CARE-HF) study. Eur Heart J. 2009;30(17):2109-16. [pmid: 19493864].
192 Cleland J, Freemantle N, Ghio S, et al. Predicting the long-term effects of cardiac resynchronization therapy on mortality from baseline variables and the early response a report from the CARE-HF (Cardiac Resynchronization in Heart Failure) Trial. J Am Coll Cardiol. 2008;52(6):438-45. [pmid: 18672164].
193 Dini FL, Conti U, Fontanive P, et al. Prognostic value of N-terminal pro-type-B natriuretic peptide and Doppler left ventricular diastolic variables in patients with chronic systolic heart failure stabilized by therapy. Am J Cardiol. 2008;102(4):463-8. [pmid: 18678307].
194 Dini FL, Guglin M, Simioniuc A, et al. Association of furosemide dose with clinical status, left ventricular dysfunction, natriuretic peptides, and outcome in clinically stable patients with chronic systolic heart failure. Congest Heart Fail. 2012;18(2):98-106. [pmid: 22432556].