# Key Question 2 Evidence Set

Table I-1 Summary of diagnostic properties of studies evaluating BNP in patients with symptoms suggestive of HF at primary care settings

Table I-2 Detailed diagnostic properties of studies evaluating BNP in patients with symptoms suggestive of HF at primary care settings

Figure I-1 Summary forest plot of sensitivity and specificity (PC BNP, manufacturer cut-point), bivariate mixed effect model

This figure shows the forest plots of sensitivity and specificity estimates of BNP assay with 95% confidence interval (95% CI) using bivariate mixed effect model approach when considering the manufacturer cut-point of diagnostic studies of heart failure in primary care settings. The pooled esimate for sensitivity of 8 included studies is 0.76 (95% CI: 0.59, 0.87) and for specificity is 0.71 (95% CI: 0.52, 0.85). 1 out of 8 studies showed a sensitivity of 90% and above while 7 studies showed a sensitivity of below 90%. Similarly, 5 out of 8 studies showed a specificity of 70% and above while 3 studies showed a specificity of below 70%

Figure I-2 Summary forest plot of sensitivity and specificity (PC BNP, optimum cut-point), bivariate mixed effect model

This figure shows the forest plots of sensitivity and specificity estimates of BNP assay with 95% confidence interval (95% CI) using bivariate mixed effect model approach when considering the optimal cut-points of diagnostic studies of heart failure in primary care settings. The pooled esimate for sensitivity of 8 included studies is 0.82 (95% CI: 0.69, 0.90) and for specificity is 0.64 (95% CI: 0.45, 0.79). 2 out of 8 studies showed a sensitivity of 90% and above while 6 studies showed a sensitivity of below 90%. Similarly, 4 out of 8 studies showed a specificity of 70% and above while 4 studies showed a specificity of below 70%.

Figure I-3 Summary forest plot of sensitivity and specificity (PC BNP, lowest cut-point), bivariate mixed effect model

This figure shows the forest plots of sensitivity and specificity estimates of BNP assay with 95% confidence interval (95% CI) using bivariate mixed effect model approach when considering the lowest cut-points of diagnostic studies of heart failure in primary care settings. The pooled esimate for sensitivity of 10 included studies is 0.89 (95% CI: 0.77, 0.95) and for specificity is 0.54 (95% CI: 0.41, 0.66). 4 out of 10 studies showed a sensitivity of 90% and above while 6 studies showed a sensitivity of below 90%. Similarly, 7 out of 10 studies showed a specificity of below 70% while 3 studies showed a specificity of 70% and above.

Figure I-4 Summary forest plot of LR+ and LR- (PC BNP, manufacturer cut-point), bivariate mixed effect model

This figure shows the forest plot of bivariate mixed effect model for estimating the positive likelihood ratio (LR+) and negative likelihood ratio (LR-) of BNP assay with 95% confidence interval (95% CI) when considering the manufacturer cut-points of diagnostic studies of heart failure in primary care settings. The poooled estimate for LR+ of 8 included studies is 2.63 (95% CI: 1.59, 4.36) and for LR- is 0.34 (95% CI: 0.20, 0.57). Off them, one study showed an LR+ of 5 or more than 5, while 7 studies have LR+ less than 5. Similarly, 7 studies have LR- of 0.1 or more than 0.1, while one study has LR- less than 0.1.

Figure I-5 Summary forest plot of LR+ and LR- (PC BNP, optimum cut-point), bivariate mixed effect model

This figure shows the forest plot of bivariate mixed effect model for estimating the positive likelihood ratio (LR+) and negative likelihood ratio (LR-) of BNP assay with 95% confidence interval (95% CI) when considering the optimal cut-points of diagnostic studies of heart failure in primary care settings. The poooled estimate for LR+ of 8 included studies is 2.27 (95% CI: 1.43, 3.62) and for LR- is 0.28 (95% CI: 0.16, 0.49). Off them, one study showed an LR+ of 5 or more than 5, while 7 studies have LR+ less than 5. All studies showed an LR- of 0.1 or more than 0.1.

Figure I-6 Summary forest plot of LR+ and LR- (PC BNP, lowest cut-point), bivariate mixed effect model

This figure shows the forest plot of bivariate mixed effect model for estimating the positive likelihood ratio (LR+) and negative likelihood ratio (LR-) of BNP assay with 95% confidence interval (95% CI) when considering the lowest cut-points of diagnostic studies of heart failure in primary care settings. The poooled estimate for LR+ of 10 included studies is 1.94 (95% CI: 1.47, 2.57) and for LR- is 0.20 (95% CI: 0.09, 0.44). Off them, none of the studies showed an LR+ of 5 or more than 5, while 10 studies have LR+ less than 5. Similarly, 8 studies have LR- of 0.1 or more than 0.1, while 2 studies have LR- less than 0.1.

Figure I-7 Summary forest plot of LogDOR and DOR (PC BNP, manufacturer cut-point), bivariate mixed effect model

This figure shows the forest plot of bivariate mixed effect model for estimating the log of diagnostic odds ratio log(DOR) and diagnostic odds ratio (DOR) of BNP assay with 95% confidence interval (95% CI) when considering the manufacturer cut-points of diagnostic studies of heart failure in primary care settings. The poooled estimate for log(DOR) of 8 included studies is 2.06 (95% CI: 1.27, 2.84) and for DOR is 7.81 (95% CI: 3.56, 17.12). Off them, none of the studies showed a log(DOR) of 5 or more than 5, while 8 studies have log(DOR) less than 5. Similarly, none of the studies showed a DOR of 100 or more than 100, while 8 studies have DOR less than 100.

Figure I-8 Summary forest plot of LogDOR and DOR (PC BNP, optimum cut-point), bivariate mixed effect model

This figure shows the forest plot of bivariate mixed effect model for estimating the log of diagnostic odds ratio log(DOR) and diagnostic odds ratio (DOR) of BNP assay with 95% confidence interval (95% CI) when considering the optimal cut-points of diagnostic studies of heart failure in primary care settings. The poooled estimate for log(DOR) of 8 included studies is 2.08 (95% CI: 1.24, 2.92) and for DOR is 8.03 (95% CI: 3.46, 18.63). Off them, none of the studies showed a log(DOR) of 5 or more than 5, while 8 studies have log(DOR) less than 5. Similarly, none of the studies showed a DOR of 100 or more than 100, while 8 studies have DOR less than 100.

Figure I-9 Summary forest plot of LogDOR and DOR (PC BNP, lowest cut-point), bivariate mixed effect model

This figure shows the forest plot of bivariate mixed effect model for estimating the log of diagnostic odds ratio log(DOR) and diagnostic odds ratio (DOR) of BNP assay with 95% confidence interval (95% CI) when considering the lowest cut-points of diagnostic studies of heart failure in primary care settings. The poooled estimate for log(DOR) of 10 included studies is 2.27 (95% CI: 1.32, 3.22) and for DOR is 9.72 (95% CI: 3.76, 25.13). Off them, one of the studies showed a log(DOR) of 5 or more than 5, while 9 studies have log(DOR) less than 5. Similarly, one of the studies showed a DOR of 100 or more than 100, while 9 studies have DOR less than 100.

Figure I-10 Summary ROC-curve (PC BNP, manufacturer cut-point), bivariate mixed effect model

This figure shows the Summary Receiver Operating Curve (SROC) using bivariate mixed effects model for estimating the area under the curve (AUC) of BNP assay with 95% confidence interval (95% CI) when considering the manufacturer cut-points (100±5 pg/ml) of diagnostic studies of heart failure in primary care settings. Estimated AUC of 8 included studies is 0.80 (95% CI: 0.76, 0.83). Each circle denotes one study. The horizontal line represents specificity and vertical line represents sensitivity.

Figure I-11 Summary ROC-curve (PC BNP, optimum cut-point), bivariate mixed effect model

This figure shows the Summary Receiver Operating Curve (SROC) using bivariate mixed effects model for estimating the area under the curve (AUC) of BNP assay with 95% confidence interval (95% CI) when considering the optimal cut-points of diagnostic studies of heart failure in primary care settings. Estimated AUC of 8 included studies is 0.81 (95% CI: 0.77, 0.84). Each circle denotes one study. The horizontal line represents specificity and vertical line represents sensitivity.

Figure I-12 Summary ROC-curve (PC BNP, lowest cut-point), bivariate mixed effect model

This figure shows the Summary Receiver Operating Curve (SROC) using bivariate mixed effects model for estimating the area under the curve (AUC) of BNP assay with 95% confidence interval (95% CI) when considering the lowest cut-points of diagnostic studies of heart failure in primary care settings. Estimated AUC of 10 included studies is 0.76 (95% CI: 0.72, 0.80). Each circle denotes one study. The horizontal line represents specificity and vertical line represents sensitivity.

Table I-3 Summary of diagnostic properties of studies that evaluated NT-proBNP in patients with symptoms suggestive of HF in the primary care settings

Table I-4 Detailed diagnostic properties of studies that evaluated NT-proBNP in patients with symptoms suggestive of heart failure in the primary care settings

Figure I-13 Summary forest plot of sensitivity and specificity (PC NTProBNP, optimum cut-point), bivariate mixed effect model

This figure shows the forest plots of sensitivity and specificity estimates of NT-proBNP assay with 95% confidence interval (95% CI) using bivariate mixed effect model approach when considering the optimal cut-points of diagnostic studies of heart failure in primary care settings. The pooled esimate for sensitivity of 11 included studies is 0.88 (95% CI: 0.81, 0.93) and for specificity is 0.61 (95% CI: 0.47, 0.74). 7 out of 11 studies showed a sensitivity of 90% and above while 4 studies showed a sensitivity of below 90%. Similarly, 2 out of 11 studies showed a specificity of 70% and above while 9 studies showed a specificity of below 70%.

Figure I-14 Summary forest plot of sensitivity and specificity (PC NTProBNP, lowest cut-point), bivariate mixed effect model

This figure shows the forest plots of sensitivity and specificity estimates of NT-proBNP assay with 95% confidence interval (95% CI) using bivariate mixed effect model approach when considering the lowest cut-points of diagnostic studies of heart failure in primary care settings. The pooled esimate for sensitivity of 12 included studies is 0.92 (95% CI: 0.86, 0.95) and for specificity is 0.50 (95% CI: 0.40, 0.60). 9 out of 12 studies showed a sensitivity of 90% and above while 3 studies showed a sensitivity of below 90%. Similarly, 2 out of 12 studies showed a specificity of 70% and above while 10 studies showed a specificity of below 70%.

Figure I-15 Summary forest plot of LR+ and LR- (PC NTProBNP, optimum cut-point), bivariate mixed effect model

This figure shows the forest plot of bivariate mixed effect model for estimating the positive likelihood ratio (LR+) and negative likelihood ratio (LR-) of NT-proBNP assay with 95% confidence interval (95% CI) when considering the optimal cut-points of diagnostic studies of heart failure in primary care settings. The poooled estimate for LR+ of 11 included studies is 2.28 (95% CI: 1.64, 3.16) and for LR- is 0.20 (95% CI: 0.13, 0.29). Off them, one study showed an LR+ of 5 or more than 5, while 10 studies have LR+ less than 5. Similarly, 9 studies have LR- of 0.1 or more than 0.1, while 2 studies have LR- less than 0.1.

Figure I-16 Summary forest plot of LR+ and LR- (PC NTProBNP, lowest cut-point), bivariate mixed effect model

This figure shows the forest plot of bivariate mixed effect model for estimating the positive likelihood ratio (LR+) and negative likelihood ratio (LR-) of NT-proBNP assay with 95% confidence interval (95% CI) when considering the lowest cut-points of diagnostic studies of heart failure in primary care settings. The poooled estimate for LR+ of 12 included studies is 1.85 (95% CI: 1.54, 2.23) and for LR- is 0.16 (95% CI: 0.11, 0.26). Off them, none of the studies showed an LR+ of 5 or more than 5, while 12 studies have LR+ less than 5. Similarly, 9 studies have LR- of 0.1 or more than 0.1, while 3 studies have LR- less than 0.1.

Figure I-17 Summary forest plot of LogDOR and DOR (PC NTProBNP, optimum cut-point), bivariate mixed effect model

This figure shows the forest plot of bivariate mixed effect model for estimating the log of diagnostic odds ratio log(DOR) and diagnostic odds ratio (DOR) of NT-proBNP assay with 95% confidence interval (95% CI) when considering the optimal cut-points of diagnostic studies of heart failure in primary care settings. The poooled estimate for log(DOR) of 11 included studies is 2.45 (95% CI: 1.93, 2.97) and for DOR is 11.60 (95% CI: 6.92, 19.45). Off them, none of the studies showed a log(DOR) of 5 or more than 5, while 11 studies have log(DOR) less than 5. Similarly, none of the studies showed a DOR of 100 or more than 100, while 11 studies have DOR less than 100.

Figure I-18 Summary forest plot of LogDOR and DOR (PC NTProBNP, lowest cut-point), bivariate mixed effect model

This figure shows the forest plot of bivariate mixed effect model for estimating the log of diagnostic odds ratio log(DOR) and diagnostic odds ratio (DOR) of NT-proBNP assay with 95% confidence interval (95% CI) when considering the lowest cut-points of diagnostic studies of heart failure in primary care settings. The poooled estimate for log(DOR) of 12 included studies is 2.42 (95% CI: 1.93, 2.91) and for DOR is 11.22 (95% CI: 6.86, 18.34). Off them, none of the studies showed a log(DOR) of 5 or more than 5, while 12 studies have log(DOR) less than 5. Similarly, none of the studies showed a DOR of 100 or more than 100, while 12 studies have DOR less than 100.

Figure I-19 Summary ROC-curve (PC NTProBNP, optimum cut-point), bivariate mixed effect model

This figure shows the Summary Receiver Operating Curve (SROC) using bivariate mixed effects model for estimating the area under the curve (AUC) of NT-proBNP assay with 95% confidence interval (95% CI) when considering the optimal cut-points of diagnostic studies of heart failure in primary care settings. Estimated AUC of 11 included studies is 0.86 (95% CI: 0.82, 0.88). Each circle denotes one study. The horizontal line represents specificity and vertical line represents sensitivity.

Figure I-20 Summary ROC-curve (PC NTProBNP, lowest cut-point), bivariate mixed effect model

This figure shows the Summary Receiver Operating Curve (SROC) using bivariate mixed effects model for estimating the area under the curve (AUC) of NT-proBNP assay with 95% confidence interval (95% CI) when considering the lowest cut-points of diagnostic studies of heart failure in primary care settings. Estimated AUC of 12 included studies is 0.82 (95% CI: 0.79, 0.85). Each circle denotes one study. The horizontal line represents specificity and vertical line represents sensitivity.

Table I-5 Risk of bias and applicability in all diagnosis studies using BNP in primary care

Table I-6 Risk of bias and applicability in all diagnostic studies using NT-ProBNP in primary care

Table I-7a Strength of evidence estimates of two primary outcomes, sensitivity and specificity, based on optimal cutpoint for diagnostic studies utilizing BNP in primary care settings

Table I-7b Strength of evidence estimates of two primary outcomes, sensitivity and specificity, based on lowest cutpoint for diagnostic studies utilizing BNP in primary care settings

Table I-7c Strength of evidence estimates of two primary outcomes, sensitivity and specificity, based on manufacturer cutpoint for diagnostic studies utilizing BNP in primary care settings

Table I-8a Strength of evidence estimates of two primary outcomes, sensitivity and specificity, based on optimal cutpoint for diagnostic studies utilizing NT-proBNP in primary care settings

Table I-8b Strength of evidence estimates of two primary outcomes, sensitivity and specificity, based on lowest cutpoint for diagnostic studies utilizing NT-proBNP in primary care settings

Table I-9 Summary test statistics of publication bias using log diagnostic odds ratios (logDOR), presented separately for different cut points

Figure I-21 Primary care publication bias: BNP and NT-proBNP

This figure shows the publication bias funnel plots using the Deeks' method for BNP and NT-proBNP assays when considering manufacturer cut-point, optimal cut-point and lowest cut-point of diagnostic studies of heart failure in primary care settings. The Deeks' method assesses the publication bias by performing linear regression of log odds ratios (horizontal axis) on inverse root of effective sample sizes (vertical axis) as a test for funnel plot asymmetry in diagnostic meta-analyses and a non-zero slope coefficient is suggestive of significant small study bias (p-value < 0.10). Based on the funnel plots, the publication bias was not significant for either BNP or NT-proBNP.

## Appendix I Reference List

1 Arques S, Roux E, Sbragia P, et al. Accuracy of tissue Doppler echocardiography in the emergency diagnosis of decompensated heart failure with preserved left ventricular systolic function: Comparison with B-type natriuretic peptide measurement. Echocardiograph. 2005;22(8):657-64.
2 Aspromonte N, Feola M, Scardovi AB, et al. Early diagnosis of congestive heart failure: Clinical utility of B-type natriuretic peptide testing associated with Doppler echocardiography. J Cardiovasc Med. 2006;7(6):406-13.
3 Barrios V, Llisterri JL, Escobar C, et al. Clinical applicability of B-type natriuretic peptide in patients with suspected heart failure in primary care in Spain: The PANAMA study. Expert Rev Cardiovasc Ther. 2011;9(5):579-85. [pmid: 21615321].
4 Christenson RH, Azzazy HM, Duh SH, et al. Impact of increased body mass index on accuracy of B-type natriuretic peptide (BNP) and N-terminal proBNP for diagnosis of decompensated heart failure and prediction of all-cause mortality. Clin Chem. 2010;56(4):633-41. [pmid: 20167699].
5 Fuat A, Murphy JJ, Hungin AP, et al. The diagnostic accuracy and utility of a B-type natriuretic peptide test in a community population of patients with suspected heart failure. Br J Gen Pract. 2006;56(526):327-33. [pmid: 16638247].
6 Jeyaseelan S, Goudie BM, Pringle SD, et al. A critical re-appraisal of different ways of selecting ambulatory patients with suspected heart failure for echocardiography. Eur J Heart Fail. 2007;9(1):55-61. [pmid: 16859991].
7 Kelder JC, Cramer MJ, Verweij WM, et al. Clinical utility of three B-type natriuretic peptide assays for the initial diagnostic assessment of new slow-onset heart failure. J Card Fail. 2011;17(9):729-34. [pmid: 21872142].
8 Macabasco-O'Connell A, Meymandi S, Bryg R. B-type Natriuretic Peptide (BNP) is useful in detecting asymptomatic left ventricular dysfunction in low-income, uninsured patients. Biol Res Nurs. 2010;11(3):280-7. [pmid: 19934109].
9 Mak G, Ryder M, Murphy NF, et al. Diagnosis of new onset heart failure in the community: The importance of a shared-care approach and judicious use of BNP. Ir J Med Sci. 2008;177(3):197-203. [pmid: 18633669].
10 Murtagh G, Dawkins IR, O'Connell R, et al. Screening to prevent heart failure (STOP-HF): Expanding the focus beyond asymptomatic left ventricular systolic dysfunction. Eur J Heart Fail. 2012;14(5):480-6. [pmid: 22416086].
11 Park HJ, Baek SH, Jang SW, et al. Direct comparison of B-type natriuretic peptide and N-terminal pro-BNP for assessment of cardiac function in a large population of symptomatic patients. Int J Cardiol. 2010;140(3):336-43. [pmid: 19147239].
12 Zaphiriou A, Robb S, Murray-Thomas T, et al. The diagnostic accuracy of plasma BNP and NTproBNP in patients referred from primary care with suspected heart failure: Results of the UK natriuretic peptide study. Eur J Heart Fail. 2005;7(4):537-41. [pmid: 15921792].
13 Goode KM, Clark AL, Bristow JA, et al. Screening for left ventricular systolic dysfunction in high-risk patients in primary-care: A cost-benefit analysis. Eur J Heart Fail. 2007;9(12):1186-95. [pmid: 18006378].
14 Goode KM, Clark AL, Cleland JG. Ruling out heart failure in primary-care: The cost-benefit of pre-screening using NT-proBNP and QRS width. Int J Cardiol. 2008;130(3):426-37. [pmid: 18178273].
15 Gustafsson F, Badskjaer J, Hansen FS, et al. Value of N-terminal proBNP in the diagnosis of left ventricular systolic dysfunction in primary care patients referred for echocardiography. Heart Drug. 2003;3(3):141-6.
16 Gustafsson F, Steensgaard-Hansen F, Badskjaer J, et al. Diagnostic and prognostic performance of N-terminal ProBNP in primary care patients with suspected heart failure. J Card Fail. 2005;11(5 Suppl):S15-20. [pmid: 15948095].
17 Hobbs FD, Davis RC, Roalfe AK, et al. Reliability of N-terminal proBNP assay in diagnosis of left ventricular systolic dysfunction within representative and high risk populations. Heart. 2004;90(8):866-70. [pmid: 15253955].
18 Koschack J, Scherer M, Luers C, et al. Natriuretic peptide vs. clinical information for diagnosis of left ventricular systolic dysfunction in primary care. BMC Fam Pract. 2008;9:14. [pmid: 18298821].
19 Lim TK, Dwivedi G, Hayat S, et al. Cost effectiveness of the B type natriuretic peptide, electrocardiography, and portable echocardiography for the assessment of patients from the community with suspected heart failure. Echocardiograph. 2007;24(3):228-36.
20 Mikkelsen KV, Bie P, Moller JE, et al. Neurohormonal activation and diagnostic value of cardiac peptides in patients with suspected mild heart failure. Int J Cardiol. 2006;110(3):324-33. [pmid: 16213609].
21 Nielsen LS, Svanegaard J, Klitgaard NA, et al. N-terminal pro-brain natriuretic peptide for discriminating between cardiac and non-cardiac dyspnoea. Eur J Heart Fail. 2004;6(1):63-70. [pmid: 15012920].
22 Olofsson M, Boman K. Usefulness of natriuretic peptides in primary health care: An exploratory study in elderly patients. Scand J Prim Health Care. 2010;28(1):29-35. [pmid: 20192890].
23 Shelton RJ, Clark AL, Goode K, et al. The diagnostic utility of N-terminal pro-B-type natriuretic peptide for the detection of major structural heart disease in patients with atrial fibrillation. Eur Heart J. 2006;27(19):2353-61. [pmid: 16952921].
24 Sivakumar R, Wellsted D, Parker K, et al. Utility of N terminal pro brain natriuretic peptide in elderly patients. Postgrad Med J. 2006;82(965):220-3. [pmid: 16517806].
25 Stahrenberg R, Edelmann F, Mende M, et al. The novel biomarker growth differentiation factor 15 in heart failure with normal ejection fraction. Eur J Heart Fail. 2010;12(12):1309-16. [pmid: 20837635].
26 Valle R, Aspromonte N, Barro S, et al. The NT-proBNP assay identifies very elderly nursing home residents suffering from pre-clinical heart failure. Eur J Heart Fail. 2005;7(4):542-51. [pmid: 15921793].
27 Kelder JC, Cramer MJ, van WJ, et al. The diagnostic value of physical examination and additional testing in primary care patients with suspected heart failure. Circulation. 2011;124(25):2865-73. [pmid: 22104551].
28 Deeks JJ. Systematic reviews in health care: Systematic reviews of evaluations of diagnostic and screening tests. BMJ. 2001;323(7305):157-62. [pmid: 11463691].