# Key Question 1 Evidence Set

Table H-1 Summary of diagnostic properties of studies evaluating BNP in patients with symptoms suggestive of HF at emergency department settings

Table H-2 Detailed diagnostic properties of papers evaluating BNP in patients with symptoms suggestive of HF in the emergency department

Figure H-1 Summary forest plot of sensitivity and specificity (ED BNP, manufacturer cut-point), bivariate mixed effect model

This figure shows the forest plots of sensitivity and specificity estimates of BNP assay with 95% confidence interval (95% CI) using bivariate mixed effect model approach when considering the manufacturer cut-points of diagnostic studies of heart failure in emergency department settings. The pooled esimate for sensitivity of 22 included studies is 0.95 (95% CI: 0.93, 0.96) and for specificity is 0.66 (95% CI: 0.56, 0.74). 20 out of 22 studies showed a sensitivity of 90% and above while two studies showed a sensitivity between 80% and 89%. 15 out of 22 studies showed a specificity of around 30% to 70% while 7 studies showed a specificity of above 70%.

Figure H-2 Summary forest plot of sensitivity and specificity (ED BNP, optimum cut-point), bivariate mixed effect model

This figure shows the forest plots of sensitivity and specificity estimates of BNP assay with 95% confidence interval (95% CI) using bivariate mixed effect model approach when considering the optimal cut-points of diagnostic studies of heart failure in emergency department settings. The pooled esimate for sensitivity of 29 included studies is 0.91 (95% CI: 0.88, 0.94) and for specificity is 0.80 (95% CI: 0.74, 0.85). 19 out of 29 studies showed a sensitivity of 90% and above while ten studies showed a sensitivity between 65% and 89%. 24 out of 29 studies showed a specificity of 70% and above while 5 studies showed a specificity of below 70%.

Figure H-3 Summary forest plot of sensitivity and specificity (ED BNP, lowest cut-point), bivariate mixed effect model

This figure shows the forest plots of sensitivity and specificity estimates of BNP assay with 95% confidence interval (95% CI) using bivariate mixed effect model approach when considering the lowest cut-points of diagnostic studies of heart failure in emergency department settings. The pooled esimate for sensitivity of 31 included studies is 0.95 (95% CI: 0.93, 0.97) and for specificity is 0.67 (95% CI: 0.58, 0.75). 27 out of 31 studies showed a sensitivity of 90% and above while ten studies showed a sensitivity below 90%. 19 out of 31 studies showed a specificity of below 70% while 12 studies showed a specificity of 70% and above. .

Figure H-4 Summary forest plot of LR+ and LR- (ED BNP, manufacturer cut-point), bivariate mixed effect model

This figure shows the forest plot of bivariate mixed effect model for estimating the positive likelihood ratio (LR+) and negative likelihood ratio (LR-) of BNP assay with 95% confidence interval (95% CI) when considering the manufacturer cut-points of diagnostic studies of heart failure in emergency department settings. The poooled estimate for LR+ of 22 studies is 2.76 (95% CI: 2.12, 3.59) and for LR- is 0.08 (95% CI: 0.06, 0.10). Off them, 4 studies have LR+ of 5 or more than 5, while 18 studies have LR+ less than 5. Similarly, 9 studies have LR- of 0.1 or more than 0.1, while 13 studies have LR- less than 0.1.

Figure H-5 Summary forest plot of LR+ and LR- (ED BNP, optimum cut-point), bivariate mixed effect model

This figure shows the forest plot of bivariate mixed effect model for estimating the positive likelihood ratio (LR+) and negative likelihood ratio (LR-) of BNP assay with 95% confidence interval (95% CI) when considering the optimal cut-points of diagnostic studies of heart failure in emergency department settings. The poooled estimate for LR+ of 29 studies is 4.61 (95% CI: 3.49, 6.09) and for LR- is 0.11 (95% CI: 0.08, 0.15). Off them, 13 studies have LR+ of 5 or more than 5, while 16 studies have LR+ less than 5. Similarly, 18 studies have LR- of 0.1 or more than 0.1, while 11 studies have LR- less than 0.1.

Figure H-6 Summary forest plot of LR+ and LR- (ED BNP, lowest cut-point), bivariate mixed effect model

This figure shows the forest plot of bivariate mixed effect model for estimating the positive likelihood ratio (LR+) and negative likelihood ratio (LR-) of BNP assay with 95% confidence interval (95% CI) when considering the lowest cut-points of diagnostic studies of heart failure in emergency department settings. The poooled estimate for LR+ of 31 studies is 2.85 (95% CI: 2.23, 3.65) and for LR- is 0.07 (95% CI: 0.05, 0.11). Off them, 7 studies have LR+ of 5 or more than 5, while 24 studies have LR+ less than 5. Similarly, 12 studies have LR- of 0.1 or more than 0.1, while 19 studies have LR- less than 0.1.

Figure H-7 Summary forest plot of LogDOR and DOR (ED BNP, manufacturer cut-point), bivariate mixed effect model

This figure shows the forest plot of bivariate mixed effect model for estimating the log of diagnostic odds ratio log(DOR) and diagnostic odds ratio (DOR) of BNP assay with 95% confidence interval (95% CI) when considering the manufacturer cut-points of diagnostic studies of heart failure in emergency department settings. The poooled estimate for log(DOR) of 22 studies is 3.55 (95% CI: 3.13, 3.97) and for DOR is 34.85 (95% CI: 22.81, 53.23). Off them, 4 studies have log(DOR) of 5 or more than 5, while 17 studies have log(DOR) less than 5. Similarly, 6 studies have DOR of 100 or more than 100, while 16 studies have DOR less than 100.

Figure H-8 Summary forest plot of LogDOR and DOR (ED BNP, optimum cut-point), bivariate mixed effect model

This figure shows the forest plot of bivariate mixed effect model for estimating the log of diagnostic odds ratio log(DOR) and diagnostic odds ratio (DOR) of BNP assay with 95% confidence interval (95% CI) when considering the optimal cut-points of diagnostic studies of heart failure in emergency department settings. The poooled estimate for log(DOR) of 29 studies is 3.74 (95% CI: 3.31, 4.18) and for DOR is 42.22 (95% CI: 22.39, 65.06). Off them, 6 studies have log(DOR) of 5 or more than 5, while 23 studies have log(DOR) less than 5. Similarly, 8 studies have DOR of 100 or more than 100, while 21 studies have DOR less than 100.

Figure H-9 Summary forest plot of LogDOR and DOR (ED BNP, lowest cut-point), bivariate mixed effect model

This figure shows the forest plot of bivariate mixed effect model for estimating the log of diagnostic odds ratio log(DOR) and diagnostic odds ratio (DOR) of BNP assay with 95% confidence interval (95% CI) when considering the lowest cut-points of diagnostic studies of heart failure in emergency department settings. The poooled estimate for log(DOR) of 31 studies is 3.68 (95% CI: 3.22, 4.13) and for DOR is 39.54 (95% CI: 25.03, 62.46). Off them, 6 studies have log(DOR) of 5 or more than 5, while 25 studies have log(DOR) less than 5. Similarly, 8 studies have DOR of 100 or more than 100, while 23 studies have DOR less than 100.

Figure H-10 Summary ROC-curve (ED BNP, manufacturer cut-point), bivariate mixed effect model

This figure shows the Summary Receiver Operating Curve (SROC) using bivariate mixed effects model for estimating the area under the curve (AUC) of BNP assay with 95% confidence interval (95% CI) when considering the manufacturer cut-points (100±5 pg/ml) of diagnostic studies of heart failure in emergency department settings. Estimated AUC of 22 studies is 0.94 (95% CI: 0.92, 0.96). Each circle denotes one study. The horizontal line represents specificity and vertical line represents sensitivity.

Figure H-11 Summary ROC-curve (ED BNP, optimum cut-point), bivariate mixed effect model

This figure shows the Summary Receiver Operating Curve (SROC) using bivariate mixed effects model for estimating the area under the curve (AUC) of BNP assay with 95% confidence interval (95% CI) when considering the optimal cut-points of diagnostic studies of heart failure in emergency department settings. Estimated AUC of 29 studies is 0.93 (95% CI: 0.91, 0.95). Each circle denotes one study. The horizontal line represents specificity and vertical line represents sensitivity.

Figure H-12 Summary ROC-curve (ED BNP, lowest cut-point), bivariate mixed effect model

This figure shows the Summary Receiver Operating Curve (SROC) using bivariate mixed effects model for estimating the area under the curve (AUC) of BNP assay with 95% confidence interval (95% CI) when considering the optimal cut-points of diagnostic studies of heart failure in emergency department settings. Estimated AUC of 31 studies is 0.92 (95% CI: 0.90, 0.94). Each circle denotes one study. The horizontal line represents specificity and vertical line represents sensitivity.

Table H-3 Summary of diagnostic properties of studies that evaluated NT-proBNP in patients with symptoms suggestive of HF in the emergency department

Table H-4 Detailed diagnostic properties of studies that evaluated NT-proBNP in patients with symptoms suggestive of HF in the ED

Figure H-13 Summary forest plot of sensitivity and specificity (ED NTProBNP, manufacturer cut-point), bivariate mixed effect model

This figure shows the forest plots of sensitivity and specificity estimates of NT-proBNP assay with 95% confidence interval (95% CI) using bivariate mixed effect model approach when considering the manufacturer cut-points of diagnostic studies of heart failure in emergency department settings. The pooled esimate for sensitivity of 4 included studies is 0.91 (95% CI: 0.88, 0.93) and for specificity is 0.67 (95% CI: 0.50, 0.80). 2 out of 4 studies showed a sensitivity of 90% and above while two studies showed a sensitivity between 80% and 89%. 3 out of 4 studies showed a specificity of around 46% to 70% while one study showed a specificity of above 70%.

Figure H-14 Summary forest plot of sensitivity and specificity (ED NTProBNP, optimum cut-point), bivariate mixed effect model

This figure shows the forest plots of sensitivity and specificity estimates of NT-proBNP assay with 95% confidence interval (95% CI) using bivariate mixed effect model approach when considering the optimal cut-points of diagnostic studies of heart failure in emergency department settings. The pooled esimate for sensitivity of 19 included studies is 0.90 (95% CI: 0.85, 0.93) and for specificity is 0.74 (95% CI: 0.67, 0.81). 8 out of 19 studies showed a sensitivity of 90% and above while 11 studies showed a sensitivity of below 90%. Similarly, 13 out of 19 studies showed a specificity of 70% and above while 6 studies showed a specificity of below 70%.

Figure H-15 Summary forest plot of sensitivity and specificity (ED NTProBNP, lowest cut-point), bivariate mixed effect model

This figure shows the forest plots of sensitivity and specificity estimates of NT-proBNP assay with 95% confidence interval (95% CI) using bivariate mixed effect model approach when considering the lowest cut-points of diagnostic studies of heart failure in emergency department settings. The pooled esimate for sensitivity of 19 included studies is 0.96 (95% CI: 0.91, 0.98) and for specificity is 0.55 (95% CI: 0.42, 0.67). 11 out of 19 studies showed a sensitivity of 90% and above while 8 studies showed a sensitivity of below 90%. Similarly, 6 out of 19 studies showed a specificity of 70% and above while 13 studies showed a specificity of below 70%.

Figure H-16 Summary forest plot of LR+ and LR- (ED NTProBNP, manufacturer cut-point), bivariate mixed effect model

This figure shows the forest plot of bivariate mixed effect model for estimating the positive likelihood ratio (LR+) and negative likelihood ratio (LR-) of NT-proBNP assay with 95% confidence interval (95% CI) when considering the manufacturer cut-points of diagnostic studies of heart failure in emergency department settings. the poooled estimate for LR+ of 4 studies is 2.74 (95% CI: 1.74, 4.32) and for LR- is 0.13 (95% CI: 0.10, 0.19). Off them, one study has LR+ of 5 or more than 5, while 3 studies have LR+ less than 5. Similarly, all studies have LR- of 0.1 or more than 0.1.

Figure H-17 Summary forest plot of LR+ and LR- (ED NTProBNP, optimum cut-point), bivariate mixed effect model

This figure shows the forest plot of bivariate mixed effect model for estimating the positive likelihood ratio (LR+) and negative likelihood ratio (LR-) of NT-proBNP assay with 95% confidence interval (95% CI) when considering the optimal cut-points of diagnostic studies of heart failure in emergency department settings. The poooled estimate for LR+ of 19 studies is 3.49 (95% CI: 2.72, 4.49) and for LR- is 0.14 (95% CI: 0.10, 0.20). Off them, 7 studies have LR+ of 5 or more than 5, while 12 studies have LR+ less than 5. Similarly, 12 studies have LR- of 0.1 or more than 0.1, while 7 studies have LR- less than 0.1.

Figure H-18 Summary forest plot of LR+ and LR- (ED NTProBNP, lowest cut-point), bivariate mixed effect model

This figure shows the forest plot of bivariate mixed effect model for estimating the positive likelihood ratio (LR+) and negative likelihood ratio (LR-) of NT-proBNP assay with 95% confidence interval (95% CI) when considering the lowest cut-points of diagnostic studies of heart failure in emergency department settings. The poooled estimate for LR+ of 19 studies is 2.14 (95% CI: 1.66, 2.76) and for LR- is 0.07 (95% CI: 0.03, 0.14). Off them, 2 studies have LR+ of 5 or more than 5, while 17 studies have LR+ less than 5. Similarly, 10 studies have LR- of 0.1 or more than 0.1, while 9 studies have LR- less than 0.1.

Figure H-19 Summary forest plot of LogDOR and DOR (ED NTProBNP, manufacturer cut-point), bivariate mixed effect model

This figure shows the forest plot of bivariate mixed effect model for estimating the log of diagnostic odds ratio log(DOR) and diagnostic odds ratio (DOR) of NT-proBNP assay with 95% confidence interval (95% CI) when considering the manufacturer cut-points of diagnostic studies of heart failure in emergency department settings. The poooled estimate for log(DOR) of 4 studies is 3.01 (95% CI: 2.34, 3.69) and for DOR is 20.38 (95% CI: 10.35, 40.11).

Figure H-20 Summary forest plot of LogDOR and DOR (ED NTProBNP, optimum cut-point), bivariate mixed effect model

This figure shows the forest plot of bivariate mixed effect model for estimating the log of diagnostic odds ratio log(DOR) and diagnostic odds ratio (DOR) of NT-proBNP assay with 95% confidence interval (95% CI) when considering the optimal cut-points of diagnostic studies of heart failure in emergency department settings. The poooled estimate for log(DOR) of 19 studies is 3.22 (95% CI: 2.80, 3.64) and for DOR is 24.99 (95% CI: 16.43, 38.01). Off them, 2 studies have log(DOR) of 5 or more than 5, while 17 studies have log(DOR) less than 5. Similarly, 3 studies have DOR of 100 or more than 100, while 16 studies have DOR less than 100.

Figure H-21 Summary forest plot of LogDOR and DOR (ED NTProBNP, lowest cut-point), bivariate mixed effect model

This figure shows the forest plot of bivariate mixed effect model for estimating the log of diagnostic odds ratio log(DOR) and diagnostic odds ratio (DOR) of NT-proBNP assay with 95% confidence interval (95% CI) when considering the lowest cut-points of diagnostic studies of heart failure in emergency department settings. The poooled estimate for log(DOR) of 19 studies is 3.44 (95% CI: 2.85, 4.03) and for DOR is 31.18 (95% CI: 17.21, 56.49). Off them, 1 study has log(DOR) of 5 or more than 5, while 18 studies have log(DOR) less than 5. Similarly, 2 studies have DOR of 100 or more than 100, while 17 studies have DOR less than 100.

Figure H-22 Summary ROC-curve (ED NTProBNP, manufacturer cut-point), bivariate mixed effect model

This figure shows the Summary Receiver Operating Curve (SROC) using bivariate mixed effects model for estimating the area under the curve (AUC) of NT-proBNP assay with 95% confidence interval (95% CI) when considering the manufacturer cut-points (100±5 pg/ml) of diagnostic studies of heart failure in emergency department settings. Estimated AUC of 4 studies is 0.92 (95% CI: 0.89, 0.94). Each circle denotes one study. The horizontal line represents specificity and vertical line represents sensitivity.

Figure H-23 Summary ROC-curve (ED NTProBNP, optimum cut-point), bivariate mixed effect model

This figure shows the Summary Receiver Operating Curve (SROC) using bivariate mixed effects model for estimating the area under the curve (AUC) of NT-proBNP assay with 95% confidence interval (95% CI) when considering the optimal cut-points of diagnostic studies of heart failure in emergency department settings. Estimated AUC of 19 studies is 0.90 (95% CI: 0.87, 0.92). Each circle denotes one study. The horizontal line represents specificity and vertical line represents sensitivity.

Figure H-24 Summary ROC-curve (ED NTProBNP, lowest cut-point), bivariate mixed effect model

This figure shows the Summary Receiver Operating Curve (SROC) using bivariate mixed effects model for estimating the area under the curve (AUC) of NT-proBNP assay with 95% confidence interval (95% CI) when considering the lowest cut-points of diagnostic studies of heart failure in emergency department settings. Estimated AUC of 19 studies is 0.86 (95% CI: 0.83, 0.89). Each circle denotes one study. The horizontal line represents specificity and vertical line represents sensitivity.

Table H-5 Risk of bias and applicability in all diagnostic studies using BNP in emergency department, results of QUADAS 2 quality assessment

Table H-6 Risk of bias and applicability in all diagnostic studies using NT-ProBNP in emergency department, results of QUADAS 2 quality assessment

Table H-7a Strength of evidence estimates of two primary outcomes, sensitivity and specificity, based on [underlined: optimal] cutpoints for diagnostic studies utilizing BNP in emergency department settings

Table H-7b Strength of evidence estimates of two primary outcomes, sensitivity and specificity, based on [underlined: lowest] cutpoints for diagnostic studies utilizing BNP in emergency department settings

Table H-7c Strength of evidence estimates of two primary outcomes, sensitivity and specificity, based on [underlined: manufacturer] cutpoints for diagnostic studies utilizing BNP in emergency department settings

Table H-8 Summary test statistics of publication bias using log diagnostic odds ratios (logDOR), presented separately for different cut points

Figure H-25 Emergency department publication bias: BNP and NT-proBNP

This figure shows the publication bias funnel plots using the Deeks' method for BNP and NT-proBNP assays when considering manufacturer cut-point, optimal cut-point and lowest cut-point of diagnostic studies of heart failure in emergency department. The Deeks' method assesses the publication bias by performing linear regression of log odds ratios (horizontal axis) on inverse root of effective sample sizes (vertical axis) as a test for funnel plot asymmetry in diagnostic meta-analyses and a non-zero slope coefficient is suggestive of significant small study bias (p-value < 0.10). Based on the funnel plots, the publication bias was significant for NT-proBNP (ED- Manufacturers cut-point, p=0.053) and NT-proBNP (ED- lowest cut-point, p=0.053).

Table H-9a Strength of evidence estimates of two primary outcomes, sensitivity and specificity, based on [underlined: optimal] cutpoints for diagnostic studies utilizing NT-proBNP in emergency department settings

Table H-9b Strength of evidence estimates of two primary outcomes, sensitivity and specificity, based on [underlined: lowest] cutpoints for diagnostic studies utilizing NT-proBNP in emergency department settings

## Appendix H Reference List

1 Alibay Y, Beauchet A, El Mahmoud R, et al. Plasma N-terminal pro-brain natriuretic peptide and brain natriuretic peptide in assessment of acute dyspnea. Biomed Pharmacother. 2005;59(1-2):20-4. [pmid: 15740931].
2 Arenja N, Reichlin T, Drexler B, et al. Sensitive cardiac troponin in the diagnosis and risk stratification of acute heart failure. J Intern Med. 2012;271(6):598-607. [pmid: 21988283].
3 Arques S, Roux E, Sbragia P, et al. Usefulness of bedside tissue Doppler echocardiography and B-type natriuretic peptide (BNP) in differentiating congestive heart failure from noncardiac cause of acute dyspnea in elderly patients with a normal left ventricular ejection fraction and permanent, nonvalvular atrial fibrillation: Insights from a prospective, monocenter study. Echocardiograph. 2007;24(5):499-507.
4 Barcarse E, Kazanegra R, Chen A, et al. Combination of B-type natriuretic peptide levels and non-invasive hemodynamic parameters in diagnosing congestive heart failure in the emergency department. Congest Heart Fail. 2004;10(4):171-6. [pmid: 15314474].
5 Boldanova T, Noveanu M, Breidthardt T, et al. Impact of history of heart failure on diagnostic and prognostic value of BNP: Results from the B-type Natriuretic Peptide for Acute Shortness of Breath Evaluation (BASEL) study. Int J Cardiol. 2010;142(3):265-72. [pmid: 19185372].
6 Chenevier-Gobeaux C, Claessens YE, Voyer S, et al. Influence of renal function on N-terminal pro-brain natriuretic peptide (NT-proBNP) in patients admitted for dyspnoea in the Emergency Department: Comparison with brain natriuretic peptide (BNP). Clin Chim Acta. 2005;361(1-2):167-75. [pmid: 15993397].
7 Chenevier-Gobeaux C, Delerme S, Allo JC, et al. B-type natriuretic peptides for the diagnosis of congestive heart failure in dyspneic oldest-old patients. Clin Biochem. 2008;41(13):1049-54. [pmid: 18573245].
8 Chenevier-Gobeaux C, Guerin S, Andre S, et al. Midregional pro-atrial natriuretic peptide for the diagnosis of cardiac-related dyspnea according to renal function in the emergency department: A comparison with B-type natriuretic peptide (BNP) and N-terminal proBNP. Clin Chem. 2010;56(11):1708-17. [pmid: 20813917].
9 Choi S, Park D, Lee S, et al. Cut-off values of B-type natriuretic peptide for the diagnosis of congestive heart failure in patients with dyspnoea visiting emergency departments: A study on Korean patients visiting emergency departments. Emerg Med J. 2007;24(5):343-7. [pmid: 17452702].
10 Chung T, Sindone A, Foo F, et al. Influence of history of heart failure on diagnostic performance and utility of B-type natriuretic peptide testing for acute dyspnea in the emergency department. Am Heart J. 2006;152(5):949-55. [pmid: 17070166].
11 Collins SP, Lindsell CJ, Peacock WF, et al. The combined utility of an S3 heart sound and B-type natriuretic peptide levels in emergency department patients with dyspnea. J Card Fail. 2006;12(4):286-92. [pmid: 16679262].
12 Coste J, Jourdain P, Pouchot J. A gray zone assigned to inconclusive results of quantitative diagnostic tests: Application to the use of brain natriuretic peptide for diagnosis of heart failure in acute dyspneic patients. Clin Chem. 2006;52(12):2229-35. [pmid: 17053156].
13 Daniels LB, Clopton P, Bhalla V, et al. How obesity affects the cut-points for B-type natriuretic peptide in the diagnosis of acute heart failure. Results from the Breathing Not Properly Multinational Study. Am Heart J. 2006;151(5):999-1005. [pmid: 16644321].
14 Dao Q, Krishnaswamy P, Kazanegra R, et al. Utility of B-type natriuretic peptide in the diagnosis of congestive heart failure in an urgent-care setting. J Am Coll Cardiol. 2001;37(2):379-85. [pmid: 11216950].
15 deFilippi CR, Seliger SL, Maynard S, et al. Impact of renal disease on natriuretic peptide testing for diagnosing decompensated heart failure and predicting mortality. Clin Chem. 2007;53(8):1511-9. [pmid: 17586595].
16 Dieplinger B, Gegenhuber A, Haltmayer M, et al. Evaluation of novel biomarkers for the diagnosis of acute destabilised heart failure in patients with shortness of breath. Heart. 2009;95(18):1508-13. [pmid: 19525245].
17 Gorissen C, Baumgarten R, De Groot M, et al. Analytical and clinical performance of three natriuretic peptide tests in the emergency room. Clin Chem Lab Med. 2007;45(5):678-84. [pmid: 17484634].
18 Gruson D, Rousseau MF, Ahn S, et al. Accuracy of N-terminal-pro-atrial natriuretic peptide in patients admitted to emergency department. Scand J Clin Lab Invest. 2008;68(5):410-4. [pmid: 19172697].
19 Gruson D, Thys F, Ketelslegers JM, et al. Multimarker panel in patients admitted to emergency department: a comparison with reference methods. Clin Biochem. 2009;42(3):185-8. [pmid: 18793629].
20 Gruson D, Ketelslegers JM, Verschuren F, et al. Head-to-head comparison of the prohormone proBNP1-108 with BNP and Nt-proBNP in patients admitted to emergency department. Clin Biochem. 2012;45(3):249-52. [pmid: 22209994].
21 Havelka EG, Rzechula KH, Bryant TO, et al. Correlation between impedance cardiography and B-type natriuretic peptide levels in dyspneic patients. J Emerg Med. 2011;40(2):146-50. [pmid: 18790589].
22 Knudsen CW, Riis JS, Finsen AV, et al. Diagnostic value of a rapid test for B-type natriuretic peptide in patients presenting with acute dyspnoe: Effect of age and gender. Eur J Heart Fail. 2004;6(1):55-62. [pmid: 15012919].
23 Knudsen CW, Omland T, Clopton P, et al. Diagnostic value of B-Type natriuretic peptide and chest radiographic findings in patients with acute dyspnea. Am J Med. 2004;116(6):363-8. [pmid: 15006584].
24 Knudsen CW, Omland T, Clopton P, et al. Impact of atrial fibrillation on the diagnostic performance of B-type natriuretic peptide concentration in dyspneic patients: An analysis from the breathing not properly multinational study. J Am Coll Cardiol. 2005;46(5):838-44. [pmid: 16139134].
25 Lainchbury JG, Campbell E, Frampton CM, et al. Brain natriuretic peptide and n-terminal brain natriuretic peptide in the diagnosis of heart failure in patients with acute shortness of breath. J Am Coll Cardiol. 2003;42(4):728-35. [pmid: 12932611].
26 Logeart D, Saudubray C, Beyne P, et al. Comparative value of Doppler echocardiography and B-type natriuretic peptide assay in the etiologic diagnosis of acute dyspnea. J Am Coll Cardiol. 2002;40(10):1794-800. [pmid: 12446063].
27 Lokuge A, Lam L, Cameron P, et al. B-type natriuretic peptide testing and the accuracy of heart failure diagnosis in the emergency department. Circulation. 2010;3(1):104-10. [pmid: 19933409].
28 Maisel AS, Krishnaswamy P, Nowak RM, et al. Rapid measurement of B-type natriuretic peptide in the emergency diagnosis of heart failure. N Engl J Med. 2002;347(3):161-7. [pmid: 12124404].
29 Maisel AS, McCord J, Nowak RM, et al. Bedside B-Type natriuretic peptide in the emergency diagnosis of heart failure with reduced or preserved ejection fraction. Results from the Breathing Not Properly Multinational Study. J Am Coll Cardiol. 2003;41(11):2010-7. [pmid: 12798574].
30 Maisel AS, Clopton P, Krishnaswamy P, et al. Impact of age, race, and sex on the ability of B-type natriuretic peptide to aid in the emergency diagnosis of heart failure: Results from the Breathing Not Properly (BNP) multinational study. Am Heart J. 2004;147(6):1078-84. [pmid: 15199359].
31 Maisel A, Mueller C, Nowak R, et al. Mid-region pro-hormone markers for diagnosis and prognosis in acute dyspnea: Results from the BACH (Biomarkers in Acute Heart Failure) trial. J Am Coll Cardiol. 2010;55(19):2062-76. [pmid: 20447528].
32 McCullough PA, Hollander JE, Nowak RM, et al. Uncovering heart failure in patients with a history of pulmonary disease: Rationale for the early use of B-type natriuretic peptide in the emergency department. Acad Emerg Med. 2003;10(3):198-204. [pmid: 12615582].
33 McCullough PA, Nowak RM, McCord J, et al. B-type natriuretic peptide and clinical judgment in emergency diagnosis of heart failure: Analysis from Breathing Not Properly (BNP) Multinational Study. Circ Cardiovasc Qual Outcomes. 2002;106(4):416-22.
34 Morrison LK, Harrison A, Krishnaswamy P, et al. Utility of a rapid B-natriuretic peptide assay in differentiating congestive heart failure from lung disease in patients presenting with dyspnea. J Am Coll Cardiol. 2002;39(2):202-9. [pmid: 11788208].
35 Mueller T, Gegenhuber A, Poelz W, et al. Diagnostic accuracy of B type natriuretic peptide and amino terminal proBNP in the emergency diagnosis of heart failure. Heart. 2005;91(5):606-12. [pmid: 15831643].
36 Gegenhuber A, Struck J, Poelz W, et al. Midregional pro-A-type natriuretic peptide measurements for diagnosis of acute destabilized heart failure in short-of-breath patients: Comparison with B-type natriuretic peptide (BNP) and amino-terminal proBNP. Clin Chem. 2006;52(5):827-31. [pmid: 16543387].
37 Noveanu M, Breidthardt T, Cayir S, et al. B-type natriuretic peptide-guided management and outcome in patients with obesity and dyspnea--Results from the BASEL study. Am Heart J. 2009;158(3):488-95. [pmid: 19699875].
38 Pahle AS, Sorli D, Omland T, et al. Impact of systemic hypertension on the diagnostic performance of B-type natriuretic peptide in patients with acute dyspnea. Am J Cardiol. 2009;104(7):966-71. [pmid: 19766765].
39 Parrinello G, Paterna S, Di Pasquale P, et al. The usefulness of bioelectrical impedance analysis in differentiating dyspnea due to decompensated heart failure. J Card Fail. 2008;14(8):676-86. [pmid: 18926440].
40 Potocki M, Breidthardt T, Reichlin T, et al. Comparison of midregional pro-atrial natriuretic peptide with N-terminal pro-B-type natriuretic peptide in the diagnosis of heart failure. J Intern Med. 2010;267(1):119-29. [pmid: 19570053].
41 Ray P, Arthaud M, Birolleau S, et al. Comparison of brain natriuretic peptide and probrain natriuretic peptide in the diagnosis of cardiogenic pulmonary edema in patients aged 65 and older. J Am Geriatr Soc. 2005;53(4):643-8. [pmid: 15817011].
42 Ray P, Arthaud M, Lefort Y, et al. Usefulness of B-type natriuretic peptide in elderly patients with acute dyspnea. Intensive Care Med. 2004;30(12):2230-6. [pmid: 15502931].
43 Ro R, Thode HC Jr., Taylor M, et al. Comparison of the diagnostic characteristics of two B-type natriuretic peptide point-of-care devices. J Emerg Med. 2011;41(6):661-7. [pmid: 21620610].
44 Kevin RR, Stehlik J, Stoddard GJ, et al. Adjusting for clinical covariates improves the ability of B-type natriuretic peptide to distinguish cardiac from non-cardiac dyspnoea: A sub-study of HEARD-IT. Eur J Heart Fail. 2009;11(11):1043-9. [pmid: 19812054].
45 Rogers RK, Stoddard GJ, Greene T, et al. Usefulness of adjusting for clinical covariates to improve the ability of B-type natriuretic peptide to distinguish cardiac from noncardiac dyspnea. Am J Cardiol. 2009;104(5):689-94. [pmid: 19699346].
46 Sanz MP, Borque L, Rus A, et al. Comparison of BNP and NT-proBNP assays in the approach to the emergency diagnosis of acute dyspnea. J Clin Lab Anal. 2006;20(6):227-32. [pmid: 17115420].
47 Shah KB, Kop WJ, Christenson RH, et al. Natriuretic peptides and echocardiography in acute dyspnoea: Implication of elevated levels with normal systolic function. Eur J Heart Fail. 2009;11(7):659-67. [pmid: 19515720].
48 Shah KB, Kop WJ, Christenson RH, et al. Lack of diagnostic and prognostic utility of circulating plasma myeloperoxidase concentrations in patients presenting with dyspnea. Clin Chem. 2009;55(1):59-67. [pmid: 18988754].
49 Steg PG, Joubin L, McCord J, et al. B-type natriuretic peptide and echocardiographic determination of ejection fraction in the diagnosis of congestive heart failure in patients with acute dyspnea. Chest. 2005;128(1):21-9. [pmid: 16002911].
50 Villacorta H, Duarte A, Duarte NM, et al. The role of B-type natriuretic peptide in the diagnosis of congestive heart failure in patients presenting to an emergency department with dyspnea. Arq Bras Cardiol. 2002;79(6):569-72. [pmid: 12532240].
51 Wang HK, Tsai MS, Chang JH, et al. Cardiac ultrasound helps for differentiating the causes of acute dyspnea with available B-type natriuretic peptide tests. Am J Emerg Med. 2010;28(9):987-93. [pmid: 20825928].
52 Wu AH, Omland T, Duc P, et al. The effect of diabetes on B-type natriuretic peptide concentrations in patients with acute dyspnea: An analysis from the Breathing Not Properly Multinational Study. Diabetes Care. 2004;27(10):2398-404. [pmid: 15451907].
53 Anwaruddin S, Lloyd-Jones DM, Baggish A, et al. Renal function, congestive heart failure, and amino-terminal pro-brain natriuretic peptide measurement: Results from the ProBNP Investigation of Dyspnea in the Emergency Department (PRIDE) Study. J Am Coll Cardiol. 2006;47(1):91-7. [pmid: 16386670].
54 Bayes-Genis A, Santalo-Bel M, Zapico-Muniz E, et al. N-terminal probrain natriuretic peptide (NT-proBNP) in the emergency diagnosis and in-hospital monitoring of patients with dyspnoea and ventricular dysfunction. Eur J Heart Fail. 2004;6(3):301-8. [pmid: 14987580].
55 Bayes-Genis A, Lloyd-Jones DM, van Kimmenade RR, et al. Effect of body mass index on diagnostic and prognostic usefulness of amino-terminal pro-brain natriuretic peptide in patients with acute dyspnea. Arch Intern Med. 2007;167(4):400-7. [pmid: 17325303].
56 Behnes M, Brueckmann M, Ahmad-Nejad P, et al. Diagnostic performance and cost effectiveness of measurements of plasma N-terminal pro brain natriuretic peptide in patients presenting with acute dyspnea or peripheral edema. Int J Cardiol. 2009;135(2):165-74. [pmid: 18603317].
57 Behnes M, Hoffmann U, Lang S, et al. Transforming growth factor beta 1 (TGF-beta 1) in atrial fibrillation and acute congestive heart failure. Clin Res Cardiol. 2011;100(4):335-42. [pmid: 21069358].
58 Berdague P, Caffin PY, Barazer I, et al. Use of N-terminal prohormone brain natriuretic peptide assay for etiologic diagnosis of acute dyspnea in elderly patients. Am Heart J. 2006;151(3):690-8. [pmid: 16504634].
59 Green SM, Martinez-Rumayor A, Gregory SA, et al. Clinical uncertainty, diagnostic accuracy, and outcomes in emergency department patients presenting with dyspnea. Arch Intern Med. 2008;168(7):741-8. [pmid: 18413557].
60 Januzzi JL Jr., Camargo CA, Anwaruddin S, et al. The N-terminal Pro-BNP investigation of dyspnea in the emergency department (PRIDE) study. Am J Cardiol. 2005;95(8):948-54. [pmid: 15820160].
61 Januzzi JL, van Kimmenade R, Lainchbury J, et al. NT-proBNP testing for diagnosis and short-term prognosis in acute destabilized heart failure: An international pooled analysis of 1256 patients: The International Collaborative of NT-proBNP Study. Eur Heart J. 2006;27(3):330-7. [pmid: 16293638].
62 Krauser DG, Chen AA, Tung R, et al. Neither race nor gender influences the usefulness of amino-terminal pro-brain natriuretic peptide testing in dyspneic subjects: A ProBNP Investigation of Dyspnea in the Emergency Department (PRIDE) substudy. J Card Fail. 2006;12(6):452-7. [pmid: 16911912].
63 Liteplo AS, Marill KA, Villen T, et al. Emergency thoracic ultrasound in the differentiation of the etiology of shortness of breath (ETUDES): Sonographic B-lines and N-terminal pro-brain-type natriuretic peptide in diagnosing congestive heart failure. Acad Emerg Med. 2009;16(3):201-10. [pmid: 19183402].
64 Martinez-Rumayor AA, Vazquez J, Rehman SU, et al. Relative value of amino-terminal pro-B-type natriuretic peptide testing and radiographic standards for the diagnostic evaluation of heart failure in acutely dyspneic subjects. Biomarkers. 2010;15(2):175-82. [pmid: 19911943].
65 Moe GW, Howlett J, Januzzi JL, et al. N-terminal pro-B-type natriuretic peptide testing improves the management of patients with suspected acute heart failure: Primary results of the Canadian prospective randomized multicenter IMPROVE-CHF study. Circ Cardiovasc Qual Outcomes. 2007;115(24):3103-10.
66 Nazerian P, Vanni S, Zanobetti M, et al. Diagnostic accuracy of emergency Doppler echocardiography for identification of acute left ventricular heart failure in patients with acute dyspnea: Comparison with Boston criteria and N-terminal prohormone brain natriuretic peptide. Acad Emerg Med. 2010;17(1):18-26. [pmid: 20078435].
67 O'Donoghue M, Kenney P, Oestreicher E, et al. Usefulness of aminoterminal pro-brain natriuretic peptide testing for the diagnostic and prognostic evaluation of dyspneic patients with diabetes mellitus seen in the emergency department (from the PRIDE Study). Am J Cardiol. 2007;100(9):1336-40. [pmid: 17950786].
68 Oh J, Kang SM, Hong N, et al. Relation between red cell distribution width with echocardiographic parameters in patients with acute heart failure. J Card Fail. 2009;15(6):517-22. [pmid: 19643363].
69 Prosen G, Klemen P, Štrnad M, et al. Combination of lung ultrasound (a comet-tail sign) and N-terminal pro-brain natriuretic peptide in differentiating acute heart failure from chronic obstructive pulmonary disease and asthma as cause of acute dyspnea in prehospital emergency setting. Crit Care. 2011;15(2):R114. [pmid: 21492424].
70 Robaei D, Koe L, Bais R, et al. Effect of NT-proBNP testing on diagnostic certainty in patients admitted to the emergency department with possible heart failure. Ann Clin Biochem. 2011;48(Pt 3):212-7. [pmid: 21398433].
71 Sakhuja R, Chen AA, Anwaruddin S, et al. Combined use of amino terminal-pro-brain natriuretic peptide levels and QRS duration to predict left ventricular systolic dysfunction in patients with dyspnea. Am J Cardiol. 2005;96(2):263-6. [pmid: 16018854].
72 Shaikh K, Ahmad M. Diagnostic significance of NT-proBNP estimation in patients with acute dyspnea. Jcpsp, Journal of the College of Physicians & Surgeons - Pakistan. 2011;21(10):584-8. [pmid: 22015116].
73 Steinhart B, Thorpe KE, Bayoumi AM, et al. Improving the diagnosis of acute heart failure using a validated prediction model. J Am Coll Cardiol. 2009;54(16):1515-21. [pmid: 19815122].
74 Tung RH, Camargo CA Jr., Krauser D, et al. Amino-terminal pro-brain natriuretic peptide for the diagnosis of acute heart failure in patients with previous obstructive airway disease. Ann Emerg Med. 2006;48(1):66-74. [pmid: 16781921].
75 van Kimmenade RR, Januzzi JL Jr., Ellinor PT, et al. Utility of amino-terminal pro-brain natriuretic peptide, galectin-3, and apelin for the evaluation of patients with acute heart failure. J Am Coll Cardiol. 2006;48(6):1217-24. [pmid: 16979009].
76 Zaninotto M, Mion M, Altinier S, et al. NT-proBNP in the differential diagnosis of acute dyspnea in the emergency department. Clin Biochem. 2005;38(11):1041-4. [pmid: 16143322].
77 Deeks JJ. Systematic reviews in health care: Systematic reviews of evaluations of diagnostic and screening tests. BMJ. 2001;323(7305):157-62. [pmid: 11463691].