# List of Excluded Articles

Aalbers J. Chronic heart failure treatment benefits from pro-BNP-directed therapy. Cardiovasc J Afr. 2011;22(1):52. Exclude: Not a primary study. [pmid: 21298211].
Abdelwhab S, Elshinnawy S. Pulmonary hypertension in chronic renal failure patients. Am J Nephrol. 2008;28(6):990-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18635926].
Abdulla J, Kober L, Torp-Pedersen C. Methods of assessing the functional status of patients with left ventricular systolic dysfunction in interventional studies: Can brain natriuretic peptide measurement be used as surrogate for the traditional methods?. Cardiovasc Drugs Ther. May. 2004;18(3):219-24. Exclude: Systematic review. [pmid: 15229390].
Abdullah SM, Khera A, Das SR, et al. Relation of coronary atherosclerosis determined by electron beam computed tomography and plasma levels of n-terminal pro-brain natriuretic peptide in a multiethnic population-based sample (the Dallas Heart Study). Am J Cardiol. Nov. 1. 2005;96(9):1284-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16253599].
Abe N, Matsunaga T, Kameda K, et al. Increased level of pericardial insulin-like growth factor-1 in patients with left ventricular dysfunction and advanced heart failure. J Am Coll Cardiol. Oct. 3. 2006;48(7):1387-95. Exclude: BNP measure not FDA approved. [pmid: 17010800].
Abe S, Taguchi I, Inoue T. Does direct inhibition bring direct benefit?. Circ J. 2012;76(6):1326. Exclude: Not a primary study. [pmid: 22739081].
Abezov DK, Kamilova UK, Shukurdzhanova SM, et al. Assessment of natriuretic peptide indices and oxidative stress in patients with chronic heart failure. Likars'ka sprava. Jan. 2010;Jan-Mar(1-2):53-6. Exclude: Not in English.
Abhayaratna WP, Marwick TH, Smith WT, et al. Characteristics of left ventricular diastolic dysfunction in the community: An echocardiographic survey. Heart. 2006;92(9):1259-64. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16488928].
Abhayaratna WP, Marwick TH, Becker NG, et al. Population-based detection of systolic and diastolic dysfunction with amino-terminal pro-B-type natriuretic peptide. Am Heart J. Nov. 2006;152(5):941-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17070165].
Abraham MR, Olson LJ, Joyner MJ, et al. Angiotensin-converting enzyme genotype modulates pulmonary function and exercise capacity in treated patients with congestive stable heart failure. Circ. Oct. 1. 2002;106(14):1794-9. Exclude: BNP measure not FDA approved.
Abraham WT, Lowes BD, Ferguson DA, et al. Systemic hemodynamic, neurohormonal, and renal effects of a steady-state infusion of human brain natriuretic peptide in patients with hemodynamically decompensated heart failure. J Card Fail. Mar. 1998;4(1):37-44. Exclude: BNP measure not FDA approved. [pmid: 9573502].
Abraham WT, Anand IS, Klapholz M, et al. Treatment of anemia with darbepoetin alfa in heart failure. Congest Heart Fail. 2010;16(3):87-95. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20557327].
Abroug F, Ouanes-Besbes L, Nciri N, et al. Association of left-heart dysfunction with severe exacerbation of chronic obstructive pulmonary disease: Diagnostic performance of cardiac biomarkers. Am J Respir Crit Care Med. Nov. 1. 2006;174(9):990-6. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16840745].
Abul Y, Karakurt S, Ozben B, et al. C-reactive protein in acute pulmonary embolism. J Investig Med. 2011;59(1):8-14. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Abulhul E, McDonald K, Martos R, et al. Long-term statin therapy in patients with systolic heart failure and normal cholesterol: Effects on elevated serum markers of collagen turnover, inflammation, and B-type natriuretic peptide. Clin Ther. Jan. 2012;34(1):91-100. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 22154198].
Adamopoulos S, Parissis JT, Iliodromitis EK, et al. Effects of levosimendan versus dobutamine on inflammatory and apoptotic pathways in acutely decompensated chronic heart failure. Am J Cardiol. Jul. 1. 2006;98(1):102-6. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16784930].
Adlam D, Silcocks P, Sparrow N. Using BNP to develop a risk score for heart failure in primary care. Eur Heart J. Jun. 2005;26(11):1086-93. Exclude: BNP measure not FDA approved. [pmid: 15769783].
Adlbrecht C, Huelsmann M, Berger R, et al. Cost analysis and cost-effectiveness of NT-proBNP-guided heart failure specialist care in addition to home-based nurse care. Eur J Clin Invest. 2011;41(3):315-22. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21070222].
Adlbrecht C, Neuhold S, Hulsmann M, et al. NT-proBNP as a means of triage for the risk of hospitalisation in primary care. European Journal of Preventive Cardiology. Feb. 2012;19(1):55-61. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21450621].
Aessopos A, Farmakis D, Polonifi A, et al. Plasma B-type natriuretic peptide concentration in beta-thalassaemia patients. Eur J Heart Fail. 2007;9(5):537-41. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17300987].
Aggarwal A, Wong J, Campbell DJ. Carvedilol reduces aldosterone release in systolic heart failure. Heart Lung Circ. Oct. 2006;15(5):306-9. Exclude: BNP measure not FDA approved. [pmid: 16935558].
Aguiar VB, Ochiai ME, Cardoso JN, et al. Relationship between depression, BNP levels and ventricular impairment in heart failure. Arq Bras Cardiol. 2010;95(6):732-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20835680].
Ahmed KA, Madhavan M, Prasad A. Brain natriuretic peptide in apical ballooning syndrome (Takotsubo/stress cardiomyopathy): Comparison with acute myocardial infarction. Coron Artery Dis. 2012;23(4):259-64. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 22395239].
Ahmed W, Zafar S, Alam AY, et al. Plasma levels of B-type natriuretic peptide in patients with unstable angina pectoris or acute myocardial infarction: Prognostic significance and therapeutic implications. Angiol. Jun. 2007;58(3):269-74. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Aidonidis G, Kanonidis I, Koutsimanis V, et al. Efficiency and safety of prolonged levosimendan infusion in patients with acute heart failure. Cardiol Res Pract. 2011;2011:342302. Exclude: BNP measure not FDA approved. [pmid: 21559263].
Ait-Oufella H, Tharaux PL, Baudel JL, et al. Variation in natriuretic peptides and mitral flow indexes during successful ventilatory weaning: A preliminary study. Intensive Care Med. 2007;33(7):1183-6. Exclude: BNP measure not FDA approved. [pmid: 17404702].
Ajuluchukwu JNA, Ekure EN, Mbakwem AC, et al. Reliability and accuracy of point-of-care amino-terminal probrain natriuretic peptide in congestive heart failure patients. Internet J Cardiol. 2010;9(1):1. Exclude: BNP measure not FDA approved.
Akanji AO, Suresh CG, Al Radwan R, et al. Body mass and atherogenic dyslipidemia as major determinants of blood levels of B-type natriuretic peptides in Arab subjects with acute coronary syndromes. Metab Synd Related Disord. Dec. 2009;7(6):563-9. Exclude: BNP measure not FDA approved.
Akashi YJ, Kida K, Suzuki K, et al. The significance of 123I-BMIPP delayed scintigraphic imaging in cardiac patients. Int J Cardiol. Apr. 25. 2007;117(2):145-51. Exclude: BNP measure not FDA approved. [pmid: 16843549].
Akazawa T, Iizuka H, Aizawa M, et al. The degree of newly emerging mitral regurgitation during off-pump coronary artery bypass is predicted by preoperative left ventricular function. J Anesth. 2008;22(1):13-20. Exclude: BNP measure not FDA approved. [pmid: 18306008].
Akerblom A, Wallentin L, Siegbahn A, et al. Cystatin C and estimated glomerular filtration rate as predictors for adverse outcome in patients with ST-elevation and non-ST-elevation acute coronary syndromes: Results from the Platelet Inhibition and Patient Outcomes study. Clin Chem. Jan. 2012;58(1):190-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 22126936].
Akioka K, Takeuchi K, Yanagi S, et al. Prognostic value of Doppler transmittal flow patterns and cardiac natriuretic peptides in patients with chronic congestive heart failure admitted for episodes of acute decompensation. Heart Ves. 2000;15(2):53-60. Exclude: BNP measure not FDA approved.
Akpinar O, Acarturk E, Kanadai M, et al. Tissue doppler imaging and NT-proBNP levels show the early impairment of ventricular function in patients with beta-thalassaemia major. Acta Cardiol. Jun. 2007;62(3):225-31. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17608095].
Aksoy H, Okutucu S, Kaya EB, et al. Clinical and echocardiographic correlates of improvement in left ventricular diastolic function after cardiac resynchronization therapy. Europace. Sep. 2010;12(9):1256-61. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20478931].
Aktas MK, Allen D, Jaber WA, et al. Relation of brain natriuretic peptide level to extent of left ventricular scarring in patients with chronic heart failure secondary to ischemic cardiomyopathy. Am J Cardiol. Jan. 15. 2009;103(2):243-5. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19121444].
Akutsu Y, Kaneko K, Kodama Y, et al. Iodine-123 mIBG imaging for predicting the development of atrial fibrillation. JACC Cardiovasc Imaging. 2011;4(1):78-86. Exclude: BNP measure not FDA approved. [pmid: 21232708].
Al Bannay RA, Husain AA. Role of tissue Doppler imaging in assessing left ventricular diastolic dysfunction severity. Does it hold the same ability?. Saudi Med J. Jan. 2012;33(1):34-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 22273645].
Al Hweish A, Sultan SS, Mogazi K, et al. Plasma myeloperoxidase, NT-proBNP, and troponin-I in patients on CAPD compared with those on regular hemodialysis. Hemodial Int. Jul. 2010;14(3):308-15. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20597992].
Al Meslmani BM, Fahoum SK, Shamia MG. N-terminal-probrain natriuretic peptide and echocardiography in patients with systolic heart failure. Saudi Med J. Nov. 2005;26(11):1695-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16311650].
Al Meslmani BM, Fahoum SK, Shamia MG. NT-proBNP in monitoring treatment of patients with congestive heart failure. Clin Lab. 2007;53(1-2):35-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17323823].
Ala-Kopsala M, Magga J, Peuhkurinen K, et al. Molecular heterogeneity has a major impact on the measurement of circulating N-terminal fragments of A- and B-type natriuretic peptides. Clin Chem. Sep. 2004;50(9):1576-88. Exclude: BNP measure not FDA approved. [pmid: 15265819].
Albertini JP, Cohen R, Valensi P, et al. B-type natriuretic peptide, a marker of asymptomatic left ventricular dysfunction in type 2 diabetic patients. Diabetes Metab. 2008;34(4):355-62. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18599336].
Albertsen AE, Nielsen JC, Poulsen SH, et al. DDD(R)-pacing, but not AAI(R)-pacing induces left ventricular desynchronization in patients with sick sinus syndrome: Tissue-Doppler and 3D echocardiographic evaluation in a randomized controlled comparison. Europace. Feb. 2008;10(2):127-33. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18192700].
Aldous SJ, Richards AM, Troughton R, et al. ST2 has diagnostic and prognostic utility for all-cause mortality and heart failure in patients presenting to the emergency department with chest pain. J Card Fail. 2012;18(4):304-10. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 22464771].
Alehagen U, Eriksson H, Nylander E, et al. Heart failure in the elderly: Characteristics of a Swedish primary health care population. Heartdrug. 2002;2(5):211-20. Exclude: BNP measure not FDA approved.
Alehagen U, Lindstedt G, Eriksson H, et al. Utility of the amino-terminal fragment of pro-brain natriuretic peptide in plasma for the evaluation of cardiac dysfunction in elderly patients in primary health care. Clin Chem. Aug. 2003;49(8):1337-46. Exclude: BNP measure not FDA approved. [pmid: 12881450].
Alehagen U, Dahlstrom U, Lindahl TL. Elevated D-dimer level is an independent risk factor for cardiovascular death in out-patients with symptoms compatible with heart failure. Thromb Haemost. Dec. 2004;92(6):1250-8. Exclude: BNP measure not FDA approved. [pmid: 15583730].
Alehagen U, Lindstedt G, Levin LA, et al. Risk of cardiovascular death in elderly patients with possible heart failure. B-type natriuretic peptide (BNP) and the aminoterminal fragment of ProBNP (N-terminal proBNP) as prognostic indicators in a 6-year follow-up of a primary care population. Int J Cardiol. Apr. 8. 2005;100(1):125-33. Exclude: BNP measure not FDA approved. [pmid: 15820295].
Alehagen U, Svensson E, Dahlstrom U. Natriuretic peptide biomarkers as information indicators in elderly patients with possible heart failure followed over six years: A head-to-head comparison of four cardiac natriuretic peptides. J Card Fail. Aug. 2007;13(6):452-61. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17675059].
Alehagen U, Goetze JP, Dahlstrom U. Reference intervals and decision limits for B-type natriuretic peptide (BNP) and its precursor (Nt-proBNP) in the elderly. Clin Chim Acta. 2007;382(1-2):8-14. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17433809].
Alehagen U, Janzon M. A clinician's experience of using the Cardiac Reader NT-proBNP point-of-care assay in a clinical setting. Eur J Heart Fail. Mar. 2008;10(3):260-6. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18304871].
Alehagen U, Dahlstrom U. Can NT-proBNP predict risk of cardiovascular mortality within 10 years? Results from an epidemiological study of elderly patients with symptoms of heart failure. Int J Cardiol. Apr. 3. 2009;133(2):233-40. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18407361].
Alehagen U, Dahlstrom U, Lindahl TL. Cystatin C and NT-proBNP, a powerful combination of biomarkers for predicting cardiovascular mortality in elderly patients with heart failure: Results from a 10-year study in primary care. Eur J Heart Fail. Apr. 2009;11(4):354-60. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19228797].
Alehagen U, Dahlstrom U, Lindahl TL. Low plasma concentrations of coagulation factors II, VII and XI indicate increased risk among elderly with symptoms of heart failure. Blood Coagul Fibrinolysis. Jan. 2010;21(1):62-9. Exclude: BNP measure not FDA approved. [pmid: 20040856].
Alehagen U, Dahlstrom U, Rehfeld JF, et al. Prognostic assessment of elderly patients with symptoms of heart failure by combining high-sensitivity troponin T and N-terminal pro-B-type natriuretic peptide measurements. Clin Chem. Nov. 2010;56(11):1718-24. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20844063].
Alehagen U, Dahlstrom U, Rehfeld JF, et al. Association of copeptin and N-terminal proBNP concentrations with risk of cardiovascular death in older patients with symptoms of heart failure. JAMA. May. 25. 2011;305(20):2088-95. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21610241].
Aleman C, Chan SB, Kordick MF. Correlation between chest x-ray and B-type natriuretic peptide in congestive heart failure. Am J Emerg Med. Jul. 2005;23(4):501-3. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16032620].
Alibay Y, Beauchet A, El Mahmoud R, et al. Analytical correlation between plasma N-terminal pro-brain natriuretic peptide and brain natriuretic peptide in patients presenting with dyspnea. Clin Biochem. Oct. 2004;37(10):933-6. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 15369727].
Allanore Y, Borderie D, Meune C, et al. N-terminal pro-brain natriuretic peptide as a diagnostic marker of early pulmonary artery hypertension in patients with systemic sclerosis and effects of calcium-channel blockers. Arthritis Rheum. Dec. 2003;48(12):3503-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 14674001].
Allanore Y, Borderie D, Avouac J, et al. High N-terminal pro-brain natriuretic peptide levels and low diffusing capacity for carbon monoxide as independent predictors of the occurrence of precapillary pulmonary arterial hypertension in patients with systemic sclerosis. Arthritis Rheum. Jan. 2008;58(1):284-91. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18163505].
Almenar L, Arnau MA, Martinez-Dolz L, et al. Is there a correlation between brain naturietic peptide levels and echocardiographic and hemodynamic parameters in heart transplant patients?. Transplant Proc. Oct. 2006;38(8):2534-6. Exclude: BNP measure not FDA approved. [pmid: 17097992].
Almog Y, Novack V, Megralishvili R, et al. Plasma level of N terminal pro-brain natriuretic peptide as a prognostic marker in critically ill patients. Anesth Analg. Jun. 2006;102(6):1809-15. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16717330].
Alonso-Martinez JL, Urbieta-Echezarreta M, Anniccherico-Sanchez FJ, et al. N-terminal pro-B-type natriuretic peptide predicts the burden of pulmonary embolism. Am J Med Sci. Feb. 2009;337(2):88-92. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19214022].
Alqaisi F, Williams LK, Peterson EL, et al. Comparing methods for identifying patients with heart failure using electronic data sources. BMC Health Serv Res. 2009;9:237. Exclude: BNP measure not FDA approved. [pmid: 20021648].
Alsuwaida A. Influence of erythropoietin dose and albumin level on the plasma brain natriuretic peptide in hemodialysis patients. Nasrat Amrad Wa Ziraat Alkulat. Jun. 2006;17(2):171-6. Exclude: BNP measure not FDA approved.
Altay H, Zorlu A, Binici S, et al. Relation of serum parathyroid hormone level to severity of heart failure. Am J Cardiol. Jan. 15. 2012;109(2):252-6. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21996143].
Altemose GT, Gritsus V, Jeevanandam V, et al. Altered myocardial phenotype after mechanical support in human beings with advanced cardiomyopathy. J Heart Lung Transplant. Jul. 1997;16(7):765-73. Exclude: BNP measure not FDA approved. [pmid: 9257259].
Alter P, Rupp H, Rominger MB, et al. Relation of B-type natriuretic peptide to left ventricular wall stress as assessed by cardiac magnetic resonance imaging in patients with dilated cardiomyopathy. Can J Physiol Pharmacol. Aug. 2007;85(8):790-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17901889].
Alter P, Rupp H, Rominger MB, et al. B-type natriuretic peptide and wall stress in dilated human heart. Mol Cell Biochem. Jul. 2008;314(1-2):179-91. Exclude: BNP measure not FDA approved. [pmid: 18461428].
Alter P, Rupp H, Rominger MB, et al. Association of hyperhomocysteinemia with left ventricular dilatation and mass in human heart. Clin Chem Lab Med. Apr. 2010;48(4):555-60. Exclude: BNP measure not FDA approved. [pmid: 20148720].
Altice NF, Madigan EA. Factors associated with delayed care-seeking in hospitalized patients with heart failure. Heart Lung. 2012;41(3):244-54. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 22054724].
Alvelos M, Ferreira A, Bettencourt P, et al. The effect of dietary sodium restriction on neurohumoral activity and renal dopaminergic response in patients with heart failure. Eur J Heart Fail. Aug. 2004;6(5):593-9. Exclude: BNP measure not FDA approved. [pmid: 15302007].
Alvelos M, Ferreira A, Bettencourt P, et al. Effect of saline load and metoclopramide on the renal dopaminergic system in patients with heart failure and healthy controls. J Cardiovasc Pharmacol. Mar. 2005;45(3):197-203. Exclude: BNP measure not FDA approved. [pmid: 15725943].
Alyan O, Kacmaz F, Ozdemir O, et al. Effects of cigarette smoking on heart rate variability and plasma N-terminal pro-B-type natriuretic peptide in healthy subjects: Is there the relationship between both markers?. Ann Noninvasive Electrocardiol. Apr. 2008;13(2):137-44. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18426439].
Ambardekar AV, Fonarow GC, Hernandez AF, et al. Characteristics and in-hospital outcomes for nonadherent patients with heart failure: Findings from Get With The Guidelines-Heart Failure (GWTG-HF). Am Heart J. 2009;158(4):644-52. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19781426].
Ambrosi P, Singeorzan S, Oddoze C, et al. Correlation of NT-proBNP with diastolic left ventricular function in elderly patients with ischemic stroke. Int J Cardiol. Apr. 1. 2010;140(1):126-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19101051].
Ambrosy AP, Fonarow GC, Albert NM, et al. B-type natriuretic peptide assessment in ambulatory heart failure patients: Insights from IMPROVE HF. J Cardiovasc Med. 2012;13(6):360-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Ameri P, Ronco D, Casu M, et al. High prevalence of vitamin D deficiency and its association with left ventricular dilation: An echocardiography study in elderly patients with chronic heart failure. Nutr Metab Cardiovasc Dis. Nov. 2010;20(9):633-40. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20399085].
Amir O, Reisfeld D, Sberro H, et al. Implications of cheyne-stokes breathing in advanced systolic heart failure. Clin Cardiol. 2010;33(3):E8-12. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20155854].
Ammar KA, Jacobsen SJ, Mahoney DW, et al. Prevalence and prognostic significance of heart failure stages: Application of the American College of Cardiology/American Heart Association heart failure staging criteria in the community. Circ. Mar. 27. 2007;115(12):1563-70. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Anand IS, Fisher LD, Chiang YT, et al. Changes in brain natriuretic peptide and norepinephrine over time and mortality and morbidity in the Valsartan Heart Failure Trial (Val-HeFT). Circ. Mar. 11. 2003;107(9):1278-83. Exclude: BNP measure not FDA approved.
Anand IS, Latini R, Florea VG, et al. C-reactive protein in heart failure: Prognostic value and the effect of valsartan. Circ. Sep. 6. 2005;112(10):1428-34. Exclude: BNP measure not FDA approved.
Anand IS, Deswal A, Kereiakes DJ, et al. Comparison of once-daily versus twice-daily dosing of valsartan in patients with chronic stable heart failure. Vasc Health Risk Manag. 2010;6:449-55. Exclude: BNP measure not FDA approved. [pmid: 20730060].
Anand IS, Kempf T, Rector TS, et al. Serial measurement of growth-differentiation factor-15 in heart failure: Relation to disease severity and prognosis in the valsartan heart failure trial. Circ. 2010;122(14):1387-95. Exclude: BNP measure not FDA approved.
Ancheta IB, Battie C, Cobb S, et al. The impact of B-type natriuretic peptide, New York Heart Association classification and depression on quality of life in nonhospitalized heart failure patients. Prog Cardiovasc Nurs. Dec. 2009;24(4):124-30. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20002336].
Andersen K, Jonsdottir S, Sigurethsson AF, et al. The effect of physical training in chronic heart failure. Laeknabladid. Nov. 2006;92(11):759-64. Exclude: BNP measure not FDA approved. [pmid: 17093327].
Andersson SE, Edvinsson ML, Edvinsson L. Cutaneous vascular reactivity is reduced in aging and in heart failure: Association with inflammation. Clin Sci. Dec. 2003;105(6):699-707. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 12848618].
Andersson SE, Edvinsson ML, Alving K, et al. Vasodilator effect of endothelin in cutaneous microcirculation of heart failure patients. Basic Clin Pharmacol Toxicol. Aug. 2005;97(2):80-5. Exclude: BNP measure not FDA approved. [pmid: 15998353].
Ando M, Yamamoto T, Hino A, et al. Norepinephrine spillover during exercise as a novel parameter to evaluate the severity of heart failure. J Nucl Cardiol. Oct. 2010;17(5):868-73. Exclude: BNP measure not FDA approved. [pmid: 20503121].
Andreas M, Zeisler H, Handisurya A, et al. N-terminal-pro-brain natriuretic peptide is decreased in insulin dependent gestational diabetes mellitus: A prospective cohort trial. Cardiovasc Diabetol. 2011;10:28. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21489265].
Andreassen AK, Wergeland R, Simonsen S, et al. N-terminal pro-B-type natriuretic peptide as an indicator of disease severity in a heterogeneous group of patients with chronic precapillary pulmonary hypertension. Am J Cardiol. Aug. 15. 2006;98(4):525-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16893710].
Andreassen M, Faber J, Vestergaard H, et al. N-terminal pro-B-type natriuretic peptide in patients with growth hormone disturbances. Clin Endocrinol. 2007;66(5):619-25. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Andreassen M, Kistorp C, Raymond I, et al. Plasma insulin-like growth factor I as predictor of progression and all cause mortality in chronic heart failure. Growth Hormone IGF Res. Dec. 2009;19(6):486-90. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Andreassen M, Andreassen M. The growth hormone system and cardiac function in patients with growth hormone disturbances and in the normal population. Dan Med Bull. Oct. 2010;57(10):B4162. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21040685].
Andreassi MG, Del Ry S, Palmieri C, et al. Up-regulation of ‘clearance’ receptors in patients with chronic heart failure: A possible explanation for the resistance to biological effects of cardiac natriuretic hormones. Eur J Heart Fail. 2001;3(4):407-14. Exclude: BNP measure not FDA approved. [pmid: 11511425].
Andresen M, Gonzalez A, Mercado M, et al. Natriuretic peptide type-B can be a marker of reperfusion in patients with pulmonary thromboembolism subjected to invasive treatment. Int J Cardiovasc Imag. 2012;28(3):659-66. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Androne AS, Hryniewicz K, Hudaihed A, et al. Relation of unrecognized hypervolemia in chronic heart failure to clinical status, hemodynamics, and patient outcomes. Am J Cardiol. May. 15. 2004;93(10):1254-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 15135699].
Ang DS, Wei L, Kao MP, et al. A comparison between B-type natriuretic peptide, global registry of acute coronary events (GRACE) score and their combination in ACS risk stratification. Heart. Nov. 2009;95(22):1836-42. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19321492].
Ang DS, Kong CF, Kao MP, et al. Serial bedside B-type natriuretic peptide strongly predicts prognosis in acute coronary syndrome independent of echocardiographic abnormalities. Am Heart J. Jul. 2009;158(1):133-40. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19540403].
Ang DS, Welsh P, Watt P, et al. Serial changes in adiponectin and BNP in ACS patients: Paradoxical associations with each other and with prognosis. Clin Sci. Jul. 2009;117(1):41-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19175359].
Anker SD, Von HS. Vitamin D in chronic kidney disease: More questions than answers. JAMA. 2012;307(7):722-3. Exclude: Not a primary study. [pmid: 22337683].
Antonelli A, Ferri C, Ferrari SM, et al. High circulating N-terminal pro-brain natriuretic peptide and tumor necrosis factor-alpha in mixed cryoglobulinemia. World J Gastroenterol. Oct. 28. 2009;15(40):5074-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19860001].
Antonelli A, Ferri C, Ferrari SM, et al. High circulating levels of N-terminal pro-brain natriuretic peptide and interleukin 6 in patients with mixed cryoglobulinemia. J Med Virol. Feb. 2010;82(2):297-303. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20029800].
Antonelli A, Ferri C, Ferrari SM, et al. High levels of circulating N-terminal pro-brain natriuretic peptide in patients with hepatitis C. J Viral Hepat. 2010;17(12):851-3. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20002300].
Antonelli A, Ferri C, Ferrari SM, et al. N-terminal pro-brain natriuretic peptide and tumor necrosis factor-alpha both are increased in patients with Hepatitis C. J Interferon Cytokine Res. May. 2010;30(5):359-63. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20187770].
Antonini-Canterin F, Popescu BA, Popescu AC, et al. Heart failure in patients with aortic stenosis: Clinical and prognostic significance of carbohydrate antigen 125 and brain natriuretic peptide measurement. Int J Cardiol. Aug. 29. 2008;128(3):406-12. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17662495].
Antonini L, P V. Ambulatory blood pressure monitoring, 2D-echo and clinical variables relating to cardiac events in ischaemic cardiomyopathy following cardioverter-defibrillator implantation. J Cardiovasc Med. 2011;12(5):334-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Anzai A, Anzai T, Naito K, et al. Prognostic significance of acute kidney injury after reperfused ST-elevation myocardial infarction: Synergistic acceleration of renal dysfunction and left ventricular remodeling. J Card Fail. 2010;16(5):381-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20447573].
Aoyagi T, Nakamura F, Tomaru T, et al. Beneficial effects of pitavastatin, a 3-hydroxy-3-methylglutaryl coenzyme a reductase inhibitor, on cardiac function in ischemic and nonischemic heart failure. Int Heart J. Jan. 2008;49(1):49-58. Exclude: BNP measure not FDA approved. [pmid: 18360064].
Apostolo A, Vignati C, Brusoni D, et al. Erectile dysfunction in heart failure: Correlation with severity, exercise performance, comorbidities, and heart failure treatment. J Sex Med. 2009;6(10):2795-805. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19674255].
Arad M, Elazar E, Shotan A, et al. Brain and atrial natriuretic peptides in patients with ischemic heart disease with and without heart failure. Cardiol. Jan. 1996;87(1):12-7. Exclude: BNP measure not FDA approved.
Arad M, Adler Y, Koren-Morag N, et al. Exercise training in advanced heart failure patients: Discordance between improved exercise tolerance and unchanged NT-proBNP levels. Int J Cardiol. May. 7. 2008;126(1):114-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17651845].
Araki T, Okeie K, Tsuchiya T, et al. Neurohumoral effects of an angiotensin II receptor blocker added to an angiotensin converting enzyme inhibitor in patients with chronic heart failure: Comparison between lasartan and valsartan. Respir Circ. 2002;50(4):425-9. Exclude: Not in English.
Araujo AQ, Arteaga E, Ianni BM, et al. Effect of Losartan on left ventricular diastolic function in patients with nonobstructive hypertrophic cardiomyopathy. Am J Cardiol. Dec. 1. 2005;96(11):1563-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16310441].
Araujo JP, Azevedo A, Lourenco P, et al. Intraindividual variation of amino-terminal pro-B-type natriuretic peptide levels in patients with stable heart failure. Am J Cardiol. Nov. 1. 2006;98(9):1248-50. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17056340].
Araujo JP, Lourenco P, Rocha-Goncalves F, et al. Adiponectin is increased in cardiac cachexia irrespective of body mass index. Eur J Heart Fail. Jun. 2009;11(6):567-72. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19359328].
Arena R, MacCarter D, Olson TP, et al. Ventilatory expired gas at constant-rate low-intensity exercise predicts adverse events and is related to neurohormonal markers in patients with heart failure. J Card Fail. Aug. 2009;15(6):482-8. Exclude: BNP measure not FDA approved. [pmid: 19643358].
Arikan S, Tuzcu A, Gokalp D, et al. Hyperthyroidism may affect serum N-terminal pro-B-type natriuretic peptide levels independently of cardiac dysfunction. Clin Endocrinol. 2007;67(2):202-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Arikan S, Bahceci M, Tuzcu A, et al. N-terminal pro-brain natriuretic peptide in newly diagnosed acromegaly. J Endocrinol Invest. Sep. 2010;33(8):571-5. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20930495].
Arikawa T, Matsuda R, Araki H, et al. Influence of obstructive sleep apnea on diastolic heart failure. Dokkyo J Med Sci. 2009;36(1):1-8. Exclude: BNP measure not FDA approved.
Arimoto T, Takeishi Y, Niizeki T, et al. Ongoing myocardial damage relates to cardiac sympathetic nervous disintegrity in patients with heart failure. Ann Nucl Med. Oct. 2005;19(7):535-40. Exclude: BNP measure not FDA approved. [pmid: 16363617].
Arimoto T, Takeishi Y, Niizeki T, et al. Cardiac sympathetic denervation and ongoing myocardial damage for prognosis in early stages of heart failure. J Card Fail. Feb. 2007;13(1):34-41. Exclude: BNP measure not FDA approved. [pmid: 17339001].
Arimoto T, Sukekawa H, Harada M, et al. Short cardiac iodine-123-metaiodobenzylguanidine imaging protocol in heart failure. Circ J. Jul. 2008;72(7):1106-11. Exclude: BNP measure not FDA approved. [pmid: 18577819].
Armstrong DJ, Gardiner PV, O'Kane MJ. Rheumatoid arthritis patients with active disease and no history of cardiac pathology have higher brain natriuretic peptide (BNP) levels than patients with inactive disease or healthy control subjects. Ulster Med J. 2010;79(2):82-4. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21116425].
Arnaldo FJ, Anatoliotakis N, Palacio C, et al. Increased N-terminal-pro-B-type natriuretic peptide levels in patients with appropriate implantable defibrillator therapies. Heart Lung. Jan. 2009;38(1):10-6. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19150526].
Arndt-Maric R, Nagele H, Schewe G, et al. Are autoantibodies against the beta1-adrenergic receptor markers for dilated cardiomyopathy?. Clin Lab. 2010;56(11-12):519-26. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21141435].
Aronson D, Burger AJ. Intravenous nesiritide (human B-type natriuretic peptide) reduces plasma endothelin-1 levels in patients with decompensated congestive heart failure. Am J Cardiol. Aug. 15. 2002;90(4):435-8. Exclude: BNP measure not FDA approved. [pmid: 12161240].
Aronson D, Burger AJ. Neurohumoral activation and ventricular arrhythmias in patients with decompensated congestive heart failure: Role of endothelin. Pacing Clin Electrophysiol. Mar. 2003;26(3):703-10. Exclude: BNP measure not FDA approved. [pmid: 12698670].
Aronson D, Burger AJ. Prognosis assessment in patients with decompensated heart failure. Simple clinical parameters or neurohormonal factors. Ital Heart J. Jul. 2004;5(7):494-7. Exclude: Not a primary study. [pmid: 15487265].
Arora S, Gullestad L, Wergeland R, et al. Probrain natriuretic peptide and C-reactive protein as markers of acute rejection, allograft vasculopathy, and mortality in heart transplantation. Transplantation. May. 27. 2007;83(10):1308-15. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17519779].
Arques S, Roux E, Sbragia P, et al. B-type natriuretic peptide and tissue Doppler study findings in elderly patients hospitalized for acute diastolic heart failure. Am J Cardiol. Jul. 1. 2005;96(1):104-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 15979445].
Arques S, Roux E, Sbragia P, et al. Accuracy of tissue Doppler echocardiography in the diagnosis of new-onset congestive heart failure in patients with levels of B-type natriuretic peptide in the midrange and normal left ventricular ejection fraction. Echocardiograph. Sep. 2006;23(8):627-34. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Arques S, Roux E, Ambrosi P, et al. Accuracy of bedside tissue Doppler echocardiography for the prediction of in-hospital mortality in elderly patients with acute heart failure with preserved left ventricular systolic function. comparison with B-type natriuretic peptide measurement. Int J Cardiol. Dec. 15. 2007;123(1):69-72. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17289178].
Arques S, Roux E, Sbragia P, et al. Accuracy of the isovolumic relaxation time in the emergency diagnosis of new-onset congestive heart failure with preserved left ventricular systolic function in the setting of B-type natriuretic peptide levels in the mid-range. Int J Cardiol. Mar. 14. 2008;124(3):400-3. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17395301].
Arques S, Roux E, Sbragia P, et al. Comparison of B-type natriuretic peptide with left atrial enlargement by echocardiography for the diagnosis of new-onset congestive heart failure with a preserved left ventricular systolic function in the setting of longstanding hypertension. Int J Cardiol. Aug. 1. 2008;128(1):123-5. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17659793].
Arques S, Ambrosi P, Roux E, et al. Tissue Doppler echocardiography for the diagnosis of new-onset heart failure with normal ejection fraction: Influence of serum protein concentration on clinical interpretation in elderly patients. Arch Cardiovasc Dis. May. 2008;101(5):343-50. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18656093].
Arques S, Jaubert MP, Bonello L, et al. Usefulness of basal B-type natriuretic peptide levels for the diagnosis of diastolic heart failure in young patients: An echocardiographic-catheterization study. Int J Cardiol. 2010;145(1):51-2. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19394710].
Arslan S, Erol MK, Bozkurt E, et al. Effect of beta-blocker therapy on left atrial function in patients with heart failure: Comparison of metoprolol succinate with carvedilol. Int J Cardiovasc Imaging. Oct. 2007;23(5):549-55. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17171429].
Arteaga E, Araujo AQ, Buck P, et al. Plasma amino-terminal pro-B-type natriuretic peptide quantification in hypertrophic cardiomyopathy. Am Heart J. Dec. 2005;150(6):1228-32. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16338263].
Arutiunov GP, Arutiunov AG, Volkova AL. Study evaluating the impact of a combination of inotropic support and heart rate control on prognosis and stabilization rate in patients with decompensated chronic heart failure (LEGION). Ter Arkh. 2010;82(3):47-52. Exclude: Not in English. [pmid: 20564923].
Ashley EA, Kardos A, Jack ES, et al. Angiotensin-converting enzyme genotype predicts cardiac and autonomic responses to prolonged exercise. J Am Coll Cardiol. 2006;48(3):523-31. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16875979].
Aspromonte N, Ceci V, Chiera A, et al. Rapid brain natriuretic peptide test and Doppler echocardiography for early diagnosis of mild heart failure. Clin Chem. Sep. 2006;52(9):1802-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16873293].
Aspromonte N, Valle R, Di Fusco SA, et al. Prognostic value of B-type natriuretic peptide in patients with left bundle-branch block admitted for acute heart failure. Eur J Intern Med. Dec. 2011;22(6):e152-e154. Exclude: Not a primary study. [pmid: 22075309].
Asselbergs FW, van den Berg MP, Bakker SJ, et al. N-terminal pro B-type natriuretic peptide levels predict newly detected atrial fibrillation in a population-based cohort. Neth Heart J. 2008;16(3):73-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18345329].
Astor BC, Yi S, Hiremath L, et al. N-terminal prohormone brain natriuretic peptide as a predictor of cardiovascular disease and mortality in blacks with hypertensive kidney disease: The African American Study of Kidney Disease and Hypertension (AASK). Circ. Apr. 1. 2008;117(13):1685-92. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Astrup AS, Kim WY, Tarnow L, et al. Relation of left ventricular function, mass, and volume to NT-proBNP in type 1 diabetic patients. Diab Care. May. 2008;31(5):968-70. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Ataga KI, Brittain JE, Moore D, et al. Urinary albumin excretion is associated with pulmonary hypertension in sickle cell disease: Potential role of soluble fms-like tyrosine kinase-1. Eur J Haematol. Sep. 2010;85(3):257-63. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20491879].
Ataga KI, Brittain JE, Desai P, et al. Association of coagulation activation with clinical complications in sickle cell disease. PLoS ONE. 2012;7(1):e29786. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 22253781].
Atehortua DSG. Effect of a cardiac rehabilitation program based on exercise on physical capacity, cardiac function and quality of life in patients with heart failure. Rev Colomb Cardiol. 2011;18(1):25-36. Exclude: Not in English.
Athanasopoulos LV, Dritsas A, Doll HA, et al. Comparative value of NYHA functional class and quality-of-life questionnaire scores in assessing heart failure. J Cardiopulm Rehabil Prev. 2010;30(2):101-5. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19952769].
Athanasopoulos LV, Dritsas A, Doll HA, et al. Explanation of the variance in quality of life and activity capacity of patients with heart failure by laboratory data. Eur J Cardiovasc Prev Rehabil. Aug. 2010;17(4):375-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19940776].
Athanasopoulos LVD. The role of NT-ProBNP in explaining the variance in anaerobic threshold and VE/VCO2 slope. J Cardiopulm Rehabil Prev. 2011;31(5):316-21. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21908983].
Atisha D, Bhalla MA, Morrison LK, et al. A prospective study in search of an optimal B-natriuretic peptide level to screen patients for cardiac dysfunction. Am Heart J. Sep. 2004;148(3):518-23. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 15389242].
Attaran S, Sherwood R, Desai J, et al. Brain natriuretic peptide a predictive marker in cardiac surgery. Interact Cardiovasc Thorac Surg. Oct. 2009;9(4):662-6. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19584071].
Attenhofer Jost CH, Oechslin E, Seifert B, et al. Remodelling after surgical repair of atrial septal defects within the oval fossa. Cardiol Young. Dec. 2002;12(6):506-12. Exclude: BNP measure not FDA approved. [pmid: 12635997].
Atwater BD, Milford-Beland S, Newby LK, et al. Patterns and implications of B-type natriuretic peptide measurement in patients with non-ST-segment elevation acute coronary syndromes. Am J Cardiol. Dec. 15. 2007;100(12):1727-33. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18082516].
Austin WJ, Bhalla V, Hernandez-Arce I, et al. Correlation and prognostic utility of B-type natriuretic peptide and its amino-terminal fragment in patients with chronic kidney disease. Am J Clin Pathol. Oct. 2006;126(4):506-12. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16938661].
Avello N, Molina BD, Llorente E, et al. N-terminal pro-brain natriuretic peptide as a potential non-invasive marker of cardiac transplantation rejection. Ann Clin Biochem. Mar. 2007;44(2):182-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17362585].
Avgeropoulou C, Andreadou I, Markantonis-Kyroudis S, et al. The Ca2+-sensitizer levosimendan improves oxidative damage, BNP and pro-inflammatory cytokine levels in patients with advanced decompensated heart failure in comparison to dobutamine. Eur J Heart Fail. Aug. 2005;7(5):882-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 15921958].
Avkarogullari M, Bozkurt A, Akpinar O, et al. The relation between serum erythropoietin level and severity of disease and mortality in patients with chronic heart failure. Acta Cardiol. Jun. 2008;63(3):297-302. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18664018].
Azevedo A, Bettencourt P, Barros H. Demographic, clinical and echocardiography determinants of B-type natriuretic peptide plasma concentration. A population-based study. Rev Port Cardiol. 2007;26(2):105-13. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17479706].
Aziz EF, Alviar CL, Herzog E, et al. Continuous infusion of furosemide combined with low-dose dopamine compared to intermittent boluses in acutely decompensated heart failure is less nephrotoxic and carries a lower readmission at thirty days. HJC Hell J Cardiol. May. 2011;52(3):227-35. Exclude: BNP measure not FDA approved.
Baba A, Akaishi M, Shimada M, et al. Complete elimination of cardiodepressant IgG3 autoantibodies by immunoadsorption in patients with severe heart failure. Circ J. 2010;74(7):1372-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20501959].
Baba O, Izuhara M, Kadota S, et al. Determinant factors of plasma B-type natriuretic peptide levels in patients with persistent nonvalvular atrial fibrillation and preserved left ventricular systolic function. J Cardiol. Dec. 2009;54(3):402-8. Exclude: BNP measure not FDA approved. [pmid: 19944315].
Babu-Narayan SV, Kilner PJ, Li W, et al. Ventricular fibrosis suggested by cardiovascular magnetic resonance in adults with repaired tetralogy of Fallot and its relationship to adverse markers of clinical outcome. Circ. 2006;113(3):405-13. Exclude: BNP measure not FDA approved.
Badesch DB, Feldman J, Keogh A, et al. ARIES-3: Ambrisentan therapy in a diverse population of patients with pulmonary hypertension. Cardiovascular therapeutics. 2012;30(2):93-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21884013].
Badran HM, Eid MA, Michael A. Doppler-derived indexes and B-type natriuretic peptide in prediction of paroxysmal atrial fibrillation in essential hypertension: A prospective study. Echocardiograph. Oct. 2007;24(9):911-22. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Baggish AL, Siebert U, Lainchbury JG, et al. A validated clinical and biochemical score for the diagnosis of acute heart failure: The ProBNP Investigation of Dyspnea in the Emergency Department (PRIDE) Acute Heart Failure Score. Am Heart J. Jan. 2006;151(1):48-54. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16368291].
Baggish AL, Lloyd-Jones DM, Blatt J, et al. A clinical and biochemical score for mortality prediction in patients with acute dyspnoea: Derivation, validation and incorporation into a bedside programme. Heart. Aug. 2008;94(8):1032-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17947362].
Baghdady Y, Kamel Y, Elwan A. N-terminal pro-brain natriuretic peptide in decompansated ventricular septal defect. Arch Med Sci. 2009;5(3):376-82. Exclude: Population aged under 18.
Bahrmann P, Hengst UM, Richartz BM, et al. Pentoxifylline in ischemic, hypertensive and idiopathic-dilated cardiomyopathy: Effects on left-ventricular function, inflammatory cytokines and symptoms. Eur J Heart Fail. Mar. 1. 2004;6(2):195-201. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 14984727].
Bai M, Yang J, Li Y. Serum N-terminal-pro-brain natriuretic peptide level and its clinical implications in patients with atrial fibrillation. Clin Cardiol. Dec. 2009;32(12):E1-5. Exclude: BNP measure not FDA approved. [pmid: 20014208].
Bail DH, Kofler M, Ziemer G. Brain natriuretic peptide (BNP) in patients undergoing coronary artery bypass grafting. Thorac Cardiovasc Surg. Jun. 2004;52(3):135-40. Exclude: BNP measure not FDA approved. [pmid: 15192772].
Baizabal JF, Martinez LC, Tejeda AO, et al. Diagnostic utility of clinical criteria for the detection of left ventricular systolic and diastolic dysfunction compared with echocardiography and NT-proBNP levels. Med Int Mex. 2005;21(2):91-105. Exclude: Not in English.
Bajric M, Barakovic F, Kusljugic Z, et al. Amino-terminal pro-brain natriuretic peptid in prediction of left ventricular ejection fraction. Bosnian J Basic Med Sci. Aug. 2008;8(3):282-6. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Bajwa EK, Januzzi JL, Gong MN, et al. Prognostic value of plasma N-terminal probrain natriuretic peptide levels in the acute respiratory distress syndrome. Crit Care Med. Aug. 2008;36(8):2322-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18596623].
Bakowski D, Wozakowska-Kaplon B, Opolski G. The effects of left ventricular diastolic function on natriuretic peptide levels after cardioversion of atrial fibrillation. Kardiol Pol. Apr. 2009;67(4):361-7. Exclude: BNP measure not FDA approved. [pmid: 19492248].
Bakowski D, Wozakowska-Kaplon B, Opolski G. The influence of left ventricle diastolic function on natriuretic peptides levels in patients with atrial fibrillation. Pacing Clin Electrophysiol. Jun. 2009;32(6):745-52. Exclude: BNP measure not FDA approved. [pmid: 19545336].
Bal L, Thierry S, Brocas E, et al. B-type natriuretic peptide (BNP) and N-terminal-proBNP for heart failure diagnosis in shock or acute respiratory distress. Acta Anaesthesiol Scand. Mar. 2006;50(3):340-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16480468].
Balak W, Sinkiewicz W, Gilewski W, et al. Relationship between thoracic fluid content and natriuretic peptide type B in patients with systolic heart failure. Kardiol Pol. Nov. 2009;67(11):1220-5. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20024849].
Balkan C, Tuluce SY, Basol G, et al. Relation between NT-proBNP levels, iron overload, and early stage of myocardial dysfunction in beta-thalassemia major patients. Echocardiograph. 2012;29(3):318-25. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Bando M, Ishii Y, Sugiyama Y, et al. Elevated plasma brain natriuretic peptide levels in chronic respiratory failure with cor pulmonale. Respir Med. Jul. 1999;93(7):507-14. Exclude: BNP measure not FDA approved. [pmid: 10464838].
Banfi G, Migliorini S, Dolci A, et al. B-type natriuretic peptide in athletes performing an Olympic triathlon. J Sports Med Phys Fitness. Dec. 2005;45(4):529-31. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16446686].
Banfi G, d'Eril GM, Barassi A, et al. N-terminal proB-type natriuretic peptide (NT-proBNP) concentrations in elite rugby players at rest and after active and passive recovery following strenuous training sessions. Clin Chem Lab Med. 2008;46(2):247-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18076361].
Banfi G, Lippi G, Susta D, et al. NT-proBNP concentrations in mountain marathoners. J Strength Condit Res. May. 2010;24(5):1369-72. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Bank AJ, Shammas RA, Mullen K, et al. Effects of short-term forearm exercise training on resistance vessel endothelial function in normal subjects and patients with heart failure. J Card Fail. Sep. 1998;4(3):193-201. Exclude: BNP measure not FDA approved. [pmid: 9754590].
Baptista RJ. B-type natriuretic peptide predicts long-term prognosis in a cohort of critically ill patients. Heart Int. 2011;6(2):65-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Barak M, Schliamser JE, Yaniv N, et al. Ability of brain natriuretic peptide tests and homocysteine to exclude congestive heart failure. Open Clin Chem J. 2010;3:1-4. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Barasch E, Gottdiener JS, Aurigemma G, et al. Association between elevated fibrosis markers and heart failure in the elderly: The cardiovascular health study. Circ. Jul. 2009;2(4):303-10. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Barasch E, Gottdiener JS, Aurigemma G, et al. The relationship between serum markers of collagen turnover and cardiovascular outcome in the elderly: The Cardiovascular Health Study. Circ Heart Fail. Nov. 1. 2011;4(6):733-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21900186].
Barbato E, Rubattu S, Bartunek J, et al. Human coronary atherosclerosis modulates cardiac natriuretic peptide release. Atherosclerosis. Sep. 2009;206(1):258-64. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19237156].
Barbosa MM, Nunes M, Ribeiro ALP, et al. N-terminal proBNP levels in patients with Chagas disease: A marker of systolic and diastolic dysfunction of the left ventricle. Eur J Echocardiogr. 2007;8(3):204-12. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16651029].
Barbosa MM, Nunes MC, Castro LR, et al. Correlation between NT-pro BNP levels and early mitral annulus velocity (E') in patients with non-ST-segment elevation acute coronary syndrome. Echocardiograph. Apr. 2008;25(4):353-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Barclay JL, Kruszewski K, Croal BL, et al. Relation of left atrial volume to B-type natriuretic peptide levels in patients with stable chronic heart failure. Am J Cardiol. Jul. 1. 2006;98(1):98-101. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16784929].
Barents M, Hillege HH, van dH I, et al. BNP and NT-proBNP, predictors of 1-year mortality in nursing home residents. J Am Med Dir Assoc. Oct. 2008;9(8):580-5. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19083292].
Barents M, van dH I, Voors AA, et al. Prevalence and misdiagnosis of chronic heart failure in nursing home residents: The role of B-type natriuretic peptides. Neth Heart J. 2008;16(4):123-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18427636].
Bargnoux AS, Klouche K, Fareh J, et al. Prohormone brain natriuretic peptide (proBNP), BNP and N-terminal-proBNP circulating levels in chronic hemodialysis patients. Correlation with ventricular function, fluid removal and effect of hemodiafiltration. Clin Chem Lab Med. 2008;46(7):1019-24. Exclude: BNP measure not FDA approved. [pmid: 18624622].
Barisione C, Garibaldi S, Ghigliotti G, et al. CD14CD16 monocyte subset levels in heart failure patients. Dis Markers. 2010;28(2):115-24. Exclude: BNP measure not FDA approved. [pmid: 20364047].
Barral MM, Nunes MC, Barbosa MM, et al. Echocardiographic parameters associated with pulmonary congestion in Chagas cardiomyopathy. Rev Soc Bras Med Trop. Jun. 2010;43(3):244-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20563489].
Bart BA, Goldsmith SR, Lee KL, et al. Cardiorenal rescue study in acute decompensated heart failure: Rationale and design of CARRESS-HF, for the heart failure clinical research network. J Card Fail. 2012;18(3):176-82. Exclude: Not a primary study. [pmid: 22385937].
Bartek J, Stejskal D, Lacnak B, et al. Application of determined NT-proBNP in physical standardized exercise. Biomed Pap Med Fac Univ Palacky Olomouc Czech Repub. Nov. 2003;147(1):71-5. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 15034608].
Bartesaghi G, Morandi F, Longoni S, et al. Outpatients repeated infusion of levosimendan in end-stage chronic heart failure: An efficacy and safety trial. Trends Med. 2010;10(4):235-9. Exclude: BNP measure not FDA approved.
Barthelemy O, Beygui F, Vicaut E, et al. Relation of high concentrations of plasma carboxy-terminal telopeptide of collagen type I with outcome in acute myocardial infarction. Am J Cardiol. Oct. 1. 2009;104(7):904-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19766754].
Bartunek J, Delrue L, Van Durme F, et al. Nonmyocardial production of ST2 protein in human hypertrophy and failure is related to diastolic load. J Am Coll Cardiol. Dec. 16. 2008;52(25):2166-74. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19095135].
Baruch L, Glazer RD, Aknay N, et al. Morbidity, mortality, physiologic and functional parameters in elderly and non-elderly patients in the Valsartan Heart Failure Trial (Val-HeFT). Am Heart J. Dec. 2004;148(6):951-7. Exclude: BNP measure not FDA approved. [pmid: 15632877].
Barutcuoglu B, Parildar Z, Basol G, et al. The detection of left ventricular diastolic dysfunction in hypertensive patients: Performance of N-terminal probrain natriuretic peptide. Blood Press. Aug. 2010;19(4):212-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20070249].
Bassan R, Tura BR, Maisel AS. B-type natriuretic peptide: A strong predictor of early and late mortality in patients with acute chest pain without ST-segment elevation in the emergency department. Coron Artery Dis. Mar. 2009;20(2):143-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19293713].
Batlle M, Roig E, Perez-Villa F, et al. Increased expression of the renin-angiotensin system and mast cell density but not of angiotensin-converting enzyme II in late stages of human heart failure. J Heart Lung Transplant. Sep. 2006;25(9):1117-25. Exclude: BNP measure not FDA approved. [pmid: 16962475].
Bavbek N, Akay H, Altay M, et al. Serum BNP concentration and left ventricular mass in CAPD and automated peritoneal dialysis patients. Perit Dial Int. Nov. 2007;27(6):663-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17984428].
Baxter J, McDonagh T. Can geriatricians improve inpatient heart failure care? Time for a heart to heart. Age Ageing. 2012;41(2):140-1. Exclude: Not a primary study. [pmid: 22217459].
Bay M, Kirk V, Parner J, et al. NT-proBNP: A new diagnostic screening tool to differentiate between patients with normal and reduced left ventricular systolic function. Heart. Feb. 2003;89(2):150-4. Exclude: BNP measure not FDA approved. [pmid: 12527664].
Bayes-Genis A, Bellido-Casado J, Zapico E, et al. N-terminal pro-brain natriuretic peptide reflects pulmonary capillary leakage in patients with acute dyspnea. Am J Cardiol. Sep. 1. 2004;94(5):669-70. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 15342307].
Bayes-Genis A, Pascual-Figal D, Januzzi JL, et al. Soluble ST2 monitoring provides additional risk stratification for outpatients with decompensated heart failure. Rev Esp Cardiol. Oct. 2010;63(10):1171-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20875357].
Bayram M, Ozkan G, Oztekin E, et al. Role of serum and pleural fluid NT-proBNP levels in identifying pleural effusion due to heart failure. Multidisciplin Resp Med. 2009;4(3):175-81. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Bazzino O, Fuselli JJ, Botto F, et al. Relative value of N-terminal probrain natriuretic peptide, TIMI risk score, ACC/AHA prognostic classification and other risk markers in patients with non-ST-elevation acute coronary syndromes. Eur Heart J. May. 2004;25(10):859-66. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 15140534].
Beatty AL, Zhang MH, Ku IA, et al. Adiponectin is associated with increased mortality and heart failure in patients with stable ischemic heart disease: Data from the Heart and Soul Study. Atherosclerosis. Feb. 2012;220(2):587-92. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 22196150].
Beaune G, Mercier-Villet A, Steidel J, et al. BNP assay on ADVIA Centaur (Bayer HealthCare): Correlations with Triage technique (Biosite) and etiologic application to the diagnosis of a dyspnea. Immuno. 2004;19(5 Spec Iss):286-93. Exclude: Not in English.
Beck-da-Silva L, de Bold A, Davies R, et al. Effect of bisoprolol on right ventricular function and brain natriuretic peptide in patients with heart failure. Congest Heart Fail. May. 2004;10(3):127-32. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 15184726].
Becker JR, Robinson TY, Sachidanandan C, et al. In vivo natriuretic peptide reporter assay identifies chemical modifiers of hypertrophic cardiomyopathy signalling. Cardiovasc Res. 2012;93(3):463-70. Exclude: Non-human population. [pmid: 22198505].
Bednarek-Skublewska A, Zaluska W, Ksiazek A. The relationship between serum level of N-terminal pro-B-type natriuretic peptide and nutritional status, and inflammation in chronic hemodialysis patients. Clin Nephrol. Jan. 2010;73(1):14-20. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20040347].
Beer S, Golay S, Bardy D, et al. Increased plasma levels of N-terminal brain natriuretic peptide (NT-proBNP) in type 2 diabetic patients with vascular complications. Diabetes Metab. Dec. 2005;31(6):567-73. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16357805].
Behnes M, Lang S, Breithardt OA, et al. Association of NT-proBNP with severity of heart valve disease in a medical patient population presenting with acute dyspnea or peripheral edema. J Heart Valve Dis. Sep. 2008;17(5):557-65. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18980090].
Beleigoli A, Diniz M, Nunes M, et al. Reduced brain natriuretic peptide levels in class III obesity: The role of metabolic and cardiovascular factors. Obesity Facts. 2011;4(6):427-32. Exclude: Systematic review. [pmid: 22248992].
Beleigoli AML. B-type natriuretic peptide and anthropometric measures in a Brazilian elderly population with a high prevalence of Trypanosoma cruzi infection. Peptides. 2011;32(9):1787-92. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21884743].
Bellavia D, Pellikka PA, Al Zahrani GB, et al. Independent predictors of survival in primary systemic (AL) amyloidosis, including cardiac biomarkers and left ventricular strain imaging: An observational cohort study. J Am Soc Echocardiogr. 2010;23(6):643-52. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20434879].
Bellone A, Etteri M, Vettorello M, et al. The effects of continuous positive airway pressure on plasma brain natriuretic peptide concentrations in patients presenting with acute cardiogenic pulmonary edema with preserved left ventricular systolic function. Am J Emerg Med. Feb. 2010;28(2):230-4. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20159397].
Belovicova M, Kinova S, Hrusovsky S. Brain natriuretic peptide (BNP) in differential diagnosis of dyspnea. Bratisl Lek Listy. 2005;106(6-7):203-6. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16201736].
Ben Dor I, Haim M, Rechavia E, et al. Serum NT-proBNP concentrations in the early phase do not predict the severity of systolic or diastolic left ventricular dysfunction among patients with ST-elevation acute myocardial infarction. Angiol. Dec. 20. 2006;57(6):686-93. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Ben Driss A, Tabet JY, Meurin P, et al. Role of B-type natriuretic peptide and echocardiographic indices in predicting the development of acute heart failure following beta-blocker uptitration in chronic heart failure patients with left ventricular systolic dysfunction. Int J Cardiol. Feb. 7. 2007;115(2):257-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16769135].
Ben Tov A, Paret G, Sela BA, et al. N-terminal pro B-type natriuretic peptide (N-BNP) levels in cystic fibrosis patients. Pediatr Pulmonol. Aug. 2007;42(8):699-703. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17588252].
Benjamin EJ, Dupuis J, Larson MG, et al. Genome-wide association with select biomarker traits in the Framingham Heart Study. BMC Med Genet. 2007;8(Suppl 1):S11. Exclude: BNP measure not FDA approved. [pmid: 17903293].
Bentzen H, Pedersen RS, Pedersen HB, et al. Abnormal rhythmic oscillations of atrial natriuretic peptide and brain natriuretic peptide in heart failure. Clin Sci. Mar. 2003;104(3):303-12. Exclude: BNP measure not FDA approved. [pmid: 12605591].
Bentzen H, Pedersen RS, Nyvad O. Effect of exercise on natriuretic peptides in plasma and urine in chronic heart failure. Int J Cardiol. Feb. 2004;93(2-3):121-30. Exclude: BNP measure not FDA approved. [pmid: 14975537].
Berdal JE, Stavem K, Omland T, et al. Prognostic merit of N-terminal-proBNP and N-terminal-proANP in mechanically ventilated critically ill patients. Acta Anaesthesiol Scand. Oct. 2008;52(9):1265-72. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18823467].
Berendes E, Van Aken H, Raufhake C, et al. Differential secretion of atrial and brain natriuretic peptide in critically ill patients. Anesth Analg. Sep. 2001;93(3):676-82. Exclude: BNP measure not FDA approved. [pmid: 11524340].
Berent R, von Duvillard SP, Crouse SF, et al. Short-term residential cardiac rehabilitation reduces B-type natriuretic peptide. Eur J Cardiovasc Prev Rehabil. Oct. 2009;16(5):603-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19494782].
Berger R, Huelsman M, Strecker K, et al. B-type natriuretic peptide predicts sudden death in patients with chronic heart failure. Circ. May. 21. 2002;105(20):2392-7. Exclude: BNP measure not FDA approved.
Berger R, Strecker K, Huelsmann M, et al. Prognostic power of neurohumoral parameters in chronic heart failure depends on clinical stage and observation period. J Heart Lung Transplant. Sep. 2003;22(9):1037-45. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 12957614].
Berger R, Huelsmann M, Strecker K, et al. Neurohormonal risk stratification for sudden death and death owing to progressive heart failure in chronic heart failure. Eur J Clin Invest. Jan. 2005;35(1):24-31. Exclude: BNP measure not FDA approved. [pmid: 15638816].
Berger R, Moertl D, Huelsmann M, et al. Levosimendan and prostaglandin E1 for uptitration of beta-blockade in patients with refractory, advanced chronic heart failure. Eur J Heart Fail. Feb. 2007;9(2):202-8. Exclude: BNP measure not FDA approved. [pmid: 16859992].
Bergh CH, Andersson B, Dahlstrom U, et al. Intravenous levosimendan vs. dobutamine in acute decompensated heart failure patients on beta-blockers. Eur J Heart Fail. 2010;12(4):404-10. Exclude: BNP measure not FDA approved. [pmid: 20335355].
Berghaus TM, Haeckel T, Behr W, et al. Central thromboembolism is a possible predictor of right heart dysfunction in normotensive patients with acute pulmonary embolism. Thromb Res. 2010;126(3):e201-5. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20638710].
Bergler-Klein J, Pacher R, Berger R, et al. Neurohumoral and hemodynamic effects of the selective endothelin antagonist darusentan in advanced chronic heart failure. J Heart Lung Transplant. Jan. 2004;23(1):20-7. Exclude: BNP measure not FDA approved. [pmid: 14734123].
Bergler-Klein J, Mundigler G, Pibarot P, et al. B-type natriuretic peptide in low-flow, low-gradient aortic stenosis: Relationship to hemodynamics and clinical outcome: Results from the multicenter Truly or Pseudo-Severe Aortic Stenosis (TOPAS) study. Circ. 2007;115(22):2848-55. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Bernal V, Pascual I, Esquivias P, et al. Cardiac hemodynamic profiles and pro-B-type natriuretic peptide in cirrhotic patients undergoing liver transplantation. Transplant Proc. Apr. 2009;41(3):985-6. Exclude: BNP measure not FDA approved. [pmid: 19376404].
Bernal V, Pascual I, Lanas A, et al. Cardiac function and aminoterminal pro-brain natriuretic peptide levels in liver-transplanted cirrhotic patients. Clin Transplant. Jan. 2012;26(1):111-6. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21447142].
Berni A, Cappelli F, Bitossi L, et al. Non-invasive tissue Doppler imaging pulmonary capillary wedge pressure measurement improves NT-proBNP prognostic value in heart failure. Acta Cardiol. Apr. 2009;64(2):213-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19476114].
Bernstein LH, Zions MY, Haq SA, et al. Effect of renal function loss on NT-proBNP level variations. Clin Biochem. Jul. 2009;42(10-11):1091-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19298805].
Berry C, Murphy N, De Vito G, et al. Effects of aldosterone receptor blockade in patients with mild-moderate heart failure taking a beta-blocker. Eur J Heart Fail. 2007;9(4):429-34. Exclude: BNP measure not FDA approved. [pmid: 17126073].
Bertinchant JP, Combes N, Polge A, et al. Prognostic value of cardiac troponin T in patients with both acute and chronic stable congestive heart failure: Comparison with atrial natriuretic peptide, brain natriuretic peptide and plasma norepinephrine. Clin Chim Acta. Feb. 2005;352(1-2):143-53. Exclude: BNP measure not FDA approved. [pmid: 15653109].
Bertsch T, Chapelle JP, Dempfle CE, et al. Multicentre analytical evaluation of a new point-of-care system for the determination of cardiac and thromboembolic markers. Clin Lab. 2010;56(1-2):37-49. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20380358].
Bethell HJN, Glover JD, Evans JA, et al. The relationship between BNP and risk assessment in cardiac rehabilitation patients. Br J Cardiol. 2008;15(3):161-5. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Bettencourt P, Ferreira A, Sousa T, et al. Brain natriuretic peptide as a marker of cardiac involvement in hypertension. Int J Cardiol. May. 15. 1999;69(2):169-77. Exclude: BNP measure not FDA approved. [pmid: 10549840].
Bettencourt P, Ferreira A, Pardal-Oliveira N, et al. Clinical significance of brain natriuretic peptide in patients with postmyocardial infarction. Clin Cardiol. Dec. 2000;23(12):921-7. Exclude: BNP measure not FDA approved. [pmid: 11129679].
Bettencourt P, Ferreira A, Dias P, et al. Evaluation of brain natriuretic peptide in the diagnosis of heart failure. Cardiol. 2000;93(1-2):19-25. Exclude: BNP measure not FDA approved.
Bettencourt P, Ferreira A, Dias P, et al. Predictors of prognosis in patients with stable mild to moderate heart failure. J Card Fail. Dec. 2000;6(4):306-13. Exclude: BNP measure not FDA approved. [pmid: 11145755].
Bettencourt P, Frioes F, Azevedo A, et al. Prognostic information provided by serial measurements of brain natriuretic peptide in heart failure. Int J Cardiol. Jan. 2004;93(1):45-8. Exclude: BNP measure not FDA approved. [pmid: 14729434].
Bettencourt P, Januzzi JL Jr. Amino-terminal pro-B-type natriuretic peptide testing for inpatient monitoring and treatment guidance of acute destabilized heart failure. Am J Cardiol. Feb. 5. 2008;101(3A):67A-71a. Exclude: Not a primary study. [pmid: 18243862].
Betti I, Castelli G, Barchielli A, et al. The role of N-terminal PRO-brain natriuretic peptide and echocardiography for screening asymptomatic left ventricular dysfunction in a population at high risk for heart failure. The PROBE-HF study. J Card Fail. Jun. 2009;15(5):377-84. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19477397].
Bevilacqua M, Vago T, Baldi G, et al. Analytical agreement and clinical correlates of plasma brain natriuretic peptide measured by three immunoassays in patients with heart failure. Clin Chem. Dec. 1997;43(12):2439-40. Exclude: BNP measure not FDA approved. [pmid: 9439475].
Beygui F, Montalescot G, Vicaut E, et al. Aldosterone and long-term outcome after myocardial infarction: A substudy of the french nationwide Observatoire sur la Prise en charge hospitaliere, l'Evolution a un an et les caRacteristiques de patients presentant un infArctus du myocarde avec ou sans onde Q (OPERA) study. Am Heart J. Apr. 2009;157(4):680-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19332195].
Beygui F, Silvain J, Pena A, et al. Usefulness of biomarker strategy to improve GRACE score's prediction performance in patients with NonST-segment elevation acute coronary syndrome and low event rates. Am J Cardiol. 2010;106(5):650-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20723640].
Bhalla MA, Chiang A, Epshteyn VA, et al. Prognostic role of B-type natriuretic peptide levels in patients with type 2 diabetes mellitus. J Am Coll Cardiol. Sep. 1. 2004;44(5):1047-52. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 15337217].
Bhalla V, Isakson S, Bhalla MA, et al. Diagnostic ability of B-type natriuretic peptide and impedance cardiography: Testing to identify left ventricular dysfunction in hypertensive patients. Am J Hypertens. Feb. 2005;18(2:Pt 2):73S-81S. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 15752936].
Bhandari SS, Loke I, Davies JE, et al. Gender and renal function influence plasma levels of copeptin in healthy individuals. Clin Sci. Feb. 2009;116(3):257-63. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18647134].
Bhatia GS, Sosin MD, Patel JV, et al. Left ventricular systolic dysfunction in rheumatoid disease: An unrecognized burden?. J Am Coll Cardiol. Mar. 21. 2006;47(6):1169-74. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16545648].
Bhatia GS, Sosin MD, Stubley J, et al. Evaluation of B-type natriuretic peptide for validation of a heart failure register in primary care. BMC Cardiovasc Disord. 2007;7:23. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17663777].
Bhatt DL, Chew DP, Grines C, et al. Peroxisome proliferator-activated receptor gamma agonists for the Prevention of Adverse events following percutaneous coronary Revascularization--results of the PPAR study. Am Heart J. Jul. 2007;154(1):137-43. Exclude: BNP measure not FDA approved. [pmid: 17584566].
Bhattacharyya S, Raja. Outcomes, risks and complications of cardiac surgery for carcinoid heart disease. Eur J Cardiothorac Surg. 2011;40(1):168-72. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21156347].
Biasucci LM, Bellocci F, Landolina M, et al. Risk stratification of ischaemic patients with implantable cardioverter defibrillators by C-reactive protein and a multi-markers strategy: Results of the CAMI-GUIDE study. Eur Heart J. 2012;33(11):1344-50. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 22285581].
Bibbins-Domingo K, Ansari M, Schiller NB, et al. B-type natriuretic peptide and ischemia in patients with stable coronary disease: Data from the Heart and Soul study. Circ. Dec. 16. 2003;108(24):2987-92. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Bibbins-Domingo K, Ansari M, Schiller NB, et al. Is B-type natriuretic peptide a useful screening test for systolic or diastolic dysfunction in patients with coronary disease? Data from the Heart and Soul Study. Am J Med. Apr. 15. 2004;116(8):509-16. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 15063811].
Bibbins-Domingo K, Gupta R, Na B, et al. N-terminal fragment of the prohormone brain-type natriuretic peptide (NT-proBNP), cardiovascular events, and mortality in patients with stable coronary heart disease. JAMA. Jan. 10. 2007;297(2):169-76. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17213400].
Biccard BM, Naidoo P, de VK. What is the best pre-operative risk stratification tool for major adverse cardiac events following elective vascular surgery? A prospective observational cohort study evaluating pre-operative myocardial ischaemia monitoring and biomarker analysis. Anaesthesia. Apr. 2012;67(4):389-95. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 22324824].
Biegus J, Zymlinski R, Szachniewicz J, et al. Clinical characteristics and predictors of in-hospital mortality in 270 consecutive patients hospitalised due to acute heart failure in a single cardiology centre during one year. Kardiol Pol. 2011;69(10):997-1005. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 22006596].
Bielecka-Dabrowa A, Goch JH, Mikhailidis DP, et al. The influence of atorvastatin on parameters of inflammation and function of the left ventricle in patients with dilated cardiomyopathy. Med Sci Monit. Dec. 2009;15(12):MS12-23. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19946241].
Bielecka-Dabrowa A, Goch JH, Rysz J, et al. Influence of co-existing atrial fibrillation on the efficacy of atorvastatin treatment in patients with dilated cardiomyopathy: A pilot study. Lipids Health Dis. 2010;9:21. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20178563].
Bilkovski RN, Kulstad EB. Elevations of B-type natriuretic peptide in pulmonary embolism: A case series. J Emerg Med. Nov. 2003;25(4):415-20. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 14654183].
Binder J, Ommen SR, Chen HH, et al. Usefulness of brain natriuretic peptide levels in the clinical evaluation of patients with hypertrophic cardiomyopathy. Am J Cardiol. Aug. 15. 2007;100(4):712-4. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17697834].
Binder L, Pieske B, Olschewski M, et al. N-terminal pro-brain natriuretic peptide or troponin testing followed by echocardiography for risk stratification of acute pulmonary embolism. Circ. Sep. 13. 2005;112(11):1573-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Biolo A, Ramamurthy S, Connors LH, et al. Matrix metalloproteinases and their tissue inhibitors in cardiac amyloidosis: Relationship to structural, functional myocardial changes and to light chain amyloid deposition. Circ. Nov. 2008;1(4):249-57. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Birner CM, Ulucan C, Fredersdorf S, et al. Head-to-head comparison of BNP and IL-6 as markers of clinical and experimental heart failure: Superiority of BNP. Cytokine. Nov. 2007;40(2):89-97. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17920926].
Bissessor N, Wee YS, Jayasinghe R, et al. Complimentary roles for N-terminal pro-B-type natriuretic peptide and spirometry to assess functional capacity in patients with complex mixed heart valve disease. Kardiol Pol. Jan. 2010;68(1):1-10. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20131183].
Bissessor N, Shanahan L, Wee YS, et al. The role of natriuretic peptides in patients with chronic complex (mixed or multiple) heart valve disease. Congest Heart Fail. Mar. 2010;16(2):50-4. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20412468].
Bitter T, Faber L, Hering D, et al. Sleep-disordered breathing in heart failure with normal left ventricular ejection fraction. Eur J Heart Fail. Jun. 2009;11(6):602-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19468022].
Bitter T, Langer C, Vogt J, et al. Sleep-disordered breathing in patients with atrial fibrillation and normal systolic left ventricular function. Deutsches Arzteblatt Int. Mar. 2009;106(10):164-70. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Bitter T, Westerheide N, Faber L, et al. Adaptive servoventilation in diastolic heart failure and Cheyne-Stokes respiration. Eur Respir J. Aug. 2010;36(2):385-92. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20032021].
Blangy H, Sadoul N, Dousset B, et al. Serum BNP, hs-C-reactive protein, procollagen to assess the risk of ventricular tachycardia in ICD recipients after myocardial infarction. Europace. Sep. 2007;9(9):724-9. Exclude: BNP measure not FDA approved. [pmid: 17526509].
Blankenberg S, Zeller T, Saarela O, et al. Contribution of 30 biomarkers to 10-year cardiovascular risk estimation in 2 population cohorts: The MONICA, risk, genetics, archiving, and monograph (MORGAM) biomarker project. Circ. 2010;121(22):2388-97. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Blatt A, Svirski R, Morawsky G, et al. Short and long-term outcome of pregnant women with preexisting dilated cardiomypathy: An NTproBNP and echocardiography-guided study. Isr Med Assoc J. Oct. 2010;12(10):613-6. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21090518].
Bleske BE, Nicklas JM, Bard RL, et al. Neutral effect on markers of heart failure, inflammation, endothelial activation and function, and vagal tone after high-dose HMG-CoA reductase inhibition in non-diabetic patients with non-ischemic cardiomyopathy and average low-density lipoprotein level. J Am Coll Cardiol. Jan. 17. 2006;47(2):338-41. Exclude: BNP measure not FDA approved. [pmid: 16412857].
Blonde-Cynober F, Morineau G, Estrugo B, et al. Diagnostic and prognostic value of brain natriuretic peptide (BNP) concentrations in very elderly heart disease patients: Specific geriatric cut-off and impacts of age, gender, renal dysfunction, and nutritional status. Arch Gerontol Geriatr. 2011;52(1):106-10. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20226544].
Blum JA, Burri C, Hatz C, et al. Sleeping hearts: The role of the heart in sleeping sickness (human African trypanosomiasis). Trop Med Int Health. Dec. 2007;12(12):1422-32. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18076548].
Blyth KG, Groenning BA, Mark PB, et al. NT-proBNP can be used to detect right ventricular systolic dysfunction in pulmonary hypertension. Eur Respir J. Apr. 2007;29(4):737-44. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17135228].
Boccanelli A, Cacciatore G, Mureddu GF, et al. Baseline characteristics of patients recruited in the AREA IN-CHF study (Antiremodelling Effect of Aldosterone Receptors Blockade with Canrenone in Mild Chronic Heart Failure). J Cardiovasc Med. 2007;8(9):683-91. Exclude: BNP measure not FDA approved.
Boccanelli A, Mureddu GF, Cacciatore G, et al. Anti-remodelling effect of canrenone in patients with mild chronic heart failure (AREA IN-CHF study): Final results. Eur J Heart Fail. Jan. 2009;11(1):68-76. Exclude: BNP measure not FDA approved. [pmid: 19147459].
Bocchi EA, Vilas-Boas F, Moreira MC, et al. Levosimendan in decompensated heart failure patients: efficacy in a Brazilian cohort. Results of the BELIEF study. Arq Bras Cardiol. Mar. 2008;90(3):182-90. Exclude: BNP measure not FDA approved. [pmid: 18392398].
Boffa GM, Zaninotto M, Nalli C, et al. Plasma levels of tumor necrosis factor-alpha correlate with the six-minute walk test results in patients with mild to moderate heart failure. Ital Heart J. Jan. 2004;5(1):48-52. Exclude: BNP measure not FDA approved. [pmid: 15080581].
Boffa GM, Zaninotto M, Bacchiega E, et al. Correlations between clinical presentation, brain natriuretic peptide, big endothelin-1, tumor necrosis factor-alpha and cardiac troponins in heart failure patients. Ital Heart J. Feb. 2005;6(2):125-32. Exclude: BNP measure not FDA approved. [pmid: 15819505].
Boger RH, Sullivan LM, Schwedhelm E, et al. Plasma asymmetric dimethylarginine and incidence of cardiovascular disease and death in the community. Circ. 2009;119(12):1592-600. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Bojunga J, Sarrazin C, Hess G, et al. Elevated plasma levels of N-terminal pro-brain natriuretic peptide in patients with chronic hepatitis C during interferon-based antiviral therapy. World J Gastroenterol. Sep. 28. 2006;12(36):5875-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17007056].
Bolger AP, Sharma R, Li W, et al. Neurohormonal activation and the chronic heart failure syndrome in adults with congenital heart disease. Circ. Jul. 2. 2002;106(1):92-9. Exclude: BNP measure not FDA approved.
Bolliger D, Seeberger MD, Lurati Buse GA, et al. A preliminary report on the prognostic significance of preoperative brain natriuretic peptide and postoperative cardiac troponin in patients undergoing major vascular surgery. Anesth Analg. Apr. 2009;108(4):1069-75. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19299763].
Bonaca MP, Morrow DA, Braunwald E, et al. Growth differentiation factor-15 and risk of recurrent events in patients stabilized after acute coronary syndrome: Observations from PROVE IT-TIMI 22. Arterioscler Thromb Vasc Biol. Jan. 2011;31(1):203-10. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20966402].
Bonderman D, Wexberg P, Martischnig AM, et al. A noninvasive algorithm to exclude pre-capillary pulmonary hypertension. Eur Respir J. May. 2011;37(5):1096-103. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20693249].
Bonfils PK, Damgaard M, Taskiran M, et al. Impact of diuretic treatment and sodium intake on plasma volume in patients with compensated systolic heart failure. Eur J Heart Fail. Sep. 2010;12(9):995-1001. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20615919].
Boonman-de Winter LJ, Rutten FH, Cramer MJ, et al. Early recognition of heart failure in patients with diabetes type 2 in primary care. A prospective diagnostic efficiency study. (UHFO-DM2). BMC Publ Health. 2009;9:479. Exclude: Not a primary study.
Booth J, Pinney J, Davenport A. N-terminal proBNP--marker of cardiac dysfunction, fluid overload, or malnutrition in hemodialysis patients?. Clin J Am Soc Nephrol. Jun. 2010;5(6):1036-40. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20507952].
Borghi C, Cosentino ER, Rinaldi ER, et al. Tinnitus in elderly patients and prognosis of mild-to-moderate congestive heart failure: A cross-sectional study with a long-term extension of the clinical follow-up. BMC Med. 2011;9:80. Exclude: BNP measure not FDA approved. [pmid: 21711572].
Boriani G, Regoli F, Saporito D, et al. Neurohormones and inflammatory mediators in patients with heart failure undergoing cardiac resynchronization therapy: Time courses and prediction of response. Peptides. Jul. 2006;27(7):1776-86. Exclude: BNP measure not FDA approved. [pmid: 16621149].
Bova C, Pesavento R, Marchiori A, et al. Risk stratification and outcomes in hemodynamically stable patients with acute pulmonary embolism: A prospective, multicentre, cohort study with three months of follow-up. J Thromb Haemostasis. 2009;7(6):938-44. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19302447].
Bove T, Van Belleghem Y, Vandenplas G, et al. Short-term systolic and diastolic ventricular performance after surgical ventricular restoration for dilated ischemic cardiomyopathy. Eur J Cardiothorac Surg. 2009;35(6):995-1003. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19136274].
Boxer RS, Dauser DA, Walsh SJ, et al. The association between vitamin D and inflammation with the 6-minute walk and frailty in patients with heart failure. J Am Geriatr Soc. Mar. 2008;56(3):454-61. Exclude: BNP measure not FDA approved. [pmid: 18194227].
Bozic B, Loncar G, Prodanovic N, et al. Relationship between high circulating adiponectin with bone mineral density and bone metabolism in elderly males with chronic heart failure. J Card Fail. Apr. 2010;16(4):301-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20350696].
Bozic B, Loncar G, Prodanovic N, et al. Parathyroid hormone response to vitamin D insufficiency in elderly males with chronic heart failure. Physiol Res. 2011;60. Suppl-63. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Brack J, Sindone A, Funston R, et al. Is addition of angiotensin receptor blockade superior to increasing ACE inhibitor dose in patients with heart failure?. Int J Cardiol. Mar. 18. 2010;139(3):309-12. Exclude: BNP measure not FDA approved. [pmid: 19027970].
Brantner R, Schandelmeyer A, Zugck C, et al. Influence of a structured, multi-moda, in-patient rehabilitation intervention on NT-proBNP values in patients with chronic heart failure NYHA II-III: A multi-centre, 6-month study. Med Klin. 2008;103(3):65-6. Exclude: Not in English.
Branzi G, Malfatto G, Villani A, et al. Acute effects of levosimendan on mitral regurgitation and diastolic function in patients with advanced chronic heart failure. J Cardiovasc Med. Sep. 2010;11(9):662-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Braun MU, Rauwolf T, Zerm T, et al. Long term biventricular resynchronisation therapy in advanced heart failure: Effect on neurohormones. Heart. 2005;91(5):601-5. Exclude: BNP measure not FDA approved. [pmid: 15831642].
Braunschweig F, Linde C, Eriksson MJ, et al. Continuous haemodynamic monitoring during withdrawal of diuretics in patients with congestive heart failure. Eur Heart J. Jan. 2002;23(1):59-69. Exclude: BNP measure not FDA approved. [pmid: 11741363].
Braunschweig F, Sorensen J, Von Bibra H, et al. Effects of biventricular pacing on myocardial blood flow and oxygen consumption using carbon-11 acetate positron emission tomography in patients with heart failure. Am J Cardiol. 2003;92(1):95-9. Exclude: BNP measure not FDA approved. [pmid: 12842260].
Braunschweig F, Fahrleitner-Pammer A, Mangiavacchi M, et al. Correlation between serial measurements of N-terminal pro brain natriuretic peptide and ambulatory cardiac filling pressures in outpatients with chronic heart failure. Eur J Heart Fail. Dec. 2006;8(8):797-803. Exclude: BNP measure not FDA approved. [pmid: 16716660].
Bredin F, Liska J, Franco-Cereceda A. Changes in natriuretic peptides following passive containment surgery in heart failure patients with dilated cardiomyopathy. Interact Cardiovasc Thorac Surg. Feb. 2009;8(2):191-4. Exclude: BNP measure not FDA approved. [pmid: 19008326].
Breidthardt T, Laule K, Strohmeyer AH, et al. Medical and economic long-term effects of B-type natriuretic peptide testing in patients with acute dyspnea. Clin Chem. Aug. 2007;53(8):1415-22. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17586596].
Breidthardt T, Noveanu M, Cayir S, et al. The use of B-type natriuretic peptide in the management of patients with atrial fibrillation and dyspnea. Int J Cardiol. Aug. 14. 2009;136(2):193-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18619686].
Breidthardt T, Kindler CH, Schindler C, et al. B-type natriuretic peptide in patients undergoing orthopaedic surgery: A prospective cohort study. Eur J Anaesthesiol. 2010;27(8):690-5. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20090534].
Breidthardt T, Noveanu M, Potocki M, et al. Impact of a high-dose nitrate strategy on cardiac stress in acute heart failure: A pilot study. J Intern Med. Mar. 2010;267(3):322-30. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19694900].
Brenta G, Thierer J, Sutton M, et al. Low plasma triiodothyronine levels in heart failure are associated with a reduced anabolic state and membrane damage. Eur J Endocrinol. Jun. 2011;164(6):937-42. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21454442].
Breuckmann F, Nassenstein K, Kondratieva J, et al. MR characterization of cardiac abnormalities in HIV+ individuals with increased BNP levels. Eur J Med Res. May. 29. 2007;12(5):185-90. Exclude: BNP measure not FDA approved. [pmid: 17513188].
Briguori C, Betocchi S, Manganelli F, et al. Determinants and clinical significance of natriuretic peptides and hypertrophic cardiomyopathy. Eur Heart J. Aug. 2001;22(15):1328-36. Exclude: BNP measure not FDA approved. [pmid: 11465965].
Brili S, Alexopoulos N, Latsios G, et al. Tissue Doppler imaging and brain natriuretic peptide levels in adults with repaired tetralogy of Fallot. J Am Soc Echocardiogr. Nov. 2005;18(11):1149-54. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16275523].
Brito D, Matias JS, Sargento L, et al. Plasma N-terminal pro-brain natriuretic peptide: A marker of left ventricular hypertrophy in hypertrophic cardiomyopathy. Rev Port Cardiol. Dec. 2004;23(12):1557-82. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 15732658].
Broberg CS, Ujita M, Prasad S, et al. Pulmonary arterial thrombosis in Eisenmenger syndrome is associated with biventricular dysfunction and decreased pulmonary flow velocity. J Am Coll Cardiol. 2007;50(7):634-42. Exclude: BNP measure not FDA approved. [pmid: 17692749].
Broeyer FJ, Osanto S, Ritsema van Eck HJ, et al. Evaluation of biomarkers for cardiotoxicity of anthracyclin-based chemotherapy. J Canc Res Clin Oncol. Sep. 2008;134(9):961-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Brophy J. ACP Journal Club. A model combining clinical assessment and NT-proBNP level accurately predicted heart failure in ED patients with dyspnea. Ann Intern Med. Jan. 19. 2010;152(2):JC1-13. Exclude: Not a primary study. [pmid: 20083816].
Brouwers C, Spindler H, Larsen ML, et al. Association between psychological measures and brain natriuretic peptide in heart failure patients. Scand Cardiovasc J. 2012;46(3):154-62. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 22251274].
Brown A, George J, Murphy MJ, et al. Could BNP screening of acute chest pain cases lead to safe earlier discharge of patients with non-cardiac causes? A pilot study. QJM. Dec. 2007;100(12):755-61. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18089541].
Brown AM, Sease KL, Robey JL, et al. The impact of B-type natriuretic peptide in addition to troponin I, creatine kinase-MB, and myoglobin on the risk stratification of emergency department chest pain patients with potential acute coronary syndrome. Ann Emerg Med. Feb. 2007;49(2):153-63. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17084941].
Bruch C, Stypmann J, Grude M, et al. Left bundle branch block in chronic heart failure-impact on diastolic function, filling pressures, and B-type natriuretic peptide levels. J Am Soc Echocardiogr. Jan. 2006;19(1):95-101. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16423676].
Brucks S, Little WC, Chao T, et al. Relation of anemia to diastolic heart failure and the effect on outcome. Am J Cardiol. Apr. 15. 2004;93(8):1055-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 15081458].
Brucks S, Little WC, Chao T, et al. Contribution of left ventricular diastolic dysfunction to heart failure regardless of ejection fraction. Am J Cardiol. Mar. 1. 2005;95(5):603-6. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 15721099].
Bruder O, Jensen C, Jochims M, et al. Relation of B-type natriuretic peptide (BNP) and infarct size as assessed by contrast-enhanced MRI. Int J Cardiol. 2010;144(1):53-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19410308].
Brueckmann M, Huhle G, Lang S, et al. Prognostic value of plasma N-terminal pro-brain natriuretic peptide in patients with severe sepsis. Circ. Jul. 26. 2005;112(4):527-34. Exclude: BNP measure not FDA approved.
Brugger-Andersen T, Ponitz V, Staines H, et al. B-type natriuretic peptide is a long-term predictor of all-cause mortality, whereas high-sensitive C-reactive protein predicts recurrent short-term troponin T positive cardiac events in chest pain patients: a prognostic study. BMC Cardiovasc Disord. 2008;8:34. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19032759].
Brugger-Andersen T, Aarsetoy H, Grundt H, et al. The long-term prognostic value of multiple biomarkers following a myocardial infarction. Thromb Res. 2008;123(1):60-6. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18387656].
Brugger-Andersen T, Ponitz V, Kontny F, et al. The long pentraxin 3 (PTX3): A novel prognostic inflammatory marker for mortality in acute chest pain. Thromb Haemost. Sep. 2009;102(3):555-63. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19718477].
Bruggink AH, de Jonge N, van Oosterhout MF, et al. Brain natriuretic peptide is produced both by cardiomyocytes and cells infiltrating the heart in patients with severe heart failure supported by a left ventricular assist device. J Heart Lung Transplant. Feb. 2006;25(2):174-80. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16446217].
Brune K, Katus HA, Moecks J, et al. N-terminal pro-B-type natriuretic peptide concentrations predict the risk of cardiovascular adverse events from antiinflammatory drugs: A pilot trial. Clin Chem. Jul. 2008;54(7):1149-57. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18451314].
Brunner-La Rocca HP, Weilenmann D, Kiowski W, et al. Plasma levels of enalaprilat in chronic therapy of heart failure: Relationship to adverse events. J Pharmacol Exp Ther. 1999;289(1):565-71. Exclude: BNP measure not FDA approved. [pmid: 10087051].
Brunner-La Rocca HP, Weilenmann D, Kiowski W, et al. Within-patient comparison of effects of different dosages of enalapril on functional capacity and neurohormone levels in patients with chronic heart failure. Am Heart J. Oct. 1999;138(4 Pt 1):654-62. Exclude: BNP measure not FDA approved. [pmid: 10502210].
Brunner-La Rocca HP, Kaye DM, Woods RL, et al. Effects of intravenous brain natriuretic peptide on regional sympathetic activity in patients with chronic heart failure as compared with healthy control subjects. J Am Coll Cardiol. Apr. 2001;37(5):1221-7. Exclude: BNP measure not FDA approved. [pmid: 11300426].
Brunner-La Rocca HP, Buser PT, Schindler R, et al. Management of elderly patients with congestive heart failure--design of the Trial of Intensified versus standard Medical therapy in Elderly patients with Congestive Heart Failure (TIME-CHF). Am Heart J. May. 2006;151(5):949-55. Exclude: Not a primary study. [pmid: 16644310].
Brzezinska U, El Mokhtari NE, Simon R, et al. The effect of coronary angioplasty on plasma NT-proBNP level in patients with and without arterial hypertension. Blood Press. 2006;15(3):173-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16864160].
Buchner S, Debl K, Barlage S, et al. Dynamic changes in N-terminal pro-brain natriuretic peptide in acute coronary syndromes treated with percutaneous coronary intervention: A marker of ischemic burden, reperfusion and outcome. Clin Chem Lab Med. Jun. 2010;48(6):875-81. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20441480].
Buckley MG, Marcus NJ, Yacoub MH, et al. Prolonged stability of brain natriuretic peptide: Importance for non-invasive assessment of cardiac function in clinical practice. Clin Sci. Sep. 1998;95(3):235-9. Exclude: BNP measure not FDA approved. [pmid: 9730841].
Budeus M, Buck T, Wieneke H, et al. Single-chamber versus dual-chamber implantable cardioverter defibrillators: do we need physiologic pacing in the course?. Indian Pacing Electrophysiol J. 2006;6(3):153-62. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16943965].
Budeus M, Salibassoglu E, Schymura AM, et al. Effect of induced ventricular fibrillation and shock delivery on brain natriuretic peptide measured serially following a predischarge ICD test. Indian Pacing Electrophysiol J. 2007;7(4):195-203. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17957267].
Budweiser S, Luchner A, Jorres RA, et al. NT-proBNP in chronic hypercapnic respiratory failure: A marker of disease severity, treatment effect and prognosis. Respir Med. Sep. 2007;101(9):2003-10. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17532200].
Bunce S, Stride A, Matthews C, et al. The effects of central arterial pressure and autonomic dysfunction on elevations in N-terminal pro-B-type natriuretic peptide (NT-proBNP) in men with diabetes. Artery Res. 2008;2(2):60-6. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Bunevicius R, Varoneckas G, Prange AJ Jr., et al. Depression and thyroid axis function in coronary artery disease: Impact of cardiac impairment and gender. Clin Cardiol. Apr. 2006;29(4):170-4. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16649727].
Burger AJ, Aronson D. Effect of vasoactive therapy on heart rate variability in patients with acutely decompensated congestive heart failure. Am J Cardiol. 1999;84(4):476-8. Exclude: BNP measure not FDA approved. [pmid: 10468094].
Burger AJ, Elkayam U, Neibaur MT, et al. Comparison of the occurrence of ventricular arrhythmias in patients with acutely decompensated congestive heart failure receiving dobutamine versus nesiritide therapy. Am J Cardiol. Jul. 1. 2001;88(1):35-9. Exclude: BNP measure not FDA approved. [pmid: 11423055].
Burger AJ, Horton DP, LeJemtel T, et al. Effect of nesiritide (B-type natriuretic peptide) and dobutamine on ventricular arrhythmias in the treatment of patients with acutely decompensated congestive heart failure: The PRECEDENT study. Am Heart J. Dec. 2002;144(6):1102-8. Exclude: BNP measure not FDA approved. [pmid: 12486437].
Burjonroppa SC, Tong AT, Xiao LC, et al. Cancer patients with markedly elevated B-type natriuretic peptide may not have volume overload. Am J Clin Oncol. Jun. 2007;30(3):287-93. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17551307].
Burkhard T, Herzog C, Linzbach S, et al. Cardiac (31)P-MRS compared to echocardiographic findings in patients with hypertensive heart disease without overt systolic dysfunction--Preliminary results. Eur J Radiol. Jul. 2009;71(1):69-74. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18485651].
Bursi F, Weston SA, Redfield MM, et al. Systolic and diastolic heart failure in the community. JAMA. Nov. 8. 2006;296(18):2209-16. Exclude: BNP measure not FDA approved. [pmid: 17090767].
Butler J, Emerman C, Peacock WF, et al. The efficacy and safety of B-type natriuretic peptide (nesiritide) in patients with renal insufficiency and acutely decompensated congestive heart failure. Nephrol Dial Transplant. Feb. 2004;19(2):391-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 14736964].
Butter C, Rastogi S, Minden HH, et al. Cardiac contractility modulation electrical signals improve myocardial gene expression in patients with heart failure. J Am Coll Cardiol. 2008;51(18):1784-9. Exclude: BNP measure not FDA approved. [pmid: 18452785].
Butterfield JA, Faddy SC, Davidson P, et al. Exercise training in patients with stable chronic heart failure: Effects on thoracic impedance cardiography and B-type natriuretic peptide. J Cardiopulm Rehabil Prev. Jan. 2008;28(1):33-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18277828].
Byrkjeland RN. Inflammatory markers as related to disease severity in patients with chronic heart failure: Limited effects of exercise training. Scand J Clin Lab Invest. 2011;71(7):598-605. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21831004].
Cabanes L, Richaud-Thiriez B, Fulla Y, et al. Brain natriuretic peptide blood levels in the differential diagnosis of dyspnea. Chest. Dec. 2001;120(6):2047-50. Exclude: BNP measure not FDA approved. [pmid: 11742939].
Cagini LC. Fluid and electrolyte balance after major thoracic surgery by bioimpedance and endocrine evaluation. Eur J Cardiothorac Surg. 2011;40(2):e71-6. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21530295].
Cai B, Wang LL, Liu J, et al. The effectiveness of NT-proBNP in diagnosing heart failure. Chin J Evid Based Med. 2005;5(3):224-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Cakir Z, Saritas A, Emet M, et al. A prospective study of brain natriuretic peptide levels in three subgroups: Stroke with hypertension, stroke without hypertension, and hypertension alone. Ann Ind Acad Neurol. 2010;13(1):47-51. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Caldwell MA, Peters KJ, Dracup KA. A simplified education program improves knowledge, self-care behavior, and disease severity in heart failure patients in rural settings. Am Heart J. Nov. 2005;150(5):983. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16290977].
Callejas-Rubio JL, Moreno-Escobar E, de la Fuente PM, et al. Prevalence of exercise pulmonary arterial hypertension in scleroderma. J Rheumatol. Sep. 2008;35(9):1812-6. Exclude: BNP measure not FDA approved. [pmid: 18634147].
Calvin AD, Somers VK, van der Walt C, et al. Relation of natriuretic peptide concentrations to central sleep apnea in patients with heart failure. Chest. Dec. 2011;140(6):1517-23. Exclude: BNP measure not FDA approved. [pmid: 21636668].
Cameron SJ, Sokoll LJ, Laterza OF, et al. A multi-marker approach for the prediction of adverse events in patients with acute coronary syndromes. Clin Chim Acta. Feb. 2007;376(1-2):168-73. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17011538].
Caminiti G, Volterrani M, Marazzi G, et al. Tai chi enhances the effects of endurance training in the rehabilitation of elderly patients with chronic heart failure. Rehab Res Pract Print. 2011;2011:761958. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Campana C, Pasotti M, Monti L, et al. The evaluation of right ventricular performance in different clinical models of heart failure. Eur Heart J. 2004;6(Suppl 6):F61-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Campana C, Alessandrino G, Striuli L, et al. The tailored medical therapy in patients with advanced heart failure referred for cardiac transplantation. Transplant Proc. Jul. 2008;40(6):1999-2000. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18675112].
Campbell DJ, Mitchelhill KI, Schlicht SM, et al. Plasma amino-terminal pro-brain natriuretic peptide: A novel approach to the diagnosis of cardiac dysfunction. J Card Fail. Jun. 2000;6(2):130-9. Exclude: BNP measure not FDA approved. [pmid: 10908087].
Campbell DJ, Munir V, Hennessy OF, et al. Plasma amino-terminal pro-brain natriuretic peptide levels in subjects presenting to the Emergency Department with suspected acute coronary syndrome: Possible role in selecting patients for follow up?. Intern Med J. May. 2001;31(4):211-9. Exclude: BNP measure not FDA approved. [pmid: 11456034].
Campbell DJ, Aggarwal A, Esler M, et al. Beta-blockers, angiotensin II, and ACE inhibitors in patients with heart failure. Lancet. Nov. 10. 2001;358(9293):1609-10. Exclude: BNP measure not FDA approved. [pmid: 11716889].
Campbell DJ, Woodward M, Chalmers JP, et al. Prediction of heart failure by amino terminal-pro-B-type natriuretic peptide and C-reactive protein in subjects with cerebrovascular disease. Hypertens. Jan. 2005;45(1):69-74. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Campbell DJ, Woodward M, Chalmers JP, et al. Perindopril-based blood pressure-lowering therapy reduces amino-terminal-pro-B-type natriuretic peptide in individuals with cerebrovascular disease. J Hypertens. Mar. 2007;25(3):699-705. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17278987].
Campbell PT, Tremaglio J, Bhardwaj A, et al. Utility of daily diuretic orders for identifying acute decompensated heart failure patients for quality improvement. Crit Pathways Cardiol. 2010;9(3):148-51. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Campbell SM, Fuat A, Summerton N, et al. Diagnostic triage and the role of natriuretic peptide testing and echocardiography for suspected heart failure: An appropriateness ratings evaluation by UK GPs. Br J Gen Pract. Jul. 2011;61(588):e427-e435. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21722451].
Canault E, Jourdain P, Deschamps P, et al. Algorithm for using B type natriuretic peptide in management of suspected heart failure patients in an Emergency Care Unit. Jeur. 2002;15(4):189-95. Exclude: Not in English.
Cao H, Xue L, Wu Y, et al. Natriuretic peptides and right atrial fibrosis in patients with paroxysmal versus persistent atrial fibrillation. Peptides. Aug. 2010;31(8):1531-9. Exclude: BNP measure not FDA approved. [pmid: 20434499].
Cao YM, Patrick J, Francois F. Long-term prognostic value of analysis of sympathetic drive by myocardial 123I-metaiodobenzylganidine scintigraphy in chronic heart failure. Chin Med J. 2010;123(15):2023-7. Exclude: BNP measure not FDA approved. [pmid: 20819536].
Cappellin E, Gatti R, Spinella P, et al. Plasma atrial natriuretic peptide (ANP) fragments proANP (1-30) and proANP (31-67) measurements in chronic heart failure: A useful index for heart transplantation?. Clin Chim Acta. Aug. 1. 2001;310(1):49-52. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 11485754].
Cappola TP, Harsch MR, Jessup M, et al. Predictors of remodeling in the CRT era: Influence of mitral regurgitation, BNP, and gender. J Card Fail. Apr. 2006;12(3):182-8. Exclude: BNP measure not FDA approved. [pmid: 16624682].
Cardin T, Marinelli A. Pulmonary embolism. Crit Care Nurs Q. Oct. 2004;27(4):310-22. Exclude: Not a primary study. [pmid: 15537120].
Cardoso J, Brito MI, Ochiai ME, et al. Anemia in patients with advanced heart failure. Arq Bras Cardiol. 2010;95(4):524-9. Exclude: BNP measure not FDA approved. [pmid: 20802963].
Cargill RI, Barr CS, Coutie WJ, et al. C-type natriuretic peptide levels in cor pulmonale and in congestive heart failure. Thorax. Dec. 1994;49(12):1247-9. Exclude: BNP measure not FDA approved. [pmid: 7878562].
Carmona-Bernal C, Quintana-Gallego E, Villa-Gil M, et al. Brain natriuretic peptide in patients with congestive heart failure and central sleep apnea. Chest. May. 2005;127(5):1667-73. Exclude: BNP measure not FDA approved. [pmid: 15888844].
Carr SJ, Bavanandan S, Fentum B, et al. Prognostic potential of brain natriuretic peptide (BNP) in predialysis chronic kidney disease patients. Clin Sci. Jul. 2005;109(1):75-82. Exclude: BNP measure not FDA approved. [pmid: 15743271].
Carstens J, Jensen KT, Pedersen EB. Effect of urodilatin infusion on renal haemodynamics, tubular function and vasoactive hormones. Clin Sci. 1997;92(4):397-407. Exclude: BNP measure not FDA approved. [pmid: 9176040].
Castano RS, Coma-Canella I, Lopez SB, et al. Echocardiographic findings and NT-proBNP level in type-2 diabetic patients with and without ischemic heart disease. Rev Esp Cardiol. Oct. 2009;62(10):1184-8. Exclude: BNP measure not FDA approved. [pmid: 19793525].
Cataliotti A, Malatino LS, Jougasaki M, et al. Circulating natriuretic peptide concentrations in patients with end-stage renal disease: Role of brain natriuretic peptide as a biomarker for ventricular remodeling. Mayo Clin Proc. Nov. 2001;76(11):1111-9. Exclude: BNP measure not FDA approved. [pmid: 11702899].
Cattadori G, Wasserman K, Meloni C, et al. Alveolar membrane conductance decreases as BNP increases during exercise in heart failure. Rationale for BNP in the evaluation of dyspnea. J Card Fail. Mar. 2009;15(2):136-44. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19254673].
Catuzzo B, Ciancamerla F, Bobbio M, et al. In patients with severe systolic dysfunction, only brain natriuretic peptide is related to diastolic restrictive pattern. J Card Fail. Aug. 2003;9(4):303-10. Exclude: BNP measure not FDA approved. [pmid: 13680551].
Cauliez B, Santos H, Bauer F, et al. Cross-reactivity with endogenous proBNP from heart failure patients for three commercial BNP immunoassays. Clin Chim Acta. Jan. 18. 2012;413(1-2):337-8. Exclude: Not a primary study. [pmid: 21978727].
Cavagna L, Caporali R, Klersy C, et al. Comparison of brain natriuretic peptide (BNP) and NT-proBNP in screening for pulmonary arterial hypertension in patients with systemic sclerosis. J Rheumatol. Oct. 2010;37(10):2064-70. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20634241].
Cavusoglu Y, Tek M, Birdane A, et al. Both levosimendan and dobutamine treatments result in significant reduction of NT-proBNP levels, but levosimendan has better and prolonged neurohormonal effects than dobutamine. Int J Cardiol. Jul. 21. 2008;127(3):e188-91. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17884200].
Ceconi C, Freedman SB, Tardif JC, et al. Effect of heart rate reduction by ivabradine on left ventricular remodeling in the echocardiographic substudy of BEAUTIFUL. Int J Cardiol. 2011;146(3):408-14. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21112101].
Celik A, Sahin S, Koc F, et al. Cardiotrophin-1 plasma levels are increased in patients with diastolic heart failure. Med Sci Monit. Jan. 2012;18(1):CR25-31. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 22207116].
Celik A, Koc F, Kadi H, et al. Relationship between red cell distribution width and echocardiographic parameters in patients with diastolic heart failure. Kaohsiung Journal of Medical Sciences. 2012;28(3):165-72. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 22385610].
Celik O, Sahin I, Celik N, et al. Diagnostic potential of serum N-terminal pro-B-type brain natriuretic peptide level in detection of cardiac wall stress in women with polycystic ovary syndrome: A cross-sectional comparison study. Hum Reprod. Nov. 2007;22(11):2992-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17855407].
Cemri M, Arslan U, Kocaman SA, et al. Relationship between N-terminal pro-B type natriuretic peptide and extensive echocardiographic parameters in mild to moderate aortic stenosis. J Postgrad Med. Jan. 2008;54(1):12-6. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18296798].
Cerisano G, Pucci PD, Valenti R, et al. Comparison of the usefulness of Doppler-derived deceleration time versus plasma brain natriuretic peptide to predict left ventricular remodeling after mechanical revascularization in patients with ST-elevation acute myocardial infarction and left ventricular systolic dysfunction. Am J Cardiol. Apr. 15. 2005;95(8):930-4. Exclude: BNP measure not FDA approved. [pmid: 15820157].
Cerisano G, Parodi G, Dovellini EV, et al. Time course of serum collagen types I and III metabolism products after reperfused acute myocardial infarction in patients with and without systemic hypertension. J Hum Hypertens. Jan. 2009;23(1):40-7. Exclude: BNP measure not FDA approved. [pmid: 18701924].
Ceyhan C, Unal S, Yenisey C, et al. The role of N terminal pro-brain natriuretic peptide in the evaluation of left ventricular diastolic dysfunction: Correlation with echocardiographic indexes in hypertensive patients. Int J Cardiovasc Imaging. Mar. 2008;24(3):253-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17687631].
Chainani-Wu N, Weidner G, Purnell DM, et al. Relation of B-type natriuretic peptide levels to body mass index after comprehensive lifestyle changes. Am J Cardiol. Jun. 1. 2010;105(11):1570-6. Exclude: BNP measure not FDA approved. [pmid: 20494664].
Chainani-Wu NW. Changes in emerging cardiac biomarkers after an intensive lifestyle intervention. Am J Cardiol. 2011;108(4):498-507. Exclude: BNP measure not FDA approved. [pmid: 21624543].
Chambers JS, Francis DP, Coats AJS. Recovery oxygen uptake and brain natriuretic peptide as markers of exercise capacity in chronic heart failure. J Sports Sci. 2000;18(7):490. Exclude: BNP measure not FDA approved.
Chandra A, Otero R, Freeman D, et al. BNP-mediated vasodilatation for dialysis-dependent patient with acute heart failure syndrome in the emergency department. Ren Fail. 2008;30(1):45-50. Exclude: BNP measure not FDA approved. [pmid: 18197542].
Chandrakala AN, Sukul D, Selvarajan K, et al. Induction of brain natriuretic peptide and monocyte chemotactic protein-1 gene expression by oxidized low-density lipoprotein: Relevance to ischemic heart failure. Am J Physiol Cell Physiol. Jan. 2012;302(1):C165-C177. Exclude: Non-human population. [pmid: 21900689].
Chandrasekaran B, Kalra PR, Donovan J, et al. Myocardial apelin production is reduced in humans with left ventricular systolic dysfunction. J Card Fail. 2010;16(7):556-61. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20610231].
Chang R, Elatre WA, Heywood JT. Effect of nesiritide on length of hospital stay in patients with decompensated heart failure. J Cardiovasc Pharmacol Ther. Sep. 2004;9(3):173-7. Exclude: BNP measure not FDA approved. [pmid: 15378137].
Changchien EM, Ahmed S, Betti F, et al. B-type natriuretic peptide increases after gastric bypass surgery and correlates with weight loss. Surg Endosc. Jul. 2011;25(7):2338-43. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21424205].
Chatzis D, Tsioufis C, Tsiachris D, et al. Brain natriuretic peptide as an integrator of cardiovascular stiffening in hypertension. Int J Cardiol. Jun. 11. 2010;141(3):291-6. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19157602].
Chaudhry A, Singer AJ, Chohan J, et al. Interrater reliability of hemodynamic profiling of patients with heart failure in the ED. Am J Emerg Med. 2008;26(2):196-201. Exclude: BNP measure not FDA approved. [pmid: 18272102].
Chazot C, Jean G, Vo-Van C, et al. The plasma level of brain natriuretic peptide is increased in malnourished hemodialysis patients. Blood Purif. 2009;28(3):187-92. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19648737].
Chen AA, Wood MJ, Krauser DG, et al. NT-proBNP levels, echocardiographic findings, and outcomes in breathless patients: Results from the ProBNP Investigation of Dyspnoea in the Emergency Department (PRIDE) echocardiographic substudy. Eur Heart J. Apr. 2006;27(7):839-45. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16510467].
Chen HH, Redfield MM, Nordstrom LJ, et al. Subcutaneous administration of the cardiac hormone BNP in symptomatic human heart failure. J Card Fail. Apr. 2004;10(2):115-9. Exclude: BNP measure not FDA approved. [pmid: 15101022].
Chen HH, Martin FL, Gibbons RJ, et al. Low-dose nesiritide in human anterior myocardial infarction suppresses aldosterone and preserves ventricular function and structure: A proof of concept study. Heart. Aug. 2009;95(16):1315-9. Exclude: BNP measure not FDA approved. [pmid: 19447837].
Chen JH, Michiue T, Ishikawa T, et al. Difference in molecular pathology of natriuretic peptides in the myocardium between acute asphyxial and cardiac deaths. Legal Medicine. 2012;14(4):177-82. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 22503242].
Chen TH, Chang CH, Lin CY, et al. Acute kidney injury biomarkers for patients in a coronary care unit: A prospective cohort study. PLoS ONE. 2012;7(2). Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Chen YT, Liu TS, Jiang SS, et al. Plasma brain natriuretic peptide and atria natriuretic peptide as predictors for diastolic heart failure in patients with type 2 diabetes mellitus. J Geriatr Cardiol. 2009;6(4):227-9. Exclude: Unable to obtain copy.
Chen YX, Wang XQ, Fang CF, et al. Value of BNP and tumour marker CA125 in patients with heart failure. Acta Cardiol. Aug. 2008;63(4):501-6. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18795589].
Chenevier-Gobeaux C, Allo JC, Arthaud M, et al. N-Terminal pro B-type natriuretic peptide testing for short-term prognosis in breathless older adults. Am J Emerg Med. Jun. 2008;26(5):555-60. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18534284].
Chiang SJ, Daimon M, Ishii K, et al. A novel global strain diastolic index correlates with plasma NT-proBNP levels in asymptomatic hypertensive patients with preserved left ventricular ejection fraction. J Echocardiograph. 2012;10(2):56-64. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Chiarelli G, Beaulieu M, Taylor P, et al. Elimination of BNP by peritoneal dialysis: Investigation of analytical issues. Perit Dial Int. Mar. 2011;31(2):199-202. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21427249].
Chida K, Otani H, Kohzuki M, et al. The relationship between plasma BNP level and the myocardial phosphocreatine/adenosine triphosphate ratio determined by phosphorus-31 magnetic resonance spectroscopy in patients with dilated cardiomyopathy. Cardiol. 2006;106(3):132-6. Exclude: BNP measure not FDA approved.
Chien JY, Lin MS, Huang YC, et al. Changes in B-type natriuretic peptide improve weaning outcome predicted by spontaneous breathing trial. Crit Care Med. May. 2008;36(5):1421-6. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18434901].
Chiladakis JA, Koutsogiannis N, Kalogeropoulos A, et al. Acute effects of VVI pacing on ventricular diastolic performance in elderly patients with normal left ventricular systolic function. Int J Cardiol. Jun. 25. 2007;119(1):117-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17049632].
Chiladakis JA, Koutsogiannis N, Kalogeropoulos A, et al. Long-term effects of atrial synchronous ventricular pacing on systolic and diastolic ventricular function in patients with normal left ventricular ejection fraction. Cardiol. 2007;108(4):290-6. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Chin KR, Young BJ, Seok CK, et al. Utility of B-type natriuretic peptide in patients with acute respiratory distress syndrome. Tubercul Resp Dis. 2007;62(5):389-97. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Choi BR, Kim JS, Yang YJ, et al. Factors associated with decreased cerebral blood flow in congestive heart failure secondary to idiopathic dilated cardiomyopathy. Am J Cardiol. May. 1. 2006;97(9):1365-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16635612].
Choi DJ, Han S, Jeon ES, et al. Characteristics, outcomes and predictors of long-term mortality for patients hospitalized for acute heart failure: A report from the Korean heart failure registry. Korean Circ J. Jul. 2011;41(7):363-71. Exclude: BNP measure not FDA approved. [pmid: 21860637].
Choi EY, Kwon HM, Yoon YW, et al. Assessment of extent of myocardial ischemia in patients with non-ST elevation acute coronary syndrome using serum B-type natriuretic peptide level. Yonsei Med J. Apr. 30. 2004;45(2):255-62. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 15118997].
Choi HJ, Shin YK, Lee HJ, et al. The clinical significance of serum N-terminal pro-brain natriuretic peptide in systemic sclerosis patients. Clin Rheumatol. Apr. 2008;27(4):437-42. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17899307].
Choi JH, Cho DK, Song YB, et al. Preoperative NT-proBNP and CRP predict perioperative major cardiovascular events in non-cardiac surgery. Heart. Jan. 2010;96(1):56-62. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19861299].
Choi SG, Jeong MH, Ahn Y, et al. Relationship between obesity and n-terminal brain natriuretic peptide level as a prognostic value after acute myocardial infarction. Korean Circ J. 2010;40(11):558-64. Exclude: BNP measure not FDA approved. [pmid: 21217932].
Choi SY, Lee JE, Jang EH, et al. Association between changes in N-terminal pro-brain natriuretic peptide levels and changes in left ventricular mass index in stable hemodialysis patients. Nephron. 2008;110(2):c93-100. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18815449].
Chong AY, Blann AD, Patel J, et al. Endothelial dysfunction and damage in congestive heart failure: Relation of flow-mediated dilation to circulating endothelial cells, plasma indexes of endothelial damage, and brain natriuretic peptide. Circ. Sep. 28. 2004;110(13):1794-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Chong AY, Freestone B, Patel J, et al. Endothelial activation, dysfunction, and damage in congestive heart failure and the relation to brain natriuretic peptide and outcomes. Am J Cardiol. Mar. 1. 2006;97(5):671-5. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16490435].
Chong AY, Freestone B, Lim HS, et al. Plasma von Willebrand factor and soluble E-selectin levels in stable outpatients with systolic heart failure: The Frederiksberg heart failure study. Int J Cardiol. Jun. 25. 2007;119(1):80-2. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17027106].
Chong CP, van Gaal WJ, Ryan JE, et al. Troponin I and NT-proBNP (N-terminal pro-brain natriuretic peptide) do not predict 6-month mortality in frail older patients undergoing orthopedic surgery. J Am Med Dir Assoc. Jul. 2010;11(6):415-20. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20627182].
Chong CP, Ryan JE, van Gaal WJ, et al. Usefulness of N-terminal pro-brain natriuretic peptide to predict postoperative cardiac complications and long-term mortality after emergency lower limb orthopedic surgery. Am J Cardiol. Sep. 15. 2010;106(6):865-72. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20816130].
Chong CP, Lim WK, Velkoska E, et al. N-terminal pro-brain natriuretic peptide and angiotensin-converting enzyme-2 levels and their association with postoperative cardiac complications after emergency orthopedic surgery. Am J Cardiol. 2012;109(9):1365-73. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 22381157].
Chong KS, Gardner RS, Morton JJ, et al. Plasma concentrations of the novel peptide apelin are decreased in patients with chronic heart failure. Eur J Heart Fail. Jun. 2006;8(4):355-60. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16464638].
Chorianopoulos E, Rosenberg M, Zugck C, et al. Decreased soluble TWEAK levels predict an adverse prognosis in patients with chronic stable heart failure. Eur J Heart Fail. Nov. 2009;11(11):1050-6. Exclude: BNP measure not FDA approved. [pmid: 19875405].
Chou PC, Chin CH, Lin CL, et al. Predicting heart failure symptoms by plasma N-terminal pro B-type natriuretic peptide for patients with chronic aortic regurgitation and preserved left ventricular function. Acta Cardiol Sin. 2008;24(1):29-34. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Chow PC, Cheung EW, Chong CY, et al. Brain natriuretic peptide as a biomarker of systemic right ventricular function in patients with transposition of great arteries after atrial switch operation. Int J Cardiol. Jul. 4. 2008;127(2):192-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17643533].
Chow SLO. Renal function and neurohormonal changes following intravenous infusions of nitroglycerin versus nesiritide in patients with acute decompensated heart failure. J Card Fail. 2011;17(3):181-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21362524].
Choy AM, Darbar D, Lang CC, et al. Detection of left ventricular dysfunction after acute myocardial infarction: Comparison of clinical, echocardiographic, and neurohormonal methods. Br Heart J. Jul. 1994;72(1):16-22. Exclude: BNP measure not FDA approved. [pmid: 7741839].
Christ-Crain M, Morgenthaler NG, Meier C, et al. Pro-A-type and N-terminal pro-B-type natriuretic peptides in different thyroid function states. Swiss Med Wkly. Sep. 17. 2005;135(37-38):549-54. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16333765].
Christ M, Laule-Kilian K, Hochholzer W, et al. Gender-specific risk stratification with B-type natriuretic peptide levels in patients with acute dyspnea: Insights from the B-type natriuretic peptide for acute shortness of breath evaluation study. J Am Coll Cardiol. Nov. 7. 2006;48(9):1808-12. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17084254].
Christ M, Sharkova Y, Fenske H, et al. Brain natriuretic peptide for prediction of Cheyne-Stokes respiration in heart failure patients. Int J Cardiol. Mar. 2. 2007;116(1):62-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16820230].
Christ M, Thuerlimann A, Laule K, et al. Long-term prognostic value of B-type natriuretic peptide in cardiac and non-cardiac causes of acute dyspnoea. Eur J Clin Invest. Nov. 2007;37(11):834-41. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17931382].
Christ M, Laule K, Klima T, et al. Multimarker strategy for risk prediction in patients presenting with acute dyspnea to the emergency department. Int J Cardiol. May. 7. 2008;126(1):73-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17481748].
Chrysohoou C, Pitsavos C, Aggelopoulos P, et al. Serum glucose level at hospital admission correlates with left ventricular systolic dysfunction in nondiabetic, acute coronary patients: The Hellenic Heart Failure Study. Heart Ves. May. 2010;25(3):209-16. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Chua G, Kang-Hoe L. Marked elevations in N-terminal brain natriuretic peptide levels in septic shock. Crit Care. Aug. 2004;8(4):R248-50. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 15312225].
Chuang CP, Lo HM, Wu CY, et al. N-terminal pro-brain natriuretic peptide as a prognostic predictor in critical care patients with acute cardiogenic pulmonary edema. Acta Cardiol Sin. 2007;23(1):20-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Chung CP, Solus JF, Oeser A, et al. N-terminal pro-brain natriuretic peptide in systemic lupus erythematosus: Relationship with inflammation, augmentation index, and coronary calcification. J Rheumatol. Jul. 2008;35(7):1314-9. Exclude: BNP measure not FDA approved. [pmid: 18528966].
Chung JH, Yun NR, Ahn CY, et al. Relationship between serum N-terminal pro-brain natriuretic peptide level and left ventricular dysfunction and extracellular water in continuous ambulatory peritoneal dialysis patients. Electrolyte Blood Press. 2008;6(1):15-21. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Chung L, Liu J, Parsons L, et al. Characterization of connective tissue disease-associated pulmonary arterial hypertension from REVEAL: Identifying systemic sclerosis as a unique phenotype. Chest. Dec. 2010;138(6):1383-94. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20507945].
Chung T, Lim WC, Sy R, et al. Subacute cardiac toxicity following autologous haematopoietic stem cell transplantation in patients with normal cardiac function. Heart. Jul. 2008;94(7):911-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18070952].
Ciampi Q, Borzillo G, Barbato E, et al. Diastolic function and BNP changes during exercise predict oxygen consumption in chronic heart failure patients. Scand Cardiovasc J. Feb. 2009;43(1):17-23. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18609042].
Ciampi Q, Petruzziello B, Della PM, et al. Effect of intraventricular dyssynchrony on diastolic function and exercise tolerance in patients with heart failure. Eur J Echocardiogr. Dec. 2009;10(8):907-13. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19602490].
Ciampi Q, Pratali L, Bombardini T, et al. Pressure-volume relationship during dobutamine stress echocardiography predicts exercise tolerance in patients with congestive heart failure. J Am Soc Echocardiogr. Jan. 2010;23(1):71-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19962273].
Ciccone MM, Iacoviello M, Puzzovivo A, et al. Clinical correlates of endothelial function in chronic heart failure. Clin Res Cardiol. Jun. 2011;100(6):515-21. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21212968].
Cicoira M, Maggioni AP, Latini R, et al. Body mass index, prognosis and mode of death in chronic heart failure: Results from the Valsartan Heart Failure Trial. Eur J Heart Fail. 2007;9(4):397-402. Exclude: BNP measure not FDA approved. [pmid: 17166768].
Cioffi G, Tarantini L, Stefenelli C, et al. Changes in plasma N-terminal proBNP levels and ventricular filling pressures during intensive unloading therapy in elderly with decompensated congestive heart failure and preserved left ventricular systolic function. J Card Fail. Oct. 2006;12(8):608-15. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17045179].
Cittadini A, Ines CL, Longobardi S, et al. A preliminary randomized study of growth hormone administration in Becker and Duchenne muscular dystrophies. Eur Heart J. Apr. 2003;24(7):664-72. Exclude: BNP measure not FDA approved. [pmid: 12657225].
Cittadini A, Saldamarco L, Marra AM, et al. Growth hormone deficiency in patients with chronic heart failure and beneficial effects of its correction. J Clin Endocrinol Metab. Sep. 2009;94(9):3329-36. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19584187].
Ciuraszkiewicz K, Janion M, Sielski J, et al. Post-myocardial infarction intraventricular conduction defects and B-type natriuretic peptide levels. Clin Cardiol. Jun. 2009;32(6):E12-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19189316].
Ciurzynski M, Bienias P, Lichodziejewska B, et al. Non-invasive diagnostic and functional evaluation of cardiac involvement in patients with systemic sclerosis. Clin Rheumatol. Aug. 2008;27(8):991-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18256871].
Clark AL, Lammiman MJ, Goode K, et al. Is taking part in clinical trials good for your health? A cohort study. Eur J Heart Fail. Nov. 2009;11(11):1078-83. Exclude: BNP measure not FDA approved. [pmid: 19875407].
Clarkson PB, Wheeldon NM, MacFadyen RJ, et al. Effects of brain natriuretic peptide on exercise hemodynamics and neurohormones in isolated diastolic heart failure. Circ. Jun. 1. 1996;93(11):2037-42. Exclude: BNP measure not FDA approved.
Cleland JG, Goode K, Erhardt L, et al. A description of the clinical characteristics at baseline of patients recruited into the Carvedilol or Metoprolol European Trial (COMET). Cardiovasc Drugs Ther. Mar. 2004;18(2):139-52. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 15162076].
Cleland JG, Louis AA, Rigby AS, et al. Noninvasive home telemonitoring for patients with heart failure at high risk of recurrent admission and death: The Trans-European Network-Home-Care Management System (TEN-HMS) study. J Am Coll Cardiol. May. 17. 2005;45(10):1654-64. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 15893183].
Cleland JGF, Freemantle N, Erdmann E, et al. Long-term mortality with cardiac resynchronization therapy in the Cardiac Resynchronization-Heart Failure (CARE-HF) trial. Eur J Heart Fail. 2012;14(6):628-34. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 22552183].
Cleland JGF, Taylor J, Freemantle N, et al. Relationship between plasma concentrations of N-terminal pro brain natriuretic peptide and the characteristics and outcome of patients with a clinical diagnosis of diastolic heart failure: A report from the PEP-CHF study. Eur J Heart Fail. 2012;14(5):487-94. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 22505395].
Clerico A, Iervasi G, Del Chicca MG, et al. Circulating levels of cardiac natriuretic peptides (ANP and BNP) measured by highly sensitive and specific immunoradiometric assays in normal subjects and in patients with different degrees of heart failure. J Endocrinol Invest. Mar. 1998;21(3):170-9. Exclude: BNP measure not FDA approved. [pmid: 9591213].
Clerico A, Fontana M, Zyw L, et al. Comparison of the diagnostic accuracy of BNP and NT-proBNP in acute and chronic heart failure. Clin Chem. 2007;53(9):1720-1. Exclude: Systematic review.
Clodi M, Resl M, Stelzeneder D, et al. Interactions of glucose metabolism and chronic heart failure. Exp Clin Endocrinol Diabetes. Mar. 2009;117(3):99-106. Exclude: BNP measure not FDA approved. [pmid: 19085703].
Cocco G, Kohn S, Sfrisi C. Comparison of the effects of cilazapril and of the combination of cilazapril plus valsartan in patients with advanced heart failure. Heartdrug. 2002;2(6):286-94. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Cocco G, Chu D. Weight reduction decreases NT-proBNP levels in obsese coronary patients with chronic diastolic heart failure. Arch Med Sci. 2007;3(2):112-6. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Cochet A, Zeller M, Cottin Y, et al. The extent of myocardial damage assessed by contrast-enhanced MRI is a major determinant of N-BNP concentration after myocardial infarction. Eur J Heart Fail. Aug. 2004;6(5):555-60. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 15302002].
Codognotto M, Piccoli A, Zaninotto M, et al. Cystatin C in heart failure is nothing more than a bystander of glomerular filtration. J Nephrol. Mar. 2007;20(2):219-27. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17514627].
Codognotto M, Piccoli A, Zaninotto M, et al. Evidence for decreased circulating apelin beyond heart involvement in uremic cardiomyopathy. Am J Nephrol. 2007;27(1):1-6. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17204831].
Codognotto M, Piccoli A, Zaninotto M, et al. Renal dysfunction is a confounder for plasma natriuretic peptides in detecting heart dysfunction in uremic and idiopathic dilated cardiomyopathies. Clin Chem. Dec. 2007;53(12):2097-104. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17934072].
Codognotto M, Piccoli A, Rubini C, et al. Determinants of circulating asymmetric and symmetric dimethylarginines in patients evaluated for acute dyspnea. Clin Chem Lab Med. Feb. 2011;49(2):237-42. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21077789].
Cohn JN. Lessons learned from the Valsartan- Heart Failure Trial (Val-HeFT): Angiotensin receptor blockers in heart failure. Am J Cardiol. 2002;90(9):992-3. Exclude: Not a primary study. [pmid: 12398968].
Cohn JN, Tam SW, Anand IS, et al. Isosorbide dinitrate and hydralazine in a fixed-dose combination produces further regression of left ventricular remodeling in a well-treated black population with heart failure: Results from A-HeFT. J Card Fail. Jun. 2007;13(5):331-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17602978].
Collier PW. Can emerging biomarkers of myocardial remodelling identify asymptomatic hypertensive patients at risk for diastolic dysfunction and diastolic heart failure?. Eur J Heart Fail. 2011;13(10):1087-95. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21719449].
Collins SP, Lindsell CJ, Peacock WF, et al. Clinical characteristics of emergency department heart failure patients initially diagnosed as non-heart failure. BMC Emerg Med. 2006;6:11. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17105668].
Collins SP, Lindsell CJ, Kontos MC, et al. Bedside prediction of increased filling pressure using acoustic electrocardiography. Am J Emerg Med. May. 2009;27(4):397-408. Exclude: BNP measure not FDA approved. [pmid: 19555608].
Colucci WS, Elkayam U, Horton DP, et al. Intravenous nesiritide, a natriuretic peptide, in the treatment of decompensated congestive heart failure. Nesiritide Study Group. N Engl J Med. Jul. 27. 2000;343(4):246-53. Exclude: BNP measure not FDA approved. [pmid: 10911006].
Colucci WS, Kolias TJ, Adams KF, et al. Metoprolol reverses left ventricular remodeling in patients with asymptomatic systolic dysfunction: The REversal of VEntricular Remodeling with Toprol-XL (REVERT) trial. Circ. Jul. 3. 2007;116(1):49-56. Exclude: BNP measure not FDA approved.
Comin-Colet J, Ruiz S, Cladellas M, et al. A pilot evaluation of the long-term effect of combined therapy with intravenous iron sucrose and erythropoietin in elderly patients with advanced chronic heart failure and cardio-renal anemia syndrome: Influence on neurohormonal activation and clinical outcomes. J Card Fail. Nov. 2009;15(9):727-35. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19879457].
Conen D, Pfisterer M, Martina B. Substantial intraindividual variability of BNP concentrations in patients with hypertension. J Hum Hypertens. Jun. 2006;20(6):387-91. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16484992].
Conen D, Zeller A, Pfisterer M, et al. Usefulness of B-type natriuretic peptide and C-reactive protein in predicting the presence or absence of left ventricular hypertrophy in patients with systemic hypertension. Am J Cardiol. Jan. 15. 2006;97(2):249-52. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16442372].
Conlon CM, Dawkins I, O'Loughlin C, et al. B-type natriuretic peptide measurement in primary care; magnitude of associations with cardiovascular risk factors and their therapies. Observations from the STOP-HF (St. Vincent's Screening TO Prevent Heart Failure) study. Clin Chem Lab Med. Apr. 2011;49(4):719-28. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21275814].
Conraads VM, Beckers P, Vaes J, et al. Combined endurance/resistance training reduces NT-proBNP levels in patients with chronic heart failure. Eur Heart J. Oct. 2004;25(20):1797-805. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 15474694].
Conraads VM, Vanderheyden M, Paelinck B, et al. The effect of endurance training on exercise capacity following cardiac resynchronization therapy in chronic heart failure patients: A pilot trial. Eur J Cardiovasc Prev Rehabil. Feb. 2007;14(1):99-106. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17301634].
Conraads VM, De Maeyer C, Beckers P, et al. Exercise-induced biphasic increase in circulating NT-proBNP levels in patients with chronic heart failure. Eur J Heart Fail. Aug. 2008;10(8):793-5. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18599343].
Conraads VM, Metra M, Kamp O, et al. Effects of the long-term administration of nebivolol on the clinical symptoms, exercise capacity, and left ventricular function of patients with diastolic dysfunction: Results of the ELANDD study. Eur J Heart Fail. Feb. 2012;14(2):219-25. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 22147202].
Coppola G, Corrado E, Mule MC, et al. Analysis of N-terminal pro-B-type natriuretic peptide in patients with acute coronary syndromes. Coron Artery Dis. May. 2009;20(3):225-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19387249].
Coppola G, Corrado E, Augugliaro S, et al. Short term prognostic role of NT-proBNP in patients after myocardial infarction. Minerva Cardioangiol. Feb. 2009;57(1):13-21. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19202516].
Coquet I, Darmon M, Doise JM, et al. Performance of N-terminal-pro-B-type natriuretic peptide in critically ill patients: A prospective observational cohort study. Crit Care. 2008;12(6):R137. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18990203].
Corte TJ, Wort SJ, Gatzoulis MA, et al. Elevated brain natriuretic peptide predicts mortality in interstitial lung disease. Eur Respir J. 2010;36(4):819-25. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20223915].
Cortes R, Portoles M, Salvador A, et al. Diagnostic and prognostic value of urine NT-proBNP levels in heart failure patients. Eur J Heart Fail. Oct. 2006;8(6):621-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16504578].
Cortes R, Rivera M, Salvador A, et al. Variability of NT-proBNP plasma and urine levels in patients with stable heart failure: a 2-year follow-up study. Heart. Aug. 2007;93(8):957-62. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17488774].
Cortes R, Otero MR, Morillas P, et al. Obese and nonobese patients with essential hypertension show similar N-terminal proBNP plasma levels. Am J Hypertens. Jul. 2008;21(7):820-5. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18443568].
Cortes R, Portoles M, Rosello-Lleti E, et al. Impact of glomerular filtration rate on urinary BNP and NT-proBNP levels in heart failure. Peptides. Feb. 2012;33(2):354-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 22281024].
Corteville DC, Bibbins-Domingo K, Wu AH, et al. N-terminal pro-B-type natriuretic peptide as a diagnostic test for ventricular dysfunction in patients with coronary disease: Data from the heart and soul study. Arch Intern Med. Mar. 12. 2007;167(5):483-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17353496].
Cosgrave J, Foley JB, McGovern E, et al. Institutional report - Arrhythmia: Brain natriuretic peptide elevation and the development of atrial fibrillation following coronary artery bypass surgery. Interact Cardiovasc Thorac Surg. 2006;5(2):111-4. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17670529].
Cosson E, Nguyen MT, Pham I, et al. N-terminal pro-B-type natriuretic peptide: An independent marker for coronary artery disease in asymptomatic diabetic patients. Diabet Med. Sep. 2009;26(9):872-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19719707].
Costa APR, de Paula RCS, Carvalho GF, et al. High sodium intake adversely affects oxidative-inflammatory response, cardiac remodelling and mortality after myocardial infarction. Atherosclerosis. 2012;222(1):284-91. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 22436606].
Costanzo MR, Saltzberg M, O'Sullivan J, et al. Early ultrafiltration in patients with decompensated heart failure and diuretic resistance. J Am Coll Cardiol. 2005;46(11):2047-51. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16325040].
Costello-Boerrigter LC, Boerrigter G, Redfield MM, et al. Amino-terminal pro-B-type natriuretic peptide and B-type natriuretic peptide in the general community: Determinants and detection of left ventricular dysfunction. J Am Coll Cardiol. Jan. 17. 2006;47(2):345-53. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16412859].
Cotter G, Kaluski E, Stangl K, et al. The hemodynamic and neurohormonal effects of low doses of tezosentan (an endothelin A/B receptor antagonist) in patients with acute heart failure. Eur J Heart Fail. Aug. 2004;6(5):601-9. Exclude: BNP measure not FDA approved. [pmid: 15302008].
Cowie MR, Struthers AD, Wood DA, et al. Value of natriuretic peptides in assessment of patients with possible new heart failure in primary care. Lancet. Nov. 8. 1997;350(9088):1349-53. Exclude: BNP measure not FDA approved. [pmid: 9365448].
Cowley CG, Bradley JD, Shaddy RE. B-type natriuretic peptide levels in congenital heart disease. Pediatr Cardiol. Jul. 2004;25(4):336-40. Exclude: Population aged under 18. [pmid: 14735252].
Crilley JG, Farrer M. Left ventricular remodelling and brain natriuretic peptide after first myocardial infarction. Heart. Dec. 2001;86(6):638-42. Exclude: BNP measure not FDA approved. [pmid: 11711456].
Crowson CS, Myasoedova E, Davis JM III. Use of B-type natriuretic peptide as a screening tool for left ventricular diastolic dysfunction in rheumatoid arthritis patients without clinical cardiovascular disease. Arthritis Care Res. May. 2011;63(5):729-34. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Cuculi F, Walz B, Zuber M, et al. Clinical correlates of very high brain natriuretic peptide levels in hospitalized patients. Am Heart Hosp J. 2008;6(1):37-41. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18256556].
Cuppoletti A, Roig E, Perez-Villa F, et al. Value of NT-proBNP determinations in the follow-up of heart transplantation. Transplant Proc. Nov. 2005;37(9):4033-5. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16386619].
Cuthbertson BH, Patel RR, Croal BL, et al. B-type natriuretic peptide and the prediction of outcome in patients admitted to intensive care. Anaesthesia. Jan. 2005;60(1):16-21. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 15601267].
Cuthbertson BH, Amiri AR, Croal BL, et al. Utility of B-type natriuretic peptide in predicting medium-term mortality in patients undergoing major non-cardiac surgery. Am J Cardiol. Oct. 15. 2007;100(8):1310-3. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17920377].
Cuthbertson BH, Croal BL, Rae D, et al. N-terminal pro-B-type natriuretic peptide levels and early outcome after cardiac surgery: A prospective cohort study. Br J Anaesth. Nov. 2009;103(5):647-53. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19713279].
Cygankiewicz I, Zareba W, Vazquez R, et al. Relation of heart rate turbulence to severity of heart failure. Am J Cardiol. 2006;98(12):1635-40. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17145225].
Czucz J, Cervenak L, Forhecz Z, et al. Serum soluble E-selectin and NT-proBNP levels additively predict mortality in diabetic patients with chronic heart failure. Clin Res Cardiol. Jul. 2011;100(7):587-94. Exclude: BNP measure not FDA approved. [pmid: 21311898].
D'Alto M. Brain natriuretic peptide, survival and response to targeting therapy: Another piece in the complex puzzle of Eisenmenger syndrome. Heart. 2012;98(9):681-2. Exclude: Not a primary study. [pmid: 22523053].
Dabrowski R, Borowiec A, Janas J, et al. High concentrations of B-type natriuretic peptide and left ventricular diastolic dysfunction in patients with paroxysmal/persistent atrial fibrillation as possible markers of conversion into permanent form of arrhythmia: 1-year prospective evaluation. Kardiol Pol. Aug. 2010;68(8):893-900. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20730719].
Daggubati S, Parks JR, Overton RM, et al. Adrenomedullin, endothelin, neuropeptide Y, atrial, brain, and C-natriuretic prohormone peptides compared as early heart failure indicators. Cardiovasc Res. Nov. 1997;36(2):246-55. Exclude: BNP measure not FDA approved. [pmid: 9463636].
Dal Bianco JP, Jaffe AS, Bell MR, et al. Cardiac function and brain-type natriuretic peptide in first-time flash pulmonary edema. Mayo Clin Proc. Mar. 2008;83(3):289-96. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18315994].
Daly MJ, Monaghan M, Hamilton A, et al. Short-term efficacy of palliative balloon aortic valvuloplasty in selected patients with high operative risk. J Invasive Cardiol. Feb. 2012;24(2):58-62. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 22294534].
Damgaard M, Norsk P, Gustafsson F, et al. Hemodynamic and neuroendocrine responses to changes in sodium intake in compensated heart failure. Am J Physiol Regul Integr Comp Physiol. 2006;290(5):R1294-301. Exclude: BNP measure not FDA approved. [pmid: 16357094].
Damgaard M, Goetze JP, Norsk P, et al. Altered sodium intake affects plasma concentrations of BNP but not proBNP in healthy individuals and patients with compensated heart failure. Eur Heart J. Nov. 2007;28(22):2726-31. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17942579].
Damman K, van Veldhuisen DJ, Navis G, et al. Urinary neutrophil gelatinase associated lipocalin (NGAL), a marker of tubular damage, is increased in patients with chronic heart failure. Eur J Heart Fail. Oct. 2008;10(10):997-1000. Exclude: BNP measure not FDA approved. [pmid: 18804416].
Damman K, van Veldhuisen DJ, Navis G, et al. Tubular damage in chronic systolic heart failure is associated with reduced survival independent of glomerular filtration rate. Heart. 2010;96(16):1297-302. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20659949].
Damman K, Ng Kam Chuen MJ, MacFadyen RJ, et al. Volume status and diuretic therapy in systolic heart failure and the detection of early abnormalities in renal and tubular function. J Am Coll Cardiol. May. 31. 2011;57(22):2233-41. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21616283].
Damy T, Viallet C, Lairez O, et al. Comparison of four right ventricular systolic echocardiographic parameters to predict adverse outcomes in chronic heart failure. Eur J Heart Fail. Sep. 2009;11(9):818-24. Exclude: BNP measure not FDA approved. [pmid: 19696055].
Damy T, Goode KM, Kallvikbacka-Bennett A, et al. Determinants and prognostic value of pulmonary arterial pressure in patients with chronic heart failure. Eur Heart J. 2010;31(18):2280-90. Exclude: BNP measure not FDA approved. [pmid: 20693169].
Damy T, Kallvikbacka-Bennett A, Goode K, et al. Prevalence of, associations with, and prognostic value of tricuspid annular plane systolic excursion (TAPSE) among out-patients referred for the evaluation of heart failure. J Card Fail. 2012;18(3):216-25. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 22385942].
Daniels LB, Bhalla V, Clopton P, et al. B-type natriuretic peptide (BNP) levels and ethnic disparities in perceived severity of heart failure: Results from the Rapid Emergency Department Heart Failure Outpatient Trial (REDHOT) multicenter study of BNP levels and emergency department decision making in patients presenting with shortness of breath. J Card Fail. May. 2006;12(4):281-5. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16679261].
Daniels LB, Clopton P, Iqbal N, et al. Association of ST2 levels with cardiac structure and function and mortality in outpatients. Am Heart J. 2010;160(4):721-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20934567].
Daniels LB, Clopton P, Jiang K, et al. Prognosis of stage A or B heart failure patients with elevated B-type natriuretic peptide levels. J Card Fail. Feb. 2010;16(2):93-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20142019].
Darbar D, Davidson NC, Gillespie N, et al. Diagnostic value of B-type natriuretic peptide concentrations in patients with acute myocardial infarction. Am J Cardiol. Aug. 1. 1996;78(3):284-7. Exclude: BNP measure not FDA approved. [pmid: 8759805].
Das SR, Drazner MH, Dries DL, et al. Impact of body mass and body composition on circulating levels of natriuretic peptides: Results from the Dallas Heart Study. Circ. Oct. 4. 2005;112(14):2163-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Das SR, Abdullah SM, Leonard D, et al. Association between renal function and circulating levels of natriuretic peptides (from the Dallas Heart Study). Am J Cardiol. Nov. 15. 2008;102(10):1394-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18993162].
Date T, Yamane T, Yamashita S, et al. Paradoxical clearance of natriuretic peptide between pulmonary and systemic circulation: A pulmonary mechanism of maintaining natriuretic peptide plasma concentration in obese individuals. J Clin Endocrinol Metab. 2012;97(1):E14-E21. Exclude: BNP measure not FDA approved. [pmid: 22049176].
Daugaard G, Lassen U, Bie P, et al. Natriuretic peptides in the monitoring of anthracycline induced reduction in left ventricular ejection fraction. Eur J Heart Fail. Jan. 2005;7(1):87-93. Exclude: BNP measure not FDA approved. [pmid: 15642537].
Dauphin R, Nonin E, Bontemps L, et al. Quantification of ventricular resynchronization reserve by radionuclide phase analysis in heart failure patients: A prospective long-term study. Circ. Mar. 1. Cardiovascular imaging. 2011;4(2):114-21. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Dautin G, Boudjeltia S, Soltani Z, et al. The changes in NT-proBNP plasma concentrations during dialysis are highly dependent of the dialysis membrane ultrafiltration coefficient. Clin Chim Acta. Feb. 2007;376(1-2):237-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16979612].
David S, Kumpers P, Seidler V, et al. Diagnostic value of N-terminal pro-B-type natriuretic peptide (NT-proBNP) for left ventricular dysfunction in patients with chronic kidney disease stage 5 on haemodialysis. Nephrol Dial Transplant. Apr. 2008;23(4):1370-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18089624].
Davidson NC, Naas AA, Hanson JK, et al. Comparison of atrial natriuretic peptide B-type natriuretic peptide, and N-terminal proatrial natriuretic peptide as indicators of left ventricular systolic dysfunction. Am J Cardiol. Apr. 15. 1996;77(10):828-31. Exclude: BNP measure not FDA approved. [pmid: 8623734].
Davidson NC, Coutie WJ, Webb DJ, et al. Hormonal and renal differences between low dose and high dose angiotensin converting enzyme inhibitor treatment in patients with chronic heart failure. Heart. Jun. 1996;75(6):576-81. Exclude: BNP measure not FDA approved. [pmid: 8697160].
Davis JMK III. A signature of aberrant immune responsiveness identifies myocardial dysfunction in rheumatoid arthritis. Arthritis Rheum. 2011;63(6):1497-506. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21384332].
Davis M, Espiner E, Richards G, et al. Plasma brain natriuretic peptide in assessment of acute dyspnoea. Lancet. Feb. 1994;343(8895):440-4. Exclude: BNP measure not FDA approved. [pmid: 7905953].
Davis ME, Richards AM, Nicholls MG, et al. Introduction of metoprolol increases plasma B-type cardiac natriuretic peptides in mild, stable heart failure. Circ. Feb. 21. 2006;113(7):977-85. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Dawson A, Davies JI, Morris AD, et al. B-type natriuretic Peptide is associated with both augmentation index and left ventricular mass in diabetic patients without heart failure. Am J Hypertens. Dec. 2005;18(12:Pt 1):1586-91. Exclude: BNP measure not FDA approved. [pmid: 16364830].
De Boeck BW, Teske AJ, Meine M, et al. Septal rebound stretch reflects the functional substrate to cardiac resynchronization therapy and predicts volumetric and neurohormonal response. Eur J Heart Fail. Sep. 2009;11(9):863-71. Exclude: BNP measure not FDA approved. [pmid: 19696058].
de Boer RA, Henning RH, Suurmeijer AJ, et al. Early expression of natriuretic peptides and SERCA in mild heart failure: Association with severity of the disease. Int J Cardiol. Mar. 2001;78(1):5-12. Exclude: BNP measure not FDA approved. [pmid: 11259807].
de Boer RA, Lok DJA, Jaarsma T, et al. Predictive value of plasma galectin-3 levels in heart failure with reduced and preserved ejection fraction. Ann Med. 2011;43(1):60-8. Exclude: BNP measure not FDA approved. [pmid: 21189092].
de Denus S, Zakrzewski-Jakubiak M, Dube MP, et al. Effects of AGTR1 A1166C gene polymorphism in patients with heart failure treated with candesartan. Ann Pharmacother. Jul. 2008;42(7):925-32. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18594050].
de Feo ML, La Villa G, Lazzeri C, et al. Urinary endothelin-1 excretion is enhanced by low-dose infusion of brain natriuretic peptide in normal humans. Hypertens. Jan. 1997;29(1 Pt 1):70-4. Exclude: BNP measure not FDA approved.
De Gennaro L, Brunetti ND, Bungaro R, et al. Carbohydrate antigen-125: Additional accuracy in identifying patients at risk of acute heart failure in acute coronary syndrome. Coron Artery Dis. Jun. 2009;20(4):274-80. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19440066].
De Greef J, Govender R, Vermaak W, et al. Does dipyridamole-induced ischaemia affect NT-proBNP secretion?. Cardiovasc J Afr. Nov. 2007;18(6):371-4. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18092112].
De Greef J, Funk M, Vermaak WJ, et al. NT-proBNP and the diagnosis of exercise-induced myocardial ischaemia. Cardiovasc J Afr. Sep. 2008;19(5):264-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18997988].
de Groote P, Dagorn J, Soudan B, et al. B-type natriuretic peptide and peak exercise oxygen consumption provide independent information for risk stratification in patients with stable congestive heart failure. J Am Coll Cardiol. May. 5. 2004;43(9):1584-9. Exclude: BNP measure not FDA approved. [pmid: 15120815].
de Groote P, Delour P, Lamblin N, et al. Effects of bisoprolol in patients with stable congestive heart failure. Ann Cardiol Angeiol. 2004;53(4):167-70. Exclude: BNP measure not FDA approved.
de Groote P, Soudan B, Lamblin N, et al. Is hormonal activation during exercise useful for risk stratification in patients with moderate congestive heart failure?. Am Heart J. Aug. 2004;148(2):349-55. Exclude: BNP measure not FDA approved. [pmid: 15309008].
de Jong RM, Blanksma PK, Cornel JH, et al. Endothelial dysfunction and reduced myocardial perfusion reserve in heart failure secondary to coronary artery disease. Am J Cardiol. Feb. 15. 2003;91(4):497-500. Exclude: BNP measure not FDA approved. [pmid: 12586279].
de Lemos JA, Morrow DA, Bentley JH, et al. The prognostic value of B-type natriuretic peptide in patients with acute coronary syndromes. N Engl J Med. Oct. 4. 2001;345(14):1014-21. Exclude: BNP measure not FDA approved. [pmid: 11586953].
de Lemos JA, Morrow DA, Blazing MA, et al. Serial measurement of monocyte chemoattractant protein-1 after acute coronary syndromes. Results from the A to Z Trial. J Am Coll Cardiol. 2007;50(22):2117-24. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18036447].
de Lemos JA, McGuire DK, Khera A, et al. Screening the population for left ventricular hypertrophy and left ventricular systolic dysfunction using natriuretic peptides: Results from the Dallas Heart Study. Am Heart J. Apr. 2009;157(4):746-53. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19332205].
de Lemos JA, Drazner MH, Omland T, et al. Association of troponin T detected with a highly sensitive assay and cardiac structure and mortality risk in the general population. JAMA. Dec. 8. 2010;304(22):2503-12. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21139111].
De Pasquale CG, Arnolda LF, Doyle IR, et al. Plasma surfactant protein-B: A novel biomarker in chronic heart failure. Circ. Aug. 31. 2004;110(9):1091-6. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
De Sutter J, De Bacquer D, Cuypers S, et al. Plasma N-terminal pro-brain natriuretic peptide concentration predicts coronary events in men at work: A report from the BELSTRESS study. Eur Heart J. Dec. 2005;26(24):2644-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16204267].
de Teresa E, Gomez-Doblas JJ, Lamas G, et al. Preventing ventricular dysfunction in pacemaker patients without advanced heart failure: Rationale and design of the PREVENT-HF study. Europace. Jun. 2007;9(6):442-6. Exclude: Not a primary study. [pmid: 17460018].
De Vecchis RC. Renoprotective effect of small volumes of hypertonic saline solution in chronic heart failure patients with marked fluid retention: Results of a case-control study. Herz. 2011;36(1):12-6. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20978728].
de Winter RJ, Stroobants A, Koch KT, et al. Plasma N-terminal pro-B-type natriuretic peptide for prediction of death or nonfatal myocardial infarction following percutaneous coronary intervention. Am J Cardiol. Dec. 15. 2004;94(12):1481-5. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 15589000].
de DS, Lavoie J, Ducharme A, et al. Differences in biomarkers in patients with heart failure with a reduced vs a preserved left ventricular ejection fraction. Can J Cardiol. Jan. 2012;28(1):62-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 22104539].
de SG, Chinali M, Mureddu GF, et al. Effect of canrenone on left ventricular mechanics in patients with mild systolic heart failure and metabolic syndrome: The AREA-in-CHF study. Nutr Metab Cardiovasc Dis. Oct. 2011;21(10):783-91. Exclude: BNP measure not FDA approved. [pmid: 21939839].
de SJ, van de Veire NR, Struyf S, et al. PF-4var/CXCL4L1 predicts outcome in stable coronary artery disease patients with preserved left ventricular function. PLoS ONE. 2012;7(2). Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Deffur A, Ker JA, Rheeder P, et al. NT-proBNP measurements in high-risk diabetic patients--A case series from Mamelodi (Gauteng). Cardiovasc J S Afr. Mar. 2006;17(2):56-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16733597].
deFilippi CR, Fink JC, Nass CM, et al. N-terminal pro-B-type natriuretic peptide for predicting coronary disease and left ventricular hypertrophy in asymptomatic CKD not requiring dialysis. Am J Kidney Dis. Jul. 2005;46(1):35-44. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 15983955].
deFilippi CR, Christenson RH, Gottdiener JS, et al. Dynamic cardiovascular risk assessment in elderly people. The role of repeated N-terminal pro-B-type natriuretic peptide testing. J Am Coll Cardiol. Feb. 2. 2010;55(5):441-50. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20117457].
deFilippi CR, Christenson RH, Kop WJ, et al. Left ventricular ejection fraction assessment in older adults: An adjunct to natriuretic peptide testing to identify risk of new-onset heart failure and cardiovascular death?. J Am Coll Cardiol. Sep. 27. 2011;58(14):1497-506. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21939835].
Deftereos S, Giannopoulos G, Kossyvakis C, et al. Short-term fluctuations of plasma NT-proBNP levels in patients with new-onset atrial fibrillation: A way to assess time of onset?. Heart. Jul. 2010;96(13):1033-6. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20483904].
Deftereos S, Giannopoulos G, Kossyvakis C, et al. Estimation of atrial fibrillation recency of onset and safety of cardioversion using NTproBNP levels in patients with unknown time of onset. Heart. Jun. 2011;97(11):914-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21303795].
Del Greco MF, Pattaro C, Luchner A, et al. Genome-wide association analysis and fine mapping of NT-proBNP level provide novel insight into the role of the MTHFR-CLCN6-NPPA-NPPB gene cluster. Hum Mol Genet. Apr. 15. 2011;20(8):1660-71. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21273288].
Del Ry S, Giannessi D, Maltinti M, et al. Increased levels of C-type natriuretic peptide in patients with idiopathic left ventricular dysfunction. Peptides. 2007;28(5):1068-73. Exclude: BNP measure not FDA approved. [pmid: 17428580].
Delagardelle C, Feiereisen P, Vaillant M, et al. Reverse remodelling through exercise training is more pronounced in non-ischemic heart failure. Clin Res Cardiol. Dec. 2008;97(12):865-71. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18696023].
Delgado RM, Palanichamy N, Radovancevic R, et al. Brain natriuretic peptide levels and response to cardiac resynchronization therapy in heart failure patients. Congest Heart Fail. Sep. 2006;12(5):250-3. Exclude: BNP measure not FDA approved. [pmid: 17033272].
Dell'Era G, Rondano E, Franchi E, et al. Atrial asynchrony and function before and after electrical cardioversion for persistent atrial fibrillation. Eur J Echocardiogr. Aug. 2010;11(7):577-83. Exclude: BNP measure not FDA approved. [pmid: 20400765].
Delnoy PP, Ottervanger JP, Luttikhuis HO, et al. Sustained benefit of cardiac resynchronization therapy. J Cardiovasc Electrophysiol. Mar. 2007;18(3):298-302. Exclude: BNP measure not FDA approved. [pmid: 17284263].
Dencker M, Stagmo M, Dorkhan M. Relationship between natriuretic peptides and echocardiography parameters in patients with poorly regulated type 2 diabetes. Vasc Health Risk Manag. 2010;6:373-82. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20539839].
Derzhko R, Plaksej R, Przewlocka-Kosmala M, et al. Prediction of left ventricular dysfunction progression in patients with a first ST-elevation myocardial infarction--Contribution of cystatin C assessment. Coron Artery Dis. Nov. 2009;20(7):453-61. Exclude: BNP measure not FDA approved. [pmid: 19741512].
Desai AS, Bibbins-Domingo K, Shlipak MG, et al. Association between anaemia and N-terminal pro-B-type natriuretic peptide (NT-proBNP): Findings from the Heart and Soul Study. Eur J Heart Fail. Sep. 2007;9(9):886-91. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17627881].
Detaint D, Messika-Zeitoun D, Avierinos JF, et al. B-type natriuretic peptide in organic mitral regurgitation: Determinants and impact on outcome. Circ. May. 10. 2005;111(18):2391-7. Exclude: BNP measure not FDA approved.
Dev S, Clare RM, Felker GM, et al. Link between decisions regarding resuscitation and preferences for quality over length of life with heart failure. Eur J Heart Fail. 2012;14(1):45-53. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 22037389].
Dhakam Z, Yasmin, McEniery CM, et al. A comparison of atenolol and nebivolol in isolated systolic hypertension. J Hypertens. Feb. 2008;26(2):351-6. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18192850].
Dhand S, Gozu A, Zolet D. Influence of diabetes and hyperglycemia on duration of stay in patients hospitalized with congestive heart failure. Endocr Pract. 2008;14(6):691-6. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18996787].
Dhillon OS, Khan SQ, Narayan HK, et al. Matrix metalloproteinase-2 predicts mortality in patients with acute coronary syndrome. Clin Sci. Feb. 2010;118(4):249-57. Exclude: BNP measure not FDA approved. [pmid: 19583569].
Dhillon OS, Khan SQ, Narayan HK, et al. Prognostic value of mid-regional pro-adrenomedullin levels taken on admission and discharge in non-ST-elevation myocardial infarction: The LAMP (Leicester Acute Myocardial Infarction Peptide) II study. J Am Coll Cardiol. Jul. 6. 2010;56(2):125-33. Exclude: BNP measure not FDA approved. [pmid: 20620726].
Dhillon OS, Narayan HK, Quinn PA, et al. Interleukin 33 and ST2 in non-ST-elevation myocardial infarction: Comparison with Global Registry of Acute Coronary Events Risk Scoring and NT-proBNP. Am Heart J. Jun. 2011;161(6):1163-70. Exclude: BNP measure not FDA approved. [pmid: 21641364].
Di Angelantonio E, De Castro S, Toni D, et al. Determinants of plasma levels of brain natriuretic peptide after acute ischemic stroke or TIA. J Neurol Sci. Sep. 15. 2007;260(1-2):139-42. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17512951].
Di Napoli P, Di Giovanni P, Gaeta MA, et al. Beneficial effects of trimetazidine treatment on exercise tolerance and B-type natriuretic peptide and troponin T plasma levels in patients with stable ischemic cardiomyopathy. Am Heart J. Sep. 2007;154(3):602-5. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17719313].
Di Somma S, Magrini L, Mazzone M, et al. Decrease in NTproBNP plasma levels indicates clinical improvement of acute decompensated heart failure. Am J Emerg Med. Mar. 2007;25(3):335-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17349910].
Di Somma S, Magrini L, Tabacco F, et al. Brain natriuretic peptide and N-terminal pro-B-type natriuretic peptide show a different profile in response to acute decompensated heart failure treatment. Congest Heart Fail. Sep. 2008;14(5):245-50. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18983287].
Di Somma S, De Berardinis B, Bongiovanni C, et al. Use of BNP and bioimpedance to drive therapy in heart failure patients. Congest Heart Fail. 2010;16(Suppl 1):S56-61. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20653713].
Di Stefano S, Casquero E, Bustamante R, et al. Analysis of inflammatory response and utility of N-terminal pro brain-type natriuretic peptide in cardiac surgery with extracorporeal circulation. J Cardiovasc Med. Jun. 2008;9(6):555-60. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Dias P, Rodrigues RA, Queiros MC, et al. Prognosis in patients with heart failure and preserved left ventricular systolic function. Rev Port Cardiol. Dec. 2001;20(12):1223-32. Exclude: BNP measure not FDA approved. [pmid: 11865682].
Diederichsen AC, Moller JE, Thayssen P, et al. Changes in left ventricular filling patterns after repeated injection of autologous bone marrow cells in heart failure patients. Scand Cardiovasc J. Jun. 2010;44(3):139-45. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20233136].
Dieplinger B, Gegenhuber A, Struck J, et al. Chromogranin A and C-terminal endothelin-1 precursor fragment add independent prognostic information to amino-terminal proBNP in patients with acute destabilized heart failure. Clin Chim Acta. Feb. 2009;400(1-2):91-6. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19000665].
Dieplinger B, Haltmayer M, Poelz W, et al. Value of adiponectin as predictor of 5-year all-cause mortality in patients with symptomatic peripheral arterial disease: Results from the Linz Peripheral Arterial Disease (LIPAD) study. Clin Chim Acta. Oct. 2009;408(1-2):87-91. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19646980].
Dieplinger B, Gegenhuber A, Kaar G, et al. Prognostic value of established and novel biomarkers in patients with shortness of breath attending an emergency department. Clin Biochem. Jun. 2010;43(9):714-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20153308].
Dieplinger B, Egger M, Koehler W, et al. Prognostic value of soluble ST2 in an unselected cohort of patients admitted to an intensive care unit - The Linz Intensive Care Unit (LICU) study. Clin Chim Acta. Mar. 22. 2012;413(5-6):587-93. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 22155704].
Diercks DB, Owen K, Tolstikov V, et al. Urinary metabolomic analysis for the identification of renal injury in patients with acute heart failure. Acad Emerg Med. Jan. 2012;19(1):18-23. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 22222043].
Diller GP, van Eijl S, Okonko DO, et al. Circulating endothelial progenitor cells in patients with Eisenmenger syndrome and idiopathic pulmonary arterial hypertension. Circ. Jun. 10. 2008;117(23):3020-30. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Dillinger JG, Deye N, Logeart D, et al. Prognostic value of plasma B-type natriuretic peptide in patients with severe cardiotoxic drug poisoning. Acute Card Care. Sep. 2011;13(3):174-80. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21877877].
Dimitroulas T, Giannakoulas G, Karvounis H, et al. Neurohormonal activation in patients with systemic sclerosis-related pulmonary arterial hypertension. Int J Cardiol. Sep. 14. 2007;121(1):135-7. Exclude: BNP measure not FDA approved. [pmid: 17088004].
Dimitroulas T, Giannakoulas G, Papadopoulou K, et al. Early detection of cardiac involvement in systemic sclerosis assessed by tissue-Doppler echocardiography: Relationship with neurohormonal activation and endothelial dysfunction. J Rheumatol. May. 2010;37(5):993-9. Exclude: BNP measure not FDA approved. [pmid: 20194451].
Dimitroulas T, Giannakoulas G, Papadopoulou K, et al. Left atrial volume and N-terminal pro-B type natriuretic peptide are associated with elevated pulmonary artery pressure in patients with systemic sclerosis. Clin Rheumatol. Sep. 2010;29(9):957-64. Exclude: BNP measure not FDA approved. [pmid: 20526641].
Ding LG, Hua W, Zhang S, et al. Decrease of plasma N-terminal pro beta-type natriuretic peptide as a predictor of clinical improvement after cardiac resynchronization therapy for heart failure. Chin Med J. Mar. 20. 2009;122(6):617-21. Exclude: BNP measure not FDA approved. [pmid: 19323922].
Dingli D, Tan TS, Kumar SK, et al. Stem cell transplantation in patients with autonomic neuropathy due to primary (AL) amyloidosis. Neurology. Mar. 16. 2010;74(11):913-8. Exclude: BNP measure not FDA approved. [pmid: 20231668].
Dinh W, Futh R, Nickl W, et al. Elevated plasma levels of TNF-alpha and interleukin-6 in patients with diastolic dysfunction and glucose metabolism disorders. Cardiovasc Diabetol. 2009;8:58. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19909503].
Dini FL, Conti U, Fontanive P, et al. Right ventricular dysfunction is a major predictor of outcome in patients with moderate to severe mitral regurgitation and left ventricular dysfunction. Am Heart J. Jul. 2007;154(1):172-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17584573].
Dini FL, Fontanive P, Conti U, et al. Plasma N-terminal protype-B natriuretic peptide levels in risk assessment of patients with mitral regurgitation secondary to ischemic and nonischemic dilated cardiomyopathy. Am Heart J. Jun. 2008;155(6):1121-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18513528].
Dini FL, Whalley G, Poppe K, et al. Plasma N-terminal protype-B natriuretic peptide and restrictive mitral flow to risk-stratify patients with stage B heart failure. Clin Cardiol. Dec. 2009;32(12):711-7. Exclude: Population aged under 18. [pmid: 20027664].
Dini FL, Ghiadoni L, Conti U, et al. Coronary flow reserve in idiopathic dilated cardiomyopathy: Relation with left ventricular wall stress, natriuretic peptides, and endothelial dysfunction. J Am Soc Echocardiogr. Apr. 2009;22(4):354-60. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19269783].
Dixen U, Wallevik L, Hansen MS, et al. Prolonged signal-averaged P wave duration as a prognostic marker for morbidity and mortality in patients with congestive heart failure. Scand Cardiovasc J. Sep. 2003;37(4):193-8. Exclude: BNP measure not FDA approved. [pmid: 12944206].
Dixen U, Ravn L, Soeby-Rasmussen C, et al. Raised plasma aldosterone and natriuretic peptides in atrial fibrillation. Cardiol. 2007;108(1):35-9. Exclude: BNP measure not FDA approved.
Dockery F, Bulpitt CJ, Agarwal S, et al. Anti-androgens increase N-terminal pro-BNP levels in men with prostate cancer. Clin Endocrinol. 2008;68(1):59-65. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Dodge-Khatami A, Buchel EV, Knirsch W, et al. Brain natriuretic peptide and magnetic resonance imaging in tetralogy with right ventricular dilatation. Ann Thorac Surg. Sep. 2006;82(3):983-8. Exclude: Population aged under 18. [pmid: 16928520].
Dodos F, Halbsguth T, Erdmann E, et al. Usefulness of myocardial performance index and biochemical markers for early detection of anthracycline-induced cardiotoxicity in adults. Clin Res Cardiol. May. 2008;97(5):318-26. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18193371].
Doesch AO, Konstandin M, Celik S, et al. Effects of protein A immunoadsorption in patients with advanced chronic dilated cardiomyopathy. J Clin Apheresis. 2009;24(4):141-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19591221].
Doesch AO, Mueller S, Konstandin M, et al. Effects of protein A immunoadsorption in patients with chronic dilated cardiomyopathy. J Clin Apheresis. 2010;25(6):315-22. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20824621].
Doesch AOM. Effects of protein a immunoadsorption on methylglyoxal levels in patients with chronic dilated cardiomyopathy and diabetes mellitus. Appl Cardiopulm Pathophysiol. 2011;15(1):3-13. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Dogan SM, Aydin M, Gursurer M, et al. N-terminal probrain natriuretic peptide predicts altered circadian variation in essential hypertension. Coron Artery Dis. Aug. 2007;18(5):347-52. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17627183].
Dohi T, Kasai T, Narui K, et al. Bi-level positive airway pressure ventilation for treating heart failure with central sleep apnea that is unresponsive to continuous positive airway pressure. Circ J. Jul. 2008;72(7):1100-5. Exclude: BNP measure not FDA approved. [pmid: 18577818].
Dokainish H, Zoghbi WA, Lakkis NM, et al. Comparative accuracy of B-type natriuretic peptide and tissue Doppler echocardiography in the diagnosis of congestive heart failure. Am J Cardiol. May. 1. 2004;93(9):1130-5. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 15110205].
Dokainish H, Pillai M, Murphy SA, et al. Prognostic implications of elevated troponin in patients with suspected acute coronary syndrome but no critical epicardial coronary disease: A TACTICS-TIMI-18 substudy. J Am Coll Cardiol. Jan. 4. 2005;45(1):19-24. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 15629367].
Dokainish H, Gonzalez R, Hartley WB, et al. Usefulness of B-type natriuretic peptide levels to predict left ventricular filling pressures in patients with body mass index >35, 31 to 35, and < or =30 kg/m2. Am J Cardiol. Oct. 1. 2007;100(7):1166-71. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17884382].
Dominguez-Rodriguez A, Abreu-Gonzalez P, Avanzas P, et al. Neopterin predicts left ventricular remodeling in patients with ST-segment elevation myocardial infarction undergoing primary percutaneous coronary intervention. Atherosclerosis. Aug. 2010;211(2):574-8. Exclude: BNP measure not FDA approved. [pmid: 20451908].
Dominguez-Rodriguez A, A-G. Relation of growth-differentiation factor 15 to left ventricular remodeling in ST-segment elevation myocardial infarction. Am J Cardiol. 2011;108(7):955-8. Exclude: BNP measure not FDA approved. [pmid: 21784389].
Donal E, Roulaud M, Raud-Raynier P, et al. Echocardiographic right ventricular strain analysis in chronic heart failure. Eur J Echocardiogr. Dec. 2007;8(6):449-56. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16962377].
Dong SJ, de las FL, Brown AL, et al. N-terminal pro B-type natriuretic peptide levels: Correlation with echocardiographically determined left ventricular diastolic function in an ambulatory cohort. J Am Soc Echocardiogr. Aug. 2006;19(8):1017-25. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16880097].
Dong YX, Burnett JC Jr., Chen HH, et al. Effect of cardiac resynchronization therapy on broad neurohormone biomarkers in heart failure. J Interv Card Electrophysiol. Apr. 2011;30(3):241-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21336616].
Dore A, Houde C, Chan KL, et al. Angiotensin receptor blockade and exercise capacity in adults with systemic right ventricles: A multicenter, randomized, placebo-controlled clinical trial. Circ. Oct. 18. 2005;112(16):2411-6. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Dorkhan M, Dencker M, Stagmo M, et al. Effect of pioglitazone versus insulin glargine on cardiac size, function, and measures of fluid retention in patients with type 2 diabetes. Cardiovasc Diabetol. 2009;8:15. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19298680].
Dorobantu M, Fruntelata AG, Scafa-Udriste A, et al. B-Type Natriuretic Peptide (BNP) and Left Ventricular (LV) function in patients with ST-Segment Elevation Myocardial Infarction (STEMI). Medica. Dec. 2010;5(4):243-9. Exclude: BNP measure not FDA approved.
Dos Santos RR, Rassi S, Feitosa G, et al. Cell therapy in chagas cardiomyopathy (Chagas arm of the multicenter randomized trial of cell therapy in cardiopathies study): A multicenter randomized trial. Circ. 2012;125(20):2454-61. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Downie PF, Talwar S, Squire IB, et al. Assessment of the stability of N-terminal pro-brain natriuretic peptide in vitro: Implications for assessment of left ventricular dysfunction. Clin Sci. Sep. 1999;97(3):255-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 10464049].
Drakos SG, Athanasoulis T, Malliaras KG, et al. Myocardial sympathetic innervation and long-term left ventricular mechanical unloading. JACC Cardiovasc Imaging. Jan. 2010;3(1):64-70. Exclude: BNP measure not FDA approved. [pmid: 20129533].
Drechsler CM. Homoarginine, heart failure, and sudden cardiac death in haemodialysis patients. Eur J Heart Fail. 2011;13(8):852-9. Exclude: BNP measure not FDA approved. [pmid: 21791541].
Drexler B, Heinisch C, Balmelli C, et al. Quantifying cardiac hemodynamic stress and cardiomyocyte damage in ischemic and nonischemic acute heart failure. Circ. Jan. 1. 2012;5(1):17-24. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Dronavalli VB, Ranasinghe AM, Venkateswaran RJ, et al. N-terminal pro-brain-type natriuretic peptide: A biochemical surrogate of cardiac function in the potential heart donor. Eur J Cardiothorac Surg. 2010;38(2):181-6. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20181489].
Dschietzig T, Teichman S, Unemori E, et al. Intravenous recombinant human relaxin in compensated heart failure: A safety, tolerability, and pharmacodynamic trial. J Card Fail. Apr. 2009;15(3):182-90. Exclude: BNP measure not FDA approved. [pmid: 19327619].
Du XH, Liang FY, Zhao XW. Effects of phosphocreatine on plasma brain natriuretic peptide level in elderly patients with chronic congestive heart failure. J South Med Uni. 2011;29(1):154-5. Exclude: Not in English.
Duan HY, W X. Factors influencing recovery of left ventricular structure in patients with chronic heart failure. Chin Med J. 2011;124(18):2868-73. Exclude: BNP measure not FDA approved. [pmid: 22040494].
Dubiel M, Krolczyk J, Gasowski J, et al. Skin microcirculation and echocardiographic and biochemical indices of left ventricular dysfunction in non-diabetic patients with heart failure. Cardiol J. 2011;18(3):270-6. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21660916].
Duckelmann C, Mittermayer F, Haider DG, et al. Asymmetric dimethylarginine enhances cardiovascular risk prediction in patients with chronic heart failure. Arterioscler Thromb Vasc Biol. Sep. 2007;27(9):2037-42. Exclude: BNP measure not FDA approved. [pmid: 17569878].
Duckelmann C, Mittermayer F, Haider DG, et al. Plasma asymmetric dimethylarginine and cardiovascular events in patients with acute decompensated heart failure. Transl Res. Jul. 2008;152(1):24-30. Exclude: BNP measure not FDA approved. [pmid: 18593634].
Due-Andersen R, Pedersen-Bjergaard U, Hoi-Hansen T, et al. NT-pro-BNP during hypoglycemia and hypoxemia in normal subjects: Impact of renin-angiotensin system activity. J Appl Physiol. Apr. 2008;104(4):1080-5. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18258801].
Duman D, Palit F, Simsek E, et al. Serum carbohydrate antigen 125 levels in advanced heart failure: Relation to B-type natriuretic peptide and left atrial volume. Eur J Heart Fail. Jun. 2008;10(6):556-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18501671].
Duman D, Palit F, Simsek E, et al. Effects of levosimendan versus dobutamine on left atrial function in decompensated heart failure. Can J Cardiol. Oct. 2009;25(10):e353-6. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19812809].
Dumitrescu D, Seck C, Mohle L, et al. Therapeutic potential of sildenafil in patients with heart failure and reactive pulmonary hypertension. Int J Cardiol. 2012;154(2):205-6. Exclude: Not a primary study. [pmid: 22104986].
Dungen HD, Platzeck M, Vollert J, et al. Autoantibodies against cardiac troponin I in patients with congestive heart failure. Eur J Heart Fail. Jul. 2010;12(7):668-75. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20513750].
Dunlay SM, Gheorghiade M, Reid KJ, et al. Critical elements of clinical follow-up after hospital discharge for heart failure: Insights from the EVEREST trial. Eur J Heart Fail. 2010;12(4):367-74. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20197265].
Ebell M. Can B-natriuretic peptide distinguish patients with congestive heart failure from those with intrinsic lung disease?. Evid Based Pract. Apr. 2002;5(4):6. Exclude: Not a primary study.
Ebell MH. Risk stratification of patients presenting with syncope. Am Fam Phys. 2012;85(11):1051-2. Exclude: Not a primary study.
Edelmann F, Stahrenberg R, Polzin F, et al. Impaired physical quality of life in patients with diastolic dysfunction associates more strongly with neurohumoral activation than with echocardiographic parameters: quality of life in diastolic dysfunction. Am Heart J. Apr. 2011;161(4):797-804. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21473981].
Edvinsson ML, U. Deteriorated function of cutaneous microcirculation in chronic congestive heart failure. J Geriatr Cardiol. 2011;8(2):82-7. Exclude: BNP measure not FDA approved. [pmid: 22783290].
Efstratiadis S, Michaels AD. Acute hemodynamic effects of intravenous nesiritide on left ventricular diastolic function in heart failure patients. J Card Fail. Oct. 2009;15(8):673-80. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19786256].
Efthimiadis GK, Hitoglou-Makedou A, Giannakoulas G, et al. Clinical significance of N-terminal-probrain natriuretic peptide in hypertrophic cardiomyopathy. Heart Ves. Sep. 2007;22(5):322-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Eggers KM, Kempf T, Allhoff T, et al. Growth-differentiation factor-15 for early risk stratification in patients with acute chest pain. Eur Heart J. Oct. 2008;29(19):2327-35. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18664460].
Eggers KM, Lagerqvist B, Oldgren J, et al. Pathophysiologic mechanisms of persistent cardiac troponin I elevation in stabilized patients after an episode of acute coronary syndrome. Am Heart J. Sep. 2008;156(3):588-94. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18760145].
Eggers KM, Dellborg M, Oldgren J, et al. Risk prediction in chest pain patients by biochemical markers including estimates of renal function. Int J Cardiol. Aug. 18. 2008;128(2):207-13. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17662484].
Eggers KM, Kempf T, Venge P, et al. Improving long-term risk prediction in patients with acute chest pain: The Global Registry of Acute Coronary Events (GRACE) risk score is enhanced by selected nonnecrosis biomarkers. Am Heart J. Jul. 2010;160(1):88-94. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20598977].
Eguchi K, Kario K, Shimada K, et al. Circadian variation of blood pressure and neurohumoral factors during the acute phase of stroke. Clin Exp Hypertens. Jan. 2002;24(1-2):109-14. Exclude: BNP measure not FDA approved. [pmid: 11848163].
Eguchi K, Matsui Y, Shibasaki S, et al. Age-specific impact of self-monitored pulse pressure on hypertensive target organ damage in treated hypertensive patients. J Clin Hypertens. Jul. 2007;9(7):522-9. Exclude: BNP measure not FDA approved.
Eimer MJ, Ekery DL, Rigolin VH, et al. Elevated B-type natriuretic peptide in asymptomatic men with chronic aortic regurgitation and preserved left ventricular systolic function. Am J Cardiol. Sep. 1. 2004;94(5):676-8. Exclude: BNP measure not FDA approved. [pmid: 15342310].
El-Armouche A, Ouchi N, Tanaka K, et al. Follistatin-like 1 in chronic systolic heart failure a marker of left ventricular remodeling. Circ Heart Fail. 2011;4(5):621-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21622850].
Elasfar AA. NT-pro-brain natriuretic peptide levels after valve replacement. Asian Cardiovasc Thorac Ann. Dec. 2011;19(6):399-402. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 22160408].
Eleuteri E. Di Stefano. Stepwise increase of angiopoietin-2 serum levels is related to haemodynamic and functional impairment in stable chronic heart failure. Eur J Cardiovasc Prev Rehabil. 2011;18(4):607-14. Exclude: BNP measure not FDA approved. [pmid: 21450636].
Eleuteri E, Di Stefano A, Ricciardolo FL, et al. Increased nitrotyrosine plasma levels in relation to systemic markers of inflammation and myeloperoxidase in chronic heart failure. Int J Cardiol. Jul. 10. 2009;135(3):386-90. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19046613].
Elkayam U, Akhter MW, Singh H, et al. Comparison of effects on left ventricular filling pressure of intravenous nesiritide and high-dose nitroglycerin in patients with decompensated heart failure. Am J Cardiol. Jan. 15. 2004;93(2):237-40. Exclude: BNP measure not FDA approved. [pmid: 14715359].
Elkayam U, Akhter MW, Liu M, et al. Assessment of renal hemodynamic effects of nesiritide in patients with heart failure using intravascular Doppler and quantitative angiography. JACC Cardiovasc Imaging. Nov. 2008;1(6):765-71. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19356514].
Ellinor PT, Low AF, Patton KK, et al. Discordant atrial natriuretic peptide and brain natriuretic peptide levels in lone atrial fibrillation. J Am Coll Cardiol. Jan. 4. 2005;45(1):82-6. Exclude: BNP measure not FDA approved. [pmid: 15629379].
Ellis GR, Nightingale AK, Blackman DJ, et al. Addition of candesartan to angiotensin converting enzyme inhibitor therapy in patients with chronic heart failure does not reduce levels of oxidative stress. Eur J Heart Fail. Mar. 2002;4(2):193-9. Exclude: BNP measure not FDA approved. [pmid: 11959049].
Ellis KL, Pilbrow AP, Potter HC, et al. Association between endothelin type A receptor haplotypes and mortality in coronary heart disease. Personalized Medicine. 2012;9(3):341-9. Exclude: BNP measure not FDA approved.
Elnoamany MF, Abdelhameed AK. Mitral annular motion as a surrogate for left ventricular function: Correlation with brain natriuretic peptide levels. Eur J Echocardiogr. Jun. 2006;7(3):187-98. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16046188].
Emdin M, Poletti R, Passino C, et al. The clinical diagnosis of heart failure is predicted by neurohormonal and immune derangement. Immuno. 2003;18(4):207-11. Exclude: BNP measure not FDA approved.
Emdin M, Passino C, Del Ry S, et al. Influence of gender on circulating cardiac natriuretic hormones in patients with heart failure. Clin Chem Lab Med. May. 2003;41(5):686-92. Exclude: BNP measure not FDA approved. [pmid: 12812268].
Emdin M, Passino C, Prontera C, et al. Cardiac natriuretic hormones, neuro-hormones, thyroid hormones and cytokines in normal subjects and patients with heart failure. Clin Chem Lab Med. 2004;42(6):627-36. Exclude: BNP measure not FDA approved. [pmid: 15259379].
Emdin M, Marini C, Passino C, et al. Right ventricular overload and cardiovascular neuroendocrine derangement in systemic sclerosis. Eur Heart J. 2004;6(Suppl 6):F68-73. Exclude: BNP measure not FDA approved.
Emdin M, Passino C, Prontera C, et al. Comparison of brain natriuretic peptide (BNP) and amino-terminal ProBNP for early diagnosis of heart failure. Clin Chem. 2007;53(7):1289-97. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17495021].
Emiroglu Y, Kargin R, Kargin F, et al. BNP levels in patients with long-term exposure to biomass fuel and its relation to right ventricular function. Pulm Pharmacol Ther. Oct. 2010;23(5):420-4. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20466065].
Engineer RS, Benoit JL, Hicks CW, et al. Hemodynamic changes as a diagnostic tool in acute heart failure--A pilot study. Am J Emerg Med. Jan. 2012;30(1):174-80. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21030189].
Enomoto KY. Improvement effect on endothelial function in patients with congestive heart failure treated with cardiac resynchronization therapy. J Cardiol. 2011;58(1):69-73. Exclude: BNP measure not FDA approved. [pmid: 21493043].
Enomoto Y, Aoki M, Nakamura Y, et al. Successful fontan completion after cardiac resynchronization therapy. Circ. 2012;125(19):e655-e658. Exclude: Population aged under 18.
Epelman S, Tang WH, Chen SY, et al. Detection of soluble angiotensin-converting enzyme 2 in heart failure: Insights into the endogenous counter-regulatory pathway of the renin-angiotensin-aldosterone system. J Am Coll Cardiol. Aug. 26. 2008;52(9):750-4. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18718423].
Epshteyn V, Morrison K, Krishnaswamy P, et al. Utility of B-type natriuretic peptide (BNP) as a screen for left ventricular dysfunction in patients with diabetes. Diab Care. Jul. 2003;26(7):2081-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Erkol AP. Relation of circulating osteoprotegerin levels on admission to microvascular obstruction after primary percutaneous coronary intervention. Am J Cardiol. 2011;107(6):857-62. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21247537].
Eroglu S, Yildirir A, Bozbas H, et al. Brain natriuretic peptide levels and cardiac functional capacity in patients with dyspnea and isolated diastolic dysfunction. Int Heart J. 2007;48(1):97-106. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17379983].
Ertugrul DT, Gursoy A, Sahin M, et al. Evaluation of brain natriuretic peptide levels in hyperthyroidism and hypothyroidism. J Natl Med Assoc. Apr. 2008;100(4):401-5. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18481478].
Ertugrul DT, Yavuz B, Ata N, et al. Decreasing brain natriuretic peptide levels after treatment for hyperthyroidism. Endocr J. 2009;56(9):1043-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19738361].
Eskafi M. Sleep apnoea in patients with stable congestive heart failure an intervention study with a mandibular advancement device. Swed Dent J Suppl. 2004;(168):1-56. Exclude: BNP measure not FDA approved. [pmid: 15638133].
Eskafi M, Cline C, Nilner M, et al. Treatment of sleep apnea in congestive heart failure with a dental device: The effect on brain natriuretic peptide and quality of life. Sleep Breath. Jun. 2006;10(2):90-7. Exclude: BNP measure not FDA approved. [pmid: 16534592].
Estensen ME, Hognestad A, Syversen U, et al. Prognostic value of plasma chromogranin A levels in patients with complicated myocardial infarction. Am Heart J. 2006;152(5):927.e1-6. Exclude: BNP measure not FDA approved. [pmid: 17070161].
Etoh T, Kato J, Takenaga M, et al. Differential hormonal profiles of adrenomedullin and proadrenomedullin N-terminal 20 peptide in patients with heart failure and effect of treatment on their plasma levels. Clin Cardiol. Feb. 1999;22(2):113-7. Exclude: BNP measure not FDA approved. [pmid: 10068849].
Ezekowitz JA, Theroux P, Chang W, et al. N-terminal pro-brain natriuretic peptide and the timing, extent and mortality in ST elevation myocardial infarction. Can J Cardiol. Apr. 2006;22(5):393-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16639474].
Ezekowitz JA, Armstrong PW, Granger CB, et al. Predicting chronic left ventricular dysfunction 90 days after ST-segment elevation myocardial infarction: An Assessment of Pexelizumab in Acute Myocardial Infarction (APEX-AMI) substudy. Am Heart J. Aug. 2010;160(2):272-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20691832].
Fabbian F, De Giorgi A, Pala M, et al. Elevated NT-proBNP levels should be interpreted in elderly patients presenting with dyspnea. Eur J Intern Med. 2011;22(1):108-11. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21238905].
Fabbian F, De GA, Portaluppi F, et al. Relationship between N-terminal pro-B-type natriuretic peptide plasma levels and renal function evaluated with different formulae in older adult subjects admitted because of dyspnea. Gerontol. 2012;58(1):50-5. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Fagugli RM, Palumbo B, Ricciardi D, et al. Association between brain natriuretic peptide and extracellular water in hemodialysis patients. Nephron Clin Pract. 2003;95(2):c60-c66. Exclude: BNP measure not FDA approved. [pmid: 14610331].
Falcao LM, Pinto F, Ravara L, et al. BNP and ANP as diagnostic and predictive markers in heart failure with left ventricular systolic dysfunction. J Renin Angiotensin Aldosterone Syst. Sep. 2004;5(3):121-9. Exclude: BNP measure not FDA approved. [pmid: 15526247].
Fallah-Rad N, Walker JR, Wassef A, et al. The utility of cardiac biomarkers, tissue velocity and strain imaging, and cardiac magnetic resonance imaging in predicting early left ventricular dysfunction in patients with human epidermal growth factor receptor II-positive breast cancer treated with adjuvant trastuzumab therapy. J Am Coll Cardiol. May. 31. 2011;57(22):2263-70. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21616287].
Fang ZY, Schull-Meade R, Leano R, et al. Screening for heart disease in diabetic subjects. Am Heart J. Feb. 2005;149(2):349-54. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 15846276].
Fatini C, Sticchi E, Marcucci R, et al. ACE insertion/deletion, but not -240A>T polymorphism, modulates the severity in heart failure. J Investig Med. Dec. 2008;56(8):1004-10. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Fatkhutdinov TK, D'Yachkov AV, Koroteyev AV, et al. Safety and efficiency of transplantation of allogenic multipotent stromal cells in surgical treatment of dilatated cardiomyopathy. Bull Experiment Biol Med. 2010;149(1):119-24. Exclude: BNP measure not FDA approved.
Faviou E, Zachari A, Nounopoulos C, et al. Elevation of serum N-terminal pro-brain natriuretic peptide after exercise is an index of myocardial damage or a cytoprotective reflection?. J Sports Med Phys Fitness. Mar. 2008;48(1):90-6. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18212715].
Fayon MJ, Tucci M, Lacroix J, et al. Nosocomial pneumonia and tracheitis in a pediatric intensive care unit: A prospective study. Am J Respir Crit Care Med. Jan. 1997;155(1):162-9. Exclude: Population aged under 18. [pmid: 9001306].
Feldman DS, Ikonomidis JS, Uber WE, et al. Human B-natriuretic peptide improves hemodynamics and renal function in heart transplant patients immediately after surgery. J Card Fail. Aug. 2004;10(4):292-6. Exclude: BNP measure not FDA approved. [pmid: 15309694].
Feliciano J, Soares R, Silva S, et al. NT-proBNP levels and resting hemodynamic parameters assessed by bioimpedance in patients with chronic heart failure. Rev Port Cardiol. Oct. 2007;26(10):1021-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18232624].
Felker GM, Whellan D, Kraus WE, et al. N-terminal pro-brain natriuretic peptide and exercise capacity in chronic heart failure: Data from the Heart Failure and a Controlled Trial Investigating Outcomes of Exercise Training (HF-ACTION) study. Am Heart J. Oct. 2009;158(Suppl 4):S37-44. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19782787].
Felker GM, Fiuzat M, Shaw LK, et al. Galectin-3 in ambulatory patients with heart failure: Results from the HF-ACTION study. Circ. Jan. 1. 2012;5(1):72-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Felkin LE, Lara-Pezzi EA, Hall JL, et al. Reverse remodelling and recovery from heart failure are associated with complex patterns of gene expression. J Cardiovasc Transl Res. Jun. 2011;4(3):321-31. Exclude: BNP measure not FDA approved. [pmid: 21424859].
Fellahi JL, Hanouz JL, Le Manach Y, et al. Simultaneous measurement of cardiac troponin I, B-type natriuretic peptide, and C-reactive protein for the prediction of long-term cardiac outcome after cardiac surgery. Anesthesiol. 2009;111(2):250-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Feola M, Menardi E, Ribichini F, et al. Effects of the addition of a low dose of spironolactone on brain natriuretic peptide plasma level and cardiopulmonary function in patients with moderate congestive heart failure. Med Sci Monit. Aug. 2003;9(8):CR341-5. Exclude: BNP measure not FDA approved. [pmid: 12942029].
Feola M, Valeri L, Menditto E, et al. Comparison between immunoradiometric and fluorimetric brain natriuretic peptide determination in patients with congestive heart failure. J Endocrinol Invest. Sep. 2010;33(8):554-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20160469].
Feola M, Lombardo E, Taglieri C, et al. Plasma BNP and renal failure as prognostic factors of mid-term clinical outcome in congestive heart failure patients. Int J Cardiol. May. 2011;149(1):114-5. Exclude: BNP measure not FDA approved. [pmid: 21342707].
Feola M, Garrone O, Occelli M, et al. Cardiotoxicity after anthracycline chemotherapy in breast carcinoma: Effects on left ventricular ejection fraction, troponin I and brain natriuretic peptide. Int J Cardiol. Apr. 14. 2011;148(2):194-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19945181].
Feola M, Lombardo E, Taglieri C, et al. Effects of levosimendan/furosemide infusion on plasma brain natriuretic peptide, echocardiographic parameters and cardiac output in end-stage heart failure patients. Med Sci Monit. Feb. 25. 2011;17(3):I7-13. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Feringa HH, Schouten O, Dunkelgrun M, et al. Plasma N-terminal pro-B-type natriuretic peptide as long-term prognostic marker after major vascular surgery. Heart. Feb. 2007;93(2):226-31. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16914484].
Feringa HH, Poldermans D, Klein P, et al. Plasma natriuretic peptide levels reflect changes in heart failure symptoms, left ventricular size and function after surgical mitral valve repair. Int J Cardiovasc Imaging. Apr. 2007;23(2):159-65. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16941223].
Fernandes F, De Almeida IJ, Ramires FJA, et al. NT pro-BNP levels in pericardial diseases and how they are used as complementary evaluation method of diastolic restriction. Inititial experience: 25 Cases. Arq Bras Cardiol. 2006;86(3):175-80. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16612443].
Fernandes F, Dantas S, Ianni BM, et al. Leptin levels in different forms of Chagas' disease. Braz J Med Biol Res. Dec. 2007;40(12):1631-6. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17713658].
Fernandes F, Ramires FJA, Buck PC, et al. N-terminal-pro-brain natriuretic peptide, but not brain natriuretic peptide, is increased in patients with severe obesity. Braz J Med Biol Res. 2007;40(2):153-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17273651].
Fernandes R, Feliciano J, Soares RM, et al. Correlation between NT-proBNP values and changes in functional capacity in patients with chronic heart failure. Rev Port Cardiol. Dec. 2007;26(12):1329-44. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18338663].
Fernandes R, Feliciano J, Soares RM, et al. NT-proBNP values and Weber functional class in patients with chronic heart failure. Rev Port Cardiol. Dec. 2007;26(12):1311-24. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18338662].
Ferratini M, Ripamonti V, Masson S, et al. Pentraxin-3 predicts functional recovery and 1-year major adverse cardiovascular events after rehabilitation of cardiac surgery patients. J Cardiopulm Rehabil Prev. Jan. 2012;32(1):17-24. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 22193930].
Ferreira A, Bettencourt P, Dias P, et al. Neurohormonal activation, the renal dopaminergic system and sodium handling in patients with severe heart failure under vasodilator therapy. Clin Sci. May. 2001;100(5):557-66. Exclude: BNP measure not FDA approved. [pmid: 11294697].
Ferreira A, Bettencourt P, Pimenta J, et al. The renal dopaminergic system, neurohumoral activation, and sodium handling in heart failure. Am Heart J. Mar. 2002;143(3):391-7. Exclude: BNP measure not FDA approved. [pmid: 11868042].
Ferreira AM, Mendes M, Ventosa A, et al. Obesity does not influence the correlation between exercise capacity and serum NT-proBNP levels in chronic heart failure. Int J Cardiol. Oct. 30. 2008;130(1):103-5. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17692409].
Ferrier K, Campbell A, Yee B, et al. Sleep-disordered breathing occurs frequently in stable outpatients with congestive heart failure. Chest. Oct. 2005;128(4):2116-22. Exclude: BNP measure not FDA approved. [pmid: 16236863].
Ferrier KA, Neill AM, O'Meeghan T, et al. Continuous positive airway pressure in heart failure patients with obstructive sleep apnoea. Intern Med J. 2008;38(11):829-36. Exclude: BNP measure not FDA approved. [pmid: 18284461].
Fertin M, Hennache B, Hamon M, et al. Usefulness of serial assessment of B-type natriuretic peptide, troponin I, and C-reactive protein to predict left ventricular remodeling after acute myocardial infarction (from the REVE-2 study). Am J Cardiol. Nov. 15. 2010;106(10):1410-6. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21059429].
Fijalkowska A, Kurzyna M, Torbicki A, et al. Serum N-terminal brain natriuretic peptide as a prognostic parameter in patients with pulmonary hypertension. Chest. May. 2006;129(5):1313-21. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16685024].
Filsoufi F, Rahmanian PB, Salzberg S, et al. B-type natriuretic peptide (BNP) in patients undergoing mitral valve surgery. J Card Surg. Nov. 2008;23(6):600-5. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18793229].
Filusch A, Giannitsis E, Katus HA, et al. High-sensitive troponin T: A novel biomarker for prognosis and disease severity in patients with pulmonary arterial hypertension. Clin Sci. Sep. 2010;119(5):207-13. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20412051].
Filusch AZ. Soluble TWEAK predicts hemodynamic impairment and functional capacity in patients with pulmonary arterial hypertension. Clin Res Cardiol. 2011;100(10):879-85. Exclude: BNP measure not FDA approved. [pmid: 21479966].
Fink AM, Sullivan SL, Zerwic JJ, et al. Fatigue with systolic heart failure. J Cardiovasc Nurs. Sep. 2009;24(5):410-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19707101].
Fischer-Rasokat U, Assmus B, Seeger FH, et al. A pilot trial to assess potential effects of selective intracoronary bone marrow-derived progenitor cell infusion in patients with nonischemic dilated cardiomyopathy: Final 1-year results of the transplantation of progenitor cells and functional regeneration enhancement pilot trial in patients with nonischemic dilated cardiomyopathy. Circ. Sep. 2009;2(5):417-23. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Fitzgibbons TP, Madias C, Seth A, et al. Prevalence and clinical characteristics of right ventricular dysfunction in transient stress cardiomyopathy. Am J Cardiol. 2009;104(1):133-6. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19576334].
Fleischer D, Espiner EA, Yandle TG, et al. Rapid assay of plasma brain natriuretic peptide in the assessment of acute dyspnoea. NZ Med J. Mar. 14. 1997;110(1039):71-4. Exclude: BNP measure not FDA approved.
Flevari P, Theodorakis G, Paraskevaidis I, et al. Coronary and peripheral blood flow changes following biventricular pacing and their relation to heart failure improvement. Europace. Jan. 2006;8(1):44-50. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16627408].
Flevari P, Parissis JT, Leftheriotis D, et al. Effect of levosimendan on ventricular arrhythmias and prognostic autonomic indexes in patients with decompensated advanced heart failure secondary to ischemic or dilated cardiomyopathy. Am J Cardiol. Dec. 15. 2006;98(12):1641-5. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17145226].
Flores-Ramirez R, Uribe-Longoria A, Rangel-Fuentes MM, et al. Intracoronary infusion of CD133+ endothelial progenitor cells improves heart function and quality of life in patients with chronic post-infarct heart insufficiency. Cardiovasc Revasc Med. Apr. 2010;11(2):72-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20347795].
Florkowski CM, Richards AM, Espiner EA, et al. Renal, endocrine, and hemodynamic interactions of atrial and brain natriuretic peptides in normal men. Am J Physiol. Apr. 1994;266(4 Pt 2):R1244-50. Exclude: BNP measure not FDA approved. [pmid: 8184968].
Folk JJ, Lipari CW, Nosovitch JT, et al. Evaluating ventricular function with B-type natriuretic peptide in obstetric patients. J Reprod Med. Mar. 2005;50(3):147-54. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 15841926].
Fonarow GC, Peacock WF, Phillips CO, et al. Admission B-type natriuretic peptide levels and in-hospital mortality in acute decompensated heart failure. J Am Coll Cardiol. May. 15. 2007;49(19):1943-50. Exclude: BNP measure not FDA approved. [pmid: 17498579].
Fonarow GC, Peacock WF, Horwich TB, et al. Usefulness of B-type natriuretic peptide and cardiac troponin levels to predict in-hospital mortality from ADHERE. Am J Cardiol. Jan. 15. 2008;101(2):231-7. Exclude: BNP measure not FDA approved. [pmid: 18178412].
Fonseca C, Sarmento PM, Minez A, et al. Comparative value of BNP and NT-proBNP in diagnosis of heart failure. Rev Port Cardiol. Jul. 2004;23(7-8):979-91. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 15478324].
Fontana M, Passino C, Poletti R, et al. Low triiodothyronine and exercise capacity in heart failure. Int J Cardiol. 2012;154(2):153-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20888651].
Forster O, Hilfiker-Kleiner D, Ansari AA, et al. Reversal of IFN-gamma, oxLDL and prolactin serum levels correlate with clinical improvement in patients with peripartum cardiomyopathy. Eur J Heart Fail. Sep. 2008;10(9):861-8. Exclude: BNP measure not FDA approved. [pmid: 18768352].
Fousteris E, Melidonis A, Panoutsopoulos G, et al. Toll/interleukin-1 receptor member ST2 exhibits higher soluble levels in type 2 diabetes, especially when accompanied with left ventricular diastolic dysfunction. Cardiovasc Diabetol. 2011;10:101. Exclude: BNP measure not FDA approved. [pmid: 22104207].
Fox AA, Shernan SK, Collard CD, et al. Preoperative B-type natriuretic peptide is as independent predictor of ventricular dysfunction and mortality after primary coronary artery bypass grafting. J Thorac Cardiovasc Surg. Aug. 2008;136(2):452-61. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18692657].
Fox AA, Collard CD, Shernan SK, et al. Natriuretic peptide system gene variants are associated with ventricular dysfunction after coronary artery bypass grafting. Anesthesiol. Apr. 2009;110(4):738-47. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Fox AA, Muehlschlegel JD, Body SC, et al. Comparison of the utility of preoperative versus postoperative B-type natriuretic peptide for predicting hospital length of stay and mortality after primary coronary artery bypass grafting. Anesthesiol. Apr. 2010;112(4):842-51. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Fox ER, Musani SK, Bidulescu A, et al. Relation of obesity to circulating B-type natriuretic peptide concentrations in blacks: The Jackson Heart Study. Circ. Aug. 30. 2011;124(9):1021-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Fragopoulou E, Panagiotakos DB, Pitsavos C, et al. N-terminal ProBNP distribution and correlations with biological characteristics in apparently healthy Greek population: ATTICA study. Angiol. May. 2010;61(4):397-404. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Franceschi F, Deharo JC, Giorgi R, et al. Peripheral plasma adenosine release in patients with chronic heart failure. Heart. Apr. 2009;95(8):651-5. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19039025].
Francia P, Salvati A, Balla C, et al. Cardiac resynchronization therapy increases plasma levels of the endogenous inotrope apelin. Eur J Heart Fail. Mar. 2007;9(3):306-9. Exclude: BNP measure not FDA approved. [pmid: 16891152].
Francis CK, Kuo YH, Azzam I, et al. Brain natriuretic peptide and biomarkers of myocardial ischemia increase after defibrillation threshold testing. PACE. 2012;35(3):314-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 22126159].
Francis DP, Davies LC, Coats AJ. Diagnostic exercise physiology in chronic heart failure. Heart. Jul. 2001;86(1):17-20. Exclude: Not a primary study. [pmid: 11410554].
Frank Peacock WN. Short-term mortality risk in emergency department acute heart failure. Acad Emerg Med. 2011;18(9):947-58. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21906204].
Frankel DS, Vasan RS, D'Agostino RB Sr., et al. Resistin, adiponectin, and risk of heart failure the Framingham offspring study. J Am Coll Cardiol. Mar. 3. 2009;53(9):754-62. Exclude: BNP measure not FDA approved. [pmid: 19245965].
Frankenstein L, Remppis A, Frankenstein J, et al. Reference change values and determinants of variability of NT-proANP and GDF15 in stable chronic heart failure. Basic Res Cardiol. Nov. 2009;104(6):731-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19352585].
Frantz RP, Olson LJ, Grill D, et al. Carvedilol therapy is associated with a sustained decline in brain natriuretic peptide levels in patients with congestive heart failure. Am Heart J. Mar. 2005;149(3):541-7. Exclude: BNP measure not FDA approved. [pmid: 15864245].
Frantz RP, Lowes BD, Grayburn PA, et al. Baseline and serial neurohormones in patients with congestive heart failure treated with and without bucindolol: Results of the neurohumoral substudy of the Beta-Blocker Evaluation of Survival Study (BEST). J Card Fail. Aug. 2007;13(6):437-44. Exclude: BNP measure not FDA approved. [pmid: 17675057].
Frantz RP, Benza RL, Kjellstrom B, et al. Continuous hemodynamic monitoring in patients with pulmonary arterial hypertension. J Heart Lung Transplant. Jul. 2008;27(7):780-8. Exclude: BNP measure not FDA approved. [pmid: 18582809].
Franzen O, van der Heyden J, Baldus S, et al. MitraClip® therapy in patients with end-stage systolic heart failure. Eur J Heart Fail. May. 2011;13(5):569-76. Exclude: BNP measure not FDA approved. [pmid: 21471146].
Frassl W, Kowoll R, Katz N, et al. Cardiac markers (BNP, NT-pro-BNP, Troponin I, Troponin T) in female amateur runners before and up until three days after a marathon. Clin Lab. 2008;54(3-4):81-7. Exclude: Unable to obtain copy. [pmid: 18630737].
Freed BH, Gomberg-Maitland M, Chandra S, et al. Late gadolinium enhancement cardiovascular magnetic resonance predicts clinical worsening in patients with pulmonary hypertension. J Cardiovasc Magn Reson. 2012;14:11. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 22296860].
Freestone B, Gustafsson F, Chong AY, et al. Influence of atrial fibrillation on plasma von willebrand factor, soluble E-selectin, and N-terminal pro B-type natriuretic peptide levels in systolic heart failure. Chest. May. 2008;133(5):1203-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18339785].
Friedl W, Mair J, Thomas S, et al. Natriuretic peptides and cyclic guanosine 3',5'-monophosphate in asymptomatic and symptomatic left ventricular dysfunction. Heart. Aug. 1996;76(2):129-36. Exclude: BNP measure not FDA approved. [pmid: 8795474].
Friedl W, Mair J, Thomas S, et al. Relationship between natriuretic peptides and hemodynamics in patients with heart failure at rest and after ergometric exercise. Clin Chim Acta. Mar. 1999;281(1-2):121-6. Exclude: BNP measure not FDA approved. [pmid: 10217633].
Friese RS, Dineen S, Jennings A, et al. Serum B-type natriuretic peptide: A marker of fluid resuscitation after injury?. J Trauma Inj Infect Crit Care. 2007;62(6):1346-50. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
From AML. Bedside assessment of cardiac hemodynamics: The impact of noninvasive testing and examiner experience. Am J Med. 2011;124(11):1051-7. Exclude: BNP measure not FDA approved. [pmid: 21944161].
Fruhwald FM, Fahrleitner A, Watzinger N, et al. Natriuretic peptides in patients with diastolic dysfunction due to idiopathic dilated cardiomyopathy. Eur Heart J. Oct. 1999;20(19):1415-23. Exclude: BNP measure not FDA approved. [pmid: 10487802].
Fruhwald FM, Fahrleitner-Pammer A, Berger R, et al. Early and sustained effects of cardiac resynchronization therapy on N-terminal pro-B-type natriuretic peptide in patients with moderate to severe heart failure and cardiac dyssynchrony. Eur Heart J. Jul. 2007;28(13):1592-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17298973].
Fujimoto N, Onishi K, Sato A, et al. Incremental prognostic values of serum tenascin-C levels with blood B-type natriuretic peptide testing at discharge in patients with dilated cardiomyopathy and decompensated heart failure. J Card Fail. Dec. 2009;15(10):898-905. Exclude: BNP measure not FDA approved. [pmid: 19944367].
Fujimoto S, Amano H, Inoue A, et al. Usefulness of 123 I-metaiodobenzylguanidine myocardial scintigraphy in the prediction of cardiac events in patients with cardiomyopathy showing stabilization of symptoms or preserved cardiac function. Ann Nucl Med. 2004;18(7):591-8. Exclude: BNP measure not FDA approved. [pmid: 15586633].
Fujimura M, Akaike M, Iwase T, et al. Decrease in plasma brain natriuretic peptide level in the early phase after the start of carvedilol therapy is a novel predictor of long-term outcome in patients with chronic heart failure. Acta Cardiol. Oct. 2009;64(5):589-95. Exclude: BNP measure not FDA approved. [pmid: 20058503].
Fujino T, Yamashita T, Suzuki S, et al. Characteristics of congestive heart failure accompanied by atrial fibrillation with special reference to tachycardia-induced cardiomyopathy. Circ J. 2007;71(6):936-40. Exclude: BNP measure not FDA approved. [pmid: 17526993].
Fujita S, Ikeda Y, Miyata M, et al. Effect of Waon therapy on oxidative stress in chronic heart failure. Circ J. 2011;75(2):348-56. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21173495].
Fukunaga T, Soejima H, Irie A, et al. Expression of interferon-gamma and interleukin-4 production in CD4^+^ T cells in patients with chronic heart failure. Heart Ves. 2007;22(3):178-83. Exclude: BNP measure not FDA approved.
Fukunaga T, Soejima H, Irie A, et al. Relation between CD4+ T-cell activation and severity of chronic heart failure secondary to ischemic or idiopathic dilated cardiomyopathy. Am J Cardiol. Aug. 1. 2007;100(3):483-8. Exclude: BNP measure not FDA approved. [pmid: 17659933].
Fukushima Y, Nakanishi M, Nonogi H, et al. Assessment of plasma miRNAs in congestive heart failure. Circ J. 2011;75(2):336-40. Exclude: BNP measure not FDA approved. [pmid: 21157109].
Fukuta H, Ohte N, Mukai S, et al. Elevated plasma levels of B-type natriuretic peptide but not C-reactive protein are associated with higher red cell distribution width in patients with coronary artery disease. Int Heart J. May. 2009;50(3):301-12. Exclude: BNP measure not FDA approved. [pmid: 19506334].
Fukutomi M, Hoshide S, Eguchi K, et al. Differential effects of strict blood pressure lowering by losartan/hydrochlorothiazide combination therapy and high-dose amlodipine monotherapy on microalbuminuria: the ALPHABET study. J Am Soc Hypertens. Jan. 2012;6(1):73-82. Exclude: BNP measure not FDA approved. [pmid: 22054782].
Funami J, Hayashi T, Nomura H, et al. Clinical factors such as B-type natriuretic peptide link to factor VII, endothelial NO synthase and estrogen receptor alpha polymorphism in elderly women. Life Sci. Aug. 12. 2009;85(7-8):316-21. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19560472].
Funayama AS. Serum pregnancy-associated plasma protein A in patients with heart failure. J Card Fail. 2011;17(10):819-26. Exclude: BNP measure not FDA approved. [pmid: 21962420].
Fung JW, Yu CM, Yip G, et al. Effect of beta blockade (carvedilol or metoprolol) on activation of the renin-angiotensin-aldosterone system and natriuretic peptides in chronic heart failure. Am J Cardiol. Aug. 15. 2003;92(4):406-10. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 12914870].
Fung JW, Chan JY, Kum LC, et al. Suboptimal medical therapy in patients with systolic heart failure is associated with less improvement by cardiac resynchronization therapy. Int J Cardiol. Feb. 7. 2007;115(2):214-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16797091].
Furst DE. Measuring outcomes in PAH: The gap between the measures that are used and their validity. Ann NY Acad Sci. Jun. 2007;1107:410-6. Exclude: Not a primary study. [pmid: 17804569].
Furumoto T, Fujii S, Mikami T, et al. Increased plasma concentrations of N-terminal pro-brain natriuretic peptide reflect the presence of mildly reduced left ventricular diastolic function in hypertension. Coron Artery Dis. Feb. 2006;17(1):45-50. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16374141].
Gabizon I, Shiyovich A, Novack V, et al. Impact of descent and stay at a Dead Sea resort (low altitude) on patients with systolic congestive heart failure and an implantable cardioverter defibrillator. Isr Med Assoc J. Jul. 2011;13(7):402-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21838181].
Gabriel RS, Kerr AJ, Sharma V, et al. B-type natriuretic peptide and left ventricular dysfunction on exercise echocardiography in patients with chronic aortic regurgitation. Heart. Jul. 2008;94(7):897-902. Exclude: BNP measure not FDA approved. [pmid: 17974697].
Gackowski A, Isnard R, Golmard JL, et al. Comparison of echocardiography and plasma B-type natriuretic peptide for monitoring the response to treatment in acute heart failure. Eur Heart J. Oct. 2004;25(20):1788-96. Exclude: BNP measure not FDA approved. [pmid: 15474693].
Gaede P, Hildebrandt P, Hess G, et al. Plasma N-terminal pro-brain natriuretic peptide as a major risk marker for cardiovascular disease in patients with type 2 diabetes and microalbuminuria. Diabetol. 2005;48(1):156-63. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Galante O, Amit G, Zahger D, et al. B-type natruiretic peptide levels stratify the risk for arrhythmia among implantable cardioverter defibrillator patients. Clin Cardiol. Dec. 2008;31(12):586-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19072881].
Galasko G, Collinson PO, Barnes SC, et al. Comparison of the clinical utility of atrial and B type natriuretic peptide measurement for the diagnosis of systolic dysfunction in a low-risk population. J Clin Pathol. May. 2007;60(5):570-2. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17513518].
Galasko GI, Lahiri A, Barnes SC, et al. What is the normal range for N-terminal pro-brain natriuretic peptide? How well does this normal range screen for cardiovascular disease?. Eur Heart J. Nov. 2005;26(21):2269-76. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16040618].
Galasko GIW, Barnes SC, Collinson P, et al. What is the most cost-effective strategy to screen for left ventricular systolic dysfunction: Natriuretic peptides, the electrocardiogram, hand-held echocardiography, traditional echocardiography, or their combination?. Eur Heart J. 2006;27(2):193-200. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16267076].
Galatius S, Gustafsson F, Atar D, et al. Tolerability of beta-blocker initiation and titration with bisoprolol and carvedilol in congestive heart failure - A randomized comparison. Cardiol. 2004;102(3):160-5. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Galema TW, Yap SC, Geleijnse ML, et al. Early detection of left ventricular dysfunction by Doppler tissue imaging and N-terminal pro-B-type natriuretic peptide in patients with symptomatic severe aortic stenosis. J Am Soc Echocardiogr. Mar. 2008;21(3):257-61. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17628412].
Galie N, Olschewski H, Oudiz RJ, et al. Ambrisentan for the treatment of pulmonary arterial hypertension: results of the ambrisentan in pulmonary arterial hypertension, randomized, double-blind, placebo-controlled, multicenter, efficacy (ARIES) study 1 and 2. Circ. Jun. 10. 2008;117(23):3010-9. Exclude: BNP measure not FDA approved.
Galli E, Marchini M, Saba A, et al. Detection of 3-iodothyronamine in human patients: A preliminary study. J Clin Endocrinol Metab. Jan. 2012;97(1):E69-E74. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 22031514].
Galrinho A, Branco L, Soares R, et al. Prognostic implications of tissue Doppler in patients with dilated cardiomyopathy. Rev Port Cardiol. Sep. 2006;25(9):781-93. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17100169].
Galrinho A, Branco LM, Oliveira MM, et al. Cardiac resynchronization therapy--Clinical and echocardiographic characteristics of responders and exceptional responders. Rev Port Cardiol. Sep. 2009;28(9):959-69. Exclude: Not in English. [pmid: 19998807].
Galrinho A, Branco LM, Soares RM, et al. Left atrial volume: An old echocardiographic measure with renewed prognostic significance: A study in patients with dilated cardiomyopathy. Rev Port Cardiol. Oct. 2009;28(10):1049-60. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20058774].
Galvani M, Ottani F, Oltrona L, et al. N-terminal pro-brain natriuretic peptide on admission has prognostic value across the whole spectrum of acute coronary syndromes. Circ. Jul. 13. 2004;110(2):128-34. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Gan CTJ, Holverda S, Marcus JT, et al. Right ventricular diastolic dysfunction and the acute effects of sildenafil in pulmonary hypertension patients. Chest. 2007;132(1):11-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17625080].
Gao HQ. Correlation of peripheral blood CD34-positive cells with creatine kinase MB, N-terminal pro-B-type natriuretic peptide, and left ventricular ejection fraction in patients with acute myocardial infarction. J Clin Rehab Tissue Engineer Res. 2011;15(23):4355-8. Exclude: BNP measure not FDA approved.
Gao LR, Wang ZG, Zhu ZM, et al. Effect of intracoronary transplantation of autologous bone marrow-derived mononuclear cells on outcomes of patients with refractory chronic heart failure secondary to ischemic cardiomyopathy. Am J Cardiol. Sep. 1. 2006;98(5):597-602. Exclude: BNP measure not FDA approved. [pmid: 16923443].
Gao LR, Xu RY, Zhang NK, et al. Increased apelin following bone marrow mononuclear cell transplantation contributes to the improvement of cardiac function in patients with severe heart failure. Cell Transplant. 2009;18(12):1311-8. Exclude: BNP measure not FDA approved. [pmid: 19785937].
Garadah TS, Mahdi N, Kassab S, et al. The pro-BNP serum level and echocardiographic tissue doppler abnormalities in patients with beta Thalassemia Major. Clin Med Insights Cardiol. 2010;4:135-41. Exclude: BNP measure not FDA approved. [pmid: 21234293].
Garcia-Alvarez A, Sitges M, Pinazo MJ, et al. Chagas cardiomyopathy: The potential of diastolic dysfunction and brain natriuretic peptide in the early identification of cardiac damage. PLoS Negl Trop Dis. 2010;4(9):2010. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Gardiwal A, Yu H, Oswald H, et al. Right ventricular pacing is an independent predictor for ventricular tachycardia/ventricular fibrillation occurrence and heart failure events in patients with an implantable cardioverter-defibrillator. Europace. Mar. 2008;10(3):358-63. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18308756].
Garg R, Raman SV, Hoffman TM, et al. Serum markers of systemic right ventricular function and exercise performance. Pediatr Cardiol. May. 2008;29(3):641-8. Exclude: BNP measure not FDA approved. [pmid: 18185948].
Gargani L, Frassi F, Soldati G, et al. Ultrasound lung comets for the differential diagnosis of acute cardiogenic dyspnoea: A comparison with natriuretic peptides. Eur J Heart Fail. Jan. 2008;10(1):70-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18077210].
Gariani K, Delabays A, Perneger TV, et al. Use of brain natriuretic peptide to detect previously unknown left ventricular dysfunction in patients with acute exacerbation of chronic obstructive pulmonary disease. Swiss Med Wkly. 2011;141:w13298. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 22072300].
Gary RA, Cress ME, Higgins MK, et al. Combined aerobic and resistance exercise program improves task performance in patients with heart failure. Arch Phys Med Rehabil. Sep. 2011;92(9):1371-81. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21878207].
Gavin AD, Struthers AD. Allopurinol reduces B-type natriuretic peptide concentrations and haemoglobin but does not alter exercise capacity in chronic heart failure. Heart. Jun. 2005;91(6):749-53. Exclude: BNP measure not FDA approved. [pmid: 15894768].
Gegenhuber A, Mueller T, Firlinger F, et al. Time course of B-type natriuretic peptide (BNP) and N-terminal proBNP changes in patients with decompensated heart failure. Clin Chem. Feb. 2004;50(2):454-6. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 14752022].
Gegenhuber A, Mueller T, Dieplinger B, et al. Plasma B-type natriuretic peptide in patients with pleural effusions: Preliminary observations. Chest. Aug. 2005;128(2):1003-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16100199].
Gegenhuber A, Mueller T, Dieplinger B, et al. B-type natriuretic peptide and amino terminal proBNP predict one-year mortality in short of breath patients independently of the baseline diagnosis of acute destabilized heart failure. Clin Chim Acta. Aug. 2006;370(1-2):174-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16600203].
Geiger S, Stemmler HJ, Suhl P, et al. Anthracycline-induced cardiotoxicity: Cardiac monitoring by continuous wave-doppler ultrasound cardiac output monitoring and correlation to echocardiography. Onkologie. 2012;35(5):241-6. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 22868502].
Gemici G, Erdim R, Celiker A, et al. B-type natriuretic peptide levels in patients with COPD and normal right ventricular function. Adv Ther. Jul. 2008;25(7):674-80. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18563310].
Gempp E, Blatteau J-E, Louge P, et al. N-Terminal pro brain natriuretic peptide increases after 1-h scuba dives at 10 m depth. Aviat Space Environ Med. 2005;76(2):114-6. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 15742826].
George J, Patal S, Wexler D, et al. Circulating adiponectin concentrations in patients with congestive heart failure. Heart. Oct. 2006;92(10):1420-4. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16621874].
George J, Wexler D, Roth A, et al. Usefulness of anti-oxidized LDL antibody determination for assessment of clinical control in patients with heart failure. Eur J Heart Fail. Jan. 2006;8(1):58-62. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16061420].
Georges A, Forestier F, Valli N, et al. Changes in type B natriuretic peptide (BNP) concentrations during cardiac valve replacement. Eur J Cardiothorac Surg. Jun. 2004;25(6):941-5. Exclude: BNP measure not FDA approved. [pmid: 15144992].
Georgiadou P, Babu-Narayan SV, Francis DP, et al. Periodic breathing as a feature of right heart failure in congenital heart disease. Heart. 2004;90(9):1075-6. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 15310713].
Gerbaud E, Erickson M, Grenouillet-Delacre M, et al. Echocardiographic evaluation and N-terminal pro-brain natriuretic peptide measurement of patients hospitalized for heart failure during weaning from mechanical ventilation. Minerva Anestesiol. 2012;78(4):415-25. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 22310189].
Germing A, Gotzmann M, Rausse R, et al. Normal values for longitudinal function of the right ventricle in healthy women >70 years of age. Eur J Echocardiogr. 2010;11(8):725-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20418271].
Germing A, Gotzmann M, Schikowski T, et al. Diastolic dysfunction without abnormalities in left atrial and left ventricular geometry does not affect quality of life in elderly women. Exp Clin Cardiol. 2011;16(2):37-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21747661].
Gerson MCC. Influence of diabetes mellitus on prognostic utility of imaging of myocardial sympathetic innervation in heart failure patients. Circ. 2011;4(2):87-93. Exclude: BNP measure not FDA approved.
Ghio S, Perlini S, Palladini G, et al. Importance of the echocardiographic evaluation of right ventricular function in patients with AL amyloidosis. Eur J Heart Fail. Aug. 2007;9(8):808-13. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17586091].
Giallauria F, De Lorenzo A, Pilerci F, et al. Reduction of N terminal-pro-brain (B-type) natriuretic peptide levels with exercise-based cardiac rehabilitation in patients with left ventricular dysfunction after myocardial infarction. Eur J Cardiovasc Prev Rehabil. Aug. 2006;13(4):625-32. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16874155].
Giallauria F, Cirillo P, Lucci R, et al. Left ventricular remodelling in patients with moderate systolic dysfunction after myocardial infarction: favourable effects of exercise training and predictive role of N-terminal pro-brain natriuretic peptide. Eur J Cardiovasc Prev Rehabil. Feb. 2008;15(1):113-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18277196].
Giannakoulas G, Hatzitolios A, Karvounis H, et al. N-terminal pro-brain natriuretic peptide levels are elevated in patients with acute ischemic stroke. Angiol. Nov. 2005;56(6):723-30. Exclude: BNP measure not FDA approved.
Giannakoulas G, Dimopoulos K, Bolger AP, et al. Usefulness of natriuretic Peptide levels to predict mortality in adults with congenital heart disease. Am J Cardiol. Mar. 15. 2010;105(6):869-73. Exclude: BNP measure not FDA approved. [pmid: 20211335].
Giannessi D, Colotti C, Maltinti M, et al. Circulating heat shock proteins and inflammatory markers in patients with idiopathic left ventricular dysfunction: Their relationships with myocardial and microvascular impairment. Cell Stress & Chaperones. 2007;12(3):265-74. Exclude: BNP measure not FDA approved. [pmid: 17915559].
Giannessi D, Caselli C, Del Ry S, et al. Adiponectin is associated with abnormal lipid profile and coronary microvascular dysfunction in patients with dilated cardiomyopathy without overt heart failure. Metabolism. 2011;60(2):227-33. Exclude: BNP measure not FDA approved. [pmid: 20199784].
Giannoni A, Emdin M, Poletti R, et al. Clinical significance of chemosensitivity in chronic heart failure: Influence on neurohormonal derangement, Cheyne-Stokes respiration and arrhythmias. Clin Sci. Apr. 2008;114(7):489-97. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17961123].
Giannoni A, Emdin M, Bramanti F, et al. Combined increased chemosensitivity to hypoxia and hypercapnia as a prognosticator in heart failure. J Am Coll Cardiol. May. 26. 2009;53(21):1975-80. Exclude: BNP measure not FDA approved. [pmid: 19460611].
Gibbons V, Devlin G, Speed J, et al. The use of amino-terminal fraction brain natriuretic peptide (NT-proBNP) assays in general practices in Waikato, New Zealand. NZ Med J. 2007;120(1255):U2555. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Gibson SC, Payne CJ, Byrne DS, et al. B-type natriuretic peptide predicts cardiac morbidity and mortality after major surgery. Br J Surg. 2007;94(7):903-9. Exclude: BNP measure not FDA approved. [pmid: 17330928].
Giglioli C, Landi D, Gensini GF, et al. Cardiac efficiency improvement after slow continuous ultrafiltration is assessed by beat-to-beat minimally invasive monitoring in congestive heart failure patients: A preliminary report. Blood Purif. 2010;29(1):44-51. Exclude: BNP measure not FDA approved. [pmid: 19907163].
Giglioli C, Landi D, Cecchi E, et al. Effects of ULTRAfiltration vs. DIureticS on clinical, biohumoral and haemodynamic variables in patients with deCOmpensated heart failure: the ULTRADISCO study. Eur J Heart Fail. Mar. 2011;13(3):337-46. Exclude: BNP measure not FDA approved. [pmid: 21131387].
Gill D, Seidler T, Troughton RW, et al. Vigorous response in plasma N-terminal pro-brain natriuretic peptide (NT-BNP) to acute myocardial infarction. Clin Sci. Feb. 2004;106(2):135-9. Exclude: BNP measure not FDA approved. [pmid: 12974669].
Glorioso N, Argiolas G, Filigheddu F, et al. Conceptual basis and methodology of the SOPHIA study. Pharmacogenomics. 2007;8(11):1497-509. Exclude: Not a primary study. [pmid: 18034615].
Gobinet A, Valli N, Bouro F, et al. BNP (Brain Natriuretic Peptide) and heart failure. Immuno. 2000;15(3):161-8. Exclude: Not in English.
Goei D, Schouten O, Boersma E, et al. Influence of renal function on the usefulness of N-terminal pro-B-type natriuretic peptide as a prognostic cardiac risk marker in patients undergoing noncardiac vascular surgery. Am J Cardiol. Jan. 1. 2008;101(1):122-6. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18157978].
Goei D, Van Kuijk JP, Flu WJ, et al. Usefulness of repeated N-Terminal Pro-B-type natriuretic peptide measurements as incremental predictor for long-term cardiovascular outcome after vascular surgery. Am J Cardiol. 2011;107(4):609-14. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21185000].
Goel S, Simes. Exploratory analysis of cardiac biomarkers in women with normal cardiac function receiving trastuzumab for breast cancer. Asia Pacific J Clin Oncol. 2011;7(3):276-80. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Goette-Di Marco P, Talha S, Enache I, et al. Endocrine heart after lung transplantation: Increased brain natriuretic peptide is related to right ventricular function. Transpl Int. Jul. 2010;23(7):728-35. Exclude: BNP measure not FDA approved. [pmid: 20102554].
Goetze JP, Kastrup J, Pedersen F, et al. Quantification of pro-B-type natriuretic peptide and its products in human plasma by use of an analysis independent of precursor processing. Clin Chem. Jul. 2002;48(7):1035-42. Exclude: BNP measure not FDA approved. [pmid: 12089172].
Goetze JP, Christoffersen C, Perko M, et al. Increased cardiac BNP expression associated with myocardial ischemia. FASEB J. Jun. 2003;17(9):1105-7. Exclude: BNP measure not FDA approved. [pmid: 12709407].
Goetze JP, Videbaek R, Boesgaard S, et al. Pro-brain natriuretic peptide as marker of cardiovascular or pulmonary causes of dyspnea in patients with terminal parenchymal lung disease. J Heart Lung Transplant. Jan. 2004;23(1):80-7. Exclude: BNP measure not FDA approved. [pmid: 14734131].
Goetze JP, Rehfeld JF, Videbaek R, et al. B-type natriuretic peptide and its precursor in cardiac venous blood from failing hearts. Eur J Heart Fail. Jan. 2005;7(1):69-74. Exclude: BNP measure not FDA approved. [pmid: 15642534].
Goetze JP, Rehfeld JF, Carlsen J, et al. Apelin: A new plasma marker of cardiopulmonary disease. Regul Pept. Jan. 15. 2006;133(1-3):134-8. Exclude: BNP measure not FDA approved. [pmid: 16263185].
Goetze JP, Jensen G, Moller S, et al. BNP and N-terminal proBNP are both extracted in the normal kidney. Eur J Clin Invest. Jan. 2006;36(1):8-15. Exclude: BNP measure not FDA approved. [pmid: 16403004].
Goetze JP, Mogelvang R, Maage L, et al. Plasma pro-B-type natriuretic peptide in the general population: Screening for left ventricular hypertrophy and systolic dysfunction. Eur Heart J. Dec. 2006;27(24):3004-10. Exclude: BNP measure not FDA approved. [pmid: 17118955].
Goetze JP, Dahlstrom U, Rehfeld JF, et al. Impact of epitope specificity and precursor maturation in pro-B-type natriuretic peptide measurement. Clin Chem. Nov. 2008;54(11):1780-7. Exclude: BNP measure not FDA approved. [pmid: 18787017].
Golabchi A. Can atrial natriuretic peptides measurement diagnose heart failure at different age groups?. J Res Med Sci. 2012;17(1):116-7. Exclude: Not a primary study. [pmid: 23248669].
Golbasy Z, Ucar O, Yuksel AG, et al. Plasma brain natriuretic peptide levels in patients with rheumatic heart disease. Eur J Heart Fail. Oct. 2004;6(6):757-60. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 15542413].
Goldenberg D, Miller E, Perna M, et al. Association of N-terminal pro-brain natriuretic peptide with cardiac disease, but not with vascular disease, in systemic lupus erythematosus. Arthritis Rheum. Jan. 2012;64(1):316-7. Exclude: Not a primary study. [pmid: 21953476].
Goldfarb-Rumyantzev AS, Chelamcharla M, Bray BE, et al. Volume indicators and left ventricular mass during aggressive volume management in patients on thrice-weekly hemodialysis. Nephron. 2009;113(4):c270-80. Exclude: BNP measure not FDA approved. [pmid: 19684412].
Goldhammer E, Maor I, Shnitzer S, et al. The early anti-oxidant effect of carvedilol predicts the clinical course in congestive heart failure patients. J Cardiovasc Med. 2007;8(6):453-6. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Goldsmith SR, Gilbertson DT, MacKedanz SA, et al. Renal effects of conivaptan, furosemide, and the combination in patients with chronic heart failure. J Card Fail. 2011;17(12):982-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 22123359].
Gombos T, Forhecz Z, Pozsonyi Z, et al. Interaction of serum 70-kDa heat shock protein levels and HspA1B (+1267) gene polymorphism with disease severity in patients with chronic heart failure. Cell Stress & Chaperones. 2008;13(2):199-206. Exclude: BNP measure not FDA approved. [pmid: 18759004].
Gombos T, Mako V, Cervenak L, et al. Levels of von Willebrand factor antigen and von Willebrand factor cleaving protease (ADAMTS13) activity predict clinical events in chronic heart failure. Thromb Haemost. Sep. 2009;102(3):573-80. Exclude: BNP measure not FDA approved. [pmid: 19718479].
Goncalves A, Azevedo A, Almeida R, et al. Left ventricular systolic function in the prognosis of patients hospitalized due to worsening heart failure. Rev Port Cardiol. Feb. 2008;27(2):177-82. Exclude: BNP measure not FDA approved. [pmid: 18488915].
Goonewardena SN, Gemignani A, Ronan A, et al. Comparison of hand-carried ultrasound assessment of the inferior vena cava and N-terminal pro-brain natriuretic peptide for predicting readmission after hospitalization for acute decompensated heart failure. JACC Cardiovasc Imaging. Sep. 2008;1(5):595-601. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19356487].
Goonewardena SN, Blair JE, Manuchehry A, et al. Use of hand carried ultrasound, B-type natriuretic peptide, and clinical assessment in identifying abnormal left ventricular filling pressures in patients referred for right heart catheterization. J Card Fail. Jan. 2010;16(1):69-75. Exclude: BNP measure not FDA approved. [pmid: 20123321].
Goren Y, Kushnir M, Zafrir B, et al. Serum levels of microRNAs in patients with heart failure. Eur J Heart Fail. Feb. 2012;14(2):147-54. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 22120965].
Gormus U, Ozmen D, Ozmen B, et al. Serum N-terminal-pro-brain natriuretic peptide (NT-pro-BNP) and homocysteine levels in type 2 diabetic patients with asymptomatic left ventricular diastolic dysfunction. Diab Res Clin Pract. Jan. 2010;87(1):51-6. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Gosling O, Martin M, Clarke E, et al. Angiotensin II, but not aldosterone and renin, correlates positively with increased concentrations of N-terminal pro-brain natriuretic peptide in patients with chronic heart failure. Heart. Sep. 2005;91(9):1223-4. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16103571].
Goswami KG, Maisel AS, Wanner EC. Brain-type (B-type) natriuretic peptide (BNP) levels: Truly cost-effective in diagnosis of congestive heart failure (CHF)?. J Crit Illness. 2003;18(1). Exclude: Not a primary study.
Goto K, Arai M, Watanabe A, et al. Utility of echocardiography versus BNP level for the prediction of pulmonary arterial pressure in patients with pulmonary arterial hypertension. Int Heart J. 2010;51(5):343-7. Exclude: BNP measure not FDA approved. [pmid: 20966607].
Goto T, Takase H, Toriyama T, et al. Circulating concentrations of cardiac proteins indicate the severity of congestive heart failure. Heart. Nov. 2003;89(11):1303-7. Exclude: BNP measure not FDA approved. [pmid: 14594884].
Goto T, Ohte N, Wakami K, et al. Usefulness of plasma brain natriuretic peptide measurement and tissue Doppler imaging in identifying isolated left ventricular diastolic dysfunction without heart failure. Am J Cardiol. Jul. 1. 2010;106(1):87-91. Exclude: BNP measure not FDA approved. [pmid: 20609653].
Gottlieb JD, Schwartz AR, Marshall J, et al. Hypoxia, not the frequency of sleep apnea, induces acute hemodynamic stress in patients with chronic heart failure. J Am Coll Cardiol. Oct. 27. 2009;54(18):1706-12. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19850211].
Gottlieb SS, Kop WJ, Ellis SJ, et al. Relation of depression to severity of illness in heart failure (from Heart Failure And a Controlled Trial Investigating Outcomes of Exercise Training [HF-ACTION]). Am J Cardiol. 2009;103(9):1285-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19406273].
Gotzmann M, Hehen T, Germing A, et al. Short-term effects of transcatheter aortic valve implantation on neurohormonal activation, quality of life and 6-minute walk test in severe and symptomatic aortic stenosis. Heart. Jul. 2010;96(14):1102-6. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19884109].
Gotzmann MB. One-year results of transcatheter aortic valve implantation in severe symptomatic aortic valve stenosis. Am J Cardiol. 2011;107(11):1687-92. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21439537].
Gould PA, D'Agostino J, Schneider HG, et al. Influence of atrial fibrillation on cardiac brain natriuretic peptide release during haemodynamic stress in heart failure. Eur J Heart Fail. May. 2006;8(3):263-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16309956].
Gould PA, Gula LJ, Bhayana V, et al. Characterization of cardiac brain natriuretic peptide release in patients with paroxysmal atrial fibrillation undergoing left atrial ablation. Circ. Feb. 1. 2010;3(1):18-23. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Gouya GH. Benefit of specialized clinics for the treatment of patients with heart failure. Eur J Intern Med. 2011;22(4):428-31. Exclude: BNP measure not FDA approved. [pmid: 21767764].
Grabowski M, Karpinski G, Filipiak KJ, et al. Diagnostic value of BNP in suspected perimyocarditis - A preliminary report. Kardiol Pol. 2004;61(11):451-60. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 15883593].
Grabowski M, Filipiak KJ, Karpinski G, et al. Serum B-type natriuretic peptide levels on admission predict not only short-term death but also angiographic success of procedure in patients with acute ST-elevation myocardial infarction treated with primary angioplasty. Am Heart J. Oct. 2004;148(4):655-62. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 15459597].
Grandin EW, Jarolim P, Murphy SA, et al. Galectin-3 and the development of heart failure after acute coronary syndrome: Pilot experience from PROVE IT-TIMI 22. Clin Chem. Jan. 2012;58(1):267-73. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 22110019].
Granja CA, Tailor PT, Gorban-Brennan N, et al. Brain natriuretic peptide and impedance cardiography to assess volume status in peritoneal dialysis patients. Adv Perit Dial Conf. 2007;23:155-60. Exclude: BNP measure not FDA approved.
Grassi P, Buscema G, Rinaldi A, et al. B-type natriuretic peptide in healthy subjects after exposure to hyperbaric oxygen at 2.5 ATA. Aviat Space Environ Med. Jan. 2007;78(1):52-3. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17225483].
Grasso S, Leone A, De Michele M, et al. Use of N-terminal pro-brain natriuretic peptide to detect acute cardiac dysfunction during weaning failure in difficult-to-wean patients with chronic obstructive pulmonary disease. Crit Care Med. Jan. 2007;35(1):96-105. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17095948].
Grauslund J, Nybo M, Green A, et al. N-terminal pro brain natriuretic peptide reflects long-term complications in type 1 diabetes. Scand J Clin Lab Invest. Oct. 2010;70(6):392-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20575653].
Greco S, Troisi F, Brunetti ND, et al. Tei index correlates with tissue Doppler parameters and reflects neurohormonal activation in patients with an abnormal transmitral flow pattern. Echocardiograph. Oct. 2009;26(9):1012-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Green SM, Redmond P, Januzzi JL, et al. The impact of amino-terminal pro-brain natriuretic peptide testing on hospital length of stay and morbidity in patients with acute decompensated heart failure. Arch Pathol Lab Med. Mar. 2007;131(3):473-6. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17516751].
Greenberg BH, Mehra M, Teerlink JR, et al. COMPARE: Comparison of the effects of carvedilol CR and carvedilol IR on left ventricular ejection fraction in patients with heart failure. Am J Cardiol. Oct. 2. 2006;98(7A):53-9. Exclude: Not a primary study.
Gremmler B, Ulbricht L, Kosch M, et al. Combined antihypertensive therapy improves moderate heart failure. J Hypertens. 2003;21(11):2195. Exclude: Not a primary study. [pmid: 14597865].
Gremmler B, Kunert M, Schleiting H, et al. Relation between N-terminal pro-brain natriuretic peptide values and invasively measured left ventricular hemodynamic indices. Exp Clin Cardiol. 2003;8(2):91-4. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19641656].
Gremmler B, Kisters K, Kunert M, et al. Does a correlation of NT-proBNP-values exist in comparison to pulse pressure-values?. Trace Elem Electrolytes. 2005;22(1):62-5. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Grewal J, McKelvie R, Lonn E, et al. BNP and NT-proBNP predict echocardiographic severity of diastolic dysfunction. Eur J Heart Fail. Mar. 2008;10(3):252-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18331967].
Groenning BA, Nilsson JC, Sondergaard L, et al. Evaluation of impaired left ventricular ejection fraction and increased dimensions by multiple neurohumoral plasma concentrations. Eur J Heart Fail. Dec. 2001;3(6):699-708. Exclude: BNP measure not FDA approved. [pmid: 11738222].
Groenning BA, Nilsson JC, Sondergaard L, et al. Detection of left ventricular enlargement and impaired systolic function with plasma N-terminal pro brain natriuretic peptide concentrations. Am Heart J. May. 2002;143(5):923-9. Exclude: BNP measure not FDA approved. [pmid: 12040359].
Groenning BA, Nilsson JC, Hildebrandt PR, et al. Neurohumoral prediction of left-ventricular morphologic response to beta-blockade with metoprolol in chronic left-ventricular systolic heart failure. Eur J Heart Fail. 2002;4(5):635-46. Exclude: BNP measure not FDA approved. [pmid: 12413508].
Groenning BA, Raymond I, Hildebrandt PR, et al. Diagnostic and prognostic evaluation of left ventricular systolic heart failure by plasma N-terminal pro-brain natriuretic peptide concentrations in a large sample of the general population. Heart. Mar. 2004;90(3):297-303. Exclude: BNP measure not FDA approved. [pmid: 14966052].
Gruner SB, Cider A, Tang MS, et al. Benefit of warm water immersion on biventricular function in patients with chronic heart failure. Cardiovasc Ultrasound. 2009;7:33. Exclude: BNP measure not FDA approved. [pmid: 19580653].
Gruson D, Rousseau MF, Ahn SA, et al. Circulating urotensin II levels in moderate to severe congestive heart failure: Its relations with myocardial function and well established neurohormonal markers. Peptides. Jun. 2006;27(6):1527-31. Exclude: BNP measure not FDA approved. [pmid: 16364499].
Gruson D, Ahn SA, Ketelslegers JM, et al. Circulating levels of stress associated peptide Urocortin in heart failure patients. Peptides. Feb. 2010;31(2):354-6. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19961889].
Gruson D, Ahn SA, Ketelslegers JM, et al. Increased plasma myostatin in heart failure. Eur J Heart Fail. Jul. 2011;13(7):734-6. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21467027].
Gruson D, Ahn SA, Lepoutre T, et al. Measurement of NT-proBNP with LOCI technology in heart failure patients. Clin Biochem. 2012;45(1-2):171-4. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21843519].
Grybauskiene R, Karciauskaite D, Brazdzionyte J, et al. Brain natriuretic peptide and other cardiac markers predicting left ventricular remodeling and function two years after myocardial infarction. Medicina. 2007;43(9):708-15. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17986844].
Grzebieniak T, Jolda-Mydlowska B, Arkowski J, et al. The influence of increasing physical effort on the concentrations of selected neurohormonal factors in patients with heart failure. Adv Clin Exp Med. 2010;19(2):185-93. Exclude: BNP measure not FDA approved.
Guazzi M, Boracchi P, Labate V, et al. Exercise oscillatory breathing and NT-proBNP levels in stable heart failure provide the strongest prediction of cardiac outcome when combining biomarkers with cardiopulmonary exercise testing. J Card Fail. 2012;18(4):313-20. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 22464773].
Gudmundsson KL. Midsummer Eve in Sweden: A natural fluid challenge in patients with heart failure. Eur J Heart Fail. 2011;13(11):1172-7. Exclude: BNP measure not FDA approved. [pmid: 21979992].
Gueant-Rodriguez RM, Juilliere Y, Nippert M, et al. Left ventricular systolic dysfunction is an independent predictor of homocysteine in angiographically documented patients with or without coronary artery lesions. J Thromb Haemostasis. Jun. 2007;5(6):1209-16. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17403112].
Guglin M, Hourani R, Pitta S. Factors determining extreme brain natriuretic peptide elevation. Congest Heart Fail. May. 2007;13(3):136-41. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17541308].
Guidez T, Marechaux S, Pincon C, et al. Addition of B-type natriuretic peptide to the GRACE score to predict outcome in acute coronary syndrome: a retrospective (development) and prospective (validation) cohort-based study. Emerg Med J. Apr. 2012;29(4):274-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21521903].
Guiraudet O, Lambert dC, Bonnevie L, et al. Evaluation of heart failure management in a Military Hospital. Arch Cardiovasc Dis. Apr. 2008;101(4):235-41. Exclude: BNP measure not FDA approved. [pmid: 18654098].
Guldner L, Haddy N, Pein F, et al. Radiation dose and long term risk of cardiac pathology following radiotherapy and anthracyclin for a childhood cancer. Radiother Oncol. 2006;81(1):47-56. Exclude: Population aged under 18. [pmid: 16989913].
Gundogdu F, Bozkurt E, Kiziltunc A, et al. The effect of beta-blocker (carvedilol) therapy on N-terminal pro-brain natriuretic peptide levels and echocardiographic findings in patients with congestive heart failure. Echocardiograph. Feb. 2007;24(2):113-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Gunes Y, Okcun B, Kavlak E, et al. Value of brain natriuretic peptide after acute myocardial infarction. Anadolu Kardiyol Derg. Jun. 2008;8(3):182-7. Exclude: BNP measure not FDA approved. [pmid: 18524723].
Gunstad J, Poppas A, Smeal S, et al. Relation of brain natriuretic peptide levels to cognitive dysfunction in adults > 55 years of age with cardiovascular disease. Am J Cardiol. Aug. 15. 2006;98(4):538-40. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16893713].
Guo J, H L. Protective effect of spironolactone on myocardium during perioperation period of percataneous coronary intervention. Acad J Second Military Med U. 2011;32(8):889-92. Exclude: Not in English.
Gupta S, Khan F, Shapiro M, et al. The associations between tricuspid annular plane systolic excursion (TAPSE), ventricular dyssynchrony, and ventricular interaction in heart failure patients. Eur J Echocardiogr. Nov. 2008;9(6):766-71. Exclude: BNP measure not FDA approved. [pmid: 18490286].
Gupta S, Berry JD, Ayers CR, et al. Association of Health Aging and Body Composition (ABC) Heart Failure score with cardiac structural and functional abnormalities in young individuals. Am Heart J. May. 2010;159(5):817-24. Exclude: BNP measure not FDA approved. [pmid: 20435191].
Gupta S, Waywell C, Gandhi N, et al. The effects of adding torasemide to standard therapy on peak oxygen consumption, natriuretic peptides, and quality of life in patients with compensated left ventricular systolic dysfunction. Eur J Heart Fail. Jul. 2010;12(7):746-52. Exclude: BNP measure not FDA approved. [pmid: 20525705].
Gupta S, Rohatgi A, Ayers CR, et al. Risk scores versus natriuretic peptides for identifying prevalent stage B heart failure. Am Heart J. May. 2011;161(5):923-30. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21570524].
Gur S, Dursunoglu D, Dursunoglu N, et al. Acute effects of adaptive servo-ventilation therapy on neurohormones and Cheyne-Stokes respiration in the patients with heart failure. Anadolu Kardiyol Derg. Jun. 2009;9(3):206-14. Exclude: Not in English. [pmid: 19520655].
Gurgun C, Ildizli M, Yavuzgil O, et al. The effects of short term statin treatment on left ventricular function and inflammatory markers in patients with chronic heart failure. Int J Cardiol. 2008;123(2):102-7. Exclude: BNP measure not FDA approved. [pmid: 17320212].
Gustafsson S, Lind L, Zethelius B, et al. Adiponectin and cardiac geometry and function in elderly: Results from two community-based cohort studies. Eur J Endocrinol. Mar. 2010;162(3):543-50. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20008076].
Gutte H, Mortensen J, Jensen CV, et al. ANP, BNP and D-dimer predict right ventricular dysfunction in patients with acute pulmonary embolism. Clin Physiol Funct Imag. Nov. 2010;30(6):466-72. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Gwechenberger M, Hulsmann M, Berger R, et al. Interleukin-6 and B-type natriuretic peptide are independent predictors for worsening of heart failure in patients with progressive congestive heart failure. J Heart Lung Transplant. Jul. 2004;23(7):839-44. Exclude: BNP measure not FDA approved. [pmid: 15261178].
Gwechenberger M, Huelsmann M, Graf S, et al. Natriuretic peptides and the prevalence of congestive heart failure in patients with pacemakers. Eur J Clin Invest. Dec. 2004;34(12):811-7. Exclude: BNP measure not FDA approved. [pmid: 15606723].
Gwechenberger M, Pacher R, Berger R, et al. Comparison of soluble glycoprotein 130 and cardiac natriuretic peptides as long-term predictors of heart failure progression. J Heart Lung Transplant. Dec. 2005;24(12):2190-5. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16364870].
Ha JW, Ahn JA, Moon JY, et al. Triphasic mitral inflow velocity with mid-diastolic flow: The presence of mid-diastolic mitral annular velocity indicates advanced diastolic dysfunction. Eur J Echocardiogr. Jan. 2006;7(1):16-21. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16378917].
Ha SI, C. Stroke prediction using mean platelet volume in patients with atrial fibrillation. Platelets. 2011;22(6):408-14. Exclude: BNP measure not FDA approved. [pmid: 21599611].
Hadase M, Azuma A, Zen K, et al. Very low frequency power of heart rate variability is a powerful predictor of clinical prognosis in patients with congestive heart failure. Circ J. Apr. 2004;68(4):343-7. Exclude: BNP measure not FDA approved. [pmid: 15056832].
Hadzovic-Dzuvo A, Kucukalic-Selimovic E, Nakas-Icindic E, et al. N-terminal pro-brain natriuretic peptide (NT-proBNP) serum concentrations in apparently healthy Bosnian women. Bosnian J Basic Med Sci. Nov. 2007;7(4):307-10. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Haghjoo M, Bonakdar HR, Jorat MV, et al. Effect of right ventricular lead location on response to cardiac resynchronization therapy in patients with end-stage heart failure. Europace. Mar. 2009;11(3):356-63. Exclude: BNP measure not FDA approved. [pmid: 19136489].
Hajsadeghi S, Samiei N, Moradi M, et al. Comparison of N-terminal pro B-natriuretic peptide and echocardiographic indices in patients with mitral regurgitation. Clin Med Insights Cardiol. 2010;4:111-6. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21151851].
Hak JK, Jeon ES, Choi JO, et al. N-terminal pro B-type natriuretic peptide predicts cardiac events in discharged patients with idiopathic dilated cardiomyopathy. Korean Circ J. 2007;37(5):202-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Hakala T, Hedman A, Turpeinen A, et al. Prediction of atrial fibrillation after coronary artery bypass grafting by measuring atrial peptide levels and preoperative atrial dimensions. Eur J Cardiothorac Surg. Dec. 2002;22(6):939-43. Exclude: BNP measure not FDA approved. [pmid: 12467817].
Halasyamani LK, Czerwinski J, Clinard R, et al. An electronic strategy to identify hospitalized heart failure patients. J Hosp Med. 2007;2(6):409-14. Exclude: BNP measure not FDA approved. [pmid: 18081171].
Halbirk M, Norrelund H, Moller N, et al. Cardiovascular and metabolic effects of 48-h glucagon-like peptide-1 infusion in compensated chronic patients with heart failure. Am J Physiol Heart Circ Physiol. Mar. 2010;298(3):H1096-102. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20081109].
Halbirk M, Norrelund H, Moller N, et al. Suppression of circulating free fatty acids with acipimox in chronic heart failure patients changes whole body metabolism but does not affect cardiac function. Am J Physiol Heart Circ Physiol. Oct. 2010;299(4):H1220-5. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20709866].
Halbirk M, Norrelund H, Moller N, et al. Short-term changes in circulating insulin and free fatty acids affect Nt-pro-BNP levels in heart failure patients. Int J Cardiol. 2010;144(1):140-2. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19176258].
Hama N, Itoh H, Shirakami G, et al. Detection of C-type natriuretic peptide in human circulation and marked increase of plasma CNP level in septic shock patients. Biochem Biophys Res Commun. Feb. 15. 1994;198(3):1177-82. Exclude: BNP measure not FDA approved. [pmid: 8117275].
Hamada Y, Tanaka N, Murata K, et al. Significance of predischarge BNP on one-year outcome in decompensated heart failure-comparative study with echo-Doppler indexes. J Card Fail. Feb. 2005;11(1):43-9. Exclude: BNP measure not FDA approved. [pmid: 15704063].
Hamilton AJ, Swales LA, Neill J, et al. Risk stratification of chest pain patients in the emergency department by a nurse utilizing a point of care protocol. Eur J Emerg Med. Feb. 2008;15(1):9-15. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18180660].
Hammerer-Lercher A, Neubauer E, Muller S, et al. Head-to-head comparison of N-terminal pro-brain natriuretic peptide, brain natriuretic peptide and N-terminal pro-atrial natriuretic peptide in diagnosing left ventricular dysfunction. Clin Chim Acta. Aug. 20. 2001;310(2):193-7. Exclude: BNP measure not FDA approved. [pmid: 11498085].
Hammerer-Lercher A, Polzl G, Falkensammer G, et al. B-type natriuretic peptide and N-terminal pro B-type natriuretic peptide are comparably useful for disease monitoring in heart failure. Int J Cardiol. Jan. 26. 2006;106(3):415-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16337058].
Hampole CV, Mehrotra AK, Thenappan T, et al. Usefulness of red cell distribution width as a prognostic marker in pulmonary hypertension. Am J Cardiol. Sep. 15. 2009;104(6):868-72. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19733726].
Han CH, Choi JE, Chung JH. Clinical utility of pleural fluid NT-pro brain natriuretic peptide (NT-proBNP) in patients with pleural effusions. Intern Med. 2008;47(19):1669-74. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18827414].
Han ZH, Wu XS, Zhang XX, et al. The primary observation on the effect of pravastatin to non-ischemic heart failure. Chin J Cardiovasc Dis. Jul. 2007;35(7):603-6. Exclude: Not in English.
Hanssen H, Keithahn A, Hertel G, et al. Magnetic resonance imaging of myocardial injury and ventricular torsion after marathon running. Clin Sci. Feb. 2011;120(4):143-52. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20815809].
Hara K, Uchida T, Takebayashi K, et al. Determinants of serum high molecular weight (HMW) adiponectin levels in patients with coronary artery disease: Associations with cardio-renal-anemia syndrome. Intern Med. 2011;50(24):2953-60. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 22185985].
Hara T, Yamashiro K, Okajima K, et al. Posterior shift of the anterior papillary muscle in patients with heart failure: A potential role in the effect of cardiac resynchronization therapy. Int Heart J. Nov. 2009;50(6):773-82. Exclude: BNP measure not FDA approved. [pmid: 19952474].
Hara Y, Hamada M, Shigematsu Y, et al. Effect of beta-blocker on left ventricular function and natriuretic peptides in patients with chronic heart failure treated with angiotensin-converting enzyme inhibitor. Jpn Circ J. May. 2000;64(5):365-9. Exclude: BNP measure not FDA approved. [pmid: 10834452].
Hara Y, Hamada M, Shigematsu Y, et al. Beneficial effect of beta-adrenergic blockade on left ventricular function in haemodialysis patients. Clin Sci. Sep. 2001;101(3):219-25. Exclude: BNP measure not FDA approved. [pmid: 11524038].
Hara Y, Hamada M, Shigematsu Y, et al. Beneficial effect of replacing of angiotensin-converting enzyme inhibitor with angiotensin II antagonist for heart failure patients. J Clin Pharm Ther. Aug. 2002;27(4):267-71. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 12174028].
Harada M, Hara F, Yamazaki J. Correlation between plasma B-type natriuretic peptide levels and left ventricular diastolic function using color kinetic imaging. J Cardiol. Jul. 2010;56(1):91-6. Exclude: BNP measure not FDA approved. [pmid: 20447804].
Harkness JR, Morrow DA, Braunwald E, et al. Myocardial ischemia and ventricular tachycardia on continuous electrocardiographic monitoring and risk of cardiovascular outcomes after non-ST-segment elevation acute coronary syndrome (from the MERLIN-TIMI 36 Trial). Am J Cardiol. Nov. 15. 2011;108(10):1373-81. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21890090].
Harris S, Tepper D, Ip R. Dynamic cardiovascular risk assessment in elderly people. Congest Heart Fail. 2010;16(4):189-90. Exclude: Not a primary study.
Harrison A, Morrison LK, Krishnaswamy P, et al. B-type natriuretic peptide predicts future cardiac events in patients presenting to the emergency department with dyspnea. Ann Emerg Med. Feb. 2002;39(2):131-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 11823766].
Hartemink KJ, Twisk JWR, Groeneveld ABJ. High circulating N-terminal pro-B-type natriuretic peptide is associated with greater systolic cardiac dysfunction and nonresponsiveness to fluids in septic vs nonseptic critically ill patients. J Crit Care. 2011;26(1):108. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20646903].
Hartmann F, Kurowski V, Maghsoudi A, et al. Plasma catecholamines and N-terminal proBNP in patients with acute myocardial infarction undergoing primary angioplasty. Relation to left ventricular function and clinical outcome. Z Kardiol. Jan. 2003;92(1):73-81. Exclude: BNP measure not FDA approved. [pmid: 12545304].
Hartmann F, Packer M, Coats AJ, et al. NT-proBNP in severe chronic heart failure: Rationale, design and preliminary results of the COPERNICUS NT-proBNP substudy. Eur J Heart Fail. Mar. 15. 2004;6(3):343-50. Exclude: BNP measure not FDA approved. [pmid: 14987586].
Hartog JW, Voors AA, Schalkwijk CG, et al. Clinical and prognostic value of advanced glycation end-products in chronic heart failure. Eur Heart J. Dec. 2007;28(23):2879-85. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17986469].
Hasegawa K, Fujiwara H, Doyama K, et al. Ventricular expression of brain natriuretic peptide in hypertrophic cardiomyopathy. Circ. Aug. 1993;88(2):372-80. Exclude: BNP measure not FDA approved.
Hassan N, Mertes PM, Mercenier C, et al. Non-viable myocardium, documented by TL-201 SPECT, is a main determinant of the increase in the secretion of cardiac natriuretic peptides. Med Nucl. 2000;24(6):301-10. Exclude: Not in English.
Hasselblad V, Gattis SW, Shah MR, et al. Relation between dose of loop diuretics and outcomes in a heart failure population: Results of the ESCAPE trial. Eur J Heart Fail. Oct. 2007;9(10):1064-9. Exclude: BNP measure not FDA approved. [pmid: 17719273].
Hastings PC, Vazir A, Meadows GE, et al. Adaptive servo-ventilation in heart failure patients with sleep apnea: A real world study. Int J Cardiol. Feb. 18. 2010;139(1):17-24. Exclude: BNP measure not FDA approved. [pmid: 18805598].
Hata N, Seino Y, Tsutamoto T, et al. Effects of carperitide on the long-term prognosis of patients with acute decompensated chronic heart failure: the PROTECT multicenter randomized controlled study. Circ J. Nov. 2008;72(11):1787-93. Exclude: BNP measure not FDA approved. [pmid: 18812677].
Haugen E, Furukawa Y, Isic A, et al. Increased adiponectin level in parallel with increased NT-pro BNP in patients with severe heart failure in the elderly: A hospital cohort study. Int J Cardiol. Apr. 10. 2008;125(2):216-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18234365].
Hawkins RC, Chung KN. B-type natriuretic peptide testing is associated with reduced cost in patients with secondary diagnosis of heart failure. Clin Chim Acta. Feb. 2007;377(1-2):276-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17140557].
Hawkins RC. A model of the effect of analytical bias on clinical classification using the example of brain natriuretic peptide measurement. Clin Chim Acta. 2012;413(11-12):1022-3. Exclude: Not a primary study. [pmid: 22425881].
Hayabuchi Y, I. Serum concentration of heart-type fatty acid-binding protein in children and adolescents with congenital heart disease. Circ J. 2011;75(8):1992-7. Exclude: Population aged under 18. [pmid: 21617322].
Hayashi T, Nomura H, Osawa M, et al. Nitric oxide metabolites are associated with survival in older patients. J Am Geriatr Soc. Sep. 2007;55(9):1398-403. Exclude: BNP measure not FDA approved. [pmid: 17767681].
Hazukova R, Pleskot M, Havlicek A. Increase in B-type natriuretic peptide following reprogramming from chronic biventricular pacing to isolated right ventricular. Cor et Vasa. 2008;50(5):195-9. Exclude: Not in English.
Heart Protection Study Collaborative Group, Emberson JR, Ng LL, et al. N-terminal pro-B-type natriuretic peptide, vascular disease risk, and cholesterol reduction among 20,536 patients in the MRC/BHF heart protection study. J Am Coll Cardiol. Jan. 23. 2007;49(3):311-9. Exclude: BNP measure not FDA approved. [pmid: 17239712].
Hebert K, Horswell R, Heidenreich P, et al. Handheld ultrasound, B-natriuretic peptide for screening stage B heart failure. South Med J. Jul. 2010;103(7):616-22. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20531053].
Hedberg P, Lonnberg I, Jonason T, et al. Electrocardiogram and B-type natriuretic peptide as screening tools for left ventricular systolic dysfunction in a population-based sample of 75-year-old men and women. Am Heart J. Sep. 2004;148(3):524-9. Exclude: BNP measure not FDA approved. [pmid: 15389243].
Heeschen C, Hamm CW, Mitrovic V, et al. N-terminal pro-B-type natriuretic peptide levels for dynamic risk stratification of patients with acute coronary syndromes. Circ. Nov. 16. 2004;110(20):3206-12. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Heidenreich PA, Gubens MA, Fonarow GC, et al. Cost-effectiveness of screening with B-type natriuretic peptide to identify patients with reduced left ventricular ejection fraction. J Am Coll Cardiol. Mar. 17. 2004;43(6):1019-26. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 15028361].
Heidenreich PA, Spertus JA, Jones PG, et al. Health status identifies heart failure outpatients at risk for hospitalization or death. J Am Coll Cardiol. Feb. 21. 2006;47(4):752-6. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16487840].
Heinrich K, Prendergast HM, Erickson T. Chronic digoxin toxicity and significantly elevated BNP levels in the presence of mild heart failure. Am J Emerg Med. Jul. 2005;23(4):561-2. Exclude: Case report. [pmid: 16032632].
Hejmdal A, Boesgaard S, Lindholm MG, et al. B-type natriuretic peptide and its molecular precursor in myocardial infarction complicated by cardiogenic shock. J Card Fail. Apr. 2007;13(3):184-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17448415].
Helal I, Belhadj R, Mohseni A, et al. Clinical significance of N-terminal Pro-B-type natriuretic peptide (NT-proBNP) in hemodialysis patients. Saudi J Kidney Dis Transplant. Mar. 2010;21(2):262-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Hendrichova M, Malek F, Koprivova H, et al. Correlation of NT-proBNP with metabolic liver function as assessed with (13)C-methacetin breath test in patients with acute decompensated heart failure. Int J Cardiol. Oct. 8. 2010;144(2):321-2. Exclude: BNP measure not FDA approved. [pmid: 19297040].
Henry-Okafor Q, Collins SP, Jenkins CA, et al. Soluble ST2 as a diagnostic and prognostic marker for acute heart failure syndromes. Open Biomarkers J. 2012;5(1):1-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Henry J, Casjens S, Schikowski T, et al. Prohepcidin, B-type natriuretic peptide, and iron status in a cohort of elderly women from the Rhine-Ruhr area. Acta Haematol. 2010;124(3):129-33. Exclude: BNP measure not FDA approved. [pmid: 20881378].
Heringlake M, Heide C, Bahlmann L, et al. Effects of tilting and volume loading on plasma levels and urinary excretion of relaxin, NT-pro-ANP, and NT-pro-BNP in male volunteers. J Appl Physiol. Jul. 2004;97(1):173-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 14990550].
Heringlake M, Kox T, Uzun O, et al. The relationship between urotensin II plasma immunoreactivity and left ventricular filling pressures in coronary artery disease. Regul Pept. Sep. 15. 2004;121(1-3):129-36. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 15256283].
Heringlake M, Kox T, Poeling J, et al. The effects of physical exercise on plasma levels of relaxin, NTproANP, and NTproBNP in patients with ischemic heart disease. Eur J Med Res. Mar. 17. 2009;14(3):106-12. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19380280].
Heringlake M, Garbers C, Kabler JH, et al. Preoperative cerebral oxygen saturation and clinical outcomes in cardiac surgery. Anesthesiol. Jan. 2011;114(1):58-69. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Hermann-Arnhof KM, Hanusch-Enserer U, Kaestenbauer T, et al. N-terminal pro-B-type natriuretic peptide as an indicator of possible cardiovascular disease in severely obese individuals: Comparison with patients in different stages of heart failure. Clin Chem. Jan. 2005;51(1):138-43. Exclude: BNP measure not FDA approved. [pmid: 15550477].
Hermans MP, Ahn SA, Rousseau MF. Raised natriuretic peptides, big-endothelin-1 and improved beta-cell function in type 2 diabetic males with hyperuricaemia. Diab Vasc Dis Res. Jul. 2009;6(3):190-3. Exclude: BNP measure not FDA approved. [pmid: 20368210].
Hernandez A, ez DM, Escobar CC, et al. Usefulness of brain natriuretic peptide to evaluate patients with heart failure treated with cardiac resynchronization. Rev Esp Cardiol. 2004;57(4):299-305. Exclude: BNP measure not FDA approved. [pmid: 15104983].
Hernandez AF, O'Connor CM, Starling RC, et al. Rationale and design of the Acute Study of Clinical Effectiveness of Nesiritide in Decompensated Heart Failure Trial (ASCEND-HF). Am Heart J. Feb. 2009;157(2):271-7. Exclude: Not a primary study. [pmid: 19185633].
Herout PM, Harshaw Q, Phatak H, et al. Impact of worsening renal function during hospital admission on resource utilization in patients with heart failure. Am J Cardiol. 2010;106(8):1139-45. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20920654].
Herrmann M, Stanger O, Paulweber B, et al. Effect of folate supplementation on N-terminal pro-brain natriuretic peptide. Int J Cardiol. 2007;118(2):267-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17052779].
Herrmann M, Muller S, Kindermann I, et al. Plasma B vitamins and their relation to the severity of chronic heart failure. Am J Clin Nutr. Jan. 2007;85(1):117-23. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17209186].
Hervas I, Osca J, Perez-Pastor JL, et al. Radioimmunometric assay of natriuretic peptide type-B (BNP) in heart failure. Nucl Med Commun. Jan. 2003;24(1):61-9. Exclude: BNP measure not FDA approved. [pmid: 12501021].
Hess G, Moecks J, Zdunek D. N-Terminal-proBNP (NT-proBNP) as an indicator of cardiac dysfunction. A study in patients presenting with suspected cardiac disorders. Z Kardiol. Apr. 2005;94(4):247-54. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 15803261].
Hess G, Runkel S, Zdunek D, et al. N-terminal pro-brain natriuretic peptide (NT-proBNP) in healthy blood donors and in patients from general practitioners with and without a diagnosis of cardiac disease. Clin Lab. 2005;51(3-4):167-72. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 15819172].
Hessel MH, Bleeker GB, Bax JJ, et al. Reverse ventricular remodelling after cardiac resynchronization therapy is associated with a reduction in serum tenascin-C and plasma matrix metalloproteinase-9 levels. Eur J Heart Fail. Oct. 2007;9(10):1058-63. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17728181].
Hettwer S, Panzner-Grote B, Witthaut R, et al. Isolated diastolic dysfunction--diagnostic value of tissue Doppler imaging, colour M-mode and N-terminal pro B-type natriuretic peptide. Clin Res Cardiol. Dec. 2007;96(12):874-82. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17874035].
Hickman PE, McGill DA, Talaulikar G, et al. Prognostic efficacy of cardiac biomarkers for mortality in dialysis patients. Intern Med J. Dec. 2009;39(12):812-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20233242].
Higashi K, Tanaka H, Shimokawahara H, et al. Irrelevant B-type natriuretic peptide levels in patients with mechanical prostheses in the mitral position presenting with congestive heart failure. Circ J. Aug. 2010;74(8):1584-90. Exclude: BNP measure not FDA approved. [pmid: 20606330].
Hijazi Z, Oldgren J, Andersson U, et al. Cardiac biomarkers are associated with an increased risk of stroke and death in patients with atrial fibrillation: A Randomized Evaluation of Long-term Anticoagulation Therapy (RE-LY) substudy. Circ. Apr. 3. 2012;125(13):1605-16. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Hildebrandt P, Boesen M, Olsen M, et al. N-terminal pro brain natriuretic peptide in arterial hypertension--A marker for left ventricular dimensions and prognosis. Eur J Heart Fail. Mar. 15. 2004;6(3):313-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 14987582].
Hill A, Rother RP, Wang X, et al. Effect of eculizumab on haemolysis-associated nitric oxide depletion, dyspnoea, and measures of pulmonary hypertension in patients with paroxysmal nocturnal haemoglobinuria. Br J Haematol. May. 2010;149(3):414-25. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20230403].
Hill JA, Hsu K, Pauly DF, et al. Sustained use of nesiritide to aid in bridging to heart transplant. Clin Cardiol. May. 2003;26(5):211-4. Exclude: BNP measure not FDA approved. [pmid: 12769247].
Hillock RJ, Frampton CM, Yandle TG, et al. B-type natriuretic peptide infusions in acute myocardial infarction. Heart. May. 2008;94(5):617-22. Exclude: BNP measure not FDA approved. [pmid: 17639095].
Hiramatsu T, Furuta S, Kakuta H. Favorable changes in lipid metabolism and cardiovascular parameters after icodextrin use in peritoneal dialysis patients. Adv Perit Dial Conf. 2007;23:58-61. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Hirashiki A, Izawa H, Somura F, et al. Prognostic value of pacing-induced mechanical alternans in patients with mild-to-moderate idiopathic dilated cardiomyopathy in sinus rhythm. J Am Coll Cardiol. 2006;47(7):1382-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16580526].
Hirayama N, Kitamura K, Imamura T, et al. Molecular forms of circulating adrenomedullin in patients with congestive heart failure. J Endocrinol. Feb. 1999;160(2):297-303. Exclude: BNP measure not FDA approved. [pmid: 9924200].
Hiremath S, Doucette SP, Richardson R, et al. Left ventricular growth after 1 year of haemodialysis does not correlate with arteriovenous access flow: A prospective cohort study. Nephrol Dial Transplant. Aug. 2010;25(8):2656-61. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20185857].
Hisatake S, Nanjo. Comparative analysis of the therapeutic effects of long-acting and short-acting loop diuretics in the treatment of chronic heart failure using 123I-metaiodobenzylguanidine scintigraphy. Eur J Heart Fail. 2011;13(8):892-8. Exclude: BNP measure not FDA approved. [pmid: 21602550].
Ho WJ, Hsu TS, Tsay PK, et al. Serial plasma brain natriuretic peptide testing in clinical management of pulmonary arterial hypertension. Acta Cardiol Sin. 2009;25(3):147-53. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Ho YL, Lin YH, Lee CM, et al. Prognostic significance of adipocytokines and extracellular matrix activity in heart failure patients with high B-type natriuretic peptide. Clin Biochem. 2009;42(13-14):1407-12. Exclude: BNP measure not FDA approved. [pmid: 19560452].
Hobbs FD, Davis RC, Roalfe AK, et al. Reliability of N-terminal pro-brain natriuretic peptide assay in diagnosis of heart failure: Cohort study in representative and high risk community populations. BMJ. Jun. 22. 2002;324(7352):1498. Exclude: BNP measure not FDA approved. [pmid: 12077039].
Hobbs RE, Miller LW, Bott-Silverman C, et al. Hemodynamic effects of a single intravenous injection of synthetic human brain natriuretic peptide in patients with heart failure secondary to ischemic or idiopathic dilated cardiomyopathy. Am J Cardiol. Oct. 15. 1996;78(8):896-901. Exclude: BNP measure not FDA approved. [pmid: 8888662].
Hoekema A, Voors AA, Wijkstra PJ, et al. Effects of oral appliances and CPAP on the left ventricle and natriuretic peptides. Int J Cardiol. Aug. 18. 2008;128(2):232-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17727981].
Hoekstra T, L-L I. Quality of life is impaired similarly in heart failure patients with preserved and reduced ejection fraction. Eur J Heart Fail. 2011;13(9):1013-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21712287].
Hofer PS. Amino-terminal pro-B-type brain natriuretic peptide: Screening for cardiovascular disease in the setting of alcoholism. Alcohol Alcohol. 2011;46(3):247-52. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21508196].
Hofsten DE, Logstrup BB, Moller JE, et al. Abnormal glucose metabolism in acute myocardial infarction: Influence on left ventricular function and prognosis. JACC Cardiovasc Imaging. May. 2009;2(5):592-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19442946].
Hogan CJ, Ward KR, Kontos MC, et al. Peripheral tissue oxygenation improves during ED treatment of acute heart failure. Am J Emerg Med. Jan. 2012;30(1):196-202. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21208761].
Hogenhuis J, Voors AA, Jaarsma T, et al. Influence of age on natriuretic peptides in patients with chronic heart failure: A comparison between ANP/NT-ANP and BNP/NT-proBNP. Eur J Heart Fail. Jan. 2005;7(1):81-6. Exclude: BNP measure not FDA approved. [pmid: 15642536].
Hogenhuis J, Jaarsma T, Voors AA, et al. Correlates of B-type natriuretic peptide and 6-min walk in heart failure patients. Int J Cardiol. Mar. 22. 2006;108(1):63-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16516699].
Hogenhuis J, Voors AA, Jaarsma T, et al. Low prevalence of B-type natriuretic peptide levels < 100 pg/mL in patients with heart failure at hospital discharge. Am Heart J. May. 2006;151(5):1012-5. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16644323].
Hogenhuis J, Voors AA, Jaarsma T, et al. Anaemia and renal dysfunction are independently associated with BNP and NT-proBNP levels in patients with heart failure. Eur J Heart Fail. Aug. 2007;9(8):787-94. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17532262].
Hogg KJ, Jenkins SMM. Prognostication or identification of palliative needs in advanced heart failure: Where should the focus lie?. Heart. 2012;98(7):523-4. Exclude: Not a primary study. [pmid: 22422741].
Hohensinner PJ, Rychli K, Zorn G, et al. Macrophage-modulating cytokines predict adverse outcome in heart failure. Thromb Haemost. Feb. 2010;103(2):435-41. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20076846].
Hoiczyk M, Iliodromitis K, Bauer S, et al. Intimal sarcoma of the pulmonary artery with unusual findings: A case report. Clin Res Cardiol. 2012;101(5):397-401. Exclude: Not a primary study. [pmid: 22362501].
Hoijer CJ, Meurling C, Brandt J. Upgrade to biventricular pacing in patients with conventional pacemakers and heart failure: A double-blind, randomized crossover study. Europace. Jan. 2006;8(1):51-5. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16627409].
Hokamaki J, Kawano H, Yoshimura M, et al. Urinary biopyrrins levels are elevated in relation to severity of heart failure. J Am Coll Cardiol. May. 2004;43(10):1880-5. Exclude: BNP measure not FDA approved. [pmid: 15145115].
Hole T, Grundtvig M, Gullestad L, et al. Improved quality of life in Norwegian heart failure patients after follow-up in outpatient heart failure clinics: Results from the Norwegian heart failure registry. Eur J Heart Fail. 2010;12(11):1247-52. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20847014].
Holley AB, Cheatham JG, Jackson JL, et al. Novel quantitative echocardiographic parameters in acute PE. J Thromb Thrombolysis. Nov. 2009;28(4):506-12. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19283447].
Holmes SJ, Espiner EA, Richards AM, et al. Renal, endocrine, and hemodynamic effects of human brain natriuretic peptide in normal man. J Clin Endocrinol Metab. Jan. 1993;76(1):91-6. Exclude: BNP measure not FDA approved. [pmid: 8380606].
Holubec JL, Topolcan O, Finek J, et al. Dynamic monitoring of cardio-specific markers and markers of thyroid gland function in cancer patients - A pilot study. Anticanc Res. 2007;27(4 A):1883-6. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Hong SN, Yoon NS, Ahn Y, et al. N-terminal pro-B-type natriuretic peptide predicts significant coronary artery lesion in the unstable angina patients with normal electrocardiogram, echocardiogram, and cardiac enzymes. Circ J. Dec. 2005;69(12):1472-6. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16308494].
Hong SN, Ahn Y, Yoon NS, et al. N-terminal pro-B-type natriuretic peptide level is depressed in patients with significant coronary artery disease who have high body mass index. Int Heart J. Jul. 2008;49(4):403-12. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18753724].
Horacek JM, Pudil R, Tichy M, et al. The use of biochemical markers in cardiotoxicity monitoring in patients treated for leukemia. Neoplasma. 2005;52(5):430-4. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16151589].
Horacek JM, Pudil R, Jebavy L, et al. Assessment of anthracycline-induced cardiotoxicity with biochemical markers. Exp Oncol. Dec. 2007;29(4):309-13. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18199989].
Horacek JM, Pudil R, Tichy M, et al. Biochemical markers and assessment of cardiotoxicity during preparative regimen and hematopoietic cell transplantation in acute leukemia. Exp Oncol. Sep. 2007;29(3):243-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18004253].
Horacek JM, Tichy M, Pudil R, et al. Multimarker approach to evaluation of cardiac toxicity during preparative regimen and hematopoietic cell transplantation. Neoplasma. 2008;55(6):532-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18999883].
Horiuchi I, Nozawa T, Fujii N, et al. Pharmacokinetics of R- and S-carvedilol in routinely treated Japanese patients with heart failure. Biol Pharmaceut Bull. 2008;31(5):976-80. Exclude: BNP measure not FDA approved.
Horwich TB, Patel J, MacLellan WR, et al. Cardiac troponin I is associated with impaired hemodynamics, progressive left ventricular dysfunction, and increased mortality rates in advanced heart failure. Circ. Aug. 2003;108(7):833-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Horwich TB, Kalantar-Zadeh K, MacLellan RW, et al. Albumin levels predict survival in patients with systolic heart failure. Am Heart J. 2008;155(5):883-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18440336].
Horwich TBM. Statins do not significantly affect muscle sympathetic nerve activity in humans with nonischemic heart failure: A double-blind placebo-controlled trial. J Card Fail. 2011;17(11):879-86. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 22041323].
Howie-Esquivel J, Dracup K. Effect of gender, ethnicity, pulmonary disease, and symptom stability on rehospitalization in patients with heart failure. Am J Cardiol. Oct. 1. 2007;100(7):1139-44. Exclude: BNP measure not FDA approved. [pmid: 17884378].
Hu S, Liu. Isolated coronary artery bypass graft combined with bone marrow mononuclear cells delivered through a graft vessel for patients with previous myocardial infarction and chronic heart failure: A single-center, randomized, double-blind, placebo-controlled clinical trial. J Am Coll Cardiol. 2011;57(24):2409-15. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21658561].
Hu M, Tian H, Zhou X, et al. Effect of insulin plus rosiglitazone or metformin on serum N-terminal pro-brain natriuretic peptide in type 2 diabetes mellitus: A randomized-controlled study. J Biomed Engineer. Jun. 2008;25(3):682-5. Exclude: Not in English.
Hu YM, Wang M, Zhao SQ. Predictive value for long term cardiac events by admission B-type natriuretic peptide and pulmonary capillary wedge pressure in patients with chronic heart failure. Chin J Cardiovasc Dis. Sep. 2008;36(9):786-9. Exclude: Not in English.
Huang CH, Tsai MS, Hsieh CC, et al. Diagnostic accuracy of tissue Doppler echocardiography for patients with acute heart failure. Heart. Dec. 2006;92(12):1790-4. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16803936].
Huang GY, Zhang LY, Long-Le MA, et al. Clinical characteristics and risk factors for peripartum cardiomyopathy. Afr Health Sci. 2012;12(1):26-31. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 23066416].
Huang PH, Leu HB, Chen JW, et al. Comparison of endothelial vasodilator function, inflammatory markers, and N-terminal pro-brain natriuretic peptide in patients with or without chronotropic incompetence to exercise test. Heart. May. 2006;92(5):609-14. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16159987].
Hubbard BL, Newton CR, Carter PM, et al. The inability of B-type natriuretic protein to predict short-term risk of death or myocardial infarction in non-heart-failure patients with marginally increased troponin levels. Ann Emerg Med. Nov. 2010;56(5):472-80. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20363529].
Huber KR, Mostafaie N, Bauer K, et al. Concentrations of N-terminal pro-brain natriuretic peptide and troponin T in plasma of 75-year-old apparently healthy persons. Clin Chem Lab Med. 2004;42(12):1430-3. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 15576307].
Hubner RH, El Mokhtari NE, Freitag S, et al. NT-proBNP is not elevated in patients with obstructive sleep apnoea. Respir Med. Jan. 2008;102(1):134-42. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17892929].
Huelsmann M, Neuhold S, Strunk G, et al. NT-proBNP has a high negative predictive value to rule-out short-term cardiovascular events in patients with diabetes mellitus. Eur Heart J. Sep. 2008;29(18):2259-64. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18650200].
Huerre C, Guiot A, Marechaux S, et al. Functional decline in elderly patients presenting with acute coronary syndromes: Impact on midterm outcome. Arch Cardiovasc Dis. 2010;103(1):19-25. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20142116].
Huh IY, Kim YK, Shin WJ, et al. Increased B-type natriuretic peptide during liver transplantation: Relationship to invasively measured hemodynamic parameters. Transplant Proc. 2012;44(5):1318-22. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 22664008].
Hulsmann M, Berger R, Sturm B, et al. Prediction of outcome by neurohumoral activation, the six-minute walk test and the Minnesota Living with Heart Failure Questionnaire in an outpatient cohort with congestive heart failure. Eur Heart J. Jun. 2002;23(11):886-91. Exclude: BNP measure not FDA approved. [pmid: 12042010].
Hulsmann M, Berger R, Mortl D, et al. Incidence of normal values of natriuretic peptides in patients with chronic heart failure and impact on survival: A direct comparison of N-terminal atrial natriuretic peptide, N-terminal brain natriuretic peptide and brain natriuretic peptide. Eur J Heart Fail. Jun. 2005;7(4):552-6. Exclude: BNP measure not FDA approved. [pmid: 15921794].
Hunt PJ, Espiner EA, Richards AM, et al. Interactions of atrial and brain natriuretic peptides at pathophysiological levels in normal men. Am J Physiol. Dec. 1995;269(6 Pt 2):R1397-403. Exclude: BNP measure not FDA approved. [pmid: 8594942].
Hunt PJ, Espiner EA, Nicholls MG, et al. Differing biological effects of equimolar atrial and brain natriuretic peptide infusions in normal man. J Clin Endocrinol Metab. Nov. 1996;81(11):3871-6. Exclude: BNP measure not FDA approved. [pmid: 8923831].
Husby S, Lind B, Goetze JP. Practical use of natriuretic peptide measurement: Questionnaire results from general practitioners and cardiologists. Biomarkers in Medicine. Feb. 2012;6(1):13-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 22296193].
Husic M, Norager B, Egstrup K, et al. Diastolic wall motion abnormality after myocardial infarction: Relation to neurohormonal activation and prognostic implications. Am Heart J. Oct. 2005;150(4):767-74. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16209980].
Hutcheon SD, Gillespie ND, Struthers AD, et al. B-type natriuretic peptide in the diagnosis of cardiac disease in elderly day hospital patients. Age Ageing. Jul. 2002;31(4):295-301. Exclude: BNP measure not FDA approved. [pmid: 12147568].
Hutfless R, Kazanegra R, Madani M, et al. Utility of B-type natriuretic peptide in predicting postoperative complications and outcomes in patients undergoing heart surgery. J Am Coll Cardiol. May. 2004;43(10):1873-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 15145114].
Hystad ME, Geiran OR, Attramadal H, et al. Regional cardiac expression and concentration of natriuretic peptides in patients with severe chronic heart failure. Acta Physiol Scand. Apr. 2001;171(4):395-403. Exclude: BNP measure not FDA approved. [pmid: 11421854].
Ibebuogu UNG. Decompensated heart failure is associated with reduced corin levels and decreased cleavage of pro-atrial natriuretic peptide. Circ. 2011;4(2):114-20. Exclude: BNP measure not FDA approved.
Ibrahim A, Baibars M, Alraies MC, et al. Q: Should target natriuretic peptide levels be used for outpatient management of chronic heart failure?. Cleveland Clinic Journal of Medicine. Jan. 2012;79(1):22-5. Exclude: Not a primary study. [pmid: 22219230].
Ichiki H, Oketani N, Hamasaki S, et al. Effect of right ventricular apex pacing on the Tei index and brain natriuretic peptide in patients with a dual-chamber pacemaker. Pacing Clin Electrophysiol. Sep. 2006;29(9):985-90. Exclude: BNP measure not FDA approved. [pmid: 16981923].
Ichiki T, Huntley BK, Heublein DM, et al. Corin is present in the normal human heart, kidney, and blood, with pro-B-type natriuretic peptide processing in the circulation. Clin Chem. Jan. 2011;57(1):40-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21075870].
Ichinose A, Otani H, Oikawa M, et al. MRI of cardiac sarcoidosis: Basal and subepicardial localization of myocardial lesions and their effect on left ventricular function. AJR. Sep. 2008;191(3):862-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18716120].
Igarashi M, Jimbu Y, Hirata A, et al. Effect of pioglitazone on the plasma level of brain nariuretic peptide in patients with type 2 diabetes. Therapeut Res. 2003;24(9):1873-81. Exclude: Not in English.
Igarashi M, Hirata A, Yamaguchi H, et al. Pioglitazone reduces atherogenic outcomes in type 2 diabetic patients. J Atherosclerosis Thromb. Feb. 2008;15(1):34-40. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Igarashi M, Hirata A, Tominaga M. Effects of diuretics on changes in plasma brain natriuretic peptide and serum uric acid in type 2 diabetic patients. Therapeut Res. 2009;30(9):1473-82. Exclude: BNP measure not FDA approved.
Iglesias JI, DePalma L, Hom D, et al. Predictors of mortality in adult patients with congestive heart failure receiving nesiritide--Retrospective analysis showing a potential adverse interaction between nesiritide and acute renal dysfunction. Nephrol Dial Transplant. Jan. 2008;23(1):144-53. Exclude: BNP measure not FDA approved. [pmid: 17804459].
Iida M, Nihei M, Yamazaki M, et al. Predictive value of von Willebrand factor for adverse clinical outcome in hypertensive patients with mild-to-moderate aortic regurgitation. J Hum Hypertens. Apr. 2008;22(4):275-81. Exclude: BNP measure not FDA approved. [pmid: 18075518].
Iida M, Maeda H, Yamamoto M, et al. Association of renal artery stenosis with aortic jet velocity in hypertensive patients with aortic valve sclerosis. Am J Hypertens. Feb. 2010;23(2):197-201. Exclude: BNP measure not FDA approved. [pmid: 19942862].
Ikeda N, Nakamura M, Yazaki Y, et al. A slightly elevated level of N-terminal pro-brain natriuretic peptide can predict coronary artery disease in a population with normal left ventricular function. Heart Ves. Sep. 2011;26(5):473-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Ikeda S, Sekijima Y, Tojo K, et al. Diagnostic value of abdominal wall fat pad biopsy in senile systemic amyloidosis. Amyloid. Dec. 2011;18(4):211-5. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 22004460].
Ikonomidis I, Parissis JT, Paraskevaidis I, et al. Effects of levosimendan on coronary artery flow and cardiac performance in patients with advanced heart failure. Eur J Heart Fail. Dec. 2007;9(12):1172-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18062901].
Ikonomidis I, Nikolaou M, Dimopoulou I, et al. Association of left ventricular diastolic dysfunction with elevated NT-pro-BNP in general intensive care unit patients with preserved ejection fraction: A complementary role of tissue Doppler imaging parameters and NT-pro-BNP levels for adverse outcome. Shock. Feb. 2010;33(2):141-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19487972].
Ilea M, Zdrenghea D, Bodisz G, et al. Cardiac peptides during exercise test in ischemic and non-ischemic heart failure patients. Rom J Intern Med. 2008;46(1):63-8. Exclude: BNP measure not FDA approved. [pmid: 19157272].
Ilva T, Lassus J, Siirila-Waris K, et al. Clinical significance of cardiac troponins I and T in acute heart failure. Eur J Heart Fail. Aug. 2008;10(8):772-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18599345].
Imamura Y, Fukuyama T, Mochizuki T, et al. Prognostic value of iodine-123-metaiodobenzylguanidine imaging and cardiac natriuretic peptide levels in patients with left ventricular dysfunction resulting from cardiomyopathy. Jpn Circ J. Mar. 2001;65(3):155-60. Exclude: BNP measure not FDA approved. [pmid: 11266187].
Inami S, Matsuda R, Toyoda S, et al. Risk of heart failure due to a combination of mild mitral regurgitation and impaired distensibility of the left ventricle in patients with old myocardial infarction. Clin Cardiol. Dec. 2008;31(12):567-71. Exclude: BNP measure not FDA approved. [pmid: 19072877].
Ingelsson E, Pencina MJ, Tofler GH, et al. Multimarker approach to evaluate the incidence of the metabolic syndrome and longitudinal changes in metabolic risk factors: The Framingham Offspring Study. Circ. 2007;116(9):984-92. Exclude: BNP measure not FDA approved.
Ingle L, Rigby AS, Nabb S, et al. Clinical determinants of poor six-minute walk test performance in patients with left ventricular systolic dysfunction and no major structural heart disease. Eur J Heart Fail. May. 2006;8(3):321-5. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16266825].
Ingle L, Rigby AS, Carroll S, et al. Prognostic value of the 6 min walk test and self-perceived symptom severity in older patients with chronic heart failure. Eur Heart J. Mar. 2007;28(5):560-8. Exclude: BNP measure not FDA approved. [pmid: 17314108].
Ingle L, Cleland JG, Clark AL. Perception of symptoms is out of proportion to cardiac pathology in patients with “diastolic heart failure”. Heart. Jun. 2008;94(6):748-53. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18070942].
Inoko M, Fujita M, Nakae I, et al. Effect of angiotensin-converting enzyme inhibition on sympathetic tone in patients with mild to moderate heart failure. Jpn Circ J. May. 2001;65(5):395-8. Exclude: BNP measure not FDA approved. [pmid: 11348042].
Inoue T, Kawai M, Nakane T, et al. Influence of low-grade inflammation on plasma B-type natriuretic peptide levels. Intern Med. 2010;49(24):2659-68. Exclude: BNP measure not FDA approved. [pmid: 21173540].
Inoue Y, Kawayama T, Iwanaga T, et al. High plasma brain natriuretic peptide levels in stable COPD without pulmonary hypertension or cor pulmonale. Intern Med. 2009;48(7):503-12. Exclude: BNP measure not FDA approved. [pmid: 19336951].
Iraqi W, Rossignol P, Angioi M, et al. Extracellular cardiac matrix biomarkers in patients with acute myocardial infarction complicated by left ventricular dysfunction and heart failure: Insights from the Eplerenone Post-Acute Myocardial Infarction Heart Failure Efficacy and Survival Study (EPHESUS) study. Circ. 2009;119(18):2471-9. Exclude: BNP measure not FDA approved.
Irzmanski R, Piechota M, Barylski M, et al. Dynamics of changes of the BNP concentration in patients with stable angina pectoris qualified for PTCA. Dependence on the selected morphological and haemodynamic parameters. Arch Med Sci. 2006;2(1):15-9. Exclude: BNP measure not FDA approved.
Ishibashi Y, Shimada T, Sakane T, et al. Contribution of endogenous nitric oxide to basal vasomotor tone of peripheral vessels and plasma B-type natriuretic peptide levels in patients with congestive heart failure. J Am Coll Cardiol. Nov. 1. 2000;36(5):1605-11. Exclude: BNP measure not FDA approved. [pmid: 11079665].
Ishibashi Y, Takahashi N, Tokumaru A, et al. Activation of inducible NOS in peripheral vessels and outcomes in heart failure patients. J Card Fail. Nov. 2008;14(9):724-31. Exclude: BNP measure not FDA approved. [pmid: 18995176].
Ishii J, Nomura M, Ito M, et al. Plasma concentration of brain natriuretic peptide as a biochemical marker for the evaluation of right ventricular overload and mortality in chronic respiratory disease. Clin Chim Acta. Nov. 2000;301(1-2):19-30. Exclude: BNP measure not FDA approved. [pmid: 11020459].
Ishii J, Nomura M, Okuma T, et al. Risk stratification using serum concentrations of cardiac troponin T in patients with end-stage renal disease on chronic maintenance dialysis. Clin Chim Acta. Oct. 2001;312(1-2):69-79. Exclude: BNP measure not FDA approved. [pmid: 11580911].
Ishii J, Nomura M, Nakamura Y, et al. Risk stratification using a combination of cardiac troponin T and brain natriuretic peptide in patients hospitalized for worsening chronic heart failure. Am J Cardiol. Mar. 15. 2002;89(6):691-5. Exclude: BNP measure not FDA approved. [pmid: 11897211].
Ishii J, Cui W, Kitagawa F, et al. Prognostic value of combination of cardiac troponin T and B-type natriuretic peptide after initiation of treatment in patients with chronic heart failure. Clin Chem. Dec. 2003;49(12):2020-6. Exclude: BNP measure not FDA approved. [pmid: 14633873].
Ishikawa C, Tsutamoto T, Fujii M, et al. Prediction of mortality by high-sensitivity C-reactive protein and brain natriuretic peptide in patients with dilated cardiomyopathy. Circ J. Jul. 2006;70(7):857-63. Exclude: BNP measure not FDA approved. [pmid: 16799238].
Ishikawa S, Miyauchi T, Ueno M, et al. Abnormal neurohumoral responses to exercise in patients with heart disease: Inhibition of an increase in endothelin-1 production during exercise. J Cardiovasc Pharmacol. 1998;31(Suppl 1):S406-11. Exclude: BNP measure not FDA approved. [pmid: 9595498].
Ishikawa Y, Bach JR, Minami R. Cardioprotection for Duchenne's muscular dystrophy. Am Heart J. May. 1999;137(5):895-902. Exclude: BNP measure not FDA approved. [pmid: 10220639].
Ishikura F, Ando Y, Park YD, et al. Changes of plasma atrial and brain natriuretic peptide levels during hemodialysis. Ren Fail. Mar. 1996;18(2):261-70. Exclude: BNP measure not FDA approved. [pmid: 8723364].
Ishino M, Takeishi Y, Niizeki T, et al. Risk stratification of chronic heart failure patients by multiple biomarkers: implications of BNP, H-FABP, and PTX3. Circ J. Nov. 2008;72(11):1800-5. Exclude: BNP measure not FDA approved. [pmid: 18832778].
Ishizaka Y, Yamamoto Y, Tanaka M, et al. Molecular forms of human brain natriuretic peptide (BNP) in plasma of patients on hemodialysis (HD). Clin Nephrol. Apr. 1995;43(4):237-42. Exclude: BNP measure not FDA approved. [pmid: 7606877].
Isik S, Cetin. Value of IGF-I levels in the evaluation of response to treatment with levosimendan in patients with severe heart failure. Anadolu Kardiyol Derg. 2011;11(6):523-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21821501].
Islamoglu F, Ozcan K, Apaydin AZ, et al. Diagnostic accuracy of N-terminal pro-brain natriuretic peptide in the evaluation of postoperative left ventricular diastolic dysfunction. Tex Heart Inst J. 2008;35(2):111-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18612440].
Isma'eel H, Chafic AH, Rassi FE, et al. Relation between iron-overload indices, cardiac echo-Doppler, and biochemical markers in thalassemia intermedia. Am J Cardiol. Aug. 1. 2008;102(3):363-7. Exclude: BNP measure not FDA approved. [pmid: 18638603].
Isnard R, Pousset F, Trochu J, et al. Prognostic value of neurohormonal activation and cardiopulmonary exercise testing in patients with chronic heart failure. Am J Cardiol. Aug. 15. 2000;86(4):417-21. Exclude: BNP measure not FDA approved. [pmid: 10946035].
Isnard R, Pousset F, Chafirovskaia O, et al. Combination of B-type natriuretic peptide and peak oxygen consumption improves risk stratification in outpatients with chronic heart failure. Am Heart J. Oct. 2003;146(4):729-35. Exclude: BNP measure not FDA approved. [pmid: 14564330].
Issa VS, Taniguchi LU, Park M, et al. Positive end-expiratory pressure and renal function influence B-type natriuretic peptide in patients with severe sepsis and septic shock. Arq Bras Cardiol. Aug. 2008;91(2):107-12. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18709262].
Ito H, Ishii K, Iwakura K, et al. Impact of azelnidipine treatment on left ventricular diastolic performance in patients with hypertension and mild diastolic dysfunction: Multi-center study with echocardiography. Hypertens Res. Oct. 2009;32(10):895-900. Exclude: BNP measure not FDA approved. [pmid: 19680260].
Ito K, Noma M, Mohri M, et al. Mitral annulus displacement measured by tissue-tracking method with Doppler-tissue images is a useful marker of the severity of heart failure. J Cardiol. Sep. 2007;50(3):159-66. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17941191].
Ito M, Kodama M, Kashimura T, et al. Comparison of patients with pulmonary arterial hypertension with versus without right-sided mechanical alternans. Am J Cardiol. 2012;109(3):428-31. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 22071213].
Ito S, Murai S, Takada N, et al. Relationship between Doppler transmitral flow velocity pattern and plasma atrial and brain natriuretic peptide concentrations in anuric patients on maintenance hemodialysis. Int Heart J. May. 2006;47(3):401-8. Exclude: BNP measure not FDA approved. [pmid: 16823246].
Ito S, Murai S, Sugiura M, et al. Predictors of congestive heart failure in patients on maintenance hemodialysis. Circ J. Sep. 2007;71(9):1424-9. Exclude: BNP measure not FDA approved. [pmid: 17721022].
Itoh K, Osada N, Inoue K, et al. Relationship between exercise intolerance and levels of neurohormonal factors and proinflammatory cytokines in patients with stable chronic heart failure. Int Heart J. Nov. 2005;46(6):1049-59. Exclude: BNP measure not FDA approved. [pmid: 16394601].
Ivanes F, Susen S, Mouquet F, et al. Aldosterone, mortality, and acute ischaemic events in coronary artery disease patients outside the setting of acute myocardial infarction or heart failure. Eur Heart J. Jan. 2012;33(2):191-202. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21719456].
Iversen K, Nielsen OW, Kirk V, et al. Heart murmur and N-terminal pro-brain natriuretic peptide as predictors of death in 2977 consecutive hospitalized patients. Am J Med Sci. Jun. 2008;335(6):444-50. Exclude: BNP measure not FDA approved. [pmid: 18552574].
Iwahashi NN. Usefulness of plasma B-type natriuretic peptide in the assessment of disease severity and prediction of outcome after aortic valve replacement in patients with severe aortic stenosis. J Am Soc Echocardiogr. 2011;24(9):984-91. Exclude: BNP measure not FDA approved. [pmid: 21570253].
Iwanaga Y, Nishi I, Furuichi S, et al. B-type natriuretic peptide strongly reflects diastolic wall stress in patients with chronic heart failure: Comparison between systolic and diastolic heart failure. J Am Coll Cardiol. Feb. 21. 2006;47(4):742-8. Exclude: BNP measure not FDA approved. [pmid: 16487838].
Iwanaga Y, Kihara Y, Niizuma S, et al. BNP in overweight and obese patients with heart failure: An analysis based on the BNP-LV diastolic wall stress relationship. J Card Fail. Oct. 2007;13(8):663-7. Exclude: BNP measure not FDA approved. [pmid: 17923359].
Iwaoka M, Obata JE, Abe M, et al. Association of low serum levels of apolipoprotein A-I with adverse outcomes in patients with nonischemic heart failure. J Card Fail. 2007;13(4):247-53. Exclude: BNP measure not FDA approved. [pmid: 17517342].
Iwasa A, Hwa M, Hassankhani A, et al. Abnormal heart rate turbulence predicts the initiation of ventricular arrhythmias. Pacing Clin Electrophysiol. Nov. 2005;28(11):1189-97. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16359285].
Iwata A, Miura SI, Nishikawa H, et al. Significance of combined angiotensin II receptor blocker and carvedilol therapy in patients with congestive heart failure and arginine variant. J Cardiol. 2006;47(1):1-7. Exclude: BNP measure not FDA approved. [pmid: 16475467].
Iyengar S, Thatipelli MR, Armentano DS, et al. Brain natriuretic peptide levels and left ventricular functional recovery in a chronic heart failure population. Congest Heart Fail. Mar. 2006;12(2):80-4. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16596041].
Izawa KP, Watanabe S, Osada N, et al. Handgrip strength as a predictor of prognosis in Japanese patients with congestive heart failure. Eur J Cardiovasc Prev Rehabil. 2009;16(1):21-7. Exclude: BNP measure not FDA approved. [pmid: 19237993].
Izawa KP, Watanabe S, Oka K, et al. Relation of the three-component model of short form-36 scores to disease severity in chronic heart failure outpatients. Int J Cardiol. 2012;157(1):130-1. Exclude: Not a primary study. [pmid: 22452788].
Izawa KP, Watanabe S, Oka K, et al. Upper and lower extremity muscle strength levels associated with an exercise capacity of 5 metabolic equivalents in male patients with heart failure. J Cardiopulm Rehabil Prev. 2012;32(2):85-91. Exclude: BNP measure not FDA approved. [pmid: 22378249].
Jaarsma T, Stewart S, De Geest S, et al. A survey of coronary risk factors and B-type natriuretic peptide concentrations in cardiac nurses from Europe: Do nurses still practice what they preach?. Eur J Cardiovasc Nurs. Apr. 2004;3(1):3-6. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 15053883].
Jabbour A, Macdonald PS, Keogh AM, et al. Differences between beta-blockers in patients with chronic heart failure and chronic obstructive pulmonary disease: A randomized crossover trial. J Am Coll Cardiol. Apr. 27. 2010;55(17):1780-7. Exclude: BNP measure not FDA approved. [pmid: 20413026].
Jabbour A, Hayward CS, Keogh AM, et al. Parenteral administration of recombinant human neuregulin-1 to patients with stable chronic heart failure produces favourable acute and chronic haemodynamic responses. Eur J Heart Fail. 2011;13(1):83-92. Exclude: BNP measure not FDA approved. [pmid: 20810473].
Jabor A, Pavlisova M, Kluh T, et al. Natriuretic peptides can predict cardiac failure. Klin Biochem Metabol. 1999;7(1):44-8. Exclude: Not in English.
Jackson CE, MacDonald MR, Petrie MC, et al. Associations of albuminuria in patients with chronic heart failure: Findings in the ALiskiren Observation of heart Failure Treatment study. Eur J Heart Fail. Jul. 2011;13(7):746-54. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21459891].
Jackson R, Ramos C, Gupta C, et al. Exercise decreases plasma antioxidant capacity and increases urinary isoprostanes of IPF patients. Respir Med. 2010;104(12):1919-28. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20739168].
Jacobshagen C, Belardinelli L, Hasenfuss G, et al. Ranolazine for the treatment of heart failure with preserved ejection fraction: background, aims, and design of the RALI-DHF study. Clin Cardiol. Jul. 2011;34(7):426-32. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21538388].
Jacobson AF, Senior R, Cerqueira MD, et al. Myocardial iodine-123 meta-iodobenzylguanidine imaging and cardiac events in heart failure. Results of the prospective ADMIRE-HF (AdreView Myocardial Imaging for Risk Evaluation in Heart Failure) study. J Am Coll Cardiol. May. 18. 2010;55(20):2212-21. Exclude: BNP measure not FDA approved. [pmid: 20188504].
Jakubik P, Janota T, Widimsky J Jr., et al. Impact of essential hypertension and primary aldosteronism on plasma brain natriuretic peptide concentration. Blood Press. 2006;15(5):302-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17380848].
James KB, Troughton RW, Feldschuh J, et al. Blood volume and brain natriuretic peptide in congestive heart failure: A pilot study. Am Heart J. Nov. 2005;150(5):984. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16290978].
James S. Coagulation, inflammation and myocardial dysfunction in unstable coronary artery disease and the influence of glycoprotein IIb/IIIa inhibition and low molecular weight heparin. Ups J Med Sci. 2004;109(2):71-122. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 15259448].
James SK, Lindahl B, Siegbahn A, et al. N-terminal pro-brain natriuretic peptide and other risk markers for the separate prediction of mortality and subsequent myocardial infarction in patients with unstable coronary artery disease: A Global Utilization of Strategies To Open occluded arteries (GUSTO)-IV substudy. Circ. Jul. 22. 2003;108(3):275-81. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
James SK, Lindahl B, Timmer JR, et al. Usefulness of biomarkers for predicting long-term mortality in patients with diabetes mellitus and non-ST-elevation acute coronary syndromes (a GUSTO IV substudy). Am J Cardiol. Jan. 15. 2006;97(2):167-72. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16442356].
Jang T, Aubin C, Naunheim R, et al. Ultrasonography of the internal jugular vein in patients with dyspnea without jugular venous distention on physical examination. Ann Emerg Med. 2004;44(2):160-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 15278091].
Jang T, Aubin C, Naunheim R, et al. Sonographic assessment of jugular venous distension and B-type natriuretic peptide levels in patients with dyspnoea. Emerg Med J. 2012;29(6):477-81. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21515878].
Jankowska EA, Wegrzynowska K, Superlak M, et al. The 12-week progressive quadriceps resistance training improves muscle strength, exercise capacity and quality of life in patients with stable chronic heart failure. Int J Cardiol. Oct. 30. 2008;130(1):36-43. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18054809].
Jankowska EA, Filippatos G, Ponikowska B, et al. Reduction in circulating testosterone relates to exercise capacity in men with chronic heart failure. J Card Fail. Jun. 2009;15(5):442-50. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19477405].
Jansson AM, Aukrust P, Ueland T, et al. Soluble CXCL16 predicts long-term mortality in acute coronary syndromes. Circ. Jun. 30. 2009;119(25):3181-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Januzzi JL, Morss A, Tung R, et al. Natriuretic peptide testing for the evaluation of critically ill patients with shock in the intensive care unit: A prospective cohort study. Crit Care. Feb. 2006;10(1):R37. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16507171].
Januzzi JL Jr., Sakhuja R, O'Donoghue M, et al. Utility of amino-terminal pro-brain natriuretic peptide testing for prediction of 1-year mortality in patients with dyspnea treated in the emergency department. Arch Intern Med. Feb. 13. 2006;166(3):315-20. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16476871].
Januzzi JL Jr., Peacock WF, Maisel AS, et al. Measurement of the interleukin family member ST2 in patients with acute dyspnea: Results from the PRIDE (Pro-Brain Natriuretic Peptide Investigation of Dyspnea in the Emergency Department) study. J Am Coll Cardiol. Aug. 14. 2007;50(7):607-13. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17692745].
Januzzi JL Jr., Chen-Tournoux AA, Moe G. Amino-terminal pro-B-type natriuretic peptide testing for the diagnosis or exclusion of heart failure in patients with acute symptoms. Am J Cardiol. Feb. 5. 2008;101(3A):29-38. Exclude: Not a primary study. [pmid: 18243855].
Januzzi JL Jr., Lewandrowski KB, Bashirians G, et al. Analytical and clinical performance of the Ortho-Clinical Diagnostics VITROS amino-terminal pro-B type natriuretic peptide assay. Clin Chim Acta. Jan. 2008;387(1-2):48-54. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17915201].
Januzzi JL Jr., Rehman S, Mueller T, et al. Importance of biomarkers for long-term mortality prediction in acutely dyspneic patients. Clin Chem. Dec. 2010;56(12):1814-21. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20921266].
Jarai R, Iordanova N, Jarai R, et al. Risk assessment in patients with unstable angina/non-ST-elevation myocardial infarction and normal N-terminal pro-brain natriuretic peptide levels by N-terminal pro-atrial natriuretic peptide. Eur Heart J. Feb. 2005;26(3):250-6. Exclude: BNP measure not FDA approved. [pmid: 15618049].
Jarai R, Huber K, Bogaerts K, et al. Plasma N-terminal fragment of the prohormone B-type natriuretic peptide concentrations in relation to time to treatment and Thrombolysis in Myocardial Infarction (TIMI) flow: A substudy of the Assessment of the Safety and Efficacy of a New Treatment Strategy with Percutaneous Coronary Intervention (ASSENT IV-PCI) trial. Am Heart J. Jan. 2010;159(1):131-40. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20102879].
Jaronik J, Mikkelson P, Fales W, et al. Evaluation of prehospital use of furosemide in patients with respiratory distress. Prehospital Emerg Care. Apr. 2006;10(2):194-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Jasaityte R, Dandel M, Lehmkuhl H, et al. Prediction of short-term outcomes in patients with idiopathic dilated cardiomyopathy referred for transplantation using standard echocardiography and strain imaging. Transplant Proc. Jan. 2009;41(1):277-80. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19249534].
Jaski BE, Jessup ML, Mancini DM, et al. Calcium upregulation by percutaneous administration of gene therapy in cardiac disease (CUPID Trial), a first-in-human phase 1/2 clinical trial. J Card Fail. Apr. 2009;15(3):171-81. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19327618].
Jaubert MP, Armero S, Bonello L, et al. Predictors of B-type natriuretic peptide and left atrial volume index in patients with preserved left ventricular systolic function: An echocardiographic-catheterization study. Arch Cardiovasc Dis. 2010;103(1):3-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20142114].
Jayadevappa R, Johnson JC, Bloom BS, et al. Effectiveness of transcendental meditation on functional capacity and quality of life of African Americans with congestive heart failure: A randomized control study. Ethn Dis. 2007;17(1):72-7. Exclude: BNP measure not FDA approved. [pmid: 17274213].
Jeevanantham V, Shrivastava R, Nannapaneni S, et al. Elevated B-type natriuretic peptide level: Use with caution in patients with multiple co-morbidities and presenting with dyspnea. Indian Heart J. 2007;59(1):64-8. Exclude: BNP measure not FDA approved. [pmid: 19098338].
Jefic D, Lee JW, Jefic D, et al. Utility of B-type natriuretic peptide and N-terminal pro B-type natriuretic peptide in evaluation of respiratory failure in critically ill patients. Chest. Jul. 2005;128(1):288-95. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16002948].
Jehn M, Schmidt-Trucksäss A, Hanssen H, et al. Association of physical activity and prognostic parameters in elderly patients with heart failure. J Aging Phys Activity. 2011;19(1):1-15. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Jensen J, Ma LP, Fu ML, et al. Inflammation increases NT-proBNP and the NT-proBNP/BNP ratio. Clin Res Cardiol. Jul. 2010;99(7):445-52. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20229122].
Jensen KT, Carstens J, Ivarsen P, et al. A new, fast and reliable radioimmunoassay of brain natriuretic peptide in human plasma. Reference values in healthy subjects and in patients with different diseases. Scand J Clin Lab Invest. Oct. 1997;57(6):529-40. Exclude: BNP measure not FDA approved. [pmid: 9350073].
Jensen KT, Eiskjaer H, Carstens J, et al. Renal effects of brain natriuretic peptide in patients with congestive heart failure. Clin Sci. Jan. 1999;96(1):5-15. Exclude: BNP measure not FDA approved. [pmid: 9857101].
Jensen SA, Hasbak P, Mortensen J, et al. Fluorouracil induces myocardial ischemia with increases of plasma brain natriuretic peptide and lactic acid but without dysfunction of left ventricle. J Clin Oncol. Dec. 20. 2010;28(36):5280-6. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21079148].
Jeong DS, Kim KH, Kim CY, et al. Relationship between plasma B-type natriuretic peptide and ventricular function in adult cardiac surgery patients. J Int Med Res. Jan. 2008;36(1):31-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18230265].
Jeong KY, Kim K, Kim TY, et al. Prognostic value of N-terminal pro-brain natriuretic peptide in hospitalised patients with community-acquired pneumonia. Emerg Med J. 2011;28(2):122-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20511643].
Jeong YH, Lee SW, Lee CW, et al. Biomarkers on admission for the prediction of cardiovascular events after primary stenting in patients with ST-elevation myocardial infarction. Clin Cardiol. Dec. 2008;31(12):572-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19072878].
Jernberg T, Stridsberg M, Venge P, et al. N-terminal pro brain natriuretic peptide on admission for early risk stratification of patients with chest pain and no ST-segment elevation. J Am Coll Cardiol. Aug. 7. 2002;40(3):437-45. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 12142108].
Jernberg T, Lindahl B, Siegbahn A, et al. N-terminal pro-brain natriuretic peptide in relation to inflammation, myocardial necrosis, and the effect of an invasive strategy in unstable coronary artery disease. J Am Coll Cardiol. Dec. 3. 2003;42(11):1909-16. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 14662251].
Jesty SA. Cardiac biomarkers in equine medicine. Vet J. 2012;192(2):131-2. Exclude: Not a primary study. [pmid: 22154229].
Jiang CY, Li N, Wang JA. Use of B-type natriuretic peptide in evaluation of early percutaneous coronary intervention in patients with acute coronary syndrome. Chin Med J. Aug. 2004;117(8):1130-4. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 15361283].
Jin B, Yang YG, Shi HM, et al. Autologous intracoronary mononuclear bone marrow cell transplantation for acute anterior myocardial infarction: Outcomes after 12-month follow-up. J Clin Rehab Tissue Engineer Res. 2008;12(12):2267-71. Exclude: Not in English.
Johansson P, Brostrom A, Dahlstrom U, et al. Global perceived health and ten-year cardiovascular mortality in elderly primary care patients with possible heart failure. Eur J Heart Fail. 2008;10(10):1040-7. Exclude: BNP measure not FDA approved. [pmid: 18693135].
Johansson P, Lesman-Leegte I, Svensson E, et al. Depressive symptoms and inflammation in patients hospitalized for heart failure. Am Heart J. Jun. 2011;161(6):1053-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21641350].
Johansson P, Van Der Wal M, van Veldhuisen DJ, et al. Association between prehospital delay and subsequent clinical course in patients with/hospitalized for heart failure. J Card Fail. 2012;18(3):202-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 22385940].
Johnson MJ, McDonagh TA, Harkness A, et al. Morphine for the relief of breathlessness in patients with chronic heart failure - A pilot study. Eur J Heart Fail. 2002;4(6):753-6. Exclude: BNP measure not FDA approved. [pmid: 12453546].
Johnson W, Omland T, Hall C, et al. Neurohormonal activation rapidly decreases after intravenous therapy with diuretics and vasodilators for class IV heart failure. J Am Coll Cardiol. May. 15. 2002;39(10):1623-9. Exclude: BNP measure not FDA approved. [pmid: 12020489].
Joho S, Oda Y, Hirai T, et al. Impact of sleeping position on central sleep apnea/Cheyne-Stokes respiration in patients with heart failure. Sleep Med. Feb. 2010;11(2):143-8. Exclude: BNP measure not FDA approved. [pmid: 20093078].
Jolda-Mydlowska B, Salomon P. Cytokines and remodeling of the heart in patients with congestive heart failure. Pol Arch Med Wewn. 2003;109(1):23-33. Exclude: Not in English. [pmid: 12879763].
Jondeau G, Neuder Y, Eicher JC, et al. B-CONVINCED: Beta-blocker CONtinuation Vs. INterruption in patients with Congestive heart failure hospitalizED for a decompensation episode. Eur Heart J. Sep. 2009;30(18):2186-92. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19717851].
Jones DJ, Willingale R, Quinn PA, et al. Improving the diagnostic accuracy of N-terminal B-type natriuretic peptide in human systolic heart failure by plasma profiling using mass spectrometry. J Proteome Res. Aug. 2007;6(8):3329-34. Exclude: BNP measure not FDA approved. [pmid: 17628091].
Jonsdottir S, Andersen KK, Sigurosson AF, et al. The effect of physical training in chronic heart failure. Eur J Heart Fail. Jan. 2006;8(1):97-101. Exclude: BNP measure not FDA approved. [pmid: 16194620].
Jonsson G, Abdelnoor M, Landaas S, et al. N-terminal pro-B-type natriuretic peptide in risk stratification after acute myocardial infarction in patients on long-term beta-adrenergic receptor blocker therapy. Cardiol. 2006;106(2):102-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Jorge AJL, Da Silva EN, Fernandes LCM, et al. Evaluation of longitudinal systolic function in heart failure with normal ejection fraction. Arq Bras Cardiol. 2010;94(6):799-805. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20464269].
Jose JV, Gupta SN, Selvakumar D. Utility of N-terminal pro-brain natriuretic peptide for the diagnosis of heart failure. Indian Heart J. Jan. 2003;55(1):35-9. Exclude: BNP measure not FDA approved. [pmid: 12760585].
Joseph J, Pencina MJ, Wang TJ, et al. Cross-sectional relations of multiple biomarkers representing distinct biological pathways to plasma markers of collagen metabolism in the community. J Hypertens. Jun. 2009;27(6):1317-24. Exclude: BNP measure not FDA approved. [pmid: 19357531].
Josephson S, Barnett PP. Nesiritide: Practical approach and benefits in the outpatient setting. J Cardiovasc Nurs. Sep. 2004;19(5):358-63. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 15495897].
Joung B, Ha JW, Ko YG, et al. Can pro-brain natriuretic peptide be used as a noninvasive predictor of elevated left ventricular diastolic pressures in patients with normal systolic function?. Am Heart J. Dec. 2005;150(6):1213-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16338261].
Joung BY, Park BE, Kim DS, et al. B-type natriuretic Peptide predicts clinical presentations and ventricular overloading in patients with heart failure. Yonsei Med J. Aug. 30. 2003;44(4):623-34. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 12950118].
Jouni H, Rodeheffer RJ, Kullo IJ. Increased serum N-terminal pro-B-type natriuretic peptide levels in patients with medial arterial calcification and poorly compressible leg arteries. Arterioscler Thromb Vasc Biol. Jan. 2011;31(1):197-202. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20947817].
Jourdain P, Funck F, Fulla Y, et al. Myocardial contractile reserve under low doses of dobutamine and improvement of left ventricular ejection fraction with treatment by carvedilol. Eur J Heart Fail. Jun. 2002;4(3):269-76. Exclude: BNP measure not FDA approved. [pmid: 12034151].
Jourdain P, Bellorini M, Funck F, et al. Short-term effects of sinus rhythm restoration in patients with lone atrial fibrillation: A hormonal study. Eur J Heart Fail. Jun. 2002;4(3):263-7. Exclude: BNP measure not FDA approved. [pmid: 12034150].
Jourdain P, Funck F, Bellorini M, et al. Bedside B-type natriuretic peptide and functional capacity in chronic heart failure. Eur J Heart Fail. Mar. 2003;5(2):155-60. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 12644005].
Jug B, Sebestjen M, Sabovic M, et al. Clopidogrel is associated with a lesser increase in NT-proBNP when compared to aspirin in patients with ischemic heart failure. J Card Fail. Aug. 2006;12(6):446-51. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16911911].
Jug B, Sebestjen M, Sabovic M, et al. Atrial fibrillation is an independent determinant of increased NT-proBNP levels in outpatients with signs and symptoms of heart failure. Wien Klin Wochenschr. 2009;121(21-22):700-6. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19998011].
Jug B, Vene N, Salobir BG, et al. Procoagulant state in heart failure with preserved left ventricular ejection fraction. Int Heart J. Sep. 2009;50(5):591-600. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19809208].
Julier K, Da Silva R, Garcia C, et al. Preconditioning by sevoflurane decreases biochemical markers for myocardial and renal dysfunction in coronary artery bypass graft surgery: A double-blinded, placebo-controlled, multicenter study. Anesthesiol. 2003;98(6):1315-27. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Jungbauer CG, Buchner S, Birner C, et al. N-terminal pro-brain natriuretic peptide from fresh urine for the biochemical detection of heart failure and left ventricular dysfunction. Eur J Heart Fail. 2010;12(4):331-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20185430].
Jungbauer CG, Birner C, Jung B, et al. Kidney injury molecule-1 and N-acetyl-beta-D-glucosaminidase in chronic heart failure: Possible biomarkers of cardiorenal syndrome. Eur J Heart Fail. Oct. 2011;13(10):1104-10. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21846754].
Junhui Z, Xingxiang W, Guosheng F, et al. Reduced number and activity of circulating endothelial progenitor cells in patients with idiopathic pulmonary arterial hypertension. Respir Med. Jul. 2008;102(7):1073-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18394873].
Kaaja RJ, Moore MP, Yandle TG, et al. Blood pressure and vasoactive hormones in mild preeclampsia and normal pregnancy. Hypertens Preg. 1999;18(2):173-87. Exclude: BNP measure not FDA approved.
Kagiyama S, Koga T, Kaseda S, et al. Correlation between increased urinary sodium excretion and decreased left ventricular diastolic function in patients with type 2 diabetes mellitus. Clin Cardiol. Oct. 2009;32(10):569-74. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19911350].
Kaji Y, Miyoshi T, Doi M, et al. Augmentation index is associated with B-type natriuretic peptide in patients with paroxysmal atrial fibrillation. Hypertens Res. Jul. 2009;32(7):611-6. Exclude: BNP measure not FDA approved. [pmid: 19407818].
Kajita M, Ezura Y, Iwasaki H, et al. Association of the -381T/C promoter variation of the brain natriuretic peptide gene with low bone-mineral density and rapid postmenopausal bone loss. J Hum Genet. 2003;48(2):77-81. Exclude: BNP measure not FDA approved. [pmid: 12601551].
Kalay N, Ozdogru I, Cetinkaya Y, et al. Cardiovascular effects of carbon monoxide poisoning. Am J Cardiol. Feb. 1. 2007;99(3):322-4. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17261390].
Kalay N, Ozdogru I, Gul A, et al. Effects of intermittent and long-term Glucose-insulin-potassium infusion in patients with systolic heart failure. Exp Clin Cardiol. 2008;13(2):85-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19343122].
Kale A, Kale E, Yalinkaya A, et al. The comparison of amino-terminal probrain natriuretic peptide levels in preeclampsia and normotensive pregnancy. J Perinatal Med. 2005;33(2):121-4. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Kallistratos MS, Dritsas A, Laoutaris ID, et al. No incremental clinical information of NT Pro BNP at peak exercise over resting levels in patients with impaired left ventricular function. Int J Cardiol. Oct. 1. 2007;121(2):221-3. Exclude: BNP measure not FDA approved. [pmid: 17145088].
Kallistratos MS, Dritsas A, Laoutaris ID, et al. N-terminal prohormone brain natriuretic peptide as a marker for detecting low functional class patients and candidates for cardiac transplantation: Linear correlation with exercise tolerance. J Heart Lung Transplant. May. 2007;26(5):516-21. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17449423].
Kallistratos MS, Dritsas A, Laoutaris ID, et al. Chronotropic and neurohumoral markers for the evaluation of functional capacity in patients with impaired left ventricular function. HJC Hell J Cardiol. Jan. 2008;49(1):26-32. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Kallistratos MS, Dritsas A, Laoutaris ID, et al. N-terminal prohormone brain natriuretic peptide plasma levels in heart failure are affected both directly and indirectly by carvedilol. Angiol. Jun. 2008;59(3):323-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Kalogeropoulos AP, Georgiopoulou VV, deFilippi CR, et al. Echocardiography, natriuretic peptides, and risk for incident heart failure in older adults: The Cardiovascular Health Study. JACC Cardiovasc Imaging. Feb. 2012;5(2):131-40. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 22340818].
Kalra PR, Struthers AD. More evidence for bedside BNP in heart failure assessment. Int J Cardiol. 2002;86(2-3):149-52. Exclude: Not a primary study.
Kalra PR, Clague JR, Bolger AP, et al. Myocardial production of C-type natriuretic peptide in chronic heart failure. Circ. Feb. 4. 2003;107(4):571-3. Exclude: BNP measure not FDA approved.
Kalsch H, Lehmann N, Mohlenkamp S, et al. Association of coronary artery calcium and congestive heart failure in the general population: Results of the Heinz Nixdorf Recall study. Clin Res Cardiol. Mar. 2010;99(3):175-82. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20054694].
Kaluski E, Gabara Z, Uriel N, et al. The benefits and safety of external counterpulsation in symptomatic heart failure. Isr Med Assoc J. Oct. 2006;8(10):687-90. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17125114].
Kamano C, Osawa H, Hashimoto K, et al. N-terminal pro-brain natriuretic peptide as a predictor of heart failure with preserved ejection fraction in hemodialysis patients without fluid overload. Blood Purif. 2012;33(1-3):37-43. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 22143056].
Kanat F, Vatansev H, Teke T. Diuretics, plasma brain natriuretic peptide and chronic obstructive pulmonary disease. Neth J Med. Sep. 2007;65(8):296-300. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17890789].
Kanda H, Kita Y, Okamura T, et al. What factors are associated with high plasma B-type natriuretic peptide levels in a general Japanese population?. J Hum Hypertens. Feb. 2005;19(2):165-72. Exclude: BNP measure not FDA approved. [pmid: 15496965].
Kandil E, Burack J, Sawas A, et al. B-type natriuretic peptide: A biomarker for the diagnosis and risk stratification of patients with septic shock. Arch Surg. 2008;143(3):242-6. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18347270].
Kaneko H, Koike A, Senoo K, et al. Role of cardiopulmonary dysfunction and left atrial remodeling in development of acute decompensated heart failure in chronic heart failure with preserved left ventricular ejection fraction. J Cardiol. 2012;59(3):359-65. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 22421198].
Kantar M, Levent E, Cetingul N, et al. Plasma natriuretic peptides levels and echocardiographic findings in late subclinical anthracycline toxicity. Pediatr Hematol Oncol. Dec. 2008;25(8):723-33. Exclude: Population aged under 18. [pmid: 19065438].
Kapoor PM, Aggarwal V, Chowdhury U, et al. Comparison of B-type natriuretic peptide and left ventricular dysfunction in patients with constrictive pericarditis undergoing pericardiectomy. Ann Cardiac Anaesth. May. 2010;13(2):123-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Kapur NK, Heffernan KS, Yunis AA, et al. Usefulness of soluble endoglin as a noninvasive measure of left ventricular filling pressure in heart failure. Am J Cardiol. 2010;106(12):1770-6. Exclude: BNP measure not FDA approved. [pmid: 21126621].
Karaahmet T, Tigen K, Gurel E, et al. Impact of systemic sclerosis on electromechanical characteristics of the heart. Heart Ves. May. 2010;25(3):223-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Karaahmet T, Tigen K, Dundar C, et al. The effect of cardiac fibrosis on left ventricular remodeling, diastolic function, and N-terminal pro-B-type natriuretic peptide levels in patients with nonischemic dilated cardiomyopathy. Echocardiograph. Sep. 2010;27(8):954-60. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Karabulut A, Kaplan A, Aslan C, et al. The association between NT-proBNP levels, functional capacity and stage in patients with heart failure. Acta Cardiol. Dec. 2005;60(6):631-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16385925].
Karaca I, Gulcu E, Yavuzkir M, et al. B-type natriuretic peptide level in the diagnosis of asymptomatic diastolic dysfunction. Anadolu Kardiyol Derg. Sep. 2007;7(3):262-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17785213].
Karadag O, Calguneri M, Yavuz B, et al. B-type natriuretic peptide (BNP) levels in female systemic lupus erythematosus patients: What is the clinical significance?. Clin Rheumatol. Oct. 2007;26(10):1701-4. Exclude: BNP measure not FDA approved. [pmid: 17318274].
Karadurmus N, Naharci MI. Prognostic significance of adipocytokines and extracellular matrix activity in heart failure patients with high B-type natriuretic peptide. Clin Biochem. Jun. 2010;43(9):774. Exclude: Not a primary study. [pmid: 20132807].
Karakilic E, Kepez A, Abali G, et al. The relationship between B-type natriuretic peptide levels and echocardiographic parameters in patients with heart failure admitted to the emergency department. Anadolu Kardiyol Derg. Apr. 2010;10(2):143-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20382614].
Karasek DS. Relationship between B-type natriuretic peptide serum level, echocardiographic TEI index and the degree of diastolic dysfunction in patients with heart failure with preserved systolic function. Arch Med Sci. 2011;7(3):449-56. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 22295028].
Karavidas A, Lazaros G, Matsakas E, et al. Clinical value of B-type natriuretic peptide for the assessment of left ventricular filling pressures in patients with systolic heart failure and inconclusive tissue Doppler indexes. Heart Ves. May. 2008;23(3):181-6. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Karavidas A, Parissis J, Arapi S, et al. Effects of functional electrical stimulation on quality of life and emotional stress in patients with chronic heart failure secondary to ischaemic or idiopathic dilated cardiomyopathy: A randomised, placebo-controlled trial. Eur J Heart Fail. Jul. 2008;10(7):709-13. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18558509].
Karavidas A, Parissis JT, Matzaraki V, et al. Functional electrical stimulation is more effective in severe symptomatic heart failure patients and improves their adherence to rehabilitation programs. J Card Fail. Mar. 2010;16(3):244-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20206900].
Karavidas A, Kapsimalis F, Lazaros G, et al. The impact of positive airway pressure on cardiac status and clinical outcomes in patients with advanced heart failure and sleep-disordered breathing: a preliminary report. Sleep Breath. Dec. 2011;15(4):701-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20890666].
Karciauskaite D, Grybauskiene R, Grybauskas P, et al. Brain natriuretic peptide and other cardiac markers in predicting left ventricular remodeling in patients with the first myocardial infarction. Medicina. 2004;40(10):949-56. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 15516817].
Kargin R, Esen O, Akcakoyun M, et al. Relationship between the tissue Doppler-derived Tei index and plasma brain natriuretic peptide levels in patients with mitral regurgitation. J Heart Valve Dis. Jan. 2010;19(1):35-42. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20329488].
Karmpaliotis D, Kirtane AJ, Ruisi CP, et al. Diagnostic and prognostic utility of brain natriuretic peptide in subjects admitted to the ICU with hypoxic respiratory failure due to noncardiogenic and cardiogenic pulmonary edema. Chest. Apr. 2007;131(4):964-71. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17426196].
Karuppiah S, Graham F, Ledwidge M, et al. Elevated BNP with normal systolic function in asymptomatic individuals at-risk for heart failure: A marker of diastolic dysfunction and clinical risk. Ir J Med Sci. 2006;175(4):5-13. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17312822].
Karyofillis P, Manginas A, Thomopoulou S, et al. Pulmonary arterial hypertension: Many years' experience and modern approach to a malignant disease in a pulmonary hypertension centre. HJC Hell J Cardiol. Nov. 2009;50(6):484-92. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Kasai T, Narui K, Dohi T, et al. Efficacy of nasal bi-level positive airway pressure in congestive heart failure patients with cheyne-stokes respiration and central sleep apnea. Circ J. Aug. 2005;69(8):913-21. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16041159].
Kasama S, Toyama T, Kumakura H, et al. Dobutamine stress 99mTc-tetrofosmin quantitative gated SPECT predicts improvement of cardiac function after carvedilol treatment in patients with dilated cardiomyopathy. J Nucl Med. Nov. 2004;45(11):1878-84. Exclude: BNP measure not FDA approved. [pmid: 15534058].
Kasama S, Toyama T, Kumakura H, et al. Effects of perindopril on cardiac sympathetic nerve activity in patients with congestive heart failure: Comparison with enalapril. Eur J Nucl Med Molecular Imag. Aug. 2005;32(8):964-71. Exclude: BNP measure not FDA approved.
Kasama S, Toyama T, Kumakura H, et al. Effects of candesartan on cardiac sympathetic nerve activity in patients with congestive heart failure and preserved left ventricular ejection fraction. J Am Coll Cardiol. Mar. 1. 2005;45(5):661-7. Exclude: BNP measure not FDA approved. [pmid: 15734608].
Kasama S, Toyama T, Hatori T, et al. Comparative effects of valsartan and enalapril on cardiac sympathetic nerve activity and plasma brain natriuretic peptide in patients with congestive heart failure. Heart. May. 2006;92(5):625-30. Exclude: BNP measure not FDA approved. [pmid: 16159967].
Kasama S, Toyama T, Sumino H, et al. Additive effects of spironolactone and candesartan on cardiac sympathetic nerve activity and left ventricular remodeling in patients with congestive heart failure. J Nucl Med. Dec. 2007;48(12):1993-2000. Exclude: BNP measure not FDA approved. [pmid: 18006623].
Kasner M, Gaub R, Westermann D, et al. Simultaneous estimation of NT-proBNP on top to mitral flow Doppler echocardiography as an accurate strategy to diagnose diastolic dysfunction in HFNEF. Int J Cardiol. May. 2011;149(1):23-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20053469].
Kataoka H. Relation of body fluid status to B-type natriuretic peptide levels in patients with chronic heart failure during long-term follow-up. Clin Cardiol. Oct. 2006;29(10):457-61. Exclude: BNP measure not FDA approved. [pmid: 17063950].
Kataoka H. Utility of thoracic sonography for follow-up examination of chronic heart failure patients with previous decompensation. Clin Cardiol. 2007;30(7):336-41. Exclude: BNP measure not FDA approved. [pmid: 17674378].
Kataoka H, Matsuno O. Age-related pulmonary crackles (rales) in asymptomatic cardiovascular patients. Ann Fam Med. 2008;6(3):239-45. Exclude: BNP measure not FDA approved. [pmid: 18474887].
Kataoka H, Madias JE, Kataoka H, et al. Changes in the amplitude of electrocardiogram QRS complexes during follow-up of heart failure patients. J Electrocardiol. May. 2011;44(3):394-9. Exclude: BNP measure not FDA approved. [pmid: 21376341].
Kataoka H, Madias JE. Effects of heart failure status on electrocardiogram precordial leads and their value for monitoring body fluid changes in heart failure patients. Int J Cardiol. Oct. 6. 2011;152(1):113-5. Exclude: Not a primary study. [pmid: 21802157].
Kataoka H. Detection of preclinical body fluid retention in established heart failure patients during follow-up by a digital weight scale incorporating a bioelectrical impedance analyzer. Congest Heart Fail. 2012;18(1):37-42. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 22277176].
Kataoka M, Satoh T, Yoshikawa T, et al. Comparison of the effects of carvedilol and metoprolol on exercise ventilatory efficiency in patients with congestive heart failure. Circ J. Mar. 2008;72(3):358-63. Exclude: BNP measure not FDA approved. [pmid: 18296829].
Katayama T, Yano K, Nakashima H, et al. Clinical significance of acute-phase endothelin-1 in acute myocardial infarction patients treated with direct coronary angioplasty. Circ J. Jun. 2005;69(6):654-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 15914941].
Kathiresan S, Gona P, Larson MG, et al. Cross-sectional relations of multiple biomarkers from distinct biological pathways to brachial artery endothelial function. Circ. Feb. 21. 2006;113(7):938-45. Exclude: BNP measure not FDA approved.
Kato H, Yasue H, Yoshimura M, et al. Suppression of hyperventilation-induced attacks with infusion of B-type (brain) natriuretic peptide in patients with variant angina. Am Heart J. Dec. 1994;128(6 Pt 1):1098-104. Exclude: BNP measure not FDA approved. [pmid: 7985589].
Kato J, Kobayashi K, Etoh T, et al. Plasma adrenomedullin concentration in patients with heart failure. J Clin Endocrinol Metab. Jan. 1996;81(1):180-3. Exclude: BNP measure not FDA approved. [pmid: 8550749].
Kato J, Kitamura K, Uemura T, et al. Plasma levels of adrenomedullin and atrial and brain natriuretic peptides in the general population: Their relations to age and pulse pressure. Hypertens Res. Nov. 2002;25(6):887-92. Exclude: BNP measure not FDA approved. [pmid: 12484513].
Kato K, Murakami H, Isozaki O, et al. Serum concentrations of BNP and ANP in patients with thyrotoxicosis. Endocr J. Mar. 2009;56(1):17-27. Exclude: BNP measure not FDA approved. [pmid: 18827406].
Kato M, Kinugawa T, Omodani H, et al. Augmented response in plasma atrial natriuretic peptide to dynamic exercise in patients with congestive heart failure. Jpn Circ J. Dec. 1996;60(12):909-16. Exclude: BNP measure not FDA approved. [pmid: 8996680].
Kato M, Kinugawa T, Ogino K, et al. Augmented response in plasma brain natriuretic peptide to dynamic exercise in patients with left ventricular dysfunction and congestive heart failure. J Intern Med. Oct. 2000;248(4):309-15. Exclude: BNP measure not FDA approved. [pmid: 11086641].
Kato N, Kinugawa K, Yao A, et al. Relationship of depressive symptoms with hospitalization and death in Japanese patients with heart failure. J Card Fail. 2009;15(10):912-9. Exclude: BNP measure not FDA approved. [pmid: 19944369].
Kato N, Kinugawa K, Ito N, et al. Adherence to self-care behavior and factors related to this behavior among patients with heart failure in Japan. Heart Lung. Sep. 2009;38(5):398-409. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19755190].
Kato TS, Chokshi A, Singh P, et al. Effects of continuous-flow versus pulsatile-flow left ventricular assist devices on myocardial unloading and remodeling. Circ Heart Fail. Sep. 2011;4(5):546-53. Exclude: BNP measure not FDA approved. [pmid: 21765125].
Katoh S, Shishido T, Kutsuzawa D, et al. Iodine-123-metaiodobenzylguanidine imaging can predict future cardiac events in heart failure patients with preserved ejection fraction. Ann Nucl Med. Nov. 2010;24(9):679-86. Exclude: BNP measure not FDA approved. [pmid: 20824398].
Kavousi M, Elias-Smale S, Rutten JH, et al. Evaluation of newer risk markers for coronary heart disease risk classification: A cohort study. Ann Intern Med. Mar. 20. 2012;156(6):438-44. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 22431676].
Kavsak PA, Ko DT, Newman AM, et al. Risk stratification for heart failure and death in an acute coronary syndrome population using inflammatory cytokines and N-terminal pro-brain natriuretic peptide. Clin Chem. Dec. 2007;53(12):2112-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17932131].
Kavsak PA, Ko DT, Newman AM, et al. “Upstream markers” provide for early identification of patients at high risk for myocardial necrosis and adverse outcomes. Clin Chim Acta. Jan. 2008;387(1-2):133-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17964560].
Kavsak PA, Newman AM, Ko DT, et al. Is a pattern of increasing biomarker concentrations important for long-term risk stratification in acute coronary syndrome patients presenting early after the onset of symptoms?. Clin Chem. Apr. 2008;54(4):747-51. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18375487].
Kawabata MH. Role of oral amiodarone in patients with atrial fibrillation and congestive heart failure. J Cardiol. 2011;58(2):108-15. Exclude: BNP measure not FDA approved. [pmid: 21831597].
Kawahara C, Tsutamoto T, Nishiyama K, et al. Prognostic role of high-sensitivity cardiac troponin T in patients with nonischemic dilated cardiomyopathy. Circ J. Mar. 2011;75(3):656-61. Exclude: BNP measure not FDA approved. [pmid: 21178288].
Kawai K, Hata K, Takaoka H, et al. Plasma brain natriuretic peptide as a novel therapeutic indicator in idiopathic dilated cardiomyopathy during beta-blocker therapy: A potential of hormone-guided treatment. Am Heart J. Jun. 2001;141(6):925-32. Exclude: BNP measure not FDA approved. [pmid: 11376305].
Kawai T, Takei I, Shimada A, et al. Effects of olmesartan medoxomil, an angiotensin II type 1 receptor antagonist, on plasma concentration of B-type natriuretic peptide, in hypertensive patients with type 2 diabetes mellitus: A preliminary, observational, open-label study. Clin Drug Invest. 2011;31(4):237-45. Exclude: BNP measure not FDA approved.
Kawakubo M, Funabashi N, Takahashi M, et al. Relationship of natriuretic peptide and transthoracic echocardiographic findings in 135 subjects with muscular dystrophy. Int J Cardiol. 2010;145(3):506-14. Exclude: BNP measure not FDA approved. [pmid: 20061036].
Kawamura T, Wago M, Kawaguchi H, et al. Plasma brain natriuretic peptide concentrations in patients with Kawasaki disease. Pediatr Int. Jun. 2000;42(3):241-8. Exclude: BNP measure not FDA approved. [pmid: 10881579].
Kawano H, Nagayoshi Y, Soejima H, et al. B-type natriuretic peptide after hormone therapy in postmenopausal women with chest pain and normal coronary angiogram. Menopause. Mar. 2008;15(2):352-6. Exclude: BNP measure not FDA approved. [pmid: 18090872].
Kaya Y, Akdemir R, Gunduz H, et al. Changes in serum natriuretic peptide levels after percutaneous closure of small to moderate ventricular septal defects. Sci World J. 2012;2012. 2012. Article Number: 328697. Date of Publication: 2012.:. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Kaye G, Stambler BS, Yee R. Search for the optimal right ventricular pacing site: Design and implementation of three randomized multicenter clinical trials. Pacing Clin Electrophysiol. 2009;32(4):426-33. Exclude: Not a primary study. [pmid: 19335850].
Kayikcioglu M, Kultursay H. Seven years of experience in patients with pulmonary arterial hypertension in Ege University Hospital: Diagnostic approach of a single center. Anadolu Kardiyol Derg. Aug. 2008;8(4):279-85. Exclude: Not in English. [pmid: 18676304].
Kazanegra R, Cheng V, Garcia A, et al. A rapid test for B-type natriuretic peptide correlates with falling wedge pressures in patients treated for decompensated heart failure: A pilot study. J Card Fail. Mar. 2001;7(1):21-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 11264546].
Kazimierczak A, Krzyzanowski K, Wierzbowski R, et al. Resolution of exercise oscillatory ventilation with adaptive servoventilation in patients with chronic heart failure and Cheyne-Stokes respiration: Preliminary study. Kardiol Pol. 2011;69(12):1266-71. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 22219104].
Kazlauskaite R, Doukky R, Evans A, et al. Predictors of diastolic dysfunction among minority patients with newly diagnosed type 2 diabetes. Diab Res Clin Pract. May. 2010;88(2):189-95. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Kazory A, Ejaz AA. Removal of BNP and inflammatory cytokines by haemodiafiltration in refractory heart failure. Nephrol Dial Transplant. 2007;22(7):2093-4. Exclude: Not a primary study. [pmid: 17452401].
Kelder JC, Cowie MR, McDonagh TA, et al. Quantifying the added value of BNP in suspected heart failure in general practice: An individual patient data meta-analysis. Heart. Jun. 2011;97(12):959-63. Exclude: Systematic review. [pmid: 21478382].
Kelesidis I, Mazurek JA, Saeed W, et al. Effect of nesiritide in isolated right ventricular failure secondary to pulmonary hypertension. Congest Heart Fail. Jan. 2012;18(1):18-24. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 22277173].
Kellett J. Prediction of in-hospital mortality by brain natriuretic peptide levels and other independent variables in acutely ill patients with suspected heart disease. Can J Cardiol. May. 15. 2004;20(7):686-90. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 15197420].
Kellett J. The prediction of in-hospital mortality by amino terminal pro-brain natriuretic peptide (NT-proBNP) levels and other independent variables in acutely ill patients with suspected heart disease. Eur J Intern Med. 2005;16(3):195-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 15967336].
Kelly CA, Newby DE, McDonagh TA, et al. Randomised controlled trial of continuous positive airway pressure and standard oxygen therapy in acute pulmonary oedema: Effects on plasma brain natriuretic peptide concentrations. Eur Heart J. Sep. 2002;23(17):1379-86. Exclude: BNP measure not FDA approved. [pmid: 12191749].
Kelly D, Khan SQ, Thompson M, et al. Plasma tissue inhibitor of metalloproteinase-1 and matrix metalloproteinase-9: Novel indicators of left ventricular remodelling and prognosis after acute myocardial infarction. Eur Heart J. 2008;29(17):2116-24. Exclude: BNP measure not FDA approved. [pmid: 18614523].
Kerbaul F, Giorgi R, Oddoze C, et al. High concentrations of N-BNP are related to non-infectious severe SIRS associated with cardiovascular dysfunction occurring after off-pump coronary artery surgery. Br J Anaesth. Nov. 2004;93(5):639-44. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 15347604].
Kerbaul F, Collart F, Giorgi R, et al. Increased plasma levels of pro-brain natriuretic peptide in patients with cardiovascular complications following off-pump coronary artery surgery. Intensive Care Med. Sep. 2004;30(9):1799-806. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 15138672].
Kerola T, Nieminen T, Hartikainen S, et al. High-density lipoprotein is superior to B-type natriuretic peptide as a marker of systolic dysfunction in an elderly general population. Scand J Clin Lab Invest. 2009;69(8):865-72. Exclude: BNP measure not FDA approved. [pmid: 20001337].
Kerola T, Nieminen T, Hartikainen S, et al. B-type natriuretic peptide as a predictor of declining cognitive function and dementia--A cohort study of an elderly general population with a 5-year follow-up. Ann Med. Apr. 2010;42(3):207-15. Exclude: BNP measure not FDA approved. [pmid: 20384435].
Kerola T, Nieminen T, Sulkava R, et al. Inverted mitral inflow pattern in echocardiography among the elderly - A marker of non-cardiovascular mortality and cognitive dysfunction. Int J Cardiol. 2012;155(1):70-4. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21392834].
Kerola TH. Mini-Mental State Examination score and B-type natriuretic peptide as predictors of cardiovascular and total mortality in an elderly general population. Ann Med. 2011;43(8):650-9. Exclude: BNP measure not FDA approved. [pmid: 20961273].
Kerr AJ, Raffel OC, Whalley GA, et al. Elevated B-type natriuretic peptide despite normal left ventricular function on rest and exercise stress echocardiography in mitral regurgitation. Eur Heart J. Feb. 2008;29(3):363-70. Exclude: BNP measure not FDA approved. [pmid: 18202251].
Khan SQ, Kelly D, Quinn P, et al. Cardiotrophin-1 predicts death or heart failure following acute myocardial infarction. J Card Fail. Oct. 2006;12(8):635-40. Exclude: BNP measure not FDA approved. [pmid: 17045183].
Khan SQ, Dhillon OS, O'Brien RJ, et al. C-terminal provasopressin (copeptin) as a novel and prognostic marker in acute myocardial infarction: Leicester Acute Myocardial Infarction Peptide (LAMP) study. Circ. Apr. 24. 2007;115(16):2103-10. Exclude: BNP measure not FDA approved.
Khan SQ, Kelly D, Quinn P, et al. Myotrophin is a more powerful predictor of major adverse cardiac events following acute coronary syndrome than N-terminal pro-B-type natriuretic peptide. Clin Sci. Apr. 2007;112(4):251-6. Exclude: BNP measure not FDA approved. [pmid: 17014419].
Khan SQ, O'Brien RJ, Struck J, et al. Prognostic value of midregional pro-adrenomedullin in patients with acute myocardial infarction: The LAMP (Leicester Acute Myocardial Infarction Peptide) study. J Am Coll Cardiol. Apr. 10. 2007;49(14):1525-32. Exclude: BNP measure not FDA approved. [pmid: 17418290].
Khan SQ, Bhandari SS, Quinn P, et al. Urotensin II is raised in acute myocardial infarction and low levels predict risk of adverse clinical outcome in humans. Int J Cardiol. May. 2. 2007;117(3):323-8. Exclude: BNP measure not FDA approved. [pmid: 16887216].
Khan SQ, Dhillon O, Struck J, et al. C-terminal pro-endothelin-1 offers additional prognostic information in patients after acute myocardial infarction: Leicester Acute Myocardial Infarction Peptide (LAMP) Study. Am Heart J. Oct. 2007;154(4):736-42. Exclude: BNP measure not FDA approved. [pmid: 17893002].
Khan SQ, Dhillon O, Kelly D, et al. Plasma N-terminal B-Type natriuretic peptide as an indicator of long-term survival after acute myocardial infarction: comparison with plasma midregional pro-atrial natriuretic peptide: the LAMP (Leicester Acute Myocardial Infarction Peptide) study. J Am Coll Cardiol. May. 13. 2008;51(19):1857-64. Exclude: BNP measure not FDA approved. [pmid: 18466800].
Khan SQ, Ng K, Dhillon O, et al. Growth differentiation factor-15 as a prognostic marker in patients with acute myocardial infarction. Eur Heart J. May. 2009;30(9):1057-65. Exclude: BNP measure not FDA approved. [pmid: 19168526].
Khush KK, Gerber IL, McKeown B, et al. Obese patients have lower B-type and atrial natriuretic peptide levels compared with nonobese. Congest Heart Fail. Mar. 2006;12(2):85-90. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16596042].
Kida K, Akashi YJ, Yoneyama K, et al. 123I-BMIPP delayed scintigraphic imaging in patients with chronic heart failure. Ann Nucl Med. Nov. 2008;22(9):769-75. Exclude: BNP measure not FDA approved. [pmid: 19039555].
Kido S, Hasebe N, Ishii Y, et al. Tachycardia-induced myocardial ischemia and diastolic dysfunction potentiate secretion of ANP, not BNP, in hypertrophic cardiomyopathy. Am J Physiol Heart Circ Physiol. Mar. 2006;290(3):H1064-70. Exclude: BNP measure not FDA approved. [pmid: 16172169].
Kiely DG, Kennedy NS, Pirzada O, et al. Elevated levels of natriuretic peptides in patients with pulmonary thromboembolism. Respir Med. Oct. 2005;99(10):1286-91. Exclude: BNP measure not FDA approved. [pmid: 16099151].
Kiencke S, Handschin R, von Dahlen R, et al. Pre-clinical diabetic cardiomyopathy: Prevalence, screening, and outcome. Eur J Heart Fail. Sep. 2010;12(9):951-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20581103].
Kihara T, Biro S, Imamura M, et al. Repeated sauna treatment improves vascular endothelial and cardiac function in patients with chronic heart failure. J Am Coll Cardiol. Mar. 6. 2002;39(5):754-9. Exclude: BNP measure not FDA approved. [pmid: 11869837].
Kihara T, Biro S, Ikeda Y, et al. Effects of repeated sauna treatment on ventricular arrhythmias in patients with chronic heart failure. Circ J. 2004;68(12):1146-51. Exclude: BNP measure not FDA approved. [pmid: 15564698].
Kilic T, Oner G, Ural E, et al. Comparison of the long-term prognostic value of cystatin C to other indicators of renal function, markers of inflammation and systolic dysfunction among patients with acute coronary syndrome. Atherosclerosis. Dec. 2009;207(2):552-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19523634].
Kim BH, Kim IJ, Cho KI, et al. The influence of diabetes on the relationship between N-terminal pro-B-type natriuretic peptide and body mass index. J Int Med Res. 2010;38(5):1737-48. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21309488].
Kim H, Yang DH, Park Y, et al. Incremental prognostic value of C-reactive protein and N-terminal proB-type natriuretic peptide in acute coronary syndrome. Circ J. Nov. 2006;70(11):1379-84. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17062957].
Kim H, Cho YK, Jun DH, et al. Prognostic implications of the NT-ProBNP level and left atrial size in non-ischemic dilated cardiomyopathy. Circ J. Oct. 2008;72(10):1658-65. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18728335].
Kim H, Jun DW, Cho YK, et al. The correlation of left atrial volume index to the level of N-terminal pro-BNP in heart failure with a preserved ejection fraction. Echocardiograph. Oct. 2008;25(9):961-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Kim H, Shin HW, Son J, et al. Uric acid as prognostic marker in advanced nonischemic dilated cardiomyopathy: Comparison with N-terminal pro B-type natriuretic peptide level. Congest Heart Fail. 2010;16(4):153-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20662867].
Kim H, Yoon HJ, Park HS, et al. Usefulness of tissue Doppler imaging-myocardial performance index in the evaluation of diastolic dysfunction and heart failure with preserved ejection fraction. Clin Cardiol. Aug. 2011;34(8):494-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21780137].
Kim HN, Januzzi JL Jr., Kim HN, et al. Natriuretic peptide testing in heart failure. Circ. May. 10. 2011;123(18):2015-9. Exclude: Case report.
Kim J, Washio T, Yamagishi M, et al. A novel data mining approach to the identification of effective drugs or combinations for targeted endpoints--Application to chronic heart failure as a new form of evidence-based medicine. Cardiovasc Drugs Ther. Nov. 2004;18(6):483-9. Exclude: BNP measure not FDA approved. [pmid: 15770436].
Kim J, Nakatani S, Hashimura K, et al. Abnormal glucose tolerance contributes to the progression of chronic heart failure in patients with dilated cardiomyopathy. Hypertens Res. Oct. 2006;29(10):775-82. Exclude: BNP measure not FDA approved. [pmid: 17283864].
Kim J, Ogai A, Nakatani S, et al. Impact of blockade of histamine H2 receptors on chronic heart failure revealed by retrospective and prospective randomized studies. J Am Coll Cardiol. Oct. 3. 2006;48(7):1378-84. Exclude: BNP measure not FDA approved. [pmid: 17010798].
Kim JY, Lee EY, Jee JH, et al. N-terminal pro-brain natriuretic peptide (NT-proBNP) in Type 2 diabetes with left ventricular dysfunction. Diab Res Clin Pract. Sep. 2007;77(Suppl 1):S238-42. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Kim KH, Park HH, Kim E, et al. The usefulness of B-type natriuretic peptide test in critically ill, noncardiac patients. Tubercul Resp Dis. 2003;54(3):311-9. Exclude: Not in English.
Kim SA, Rhee SJ, Shim CY, et al. Prognostic value of N-terminal probrain natriuretic peptide level on admission in patients with acute myocardial infarction and preserved left ventricular ejection fraction. Coron Artery Dis. May. 2011;22(3):153-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21383622].
Kim SE, Park DG, Lee JH, et al. Utility of B-type natriuretic Peptide for predicting perioperative cardiovascular events in patients without history of cardiovascular disease undergoing major non-cardiac surgery. Korean Circ J. Jan. 2011;41(1):11-5. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21359063].
Kim SJ, Shin ES, Lee SG. N-terminal pro-B-type natriuretic peptide as a marker of disease severity in patients with pericardial effusions. Korean J Intern Med. Jun. 2008;23(2):78-86. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18646510].
Kim SW, Park SW, Lim SH, et al. Amount of left ventricular hypertrophy determines the plasma N-terminal pro-brain natriuretic peptide level in patients with hypertrophic cardiomyopathy and normal left ventricular ejection fraction. Clin Cardiol. Apr. 2006;29(4):155-60. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16649724].
Kim WS, Park SH, Kim WS, et al. Correlation between N-Terminal pro-brain natriuretic peptide and Doppler echocardiographic parameters of left ventricular filling pressure in atrial fibrillation. J Cardiovasc Ultrasound. Mar. 2011;19(1):26-31. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21519489].
Kim YK, Shin SJ, Ihm SH, et al. Association between N-terminal pro-brain natriuretic peptide and acute ischemic stroke in patients on chronic hemodialysis. Int Urol Nephrol. Jun. 2010;42(2):537-43. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20039125].
Kim YK, Seong SH, Jun IG, et al. Preoperative echocardiographic indices associated with elevated brain natriuretic peptide in liver transplant recipients. Transplant Proc. Jun. 2011;43(5):1691-5. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21693259].
Kimura H, Hiramitsu S, Miyagishima K, et al. Cardio-renal interaction: Impact of renal function and anemia on the outcome of chronic heart failure. Heart Ves. Jul. 2010;25(4):306-12. Exclude: BNP measure not FDA approved.
Kimura K, Yamaguchi Y, Horii M, et al. ANP is cleared much faster than BNP in patients with congestive heart failure. Eur J Clin Pharmacol. 2007;63(7):699-702. Exclude: BNP measure not FDA approved. [pmid: 17479256].
Kimura K, Miura S, Iwata A, et al. Association between cardiac function and metabolic factors including adiponectin in patients with acute myocardial infarction. J Cardiol. 2009;53(1):65-71. Exclude: BNP measure not FDA approved. [pmid: 19167640].
Kimura K, Shibazaki K, Iguchi Y, et al. The combination of elevated BNP and AF as a predictor of no early recanalization after IV-t-PA in acute ischemic stroke. J Neurol Sci. Mar. 15. 2010;290(1-2):37-40. Exclude: BNP measure not FDA approved. [pmid: 20015516].
Kindermann I, Fischer D, Karbach J, et al. Cognitive function in patients with decompensated heart failure: The Cognitive Impairment in Heart Failure (CogImpair-HF) study. Eur J Heart Fail. 2012;14(4):404-13. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 22431406].
Kindermann M, Hennen B, Jung J, et al. Biventricular versus conventional right ventricular stimulation for patients with standard pacing indication and left ventricular dysfunction: The Homburg Biventricular Pacing Evaluation (HOBIPACE). J Am Coll Cardiol. May. 16. 2006;47(10):1927-37. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16697307].
Kinugasa Y, Kato M, Sugihara S, et al. A simple risk score to predict in-hospital death of elderly patients with acute decompensated heart failure--Hypoalbuminemia as an additional prognostic factor. Circ J. Dec. 2009;73(12):2276-81. Exclude: BNP measure not FDA approved. [pmid: 19822976].
Kinugawa T, Osaki S, Kato M, et al. Effects of the angiotensin-converting enzyme inhibitor alacepril on exercise capacity and neurohormonal factors in patients with mild-to-moderate heart failure. Clin Exp Pharmacol Physiol. Dec. 2002;29(12):1060-5. Exclude: BNP measure not FDA approved. [pmid: 12390293].
Kinugawa T, Tomikura Y, Ogino K, et al. Relation between neurohormonal activation and enhanced ventilatory response to exercise in patients with chronic congestive heart failure. Am J Cardiol. 2002;89(5):604-7. Exclude: BNP measure not FDA approved. [pmid: 11867051].
Kinugawa T, Kato M, Ogino K, et al. Interleukin-6 and tumor necrosis factor-alpha levels increase in response to maximal exercise in patients with chronic heart failure. Int J Cardiol. Jan. 2003;87(1):83-90. Exclude: BNP measure not FDA approved. [pmid: 12468058].
Kinugawa T, Kato M, Ogino K, et al. Neurohormonal determinants of peak oxygen uptake in patients with chronic heart failure. Jpn Heart J. Sep. 2003;44(5):725-34. Exclude: BNP measure not FDA approved. [pmid: 14587654].
Kinugawa T, Kato M, Ogino K, et al. Plasma endothelin-1 levels and clinical correlates in patients with chronic heart failure. J Card Fail. Aug. 2003;9(4):318-24. Exclude: BNP measure not FDA approved. [pmid: 13680553].
Kinugawa T, Kato M, Ogino K, et al. Effects of angiotensin II type 1 receptor antagonist, losartan, on ventilatory response to exercise and neurohormonal profiles in patients with chronic heart failure. Jpn J Physiol. 2004;54(1):15-21. Exclude: BNP measure not FDA approved. [pmid: 15040844].
Kirchhoff C, Leidel BA, Kirchhoff S, et al. Analysis of N-terminal pro-B-type natriuretic peptide and cardiac index in multiple injured patients: A prospective cohort study. Crit Care. 2008;12(5):R118. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18789145].
Kirchhoff WC, Gradaus R, Stypmann J, et al. Vasoactive peptides during long-term follow-up of patients after cardiac transplantation. J Heart Lung Transplant. Mar. 2004;23(3):284-8. Exclude: BNP measure not FDA approved. [pmid: 15019637].
Kirk V, Bay M, Parner J, et al. N-terminal proBNP and mortality in hospitalised patients with heart failure and preserved vs. reduced systolic function: Data from the prospective Copenhagen Hospital Heart Failure Study (CHHF). Eur J Heart Fail. Mar. 15. 2004;6(3):335-41. Exclude: BNP measure not FDA approved. [pmid: 14987585].
Kishi T, Yamada A, Okamatsu S, et al. Atorvastatin might improve ventricular electrostability and decelerate the deterioration of renal function in patients with heart failure and diabetes mellitus. J Cardiol. Jun. 2009;53(3):341-8. Exclude: BNP measure not FDA approved. [pmid: 19477374].
Kishimoto C, Shioji K, Ito H, et al. Evaluation of arteriolar hyalinosis of the skin of patients with chronic congestive heart failure. Circ J. Apr. 2002;66(4):382-4. Exclude: BNP measure not FDA approved. [pmid: 11954954].
Kistorp C, Raymond I, Pedersen F, et al. N-terminal pro-brain natriuretic peptide, C-reactive protein, and urinary albumin levels as predictors of mortality and cardiovascular events in older adults. JAMA. Apr. 6. 2005;293(13):1609-16. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 15811980].
Kistorp C, Galatius S, Gustafsson F, et al. Prevalence and characteristics of diabetic patients in a chronic heart failure population. Int J Cardiol. Apr. 20. 2005;100(2):281-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 15823636].
Kita H, Ohi M, Chin K, et al. The nocturnal secretion of cardiac natriuretic peptides during obstructive sleep apnoea and its response to therapy with nasal continuous positive airway pressure. J Sleep Res. Sep. 1998;7(3):199-207. Exclude: BNP measure not FDA approved. [pmid: 9785275].
Kitaoka H, Kubo T, Okawa M, et al. Impact of metalloproteinases on left ventricular remodeling and heart failure events in patients with hypertrophic cardiomyopathy. Circ J. May. 25. 2010;74(6):1191-6. Exclude: BNP measure not FDA approved. [pmid: 20453389].
Kitaoka H, Kubo T, Okawa M, et al. Plasma adiponectin levels and left ventricular remodeling in hypertrophic cardiomyopathy. Int Heart J. Jan. 2010;51(1):51-5. Exclude: BNP measure not FDA approved. [pmid: 20145352].
Kitaoka HK. Tissue doppler imaging and plasma BNP levels to assess the prognosis in patients with hypertrophic cardiomyopathy. J Am Soc Echocardiogr. 2011;24(9):1020-5. Exclude: BNP measure not FDA approved. [pmid: 21684113].
Kittleson MM, St John ME, Bead V, et al. Increased levels of uric acid predict haemodynamic compromise in patients with heart failure independently of B-type natriuretic peptide levels. Heart. Mar. 2007;93(3):365-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17322514].
Kittleson MM, Skojec DV, Wittstein IS, et al. The change in B-type natriuretic peptide levels over time predicts significant rejection in cardiac transplant recipients. J Heart Lung Transplant. Jul. 2009;28(7):704-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19560699].
Kitzman DW, Little WC, Brubaker PH, et al. Pathophysiological characterization of isolated diastolic heart failure in comparison to systolic heart failure. JAMA. Nov. 6. 2002;288(17):2144-50. Exclude: BNP measure not FDA approved. [pmid: 12413374].
Kiyono K, Hayano J, Watanabe E, et al. Non-Gaussian heart rate as an independent predictor of mortality in patients with chronic heart failure. Heart Rhythm. 2008;5(2):261-8. Exclude: BNP measure not FDA approved. [pmid: 18242551].
Kizer JR, Krauser DG, Rodeheffer RJ, et al. Prognostic value of multiple biomarkers in American Indians free of clinically overt cardiovascular disease (from the Strong Heart Study). Am J Cardiol. 2009;104(2):247-53. Exclude: BNP measure not FDA approved. [pmid: 19576355].
Kjaer A, Appel J, Hildebrandt P, et al. Basal and exercise-induced neuroendocrine activation in patients with heart failure and in normal subjects. Eur J Heart Fail. Jan. 2004;6(1):29-39. Exclude: BNP measure not FDA approved. [pmid: 15012916].
Kjaer A, Hildebrandt P, Appel J, et al. Neurohormones as markers of right- and left-sided cardiac dimensions and function in patients with untreated chronic heart failure. Int J Cardiol. Mar. 18. 2005;99(2):301-6. Exclude: BNP measure not FDA approved. [pmid: 15749191].
Kjekshus JK, Torp-Pedersen C, Gullestad L, et al. Effect of piboserod, a 5-HT4 serotonin receptor antagonist, on left ventricular function in patients with symptomatic heart failure. Eur J Heart Fail. Aug. 2009;11(8):771-8. Exclude: BNP measure not FDA approved. [pmid: 19567409].
Klaar U, Gabriel H, Bergler-Klein J, et al. Prognostic value of serial B-type natriuretic peptide measurement in asymptomatic organic mitral regurgitation. Eur J Heart Fail. 2011;13(2):163-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21051463].
Kleczyk R, Mysiak A, Brzostowicz P, et al. The dynamics of perioperative changes in serum BNP and troponin I concentrations in patients undergoing heart-valve correction with extracorporeal circulation. Adv Clin Exp Med. 2007;16(3):383-8. Exclude: BNP measure not FDA approved.
Klemen P, Golub M, Grmec S. Combination of quantitative capnometry, N-terminal pro-brain natriuretic peptide, and clinical assessment in differentiating acute heart failure from pulmonary disease as cause of acute dyspnea in pre-hospital emergency setting: Study of diagnostic accuracy. Croatian Med J. Apr. 2009;50(2):133-42. Exclude: BNP measure not FDA approved.
Klersy C, d'Eril GV, Barassi A, et al. Advantages of the lognormal approach to determining reference change values for N-terminal propeptide B-type natriuretic peptide. Clin Chim Acta. Mar. 22. 2012;413(5-6):544-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 22155398].
Klima T, Schindler C, Christ M, et al. Impact of body temperature on in-hospital and long-term mortality in patients with acute heart failure. Swiss Med Wkly. 2008;138(21-22):299-304. Exclude: BNP measure not FDA approved. [pmid: 18516750].
Kline JA, Hernandez-Nino J, Rose GA, et al. Surrogate markers for adverse outcomes in normotensive patients with pulmonary embolism. Crit Care Med. Nov. 2006;34(11):2773-80. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16943732].
Kline JA, Zeitouni R, Marchick MR, et al. Comparison of 8 biomarkers for prediction of right ventricular hypokinesis 6 months after submassive pulmonary embolism. Am Heart J. Aug. 2008;156(2):308-14. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18657661].
Klip IT, Voors AA, Anker SD, et al. Prognostic value of mid-regional pro-adrenomedullin in patients with heart failure after an acute myocardial infarction. Heart. Jun. 2011;97(11):892-8. Exclude: BNP measure not FDA approved. [pmid: 21415071].
Kluh T, Jabor A, Pavlisova M, et al. ROC analysis of BNP and left ventricular ejection fraction suggest higher diagnostic effectivity of BNP only from the prognostic aspect. Klin Biochem Metabol. 2003;11(2):93-6. Exclude: Not in English.
Knaapen P, Germans T, Camici PG, et al. Determinants of coronary microvascular dysfunction in symptomatic hypertrophic cardiomyopathy. Am J Physiol Heart Circ Physiol. Feb. 2008;294(2):H986-93. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18156203].
Knackstedt C, Mischke K, Schimpf T, et al. Integration of automatic intrathoracic fluid content measurement into clinical decision making in patients with congestive heart failure. Pacing Clin Electrophysiol. Aug. 2008;31(8):961-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18684251].
Knebel F, Schimke I, Pliet K, et al. NT-ProBNP in acute heart failure: Correlation with invasively measured hemodynamic parameters during recompensation. J Card Fail. Jun. 2005;11(5 Suppl):S38-41. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 15948099].
Knebel F, Eddicks S, Schimke I, et al. Myocardial tissue Doppler echocardiography and N-terminal B-type natriuretic peptide (NT-proBNP) in diastolic and systolic heart failure. Cardiovasc Ultrasound. 2008;6:45. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18778476].
Knebel F, Schimke I, Diaz R I, et al. Hemodynamic improvement of acutely decompensated heart failure patients is associated with decreasing levels of NT-proBNP. Int J Cardiol. May. 15. 2009;134(2):260-3. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18384896].
Knebel F, Schimke I, Schroeckh S, et al. Myocardial function in older male amateur marathon runners: Assessment by tissue Doppler echocardiography, speckle tracking, and cardiac biomarkers. J Am Soc Echocardiogr. Jul. 2009;22(7):803-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19505796].
Knight EL, Fish LC, Kiely DK, et al. Atrial natriuretic peptide and the development of congestive heart failure in the oldest old: A seven-year prospective study. J Am Geriatr Soc. Apr. 1999;47(4):407-11. Exclude: BNP measure not FDA approved. [pmid: 10203114].
Knudsen CW, Omland T, Clapton P, et al. Chest radiographs and BNP levels provided complementary information beyond clinical findings for diagnosing heart failure. Evid Based Med. 2004;9(5):152. Exclude: Not a primary study.
Knudsen CW, Clopton P, Westheim A, et al. Predictors of elevated B-type natriuretic peptide concentrations in dyspneic patients without heart failure: An analysis from the breathing not properly multinational study. Ann Emerg Med. Jun. 2005;45(6):573-80. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 15940086].
Kobayashi S, Susa T, Tanaka T, et al. Urinary 8-hydroxy-2'-deoxyguanosine reflects symptomatic status and severity of systolic dysfunction in patients with chronic heart failure. Eur J Heart Fail. 2011;13(1):29-36. Exclude: BNP measure not FDA approved. [pmid: 20965876].
Koc M, Karaarslan O, Abali G, et al. Variation in high-sensitivity C-reactive protein levels over 24 hours in patients with stable coronary artery disease. Tex Heart Inst J. 2010;37(1):42-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20200626].
Koca F, T I. Neutrophil gelatinase-associated lipocalin levels in right and left heart failure: An observational study. Anadolu Kardiyol Derg. 2011;11(6):498-503. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21788201].
Kocaman SA, Tacoy G, Ozdemir M, et al. The preserved autonomic functions may provide the asymptomatic clinical status in heart failure despite advanced left ventricular systolic dysfunction. Anadolu Kardiyol Derg. Dec. 2010;10(6):519-25. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20952357].
Koch M, Trapp R, Kohnle M, et al. B-type natriuretic peptide and severe heart failure at baseline predict overall mortality in incident dialysis patients. Clin Nephrol. Jan. 2010;73(1):21-9. Exclude: Not in English. [pmid: 20040348].
Kociol RD, Horton JR, Fonarow GC, et al. Admission, discharge, or change in B-type natriuretic peptide and long-term outcomes: Data from Organized Program to Initiate Lifesaving Treatment in Hospitalized Patients with Heart Failure (OPTIMIZE-HF) linked to Medicare claims. Circ Heart Fail. Sep. 2011;4(5):628-36. Exclude: BNP measure not FDA approved. [pmid: 21743005].
Koenig MA, Puttgen HA, Prabhakaran V, et al. B-type natriuretic peptide as a marker for heart failure in patients with acute stroke. Intensive Care Med. Sep. 2007;33(9):1587-93. Exclude: BNP measure not FDA approved. [pmid: 17541542].
Koga S, Ikeda S, Urata J, et al. Effect of nasal continuous positive airway pressure in men on global left ventricular myocardial performance in patients with obstructive sleep apnea syndrome. Am J Cardiol. Jun. 15. 2008;101(12):1796-800. Exclude: BNP measure not FDA approved. [pmid: 18549862].
Koglin J, Pehlivanli S, Schwaiblmair M, et al. Role of brain natriuretic peptide in risk stratification of patients with congestive heart failure. J Am Coll Cardiol. Dec. 2001;38(7):1934-41. Exclude: BNP measure not FDA approved. [pmid: 11738297].
Kohli P, Bonaca MP, Kakkar R, et al. Role of ST2 in non-ST-elevation acute coronary syndrome in the MERLIN-TIMI 36 trial. Clin Chem. Jan. 2012;58(1):257-66. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 22096031].
Kohno M, Yokokawa K, Yasunari K, et al. Changes in plasma cardiac natriuretic peptides concentrations during 1 year treatment with angiotensin-converting enzyme inhibitor in elderly hypertensive patients with left ventricular hypertrophy. Int J Clin Pharmacol Ther. Jan. 1997;35(1):38-42. Exclude: BNP measure not FDA approved. [pmid: 9021441].
Kohno T, Yoshikawa T, Yoshizawa A, et al. Carvedilol exerts more potent antiadrenergic effect than metoprolol in heart failure. Cardiovasc Drugs Ther. Oct. 2005;19(5):347-55. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16382297].
Koide K, Yoshikawa T, Nagatomo Y, et al. Elevated troponin T on discharge predicts poor outcome of decompensated heart failure. Heart Ves. May. 2010;25(3):217-22. Exclude: BNP measure not FDA approved.
Koitabashi N, Arai M, Niwano K, et al. Plasma connective tissue growth factor is a novel potential biomarker of cardiac dysfunction in patients with chronic heart failure. Eur J Heart Fail. Apr. 2008;10(4):373-9. Exclude: BNP measure not FDA approved. [pmid: 18337169].
Koitabashi T, Inomata T, Niwano S, et al. Distinguishable optimal levels of plasma B-type natriuretic peptide in heart failure management based on complicated atrial fibrillation. Int Heart J. May. 2005;46(3):453-64. Exclude: BNP measure not FDA approved. [pmid: 16043941].
Koivuviita N, Tertti R, Luotolahti M, et al. The effect of revascularization of atherosclerotic renal artery stenosis on coronary flow reserve and peripheral endothelial function. Nephron. 2011;118(3):c241-c248. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21196769].
Kojima M, Sato K, Kimura G, et al. Carvedilol reduces elevated B-type natriuretic peptide in dialyzed patients without heart failure: Cardioprotective effect of the beta-blocker. J Cardiovasc Pharmacol. 2007;49(4):191-6. Exclude: BNP measure not FDA approved. [pmid: 17438403].
Kojuri J, Atabati E, Moslemi S. Assessment of BNP level in patients with single chamber and dual chamber pacemakers. Iran Cardiovasc Res J. 2010;4(3):118-22. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Kokowicz P, Stec S, Flasinska K, et al. Troponin release following exercise test in patients with stable angina pectoris - Risk factors and prognostic significance. Kardiol Pol. 2010;68(4):414-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20425701].
Kolditz M, Halank M, Schiemanck CS, et al. High diagnostic accuracy of NT-proBNP for cardiac origin of pleural effusions. Eur Respir J. Jul. 2006;28(1):144-50. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16481382].
Koller A, Sumann G, Griesmacher A, et al. Cardiac troponins after a downhill marathon. Int J Cardiol. 2008;129(3):449-52. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17689705].
Komaba H, Igaki N, Goto S, et al. Adiponectin is associated with brain natriuretic peptide and left ventricular hypertrophy in hemodialysis patients with type 2 diabetes mellitus. Nephron. 2007;107(3):c103-8. Exclude: BNP measure not FDA approved. [pmid: 17890872].
Komajda M, Carson PE, Hetzel S, et al. Factors associated with outcome in heart failure with preserved ejection fraction: Findings from the Irbesartan in Heart Failure with Preserved Ejection Fraction Study (I-PRESERVE). Circ. Jan. 1. 2011;4(1):27-35. Exclude: BNP measure not FDA approved.
Komori T, Eguchi K, Tomizawa H, et al. Factors associated with incident ischemic stroke in hospitalized heart failure patients: A pilot study. Hypertens Res. Feb. 2008;31(2):289-94. Exclude: BNP measure not FDA approved. [pmid: 18360049].
Komukai K, Minai K, Arase S, et al. Impact of body mass index on clinical outcome in patients hospitalized with congestive heart failure. Circ J. 2012;76(1):145-51. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 22094909].
Konduracka E, Gackowski A, Rostoff P, et al. Diabetes-specific cardiomyopathy in type 1 diabetes mellitus: No evidence for its occurrence in the era of intensive insulin therapy. Eur Heart J. Oct. 2007;28(20):2465-71. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17766928].
Kondziella D, Gothlin M, Fu M, et al. B-type natriuretic peptide plasma levels are elevated in subcortical vascular dementia. Neuroreport. Jun. 17. 2009;20(9):825-7. Exclude: BNP measure not FDA approved. [pmid: 19424098].
Konig D, Neubauer O, Nics L, et al. Biomarkers of exercise-induced myocardial stress in relation to inflammatory and oxidative stress. Exerc Immunol Rev. 2007;13:15-36. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18198658].
Konishi H, Nishio S, Tsutamoto T, et al. Serum carvedilol concentration and its relation to change in plasma brain natriuretic peptide level in the treatment of heart failure: A preliminary study. Int J Clin Pharmacol Ther. Dec. 2003;41(12):578-86. Exclude: BNP measure not FDA approved. [pmid: 14692707].
Konishi M, Haraguchi G, Kimura S, et al. Comparative effects of carvedilol vs bisoprolol for severe congestive heart failure. Circ J. May. 25. 2010;74(6):1127-34. Exclude: BNP measure not FDA approved. [pmid: 20354334].
Konstantino Y, Kusniec J, Reshef T, et al. Inflammatory biomarkers are not predictive of intermediate-term risk of ventricular tachyarrhythmias in stable CHF patients. Clin Cardiol. Aug. 2007;30(8):408-13. Exclude: BNP measure not FDA approved. [pmid: 17680622].
Korngold EC, Januzzi JL Jr., Gantzer ML, et al. Amino-terminal pro-B-type natriuretic peptide and high-sensitivity C-reactive protein as predictors of sudden cardiac death among women. Circ. Jun. 9. 2009;119(22):2868-76. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Korse CM, Taal BG, de Groot CA, et al. Chromogranin-A and N-terminal pro-brain natriuretic peptide: An excellent pair of biomarkers for diagnostics in patients with neuroendocrine tumor. J Clin Oncol. Sep. 10. 2009;27(26):4293-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19667278].
Koseki Y, Watanabe J, Shinozaki T, et al. Characteristics and 1-year prognosis of medically treated patients with chronic heart failure in Japan. Circ J. May. 2003;67(5):431-6. Exclude: BNP measure not FDA approved. [pmid: 12736483].
Kosmala W, Spring A, Zysko D, et al. Effects of exercise on left ventricular diastolic dysfunction and neurohormonal activity in patients with essential hypertension. Kardiol Pol. 1999;50(3):217-24. Exclude: BNP measure not FDA approved.
Kosmala W, Kucharski W, Przewlocka-Kosmala M, et al. Comparison of left ventricular function by tissue Doppler imaging in patients with diabetes mellitus without systemic hypertension versus diabetes mellitus with systemic hypertension. Am J Cardiol. 2004;94(3):395-9. Exclude: BNP measure not FDA approved. [pmid: 15276118].
Kosmicki DL, Collins SP, Kontos MC, et al. Noninvasive prediction of left ventricular systolic dysfunction in patients with clinically suspected heart failure using acoustic cardiography. Congest Heart Fail. 2010;16(6):249-53. Exclude: BNP measure not FDA approved. [pmid: 21091608].
Kosowsky JM, Weiner C, Aronson AA, et al. Impact of point-of-care B-type natriuretic peptide (BNP) measurement on medical decision-making for older emergency department patients with dyspnea. J Emerg Med. Aug. 2006;31(2):147-50. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17044575].
Kostrubiec M, Pruszczyk P, Kaczynska A, et al. Persistent NT-proBNP elevation in acute pulmonary embolism predicts early death. Clin Chim Acta. 2007;382(1-2):124-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17507005].
Kotake T, Takada M, Komamura K, et al. Heart failure elevates serum levels of cibenzoline in arrhythmic patients. Circ J. May. 2006;70(5):588-92. Exclude: BNP measure not FDA approved. [pmid: 16636495].
Kotanidou A, Karsaliakos P, Tzanela M, et al. Prognostic importance of increased plasma amino-terminal pro-brain natriuretic peptide levels in a large noncardiac, general intensive care unit population. Shock. Apr. 2009;31(4):342-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18791494].
Kotaska K, Popelova J, Tiserova M, et al. NT-proBNP and BNP values in cardiac patients with different degree of left ventricular systolic dysfunction. Biomed Pap Med Fac Univ Palacky Olomouc Czech Repub. Jul. 2006;150(1):125-30. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16936915].
Kotaska K, Popelova J, Tiserova M, et al. The relevance of brain natriuretic peptides investigation in various cardiovascular diseases. Biomed Pap Med Fac Univ Palacky Olomouc Czech Repub. Nov. 2006;150(2):285-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17426794].
Kotlyar E, Vita JA, Winter MR, et al. The relationship between aldosterone, oxidative stress, and inflammation in chronic, stable human heart failure. J Card Fail. Mar. 2006;12(2):122-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16520260].
Kotyla PJ, Owczarek A, Rakoczy J, et al. Infliximab treatment increases left ventricular ejection fraction in patients with rheumatoid arthritis: Assessment of heart function by echocardiography, endothelin 1, interleukin 6, and NT-pro brain natriuretic peptide. J Rheumatol. 2012;39(4):701-6. Exclude: BNP measure not FDA approved. [pmid: 22337242].
Kouloubinis A, Kaklamanis L, Ziras N, et al. ProANP and NT-proBNP levels to prospectively assess cardiac function in breast cancer patients treated with cardiotoxic chemotherapy. Int J Cardiol. Nov. 30. 2007;122(3):195-201. Exclude: BNP measure not FDA approved. [pmid: 17289172].
Kourea K, Parissis JT, Farmakis D, et al. Effects of darbepoetin-alpha on plasma pro-inflammatory cytokines, anti-inflammatory cytokine interleukin-10 and soluble Fas/Fas ligand system in anemic patients with chronic heart failure. Atherosclerosis. Jul. 2008;199(1):215-21. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17991471].
Koyama T, Watanabe H, Kobukai Y, et al. Beneficial effects of adaptive servo ventilation in patients with chronic heart failure. Circ J. Oct. 2010;74(10):2118-24. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20679736].
Koyama T, Watanabe H, Igarashi G, et al. Short-term prognosis of adaptive servo-ventilation therapy in patients with heart failure. Circ J. Mar. 2011;75(3):710-2. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21266785].
Koyama Y, Takeishi Y, Arimoto T, et al. High serum level of pentosidine, an Advanced Glycation End Product (AGE), is a risk factor of patients with heart failure. J Card Fail. 2007;13(3):199-206. Exclude: BNP measure not FDA approved. [pmid: 17448417].
Kozdag G, Ertas G, Kilic T, et al. Elevated level of high-sensitivity C-reactive protein is important in determining prognosis in chronic heart failure. Med Sci Monit. Feb. 26. 2010;16(3):CR156-61. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20190687].
Kozdag G, Ertas G, Aygun F, et al. Clinical effects of enhanced external counterpulsation treatment in patients with ischemic heart failure. Anadolu Kardiyol Derg. 2012;12(3):214-21. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 22366105].
Kozelj M, Prokselj K, Berden P, et al. The syndrome of cardiac failure in adults with congenitally corrected transposition. Cardiol Young. Dec. 2008;18(6):599-607. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18828955].
Kozelj M, Zver S, Zadnik V. Echocardiographic assessment of left ventricular function in type 1 Gaucher's disease. Adv Hematol. 2010. Article Number: 820843:. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Kragelund C, Gronning B, Kober L, et al. N-terminal pro-B-type natriuretic peptide and long-term mortality in stable coronary heart disease. N Engl J Med. Feb. 17. 2005;352(7):666-75. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 15716560].
Kragelund C, Gronning B, Omland T, et al. Is N-terminal pro B-type natriuretic peptide (NT-proBNP) a useful screening test for angiographic findings in patients with stable coronary disease?. Am Heart J. Mar. 2006;151(3):712. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16504637].
Krakowiak B, Banasiak W, Ponikowski P, et al. Chronotropic response during exercise and recovery in men with mild systolic chronic heart failure. Kardiol Pol. Dec. 2010;68(12):1323-30. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21174283].
Krauser DG, Lloyd-Jones DM, Chae CU, et al. Effect of body mass index on natriuretic peptide levels in patients with acute congestive heart failure: A ProBNP Investigation of Dyspnea in the Emergency Department (PRIDE) substudy. Am Heart J. Apr. 2005;149(4):744-50. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 15990762].
Krecki R, Drozdz J, Szczesniak P, et al. Novel atherogenesis markers for identification of patients with a multivessel coronary artery disease. Kardiol Pol. 1181. Feb. 66(11):1173-80. Exclude: BNP measure not FDA approved. [pmid: 19105094].
Kremastinos DT, Tsiapras DP, Kostopoulou AG, et al. NT-proBNP levels and diastolic dysfunction in beta-Thalassaemia major patients. Eur J Heart Fail. 2007;9(5):531-6. Exclude: BNP measure not FDA approved. [pmid: 17317307].
Kremastinos DT, Hamodraka E, Parissis J, et al. Predictive value of B-type natriuretic peptides in detecting latent left ventricular diastolic dysfunction in beta-thalassemia major. Am Heart J. Jan. 2010;159(1):68-74. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20102869].
Krishnaswamy P, Lubien E, Clopton P, et al. Utility of B-natriuretic peptide levels in identifying patients with left ventricular systolic or diastolic dysfunction. Am J Med. 2001;111(4):274-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 11566457].
Kristoffersen US, Lebech AM, Gerstoft J, et al. Right and left cardiac function in HIV-infected patients investigated using radionuclide ventriculography and brain natriuretic peptide: A 5-year follow-up study. HIV Med. 2008;9(3):180-6. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18218002].
Krittayaphong R, Boonyasirinant T, Saiviroonporn P, et al. NT-proBNP levels in the evaluation of right ventricular dysfunction in patients with coronary artery disease and abnormal left ventricular wall motion: A magnetic resonance imaging study. Coron Artery Dis. Nov. 2008;19(7):481-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18923244].
Kroll MH, Srisawasdi P. The clearance of BNP modeled using the NT-proBNP-BNP relationship. Biosyst. Mar. 2007;88(1-2):147-55. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Kropp S, Tountopoulou A, Schneider U, et al. N-terminal fragment of B-type natriuretic peptide (NT-proBNP), a marker of cardiac safety during antipsychotic treatment. Ann Gen Psychiatry. 2005;4:10. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 15882448].
Kruger S, Graf J, Kunz D, et al. brain natriuretic peptide levels predict functional capacity in patients with chronic heart failure. J Am Coll Cardiol. Aug. 21. 2002;40(4):718-22. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 12204502].
Kruger S, Graf J, Merx MW, et al. Brain natriuretic peptide kinetics during dynamic exercise in patients with chronic heart failure. Int J Cardiol. May. 2004;95(1):49-54. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 15159038].
Kruger S, Graf J, Merx MW, et al. Brain natriuretic peptide predicts right heart failure in patients with acute pulmonary embolism. Am Heart J. Jan. 2004;147(1):60-5. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 14691420].
Krum H, Carson P, Farsang C, et al. Effect of valsartan added to background ACE inhibitor therapy in patients with heart failure: Results from Val-HeFT. Eur J Heart Fail. 2004;6(7):937-45. Exclude: BNP measure not FDA approved. [pmid: 15556056].
Krum H, Ashton E, Reid C, et al. Double-blind, randomized, placebo-controlled study of high-dose HMG CoA reductase inhibitor therapy on ventricular remodeling, pro-inflammatory cytokines and neurohormonal parameters in patients with chronic systolic heart failure. J Card Fail. 2007;13(1):1-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17338996].
Krum H, Massie B, Abraham WT, et al. Direct renin inhibition in addition to or as an alternative to angiotensin converting enzyme inhibition in patients with chronic systolic heart failure: Rationale and design of the Aliskiren Trial to Minimize OutcomeS in Patients with HEart failuRE (ATMOSPHERE) study. Eur J Heart Fail. 2011;13(1):107-14. Exclude: Not a primary study. [pmid: 21169387].
Krupicka J, Janota T, Kasalova Z, et al. Effect of short-term maximal exercise on BNP plasma levels in healthy individuals. Physiol Res. 2010;59(4):625-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19929142].
Kruszewski K, Scott AE, Barclay JL, et al. Noninvasive assessment of left ventricular filling pressure after acute myocardial infarction: A prospective study of the relative prognostic utility of clinical assessment, echocardiography, and B-type natriuretic peptide. Am Heart J. Jan. 2010;159(1):47-54. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20102866].
Krzych LJ, Szurlej D, Kolodziej T, et al. Diagnostic accuracy of pre-operative NT-proBNP level in predicting short-term outcomes in coronary surgery: A pilot study. Kardiol Pol. 2011;69(11):1121-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 22090218].
Kubanek M, Malek I, Bytesnik J, et al. Decrease in plasma B-type natriuretic peptide early after initiation of cardiac resynchronization therapy predicts clinical improvement at 12 months. Eur J Heart Fail. Dec. 2006;8(8):832-40. Exclude: BNP measure not FDA approved. [pmid: 16546444].
Kubo T, Kitaoka H, Okawa M, et al. Serum cardiac troponin I is related to increased left ventricular wall thickness, left ventricular dysfunction, and male gender in hypertrophic cardiomyopathy. Clin Cardiol. Feb. 2010;33(2):E1-7. Exclude: BNP measure not FDA approved. [pmid: 20043329].
Kubozono T, Itoh H, Oikawa K, et al. Peak VO(2) is more potent than B-type natriuretic peptide as a prognostic parameter in cardiac patients. Circ J. Apr. 2008;72(4):575-81. Exclude: BNP measure not FDA approved. [pmid: 18362428].
Kucher N, Printzen G, Doernhoefer T, et al. Low pro-brain natriuretic peptide levels predict benign clinical outcome in acute pulmonary embolism. Circ. Apr. 1. 2003;107(12):1576-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Kucher N, Printzen G, Goldhaber SZ. Prognostic role of brain natriuretic peptide in acute pulmonary embolism. Circ. May. 27. 2003;107(20):2545-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Kucher N, Quiroz R, McKean S, et al. Extended enoxaparin monotherapy for acute symptomatic pulmonary embolism. Vasc Med. 2005;10(4):251-6. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16444853].
Kudo Y, Oyama J, Nishiyama Y, et al. Immersion in hot spring improves cardiovascular functions in patients with chronic heart failure. J Jpn Assoc Phys Med Balneol Climatol. Aug. 2008;71(4):234-40. Exclude: Not in English.
Kuhn M, Voss M, Mitko D, et al. Left ventricular assist device support reverses altered cardiac expression and function of natriuretic peptides and receptors in end-stage heart failure. Cardiovasc Res. Nov. 1. 2004;64(2):308-14. Exclude: BNP measure not FDA approved. [pmid: 15485690].
Kuittinen T, Jantunen E, Vanninen E, et al. Cardiac effects within 3 months of BEAC high-dose therapy in non-Hodgkin's lymphoma patients undergoing autologous stem cell transplantation. Eur J Haematol. Aug. 2006;77(2):120-7. Exclude: BNP measure not FDA approved. [pmid: 16856907].
Kuklinska AM, Sobkowicz B, Kaminski KA, et al. The benefits of repeated measurements of B-type natriuretic peptide in patients with first ST-elevation myocardial infarction treated with primary percutaneous coronary intervention. Int Heart J. 2007;47(6):843-54. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17268119].
Kumagai J, Yorioka N, Kawanishi H, et al. Relationship between erythropoietin and chronic heart failure in patients on chronic hemodialysis. J Am Soc Nephrol. Nov. 1999;10(11):2407-11. Exclude: BNP measure not FDA approved. [pmid: 10541302].
Kumar S, Dispenzieri A, Lacy MQ, et al. Serum uric acid: Novel prognostic factor in primary systemic amyloidosis. Mayo Clin Proc. Mar. 2008;83(3):297-303. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18315995].
Kumar SK, Gertz MA, Lacy MQ, et al. Recent improvements in survival in primary systemic amyloidosis and the importance of an early mortality risk score. Mayo Clin Proc. Jan. 2011;86(1):12-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21193650].
Kupari M, Turto H, Lommi J. Diagnosing heart failure in aortic valve stenosis. J Intern Med. Nov. 2004;256(5):381-7. Exclude: BNP measure not FDA approved. [pmid: 15485473].
Kupari M, Turto H, Lommi J, et al. Transcardiac gradients of N-terminal B-type natriuretic peptide in aortic valve stenosis. Eur J Heart Fail. Aug. 2005;7(5):809-14. Exclude: BNP measure not FDA approved. [pmid: 16087135].
Kurl S, Ala-Kopsala M, Ruskoaho H, et al. Plasma N-terminal fragments of natriuretic peptides predict the risk of stroke and atrial fibrillation in men. Heart. Jul. 2009;95(13):1067-71. Exclude: BNP measure not FDA approved. [pmid: 19321489].
Kurosaki K, Tada H, Hashimoto T, et al. Plasma natriuretic peptide concentrations as a predictor for successful catheter ablation in patients with drug-refractory atrial fibrillation. Circ J. Mar. 2007;71(3):313-20. Exclude: BNP measure not FDA approved. [pmid: 17322627].
Kurt IH, Yavuzer K, Batur MK. Short-term effect of levosimendan on free light chain kappa and lambda levels in patients with decompensated chronic heart failure. Heart Ves. Sep. 2010;25(5):392-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Kurt IHC. The effect of levosimendan on BNP and other myocardial injury indicators in chronic atrial fibrillation cases with heart failure. Afr J Pharm Phamacol. 2011;5(1):53-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Kusumoto A, Miyata M, Kubozono T, et al. Highly sensitive cardiac troponin T in heart failure: Comparison with echocardiographic parameters and natriuretic peptides. J Cardiol. 2012;59(2):202-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 22266455].
Kuwabara Y, Sato Y, Miyamoto T, et al. Persistently increased serum concentrations of cardiac troponin in patients with acutely decompensated heart failure are predictive of adverse outcomes. Circ J. 2007;71(7):1047-51. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17587709].
Kuznetsova T, Herbots L, Lopez B, et al. Prevalence of left ventricular diastolic dysfunction in a general population. Circ. Mar. 2009;2(2):105-12. Exclude: BNP measure not FDA approved.
Kwan G, Isakson SR, Beede J, et al. Short-term serial sampling of natriuretic peptides in patients presenting with chest pain. J Am Coll Cardiol. Mar. 20. 2007;49(11):1186-92. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17367663].
Ky B, Kimmel SE, Safa RN, et al. Neuregulin-1beta is associated with disease severity and adverse outcomes in chronic heart failure. Circ. 2009;120(4):310-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Ky B, French B, Levy WC, et al. Multiple biomarkers for risk prediction in chronic heart failure. Circ Heart Fail. 2012;5(2):183-90. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 22361079].
Kypta A, Steinwender C, Kammler J, et al. Long-term outcomes in patients with atrioventricular block undergoing septal ventricular lead implantation compared with standard apical pacing. Europace. May. 2008;10(5):574-9. Exclude: BNP measure not FDA approved. [pmid: 18403387].
Kyriakides ZS, Markianos M, Michalis L, et al. Brain natriuretic peptide increases acutely and much more prominently than atrial natriuretic peptide during coronary angioplasty. Clin Cardiol. Apr. 2000;23(4):285-8. Exclude: BNP measure not FDA approved. [pmid: 10763077].
Kyrzopoulos S, Adamopoulos S, Parissis JT, et al. Levosimendan reduces plasma B-type natriuretic peptide and interleukin 6, and improves central hemodynamics in severe heart failure patients. Int J Cardiol. Mar. 30. 2005;99(3):409-13. Exclude: BNP measure not FDA approved. [pmid: 15771921].
Kyuma M, Nakata T, Hashimoto A, et al. Incremental prognostic implications of brain natriuretic peptide, cardiac sympathetic nerve innervation, and noncardiac disorders in patients with heart failure. J Nucl Med. Feb. 2004;45(2):155-63. Exclude: BNP measure not FDA approved. [pmid: 14960630].
La Gerche A, Connelly KA, Mooney DJ, et al. Biochemical and functional abnormalities of left and right ventricular function after ultra-endurance exercise. Heart. Jul. 2008;94(7):860-6. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17483127].
La Villa G, Fronzaroli C, Lazzeri C, et al. Cardiovascular and renal effects of low dose brain natriuretic peptide infusion in man. J Clin Endocrinol Metab. May. 1994;78(5):1166-71. Exclude: BNP measure not FDA approved. [pmid: 8175974].
LaBan MM, McNeary L. The clinical value of B-type natriuretic peptide (BNP) in predicting nocturnal low back pain in patients with concurrent lumbar spinal stenosis and cardiopulmonary dysfunction (Vesper's Curse): a clinical case series. Am J Phys Med Rehabil. Oct. 2008;87(10):798-802. Exclude: BNP measure not FDA approved. [pmid: 18806508].
Lader E. Doppler echocardiography was more accurate than B-type natriuretic peptide assay for detecting CHF in acute dyspnea. ACP J Club. Jul. 2003;139(1):22. Exclude: Not a primary study. [pmid: 12841726].
Laederach-Hofmann K, Roher-Gubeli R, Messerli N, et al. Comprehensive rehabilitation in chronic heart failure--better psycho-emotional status related to quality of life, brain natriuretic peptide concentrations, and clinical severity of disease. Clin Invest Med. 2007;30(2):E54-62. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17716542].
Lafaras C, Mandala E, Saratzis A, et al. Pro-brain natriuretic peptide is a sensitive marker for detecting cardiac metastases in patients with non-small cell lung cancer. Onkologie. Jul. 2009;32(7):389-92. Exclude: Not in English. [pmid: 19556815].
Lainchbury JG, Richards AM, Nicholls MG, et al. The effects of pathophysiological increments in brain natriuretic peptide in left ventricular systolic dysfunction. Hypertens. Sep. 1997;30(3 Pt 1):398-404. Exclude: BNP measure not FDA approved.
Lainchbury JG, Nicholls MG, Espiner EA, et al. Bioactivity and interactions of adrenomedullin and brain natriuretic peptide in patients with heart failure. Hypertens. Jul. 1999;34(1):70-5. Exclude: BNP measure not FDA approved.
Lainchbury JG, Richards AM. Exercise testing in the assessment of chronic congestive heart failure. Heart. 2002;88(5):538-43. Exclude: Not a primary study. [pmid: 12381653].
Lainchbury JG, Troughton RW, Strangman KM, et al. N-terminal pro-B-type natriuretic peptide-guided treatment for chronic heart failure: Results from the BATTLESCARRED (NT-proBNP-Assisted Treatment To Lessen Serial Cardiac Readmissions and Death) trial. J Am Coll Cardiol. Dec. 29. 2009;55(1):53-60. Exclude: BNP measure not FDA approved. [pmid: 20117364].
Lam CS, Burnett JC Jr., Costello-Boerrigter L, et al. Alternate circulating pro-B-type natriuretic peptide and B-type natriuretic peptide forms in the general population. J Am Coll Cardiol. Mar. 20. 2007;49(11):1193-202. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17367664].
Lambert M. NICE updates guidelines on management of chronic heart failure. Am Fam Phys. 2012;85(8):832-4. Exclude: Systematic review.
Lamblin N, Mouquet F, Hennache B, et al. High-sensitivity C-reactive protein: Potential adjunct for risk stratification in patients with stable congestive heart failure. Eur Heart J. Nov. 2005;26(21):2245-50. Exclude: BNP measure not FDA approved. [pmid: 16183690].
Lamblin N, Susen S, Dagorn J, et al. Prognostic significance of circulating levels of angiogenic cytokines in patients with congestive heart failure. Am Heart J. 2005;150(1):137-43. Exclude: BNP measure not FDA approved. [pmid: 16084160].
Lamblin N, Bauters A, Fertin M, et al. Circulating levels of hepatocyte growth factor and left ventricular remodelling after acute myocardial infarction (from the REVE-2 study). Eur J Heart Fail. Dec. 2011;13(12):1314-22. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21996026].
Lamblin N, Fertin M, de GP, et al. Incidence, determinants and consequences of left atrial remodelling after a first anterior myocardial infarction. Arch Cardiovasc Dis. 2012;105(1):18-23. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 22369914].
Lammers A, Kaemmerer H, Hollweck R, et al. Impaired cardiac autonomic nervous activity predicts sudden cardiac death in patients with operated and unoperated congenital cardiac disease. J Thorac Cardiovasc Surg. 2006;132(3):647-55. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16935122].
Lancellotti P, Cosyns B, Pierard LA. Dynamic left ventricular dyssynchrony contributes to B-type natriuretic peptide release during exercise in patients with systolic heart failure. Europace. Apr. 2008;10(4):496-501. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18319268].
Landberg E, Dahlstrom U, Alehagen U. Serum prolactin and macroprolactin in heart failure: No relation to established laboratory or clinical parameters. Ann Clin Biochem. 2011;48(1):51-6. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21115571].
Landesberg G, Gilon D, Meroz Y, et al. Diastolic dysfunction and mortality in severe sepsis and septic shock. Eur Heart J. Apr. 2012;33(7):895-903. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21911341].
Landray MJ, Lehman R, Arnold I. Measuring brain natriuretic peptide in suspected left ventricular systolic dysfunction in general practice: Cross-sectional study. BMJ. Apr. 8. 2000;320(7240):985-6. Exclude: BNP measure not FDA approved. [pmid: 10753153].
Lanfear DE, Stolker JM, Marsh S, et al. Natriuretic peptide receptor 3 genotype modulates the relationship between B-type natriuretic peptide and left ventricular end-diastolic pressure. Therapy. 2006;3(6):765-71. Exclude: BNP measure not FDA approved.
Lanfear DE, Stolker JM, Marsh S, et al. Genetic variation in the B-type natiuretic peptide pathway affects BNP levels. Cardiovasc Drugs Ther. 2007;21(1):55-62. Exclude: BNP measure not FDA approved. [pmid: 17340039].
Lanfear DE, Hasan R, Gupta RC, et al. Short term effects of milrinone on biomarkers of necrosis, apoptosis, and inflammation in patients with severe heart failure. J Translational Med. 2009;7:67. Exclude: BNP measure not FDA approved.
Lang CC, Motwani JG, Coutie WJ, et al. Clearance of brain natriuretic peptide in patients with chronic heart failure: Indirect evidence for a neutral endopeptidase mechanism but against an atrial natriuretic peptide clearance receptor mechanism. Clin Sci. Jun. 1992;82(6):619-23. Exclude: BNP measure not FDA approved. [pmid: 1320540].
Lang CC, Motwani JG, Rahman AR, et al. Effect of angiotensin-converting enzyme inhibition on plasma brain natriuretic peptide levels in patients with heart failure. Clin Sci. Aug. 1992;83(2):143-7. Exclude: BNP measure not FDA approved. [pmid: 1327628].
Lankeit M, Kempf T, Dellas C, et al. Growth differentiation factor-15 for prognostic assessment of patients with acute pulmonary embolism. Am J Respir Crit Care Med. May. 1. 2008;177(9):1018-25. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18263797].
Lansink-Hartgring AO, Eshuis J, Nieuwenhuis MK, et al. Adult respiratory distress syndrome or congestive heart failure in severe burn: a role for brain natriuretic peptide. Burns. Sep. 2010;36(6):e87-90. Exclude: Case report. [pmid: 20036070].
Laoutaris ID, Dritsas A, Brown MD, et al. Effects of inspiratory muscle training on autonomic activity, endothelial vasodilator function, and N-terminal pro-brain natriuretic peptide levels in chronic heart failure. J Cardiopulm Rehabil Prev. 2008;28(2):99-106. Exclude: BNP measure not FDA approved. [pmid: 18360185].
Lapp H, Boerrigter G, Costello-Boerrigter LC, et al. Elevated plasma human urotensin-II-like immunoreactivity in ischemic cardiomyopathy. Int J Cardiol. 2004;94(1):93-7. Exclude: BNP measure not FDA approved. [pmid: 14996481].
Lappegard KT, Bjornstad H. Anti-inflammatory effect of cardiac resynchronization therapy. Pacing Clin Electrophysiol. Jul. 2006;29(7):753-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16884512].
Larsen AI, Hall C, Aukrust P, et al. Prognostic usefulness of an increase of N-terminal proatrial natriuretic peptide during exercise in patients with chronic heart failure. Am J Cardiol. Jul. 1. 2003;92(1):91-4. Exclude: BNP measure not FDA approved. [pmid: 12842259].
Larsen AI, Dickstein K, Ahmadi NS, et al. The effect of altering haemodynamics on the plasma concentrations of natriuretic peptides in heart failure. Eur J Heart Fail. Oct. 2006;8(6):628-33. Exclude: BNP measure not FDA approved. [pmid: 16464637].
Larsen AI, Skadberg O, Aarsland T, et al. B-type natriuretic peptide is related to histological skeletal muscle abnormalities in patients with chronic heart failure. Int J Cardiol. Aug. 21. 2009;136(3):358-62. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18703243].
Laskowitz DT, Kasner SE, Saver J, et al. Clinical usefulness of a biomarker-based diagnostic test for acute stroke: The Biomarker Rapid Assessment in Ischemic Injury (BRAIN) study. Stroke. Jan. 2009;40(1):77-85. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18948614].
Lassus JP, Harjola VP, Peuhkurinen K, et al. Cystatin C, NT-proBNP, and inflammatory markers in acute heart failure: Insights into the cardiorenal syndrome. Biomarkers. Jun. 2011;16(4):302-10. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21417622].
Latini R, Masson S, Anand I, et al. Effects of valsartan on circulating brain natriuretic peptide and norepinephrine in symptomatic chronic heart failure: The Valsartan Heart Failure Trial (Val-HeFT). Circ. Nov. 5. 2002;106(19):2454-8. Exclude: BNP measure not FDA approved.
Latini R, Maggioni AP, Peri G, et al. Prognostic significance of the long pentraxin PTX3 in acute myocardial infarction. Circ. Oct. 2004;110(16):2349-54. Exclude: BNP measure not FDA approved.
Latini R, Masson S, Anand I, et al. The comparative prognostic value of plasma neurohormones at baseline in patients with heart failure enrolled in Val-HeFT. Eur Heart J. Feb. 2004;25(4):292-9. Exclude: BNP measure not FDA approved. [pmid: 14984917].
Latini R, Masson S, Wong M, et al. Incremental prognostic value of changes in B-type natriuretic peptide in heart failure. Am J Med. Jan. 2006;119(1):70-30. Exclude: BNP measure not FDA approved. [pmid: 16431191].
Latini R, Masson S, Anand IS, et al. Prognostic value of very low plasma concentrations of troponin T in patients with stable chronic heart failure. Circ. 2007;116(11):1242-9. Exclude: BNP measure not FDA approved.
Laukkanen JA, Kurl S, Ala-Kopsala M, et al. Plasma N-terminal fragments of natriuretic propeptides predict the risk of cardiovascular events and mortality in middle-aged men. Eur Heart J. May. 2006;27(10):1230-7. Exclude: BNP measure not FDA approved. [pmid: 16621869].
Lauten A, Ferrari M, Goebel B, et al. Microvascular tissue perfusion is impaired in acutely decompensated heart failure and improves following standard treatment. Eur J Heart Fail. Jul. 2011;13(7):711-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21543374].
Law C, Glover C, Benson K, et al. Extremely high brain natriuretic peptide does not reflect the severity of heart failure. Congest Heart Fail. 2010;16(5):221-5. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20887619].
Law YM, Keller BB, Feingold BM, et al. Usefulness of plasma B-type natriuretic peptide to identify ventricular dysfunction in pediatric and adult patients with congenital heart disease. Am J Cardiol. Feb. 15. 2005;95(4):474-8. Exclude: Population aged under 18. [pmid: 15695131].
Law YM, Ettedgui J, Beerman L, et al. Comparison of plasma B-type natriuretic peptide levels in single ventricle patients with systemic ventricle heart failure versus isolated cavopulmonary failure. Am J Cardiol. Aug. 15. 2006;98(4):520-4. Exclude: Population aged under 18. [pmid: 16893709].
Lazzeri C, Valente S, Chiostri M, et al. Uric acid in the early risk stratification of ST-elevation myocardial infarction. Internal & Emergency Medicine. Feb. 2012;7(1):33-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21234713].
Lebovitz HE, Banerji MA. Non-insulin injectable treatments (glucagon-like peptide-1 and its analogs) and cardiovascular disease. Diabetes Technol Therapeut. 2012;14(SUPPL. 1):S43-S50. Exclude: Not a primary study.
Lebrun C, Neuder Y, Pison C, et al. BNP or NT-proBNP: “That is the question”. Ann Biol Clin. Sep. 2007;65(5):533-8. Exclude: Not in English.
Lee CS, Moser DK, Lennie TA, et al. Biomarkers of myocardial stress and systemic inflammation in patients who engage in heart failure self-care management. J Cardiovasc Nurs. Jul. 2011;26(4):321-8. Exclude: BNP measure not FDA approved. [pmid: 21263344].
Lee HS, Son CB, Shin SH, et al. Clinical correlation between brain natriutetic peptide and anthracyclin-induced cardiac toxicity. Canc Res Treat. Sep. 2008;40(3):121-6. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Lee JA, Kim DH, Yoo SJ, et al. Association between serum n-terminal pro-brain natriuretic peptide concentration and left ventricular dysfunction and extracellular water in continuous ambulatory peritoneal dialysis patients. Perit Dial Int. May. 2006;26(3):360-5. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16722030].
Lee JE, Choi SY, Huh W, et al. N-terminal pro-brain natriuretic peptide levels predict left ventricular systolic function in patients with chronic kidney disease. J Korean Med Sci. Jan. 2009;24(Suppl):S63-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19194564].
Lee JE, Kim BS, Park W, et al. The relationship between heart rate recovery and brain natruretic peptide in patients with chest discomfort: A study for relationship between heart rate recovery and pre-exercise, post-exercise levels of brain natruretic peptide in patients with normal systolic function and chest discomfort. Korean Circ J. 2010;40(4):172-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20421957].
Lee JH, Park HS, Chae SC, et al. Predictors of six-month major adverse cardiac events in 30-day survivors after acute myocardial infarction (from the Korea Acute Myocardial Infarction Registry). Am J Cardiol. Jul. 15. 2009;104(2):182-9. Exclude: BNP measure not FDA approved. [pmid: 19576343].
Lee KH, Kim JY, Koh SB, et al. N-terminal pro-B-type natriuretic peptide levels in the Korean general population. Korean Circ J. 2010;40(12):645-50. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21267387].
Lee SC, Stevens TL, Sandberg SM, et al. The potential of brain natriuretic peptide as a biomarker for New York Heart Association class during the outpatient treatment of heart failure. J Card Fail. Jun. 2002;8(3):149-54. Exclude: BNP measure not FDA approved. [pmid: 12140807].
Lee SH, Jung JH, Choi SH, et al. Determinants of brain natriuretic peptide levels in patients with lone atrial fibrillation. Circ J. Jan. 2006;70(1):100-4. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16377932].
Lee SH, Choi S, Chung WJ, et al. Tissue Doppler index, E/E', and ischemic stroke in patients with atrial fibrillation and preserved left ventricular ejection fraction. J Neurol Sci. Aug. 15. 2008;271(1-2):148-52. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18501379].
Lee SJ, Kang JG, Ryu OH, et al. The relationship of thyroid hormone status with myocardial function in stress cardiomyopathy. Eur J Endocrinol. May. 2009;160(5):799-806. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19221174].
Lee YS, Kim KS, Lee JB, et al. Effect of valsartan on N-terminal pro-brain natriuretic peptide in patient with stable chronic heart failure: Comparison with enalapril. Korean Circ J. Feb. 2011;41(2):61-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21430990].
Leenders GE, De Boeck BWL, Teske AJ, et al. Septal rebound stretch is a strong predictor of outcome after cardiac resynchronization therapy. J Card Fail. 2012;18(5):404-12. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 22555272].
Leetmaa TH, Dam A, Glintborg D, et al. Myocardial response to a triathlon in male athletes evaluated by Doppler tissue imaging and biochemical parameters. Scand J Med Sci Sports. Dec. 2008;18(6):698-705. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18248532].
Leetmaa TH, Villadsen H, Mikkelsen KV, et al. Are there long-term benefits in following stable heart failure patients in a heart failure clinic?. Scand Cardiovasc J. Jun. 2009;43(3):158-62. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19065446].
Lefebvre A, Kural-Menasche S, Darmon M, et al. Use of N-terminal pro-brain natriuretic peptide to detect cardiac origin in critically ill cancer patients with acute respiratory failure. Intensive Care Med. May. 2008;34(5):833-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18214439].
Legaz-Arrese A, George K, Carranza-Garcia LE, et al. The impact of exercise intensity on the release of cardiac biomarkers in marathon runners. Eur J Appl Physiol. Dec. 2011;111(12):2961-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21442162].
Leistner DM, Klotsche J, Pieper L, et al. Circulating troponin as measured by a sensitive assay for cardiovascular risk assessment in primary prevention. Clin Chem. Jan. 2012;58(1):200-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 22156668].
Leistner DMF. Transplantation of progenitor cells and regeneration enhancement in acute myocardial infarction (TOPCARE-AMI): Final 5-year results suggest long-term safety and efficacy. Clin Res Cardiol. 2011;100(10):925-34. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21633921].
Leli C. Utility of brain natriuretic peptide as prognostic marker in community-acquired pneumonia and chronic obstructive pulmonary disease exacerbation patients presenting to the emergency department. Infezioni in Medicina. Dec. 2011;19(4):235-40. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 22212162].
Lellouche N, Berthier R, Mekontso-Dessap A, et al. Usefulness of plasma B-type natriuretic peptide in predicting recurrence of atrial fibrillation one year after external cardioversion. Am J Cardiol. Jun. 1. 2005;95(11):1380-2. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 15904651].
Lemmer J, Heise G, Rentzsch A, et al. Right ventricular function in grown-up patients after correction of congenital right heart disease. Clin Res Cardiol. Apr. 2011;100(4):289-96. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20981430].
Lenz TL, Foral PA, Malesker MA, et al. Impact of nesiritide on health care resource utilization and complications in patients with decompensated heart failure. Pharmacotherapy. Sep. 2004;24(9):1137-46. Exclude: BNP measure not FDA approved. [pmid: 15460174].
Leon I, Vicente R, Moreno I, et al. Plasma levels of N terminal pro-brain natriuretic peptide as a prognostic value in primary graft dysfunction and a predictor of mortality in the immediate postoperative period of lung transplantation. Transplant Proc. Jul. 2009;41(6):2216-7. Exclude: BNP measure not FDA approved. [pmid: 19715877].
Leong DP, Chakrabarty A, Shipp N, et al. Effects of myocardial fibrosis and ventricular dyssynchrony on response to therapy in new-presentation idiopathic dilated cardiomyopathy: Insights from cardiovascular magnetic resonance and echocardiography. Eur Heart J. Mar. 2012;33(5):640-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 22048681].
Leowattana W, Ong-Ajyooth L, Taruangsri P, et al. Circulating N-terminal pro-brain natriuretic peptide and cardiac troponin T in chronic dialysis patients. J Med Assoc Thai. May. 2003;86(Suppl 1):S52-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 12866769].
Leowattana W, Sirithunyanont C, Sukumalchantra Y, et al. Serum N-terminal pro-brain natriuretic peptide in normal Thai subjects. J Med Assoc Thai. May. 2003;86(Suppl 1):S46-51. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 12866768].
Lesman-Leegte I, van Veldhuisen DJ, Hillege HL, et al. Depressive symptoms and outcomes in patients with heart failure: Data from the COACH study. Eur J Heart Fail. Dec. 2009;11(12):1202-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19926602].
Leszek P, Szperl M, Klisiewicz A, et al. Alteration of myocardial sarcoplasmic reticulum Ca^2+^-ATPase and Na^+^-Ca^2+^ exchanger expression in human left ventricular volume overload. Eur J Heart Fail. 2007;9(6-7):579-86. Exclude: BNP measure not FDA approved. [pmid: 17347034].
Leszek P, Szperl M, Klisiewicz A, et al. Alterations in calcium regulatory protein expression in patients with preserved left ventricle systolic function and mitral valve stenosis. J Card Fail. Dec. 2008;14(10):873-80. Exclude: BNP measure not FDA approved. [pmid: 19041052].
Leszek P, Klisiewicz A, Janas J, et al. Determinants of the reduction in B-type natriuretic peptide after mitral valve replacement in patients with rheumatic mitral stenosis. Clin Physiol Funct Imag. Nov. 2010;30(6):473-9. Exclude: BNP measure not FDA approved.
Leszek P, Klisiewicz A, Janas J, et al. Usefulness of 6-minute walk test, plasma neurohumoral and cytokine activation in the assessment of symptomatic patients with left ventricle dysfunction caused by chronic severe mitral valve regurgitation. Acta Cardiol. Feb. 2010;65(1):43-51. Exclude: BNP measure not FDA approved. [pmid: 20306889].
Leuchte HH, Holzapfel M, Baumgartner RA, et al. Clinical significance of brain natriuretic peptide in primary pulmonary hypertension. J Am Coll Cardiol. Mar. 3. 2004;43(5):764-70. Exclude: BNP measure not FDA approved. [pmid: 14998614].
Leuchte HH, El Nounou M, Tuerpe JC, et al. N-terminal pro-brain natriuretic peptide and renal insufficiency as predictors of mortality in pulmonary hypertension. Chest. Feb. 2007;131(2):402-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17296640].
Leuppi JD, Dieterle T, Koch G, et al. Diagnostic value of lung auscultation in an emergency room setting. Swiss Med Wkly. Sep. 3. 2005;135(35-36):520-4. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16323069].
Lever M, George PM, Elmslie JL, et al. Betaine and secondary events in an acute coronary syndrome cohort. PLoS ONE. 2012;7(5). Exclude: BNP measure not FDA approved.
Levitt JE, Vinayak AG, Gehlbach BK, et al. Diagnostic utility of B-type natriuretic peptide in critically ill patients with pulmonary edema: A prospective cohort study. Crit Care. 2008;12(1):R3. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18194554].
Lewin J, Ledwidge M, O'Loughlin C, et al. Clinical deterioration in established heart failure: What is the value of BNP and weight gain in aiding diagnosis?. Eur J Heart Fail. Oct. 2005;7(6):953-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16227134].
Lewis DA, Gurram NR, Abraham WT, et al. Effect of nesiritide versus milrinone in the treatment of acute decompensated heart failure. Am J Health Syst Pharm. Aug. 15. 2003;60(Suppl 4):S16-20. Exclude: BNP measure not FDA approved. [pmid: 12966902].
Li G, Daniels CE, Kojicic M, et al. The accuracy of natriuretic peptides (brain natriuretic peptide and N-terminal pro-brain natriuretic) in the differentiation between transfusion-related acute lung injury and transfusion-related circulatory overload in the critically ill. Transfusion. Jan. 2009;49(1):13-20. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18954397].
Li JPL. Increased serum levels of S100B are related to the severity of cardiac dysfunction, renal insufficiency and major cardiac events in patients with chronic heart failure. Clin Biochem. 2011;44(12):984-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21640093].
Li L, Liu RY, Zhao XY, et al. Effects of combination therapy with perindopril and losartan on left ventricular remodelling in patients with myocardial infarction. Clin Exp Pharmacol Physiol. Jul. 2009;36(7):704-10. Exclude: BNP measure not FDA approved. [pmid: 19207720].
Li N, Li Y, Wang F, et al. Does NT-proBNP remain a sensitive biomarker for chronic heart failure after administration of a beta-blocker?. Clin Cardiol. Sep. 2007;30(9):469-74. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17803204].
Lian W, G X. Elevated plasma levels of adropin in heart failure patients. Intern Med. 2011;50(15):1523-7. Exclude: BNP measure not FDA approved. [pmid: 21804276].
Liang W, Li Y, Zhang B, et al. A novel microfluidic immunoassay system based on electrochemical immunosensors: An application for the detection of NT-proBNP in whole blood. Biosens Bioelectron. Jan. 15. 2012;31(1):480-5. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 22169814].
Liang Y, Gu M, Wang S. Reasons elevated B-type natriuretic peptide levels are associated with adverse outcome in patients undergoing cardiac surgery. J Cardiothorac Vasc Anesth. 2012;26(1):e6. Exclude: Not a primary study. [pmid: 22000985].
Liao H, Na MJ, Dikensoy O, et al. Diagnostic value of pleural fluid N-terminal pro-brain natriuretic peptide levels in patients with cardiovascular diseases. Respirology. Jan. 2008;13(1):53-7. Exclude: BNP measure not FDA approved. [pmid: 18197911].
Libetta C, Sepe V, Zucchi M, et al. Intermittent haemodiafiltration in refractory congestive heart failure: BNP and balance of inflammatory cytokines. Nephrol Dial Transplant. Jul. 2007;22(7):2013-9. Exclude: BNP measure not FDA approved. [pmid: 17298996].
Lieppman K, Kramer-Clark L, Tobias JD. Plasma B-type natriuretic peptide monitoring to evaluate cardiovascular function prior to organ procurement in patients with brain death. Paediatr Anaesth. Sep. 2008;18(9):852-6. Exclude: Population aged under 18. [pmid: 18768045].
Light RW. Use of pleural fluid N-terminal-pro-brain natriuretic peptide and brain natriuretic peptide in diagnosing pleural effusion due to congestive heart failure. Chest. Sep. 2009;136(3):656-8. Exclude: Not a primary study. [pmid: 19736184].
Lilleberg J, Laine M, Palkama T, et al. Duration of the haemodynamic action of a 24-h infusion of levosimendan in patients with congestive heart failure. Eur J Heart Fail. Jan. 2007;9(1):75-82. Exclude: BNP measure not FDA approved. [pmid: 16829185].
Lim TK, Ashrafian H, Dwivedi G, et al. Increased left atrial volume index is an independent predictor of raised serum natriuretic peptide in patients with suspected heart failure but normal left ventricular ejection fraction: Implication for diagnosis of diastolic heart failure. Eur J Heart Fail. Jan. 2006;8(1):38-45. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16115798].
Lim TK, Collinson PO, Celik E, et al. Value of primary care electrocardiography for the prediction of left ventricular systolic dysfunction in patients with suspected heart failure. Int J Cardiol. Jan. 31. 2007;115(1):73-4. Exclude: BNP measure not FDA approved. [pmid: 16777249].
Lim TK, Hayat SA, Gaze D, et al. Independent value of echocardiography and N-terminal pro-natriuretic peptide for the prediction of major outcomes in patients with suspected heart failure. Am J Cardiol. Sep. 1. 2007;100(5):870-5. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17719336].
Lim YJ, Yamamoto K, Ichikawa M, et al. Elevation of the ratio of transmitral E velocity to early diastolic mitral annular velocity continues even after recovery from acute stage in patients with diastolic heart failure. J Cardiol. Dec. 2008;52(3):254-60. Exclude: BNP measure not FDA approved. [pmid: 19027604].
Lima-Costa MF, Matos DL, Ribeiro AL. Chagas disease predicts 10-year stroke mortality in community-dwelling elderly: The Bambui cohort study of aging. Stroke. Nov. 2010;41(11):2477-82. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20864663].
Lima-Costa MF, Cesar CC, Peixoto SV, et al. Plasma B-type natriuretic peptide as a predictor of mortality in community-dwelling older adults with Chagas disease: 10-year follow-up of the Bambui Cohort Study of Aging. Am J Epidemiol. Jul. 15. 2010;172(2):190-6. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20581155].
Lima-Costa MF, Cesar CC, Chor D, et al. Self-rated health compared with objectively measured health status as a tool for mortality risk screening in older adults: 10-year follow-up of the bambui cohort study of aging. Am J Epidemiol. 2012;175(3):228-35. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 22193172].
Lima MMO, Rocha MOC, Nunes MCP, et al. A randomized trial of the effects of exercise training in Chagas cardiomyopathy. Eur J Heart Fail. 2010;12(8):866-73. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20675669].
Limkakeng AT Jr., Drake W, Mani G, et al. Left ventricular dysfunction screening in hypertensive patients with N-terminal pro-B-type natriuretic peptide and electrocardiogram. Am J Emerg Med. Jan. 2012;30(1):214-7. Exclude: BNP measure not FDA approved. [pmid: 21185671].
Limongelli G, Pacileo G, Ancona R, et al. Clinical course and risk profile in adolescents with idiopathic dilated cardiomyopathy. Am J Cardiol. Mar. 1. 2010;105(5):716-20. Exclude: Population aged under 18. [pmid: 20185022].
Lin JM, Lai LP, Tsai CT, et al. Interventricular mechanical dyssynchrony determines abnormal heightening of plasma N-terminal probrain natriuretic peptide level in symptomatic bradyarrhythmia patients with chronic dual-chamber vs. single-chamber atrial pacing. Cardiol. 2008;110(3):167-73. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Lindahl B, Lindback J, Jernberg T, et al. Serial analyses of N-terminal pro-B-type natriuretic peptide in patients with non-ST-segment elevation acute coronary syndromes A Fragmin and fast Revascularisation during InStability in coronary artery disease (FRISC)-II substudy. J Am Coll Cardiol. Feb. 15. 2005;45(4):533-41. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 15708700].
Lindner G, Doberer E, Vychytil A, et al. Prognosis in patients with congestive heart failure and subacute renal failure treated with hemodialysis. Wien Klin Wochenschr. 2009;121(11-12):391-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19626297].
Linssen GC, Damman K, Hillege HL, et al. Urinary N-terminal prohormone brain natriuretic peptide excretion in patients with chronic heart failure. Circ. Jul. 7. 2009;120(1):35-41. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Linssen GC, Bakker SJ, Voors AA, et al. N-terminal pro-B-type natriuretic peptide is an independent predictor of cardiovascular morbidity and mortality in the general population. Eur Heart J. Jan. 2010;31(1):120-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19854731].
Linssen GCM. Clinical and prognostic effects of atrial fibrillation in heart failure patients with reduced and preserved left ventricular ejection fraction. Eur J Heart Fail. 2011;13(10):1111-20. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21642293].
Linzbach S, Samigullin A, Yilmaz S, et al. Role of N-terminal pro-brain natriuretic peptide and cystatin C to estimate renal function in patients with and without heart failure. Am J Cardiol. Apr. 15. 2009;103(8):1128-33. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19361601].
Lippi G, Schena F, Salvagno GL, et al. Influence of a half-marathon run on NT-proBNP and troponin T. Clin Lab. 2008;54(7-8):251-4. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18942493].
Lipsanen-Nyman M, Perheentupa J, Rapola J, et al. Mulibrey heart disease: Clinical manifestations, long-term course, and results of pericardiectomy in a series of 49 patients born before 1985. Circ. Jun. 10. 2003;107(22):2810-5. Exclude: BNP measure not FDA approved.
Liu H, Zhang YZ, Gao M, et al. Elevation of B-type natriuretic peptide is a sensitive marker of left ventricular diastolic dysfunction in patients with maintenance haemodialysis. Biomarkers. Sep. 2010;15(6):533-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20536328].
Liu LC, Voors AA, van Veldhuisen DJ, et al. Vitamin D status and outcomes in heart failure patients. Eur J Heart Fail. Jun. 2011;13(6):619-25. Exclude: BNP measure not FDA approved. [pmid: 21543375].
Liu MH, Wang CH, Huang YY, et al. Edema index-guided disease management improves 6-month outcomes of patients with acute heart failure. Int Heart J. 2012;53(1):11-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 22398670].
Locatelli F, Eckardt KU, MacDougall IC, et al. Value of N-terminal brain natriuretic peptide as a prognostic marker in patients with CKD: Results from the CREATE study. Curr Med Res Opin. 2010;26(11):2543-52. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20849244].
Logeart D, Beyne P, Cusson C, et al. Evidence of cardiac myolysis in severe nonischemic heart failure and the potential role of increased wall strain. Am Heart J. Feb. 2001;141(2):247-53. Exclude: BNP measure not FDA approved. [pmid: 11174339].
Logeart D, Lecuyer L, Thabut G, et al. Biomarker-based strategy for screening right ventricular dysfunction in patients with non-massive pulmonary embolism. Intensive Care Med. Feb. 2007;33(2):286-92. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17165016].
Logeart D, Gueffet JP, Rouzet F, et al. Heart rate per se impacts cardiac function in patients with systolic heart failure and pacing: A pilot study. Eur J Heart Fail. Jan. 2009;11(1):53-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19147457].
Lok DJ, van der MP, de la Porte PW, et al. Prognostic value of galectin-3, a novel marker of fibrosis, in patients with chronic heart failure: Data from the DEAL-HF study. Clin Res Cardiol. May. 2010;99(5):323-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20130888].
Loke I, Squire IB, Davies JE, et al. Reference ranges for natriuretic peptides for diagnostic use are dependent on age, gender and heart rate. Eur J Heart Fail. Oct. 2003;5(5):599-606. Exclude: BNP measure not FDA approved. [pmid: 14607197].
Lombardi F, Tundo F, Belletti S, et al. C-reactive protein but not atrial dysfunction predicts recurrences of atrial fibrillation after cardioversion in patients with preserved left ventricular function. J Cardiovasc Med. Jun. 2008;9(6):581-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Loncar G, Bozic B, Cvorovic V, et al. Relationship between RANKL and neuroendocrine activation in elderly males with heart failure. Endocr. 2010;37(1):148-56. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Loncar G, Bozic B, Dimkovic S, et al. Association of increased parathyroid hormone with neuroendocrine activation and endothelial dysfunction in elderly men with heart failure. J Endocrinol Invest. Mar. 2011;34(3):e78-85. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20820131].
Loncar G, Bozic B, Lepic T, et al. Relationship of reduced cerebral blood flow and heart failure severity in elderly males. Aging Male. 2011;14(1):59-65. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20873985].
Loncar G, Von HS, Tahirovic E, et al. Effect of beta blockade on natriuretic peptides and copeptin in elderly patients with heart failure and preserved or reduced ejection fraction: Results from the CIBIS-ELD trial. Clin Biochem. 2012;45(1-2):117-22. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 22155435].
Long AC, O'Neal HR Jr., Peng S, et al. Comparison of pleural fluid N-terminal pro-brain natriuretic peptide and brain natriuretic-32 peptide levels. Chest. Jun. 2010;137(6):1369-74. Exclude: BNP measure not FDA approved. [pmid: 20139229].
Lopez B, Gonzalez A, Querejeta R, et al. Association of plasma cardiotrophin-1 with stage C heart failure in hypertensive patients: Potential diagnostic implications. J Hypertens. Feb. 2009;27(2):418-24. Exclude: BNP measure not FDA approved. [pmid: 19155793].
Lorgis L, Zeller M, Dentan G, et al. Prognostic value of N-terminal pro-brain natriuretic peptide in elderly people with acute myocardial infarction: Prospective observational study. BMJ. 2009;338:b1605. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19420032].
Lossnitzer D, Steen H, Zahn A, et al. Myocardial late gadolinium enhancement cardiovascular magnetic resonance in patients with cirrhosis. J Cardiovasc Magn Reson. 2010;12:47. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20704762].
Lourenco C, Saraiva F, Martins H, et al. Ischemic versus non-ischemic cardiomyopathy--Are there differences in prognosis? Experience of an advanced heart failure center. Rev Port Cardiol. Feb. 2011;30(2):181-97. Exclude: BNP measure not FDA approved. [pmid: 21553611].
Lourenco P, Araujo JP, Azevedo A, et al. The cyclic guanosine monophosphate/B-type natriuretic peptide ratio and mortality in advanced heart failure. Eur J Heart Fail. Feb. 2009;11(2):185-90. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19168517].
Lowbeer C, Gustafsson SA, Seeberger A, et al. Serum cardiac troponin T in patients hospitalized with heart failure is associated with left ventricular hypertrophy and systolic dysfunction. Scand J Clin Lab Invest. 2004;64(7):667-76. Exclude: BNP measure not FDA approved. [pmid: 15513324].
Lowbeer C, Seeberger A, Gustafsson SA, et al. Serum cardiac troponin T, troponin I, plasma BNP and left ventricular mass index in professional football players. J Sci Med Sport. Oct. 2007;10(5):291-6. Exclude: BNP measure not FDA approved. [pmid: 17289431].
Luchner A, Brockel U, Muscholl M, et al. Gender-specific differences of cardiac remodeling in subjects with left ventricular dysfunction: A population-based study. Cardiovasc Res. Feb. 15. 2002;53(3):720-7. Exclude: BNP measure not FDA approved. [pmid: 11861042].
Luchner A, Hengstenberg C, Lowel H, et al. Effect of compensated renal dysfunction on approved heart failure markers: Direct comparison of brain natriuretic peptide (BNP) and N-terminal pro-BNP. Hypertens. Jul. 2005;46(1):118-23. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Luchner A, Hengstenberg C, Lowel H, et al. NT-ProBNP in outpatients after myocardial infarction: Interaction between symptoms and left ventricular function and optimized cut-points. J Card Fail. Jun. 2005;11(5:Suppl):S21-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 15948096].
Luchner A, Weidemann A, Willenbrock R, et al. Improvement of the cardiac marker N-terminal-pro brain natriuretic peptide through adjustment for renal function: A stratified multicenter trial. Clin Chem Lab Med. 2010;48(1):121-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20047532].
Luchner A, Mockel M, Spanuth E, et al. N-terminal pro brain natriuretic peptide in the management of patients in the medical emergency department (PROMPT): Correlation with disease severity, utilization of hospital resources, and prognosis in a large, prospective, randomized multicentre trial. Eur J Heart Fail. Mar. 2012;14(3):259-67. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 22265921].
Luchowski P, Mitosek-Szewczyk K, Bartosik-Psujek H, et al. B-type natriuretic peptide as a marker of subclinical heart injury during mitoxantrone therapy in MS patients--Preliminary study. Clin Neurol Neurosurg. Oct. 2009;111(8):676-8. Exclude: BNP measure not FDA approved. [pmid: 19632767].
Luedorff G, Grove R, Kowalski M, et al. Impact of chronic atrial fibrillation in patients with severe heart failure and indication for CRT: Data of two registries with 711 patients (1999-2006 and 2007-6/2008). Herzschrittmacherther Elecktrophysiol. Dec. 2011;22(4):226-32. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Luers C, Wachter R, Kleta S, et al. Natriuretic peptides in the detection of preclinical diastolic or systolic dysfunction. Clin Res Cardiol. Apr. 2010;99(4):217-26. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20052479].
Lukowicz TV, Fischer M, Hense HW, et al. BNP as a marker of diastolic dysfunction in the general population: Importance of left ventricular hypertrophy. Eur J Heart Fail. Jun. 2005;7(4):525-31. Exclude: BNP measure not FDA approved. [pmid: 15921790].
Lula JF, Rocha MODC, Nunes MDCP, et al. Plasma concentrations of tumour necrosis factor-alpha, tumour necrosis factor-related apoptosis-inducing ligand, and FasLigand/CD95L in patients with Chagas cardiomyopathy correlate with left ventricular dysfunction. Eur J Heart Fail. 2009;11(9):825-31. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19654138].
Lunghetti S, Palmerini. Effects of levosimendan without loading dose on systolic and diastolic function in patients with end-stage heart failure. Cardiol J. 2011;18(5):532-7. Exclude: BNP measure not FDA approved. [pmid: 21947989].
Lupattelli G, Marchesi S, Siepi D, et al. Natriuretic peptides levels are related to HDL-cholesterol with no influence on endothelium dependent vasodilatation. Vasa. Nov. 2006;35(4):215-20. Exclude: BNP measure not FDA approved. [pmid: 17109362].
Luscher TF, Ruschitzka F, Anand I, et al. EARTH: Endothelin A receptor antagonist trial in heart failure. Heartdrug. 2001;1(6):294-8. Exclude: BNP measure not FDA approved.
Luther SA, McCullough PA, Havranek EP, et al. The relationship between B-type natriuretic peptide and health status in patients with heart failure. J Card Fail. Aug. 2005;11(6):414-21. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16105631].
Luthi P, Zuber M, Ritter M, et al. Echocardiographic findings in former professional cyclists after long-term deconditioning of more than 30 years. Eur J Echocardiogr. Mar. 2008;9(2):261-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17470417].
Luthje L, Vollmann D, Drescher T, et al. Intrathoracic impedance monitoring to detect chronic heart failure deterioration: Relationship to changes in NT-proBNP. Eur J Heart Fail. 2007;9(6-7):716-22. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17462948].
Lycholip E, Celutkiene J, Rudys A, et al. Patient education significantly improves quality of life, exercise capacity and BNP level in stable heart failure patients. Acta Cardiol. Oct. 2010;65(5):549-56. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21125977].
Mabuchi N, Tsutamoto T, Maeda K, et al. Plasma cardiac natriuretic peptides as biochemical markers of recurrence of atrial fibrillation in patients with mild congestive heart failure. Jpn Circ J. Oct. 2000;64(10):765-71. Exclude: BNP measure not FDA approved. [pmid: 11059617].
Mabuchi N, Tsutamoto T, Wada A, et al. Relationship between interleukin-6 production in the lungs and pulmonary vascular resistance in patients with congestive heart failure. Chest. 2002;121(4):1195-202. Exclude: BNP measure not FDA approved. [pmid: 11948053].
MacChi A, Franzoni I, Buzzetti F, et al. The role of nutritional supplementation with essential amino acids in patients with chronic heart failure. Mediterran J Nutr Metab. 2010;3(3):209-14. Exclude: BNP measure not FDA approved.
Macchia A, Rodriguez Moncalvo JJ, Kleinert M, et al. Unrecognised ventricular dysfunction in COPD. Eur Respir J. Jan. 2012;39(1):51-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21700606].
Macdonald JE, Kennedy N, Struthers AD. Effects of spironolactone on endothelial function, vascular angiotensin converting enzyme activity, and other prognostic markers in patients with mild heart failure already taking optimal treatment. Heart. Jul. 2004;90(7):765-70. Exclude: BNP measure not FDA approved. [pmid: 15201246].
MacDonald MR, Connelly DT, Hawkins NM, et al. Radiofrequency ablation for persistent atrial fibrillation in patients with advanced heart failure and severe left ventricular systolic dysfunction: A randomised controlled trial. Heart. May. 2011;97(9):740-7. Exclude: BNP measure not FDA approved. [pmid: 21051458].
Macdonald S, Arendts G, Nagree Y, et al. Neutrophil Gelatinase-Associated Lipocalin (NGAL) predicts renal injury in acute decompensated cardiac failure: A prospective observational study. BMC Cardiovasc Disord. 2012;12:8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 22340728].
Maceira AM, Prasad SK, Hawkins PN, et al. Cardiovascular magnetic resonance and prognosis in cardiac amyloidosis. J Cardiovasc Magn Reson. 2008;10:54. Exclude: BNP measure not FDA approved. [pmid: 19032744].
Machado RF, Anthi A, Steinberg MH, et al. N-terminal pro-brain natriuretic peptide levels and risk of death in sickle cell disease. JAMA. Jul. 19. 2006;296(3):310-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16849664].
Macheret F, Boerrigter G, McKie P, et al. Pro-B-type natriuretic peptide(1-108) circulates in the general community: Plasma determinants and detection of left ventricular dysfunction. J Am Coll Cardiol. Mar. 22. 2011;57(12):1386-95. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21414536].
MacKenzie E, Smith A, Angus N, et al. Mixed-method exploratory study of general practitioner and nurse perceptions of a new community based nurse-led heart failure service. Rural Rem Health. 2010;10(4):1510. Exclude: BNP measure not FDA approved.
Madaric J, Vanderheyden M, Van Laethem C, et al. Early and late effects of cardiac resynchronization therapy on exercise-induced mitral regurgitation: Relationship with left ventricular dyssynchrony, remodelling and cardiopulmonary performance. Eur Heart J. Sep. 2007;28(17):2134-41. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17504802].
Madhavan M, Borlaug BA, Lerman A, et al. Stress hormone and circulating biomarker profile of apical ballooning syndrome (Takotsubo cardiomyopathy): Insights into the clinical significance of B-type natriuretic peptide and troponin levels. Heart. Sep. 2009;95(17):1436-41. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19468013].
Madsen LH, Ladefoged S, Corell P, et al. N-terminal pro brain natriuretic peptide predicts mortality in patients with end-stage renal disease in hemodialysis. Kidney Int. Mar. 2007;71(6):548-54. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17299526].
Mady C, Fernandes F, Ramires FJ, et al. N-terminal prohormone brain natriuretic peptide (NT-proBNP) as a noninvasive marker for restrictive syndromes. Braz J Med Biol Res. Aug. 2008;41(8):664-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18797698].
Mady C, Fernandes F, Arteaga E, et al. Serum NT pro-BNP: Relation to systolic and diastolic function in cardiomyopathies and pericardiopathies. Arq Bras Cardiol. Jul. 2008;91(1):46-54. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18660945].
Maeda K, Tsutamoto T, Wada A, et al. Plasma brain natriuretic peptide as a biochemical marker of high left ventricular end-diastolic pressure in patients with symptomatic left ventricular dysfunction. Am Heart J. May. 1998;135(5 Pt 1):825-32. Exclude: BNP measure not FDA approved. [pmid: 9588412].
Maeda K, Tsutamoto T, Wada A, et al. High levels of plasma brain natriuretic peptide and interleukin-6 after optimized treatment for heart failure are independent risk factors for morbidity and mortality in patients with congestive heart failure. J Am Coll Cardiol. Nov. 1. 2000;36(5):1587-93. Exclude: BNP measure not FDA approved. [pmid: 11079662].
Maeder M, Wolber T, Rickli H, et al. B-type natriuretic peptide kinetics and cardiopulmonary exercise testing in heart failure. Int J Cardiol. 2007;120(3):391-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17182129].
Maeder MT, Ammann P, Rickli H, et al. N-terminal pro-B-type natriuretic peptide and functional capacity in patients with obstructive sleep apnea. Sleep Breath. Mar. 2008;12(1):7-16. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17906885].
Maeder MT, Hack D, Rickli H, et al. Relevance of short-term variation of B-type natriuretic peptide in patients with clinically stable heart failure. Wien Klin Wochenschr. 2008;120(21-22):672-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19116708].
Maeder MT, Ammann P, Munzer T, et al. Continuous positive airway pressure improves exercise capacity and heart rate recovery in obstructive sleep apnea. Int J Cardiol. Feb. 6. 2009;132(1):75-83. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18191481].
Maeder MT, Mariani JA, Kaye DM. Hemodynamic determinants of myocardial B-type natriuretic peptide release: Relative contributions of systolic and diastolic wall stress. Hypertens. Oct. 2010;56(4):682-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Maejima YN. Synergistic effect of combined HMG-CoA reductase inhibitor and angiotensin-II receptor blocker therapy in patients with chronic heart failure: The HF-COSTAR trial. Circ J. 2011;75(3):589-95. Exclude: BNP measure not FDA approved. [pmid: 21242642].
Maekawa Y, Kawamura A, Yuasa S, et al. Direct comparison of takotsubo cardiomyopathy between Japan and USA: 3-year follow-up study. Intern Med. 2012;51(3):257-62. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 22293799].
Maffei S, Clerico A, Iervasi G, et al. Circulating levels of cardiac natriuretic hormones measured in women during menstrual cycle. J Endocrinol Invest. Jan. 1999;22(1):1-5. Exclude: BNP measure not FDA approved. [pmid: 10090129].
Magga J, Sipola P, Vuolteenaho O, et al. Significance of plasma levels of N-terminal Pro-B-type natriuretic peptide on left ventricular remodeling in non-obstructive hypertrophic cardiomyopathy attributable to the Asp175Asn mutation in the alpha-tropomyosin gene. Am J Cardiol. Apr. 15. 2008;101(8):1185-90. Exclude: BNP measure not FDA approved. [pmid: 18394456].
Maggioni AP, Anand I, Gottlieb SO, et al. Effects of valsartan on morbidity and mortality in patients with heart failure not receiving angiotensin-converting enzyme inhibitors. J Am Coll Cardiol. 2002;40(8):1414-21. Exclude: BNP measure not FDA approved. [pmid: 12392830].
Maggioni AP, Latini R, Carson PE, et al. Valsartan reduces the incidence of atrial fibrillation in patients with heart failure: Results from the Valsartan Heart Failure Trial (Val-HeFT). Am Heart J. Mar. 2005;149(3):548-57. Exclude: BNP measure not FDA approved. [pmid: 15864246].
Magne J, Dubois M, Champagne J, et al. Usefulness of NT-pro BNP monitoring to identify echocardiographic responders following cardiac resynchronization therapy. Cardiovasc Ultrasound. 2009;7:39. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19695099].
Magnusson M, Jovinge S, Rydberg E, et al. Natriuretic peptides as indicators of cardiac remodeling in hypertensive patients. Blood Press. Sep. 2009;18(4):196-203. Exclude: BNP measure not FDA approved. [pmid: 19562575].
Magnusson M, Jovinge S, Shahgaldi K, et al. Brain natriuretic peptide is related to diastolic dysfunction whereas urinary albumin excretion rate is related to left ventricular mass in asymptomatic type 2 diabetes patients. Cardiovasc Diabetol. 2010;9:2. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20078898].
Magnusson M, Jujic A, Hedblad B, et al. Low plasma level of atrial natriuretic peptide predicts development of diabetes: The prospective Malmo Diet and Cancer study. J Clin Endocrinol Metab. Feb. 2012;97(2):638-45. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 22112816].
Mahadevan G, Dwivedi G, Williams L, et al. Epidemiology and diagnosis of heart failure with preserved left ventricular ejection fraction: rationale and design of the study. Eur J Heart Fail. Jan. 2012;14(1):106-12. Exclude: Not a primary study. [pmid: 22120964].
Maimaitiming S, Roussel R, Hadjadj S, et al. Association of common variants in NPPA and NPPB with blood pressure does not translate into kidney damage in a general population study. J Hypertens. Jun. 2010;28(6):1230-3. Exclude: BNP measure not FDA approved. [pmid: 20407391].
Mair J, Falkensammer G, Poelzl G, et al. B-type natriuretic peptide (BNP) is more sensitive to rapid hemodynamic changes in acute heart failure than N-terminal proBNP. Clin Chim Acta. Apr. 2007;379(1-2):163-6. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17258185].
Mair J, Gerda F, Renate H, et al. Head-to-head comparison of B-type natriuretic peptide (BNP) and NT-proBNP in daily clinical practice. Int J Cardiol. Feb. 29. 2008;124(2):244-6. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17360054].
Maisel A. Brain natriuretic peptide and breathing not properly: The merger of 2 BNPs. Clin Chem. Feb. 2012;58(2):469-70. Exclude: Not a primary study. [pmid: 21965554].
Maisel A, Neath SX, Landsberg J, et al. Use of procalcitonin for the diagnosis of pneumonia in patients presenting with a chief complaint of dyspnoea: Results from the BACH (Biomarkers in Acute Heart Failure) trial. Eur J Heart Fail. 2012;14(3):278-86. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 22302662].
Maisel AM. Midregion prohormone adrenomedullin and prognosis in patients presenting with acute dyspnea: Results from the BACH (Biomarkers in Acute Heart Failure) Trial. J Am Coll Cardiol. 2011;58(10):1057-67. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21867843].
Maisel AS, Koon J, Krishnaswamy P, et al. Utility of B-natriuretic peptide as a rapid, point-of-care test for screening patients undergoing echocardiography to determine left ventricular dysfunction. Am Heart J. Mar. 2001;141(3):367-74. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 11231433].
Maisel AS, Peacock WF, McMullin N, et al. Timing of immunoreactive B-type natriuretic peptide levels and treatment delay in acute decompensated heart failure: An ADHERE (Acute Decompensated Heart Failure National Registry) analysis. J Am Coll Cardiol. Aug. 12. 2008;52(7):534-40. Exclude: BNP measure not FDA approved. [pmid: 18687247].
Maisel AS, Nakao K, Ponikowski P, et al. Japanese-Western consensus meeting on biomarkers. Int Heart J. 2011;52(5):253-65. Exclude: Not a primary study. [pmid: 22008432].
Maisel ASP. Acoustic cardiography S3 detection use in problematic subgroups and B-type natriuretic peptide “gray zone”: Secondary results from the Heart failure and Audicor technology for Rapid Diagnosis and Initial Treatment Multinational Investigation. Am J Emerg Med. 2011;29(8):924-31. Exclude: BNP measure not FDA approved. [pmid: 20627217].
Maki N, Yoshiyama M, Omura T, et al. Effect of diltiazem on cardiac function assessed by echocardiography and neurohumoral factors after reperfused myocardial infarction without congestive heart failure. Cardiovasc Drugs Ther. Nov. 2001;15(6):493-9. Exclude: BNP measure not FDA approved. [pmid: 11916358].
Makoto A, Shiro I, Keiichi F, et al. The safety of enalapril upward titration in chronic heart failure. Respir Circ. 2000;48(10):1061-6. Exclude: Not in English.
Malecka B, Zabek A, Lelakowski J. Shortening of paced QRS complex and clinical improvement following upgrading from apical right ventricular pacing to bifocal right ventricular or biventricular pacing in patients with permanent atrial fibrillation. Kardiol Pol. 2010;68(11):1234-41. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21108200].
Malecka B, Zabek A, Maziarz A, et al. Influence of heart failure etiology on the effect of upgrading from right ventricular apical to biventricular or bifocal pacing in patients with permanent atrial fibrillation and advanced heart failure. Pol Arch Med Wewn. 2012;122(3):89-97. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 22415222].
Malfatto G, Branzi G, Osculati G, et al. Improvement in left ventricular diastolic stiffness induced by physical training in patients with dilated cardiomyopathy. J Card Fail. May. 2009;15(4):327-33. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19398081].
Malfatto G, Branzi G, Giglio A, et al. Transthoracic bioimpedance and brain natriuretic peptide levels accurately indicate additional diastolic dysfunction in patients with chronic advanced systolic heart failure. Eur J Heart Fail. Sep. 2010;12(9):928-35. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20562427].
Malfatto G, Blengino S, Perego GB, et al. Transthoracic impedance accurately estimates pulmonary wedge pressure in patients with decompensated chronic heart failure. Congest Heart Fail. Jan. 2012;18(1):25-31. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 22277174].
Malik J, Tuka V, Krupickova Z, et al. Creation of dialysis vascular access with normal flow increases brain natriuretic peptide levels. Int Urol Nephrol. Dec. 2009;41(4):997-1002. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19238573].
Mallamaci F, Zoccali C, Tripepi G, et al. Diagnostic potential of cardiac natriuretic peptides in dialysis patients. Kidney Int. Apr. 2001;59(4):1559-66. Exclude: BNP measure not FDA approved. [pmid: 11260421].
Mallamaci F, Tripepi G, Cutrupi S, et al. Prognostic value of combined use of biomarkers of inflammation, endothelial dysfunction, and myocardiopathy in patients with ESRD. Kidney Int. Jun. 2005;67(6):2330-7. Exclude: BNP measure not FDA approved. [pmid: 15882276].
Mallamaci F, Cutrupi S, Pizzini P, et al. Urotensin II in end-stage renal disease: An inverse correlate of sympathetic function and cardiac natriuretic peptides. J Nephrol. Nov. 2005;18(6):727-32. Exclude: BNP measure not FDA approved. [pmid: 16358231].
Mallat Z, Heymes C, Corbaz A, et al. Evidence for altered interleukin 18 (IL)-18 pathway in human heart failure. FASEB J. 2004;18(14):1752-4. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 15371332].
Mallion J, Neuder Y, Ormezzano O, et al. Study of nycthemeral variations in blood pressure in patients with heart failure. Blood Press Monit. Jun. 2008;13(3):163-5. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18496294].
Malyszko J, Przybylowski P, Koc-Zorawska E, et al. Copeptin in relation to New York heart association class in heart transplant recipients and kidney transplant recipients. Transplant Proc. 2010;42(10):4259-62. Exclude: BNP measure not FDA approved. [pmid: 21168678].
Malyszko J, L I. Copeptin and its relation to arteriovenous fistula (AVF) type and NYHA class in hemodialysis patients. Ren Fail. 2011;33(10):929-34. Exclude: BNP measure not FDA approved. [pmid: 22013928].
Man JP, Sin DD, Ignaszewski A, et al. The complex relationship between ischemic heart disease and COPD exacerbations. Chest. 2012;141(4):837-8. Exclude: Not a primary study. [pmid: 22474142].
Manenti ER, Bodanese LC, Camey SA, et al. Prognostic value of serum biomarkers in association with TIMI risk score for acute coronary syndromes. Clin Cardiol. Sep. 2006;29(9):405-10. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17007172].
Mangge HA. N-terminal pro-B-type natriuretic peptide in early and advanced phases of obesity. Clin Chem Lab Med. 2011;49(9):1539-45. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21663466].
Manginas A, Tsiavou A, Sfyrakis P, et al. Increased number of circulating progenitor cells after implantation of ventricular assist devices. J Heart Lung Transplant. Jul. 2009;28(7):710-7. Exclude: BNP measure not FDA approved. [pmid: 19560700].
Manikandan R, Nathaniel C, Lewis P, et al. Troponin T and N-terminal pro-brain natriuretic peptide changes in patients undergoing transurethral resection of the prostate. J Urol. 2005;174(5):1892-5. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16217331].
Manios EG, Kallergis EM, Kanoupakis EM, et al. Amino-terminal pro-brain natriuretic peptide predicts ventricular arrhythmogenesis in patients with ischemic cardiomyopathy and implantable cardioverter-defibrillators. Chest. Oct. 2005;128(4):2604-10. Exclude: BNP measure not FDA approved. [pmid: 16236931].
Mano A, Nakatani T, Oda N, et al. Which factors predict the recovery of natural heart function after insertion of a left ventricular assist system?. J Heart Lung Transplant. Aug. 2008;27(8):869-74. Exclude: BNP measure not FDA approved. [pmid: 18656800].
Manola S, Pavlovic N, Radeljic V, et al. B-type natriuretic peptide as predictor of heart failure in patients with acute ST elevation myocardial infarction, single-vessel disease, and complete revascularization: Follow-up study. Croatian Med J. Oct. 2009;50(5):449-54. Exclude: BNP measure not FDA approved.
Manson WC, Bonz JW, Carmody K, et al. Identification of sonographic B-lines with linear transducer predicts elevated B-Type natriuretic peptide level. West J Emerg Med. Feb. 2011;12(1):102-6. Exclude: BNP measure not FDA approved. [pmid: 21691481].
Mansoor A, Althoff K, Gange S, et al. Elevated NT-pro-BNP levels are associated with comorbidities among HIV-infected women. AIDS Res Hum Retrovir. Oct. 2009;25(10):997-1004. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19803714].
Mant D, Hobbs FR, Glasziou P, et al. Identification and guided treatment of ventricular dysfunction in general practice using blood B-type natriuretic peptide. Br J Gen Pract. Jun. 2008;58(551):393-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18505615].
Manuchehri AM, Jayagopal V, Kilpatrick ES, et al. The effect of thyroid dysfunction on N-terminal pro-B-type natriuretic peptide concentrations. Ann Clin Biochem. May. 2006;43(Pt:3):3-8. Exclude: BNP measure not FDA approved. [pmid: 16390603].
Manzano-Fernandez S, Januzzi JL, Boronat-Garcia M, et al. Impact of kidney dysfunction on plasma and urinary N-terminal pro-B-type natriuretic peptide in patients with acute heart failure. Congest Heart Fail. 2010;16(5):214-20. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20887618].
Marantz PR, Kuwabara Y, Derby CA, et al. Plasma atrial natriuretic peptide factor is elevated in elderly patients with occult valvular insufficiency. Cardiol Elderly. Jun. 1993;1(3):195-201. Exclude: BNP measure not FDA approved.
Marci M, Pitrolo L, Lo PC, et al. Detection of early cardiac dysfunction in patients with beta thalassemia by tissue doppler echocardiography. Echocardiograph. 2011;28(2):175-80. Exclude: BNP measure not FDA approved.
Marcus GM, Gerber IL, McKeown BH, et al. Association between phonocardiographic third and fourth heart sounds and objective measures of left ventricular function. JAMA. May. 11. 2005;293(18):2238-44. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 15886379].
Marcus LS, Hart D, Packer M, et al. Hemodynamic and renal excretory effects of human brain natriuretic peptide infusion in patients with congestive heart failure. A double-blind, placebo-controlled, randomized crossover trial. Circ. Dec. 15. 1996;94(12):3184-9. Exclude: BNP measure not FDA approved.
Marechaux S, Hattabi. Clinical and echocardiographic correlates of plasma B-type natriuretic peptide levels in patients with aortic valve stenosis and normal left ventricular ejection fraction. Echocardiograph. 2011;28(7):695-702. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Margato R, Carvalho S, Ribeiro H, et al. Cardiac troponin I levels in acute pulmonary embolism. Rev Port Cardiol. Nov. 2009;28(11):1213-22. Exclude: BNP measure not FDA approved. [pmid: 20222345].
Margulies KB, Jaffer S, Pollack PS, et al. Physiological significance of early deceleration time prolongation in asymptomatic elderly subjects. J Card Fail. Jun. 1999;5(2):92-9. Exclude: BNP measure not FDA approved. [pmid: 10404348].
Maria SF, Gristina T, Brusca I, et al. Effect of physical training on exercise capacity, gas exchange and N-terminal pro-brain natriuretic peptide levels in patients with chronic heart failure. Eur J Cardiovasc Prev Rehabil. Oct. 2006;13(5):812-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17001223].
Mariano-Goulart D, Eberle MC, Boudousq V, et al. Major increase in brain natriuretic peptide indicates right ventricular systolic dysfunction in patients with heart failure. Eur J Heart Fail. Aug. 2003;5(4):481-8. Exclude: BNP measure not FDA approved. [pmid: 12921809].
Maric B, Kaan A, Araki Y, et al. The use of the Internet to remotely monitor patients with heart failure. Telemed J EHealth. Jan. 2010;16(1):26-33. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Marinho FC, Vargas FS, Fabri J Jr., et al. Clinical usefulness of B-type natriuretic peptide in the diagnosis of pleural effusions due to heart failure. Respirology. Apr. 2011;16(3):495-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21261781].
Mark PB, Stewart GA, Gansevoort RT, et al. Diagnostic potential of circulating natriuretic peptides in chronic kidney disease. Nephrol Dial Transplant. Feb. 2006;21(2):402-10. Exclude: BNP measure not FDA approved. [pmid: 16221702].
Maron BJ, Tholakanahalli VN, Zenovich AG, et al. Usefulness of B-type natriuretic peptide assay in the assessment of symptomatic state in hypertrophic cardiomyopathy. Circ. Mar. 2. 2004;109(8):984-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Marques DS, Canesin MF, Barutta JF, et al. Evaluation of asymptomatic patients with chronic Chagas disease through ambulatory electrocardiogram, echocardiogram and B-Type natriuretic peptide analyses. Arq Bras Cardiol. Sep. 2006;87(3):336-43. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17057935].
Martinez-Dolz L, Almenar L, Moro J, et al. Prognostic value of brain natriuretic peptide in heart transplant patients. J Heart Lung Transplant. Oct. 2007;26(10):986-91. Exclude: BNP measure not FDA approved. [pmid: 17919617].
Martinez-Dolz L, Almenar L, Hervas I, et al. Prognostic relationship between two serial determinations of B-type natriuretic peptide and medium-long-term events in heart transplantation. J Heart Lung Transplant. Jul. 2008;27(7):735-40. Exclude: BNP measure not FDA approved. [pmid: 18582802].
Martins E, Silva-Cardoso J, Silveira F, et al. Left ventricular function in adults with muscular dystrophies: Genotype-phenotype correlations. Rev Port Cardiol. Jan. 2005;24(1):23-35. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 15773664].
Martins E, Faria T, Silva-Cardoso J, et al. I-123-MIBG cardiac uptake imaging, in familial dilated cardiomyopathy. Rev Port Cardiol. Jan. 2009;28(1):29-36. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19388491].
Martischnig AM, Tichy A, Nikfardjam M, et al. Inhaled iloprost for patients with precapillary pulmonary hypertension and right-side heart failure. J Card Fail. Oct. 2011;17(10):813-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21962419].
Martos R, Baugh J, Ledwidge M, et al. Diagnosis of heart failure with preserved ejection fraction: Improved accuracy with the use of markers of collagen turnover. Eur J Heart Fail. Feb. 2009;11(2):191-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19168518].
Marz W, Tiran B, Seelhorst U, et al. N-terminal pro-B-type natriuretic peptide predicts total and cardiovascular mortality in individuals with or without stable coronary artery disease: The Ludwigshafen Risk and Cardiovascular Health Study. Clin Chem. Jun. 2007;53(6):1075-83. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17446333].
Masaki Y, Shimada K, Kojima T, et al. Clinical significance of the measurements of plasma N-terminal pro-B-type natriuretic peptide levels in patients with coronary artery disease who have undergone elective drug-eluting stent implantation. J Cardiol. May. 2011;57(3):303-10. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21388786].
Masson S, Gorini M, Salio M, et al. Clinical correlates of elevated plasma natriuretic peptides and Big endothelin-1 in a population of ambulatory patients with heart failure. A substudy of the Italian Network on Congestive Heart Failure (IN-CHF) registry. IN-CHF Investigators. Ital Heart J. Apr. 2000;1(4):282-8. Exclude: BNP measure not FDA approved. [pmid: 10824729].
Masson S, Vago T, Baldi G, et al. Comparative measurement of N-terminal pro-brain natriuretic peptide and brain natriuretic peptide in ambulatory patients with heart failure. Clin Chem Lab Med. Aug. 2002;40(8):761-3. Exclude: BNP measure not FDA approved. [pmid: 12392300].
Masson S, Latini R, Anand IS, et al. The prognostic value of big endothelin-1 in more than 2,300 patients with heart failure enrolled in the Valsartan Heart Failure Trial (Val-HeFT). J Card Fail. Jun. 2006;12(5):375-80. Exclude: BNP measure not FDA approved. [pmid: 16762801].
Masson S, Latini R, Carbonieri E, et al. The predictive value of stable precursor fragments of vasoactive peptides in patients with chronic heart failure: Data from the GISSI-heart failure (GISSI-HF) trial. Eur J Heart Fail. 2010;12(4):338-47. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20097683].
Masson S, Gori F, Latini R, et al. Adiponectin in chronic heart failure: Influence of diabetes and genetic variants. Eur J Clin Invest. Dec. 2011;41(12):1330-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21623778].
Masuda M, Morita S, Tomita H, et al. Off-pump CABG attenuates myocardial enzyme leakage but not postoperative brain natriuretic peptide secretion. Ann Thorac Cardiovasc Surg. Jun. 2002;8(3):139-44. Exclude: BNP measure not FDA approved. [pmid: 12472395].
Masugata H, Senda S, Inukai M, et al. Association of cardio-ankle vascular index with brain natriuretic peptide levels in hypertension. J Atherosclerosis Thromb. 2012;19(3):255-62. Exclude: BNP measure not FDA approved.
Masutani S, Taketazu M, Mihara C, et al. Usefulness of early diastolic mitral annular velocity to predict plasma levels of brain natriuretic peptide and transient heart failure development after device closure of atrial septal defect. Am J Cardiol. Dec. 15. 2009;104(12):1732-6. Exclude: BNP measure not FDA approved. [pmid: 19962485].
Masutani S, Senzaki H. Left ventricular function in adult patients with atrial septal defect: Implication for development of heart failure after transcatheter closure. J Card Fail. Nov. 2011;17(11):957-63. Exclude: Systematic review. [pmid: 22041334].
Masuyama T, Tsujino T, Origasa H, et al. Superiority of long-acting to short-acting loop diuretics in the treatment of congestive heart failure - The J-MELODIC study. Circ J. 2012;76(4):833-42. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 22451450].
Matayoshi T, Kato T, Nakahama H, et al. Brain natriuretic peptide in hemodialysis patients: Predictive value for hemodynamic change during hemodialysis and cardiac function. Am J Nephrol. 2008;28(1):122-7. Exclude: BNP measure not FDA approved. [pmid: 17943021].
Mathai SC, Bueso M, Hummers LK, et al. Disproportionate elevation of N-terminal pro-brain natriuretic peptide in scleroderma-related pulmonary hypertension. Eur Respir J. Jan. 2010;35(1):95-104. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19643943].
Matias PJ, Jorge C, Ferreira C, et al. Cholecalciferol supplementation in hemodialysis patients: Effects on mineral metabolism, inflammation, and cardiac dimension parameters. Clin J Am Soc Nephrol. May. 2010;5(5):905-11. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20203163].
Matsudaira K, Maeda K, Okumura N, et al. Impact of low levels of vascular endothelial growth factor after myocardial infarction on 6-month clinical outcome-results from the Nagoya acute myocardial infarction study. Circ J. 2012;76(6):1509-16. Exclude: BNP measure not FDA approved. [pmid: 22452999].
Matsui S, Ishii J, Kitagawa F, et al. Pentraxin 3 in unstable angina and non-ST-segment elevation myocardial infarction. Atherosclerosis. May. 2010;210(1):220-5. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19945702].
Matsui T, Tsutamoto T, Kinoshita M. Relationship between cardiac 123I-metaiodobenzylguanidine imaging and the transcardiac gradient of neurohumoral factors in patients with dilated cardiomyopathy. Jpn Circ J. Dec. 2001;65(12):1041-6. Exclude: BNP measure not FDA approved. [pmid: 11767995].
Matsui T, Tsutamoto T, Maeda K, et al. Prognostic value of repeated 123I-metaiodobenzylguanidine imaging in patients with dilated cardiomyopathy with congestive heart failure before and after optimized treatments--Comparison with neurohumoral factors. Circ J. Jun. 2002;66(6):537-43. Exclude: BNP measure not FDA approved. [pmid: 12074268].
Matsui Y, Eguchi K, Shibasaki S, et al. Effect of doxazosin on the left ventricular structure and function in morning hypertensive patients: the Japan Morning Surge 1 study. J Hypertens. Jul. 2008;26(7):1463-71. Exclude: BNP measure not FDA approved. [pmid: 18551024].
Matsumori A, Shimada T, Chapman NM, et al. Myocarditis and heart failure associated with hepatitis C virus infection. J Card Fail. May. 2006;12(4):293-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16679263].
Matsumoto A, Hirata Y, Momomura S, et al. Effects of exercise on plasma level of brain natriuretic peptide in congestive heart failure with and without left ventricular dysfunction. Am Heart J. Jan. 1995;129(1):139-45. Exclude: BNP measure not FDA approved. [pmid: 7817907].
Matsumoto M, Tsujino T, Naito Y, et al. Anemia as a factor that elevates plasma brain natriuretic peptide concentration in apparently healthy subjects. Int Heart J. Sep. 2008;49(5):577-86. Exclude: BNP measure not FDA approved. [pmid: 18971569].
Matsumoto M, Tsujino T, Lee-Kawabata M, et al. Serum interleukin-6 and C-reactive protein are markedly elevated in acute decompensated heart failure patients with left ventricular systolic dysfunction. Cytokine. Mar. 2010;49(3):264-8. Exclude: BNP measure not FDA approved. [pmid: 20005739].
Matsuo S, Nakamura Y, Kinoshita M, et al. Plasma B-type natriuretic peptide measurement in asymptomatic population. Int Med J. 2003;10(2):105-8. Exclude: BNP measure not FDA approved.
Matsuo S, Nakamura Y, Matsumoto T, et al. Prognostic value of iodine-123 metaiodobenzylguanidine imaging in patients with heart failure. Exp Clin Cardiol. 2003;8(2):95-8. Exclude: BNP measure not FDA approved. [pmid: 19641657].
Matsuo S, Nakae I, Tsutamoto T, et al. A novel clinical indicator using Tc-99m sestamibi for evaluating cardiac mitochondrial function in patients with cardiomyopathies. J Nucl Cardiol. 2007;14(2):215-20. Exclude: BNP measure not FDA approved. [pmid: 17386384].
Matsushita K, Ishikawa T, Sumita S, et al. Daily shock impedance measured by implantable cardioverter defibrillator is useful in the management of congestive heart failure. Circ J. Nov. 2006;70(11):1462-5. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17062972].
Maurer M, Burri S, de Marchi S, et al. Plasma homocysteine and cardiovascular risk in heart failure with and without cardiorenal syndrome. Int J Cardiol. May. 14. 2010;141(1):32-8. Exclude: BNP measure not FDA approved. [pmid: 19181408].
Maurer MS, Cuddihy P, Weisenberg J, et al. The prevalence and impact of anergia (lack of energy) in subjects with heart failure and its associations with actigraphy. J Card Fail. 2009;15(2):145-51. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19254674].
Mauro F, Rosso GL, Peano M, et al. Correlation between cognitive impairment and prognostic parameters in patients with congestive heart failure. Arch Med Res. Feb. 2007;38(2):234-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17227734].
Mavinkurve-Groothuis AMC, Groot-Loonen J, Marcus KA, et al. Myocardial strain and strain rate in monitoring subclinical heart failure in asymptomatic long-term survivors of childhood cancer. Ultrasound Med Biol. 2010;36(11):1783-91. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20870348].
May HT, Horne BD, Levy WC, et al. Validation of the Seattle Heart Failure Model in a community-based heart failure population and enhancement by adding B-type natriuretic peptide. Am J Cardiol. Aug. 15. 2007;100(4):697-700. Exclude: BNP measure not FDA approved. [pmid: 17697831].
May KA, Ky B. Defining the role of ST2: A multimarker approach?. J Card Fail. 2012;18(4):311-2. Exclude: Not a primary study. [pmid: 22464772].
Mayer J, Boldt J, Beschmann R, et al. Individualized intraoperative patient optimization using uncalibrated arterial pressure waveform analysis in high-risk patients undergoing major abdominal surgery. Crit Care. 2009;13(Suppl 1):P219. Exclude: BNP measure not FDA approved.
Mayer J, Simon J, Cech J, et al. Even mild changes in free thyroxine could influence the degree of heart failure measured by its biological surrogates. Physiol Res. 2008;57(4):525-9. Exclude: BNP measure not FDA approved. [pmid: 17705668].
Mayer J, Simon J, Plaskova M, et al. N-terminal pro B-type natriuretic peptide as prognostic marker for mortality in coronary patients without clinically manifest heart failure. Eur J Epidemiol. 2009;24(7):363-8. Exclude: BNP measure not FDA approved. [pmid: 19357972].
Mayer SA, de Lemos JA, Murphy SA, et al. Comparison of B-type natriuretic peptide levels in patients with heart failure with versus without mitral regurgitation. Am J Cardiol. Apr. 15. 2004;93(8):1002-6. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 15081443].
McClean DR, Ikram H, Garlick AH, et al. The clinical, cardiac, renal, arterial and neurohormonal effects of omapatrilat, a vasopeptidase inhibitor, in patients with chronic heart failure. J Am Coll Cardiol. Aug. 2000;36(2):479-86. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 10933361].
McClean DR, Ikram H, Mehta S, et al. Vasopeptidase inhibition with omapatrilat in chronic heart failure: Acute and long-term hemodynamic and neurohumoral effects. J Am Coll Cardiol. Jun. 2002;39(12):2034-41. Exclude: BNP measure not FDA approved. [pmid: 12084605].
McClure SJ, Caruana L, Davie AP, et al. Cohort study of plasma natriuretic peptides for identifying left ventricular systolic dysfunction in primary care. BMJ. 1998;317(7157):516-9. Exclude: BNP measure not FDA approved. [pmid: 9712601].
McClure SJ, Gall S, Schechter CB, et al. Percutaneous coronary revascularization reduces plasma N-terminal pro-B-type natriuretic peptide concentration in stable coronary artery disease. J Am Coll Cardiol. Jun. 26. 2007;49(25):2394-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17599601].
McCord J, Mundy BJ, Hudson MP, et al. Relationship between obesity and B-type natriuretic peptide levels. Arch Intern Med. Nov. 8. 2004;164(20):2247-52. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 15534162].
McCord J, Nowak RM, Jacobsen G, et al. B-type natriuretic peptide levels in patients in the emergency department with possible heart failure and previous stable angina pectoris and/or healed myocardial infarction. Am J Cardiol. Nov. 15. 2005;96(10):1370-3. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16275180].
McCrindle BW, Zak V, Sleeper LA, et al. Laboratory measures of exercise capacity and ventricular characteristics and function are weakly associated with functional health status after Fontan procedure. Circ. Jan. 5. 2010;121(1):34-42. Exclude: Population aged under 18.
McCullough PA, Duc P, Omland T, et al. B-type natriuretic peptide and renal function in the diagnosis of heart failure: An analysis from the Breathing Not Properly Multinational Study. Am J Kidney Dis. Mar. 2003;41(3):571-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 12612980].
McDonagh DL, Mathew JP, White WD, et al. Cognitive function after major noncardiac surgery, apolipoprotein E4 genotype, and biomarkers of brain injury. Anesthesiol. 2010;112(4):852-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
McDonagh TA, Robb SD, Murdoch DR, et al. Biochemical detection of left-ventricular systolic dysfunction. Lancet. Jan. 3. 1998;351(9095):9-13. Exclude: BNP measure not FDA approved. [pmid: 9433422].
McDonagh TA, Cunningham AD, Morrison CE, et al. Left ventricular dysfunction, natriuretic peptides, and mortality in an urban population. Heart. Jul. 2001;86(1):21-6. Exclude: BNP measure not FDA approved. [pmid: 11410555].
McDowell G, Coutie W, Shaw C, et al. The effect of the neutral endopeptidase inhibitor drug, candoxatril, on circulating levels of two of the most potent vasoactive peptides. Br J Clin Pharmacol. Mar. 1997;43(3):329-32. Exclude: BNP measure not FDA approved. [pmid: 9088591].
McEntegart MB, Awede B, Petrie MC, et al. Increase in serum adiponectin concentration in patients with heart failure and cachexia: Relationship with leptin, other cytokines, and B-type natriuretic peptide. Eur Heart J. Apr. 2007;28(7):829-35. Exclude: BNP measure not FDA approved. [pmid: 17403719].
McGeoch G, Lainchbury J, Town GI, et al. Plasma brain natriuretic peptide after long-term treatment for heart failure in general practice. Eur J Heart Fail. Aug. 2002;4(4):479-83. Exclude: BNP measure not FDA approved. [pmid: 12167387].
McGirt MJ, Blessing R, Nimjee SM, et al. Correlation of serum brain natriuretic peptide with hyponatremia and delayed ischemic neurological deficits after subarachnoid hemorrhage. Neurosurgery. Jun. 2004;54(6):1369-73. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 15157293].
McGoon MD, Miller DP. REVEAL: A contemporary US pulmonary arterial hypertension registry. Eur Respir Rev. 2012;21(123):8-18. Exclude: Population aged under 18. [pmid: 22379169].
McIlroy DR, Wallace S, Roubos N. Brain natriuretic peptide (BNP) as a biomarker of myocardial ischemia-reperfusion injury in cardiac transplantation. J Cardiothorac Vasc Anesth. 2010;24(6):939-45. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20655247].
McKelvie RS, Yusuf S, Pericak D, et al. Comparison of candesartan, enalapril, and their combination in congestive heart failure: Randomized evaluation of strategies for left ventricular dysfunction (RESOLVD) pilot study: The RESOLVD pilot study investigators. Circ. 1999;100(10):1056-64. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
McKelvie RS, Yusuf S, Pericak D. Comparison of candesartan, enalapril, and their combination in congestive heart failure: Randomized evaluation of strategies for left ventricular dysfunction (RESOLVD) pilot study. Prev Manag Cong Heart Fail. 1999;5(6):286-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
McKelvie RS, Komajda M, McMurray J, et al. Baseline plasma NT-proBNP and clinical characteristics: Results from the irbesartan in heart failure with preserved ejection fraction trial. J Card Fail. Feb. 2010;16(2):128-34. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20142024].
McKie PM, Rodeheffer RJ, Cataliotti A, et al. Amino-terminal pro-B-type natriuretic peptide and B-type natriuretic peptide: Biomarkers for mortality in a large community-based cohort free of heart failure. Hypertens. May. 2006;47(5):874-80. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
McKie PM, Cataliotti A, Lahr BD, et al. The prognostic value of N-terminal pro-B-type natriuretic peptide for death and cardiovascular events in healthy normal and stage A/B heart failure subjects. J Am Coll Cardiol. May. 11. 2010;55(19):2140-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20447539].
McKie PM, Cataliotti A, Sangaralingham SJ, et al. Predictive utility of atrial, N-terminal pro-atrial, and N-terminal pro-B-type natriuretic peptides for mortality and cardiovascular events in the general community: A 9-year follow-up study. Mayo Clin Proc. Dec. 2011;86(12):1154-60. Exclude: BNP measure not FDA approved. [pmid: 22134933].
McKie PM, Schirger JA, Costello-Boerrigter LC, et al. Impaired natriuretic and renal endocrine response to acute volume expansion in pre-clinical systolic and diastolic dysfunction. J Am Coll Cardiol. Nov. 8. 2011;58(20):2095-103. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 22051332].
McLaughlin VV, Benza RL, Rubin LJ, et al. Addition of inhaled treprostinil to oral therapy for pulmonary arterial hypertension: A randomized controlled clinical trial. J Am Coll Cardiol. May. 4. 2010;55(18):1915-22. Exclude: BNP measure not FDA approved. [pmid: 20430262].
McLean AS, Huang SJ, Nalos M, et al. The confounding effects of age, gender, serum creatinine, and electrolyte concentrations on plasma B-type natriuretic peptide concentrations in critically ill patients. Crit Care Med. Nov. 2003;31(11):2611-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 14605532].
McLean AS, Huang SJ, Nalos M, et al. Duration of the beneficial effects of levosimendan in decompensated heart failure as measured by echocardiographic indices and B-type natriuretic peptide. J Cardiovasc Pharmacol. Dec. 2005;46(6):830-5. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16306809].
McLean AS, Huang SJ, Hyams S, et al. Prognostic values of B-type natriuretic peptide in severe sepsis and septic shock. Crit Care Med. Apr. 2007;35(4):1019-26. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17334249].
McMurray JJ, Pitt B, Latini R, et al. Effects of the oral direct renin inhibitor aliskiren in patients with symptomatic heart failure. Circ Heart Fail. May. 2008;1(1):17-24. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19808266].
McMurray JJV, Teerlink JR, Cotter G, et al. Effects of tezosentan on symptoms and clinical outcomes in patients with acute heart failure: The VERITAS randomized controlled trials. JAMA. 2007;298(17):2009-19. Exclude: BNP measure not FDA approved. [pmid: 17986694].
McMurray JJV, Abraham WT, Dickstein K, et al. Aliskiren, ALTITUDE, and the implications for ATMOSPHERE. Eur J Heart Fail. 2012;14(4):341-3. Exclude: Not a primary study. [pmid: 22431404].
McNairy M, Gardetto N, Clopton P, et al. Stability of B-type natriuretic peptide levels during exercise in patients with congestive heart failure: Implications for outpatient monitoring with B-type natriuretic peptide. Am Heart J. Mar. 2002;143(3):406-11. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 11868044].
Meaudre E, Jego C, Kenane N, et al. B-type natriuretic peptide release and left ventricular filling pressure assessed by echocardiographic study after subarachnoid hemorrhage: A prospective study in non-cardiac patients. Crit Care. 2009;13(3):R76. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19454040].
Mebazaa A, Nieminen MS, Packer M, et al. Levosimendan vs dobutamine for patients with acute decompensated heart failure: The SURVIVE Randomized Trial. JAMA. May. 2. 2007;297(17):1883-91. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17473298].
Meco M, Cirri S, Gallazzi C, et al. Desflurane preconditioning in coronary artery bypass graft surgery: A double-blinded, randomised and placebo-controlled study. Eur J Cardiothorac Surg. 2007;32(2):319-25. Exclude: BNP measure not FDA approved. [pmid: 17574858].
Medina AM, Marteles MS, Saiz EB, et al. Prognostic utility of NT-proBNP in acute exacerbations of chronic pulmonary diseases. Eur J Intern Med. Apr. 2011;22(2):167-71. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21402247].
Mega JL, Morrow DA, de Lemos JA, et al. B-type natriuretic peptide at presentation and prognosis in patients with ST-segment elevation myocardial infarction: An ENTIRE-TIMI-23 substudy. J Am Coll Cardiol. Jul. 21. 2004;44(2):335-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 15261928].
Meglic U, Sorli J, Kosnik M, et al. Feasibility of transcutaneous electrical muscle stimulation in acute exacerbation of COPD. Wien Klin Wochenschr. Jun. 2011;123(11-12):384-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21607562].
Meguro T, Nagatomo Y, Nagae A, et al. Elevated arterial stiffness evaluated by brachial-ankle pulse wave velocity is deleterious for the prognosis of patients with heart failure. Circ J. 2009;73(4):673-80. Exclude: BNP measure not FDA approved. [pmid: 19246812].
Mehra MR, Uber PA, Park MH, et al. Corticosteroid weaning in the tacrolimus and mycophenolate era in heart transplantation: Clinical and neurohormonal benefits. Transplant Proc. Dec. 2004;36(10):3152-5. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 15686716].
Mehra MR, Uber PA, Walther D, et al. Gene expression profiles and B-type natriuretic peptide elevation in heart transplantation: More than a hemodynamic marker. Circ. Jul. 4. 2006;114(1:Suppl):I21-I26. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Mehta RH, Rogers JG, Hasselblad V, et al. Association of weight change with subsequent outcomes in patients hospitalized with acute decompensated heart failure. Am J Cardiol. 2009;103(1):76-81. Exclude: BNP measure not FDA approved. [pmid: 19101234].
Meinardi MT, van Veldhuisen DJ, Gietema JA, et al. Prospective evaluation of early cardiac damage induced by epirubicin-containing adjuvant chemotherapy and locoregional radiotherapy in breast cancer patients. J Clin Oncol. May. 15. 2001;19(10):2746-53. Exclude: BNP measure not FDA approved. [pmid: 11352968].
Mejhert M, Kahan T, Persson H, et al. Limited long term effects of a management programme for heart failure. Heart. 2004;90(9):1010-5. Exclude: BNP measure not FDA approved. [pmid: 15310688].
Mejhert M, Kahan T, Persson H, et al. Predicting readmissions and cardiovascular events in heart failure patients. Int J Cardiol. Apr. 28. 2006;109(1):108-13. Exclude: BNP measure not FDA approved. [pmid: 16213040].
Mekinian A, Lions C, Leleu X, et al. Prognosis assessment of cardiac involvement in systemic AL amyloidosis by magnetic resonance imaging. Am J Med. Sep. 2010;123(9):864-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20800158].
Mekontso-Dessap A, de Prost N, Girou E, et al. B-type natriuretic peptide and weaning from mechanical ventilation. Intensive Care Med. Oct. 2006;32(10):1529-36. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16941172].
Mekontso-Dessap A, Tual L, Kirsch M, et al. B-type natriuretic peptide to assess haemodynamic status after cardiac surgery. Br J Anaesth. Dec. 2006;97(6):777-82. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17046851].
Melander O, Newton-Cheh C, Almgren P, et al. Novel and conventional biomarkers for prediction of incident cardiovascular events in the community. JAMA. Jul. 1. 2009;302(1):49-57. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19567439].
Melanson SE, Laposata M, Camargo CA Jr., et al. Combination of D-dimer and amino-terminal pro-B-type natriuretic peptide testing for the evaluation of dyspneic patients with and without acute pulmonary embolism. Arch Pathol Lab Med. Sep. 2006;130(9):1326-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16948519].
Melenovsky V, Al Hiti H, Kazdova L, et al. Transpulmonary B-type natriuretic peptide uptake and cyclic guanosine monophosphate release in heart failure and pulmonary hypertension: The effects of sildenafil. J Am Coll Cardiol. Aug. 11. 2009;54(7):595-600. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19660688].
Melina G, Angeloni E, Benedetto U, et al. Relationship between prosthesis-patient mismatch and pro-brain natriuretic peptides after aortic valve replacement. J Heart Valve Dis. Mar. 2010;19(2):171-6. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20369499].
Melki D, Lind S, Agewall S, et al. Prognostic value of combining high sensitive troponin T and N-terminal pro B-type natriuretic peptide in chest pain patients with no persistent ST-elevation. Clin Chim Acta. 2012;413(9-10):933-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 22366164].
Meluzin JS. The role of exercise echocardiography in the diagnostics of heart failure with normal left ventricular ejection fraction. Eur J Echocardiogr. 2011;12(8):591-602. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21685198].
Menardi E, Vado A, Rossetti G, et al. Cardiac resynchronization therapy modifies the neurohormonal profile, hemodynamic and functional capacity in heart failure patients. Arch Med Res. Oct. 2008;39(7):702-8. Exclude: BNP measure not FDA approved. [pmid: 18760200].
Meng F, Yoshikawa T, Baba A, et al. Beta-blockers are effective in congestive heart failure patients with atrial fibrillation. J Card Fail. 2003;9(5):398-403. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 14583902].
Meno H, Inou T, Tanaka M, et al. Antihypertensive efficacy of the losartan/hydrochlorothiazide combination and its effect on plasma B-type natriuretic peptide in hypertensive patients uncontrolled by angiotensin II type 1 receptor antagonist-based therapy: A multicentre prospective observational study. Clin Drug Invest. Mar. 1. 2012;32(3):171-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Mercuro G, Cadeddu C, Piras A, et al. Early epirubicin-induced myocardial dysfunction revealed by serial tissue Doppler echocardiography: Correlation with inflammatory and oxidative stress markers. Oncologist. Sep. 2007;12(9):1124-33. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17914082].
Messer PB, Singh R, McAuley FT, et al. The use of N-terminal pro-B type natriuretic peptide in a pre-operative setting to predict left ventricular systolic dysfunction on echocardiogram. Anaesthesia. May. 2008;63(5):482-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18412645].
Meune C, Wahbi K, Fulla Y, et al. Effects of aspirin and clopidogrel on plasma brain natriuretic peptide in patients with heart failure receiving ACE inhibitors. Eur J Heart Fail. Feb. 2007;9(2):197-201. Exclude: BNP measure not FDA approved. [pmid: 16914369].
Meyer B, Huelsmann M, Wexberg P, et al. N-terminal pro-B-type natriuretic peptide is an independent predictor of outcome in an unselected cohort of critically ill patients. Crit Care Med. Oct. 2007;35(10):2268-73. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17717488].
Meyer T, Schwaab B, Gorge G, et al. Can serum NT-proBNP detect changes of functional capacity in patients with chronic heart failure?. Z Kardiol. Jul. 2004;93(7):540-5. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 15243765].
Michaels AD, Klein A, Madden JA, et al. Effects of intravenous nesiritide on human coronary vasomotor regulation and myocardial oxygen uptake. Circ. Jun. 3. 2003;107(21):2697-701. Exclude: BNP measure not FDA approved.
Michalopoulou H, Stamatis P, Bakhal A, et al. The calcium sensitizer levosimendan reduces the brain natriuretic peptide levels as compared with dobutamine in intensive care unit septic patients with decompensated heart failure. Crit Care. 2007;11(Suppl 2):P222. Exclude: BNP measure not FDA approved.
Michielsen EC, Bakker JA, Kimmenade RR, et al. The diagnostic value of serum and urinary NT-proBNP for heart failure. Ann Clin Biochem. Jul. 2008;45(Pt:4):4-94. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Miettinen KH, Magga J, Vuolteenaho O, et al. Utility of plasma apelin and other indices of cardiac dysfunction in the clinical assessment of patients with dilated cardiomyopathy. Regul Pept. May. 3. 2007;140(3):178-84. Exclude: BNP measure not FDA approved. [pmid: 17223209].
Miettinen KH, Lassus J, Harjola VP, et al. Prognostic role of pro- and anti-inflammatory cytokines and their polymorphisms in acute decompensated heart failure. Eur J Heart Fail. Apr. 2008;10(4):396-403. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18353715].
Mikkelsen KV, Bie P, Moller JE, et al. Diagnostic accuracy of plasma brain natriuretic peptide and aminoterminal-proBNP in mild heart failure depends on assay and introduction of therapy. Scand J Clin Lab Invest. 2005;65(8):633-47. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16319038].
Miller WL, Hartman KA, Burritt MF, et al. Serial biomarker measurements in ambulatory patients with chronic heart failure: The importance of change over time. Circ. Jul. 17. 2007;116(3):249-57. Exclude: BNP measure not FDA approved.
Miller WL, Hartman KA, Burritt MF, et al. Troponin, B-type natriuretic peptides and outcomes in severe heart failure: Differences between ischemic and dilated cardiomyopathies. Clin Cardiol. May. 2007;30(5):245-50. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17492679].
Miller WL, Jaffe AS. Serial biomarker measurements in chronic heart failure. Cardiol Rev. 2008;25(3):53-8. Exclude: BNP measure not FDA approved.
Miller WL, Hartman KA, Hodge DO, et al. Response of novel biomarkers to BNP infusion in patients with decompensated heart failure: A multimarker paradigm. J Cardiovasc Transl Res. Dec. 2009;2(4):526-35. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20560012].
Miller WL, Burnett JC Jr., Hartman KA, et al. Role for precursor Pro-B type natriuretic peptide in assessing response to therapy and prognosis in patients with decompensated heart failure treated with nesiritide. Clin Chim Acta. Aug. 2009;406(1-2):119-23. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19523938].
Miller WL, Hartman KA, Grill DE, et al. Only large reductions in concentrations of natriuretic peptides (BNP and NT-proBNP) are associated with improved outcome in ambulatory patients with chronic heart failure. Clin Chem. Jan. 2009;55(1):78-84. Exclude: BNP measure not FDA approved. [pmid: 19028821].
Miller WL, Phelps MA, Wood CM, et al. Comparison of mass spectrometry and clinical assay measurements of circulating fragments of B-type natriuretic peptide in patients with chronic heart failure. Circ. May. 1. 2011;4(3):355-60. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Miller WL, Grill DE, Jaffe AS. Comparison of novel pro-BNP1-108 and standard BNP assays in heart failure patients. Clin Chim Acta. 2012;413(9-10):920-6. Exclude: BNP measure not FDA approved. [pmid: 22366122].
Milliez P, Thomas O, Haggui A, et al. Cardiac resynchronisation as a rescue therapy in patients with catecholamine-dependent overt heart failure: Results from a short and mid-term study. Eur J Heart Fail. Mar. 2008;10(3):291-7. Exclude: BNP measure not FDA approved. [pmid: 18313982].
Mills RM, LeJemtel TH, Horton DP, et al. Sustained hemodynamic effects of an infusion of nesiritide (human b-type natriuretic peptide) in heart failure: A randomized, double-blind, placebo-controlled clinical trial. Natrecor Study Group. J Am Coll Cardiol. Jul. 1999;34(1):155-62. Exclude: BNP measure not FDA approved. [pmid: 10400005].
Milo-Cotter O, Teerlink JR, Metra M, et al. Low lymphocyte ratio as a novel prognostic factor in acute heart failure: Results from the Pre-RELAX-AHF study. Cardiol. 2010;117(3):190-6. Exclude: BNP measure not FDA approved.
Milo-Cotter O, C D. Neurohormonal activation in acute heart failure: Results from VERITAS. Cardiol. 2011;119(2):96-105. Exclude: BNP measure not FDA approved.
Milting H, EL Banayosy A, Kassner A, et al. The time course of natriuretic hormones as plasma markers of myocardial recovery in heart transplant candidates during ventricular assist device support reveals differences among device types. J Heart Lung Transplant. Sep. 2001;20(9):949-55. Exclude: BNP measure not FDA approved. [pmid: 11557189].
Milting H, Ellinghaus P, Seewald M, et al. Plasma biomarkers of myocardial fibrosis and remodeling in terminal heart failure patients supported by mechanical circulatory support devices. J Heart Lung Transplant. Jun. 2008;27(6):589-96. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18503956].
Missouris CG, Grouzmann E, Buckley MG, et al. How does treatment influence endocrine mechanisms in acute severe heart failure? Effects on cardiac natriuretic peptides, the renin system, neuropeptide Y and catecholamines. Clin Sci. Jun. 1998;94(6):591-9. Exclude: BNP measure not FDA approved. [pmid: 9854456].
Misumi I, Fujimoto K, Miyao Y, et al. Marked decrease in BNP levels in 2 related patients with reversible dilated cardiomyopathy. J Cardiol Cases. 2012;5(1):e65-e68. Exclude: BNP measure not FDA approved.
Mitaka C, Kudo T, Jibiki M, et al. Effects of human atrial natriuretic peptide on renal function in patients undergoing abdominal aortic aneurysm repair. Crit Care Med. Mar. 2008;36(3):745-51. Exclude: BNP measure not FDA approved. [pmid: 18431264].
Mitrovic V, Luss H, Nitsche K, et al. Effects of the renal natriuretic peptide urodilatin (ularitide) in patients with decompensated chronic heart failure: A double-blind, placebo-controlled, ascending-dose trial. Am Heart J. 2005;150(6):1239. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16338265].
Mitrovic V, Appel KF, Proskynitopoulos N, et al. Effects of candesartan cilexetil “add-on” treatment in congestive heart failure outpatients in daily practice. Clin Res Cardiol. Jun. 2009;98(6):379-89. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19294444].
Mitsuhashi H, Tamura K, Yamauchi J, et al. Effect of losartan on ambulatory short-term blood pressure variability and cardiovascular remodeling in hypertensive patients on hemodialysis. Atherosclerosis. Nov. 2009;207(1):186-90. Exclude: BNP measure not FDA approved. [pmid: 19423110].
Mitsuke Y, Lee JD, Shimizu H, et al. Nitric oxide synthase activity in peripheral polymorphonuclear leukocytes in patients with chronic congestive heart failure. Am J Cardiol. Jan. 15. 2001;87(2):183-7. Exclude: BNP measure not FDA approved. [pmid: 11152836].
Miura M, Shiba N, Nochioka K, et al. Urinary albumin excretion in heart failure with preserved ejection fraction: An interim analysis of the CHART 2 study. Eur J Heart Fail. 2012;14(4):367-76. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 22298637].
Miura Y, Fukumoto Y, Sugimura K, et al. Identification of new prognostic factors of pulmonary hypertension. Circ J. 2010;74(9):1965-71. Exclude: BNP measure not FDA approved. [pmid: 20631450].
Miyagawa S, Sawa Y, Fukushima N, et al. Analysis of sympathetic nerve activity in end-stage cardiomyopathy patients receiving left ventricular support. J Heart Lung Transplant. Nov. 2001;20(11):1181-7. Exclude: BNP measure not FDA approved. [pmid: 11704478].
Miyamoto S, Tambara K, Tamaki SI, et al. Effects of right lateral decubitus position on plasma norepinephrine and plasma atrial natriuretic peptide levels in patients with chronic congestive heart failure. Am J Cardiol. 2002;89(2):240-2. Exclude: BNP measure not FDA approved. [pmid: 11792354].
Miyata M, Kihara T, Kubozono T, et al. Beneficial effects of Waon therapy on patients with chronic heart failure: Results of a prospective multicenter study. J Cardiol. Oct. 2008;52(2):79-85. Exclude: BNP measure not FDA approved. [pmid: 18922381].
Miyata M, Sasaki T, Ikeda Y, et al. Comparative study of therapeutic effects of short- and long-acting loop diuretics in outpatients with chronic heart failure (COLD-CHF). J Cardiol. 2012;59(3):352-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 22365947].
Miyazaki A, Yamamoto M, Sakaguchi H, et al. Pulmonary valve replacement in adult patients with a severely dilated right ventricle and refractory arrhythmias after repair of tetralogy of fallot. Circ J. 2009;73(11):2135-42. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19755751].
Mizariene VG. Strain value in the assessment of left ventricular function and prediction of heart failure markers in aortic regurgitation. Echocardiograph. 2011;28(9):983-92. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Mizuno Y, Yasue H, Oshima S, et al. Effects of angiotensin-converting enzyme inhibitor on plasma B-type natriuretic peptide levels in patients with acute myocardial infarction. J Card Fail. Dec. 1997;3(4):287-93. Exclude: BNP measure not FDA approved. [pmid: 9547443].
Mizutani T, Inomata T, Watanabe I, et al. Comparison of nitrite compounds and carperitide for initial treatment of acute decompensated heart failure. Int Heart J. 2011;52(2):114-8. Exclude: BNP measure not FDA approved. [pmid: 21483172].
Moammar MQ, Ali MI, Mahmood NA, et al. Cardiac troponin I levels and alveolar-arterial oxygen gradient in patients with community-acquired pneumonia. Heart Lung Circ. 2010;19(2):90-2. Exclude: BNP measure not FDA approved. [pmid: 19914870].
Mocelin AO, Issa VS, Bacal F, et al. The influence of aetiology on inflammatory and neurohumoral activation in patients with severe heart failure: A prospective study comparing Chagas' heart disease and idiopathic dilated cardiomyopathy. Eur J Heart Fail. Aug. 2005;7(5):869-73. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16043406].
Mockel M, Muller R, Vollert JO, et al. Role of N-terminal pro-B-type natriuretic peptide in risk stratification in patients presenting in the emergency room. Clin Chem. Sep. 2005;51(9):1624-31. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16120947].
Mockel M, Muller R, Vollert JO, et al. Lipoprotein-associated phospholipase A2 for early risk stratification in patients with suspected acute coronary syndrome: A multi-marker approach: The North Wuerttemberg and Berlin Infarction Study-II (NOBIS-II). Clin Res Cardiol. Sep. 2007;96(9):604-12. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17593313].
Mockel M, Danne O, Muller R, et al. Development of an optimized multimarker strategy for early risk assessment of patients with acute coronary syndromes. Clin Chim Acta. Jul. 17. 2008;393(2):103-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18423399].
Modesti PA, Cecioni I, Costoli A, et al. Renal endothelin in heart failure and its relation to sodium excretion. Am Heart J. Oct. 2000;140(4):617-22. Exclude: BNP measure not FDA approved. [pmid: 11011335].
Moertl D, Berger R, Huelsmann M, et al. Short-term effects of levosimendan and prostaglandin E1 on hemodynamic parameters and B-type natriuretic peptide levels in patients with decompensated chronic heart failure. Eur J Heart Fail. Dec. 2005;7(7):1156-63. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16084762].
Moertl D, Berger R, Hammer A, et al. B-type natriuretic peptide predicts benefit from a home-based nurse care in chronic heart failure. J Card Fail. Apr. 2009;15(3):233-40. Exclude: BNP measure not FDA approved. [pmid: 19327625].
Moesgaard J, Kristensen JH, Malczynski J, et al. Can new pulmonary gas exchange parameters contribute to evaluation of pulmonary congestion in left-sided heart failure?. Can J Cardiol. Mar. 2009;25(3):149-55. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19279982].
Mogelvang R, Goetze JP, Schnohr P, et al. Discriminating between cardiac and pulmonary dysfunction in the general population with dyspnea by plasma pro-B-type natriuretic peptide. J Am Coll Cardiol. Oct. 23. 2007;50(17):1694-701. Exclude: BNP measure not FDA approved. [pmid: 17950153].
Mogelvang R, Goetze JP, Pedersen SA, et al. Preclinical systolic and diastolic dysfunction assessed by tissue Doppler imaging is associated with elevated plasma pro-B-type natriuretic peptide concentrations. J Card Fail. Aug. 2009;15(6):489-95. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19643359].
Mohyuddin T, Jacobs IB, Bahler RC. B-type natriuretic peptide and cardiac dysfunction in Duchenne muscular dystrophy. Int J Cardiol. Jul. 31. 2007;119(3):389-91. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17079036].
Mokart D, Sannini A, Brun JP, et al. N-terminal pro-brain natriuretic peptide as an early prognostic factor in cancer patients developing septic shock. Crit Care. 2007;11(2):R37. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17359530].
Monahan K, Zhou C, Rose J, et al. Determinants of changes in B-type natriuretic peptide levels in hospitalized patients. J Clin Basic Cardiol. 2006;9(1-4):31-6. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Monin JL, Lancellotti P, Monchi M, et al. Risk score for predicting outcome in patients with asymptomatic aortic stenosis. Circ. 2009;120(1):69-75. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Montagnana M, Lippi G, Regis D, et al. Evaluation of cardiac involvement following major orthopedic surgery. Clin Chem Lab Med. 2006;44(11):1340-6. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17087646].
Montagnana M, Lippi G, Fava C, et al. Ischemia-modified albumin and NT-prohormone-brain natriuretic peptide in peripheral arterial disease. Clin Chem Lab Med. 2006;44(2):207-12. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16475909].
Montagnana M, Lippi G, Salvagno GL, et al. Reference ranges and diagnostic thresholds of laboratory markers of cardiac damage and dysfunction in a population of apparently healthy black Africans. Clin Chem Lab Med. 2008;46(5):714-6. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18839473].
Moon J, Rim SJ, Cho IJ, et al. Left ventricular hypertrophy determines the severity of diastolic dysfunction in patients with nonvalvular atrial fibrillation and preserved left ventricular systolic function. Clin Exp Hypertens. 2010;32(8):540-6. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21091364].
Moon KT. Tai Chi improves quality of life in patients with chronic heart failure. Am Fam Phys. 2012;85(9):918. Exclude: Not a primary study.
Morales MA, Del Ry S, Startari U, et al. Plasma adrenomedullin relation with Doppler-derived dP/dt in patients with congestive heart failure. Clin Cardiol. Mar. 2006;29(3):126-30. Exclude: BNP measure not FDA approved. [pmid: 16596836].
Morales MA, Maltinti M, Piacenti M, et al. Adrenomedullin plasma levels predict left ventricular reverse remodeling after cardiac resynchronization therapy. Pacing Clin Electrophysiol. Jul. 2010;33(7):865-72. Exclude: BNP measure not FDA approved. [pmid: 20230463].
Moreira Md, Wang Y, Heringer-Walther S, et al. Prognostic value of natriuretic peptides in Chagas' disease: A head-to-head comparison of the 3 natriuretic peptides. Congest Heart Fail. 2009;15(2):75-81. Exclude: BNP measure not FDA approved. [pmid: 19379453].
Moreira MC, Heringer-Walther S, Wessel N, et al. Prognostic value of natriuretic peptides in Chagas' disease: A 3-year follow-up investigation. Cardiol. 2008;110(4):217-25. Exclude: BNP measure not FDA approved.
Morello A, Lloyd-Jones DM, Chae CU, et al. Association of atrial fibrillation and amino-terminal pro-brain natriuretic peptide concentrations in dyspneic subjects with and without acute heart failure: Results from the ProBNP Investigation of Dyspnea in the Emergency Department (PRIDE) study. Am Heart J. Jan. 2007;153(1):90-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17174644].
Morimoto K, Mori T, Ishiguro S, et al. Perioperative changes in plasma brain natriuretic peptide concentrations in patients undergoing cardiac surgery. Surg Today. 1998;28(1):23-9. Exclude: BNP measure not FDA approved. [pmid: 9505313].
Morimoto T, Hayashino Y, Shimbo T, et al. Is B-type natriuretic peptide-guided heart failure management cost-effective?. Int J Cardiol. Aug. 2004;96(2):177-81. Exclude: BNP measure not FDA approved. [pmid: 15262031].
Morita E, Yasue H, Yoshimura M, et al. Increased plasma levels of brain natriuretic peptide in patients with acute myocardial infarction. Circ. Jul. 1993;88(1):82-91. Exclude: BNP measure not FDA approved.
Moriyama Y, Yasue H, Yoshimura M, et al. The plasma levels of dehydroepiandrosterone sulfate are decreased in patients with chronic heart failure in proportion to the severity. J Clin Endocrinol Metab. May. 2000;85(5):1834-40. Exclude: BNP measure not FDA approved. [pmid: 10843161].
Mornos C, Rusinaru D, Ionac A, et al. Additive value of torsion to global longitudinal left ventricular strain in patients with reduced ejection fraction. Acta Cardiol. Oct. 2011;66(5):565-72. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 22032049].
Morrow DA, de Lemos JA, Sabatine MS, et al. Evaluation of B-type natriuretic peptide for risk assessment in unstable angina/non-ST-elevation myocardial infarction: B-type natriuretic peptide and prognosis in TACTICS-TIMI 18. J Am Coll Cardiol. Apr. 16. 2003;41(8):1264-72. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 12706919].
Morrow DA, de Lemos JA, Blazing MA, et al. Prognostic value of serial B-type natriuretic peptide testing during follow-up of patients with unstable coronary artery disease. JAMA. Dec. 14. 2005;294(22):2866-71. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16352794].
Morrow DA, Sabatine MS, Brennan ML, et al. Concurrent evaluation of novel cardiac biomarkers in acute coronary syndrome: Myeloperoxidase and soluble CD40 ligand and the risk of recurrent ischaemic events in TACTICS-TIMI 18. Eur Heart J. May. 2008;29(9):1096-102. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18339606].
Motoki N, Ohuchi H, Miyazaki A, et al. Clinical profiles of adult patients with single ventricular physiology. Circ J. Sep. 2009;73(9):1711-6. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19638711].
Mottram PM, Leano R, Marwick TH. Usefulness of B-type natriuretic peptide in hypertensive patients with exertional dyspnea and normal left ventricular ejection fraction and correlation with new echocardiographic indexes of systolic and diastolic function. Am J Cardiol. Dec. 15. 2003;92(12):1434-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 14675580].
Mottram PM, Haluska B, Leano R, et al. Effect of aldosterone antagonism on myocardial dysfunction in hypertensive patients with diastolic heart failure. Circ. 2004;110(5):558-65. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Mottram PM, Haluska BA, Marwick TH. Response of B-type natriuretic peptide to exercise in hypertensive patients with suspected diastolic heart failure: Correlation with cardiac function, hemodynamics, and workload. Am Heart J. Aug. 2004;148(2):365-70. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 15309010].
Mountantonakis SE, Grau-Sepulveda MV, Bhatt DL, et al. Presence of atrial fibrillation is independently associated with adverse outcomes in patients hospitalized with heart failure an analysis of get with the guidelines-heart failure. Circ Heart Fail. 2012;5(2):191-201. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 22361078].
Moyers B, Shapiro M, Marcus GM, et al. Performance of phonoelectrocardiographic left ventricular systolic time intervals and B-type natriuretic peptide levels in the diagnosis of left ventricular dysfunction. Ann Noninvasive Electrocardiol. Apr. 2007;12(2):89-97. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17593176].
Mozaffarian D, Minami E, Letterer RA, et al. The effects of Atorvastatin (10 mg) on systemic inflammation in heart failure. Am J Cardiol. 2005;96(12):1699-704. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16360360].
Mozid AMP. Audit of the NT-ProBNP guided transthoracic echocardiogram service in Southend. Br J Cardiol. 2011;18(4):189-92. Exclude: BNP measure not FDA approved.
Mueller C, Laule-Kilian K, Scholer A, et al. Use of B-type natriuretic peptide for the management of women with dyspnea. Am J Cardiol. Dec. 15. 2004;94(12):1510-4. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 15589006].
Mueller C, Scholer A, Laule-Kilian K, et al. Use of B-type natriuretic peptide in the evaluation and management of acute dyspnea. N Engl J Med. Feb. 12. 2004;350(7):647-54. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 14960741].
Mueller C, Laule-Kilian K, Scholer A, et al. B-type natriuretic peptide for acute dyspnea in patients with kidney disease: Insights from a randomized comparison. Kidney Int. Jan. 2005;67(1):278-84. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 15610252].
Mueller C, Laule-Kilian K, Staub D, et al. Natriuretic peptide and the management of acute dyspnea. Cardiol Rev. 2005;22(1):32-4. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Mueller C, Laule-Kilian K, Frana B, et al. The use of B-type natriuretic peptide in the management of elderly patients with acute dyspnoea. J Intern Med. Jul. 2005;258(1):77-85. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 15953135].
Mueller C, Laule-Kilian K, Schindler C, et al. Cost-effectiveness of B-type natriuretic peptide testing in patients with acute dyspnea. Arch Intern Med. May. 22. 2006;166(10):1081-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16717170].
Mueller C, Laule-Kilian K, Christ A, et al. The use of B-type natriuretic peptide in the management of patients with diabetes and acute dyspnoea. Diabetol. Apr. 2006;49(4):629-36. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Mueller C, Laule-Kilian K, Frana B, et al. Use of B-type natriuretic peptide in the management of acute dyspnea in patients with pulmonary disease. Am Heart J. Feb. 2006;151(2):471-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16442916].
Mueller T, Gegenhuber A, Poelz W, et al. Head-to-head comparison of the diagnostic utility of BNP and NT-proBNP in symptomatic and asymptomatic structural heart disease. Clin Chim Acta. Mar. 2004;341(1-2):41-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 14967157].
Mueller T, Gegenhuber A, Dieplinger B, et al. Capability of B-type natriuretic peptide (BNP) and amino-terminal proBNP as indicators of cardiac structural disease in asymptomatic patients with systemic arterial hypertension. Clin Chem. Dec. 2005;51(12):2245-51. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16223888].
Mueller T, Dieplinger B, Poelz W, et al. Amino-terminal pro-B-type natriuretic peptide as predictor of mortality in patients with symptomatic peripheral arterial disease: 5-year follow-up data from the Linz Peripheral Arterial Disease Study. Clin Chem. Jan. 2009;55(1):68-77. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18988753].
Mukoyama M, Nakao K, Saito Y, et al. Increased human brain natriuretic peptide in congestive heart failure. N Engl J Med. Sep. 13. 1990;323(11):757-8. Exclude: BNP measure not FDA approved. [pmid: 2143809].
Mukoyama M, Nakao K, Hosoda K, et al. Brain natriuretic peptide as a novel cardiac hormone in humans. Evidence for an exquisite dual natriuretic peptide system, atrial natriuretic peptide and brain natriuretic peptide. J Clin Invest. Apr. 1991;87(4):1402-12. Exclude: BNP measure not FDA approved. [pmid: 1849149].
Muller-Tasch T, Peters-Klimm F, Schellberg D, et al. Depression is a major determinant of quality of life in patients with chronic systolic heart failure in general practice. J Card Fail. Dec. 2007;13(10):818-24. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18068614].
Murdoch DR, Byrne J, Morton JJ, et al. Brain natriuretic peptide is stable in whole blood and can be measured using a simple rapid assay: Implications for clinical practice. Heart. Dec. 1997;78(6):594-7. Exclude: BNP measure not FDA approved. [pmid: 9470878].
Murdoch DR, McDonagh TA, Byrne J, et al. Titration of vasodilator therapy in chronic heart failure according to plasma brain natriuretic peptide concentration: Randomized comparison of the hemodynamic and neuroendocrine effects of tailored versus empirical therapy. Am Heart J. Dec. 1999;138(6 Pt 1):1126-32. Exclude: BNP measure not FDA approved. [pmid: 10577444].
Murphy JJ, Chakraborty RR, Fuat A, et al. Diagnosis and management of patients with heart failure in England. Clin Med. 2008;8(3):264-6. Exclude: BNP measure not FDA approved. [pmid: 18624031].
Murphy NF, O'Loughlin C, Ledwidge M, et al. Improvement but no cure of left ventricular systolic dysfunction in treated heart failure patients. Eur J Heart Fail. Dec. 2007;9(12):1196-204. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18039520].
Murray H, Cload B, Collier CP, et al. Potential impact of N-terminal pro-BNP testing on the emergency department evaluation of acute dyspnea. CJEM. Jul. 2006;8(4):251-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17324304].
Murray MD, Young JM, Morrow DG, et al. Methodology of an ongoing, randomized, controlled trial to improve drug use for elderly patients with chronic heart failure. Am J Geriatr Pharmacother. 2004;2(1):53-65. Exclude: Not a primary study. [pmid: 15555479].
Murtagh G, Canniffe C, Mahgoub M, et al. Introduction of an NT-proBNP assay to an acute admission unit--A 2-year audit. Eur J Intern Med. Jan. 2009;20(1):58-62. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19237094].
Muscari A, Berzigotti A, Bianchi G, et al. Non-cardiac determinants of NT-proBNP levels in the elderly: Relevance of haematocrit and hepatic steatosis. Eur J Heart Fail. Aug. 2006;8(5):468-76. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16386463].
Mutlu B, Bayrak F, Kahveci G, et al. Usefulness of N-terminal pro-B-type natriuretic peptide to predict clinical course in patients with hypertrophic cardiomyopathy. Am J Cardiol. Dec. 1. 2006;98(11):1504-6. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17126659].
Muzzarelli S, Tobler D, Leibundgut G, et al. Detection of intake of nonsteroidal anti-inflammatory drugs in elderly patients with heart failure. How to ask the patient?. Swiss Med Wkly. Aug. 22. 2009;139(33-34):481-5. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19705308].
Muzzarelli S, Maeder MT, Toggweiler S, et al. Frequency and predictors of hyperkalemia in patients >=60 years of age with heart failure undergoing intense medical therapy. Am J Cardiol. Mar. 1. 2012;109(5):693-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 22152974].
Naegeli B, Kurz DJ, Koller D, et al. Single-chamber ventricular pacing increases markers of left ventricular dysfunction compared with dual-chamber pacing. Europace. Mar. 2007;9(3):194-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17272326].
Naganuma T, Takemoto Y, Taiyou O, et al. Risk of cardiovascular disease in kidney donors as a chronic kidney disease cohort. Mol Med Rep. Jan. 2012;5(1):7-11. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21993905].
Nagao K, Hayashi N, Kanmatsuse K, et al. B-type natriuretic peptide as a marker of resuscitation in patients with cardiac arrest outside the hospital. Circ J. May. 2004;68(5):477-82. Exclude: BNP measure not FDA approved. [pmid: 15118292].
Nagatomo Y, Yoshikawa T, Kohno T, et al. A pilot study on the role of autoantibody targeting the beta1-adrenergic receptor in the response to beta-blocker therapy for congestive heart failure. J Card Fail. Apr. 2009;15(3):224-32. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19327624].
Nagatomo Y, Baba A, Ito H, et al. Specific immunoadsorption therapy using a tryptophan column in patients with refractory heart failure due to dilated cardiomyopathy. J Clin Apheresis. 2011;26(1):1-8. Exclude: BNP measure not FDA approved. [pmid: 21312253].
Nagaya N, Sasaki N, Ando M, et al. Prostacyclin therapy before pulmonary thromboendarterectomy in patients with chronic thromboembolic pulmonary hypertension. Chest. Feb. 2003;123(2):338-43. Exclude: BNP measure not FDA approved. [pmid: 12576349].
Nagayoshi Y, Kawano H, Hokamaki J, et al. Differences in oxidative stress markers based on the aetiology of heart failure: Comparison of oxidative stress in patients with and without coronary artery disease. Free Radic Res. Dec. 2009;43(12):1159-66. Exclude: BNP measure not FDA approved. [pmid: 19905978].
Nageh T, Chin D, Cooke JC, et al. Interpretation of plasma brain natriuretic peptide concentrations may require adjustment for patient's age. Ann Clin Biochem. Mar. 2002;39(Pt 2):151-3. Exclude: BNP measure not FDA approved. [pmid: 11928764].
Nagele H, Hashagen S, Azizi M, et al. Long-term hemodynamic benefit of biventricular pacing depending on coronary sinus lead position. Herzschrittmacherther Elecktrophysiol. Dec. 2006;17(4):185-90. Exclude: BNP measure not FDA approved.
Nagele H, Azizi M, Castel MA. Hemodynamic changes during cardiac resynchronization therapy. Clin Cardiol. Mar. 2007;30(3):141-3. Exclude: BNP measure not FDA approved. [pmid: 17385702].
Nagele H, Dodeck J, Behrens S, et al. Hemodynamics and prognosis after primary cardiac resynchronization system implantation compared to “upgrade” procedures. Pacing Clin Electrophysiol. 2008;31(10):1265-71. Exclude: BNP measure not FDA approved. [pmid: 18811806].
Nagy G, Gaszner B, Lanyi E, et al. Selective association of endogenous ouabain with subclinical organ damage in treated hypertensive patients. J Hum Hypertens. 2011;25(2):122-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20220772].
Naito J, Naka Y, Watanabe H. Clinical impression of brain natriuretic peptide levels in demented patients without cardiovascular disease. Geriatr Gerontol Int. Sep. 2009;9(3):242-5. Exclude: BNP measure not FDA approved. [pmid: 19702933].
Naito Y, Tsujino T, Lee-Kawabata M, et al. Matrix metalloproteinase-1 and -2 levels are differently regulated in acute exacerbation of heart failure in patients with and without left ventricular systolic dysfunction. Heart Ves. May. 2009;24(3):181-6. Exclude: BNP measure not FDA approved.
Najem B, Unger P, Preumont N, et al. Sympathetic control after cardiac resynchronization therapy: Responders versus nonresponders. Am J Physiol Heart Circ Physiol. 2006;291(6):H2647-52. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16844919].
Nakae I, Mitsunami K, Omura T, et al. Proton magnetic resonance spectroscopy can detect creatine depletion associated with the progression of heart failure in cardiomyopathy. J Am Coll Cardiol. Nov. 5. 2003;42(9):1587-93. Exclude: BNP measure not FDA approved. [pmid: 14607443].
Nakae I, Mitsunami K, Matsuo S, et al. Assessment of myocardial creatine concentration in dysfunctional human heart by proton magnetic resonance spectroscopy. Magn Reson Med Sci. Apr. 1. 2004;3(1):19-25. Exclude: BNP measure not FDA approved. [pmid: 16093616].
Nakae I, Matsuo S, Koh T, et al. Left ventricular systolic/diastolic function evaluated by quantitative ECG-gated SPECT: Comparison with echocardiography and plasma BNP analysis. Ann Nucl Med. Sep. 2005;19(6):447-54. Exclude: BNP measure not FDA approved. [pmid: 16248380].
Nakae I, Matsuo S, Koh T, et al. Clinical significance of plasma BNP measurement in patients with pychiatric disease. Int Med J. 2005;12(3):181-4. Exclude: BNP measure not FDA approved.
Nakae I, Matsuo S, Koh T, et al. Iodine-123 BMIPP scintigraphy in the evaluation of patients with heart failure. Acta Radiol. Oct. 2006;47(8):810-6. Exclude: BNP measure not FDA approved. [pmid: 17050361].
Nakagawa K, Umetani K, Fujioka D, et al. Correlation of plasma concentrations of B-type natriuretic peptide with infarct size quantified by tomographic thallium-201 myocardial scintigraphy in asymptomatic patients with previous myocardial infarction. Circ J. Oct. 2004;68(10):923-7. Exclude: BNP measure not FDA approved. [pmid: 15459465].
Nakajima K, Onishi K, Dohi K, et al. Effects of human atrial natriuretic peptide on cardiac function and hemodynamics in patients with high plasma BNP levels. Int J Cardiol. Oct. 10. 2005;104(3):332-7. Exclude: BNP measure not FDA approved. [pmid: 16186065].
Nakamura M, Niinuma H, Chiba M, et al. Effect of the maze procedure for atrial fibrillation on atrial and brain natriuretic peptide. Am J Cardiol. Apr. 1. 1997;79(7):966-70. Exclude: BNP measure not FDA approved. [pmid: 9104915].
Nakamura M, Arakawa N, Yoshida H, et al. Vasodilatory effects of B-type natriuretic peptide are impaired in patients with chronic heart failure. Am Heart J. Mar. 1998;135(3):414-20. Exclude: BNP measure not FDA approved. [pmid: 9506326].
Nakamura M, Endo H, Nasu M, et al. Value of plasma B type natriuretic peptide measurement for heart disease screening in a Japanese population. Heart. Feb. 2002;87(2):131-5. Exclude: BNP measure not FDA approved. [pmid: 11796549].
Nakamura M, Tanaka F, Yonezawa S, et al. The limited value of plasma B-type natriuretic peptide for screening for left ventricular hypertrophy among hypertensive patients. Am J Hypertens. Dec. 2003;16(12):1025-9. Exclude: BNP measure not FDA approved. [pmid: 14643576].
Nakamura M, Tanaka F, Sato K, et al. B-type natriuretic peptide testing for structural heart disease screening: A general population-based study. J Card Fail. Dec. 2005;11(9):705-12. Exclude: BNP measure not FDA approved. [pmid: 16360967].
Nakamura M, Sakai T, Osawa M, et al. Comparison of positive cases for B-type natriuretic peptide and ECG testing for identification of precursor forms of heart failure in an elderly population. Int Heart J. May. 2005;46(3):477-87. Exclude: BNP measure not FDA approved. [pmid: 16043943].
Nakamura M, Tanaka F, Onoda T, et al. Gender-specific risk stratification with plasma B-type natriuretic peptide for future onset of congestive heart failure and mortality in the Japanese general population. Int J Cardiol. Aug. 20. 2010;143(2):124-9. Exclude: BNP measure not FDA approved. [pmid: 19272660].
Nakamura M, Tanaka F, Takahashi T, et al. Sex-specific threshold levels of plasma B-type natriuretic peptide for prediction of cardiovascular event risk in a Japanese population initially free of cardiovascular disease. Am J Cardiol. Dec. 1. 2011;108(11):1564-9. Exclude: BNP measure not FDA approved. [pmid: 21871591].
Nakamura T, Funayama H, Kubo N, et al. Association of hyperadiponectinemia with severity of ventricular dysfunction in congestive heart failure. Circ J. Dec. 2006;70(12):1557-62. Exclude: BNP measure not FDA approved. [pmid: 17127799].
Nakamura T, Funayama H, Yoshimura A, et al. Possible vascular role of increased plasma arginine vasopressin in congestive heart failure. Int J Cardiol. Jan. 13. 2006;106(2):191-5. Exclude: BNP measure not FDA approved. [pmid: 16321691].
Nakamura T, Suzuki T, Kawagoe Y, et al. Polymyxin B-immobilized fiber hemoperfusion attenuates increased plasma atrial natriuretic peptide and brain natriuretic Peptide levels in patients with septic shock. ASAIO J. Mar. 2008;54(2):210-3. Exclude: BNP measure not FDA approved. [pmid: 18356658].
Nakamura T, Funayama H, Kubo N, et al. Elevation of plasma placental growth factor in the patients with ischemic cardiomyopathy. Int J Cardiol. Jan. 9. 2009;131(2):186-91. Exclude: BNP measure not FDA approved. [pmid: 18192038].
Nakane T, Kawai M, Komukai K, et al. Contribution of extracardiac factors to the inconsistency between plasma B-type natriuretic peptide levels and the severity of pulmonary congestion on chest X-rays in the diagnosis of heart failure. Intern Med. 2012;51(3):239-48. Exclude: BNP measure not FDA approved. [pmid: 22293797].
Nakano M, Kondo M, Wakayama Y, et al. Increased incidence of tachyarrhythmias and heart failure hospitalization in patients with implanted cardiac devices after the great East Japan Earthquake disaster. Circ J. 2012;76(5):1283-5. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 22498569].
Nakao K, Mukoyama M, Hosoda K, et al. Biosynthesis, secretion, and receptor selectivity of human brain natriuretic peptide. Can J Physiol Pharmacol. Oct. 1991;69(10):1500-6. Exclude: BNP measure not FDA approved. [pmid: 1723349].
Nakao S, Goda A, Yuba M, et al. Characterization of left ventricular filling abnormalities and its relation to elevated plasma brain natriuretic peptide level in acute to chronic diastolic heart failure. Circ J. Sep. 2007;71(9):1412-7. Exclude: BNP measure not FDA approved. [pmid: 17721020].
Nakashima T, Takasugi N, Kubota T, et al. ‘False-positive’ intrathoracic impedance monitor alarm caused by amiodarone-induced hypothyroidism in a patient with cardiac resynchronization therapy-defibrillator. Europace. 2012;14(5):768-9. Exclude: Case report. [pmid: 22158828].
Nakatani T, Naganuma T, Masuda C, et al. Significance of brain natriuretic peptides in patients on continuous ambulatory peritoneal dialysis. Int J Mol Med. Oct. 2002;10(4):457-61. Exclude: BNP measure not FDA approved. [pmid: 12239593].
Nakatsu T, Shinohata R, Mashima K, et al. Use of plasma B-type natriuretic peptide level to identify asymptomatic hypertensive patients with abnormal diurnal blood pressure variation profiles: Nondippers, extreme dippers, and risers. Hypertens Res. Jul. 2007;30(7):651-8. Exclude: BNP measure not FDA approved. [pmid: 17785934].
Nakatsuji H, Kishida K, Funahashi T, et al. Hyperinsulinemia correlates with low levels of plasma B-type natriuretic peptide in Japanese men irrespective of fat distribution. Cardiovasc Diabetol. 2012;11:22. Exclude: BNP measure not FDA approved. [pmid: 22397400].
Nakayama M, Nakano H, Nakayama M. Novel therapeutic option for refractory heart failure in elderly patients with chronic kidney disease by incremental peritoneal dialysis. J Cardiol. Jan. 2010;55(1):49-54. Exclude: BNP measure not FDA approved. [pmid: 20122548].
Nakayama T, Soma M, Mizutani Y, et al. A novel missense mutation of exon 3 in the type A human natriuretic peptide receptor gene: Possible association with essential hypertension. Hypertens Res. May. 2002;25(3):395-401. Exclude: BNP measure not FDA approved. [pmid: 12135318].
Namiki A, Kubota T, Fukazawa M, et al. Endothelin-1 concentrations in pericardial fluid are more elevated in patients with ischemic heart disease than in patients with nonischemic heart disease. Jpn Heart J. Sep. 2003;44(5):633-44. Exclude: BNP measure not FDA approved. [pmid: 14587645].
Nanjo S, Yamashiro Y, Fujimoto S, et al. Evaluation of sympathetic activity by 123I-metaiodobenzylguanidine myocardial scintigraphy in dilated cardiomyopathy patients with sleep breathing disorder. Circ J. Apr. 2009;73(4):686-90. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19261990].
Narain VS, Puri A, Gilhotra HS, et al. Third heart sound revisited: A correlation with N-terminal pro brain natriuretic peptide and echocardiography to detect left ventricular dysfunction. Indian Heart J. Jan. 2005;57(1):31-4. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 15852891].
Narain VS, Gupta N, Sethi R, et al. Clinical correlation of multiple biomarkers for risk assessment in patients with acute coronary syndrome. Indian Heart J. Nov. 2008;60(6):536-42. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19276492].
Naruse M, Takeyama Y, Tanabe A, et al. Atrial and brain natriuretic peptides in cardiovascular diseases. Hypertens. Jan. 1994;23(1 Suppl):I231-4. Exclude: BNP measure not FDA approved.
Naruszewicz M, Jankowska EA, Zymlinski R, et al. Hyperhomocysteinemia in patients with symptomatic chronic heart failure: Prevalence and prognostic importance--Pilot study. Atherosclerosis. Oct. 2007;194(2):408-14. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16970949].
Natali R, Lotrionte M, Marchese N, et al. Prediction of functional capacity by low-dose dobutamine stress echocardiography in chronic heart failure. Minerva Cardioangiol. Jun. 2008;56(3):277-85. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18509288].
Navarro Estrada JL, Rubinstein F, Bahit MC, et al. NT-probrain natriuretic peptide predicts complexity and severity of the coronary lesions in patients with non-ST-elevation acute coronary syndromes. Am Heart J. May. 2006;151(5):1093-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16644341].
Naya T, Yukiiri K, Hosomi N, et al. Brain natriuretic peptide as a surrogate marker for cardioembolic stroke with paroxysmal atrial fibrillation. Cerebrovasc Dis. 2008;26(4):434-40. Exclude: BNP measure not FDA approved. [pmid: 18799875].
Nazer BR. Prognostic utility of neopterin and risk of heart failure hospitalization after an acute coronary syndrome. Eur Heart J. 2011;32(11):1390-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21345849].
Nazeri A, Massumi A, Rasekh A, et al. Cardiac resynchronization therapy may improve symptoms of congestive heart failure in patients without electrical or mechanical dyssynchrony. Europace. Jan. 2009;11(1):86-8. Exclude: BNP measure not FDA approved. [pmid: 19056743].
Ndrepepa G, Kastrati A, Braun S, et al. N-terminal probrain natriuretic peptide and C-reactive protein in stable coronary heart disease. Am J Med. Apr. 2006;119(4):355-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16564781].
Ndrepepa G, Braun S, Mehilli J, et al. A prospective cohort study of prognostic power of N-terminal probrain natriuretic peptide in patients with non-ST segment elevation acute coronary syndromes. Clin Res Cardiol. 2007;96(1):30-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17066344].
Ndrepepa G, Braun S, Mehilli J, et al. Accuracy of N-terminal probrain natriuretic peptide to predict mortality or detect acute ischemia in patients with coronary artery disease. Cardiol. 2008;109(4):249-57. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Nearing BD, Wellenius GA, Mittleman MA, et al. Crescendo in depolarization and repolarization heterogeneity heralds development of ventricular tachycardia in hospitalized patients with decompensated heart failure. Circ. Feb. 1. 2012;5(1):84-90. Exclude: BNP measure not FDA approved.
Neilan TG, Januzzi JL, Lee-Lewandrowski E, et al. Myocardial injury and ventricular dysfunction related to training levels among nonelite participants in the Boston marathon. Circ. Nov. 28. 2006;114(22):2325-33. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Neizel M, Steen H, Korosoglou G, et al. Minor troponin T elevation in patients 6 months after acute myocardial infarction: An observational study. Clin Res Cardiol. May. 2009;98(5):297-304. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19280086].
Nellessen U, Zingel M, Hecker H, et al. Effects of radiation therapy on myocardial cell integrity and pump function: Which role for cardiac biomarkers?. Chemother. 2010;56(2):147-52. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Nelson CA, Case C, McCrohon J, et al. Relationship of extent and nature of dysfunctional myocardium to brain natriuretic peptide in patients with ischemic left ventricular dysfunction. Int J Cardiovasc Imaging. 2005;21(2-3):295-300. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16015444].
Nessler J, Nessler B, Stopyra K, et al. Cardiopulmonary stress test in patients with heart failure and atrial fibrillation. Kardiol Pol. 2004;61(Suppl 2):II76-81. Exclude: Not in English. [pmid: 20527422].
Nessler J, Nessler B, Kitlinski M, et al. Restrictive left ventricular filling pattern and its effect on the clinical course of systolic heart failure in patients receiving carvedilol. Cardiol J. 2008;15(4):329-37. Exclude: BNP measure not FDA approved. [pmid: 18698541].
Nessler J, Nessler B, Kitlinski M, et al. Concentration of BNP, endothelin 1, pro-inflammatory cytokines (TNF-alpha, IL-6) and exercise capacity in patients with heart failure treated with carvedilol. Kardiol Pol. 2008;66(2):144-51. Exclude: BNP measure not FDA approved. [pmid: 18344152].
Nessmith MG, Fukuta H, Brucks S, et al. Usefulness of an elevated B-type natriuretic peptide in predicting survival in patients with aortic stenosis treated without surgery. Am J Cardiol. Nov. 15. 2005;96(10):1445-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16275196].
Neumann T, Esser S, Potthoff A, et al. Prevalence and natural history of heart failure in outpatient HIV-infected subjects: Rationale and design of the HIV-HEART study. Eur J Med Res. Jun. 27. 2007;12(6):243-8. Exclude: BNP measure not FDA approved. [pmid: 17666313].
Neumann T, Aidonides G, Konorza T, et al. Neurohumoral response and clinical effectiveness of continuous aortic flow augmentation in patients with decompensated heart failure. J Artif Organs. 2009;12(3):166-71. Exclude: BNP measure not FDA approved. [pmid: 19894090].
Neumayr G, Pfister R, Mitterbauer G, et al. Effect of competitive marathon cycling on plasma N-terminal pro-brain natriuretic peptide and cardiac troponin T in healthy recreational cyclists. Am J Cardiol. Sep. 1. 2005;96(5):732-5. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16125505].
Neyou A, O'Neil B, Berman AD, et al. Determinants of markedly increased B-type natriuretic peptide in patients with ST-segment elevation myocardial infarction. Am J Emerg Med. 2011;29(2):141-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20825778].
Ng ACC, Davis GM, Chow CM, et al. Impact of sleep disordered breathing severity on hemodynamics, autonomic balance and cardiopulmonary functional status in chronic heart failure. Int J Cardiol. 2010;141(3):227-35. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19144429].
Ng LL, Loke I, O'Brien RJ, et al. Plasma urotensin in human systolic heart failure. Circ. Dec. 3. 2002;106(23):2877-80. Exclude: BNP measure not FDA approved.
Ng LL, Loke IW, O'Brien RJ, et al. Plasma urocortin in human systolic heart failure. Clin Sci. Apr. 2004;106(4):383-8. Exclude: BNP measure not FDA approved. [pmid: 14651473].
Ng LL, Geeranavar S, Jennings SC, et al. Diagnosis of heart failure using urinary natriuretic peptides. Clin Sci. Feb. 2004;106(2):129-33. Exclude: BNP measure not FDA approved. [pmid: 13678415].
Ng LL, Loke IW, Davies JE, et al. Community screening for left ventricular systolic dysfunction using plasma and urinary natriuretic peptides. J Am Coll Cardiol. Apr. 5. 2005;45(7):1043-50. Exclude: BNP measure not FDA approved. [pmid: 15808762].
Ng LL, Pathik B, Loke IW, et al. Myeloperoxidase and C-reactive protein augment the specificity of B-type natriuretic peptide in community screening for systolic heart failure. Am Heart J. Jul. 2006;152(1):94-101. Exclude: BNP measure not FDA approved. [pmid: 16824837].
Ng LL, O'Brien RJ, Quinn PA, et al. Oxygen-regulated protein 150 and prognosis following myocardial infarction. Clin Sci. Jul. 2007;112(9):477-84. Exclude: BNP measure not FDA approved. [pmid: 17176249].
Ng LL, Khan SQ, Narayan H, et al. Proteinase 3 and prognosis of patients with acute myocardial infarction. Clin Sci. Dec. 3. 2010;120(6):231-8. Exclude: BNP measure not FDA approved. [pmid: 20942801].
Nia AMG. Diagnostic accuracy of NT-proBNP ratio (BNP-R) for early diagnosis of tachycardia-mediated cardiomyopathy: A pilot study. Clin Res Cardiol. 2011;100(10):887-96. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21538234].
Nicholls MG, Lainchbury JG, Richards AM, et al. Brain natriuretic peptide-guided therapy for heart failure. Ann Med. Sep. 2001;33(6):422-7. Exclude: Not a primary study. [pmid: 11585103].
Nickel N, Kempf T, Tapken H, et al. Growth differentiation factor-15 in idiopathic pulmonary arterial hypertension. Am J Respir Crit Care Med. Sep. 1. 2008;178(5):534-41. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18565955].
Nickel N, Golpon H, Greer M, et al. The prognostic impact of follow-up assessments in patients with idiopathic pulmonary arterial hypertension. Eur Respir J. 2012;39(3):589-96. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21885392].
Nickel T, Vogeser M, Emslander I, et al. Extreme exercise enhances chromogranin A levels correlating with stress levels but not with cardiac burden. Atherosclerosis. Jan. 2012;220(1):219-22. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 22035982].
Nicolas-Robin A, Salvi N, Medimagh S, et al. Combined measurements of N-terminal pro-brain natriuretic peptide and cardiac troponins in potential organ donors. Intensive Care Med. 2007;33(6):986-92. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17393140].
Niedeggen A, Skobel E, Haager P, et al. Comparison of the 6-minute walk test with established parameters for assessment of cardiopulmonary capacity in adults with complex congenital cardiac disease. Cardiol Young. Aug. 2005;15(4):385-90. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16014186].
Niederkofler EE, Kiernan UA, O'Rear J, et al. Detection of endogenous B-type natriuretic peptide at very low concentrations in patients with heart failure. Circ Heart Fail. Nov. 2008;1(4):258-64. Exclude: BNP measure not FDA approved. [pmid: 19808300].
Nielsen OW, McDonagh TA, Robb SD, et al. Retrospective analysis of the cost-effectiveness of using plasma brain natriuretic peptide in screening for left ventricular systolic dysfunction in the general population. J Am Coll Cardiol. Jan. 1. 2003;41(1):113-20. Exclude: BNP measure not FDA approved. [pmid: 12570953].
Nielsen OW, Rasmussen V, Christensen NJ, et al. Neuroendocrine testing in community patients with heart disease: Plasma N-terminal proatrial natriuretic peptide predicts morbidity and mortality stronger than catecholamines and heart rate variability. Scand J Clin Lab Invest. 2004;64(7):619-28. Exclude: BNP measure not FDA approved. [pmid: 15513318].
Nielsen OW, Cowburn PJ, Sajadieh A, et al. Value of BNP to estimate cardiac risk in patients on cardioactive treatment in primary care. Eur J Heart Fail. Dec. 2007;9(12):1178-85. Exclude: BNP measure not FDA approved. [pmid: 18062902].
Niemann B, Chen Y, Teschner M, et al. Obesity induces signs of premature cardiac aging in younger patients: The role of mitochondria. J Am Coll Cardiol. 2011;57(5):577-85. Exclude: BNP measure not FDA approved. [pmid: 21272749].
Nieminen MS, Cleland JG, Eha J, et al. Oral levosimendan in patients with severe chronic heart failure --the PERSIST study. Eur J Heart Fail. Dec. 2008;10(12):1246-54. Exclude: BNP measure not FDA approved. [pmid: 18945637].
Niessner A, Hohensinner PJ, Rychli K, et al. Prognostic value of apoptosis markers in advanced heart failure patients. Eur Heart J. Apr. 2009;30(7):789-96. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19196721].
Niethammer M, Sieber M, von Haehling S, et al. Inflammatory pathways in patients with heart failure and preserved ejection fraction. Int J Cardiol. Sep. 16. 2008;129(1):111-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17658631].
Niizeki T, Takeishi Y, Arimoto T, et al. Combination of heart-type fatty acid binding protein and brain natriuretic peptide can reliably risk stratify patients hospitalized for chronic heart failure. Circ J. Aug. 2005;69(8):922-7. Exclude: BNP measure not FDA approved. [pmid: 16041160].
Niizeki T, Takeishi Y, Arimoto T, et al. Heart-type fatty acid-binding protein is more sensitive than troponin T to detect the ongoing myocardial damage in chronic heart failure patients. J Card Fail. Mar. 2007;13(2):120-7. Exclude: BNP measure not FDA approved. [pmid: 17395052].
Niizeki T, Takeishi Y, Kitahara T, et al. Combination of conventional biomarkers for risk stratification in chronic heart failure. J Cardiol. 2009;53(2):179-87. Exclude: BNP measure not FDA approved. [pmid: 19304120].
Niizuma S, Iwanaga Y, Yahata T, et al. Impact of left ventricular end-diastolic wall stress on plasma B-type natriuretic peptide in heart failure with chronic kidney disease and end-stage renal disease. Clin Chem. Jul. 2009;55(7):1347-53. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19460838].
Nikaido A, Tada T, Nakamura K, et al. Clinical features of and effects of angiotensin system antagonists on amiodarone-induced pulmonary toxicity. Int J Cardiol. 2010;140(3):328-35. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19106010].
Nikolaou NI, Kyriakides ZS, Tsaglis EP, et al. Early brain natriuretic peptide increase reflects acute myocardial ischemia in patients with ongoing chest pain. Int J Cardiol. May. 25. 2005;101(2):223-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 15882668].
Nilsson BB, Westheim A, Risberg MA, et al. No effect of group-based aerobic interval training on N-terminal pro-B-type natriuretic peptide levels in patients with chronic heart failure. Scand Cardiovasc J. Aug. 2010;44(4):223-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20636229].
Nilsson G, Hedberg P, Jonasson T, et al. QTc interval and survival in 75-year-old men and women from the general population. Europace. Apr. 2006;8(4):233-40. Exclude: BNP measure not FDA approved. [pmid: 16627447].
Nilsson K, Gustafson L, Hultberg B. Plasma homocysteine concentration and its relation to symptoms of vascular disease in psychogeriatric patients. Dement Geriatr Cognit Disord. 2005;20(1):35-41. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 15832034].
Nishi I, Noguchi T, Furuichi S, et al. Are cardiac events during exercise therapy for heart failure predictable from the baseline variables?. Circ J. 2007;71(7):1035-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17587707].
Nishi IN. Effects of exercise training in patients with chronic heart failure and advanced left ventricular systolic dysfunction receiving beta-blockers. Circ J. 2011;75(7):1649-55. Exclude: BNP measure not FDA approved. [pmid: 21613745].
Nishii M, Inomata T, Takehana H, et al. Prognostic utility of B-type natriuretic peptide assessment in stable low-risk outpatients with nonischemic cardiomyopathy after decompensated heart failure. J Am Coll Cardiol. Jun. 17. 2008;51(24):2329-35. Exclude: BNP measure not FDA approved. [pmid: 18549918].
Nishikimi T, Saito Y, Kitamura K, et al. Increased plasma levels of adrenomedullin in patients with heart failure. J Am Coll Cardiol. Nov. 15. 1995;26(6):1424-31. Exclude: BNP measure not FDA approved. [pmid: 7594065].
Nishikimi T, Minami J, Tamano K, et al. Left ventricular mass relates to average systolic blood pressure, but not loss of circadian blood pressure in stable hemodialysis patients: An ambulatory 48-hour blood pressure study. Hypertens Res. Sep. 2001;24(5):507-14. Exclude: BNP measure not FDA approved. [pmid: 11675944].
Nishikimi T, Karasawa T, Inaba C, et al. Effects of long-term intravenous administration of adrenomedullin (AM) plus hANP therapy in acute decompensated heart failure - A pilot study. Circ J. 2009;73(5):892-8. Exclude: BNP measure not FDA approved. [pmid: 19346663].
Nishikimi T, Minamino N, Ikeda M, et al. Diversity of molecular forms of plasma brain natriuretic peptide in heart failure--Different proBNP-108 to BNP-32 ratios in atrial and ventricular overload. Heart. Mar. 2010;96(6):432-9. Exclude: BNP measure not FDA approved. [pmid: 19966110].
Nishikimi T, Ikeda M, Takeda Y, et al. The effect of glycosylation on plasma N-terminal proBNP-76 levels in patients with heart or renal failure. Heart. Jan. 2012;98(2):152-61. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21719557].
Nishimura M, Hashimoto T, Kobayashi H, et al. Different remodelling against left ventricular overload between diabetic and non-diabetic haemodialysis patients. Clin Exp Pharmacol Physiol. Oct. 2003;30(10):786-92. Exclude: BNP measure not FDA approved. [pmid: 14516419].
Nishimura Y, Inoue T, Nitto T, et al. Increased interleukin-13 levels in patients with chronic heart failure. Int J Cardiol. Jan. 24. 2009;131(3):421-3. Exclude: BNP measure not FDA approved. [pmid: 18031842].
Nishino M, Kimura T, Kanda T, et al. Circulating interleukin-6 significantly correlates to thyroid hormone in acute myocardial infarction but not in chronic heart failure. J Endocrinol Invest. Sep. 2000;23(8):509-14. Exclude: BNP measure not FDA approved. [pmid: 11021766].
Nishio Y, Sato Y, Taniguchi R, et al. Cardiac troponin T vs other biochemical markers in patients with congestive heart failure. Circ J. May. 2007;71(5):631-5. Exclude: BNP measure not FDA approved. [pmid: 17456983].
Nishiyama K, Tsutamoto T, Tanaka T, et al. Plasma NT-proBNP as a more reliable biomarker of endogenous cardiac natriuretic peptides than BNP during carperitide infusion. Int Heart J. Mar. 2009;50(2):183-90. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19367029].
Nishiyama K, Tsutamoto T, Yamaji M, et al. Biological variation of brain natriuretic peptide and cardiac events in stable outpatients with nonischemic chronic heart failure. Circ J. 2011;75(2):341-7. Exclude: BNP measure not FDA approved. [pmid: 21178290].
Nishiyama KT. Relationship between biological variation in B-type natriuretic peptide and plasma renin concentration in stable outpatients with dilated cardiomyopathy. Circ J. 2011;75(8):1897-904. Exclude: BNP measure not FDA approved. [pmid: 21697610].
Nishiyama M, Park IS, Yoshikawa T, et al. Efficacy and safety of carvedilol for heart failure in children and patients with congenital heart disease. Heart Ves. May. 2009;24(3):187-92. Exclude: Population aged under 18.
Niwa N, Watanabe E, Hamaguchi M, et al. Early and late elevation of plasma atrial and brain natriuretic peptides in patients after bone marrow transplantation. Ann Hematol. Aug. 2001;80(8):460-5. Exclude: BNP measure not FDA approved. [pmid: 11563591].
Noda A, Izawa H, Asano H, et al. Beneficial effect of bilevel positive airway pressure on left ventricular function in ambulatory patients with idiopathic dilated cardiomyopathy and central sleep apnea-hypopnea: A preliminary study. Chest. Jun. 2007;131(6):1694-701. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17400681].
Node K, Fujita M, Kitakaze M, et al. Short-term statin therapy improves cardiac function and symptoms in patients with idiopathic dilated cardiomyopathy. Circ. 2003;108(7):839-43. Exclude: BNP measure not FDA approved.
Nonaka-Sarukawa M, Yamamoto K, Aoki H, et al. Increased urinary 15-F2t-isoprostane concentrations in patients with non-ischaemic congestive heart failure: A marker of oxidative stress. Heart. Aug. 2003;89(8):871-4. Exclude: BNP measure not FDA approved. [pmid: 12860861].
Nonaka-Sarukawa M, Yamamoto K, Aoki H, et al. Circulating endothelial progenitor cells in congestive heart failure. Int J Cardiol. Jul. 31. 2007;119(3):344-8. Exclude: BNP measure not FDA approved. [pmid: 17070610].
Norager B, Husic M, Moller JE, et al. Changes in the Doppler myocardial performance index during dobutamine echocardiography: Association with neurohormonal activation and prognosis after acute myocardial infarction. Heart. Aug. 2006;92(8):1071-6. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16387817].
Nordlinger M, Magnani B, Skinner M, et al. Is elevated plasma B-natriuretic peptide in amyloidosis simply a function of the presence of heart failure?. Am J Cardiol. Oct. 1. 2005;96(7):982-4. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16188528].
Norman JF, Pozehl BJ, Duncan KA, et al. Relationship of resting B-type natriuretic peptide level to cardiac work and total physical work capacity in heart failure patients. J Cardiopulm Rehabil Prev. Sep. 2009;29(5):310-3. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19561522].
Norozi K, Buchhorn R, Kaiser C, et al. Plasma N-terminal pro-brain natriuretic peptide as a marker of right ventricular dysfunction in patients with tetralogy of Fallot after surgical repair. Chest. Oct. 2005;128(4):2563-70. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16236924].
Norozi K, Buchhorn R, Alpers V, et al. Relation of systemic ventricular function quantified by myocardial performance index (Tei) to cardiopulmonary exercise capacity in adults after Mustard procedure for transposition of the great arteries. Am J Cardiol. Dec. 15. 2005;96(12):1721-5. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16360364].
Norozi K, Buchhorn R, Bartmus D, et al. Elevated brain natriuretic peptide and reduced exercise capacity in adult patients operated on for tetralogy of fallot is due to biventricular dysfunction as determined by the myocardial performance index. Am J Cardiol. May. 1. 2006;97(9):1377-82. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16635615].
Norozi K, Wessel A, Alpers V, et al. Incidence and risk distribution of heart failure in adolescents and adults with congenital heart disease after cardiac surgery. Am J Cardiol. Apr. 15. 2006;97(8):1238-43. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16616033].
Norozi K, Bahlmann J, Raab B, et al. A prospective, randomized, double-blind, placebo controlled trial of beta-blockade in patients who have undergone surgical correction of tetralogy of Fallot. Cardiol Young. Aug. 2007;17(4):372-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17572925].
Norozi K, Wessel A, Alpers V, et al. Chronotropic incompetence in adolescents and adults with congenital heart disease after cardiac surgery. J Card Fail. 2007;13(4):263-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17517345].
Norozi K, Wessel A, Buchhorn R, et al. Is the Ability index superior to the NYHA classification for assessing heart failure? Comparison of two classification scales in adolescents and adults with operated congenital heart defects. Clin Res Cardiol. Aug. 2007;96(8):542-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17593319].
Norozi K, Buchhorn R, Wessel A, et al. Beta-blockade does not alter plasma cytokine concentrations and ventricular function in young adults with right ventricular dysfunction secondary to operated congenital heart disease. Circ J. May. 2008;72(5):747-52. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18441454].
Norozi K, Buchhorn R, Yasin A, et al. Growth differentiation factor 15: An additional diagnostic tool for the risk stratification of developing heart failure in patients with operated congenital heart defects?. Am Heart J. Jul. 2011;162(1):131-5. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21742099].
Nothroff J, Norozi K, Alpers V, et al. Pacemaker implantation as a risk factor for heart failure in young adults with congenital heart disease. Pacing Clin Electrophysiol. Apr. 2006;29(4):386-92. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16650267].
Nousiainen T, Jantunen E, Vanninen E, et al. Natriuretic peptides as markers of cardiotoxicity during doxorubicin treatment for non-Hodgkin's lymphoma. Eur J Haematol. Feb. 1999;62(2):135-41. Exclude: BNP measure not FDA approved. [pmid: 10052718].
Noveanu M, Breidthardt T, Reichlin T, et al. Effect of oral beta-blocker on short and long-term mortality in patients with acute respiratory failure: Results from the BASEL-II-ICU study. Crit Care. 2010;14(6):R198. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21047406].
Noveanu M, Pargger H, Breidthardt T, et al. Use of B-type natriuretic peptide in the management of hypoxaemic respiratory failure. Eur J Heart Fail. 2011;13(2):154-62. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21036778].
Nowak A, Breidthardt T, Christ-Crain M, et al. Direct comparison of three natriuretic peptides for prediction of short- and long-term mortality in patients with community-acquired pneumonia. Chest. Apr. 2012;141(4):974-82. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 22135381].
Nozaki N, Yamaguchi S, Shirakabe M, et al. Soluble tumor necrosis factor receptors are elevated in relation to severity of congestive heart failure. Jpn Circ J. Aug. 1997;61(8):657-64. Exclude: BNP measure not FDA approved. [pmid: 9276770].
Nozaki T, Sugiyama S, Koga H, et al. Significance of a multiple biomarkers strategy including endothelial dysfunction to improve risk stratification for cardiovascular events in patients at high risk for coronary heart disease. J Am Coll Cardiol. Aug. 11. 2009;54(7):601-8. Exclude: BNP measure not FDA approved. [pmid: 19660689].
Nozohoor S, Nilsson J, Luhrs C, et al. B-type natriuretic peptide as a predictor of postoperative heart failure after aortic valve replacement. J Cardiothorac Vasc Anesth. Apr. 2009;23(2):161-5. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19167912].
Nozohoor S, Nilsson J, Algotsson L, et al. Postoperative increase in B-type natriuretic peptide levels predicts adverse outcome after cardiac surgery. J Cardiothorac Vasc Anesth. Jun. 2011;25(3):469-75. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20829070].
Nunes H, Uzunhan Y, Freynet O, et al. Pulmonary hypertension complicating sarcoidosis. Presse Med. 2012;41(6 PART 2):e303-e316. Exclude: Systematic review. [pmid: 22608948].
Nunez J, Gonzalez M, Minana G, et al. Continuous ambulatory peritoneal dialysis as a therapeutic alternative in patients with advanced congestive heart failure. Eur J Heart Fail. 2012;14(5):540-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 22327061].
Nuver J, Smit AJ, Sleijfer DT, et al. Left ventricular and cardiac autonomic function in survivors of testicular cancer. Eur J Clin Invest. 2005;35(2):99-103. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 15667580].
Nybo M, Benn M, Mogelvang R, et al. Impact of hemoglobin on plasma pro-B-type natriuretic peptide concentrations in the general population. Clin Chem. Nov. 2007;53(11):1921-7. Exclude: BNP measure not FDA approved. [pmid: 17872941].
Nybo M, Kristensen SR, Mickley H, et al. The influence of anaemia on stroke prognosis and its relation to N-terminal pro-brain natriuretic peptide. Eur J Neurol. May. 2007;14(5):477-82. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17437604].
Nymo SH, Ueland T, Askevold ET, et al. The association between neutrophil gelatinase-associated lipocalin and clinical outcome in chronic heart failure: Results from CORONA. J Intern Med. 2012;271(5):436-43. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 22211640].
O'Brien RJ, Squire IB, Demme B, et al. Pre-discharge, but not admission, levels of NT-proBNP predict adverse prognosis following acute LVF. Eur J Heart Fail. Aug. 2003;5(4):499-506. Exclude: BNP measure not FDA approved. [pmid: 12921811].
O'Brien TM, Menon S, Stephens T, et al. Algorithm-based assessment of target weight removal in acute decompensated heart failure. Congest Heart Fail. 2012;18(1):43-6. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 22277177].
O'Byrne MI, Rosenzweig ESB, Barst RJ. The effect of atrial septostomy on the concentration of brain-type natriuretic peptide in patients with idiopathic pulmonary arterial hypertension. Cardiol Young. 2007;17(5):557-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17868499].
O'Callaghan DS, Rich J, Thenappan T. From NT-proBNP as a survival parameter to left-sided heart failure, and more: 6 Months in pulmonary hypertension. Int J Clin Pract. 2007;61(Suppl 156):32-43. Exclude: Not a primary study. [pmid: 17229178].
O'Connor CM, Hasselblad V, Mehta RH, et al. Triage after hospitalization with advanced heart failure: The ESCAPE (Evaluation Study of Congestive Heart Failure and Pulmonary Artery Catheterization Effectiveness) risk model and discharge score. J Am Coll Cardiol. Mar. 2. 2010;55(9):872-8. Exclude: BNP measure not FDA approved. [pmid: 20185037].
O'Connor CM, Fiuzat M, Lindenfeld J, et al. Mode of death and hospitalization from the Second Follow-up Serial Infusions of Nesiritide (FUSION II) trial and comparison of clinical events committee adjudicated versus investigator reported outcomes. Am J Cardiol. Nov. 15. 2011;108(10):1449-57. Exclude: BNP measure not FDA approved. [pmid: 21890092].
O'Connor J, Meurer LN. B-type natriuretic peptide is an accurate predictor of heart failure in the emergency department. J Fam Pract. 2002;51(10):816. Exclude: Not a primary study. [pmid: 12401145].
O'Donoghue M, Chen A, Baggish AL, et al. The effects of ejection fraction on N-terminal ProBNP and BNP levels in patients with acute CHF: Analysis from the ProBNP Investigation of Dyspnea in the Emergency Department (PRIDE) study. J Card Fail. Jun. 2005;11(5 Suppl):S9-14. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 15948094].
O'Donoghue M, de Lemos JA, Morrow DA, et al. Prognostic utility of heart-type fatty acid binding protein in patients with acute coronary syndromes. Circ. Aug. 8. 2006;114(6):550-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
O'Neill JO, Bott-Silverman CE, McRae AT III, et al. B-type natriuretic peptide levels are not a surrogate marker for invasive hemodynamics during management of patients with severe heart failure. Am Heart J. Feb. 2005;149(2):363-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 15846278].
O'Neill JO, McRae AT III, Troughton RW, et al. Brain natriuretic peptide levels do not correlate with acute cellular rejection in De Novo orthotopic heart transplant recipients. J Heart Lung Transplant. Apr. 2005;24(4):416-20. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 15797742].
Obineche EN, Pathan JY, Fisher S, et al. Natriuretic peptide and adrenomedullin levels in chronic renal failure and effects of peritoneal dialysis. Kidney Int. Jan. 2006;69(1):152-6. Exclude: BNP measure not FDA approved. [pmid: 16374436].
Ochiai ME, Cardoso JN, Vieira KR, et al. Predictors of low cardiac output in decompensated severe heart failure. Clinics. 2011;66(2):239-44. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21484040].
Odar-Cederlof I, Bjellerup P, Williams A, et al. Daily dialyses decrease plasma levels of brain natriuretic peptide (BNP), a biomarker of left ventricular dysfunction. Hemodial Int. Oct. 2006;10(4):394-8. Exclude: BNP measure not FDA approved. [pmid: 17014518].
Oduncu V, Erkol A, Tanalp AC, et al. In-hospital prognostic value of admission plasma B-type natriuretic peptide levels in patients undergoing primary angioplasty for acute ST-elevation myocardial infarction. Turk Kardiyol Dern Ars. Oct. 2011;39(7):540-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21983763].
Ogawa S, Takeuchi K, Ito S. Plasma BNP levels in the treatment of type 2 diabetes with pioglitazone. J Clin Endocrinol Metab. Aug. 2003;88(8):3993-6. Exclude: BNP measure not FDA approved. [pmid: 12915698].
Ogawa S, Takeuchi K, Mori T, et al. Spironolactone further reduces urinary albumin excretion and plasma B-type natriuretic peptide levels in hypertensive type II diabetes treated with angiotensin-converting enzyme inhibitor. Clin Exp Pharmacol Physiol. May. 2006;33(5-6):477-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16700881].
Ogino K, Ogura K, Kinugasa Y, et al. Parathyroid hormone-related protein is produced in the myocardium and increased in patients with congestive heart failure. J Clin Endocrinol Metab. Oct. 2002;87(10):4722-7. Exclude: BNP measure not FDA approved. [pmid: 12364464].
Ogino K, Kato M, Furuse Y, et al. Uric acid-lowering treatment with benzbromarone in patients with heart failure a double-blind placebo-controlled crossover preliminary study. Circ. 2010;3(1):73-81. Exclude: BNP measure not FDA approved.
Oginosawa Y, Nogami A, Soejima K, et al. Effect of cardiac resynchronization therapy in isolated ventricular noncompaction in adults: Follow-up of four cases. J Cardiovasc Electrophysiol. 2008;19(9):935-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18399967].
Ohata T, Sakakibara T, Takano H, et al. Plasma brain natriuretic peptide reflects left ventricular function during percutaneous cardiopulmonary support. Ann Thorac Surg. Jan. 2004;77(1):164-7. Exclude: BNP measure not FDA approved. [pmid: 14726055].
Ohigashi H, Haraguchi G, Yoshikawa S, et al. Comparison of biomarkers for predicting disease severity and long-term respiratory prognosis in patients with acute pulmonary embolism. Int Heart J. 2010;51(6):416-20. Exclude: BNP measure not FDA approved. [pmid: 21173518].
Ohmae M. Endothelin-1 levels in chronic congestive heart failure. Wien Klin Wochenschr. Dec. 2011;123(23-24):714-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 22113444].
Ohsaka T, Inomata T, Naruke T, et al. Clinical impact of adherence to guidelines on the outcome of chronic heart failure in Japan. Int Heart J. Jan. 2008;49(1):59-73. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18360065].
Ohshima K, Hirashiki A, Cheng XW, et al. Impact of mild to moderate renal dysfunction on left ventricular relaxation function and prognosis in ambulatory patients with nonischemic dilated cardiomyopathy. Int Heart J. 2011;52(6):366-71. Exclude: BNP measure not FDA approved. [pmid: 22188710].
Ohtsuka T, Nishimura K, Kurata A, et al. Serum matrix metalloproteinase-3 as a novel marker for risk stratification of patients with nonischemic dilated cardiomyopathy. J Card Fail. Nov. 2007;13(9):752-8. Exclude: BNP measure not FDA approved. [pmid: 17996824].
Oie E, Ueland T, Dahl CP, et al. Fatty acid composition in chronic heart failure: Low circulating levels of eicosatetraenoic acid and high levels of vaccenic acid are associated with disease severity and mortality. J Intern Med. Sep. 2011;270(3):263-72. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21466599].
Oikawa O, Higuchi T, Yamazaki T, et al. Evaluation of serum fetuin-A relationships with biochemical parameters in patients on hemodialysis. Clin Exp Nephrol. Dec. 2007;11(4):304-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18085392].
Oka K, Tsujino T, Nakao S, et al. Symptomatic ventricular tachyarrhythmia is associated with delayed gadolinium enhancement in cardiac magnetic resonance imaging and with elevated plasma brain natriuretic peptide level in hypertrophic cardiomyopathy. J Cardiol. Oct. 2008;52(2):146-53. Exclude: BNP measure not FDA approved. [pmid: 18922389].
Okamoto S, Yamashita T, Ando Y, et al. Evaluation of myocardial changes in familial amyloid polyneuropathy after liver transplantation. Intern Med. 2008;47(24):2133-7. Exclude: BNP measure not FDA approved. [pmid: 19075538].
Okawa M, Kitaoka H, Matsumura Y, et al. Functional assessment by myocardial performance index (Tei index) correlates with plasma brain natriuretic peptide concentration in patients with hypertrophic cardiomyopathy. Circ J. Aug. 2005;69(8):951-7. Exclude: BNP measure not FDA approved. [pmid: 16041165].
Okkonen M, Varpula M, Linko R, et al. N-terminal-pro-BNP in critically ill patients with acute respiratory failure: A prospective cohort study. Acta Anaesthesiol Scand. Jul. 2011;55(6):749-57. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21480833].
Okumura H, Iuchi K, Yoshida T, et al. Brain natriuretic peptide is a predictor of anthracycline-induced cardiotoxicity. Acta Haematol. 2000;104(4):158-63. Exclude: BNP measure not FDA approved. [pmid: 11279304].
Okumura Y, Watanabe I, Ashino S, et al. Electrophysiological properties of the atrium after cardioversion of chronic atrial fibrillation: Relation to the plasma brain natriuretic peptide level. Int Heart J. Jul. 2007;48(4):485-96. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17827820].
Okumus G, Kiyan E, Bilge AK, et al. Can Brain Natriuretic Peptide (BNP) be a predictor for pulmonary arterial hypertension?. Turk Toraks Dergisi. 2011;12(4):134-8. Exclude: Not in English.
Okuyan E, Uslu A, Cakar MA, et al. Homocysteine levels in patients with heart failure with preserved ejection fraction. Cardiol. 2010;117(1):21-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Oldenburg O, Schmidt A, Lamp B, et al. Adaptive servoventilation improves cardiac function in patients with chronic heart failure and Cheyne-Stokes respiration. Eur J Heart Fail. Jun. 2008;10(6):581-6. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18486550].
Oldenburg O, Bitter T, Lehmann R, et al. Adaptive servoventilation improves cardiac function and respiratory stability. Clin Res Cardiol. Feb. 2011;100(2):107-15. Exclude: BNP measure not FDA approved. [pmid: 20835903].
Oldgren J, James SK, Siegbahn A, et al. Lipoprotein-associated phospholipase A2 does not predict mortality or new ischaemic events in acute coronary syndrome patients. Eur Heart J. 2007;28(6):699-704. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17314110].
Oliveira BM, Botoni FA, Ribeiro AL, et al. Correlation between BNP levels and Doppler echocardiographic parameters of left ventricle filling pressure in patients with Chagasic cardiomyopathy. Echocardiograph. May. 2009;26(5):521-7. Exclude: BNP measure not FDA approved.
Olivieri F, Galeazzi R, Giavarina D, et al. Aged-related increase of high sensitive Troponin T and its implication in acute myocardial infarction diagnosis of elderly patients. Mech Ageing Dev. 2012;133(5):300-5. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 22446505].
Olsen MH, Wachtell K, Tuxen C, et al. N-terminal pro-brain natriuretic peptide predicts cardiovascular events in patients with hypertension and left ventricular hypertrophy: A LIFE study. J Hypertens. Aug. 2004;22(8):1597-604. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 15257184].
Olsen MH, Hansen TW, Christensen MK, et al. N-terminal pro brain natriuretic peptide is inversely related to metabolic cardiovascular risk factors and the metabolic syndrome. Hypertens. Oct. 2005;46(4):660-6. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Olsen MH, Hansen TW, Christensen MK, et al. Cardiovascular risk prediction by N-terminal pro brain natriuretic peptide and high sensitivity C-reactive protein is affected by age and sex. J Hypertens. Jan. 2008;26(1):26-34. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18090537].
Olsen MH, Hansen TW, Christensen MK, et al. Impact of the metabolic syndrome on the predictive values of new risk markers in the general population. J Hum Hypertens. Sep. 2008;22(9):634-40. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18528412].
Olson TP, Frantz RP, Turner ST, et al. Gene variant of the bradykinin B2 receptor influences pulmonary arterial pressures in heart failure patients. Clin Med Circ Resp Pulm Med. 2009;2009(3):9-17. Exclude: BNP measure not FDA approved.
Omland T, Aakvaag A, Bonarjee VV, et al. Plasma brain natriuretic peptide as an indicator of left ventricular systolic function and long-term survival after acute myocardial infarction. Comparison with plasma atrial natriuretic peptide and N-terminal proatrial natriuretic peptide. Circ. Jun. 1. 1996;93(11):1963-9. Exclude: BNP measure not FDA approved.
Omland T, Aakvaag A, Vik-Mo H. Plasma cardiac natriuretic peptide determination as a screening test for the detection of patients with mild left ventricular impairment. Heart. 1996;76(3):232-7. Exclude: BNP measure not FDA approved. [pmid: 8868981].
Omland T, Persson A, Ng L, et al. N-terminal pro-B-type natriuretic peptide and long-term mortality in acute coronary syndromes. Circ. Dec. 3. 2002;106(23):2913-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Omland T, Richards AM, Wergeland R, et al. B-type natriuretic peptide and long-term survival in patients with stable coronary artery disease. Am J Cardiol. Jan. 1. 2005;95(1):24-8. Exclude: BNP measure not FDA approved. [pmid: 15619389].
Omland T, Sabatine MS, Jablonski KA, et al. Prognostic value of B-Type natriuretic peptides in patients with stable coronary artery disease: The PEACE Trial. J Am Coll Cardiol. Jul. 17. 2007;50(3):205-14. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17631211].
Omland T, Ueland T, Jansson AM, et al. Circulating osteoprotegerin levels and long-term prognosis in patients with acute coronary syndromes. J Am Coll Cardiol. Feb. 12. 2008;51(6):627-33. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18261681].
Ono M, Tanabe K, Asanuma T, et al. Doppler echocardiography-derived index of myocardial performance (TEI index): Comparison with brain natriuretic peptide levels in various heart disease. Jpn Circ J. Jul. 2001;65(7):637-42. Exclude: BNP measure not FDA approved. [pmid: 11446498].
Onodera H, Matsunaga T, Tamura Y, et al. Enalapril suppresses ventricular remodeling more effectively than losartan in patients with acute myocardial infarction. Am Heart J. 2005;150(4):689. Exclude: BNP measure not FDA approved. [pmid: 16209966].
Onoue Y, Izumiya Y, Takashio S, et al. Multidisciplinary mechanical supports improve outcome in a shock patient with cardiac amyloidosis: A case report. Intern Med. 2012;51(10):1215-9. Exclude: Case report. [pmid: 22687793].
Onuoha GN, Nugent AM, Hunter SJ, et al. Neuropeptide variability in man. Eur J Clin Invest. Jul. 2000;30(7):570-7. Exclude: BNP measure not FDA approved. [pmid: 10886296].
Oral I, Mistrik J, Naplava R. Clinical status and B-type natriuretic peptide levels in patients with heart failure at hospital discharge. Herz. Oct. 2007;32(7):583-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17972033].
Oravec RM, Bredemeier M, Laurino CC, et al. NT-proBNP levels in systemic sclerosis: Association with clinical and laboratory abnormalities. Clin Biochem. Jun. 2010;43(9):745-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20350538].
Oreopoulos A, Ezekowitz JA, McAlister FA, et al. Association between direct measures of body composition and prognostic factors in chronic heart failure. Mayo Clin Proc. Jul. 2010;85(7):609-17. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20592169].
Orn S, Manhenke C, Squire IB, et al. Plasma MMP-2, MMP-9 and N-BNP in long-term survivors following complicated myocardial infarction: Relation to cardiac magnetic resonance imaging measures of left ventricular structure and function. J Card Fail. Dec. 2007;13(10):843-9. Exclude: BNP measure not FDA approved. [pmid: 18068618].
Ortega O, Rodriguez I, Gracia C, et al. Strict volume control and longitudinal changes in cardiac biomarker levels in hemodialysis patients. Nephron. 2009;113(2):c96-103. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19602905].
Osajima A, Okazaki M, Tamura M, et al. Comparison of plasma levels of mature adrenomedullin and natriuretic peptide as markers of cardiac function in hemodialysis patients with coronary artery disease. Nephron. Dec. 2002;92(4):832-9. Exclude: BNP measure not FDA approved. [pmid: 12399629].
Oscarsson A, Fredrikson M, Sorliden M, et al. N-terminal fragment of pro-B-type natriuretic peptide is a predictor of cardiac events in high-risk patients undergoing acute hip fracture surgery. Br J Anaesth. Aug. 2009;103(2):206-12. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19525507].
Oscarsson A, Fredrikson M, Sorliden M, et al. Predictors of cardiac events in high-risk patients undergoing emergency surgery. Acta Anaesthesiol Scand. Sep. 2009;53(8):986-94. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19388892].
Otani H, Kagaya Y, Imahori Y, et al. Myocardial 11C-diacylglycerol accumulation and left ventricular remodeling in patients after myocardial infarction. J Nucl Med. 2005;46(4):553-9. Exclude: BNP measure not FDA approved. [pmid: 15809475].
Oterdoom LH, de Vries AP, van Ree RM, et al. N-terminal pro-B-type natriuretic peptide and mortality in renal transplant recipients versus the general population. Transplantation. May. 27. 2009;87(10):1562-70. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19461495].
Oudejans I, Mosterd A, Bloemen JA, et al. Clinical evaluation of geriatric outpatients with suspected heart failure: Value of symptoms, signs, and additional tests. Eur J Heart Fail. May. 2011;13(5):518-27. Exclude: BNP measure not FDA approved. [pmid: 21422000].
Oudejans I, Mosterd A, Zuithoff NPA, et al. Applicability of current diagnostic algorithms in geriatric patients suspected of new, slow onset heart failure. Age Ageing. 2012;41(3):309-16. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 22258114].
Owan TE, Chen HH, Frantz RP, et al. The effects of nesiritide on renal function and diuretic responsiveness in acutely decompensated heart failure patients with renal dysfunction. J Card Fail. May. 2008;14(4):267-75. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18474338].
Oyama R, Murata K, Tanaka N, et al. Is the ratio of transmitral peak E-wave velocity to color flow propagation velocity useful for evaluating the severity of heart failure in atrial fibrillation?. Circ J. Dec. 2004;68(12):1132-8. Exclude: BNP measure not FDA approved. [pmid: 15564696].
Ozkan M, Baysan O, Erinc K, et al. Brain natriuretic peptide and the severity of aortic regurgitation: Is there any correlation?. J Int Med Res. Jul. 2005;33(4):454-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16104449].
Ozkara A, Turgut F, Selcoki Y, et al. Probrain natriuretic peptide for assessment of efficacy in heart failure treatment. Adv Ther. Nov. 2007;24(6):1233-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18165205].
Ozmen B, Ozmen D, Parildar Z, et al. Serum N-terminal-pro-B-type natriuretic peptide (NT-pro-BNP) levels in hyperthyroidism and hypothyroidism. Endocr Res. 2006;32(1-2):1-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18271501].
Oztekin S, Karakurt O, Yazihan N, et al. Relationship of brain natriuretic peptide with metabolic syndrome parameters: An observational study. Anadolu Kardiyol Derg. Dec. 2011;11(8):678-84. Exclude: BNP measure not FDA approved. [pmid: 22037102].
Ozturk TC, Unluer E, Denizbasi A, et al. Can NT-proBNP be used as a criterion for heart failure hospitalization in emergency room?. J Res Med Sci. 2011;16(12):1564-71. Exclude: BNP measure not FDA approved. [pmid: 22973364].
Pach D, Gawlikowski T, Targosz D, et al. B-type natriuretic peptide plasma concentration in acutely poisoned patients. Przeglad Lekarski. 2005;62(6):465-7. Exclude: Not in English. [pmid: 16225096].
Padeletti L, Valleggi A, Vergaro G, et al. Concordant versus discordant left bundle branch block in heart failure patients: Novel clinical value of an old electrocardiographic diagnosis. J Card Fail. 2010;16(4):320-6. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20350699].
Padeletti M, Green P, Mooney AM, et al. Sleep disordered breathing in patients with acutely decompensated heart failure. Sleep Med. 2009;10(3):353-60. Exclude: BNP measure not FDA approved. [pmid: 18614398].
Padillo J, Rioja P, Munoz-Villanueva MC, et al. BNP as marker of heart dysfunction in patients with liver cirrhosis. Eur J Gastroenterol Hepatol. Nov. 2010;22(11):1331-6. Exclude: BNP measure not FDA approved. [pmid: 20729741].
Paelinck BP, Vrints CJ, Bax JJ, et al. Relation of B-type natriuretic peptide early after acute myocardial infarction to left ventricular diastolic function and extent of myocardial damage determined by magnetic resonance imaging. Am J Cardiol. Apr. 15. 2006;97(8):1146-50. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16616016].
Paget V, Legedz L, Gaudebout N, et al. N-terminal pro-brain natriuretic peptide: A powerful predictor of mortality in hypertension. Hypertens. Apr. 2011;57(4):702-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Palazzuoli A, Calabria P, Vecchiato L, et al. Plasma brain natriuretic peptide levels in coronary heart disease with preserved systolic function. Clin Exp Med. Sep. 2004;4(1):44-9. Exclude: BNP measure not FDA approved. [pmid: 15598085].
Palazzuoli A, Gennari L, Calabria P, et al. Relation of plasma brain natriuretic peptide levels in non-ST-elevation coronary disease and preserved systolic function to number of narrowed coronary arteries. Am J Cardiol. Dec. 15. 2005;96(12):1705-10. Exclude: BNP measure not FDA approved. [pmid: 16360361].
Palazzuoli A, Deckers J, Calabro A, et al. Brain natriuretic peptide and other risk markers for outcome assessment in patients with non-ST-elevation coronary syndromes and preserved systolic function. Am J Cardiol. Nov. 15. 2006;98(10):1322-8. Exclude: BNP measure not FDA approved. [pmid: 17134622].
Palazzuoli A, Silverberg D, Iovine F, et al. Erythropoietin improves anemia exercise tolerance and renal function and reduces B-type natriuretic peptide and hospitalization in patients with heart failure and anemia. Am Heart J. Dec. 2006;152(6):1096-15. Exclude: BNP measure not FDA approved. [pmid: 17161060].
Palazzuoli A, Silverberg DS, Iovine F, et al. Effects of beta-erythropoietin treatment on left ventricular remodeling, systolic function, and B-type natriuretic peptide levels in patients with the cardiorenal anemia syndrome. Am Heart J. Oct. 2007;154(4):645-15. Exclude: BNP measure not FDA approved. [pmid: 17892986].
Palazzuoli A, Silverberg DS, Calabro A, et al. Beta-erythropoietin effects on ventricular remodeling, left and right systolic function, pulmonary pressure, and hospitalizations in patients affected with heart failure and anemia. J Cardiovasc Pharmacol. Jun. 2009;53(6):462-7. Exclude: BNP measure not FDA approved. [pmid: 19455052].
Palazzuoli A, Quatrini I, Calabro A, et al. Anemia correction by erythropoietin reduces BNP levels, hospitalization rate, and NYHA class in patients with cardio-renal anemia syndrome. Clin Exp Med. Mar. 2011;11(1):43-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20512394].
Palladini G, Campana C, Klersy C, et al. Serum N-terminal pro-brain natriuretic peptide is a sensitive marker of myocardial dysfunction in AL amyloidosis. Circ. May. 20. 2003;107(19):2440-5. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Palladini G, Lavatelli F, Russo P, et al. Circulating amyloidogenic free light chains and serum N-terminal natriuretic peptide type B decrease simultaneously in association with improvement of survival in AL. Blood. May. 15. 2006;107(10):3854-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16434487].
Palladini G, Russo P, Bosoni T, et al. AL amyloidosis associated with IgM monoclonal protein: A distinct clinical entity. Clin Lymphoma Myeloma. Mar. 2009;9(1):80-3. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19362981].
Palladini G, Barassi A, Klersy C, et al. The combination of high-sensitivity cardiac troponin T (hs-cTnT) at presentation and changes in N-terminal natriuretic peptide type B (NT-proBNP) after chemotherapy best predicts survival in AL amyloidosis. Blood. Nov. 4. 2010;116(18):3426-30. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20644111].
Palladini G, Barassi A, Perlini S, et al. Midregional proadrenomedullin (MR-proADM) is a powerful predictor of early death in AL amyloidosis. Amyloid. Dec. 2011;18(4):216-21. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 22070520].
Palmer BR, Pilbrow AP, Yandle TG, et al. Angiotensin-converting enzyme gene polymorphism interacts with left ventricular ejection fraction and brain natriuretic peptide levels to predict mortality after myocardial infarction. J Am Coll Cardiol. Mar. 5. 2003;41(5):729-36. Exclude: BNP measure not FDA approved. [pmid: 12628714].
Palmer BR, Pilbrow AP, Frampton CM, et al. Plasma aldosterone levels during hospitalization are predictive of survival post-myocardial infarction. [Erratum appears in Eur Heart J. 2008 Dec;29(24):3068]. Eur Heart J. Oct. 2008;29(20):2489-96. Exclude: BNP measure not FDA approved. [pmid: 18757359].
Palmer SC, Yandle TG, Frampton CM, et al. Renal and cardiac function for long-term (10 year) risk stratification after myocardial infarction. Eur Heart J. Jun. 2009;30(12):1486-94. Exclude: BNP measure not FDA approved. [pmid: 19389787].
Palmer SC, Endre ZH, Richards AM, et al. Characterization of NT-proBNP in human urine. Clin Chem. Jun. 2009;55(6):1126-34. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19359532].
Palmer SC, Yandle TG, Nicholls MG, et al. Regional clearance of amino-terminal pro-brain natriuretic peptide from human plasma. Eur J Heart Fail. Sep. 2009;11(9):832-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19605456].
Pan W, Wang LF, Yu JH, et al. Intracoronary nitroprusside in the prevention of the no-reflow phenomenon in acute myocardial infarction. Chin Med J. Nov. 20. 2009;122(22):2718-23. Exclude: BNP measure not FDA approved. [pmid: 19951602].
Pan W, Su Y, Gong X, et al. Value of the paced QRS duration. J Card Fail. May. 2009;15(4):347-52. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19398084].
Pande S, Agarwal SK, Dhir U, et al. Pulmonary arterial hypertension in rheumatic mitral stenosis: does it affect right ventricular function and outcome after mitral valve replacement?. Interact Cardiovasc Thorac Surg. Sep. 2009;9(3):421-5. Exclude: BNP measure not FDA approved. [pmid: 19497952].
Pang PSM. Rationale, design, and results from RENO-DEFEND 1: A randomized, dose-finding study of the selective A1 adenosine antagonist SLV320 in patients hospitalized with acute heart failure. Am Heart J. 2011;161(6):1012-23. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21641345].
Paniagua R, Ventura MD, Avila-Diaz M, et al. NT-proBNP, fluid volume overload and dialysis modality are independent predictors of mortality in ESRD patients. Nephrol Dial Transplant. Feb. 2010;25(2):551-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19679559].
Panou FK, Kotseroglou VK, Lakoumentas JA, et al. Significance of brain natriuretic peptide in the evaluation of symptoms and the degree of left ventricular diastolic dysfunction in patients with hypertrophic cardiomyopathy. HJC Hell J Cardiol. Nov. 2006;47(6):344-51. Exclude: BNP measure not FDA approved.
Panteghini M, Cuccia C, Bonetti G, et al. Rapid determination of brain natriuretic peptide in patients with acute myocardial infarction. Clin Chem Lab Med. Feb. 2003;41(2):164-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 12667002].
Paparella D, Malvindi PG, Romito R, et al. BNP in mitral valve restrictive annuloplasty for ischemic mitral regurgitation. Int J Cardiol. Sep. 11. 2009;137(1):57-60. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18657328].
Papazisis KT, Kontovinis LF, Papandreou CN, et al. Brain natriuretic peptide precursor (NT-pro-BNP) levels predict for clinical benefit to sunitinib treatment in patients with metastatic renal cell carcinoma. BMC Canc. 2010;10:489. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Parab R, Vasudevan A, Brensilver J, et al. Utility of brain natriuritic peptide as a diagnostic tool for congestive heart failure in the elderly. Crit Pathways Cardiol. 2005;4(3):140-4. Exclude: BNP measure not FDA approved.
Paraskevaidis IA, Bistola V, Ikonomidis I, et al. Usefulness of dobutamine-induced changes of the two-dimensional longitudinal deformation predict clinical and neurohumoral improvement in men after levosimendan treatment in acutely decompensated chronic heart failure. Am J Cardiol. Nov. 1. 2008;102(9):1225-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18940297].
Paraskevaidis IA, Tsougos E, Varounis C, et al. Exercise-induced changes of B-type natriuretic peptide uncover the unknown coronary artery disease in patients with chest pain and normal left ventricular systolic function. Eur J Cardiovasc Prev Rehabil. Feb. 2011;18(1):72-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20485180].
Paraskevaidis IA, Ikonomidis I, Parissis J, et al. Dobutamine-induced changes of left atrial two-dimensional deformation predict clinical and neurohumoral improvement after levosimendan treatment in patients with acutely decompensated chronic heart failure. Int J Cardiol. 2012;157(1):31-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21176979].
Parenica J, Goldbergova MP, Kala P, et al. ACE gene insertion/deletion polymorphism has a mild influence on the acute development of left ventricular dysfunction in patients with ST elevation myocardial infarction treated with primary PCI. BMC Cardiovasc Disord. 2010;10. (Article Number: 60.):. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Parissis JT, Panou F, Farmakis D, et al. Effects of levosimendan on markers of left ventricular diastolic function and neurohormonal activation in patients with advanced heart failure. Am J Cardiol. Aug. 1. 2005;96(3):423-6. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16054474].
Parissis JT, Paraskevaidis I, Bistola V, et al. Effects of levosimendan on right ventricular function in patients with advanced heart failure. Am J Cardiol. 2006;98(11):1489-92. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17126656].
Parissis JT, Adamopoulos S, Farmakis D, et al. Effects of serial levosimendan infusions on left ventricular performance and plasma biomarkers of myocardial injury and neurohormonal and immune activation in patients with advanced heart failure. Heart. Dec. 2006;92(12):1768-72. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17105880].
Parissis JT, Andreadou I, Markantonis SL, et al. Effects of Levosimendan on circulating markers of oxidative and nitrosative stress in patients with advanced heart failure. Atherosclerosis. Dec. 2007;195(2):e210-5. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17707851].
Parissis JT, Papadopoulos C, Nikolaou M, et al. Effects of levosimendan on quality of life and emotional stress in advanced heart failure patients. Cardiovasc Drugs Ther. Aug. 2007;21(4):263-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17610056].
Parissis JT, Kourea K, Panou F, et al. Effects of darbepoetin alpha on right and left ventricular systolic and diastolic function in anemic patients with chronic heart failure secondary to ischemic or idiopathic dilated cardiomyopathy. Am Heart J. Apr. 2008;155(4):751-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18371487].
Parissis JT, Nikolaou M, Birmpa D, et al. Clinical and prognostic value of Duke's Activity Status Index along with plasma B-type natriuretic peptide levels in chronic heart failure secondary to ischemic or idiopathic dilated cardiomyopathy. Am J Cardiol. Jan. 1. 2009;103(1):73-5. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19101233].
Parissis JT, Kourea K, Andreadou I, et al. Effects of Darbepoetin Alfa on plasma mediators of oxidative and nitrosative stress in anemic patients with chronic heart failure secondary to ischemic or idiopathic dilated cardiomyopathy. Am J Cardiol. Apr. 15. 2009;103(8):1134-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19361602].
Parissis JT, Nikolaou M, Farmakis D, et al. Self-assessment of health status is associated with inflammatory activation and predicts long-term outcomes in chronic heart failure. Eur J Heart Fail. Feb. 2009;11(2):163-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19168514].
Park HH, Kim S, Choi J, et al. The application of B-type natriuretic peptide level of the dyspneic patients: Differentiation between cor pulmonale and left ventricular dysfunction. Tubercul Resp Dis. 2003;54(3):320-9. Exclude: Not in English.
Park HJ, Jung HO, Min J, et al. Left atrial volume index over late diastolic mitral annulus velocity (LAVi/A') is a useful echo index to identify advanced diastolic dysfunction and predict clinical outcomes. Clin Cardiol. 2011;34(2):124-30. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21298657].
Park MH, Scott RL, Uber PA, et al. Usefulness of B-type natriuretic peptide levels in predicting hemodynamic perturbations after heart transplantation despite preserved left ventricular systolic function. Am J Cardiol. Dec. 15. 2002;90(12):1326-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 12480042].
Park S, Cho GY, Kim SG, et al. Brain natriuretic peptide levels have diagnostic and prognostic capability for cardio-renal syndrome type 4 in intensive care unit patients. Crit Care. 2009;13(3):R70. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19445682].
Park SJ, Cho KI, Jung SJ, et al. N-terminal pro-B-type natriuretic peptide in overweight and obese patients with and without diabetes: An analysis based on body mass index and left ventricular geometry. Korean Circ J. 2009;39(12):538-44. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20049140].
Parle NM, Thomas MD, Dembo L, et al. Repeated infusions of levosimendan: well tolerated and improves functional capacity in decompensated heart failure - A single-centre experience. Heart Lung Circ. Jun. 2008;17(3):206-10. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18242130].
Parrinello G, Di Pasquale P, Licata G, et al. Long-term effects of dietary sodium intake on cytokines and neurohormonal activation in patients with recently compensated congestive heart failure. J Card Fail. 2009;15(10):864-73. Exclude: BNP measure not FDA approved. [pmid: 19944363].
Parrinello G, Torres D, Paterna S, et al. Wet BNP, fluid and hemodynamic status at discharge in acute heart failure. Int J Cardiol. 2010;145(2):335-6. Exclude: Not a primary study. [pmid: 20045208].
Parrinello G, Torres D, Paterna S, et al. Short-term walking physical training and changes in body hydration status, B-type natriuretic peptide and C-reactive protein levels in compensated congestive heart failure. Int J Cardiol. 2010;144(1):97-100. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19176263].
Parrinello G, Paterna S, Di PP, et al. Changes in estimating echocardiography pulmonary capillary wedge pressure after hypersaline plus furosemide versus furosemide alone in decompensated heart failure. J Card Fail. Apr. 2011;17(4):331-9. Exclude: BNP measure not FDA approved. [pmid: 21440872].
Parsonage WA, Galbraith AJ, Koerbin GL, et al. Value of B-type natriuretic peptide for identifying significantly elevated pulmonary artery wedge pressure in patients treated for established chronic heart failure secondary to ischemic or idiopathic dilated cardiomyopathy. Am J Cardiol. Apr. 1. 2005;95(7):883-5. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 15781024].
Parthenakis FI, Patrianakos AP, Skalidis EI, et al. Atrial fibrillation is associated with increased neurohumoral activation and reduced exercise tolerance in patients with non-ischemic dilated cardiomyopathy. Int J Cardiol. 2007;118(2):206-14. Exclude: BNP measure not FDA approved. [pmid: 17027102].
Parthenakis FI, Patrianakos AP, Haritakis CN, et al. NT-proBNP response to dobutamine stress echocardiography predicts left ventricular contractile reserve in dilated cardiomyopathy. Eur J Heart Fail. May. 2008;10(5):475-81. Exclude: BNP measure not FDA approved. [pmid: 18396456].
Pascu AM, Radoi M, Coculescu M. Plasma brain natriuretic peptide (BNP) increase is associated with acute right ventricular dysfunction in pulmonary embolism. Rom J Endocrinol. 2005;1(4):393-410. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Pascual-Figal DA, Penafiel P, de la MG, et al. Relation of B-type natriuretic peptide levels before and after exercise and functional capacity in patients with idiopathic dilated cardiomyopathy. Am J Cardiol. May. 1. 2007;99(9):1279-83. Exclude: BNP measure not FDA approved. [pmid: 17478157].
Pascual-Figal DA, Penafiel P, Nicolas F, et al. Prognostic value of BNP and cardiopulmonary exercise testing in patients with systolic heart failure on beta-blocker therapy. Rev Esp Cardiol. 2008;61(3):260-8. Exclude: BNP measure not FDA approved. [pmid: 18361899].
Pascual-Figal DA, Ordonez-Llanos J, Tornel PL, et al. Soluble ST2 for predicting sudden cardiac death in patients with chronic heart failure and left ventricular systolic dysfunction. J Am Coll Cardiol. Dec. 1. 2009;54(23):2174-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19942089].
Pascual-Figal DA, Garrido IP, Blanco R, et al. Soluble ST2 is a marker for acute cardiac allograft rejection. Ann Thorac Surg. Dec. 2011;92(6):2118-24. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 22035779].
Pascual Figal DA, de lM V, Nicolas RF, et al. Addition of an angiotensin II receptor blocker to maximal dose of ACE inhibitors in heart failure. Rev Esp Cardiol. 2002;55(8):862-6. Exclude: BNP measure not FDA approved. [pmid: 12199983].
Passino C, Maria SA, Favilli B, et al. Right heart overload contributes to cardiac natriuretic hormone elevation in patients with heart failure. Int J Cardiol. Sep. 15. 2005;104(1):39-45. Exclude: BNP measure not FDA approved. [pmid: 16137508].
Passino C, Poletti R, Bramanti F, et al. Neuro-hormonal activation predicts ventilatory response to exercise and functional capacity in patients with heart failure. Eur J Heart Fail. Jan. 2006;8(1):46-53. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16112902].
Passino C, Severino S, Poletti R, et al. Aerobic training decreases B-type natriuretic peptide expression and adrenergic activation in patients with heart failure. J Am Coll Cardiol. May. 2. 2006;47(9):1835-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16682309].
Passino C, Del Ry S, Severino S, et al. C-type natriuretic peptide expression in patients with chronic heart failure: Effects of aerobic training. Eur J Cardiovasc Prev Rehabil. Apr. 2008;15(2):168-72. Exclude: BNP measure not FDA approved. [pmid: 18391643].
Passino C, Pingitore A, Landi P, et al. Prognostic value of combined measurement of brain natriuretic peptide and triiodothyronine in heart failure. J Card Fail. Feb. 2009;15(1):35-40. Exclude: BNP measure not FDA approved. [pmid: 19181292].
Patel JV, Sosin M, Lim HS, et al. Raised leptin concentrations among South Asian patients with chronic heart failure. Int J Cardiol. Oct. 31. 2007;122(1):34-40. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17187880].
Patel JV, Sosin M, Gunarathne A, et al. Elevated angiogenin levels in chronic heart failure. Ann Med. 2008;40(6):474-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19160530].
Patel UD, Garg AX, Krumholz HM, et al. Preoperative serum brain natriuretic peptide and risk of acute kidney injury after cardiac surgery. Circ. Mar. 20. 2012;125(11):1347-55. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Paterna S, Di Pasquale P, Parrinello G, et al. Changes in brain natriuretic peptide levels and bioelectrical impedance measurements after treatment with high-dose furosemide and hypertonic saline solution versus high-dose furosemide alone in refractory congestive heart failure: A double-blind study. J Am Coll Cardiol. Jun. 21. 2005;45(12):1997-2003. Exclude: BNP measure not FDA approved. [pmid: 15963399].
Paterna S, Gaspare P, Fasullo S, et al. Normal-sodium diet compared with low-sodium diet in compensated congestive heart failure: Is sodium an old enemy or a new friend?. Clin Sci. Feb. 2008;114(3):221-30. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17688420].
Paterna S, Parrinello G, Cannizzaro S, et al. Medium term effects of different dosage of diuretic, sodium, and fluid administration on neurohormonal and clinical outcome in patients with recently compensated heart failure. Am J Cardiol. Jan. 1. 2009;103(1):93-102. Exclude: BNP measure not FDA approved. [pmid: 19101237].
Patrianakos AP, Parthenakis FI, Papadimitriou EA, et al. Restrictive filling pattern is associated with increased humoral activation and impaired exercise capacity in dilated cardiomyopathy. Eur J Heart Fail. Oct. 2004;6(6):735-43. Exclude: BNP measure not FDA approved. [pmid: 15542409].
Patrianakos AP, Parthenakis FI, Nyktari E, et al. Central aortic stiffness in patients with nonischemic dilated cardiomyopathy: Relationship with neurohumoral activation. J Card Fail. Oct. 2009;15(8):665-72. Exclude: BNP measure not FDA approved. [pmid: 19786255].
Patton KK, Ellinor PT, Heckbert SR, et al. N-terminal pro-B-type natriuretic peptide is a major predictor of the development of atrial fibrillation: The Cardiovascular Health Study. Circ. Nov. 3. 2009;120(18):1768-74. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Patwardhan AA, Larson MG, Levy D, et al. Obstructive sleep apnea and plasma natriuretic peptide levels in a community-based sample. Sleep. Oct. 1. 2006;29(10):1301-6. Exclude: BNP measure not FDA approved. [pmid: 17068983].
Paul B, Joseph M, De Pasquale CG. Domiciliary oxygen therapy improves sub-maximal exercise capacity and quality of life in chronic heart failure. Heart Lung Circ. 2008;17(3):220-3. Exclude: BNP measure not FDA approved. [pmid: 18403260].
Pawlowska-Jenerowicz W, Serwacka M, Dabrowski M. Cardiopulmonary exercise testing - Enhancing validity for patients with chronic heart failure. Folia Cardiol. 2003;10(6):727-31. Exclude: Not in English.
Pawlowska-Jenerowicz W, Drewniak W, Dabrowski M. Left ventricular performance and exercise capacity in patients aged 65 years and older treated by primary coronary angioplasty or conservatively for acute myocardial infarction--A one-year follow-up. Kardiol Pol. 2008;66(11):1153-61. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19105092].
Payne CJ, Gibson SC, Bryce G, et al. B-type natriuretic peptide predicts long-term survival after major non-cardiac surgery. Br J Anaesth. Aug. 2011;107(2):144-9. Exclude: BNP measure not FDA approved. [pmid: 21610013].
Peacock FA. Hypertensive heart failure: Patient characteristics, treatment, and outcomes. Am J Emerg Med. 2011;29(8):855-62. Exclude: BNP measure not FDA approved. [pmid: 20825913].
Peacock WF, Harrison A, Moffa D. Clinical and economic benefits of using AUDICOR S3 detection for diagnosis and treatment of acute decompensated heart failure. Congest Heart Fail. Jul. 2006;12(Suppl 1):32-6. Exclude: BNP measure not FDA approved. [pmid: 16894272].
Pearl A, Wright S, Gamble G, et al. Randomised trials in general practice--A New Zealand experience in recruitment. NZ Med J. Nov. 21. 2003;116(1186):U681. Exclude: BNP measure not FDA approved.
Pedersen EB, Pedersen HB, Jensen KT. Pulsatile secretion of atrial natriuretic peptide and brain natriuretic peptide in healthy humans. Clin Sci. Aug. 1999;97(2):201-6. Exclude: BNP measure not FDA approved. [pmid: 10409475].
Pedersen F, Raymond I, Kistorp C, et al. N-terminal pro-brain natriuretic peptide in arterial hypertension: A valuable prognostic marker of cardiovascular events. J Card Fail. Jun. 2005;11(5 Suppl):S70-5. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 15948105].
Peer A, Falkensammer G, Alber H, et al. Limited utilities of N-terminal pro B-type natriuretic peptide and other newer risk markers compared with traditional risk factors for prediction of significant angiographic lesions in stable coronary artery disease. Heart. Feb. 2009;95(4):297-303. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18708421].
Pejovic J, I. N-terminal pro-B-type natriuretic peptide in patients with hypertensive heart disease. J Med Biochem. 2011;30(3):244-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Pelle AJ, Van Den Broek KC, Szabo B, et al. The relationship between Type D personality and chronic heart failure is not confounded by disease severity as assessed by BNP. Int J Cardiol. 2010;145(1):82-3. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19477027].
Peng T, Gao H, Shen L, et al. Correlation of brain natriuretic peptide and microalbuminuria in patients with heart failure. West Indian Medical Journal. Dec. 2011;60(6):658-61. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 22512224].
Pepperell JC, Maskell NA, Jones DR, et al. A randomized controlled trial of adaptive ventilation for Cheyne-Stokes breathing in heart failure. Am J Respir Crit Care Med. Nov. 1. 2003;168(9):1109-14. Exclude: BNP measure not FDA approved. [pmid: 12928310].
Pereira-Barretto AC, de OM Jr., Franco FG, et al. ProBNP for stratifying patients with heart failure. Arq Bras Cardiol. Sep. 2003;81(3):239-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 14569369].
Pereira M, Azevedo A, Severo M, et al. Long-term stability of endogenous B-type natriuretic peptide after storage at -20 degrees C or -80 degrees C. Clin Chem Lab Med. 2008;46(8):1171-4. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18588432].
Peres E, Levine JE, Khaled YA, et al. Cardiac complications in patients undergoing a reduced-intensity conditioning hematopoietic stem cell transplantation. Bone Marrow Transplant. 2010;45(1):149-52. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19465940].
Perik PJ, de Vries EG, Boomsma F, et al. Use of natriuretic peptides for detecting cardiac dysfunction in long-term disease-free breast cancer survivors. Anticanc Res. Sep. 2005;25(5):3651-7. Exclude: BNP measure not FDA approved.
Perik PJ, van der Graaf WT, de Vries EG, et al. Circulating apoptotic proteins are increased in long-term disease-free breast cancer survivors. Acta Oncol. 2006;45(2):175-83. Exclude: BNP measure not FDA approved. [pmid: 16546863].
Perik PJ, Lub-De Hooge MN, Gietema JA, et al. Indium-111-labeled trastuzumab scintigraphy in patients with human epidermal growth factor receptor 2-positive metastatic breast cancer. J Clin Oncol. May. 20. 2006;24(15):2276-82. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16710024].
Perik PJ, Rikhof B, de Jong FA, et al. Results of plasma N-terminal pro B-type natriuretic peptide and cardiac troponin monitoring in GIST patients do not support the existence of imatinib-induced cardiotoxicity. Ann Oncol. Feb. 2008;19(2):359-61. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17962203].
Perin EC, Dohmann HFR, Borojevic R, et al. Transendocardial, autologous bone marrow cell transplantation for severe, chronic ischemic heart failure. Circ. 2003;107(18):2294-302. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Perkiomaki JS, Hamekoski S, Junttila MJ, et al. Predictors of long-term risk for heart failure hospitalization after acute myocardial infarction. Ann Noninvasive Electrocardiol. Jul. 2010;15(3):250-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20645968].
Perlini S, Musca. Functional correlates of N-terminal natriuretic peptide type B (NT-proBNP) response to therapy in cardiac light chain (AL) amyloidosis. Amyloid. 2011;18(Suppl 1):96-7. Exclude: BNP measure not FDA approved. [pmid: 21838447].
Perlowski AA, Aboulhosn J, Castellon Y, et al. Relation of brain natriuretic peptide to myocardial performance index in adults with congenital heart disease. Am J Cardiol. 2007;100(1):110-4. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17599451].
Persson A, Hartford M, Herlitz J, et al. Long-term prognostic value of mitral regurgitation in acute coronary syndromes. Heart. 2010;96(22):1803-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20876739].
Persson H, Lonn E, Edner M, et al. Diastolic dysfunction in heart failure with preserved systolic function: Need for objective evidence:results from the CHARM Echocardiographic Substudy-CHARMES. J Am Coll Cardiol. Feb. 13. 2007;49(6):687-94. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17291934].
Peters-Klimm F, Muller-Tasch T, Schellberg D, et al. Rationale, design and conduct of a randomised controlled trial evaluating a primary care-based complex intervention to improve the quality of life of heart failure patients: HICMan (Heidelberg Integrated Case Management). BMC Cardiovasc Disord. 2007;7:25. Exclude: Not a primary study. [pmid: 17716364].
Peters-Klimm F, Campbell S, Muller-Tasch T, et al. Primary care-based multifaceted, interdisciplinary medical educational intervention for patients with systolic heart failure: Lessons learned from a cluster randomised controlled trial. Trials. 2009;10:68. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19678944].
Peters-Klimm F, Kunz CU, Laux G, et al. Patient- and provider-related determinants of generic and specific health-related quality of life of patients with chronic systolic heart failure in primary care: A cross-sectional study. Health Qual Life Outcomes. 2010;13(98). Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Peters MJ, Welsh P, McInnes IB, et al. Tumour necrosis factor (alpha) blockade reduces circulating N-terminal pro-brain natriuretic peptide levels in patients with active rheumatoid arthritis: results from a prospective cohort study. Ann Rheum Dis. Jul. 2010;69(7):1281-5. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19934107].
Petracca F, Affuso F, Di Conza P, et al. Usefulness of NT-proBNP in the assessment of patients with aortic or mitral regurgitation. J Cardiovasc Med. Dec. 2009;10(12):928-32. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Pfister R, Tan D, Thekkanal J, et al. NT-pro-BNP is associated with long-term outcome in a heterogeneous sample of cardiac inpatients. Eur J Intern Med. 2007;18(3):215-20. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17449394].
Pfister R, Tan D, Thekkanal J, et al. NT-pro-BNP measured at discharge predicts outcome in multimorbid diabetic inpatients with a broad spectrum of cardiovascular disease. Acta Diabetol. 2007;44(2):91-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17530473].
Pfister R, Tan D, Thekkanal J, et al. Predictors of elevated NT-pro-BNP in cardiovascular patients without acute heart failure. Int J Cardiol. Jan. 9. 2009;131(2):277-80. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17913264].
Pfister R, Sharp S, Luben R, et al. Mendelian randomization study of B-type natriuretic peptide and type 2 diabetes: Evidence of causal association from population studies. PLoS Medicine / Public Library of Science. Oct. 2011;8(10):e1001112. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Phelan D, Smyth L, Ryder M, et al. Can we reduce preventable heart failure readmissions in patients enrolled in a Disease Management Programme?. Ir J Med Sci. Jun. 2009;178(2):167-71. Exclude: BNP measure not FDA approved. [pmid: 19408042].
Philipp S, Monti J, Pagel I, et al. Treatment with darusentan over 21 days improved cGMP generation in patients with chronic heart failure. Clin Sci. Aug. 2002;103(Suppl 48):249S-53S. Exclude: BNP measure not FDA approved. [pmid: 12193097].
Phrommintikul A, Sivasinprasasn S, Lailerd N, et al. Plasma urocortin in acute myocardial infarction patients. Eur J Clin Invest. Oct. 2010;40(10):874-82. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20636379].
Piccoli A. Bioelectric impedance measurement for fluid status assessment. Contrib Nephrol. 2010;164:143-52. Exclude: Not a primary study. [pmid: 20428000].
Piccoli A, Codognotto M, Cianci V, et al. Differentiation of cardiac and noncardiac dyspnea using bioelectrical impedance vector analysis (BIVA). J Card Fail. 2012;18(3):226-32. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 22385943].
Pichon MF, Cvitkovic F, Hacene K, et al. Drug-induced cardiotoxicity studied by longitudinal B-type natriuretic peptide assays and radionuclide ventriculography. In Vivo. May. 2005;19(3):567-76. Exclude: BNP measure not FDA approved. [pmid: 15875778].
Pidgeon GB, Richards AM, Nicholls MG, et al. Differing metabolism and bioactivity of atrial and brain natriuretic peptides in essential hypertension. Hypertens. Apr. 1996;27(4):906-13. Exclude: BNP measure not FDA approved.
Piechota M, Banach M, Irzmaski R, et al. NT-proBNP levels correlate with organ failure in septic patients: A preliminary report. Postepy Hig Med Dosw. 2006;60:632-6. Exclude: BNP measure not FDA approved.
Piechota M, Banach M, Irzmanski R, et al. Plasma endothelin-1 levels in septic patients. J Intensive Care Med. 2007;22(4):232-9. Exclude: BNP measure not FDA approved. [pmid: 17722367].
Piechota WN, Piechota WT, Bejm J, et al. Correlation of B type natriuretic peptides with clinical and echocardiographic parameters in heterogeneous population of patients with symptoms suggestive of heart failure. Adv Med Sci. 2006;51:164-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17357300].
Piepoli MF, Villani GQ, Corra U, et al. Time course of effects of cardiac resynchronization therapy in chronic heart failure: Benefits in patients with preserved exercise capacity. Pacing Clin Electrophysiol. Jun. 2008;31(6):701-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18507542].
Pieroni M, Bellocci F, Sanna T, et al. Increased brain natriuretic peptide secretion is a marker of disease progression in nonobstructive hypertrophic cardiomyopathy. J Card Fail. Jun. 2007;13(5):380-8. Exclude: BNP measure not FDA approved. [pmid: 17602985].
Pieroni M, Corti A, Tota B, et al. Myocardial production of chromogranin A in human heart: A new regulatory peptide of cardiac function. Eur Heart J. May. 2007;28(9):1117-27. Exclude: BNP measure not FDA approved. [pmid: 17389654].
Pilz S, Mangge H, Wellnitz B, et al. Adiponectin and mortality in patients undergoing coronary angiography. J Clin Endocrinol Metab. 2006;91(11):4277-86. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16912132].
Pilz S, Scharnagl H, Tiran B, et al. Free fatty acids are independently associated with all-cause and cardiovascular mortality in subjects with coronary artery disease. J Clin Endocrinol Metab. 2006;91(7):2542-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16595593].
Pimenta E, Calhoun DA. Hypertensive crisis: Forget the numbers. J Hypertens. 2012;30(5):882-3. Exclude: Not a primary study. [pmid: 22495131].
Pimenta J, Sampaio F, Martins P, et al. Aminoterminal B-type natriuretic peptide (NT-proBNP) in end-stage renal failure patients on regular hemodialysis: Does it have diagnostic and prognostic implications?. Nephron. 2009;111(3):c182-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19194108].
Pimenta J, Paulo C, Gomes A, et al. B-type natriuretic peptide is related to cardiac function and prognosis in hospitalized patients with decompensated cirrhosis. Liver Int. Aug. 2010;30(7):1059-66. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20492497].
Pinelli M, Bindi M, Cassetti G, et al. Relationship between low T3 syndrome and NT-proBNP levels in non-cardiac patients. Acta Cardiol. Feb. 2007;62(1):19-24. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17375888].
Pinelli M, Bindi M, Moroni F, et al. Relationship between serum uric acid levels and urinary albumin excretion in patients with heart failure. Acta Cardiol. Apr. 2008;63(2):191-5. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18468199].
Pingitore A, Iervasi G, Barison A, et al. Early activation of an altered thyroid hormone profile in asymptomatic or mildly symptomatic idiopathic left ventricular dysfunction. J Card Fail. Sep. 2006;12(7):520-6. Exclude: BNP measure not FDA approved. [pmid: 16952785].
Pitt B, Latini R, Maggioni AP, et al. Neurohumoral effects of aliskiren in patients with symptomatic heart failure receiving a mineralocorticoid receptor antagonist: The Aliskiren Observation of Heart Failure Treatment study. Eur J Heart Fail. Jul. 2011;13(7):755-64. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21467028].
Pitt B, Zannad F. Eplerenone: Is it time to add this drug to current heart failure therapy?. Therapeut Adv Chron Dis. 2012;3(1):5-9. Exclude: Not a primary study.
Pizarro R, Bazzino OO, Oberti PF, et al. Prospective validation of the prognostic usefulness of brain natriuretic peptide in asymptomatic patients with chronic severe mitral regurgitation. J Am Coll Cardiol. Sep. 15. 2009;54(12):1099-106. Exclude: BNP measure not FDA approved. [pmid: 19744620].
Pizarro RB. Prospective validation of the prognostic usefulness of B-type natriuretic peptide in asymptomatic patients with chronic severe aortic regurgitation. J Am Coll Cardiol. 2011;58(16):1705-14. Exclude: BNP measure not FDA approved. [pmid: 21982316].
Pleger STM. Acute safety and 30-day outcome after percutaneous edge-to-edge repair of mitral regurgitation in very high-risk patients. Am J Cardiol. 2011;108(10):1478-82. Exclude: BNP measure not FDA approved. [pmid: 21890084].
Pleister AP, Baliga RR, Haas GJ. Acute study of clinical effectiveness of nesiritide in decompensated heart failure: Nesiritide redux. Curr Heart Fail Rep. Sep. 2011;8(3):226-32. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21695395].
Plymen CM, Hughes ML, Picaut N, et al. The relationship of systemic right ventricular function to ECG parameters and NT-proBNP levels in adults with transposition of the great arteries late after Senning or Mustard surgery. Heart. 2010;96(19):1569-73. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20720248].
Poelzl G, Frick M, Lackner B, et al. Short-term improvement in submaximal exercise capacity by optimized therapy with ACE inhibitors and beta blockers in heart failure patients is associated with restoration of peripheral endothelial function. Int J Cardiol. Mar. 22. 2006;108(1):48-54. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16516697].
Poh KK, Chan MYY, Yang H, et al. Prognostication of valvular aortic stenosis using tissue Doppler echocardiography: Underappreciated importance of late diastolic mitral annular velocity. J Am Soc Echocardiogr. 2008;21(5):475-81. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17928192].
Polak J, Kotrc M, Wedellova Z, et al. Lipolytic effects of B-type natriuretic peptide 1-32 in adipose tissue of heart failure patients compared with healthy controls. J Am Coll Cardiol. Sep. 6. 2011;58(11):1119-25. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21884948].
Politi P, Brondino N, Emanuele E. Increased proapoptotic serum activity in patients with chronic mood disorders. Arch Med Res. Feb. 2008;39(2):242-5. Exclude: BNP measure not FDA approved. [pmid: 18164972].
Poliwczak AR, Bialkowska J, Broncel M, et al. Heart rhythm turbulence and NT-proBNP in decompensated liver cirrhosis--A pilot study. Med Sci Monit. Jun. 2011;17(6):R5-11. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Ponitz V, Brugger-Andersen T, Pritchard D, et al. Activated factor XII type A and B-type natriuretic peptide are complementary and incremental predictors of mortality in patients following admission with acute coronary syndrome. Blood Coagul Fibrinolysis. 2009;20(8):652-60. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19809305].
Ponitz V, Brugger-Andersen T, Pritchard D, et al. Activated factor XII type A predicts long-term mortality in patients admitted with chest pain. J Thromb Haemostasis. Feb. 2009;7(2):277-87. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19054318].
Ponschab M, Hochmair N, Ghazwinian N, et al. Levosimendan infusion improves haemodynamics in elderly heart failure patients undergoing urgent hip fracture repair. Eur J Anaesthesiol. 2008;25(8):627-33. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18405408].
Popescu BA, Calin A, Beladan CC, et al. Left ventricular torsional dynamics in aortic stenosis: Relationship between left ventricular untwisting and filling pressures. A two-dimensional speckle tracking study. Eur J Echocardiogr. 2010;11(5):406-13. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20053657].
Poppe KK, Whalley GA, Richards AM, et al. Prediction of ACC/AHA stage B heart failure by clinical and neurohormonal profiling among patients in the community. J Card Fail. 2010;16(12):957-63. Exclude: BNP measure not FDA approved. [pmid: 21111985].
Porcel JM, Vives M, Cao G, et al. Measurement of pro-brain natriuretic peptide in pleural fluid for the diagnosis of pleural effusions due to heart failure. Am J Med. Mar. 15. 2004;116(6):417-20. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 15006591].
Porcel JM, Chorda J, Cao G, et al. Comparing serum and pleural fluid pro-brain natriuretic peptide (NT-proBNP) levels with pleural-to-serum albumin gradient for the identification of cardiac effusions misclassified by Light's criteria. Respirology. Sep. 2007;12(5):654-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17875051].
Porcel JM, Martinez-Alonso M, Cao G, et al. Biomarkers of heart failure in pleural fluid. Chest. Sep. 2009;136(3):671-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19363209].
Post F, Weilemann LS, Messow CM, et al. B-type natriuretic peptide as a marker for sepsis-induced myocardial depression in intensive care patients. Crit Care Med. Nov. 2008;36(11):3030-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18824903].
Potapov EV, Hennig F, Wagner FD, et al. Natriuretic peptides and E-selectin as predictors of acute deterioration in patients with inotrope-dependent heart failure. Eur J Cardiothorac Surg. May. 2005;27(5):899-905. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 15848333].
Potocki M, Breidthardt T, Reichlin T, et al. Midregional pro-adrenomedullin in addition to b-type natriuretic peptides in the risk stratification of patients with acute dyspnea: An observational study. Crit Care. 2009;13(4):R122. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19627611].
Potocki M, Breidthardt T, Mueller A, et al. Copeptin and risk stratification in patients with acute dyspnea. Crit Care. 2010;14(6):R213. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21106053].
Potter BJ, Beauregard C, Serri O. Serum markers of cardiovascular risk in patients with acromegaly before and after six months of treatment with octreotide LAR. Pituitary. 2008;11(1):49-53. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17917813].
Poulsen SH, Sogaard P, Nielsen-Kudsk JE, et al. Recovery of left ventricular systolic longitudinal strain after valve replacement in aortic stenosis and relation to natriuretic peptides. J Am Soc Echocardiogr. Jul. 2007;20(7):877-84. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17617315].
Prakaschandra DR, Esterhuizen T, Naidoo DP. The time-course changes of NT-proBNP and tissue Doppler indices in patients undergoing mitral valve replacement. Cardiovasc J Afr. 2012;23(4):200-5. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 22614663].
Prasad SK, Dargie HJ, Smith GC, et al. Comparison of the dual receptor endothelin antagonist enrasentan with enalapril in asymptomatic left ventricular systolic dysfunction: A cardiovascular magnetic resonance study. Heart. 2006;92(6):798-803. Exclude: BNP measure not FDA approved. [pmid: 16339819].
Prastaro MP. N-terminal pro-B-type natriuretic peptide and left atrial function in patients with congestive heart failure and severely reduced ejection fraction. Eur J Echocardiogr. 2011;12(7):506-13. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21685193].
Prasun MA. The effects of a diuretic titration protocol on clinical outcomes in heart failure patients. University of Illinois at Chicago, Health Sciences Center. 2002. Exclude: BNP measure not FDA approved.
Prasun MA, Kocheril AG, Klass PH, et al. The effects of a sliding scale diuretic titration protocol in patients with heart failure. J Cardiovasc Nurs. Jan. 2005;20(1):62-70. Exclude: BNP measure not FDA approved. [pmid: 15632815].
Preechaburana P, Macken S, Suska A, et al. HDR imaging evaluation of a NT-proBNP test with a mobile phone. Biosens Bioelectron. 2011;26(5):2107-13. Exclude: Non-human population. [pmid: 20926279].
Prefumo F, Sharma R, Brecker SJD, et al. Maternal cardiac function in early pregnancies with high uterine artery resistance. Ultrasound Obstet Gynecol. 2007;29(1):58-64. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17154248].
Prescott E, Hjardem-Hansen R, Dela F, et al. Exercise training in older patients with systolic heart failure: Adherence, exercise capacity, inflammation and glycemic control. Scand Cardiovasc J. Aug. 2009;43(4):249-55. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19101855].
Principi T, Falzetti G, Elisei D, et al. Behavior of B-type natriuretic peptide during mechanical ventilation and spontaneous breathing after extubation. Minerva Anestesiol. Apr. 2009;75(4):179-83. Exclude: BNP measure not FDA approved. [pmid: 19078903].
Prondzinsky R, Lemm H, Swyter M, et al. Intra-aortic balloon counterpulsation in patients with acute myocardial infarction complicated by cardiogenic shock: The prospective, randomized IABP SHOCK Trial for attenuation of multiorgan dysfunction syndrome. Crit Care Med. Jan. 2010;38(1):152-60. Exclude: BNP measure not FDA approved. [pmid: 19770739].
Prontera C, Emdin M, Zucchelli GC, et al. Analytical performance and diagnostic accuracy of a fully-automated electrochemiluminescent assay for the N-terminal fragment of the pro-peptide of brain natriuretic peptide in patients with cardiomyopathy: Comparison with immunoradiometric assay methods for brain natriuretic peptide and atrial natriuretic peptide. Clin Chem Lab Med. Jan. 2004;42(1):37-44. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 15061378].
Provan S, Angel K, Semb AG, et al. NT-proBNP predicts mortality in patients with rheumatoid arthritis: Results from 10-year follow-up of the EURIDISS study. Ann Rheum Dis. Nov. 2010;69(11):1946-50. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20525846].
Pruijsten RV, de Jonge N, Kirkels JH, et al. Left ventricular assist device: A functional comparison with heart transplantation. Neth Heart J. 2008;16(2):41-6. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18335020].
Pruijsten RV, Lok SI, Kirkels HH, et al. Functional and haemodynamic recovery after implantation of continuous-flow left ventricular assist devices in comparison with pulsatile left ventricular assist devices in patients with end-stage heart failure. Eur J Heart Fail. 2012;14(3):319-25. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 22294758].
Przybylowski P, Malyszko J, Malyszko JS. A possible role of hepcidin in the pathogenesis of anemia in heart allograft recipients. Transplant Proc. Jun. 2010;42(5):1803-7. Exclude: BNP measure not FDA approved. [pmid: 20620527].
Przybylowski P, Malyszko J, Malyszko JS, et al. Anemia in heart and kidney allograft recipients: Is there a role for hepcidin?. Transplant Proc. 2010;42(10):4255-8. Exclude: BNP measure not FDA approved. [pmid: 21168677].
Przybylowski P, Malyszko J, Malyszko JS. Copeptin in heart transplant recipients depends on kidney function and intraventricular septal thickness. Transplant Proc. Jun. 2010;42(5):1808-11. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20620528].
Przybylowski P, Malyszko J. Chronic kidney disease in orthotopic heart transplant recipients. Med Sci Monit. 2010;16(11):563-6. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Przybylowski P, Malyszko J, Malyszko JS. Serum midkine is related to NYHA class and cystatin C in heart transplant recipients. Transplant Proc. 2010;42(9):3704-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21094842].
Psychari SN, Apostolou TS, Iliodromitis EK, et al. DDDR pacing results in left ventricular asynchrony with preservation of ejection fraction and NT-proBNP: A prospective study in sick sinus syndrome and normal ventricular function. Int J Cardiol. Oct. 8. 2010;144(2):310-2. Exclude: BNP measure not FDA approved. [pmid: 19342110].
Pucci A, Wharton J, Arbustini E, et al. Atrial amyloid deposits in the failing human heart display both atrial and brain natriuretic peptide-like immunoreactivity. J Pathol. Nov. 1991;165(3):235-41. Exclude: BNP measure not FDA approved. [pmid: 1837051].
Pudil R, Tichy M, Praus R, et al. NT-proBNP and echocardiographic parameters in patients with acute heart failure. Acta Med. 2007;50(1):51-6. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Pudil R, Tichy M, Blaha V, et al. NT-proBNP correlates not only with ejection fraction, but also with inferior vena cava diameter in patients with acute heart failure. Clin Chim Acta. Mar. 2007;378(1-2):230. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17182022].
Pudil R, Tichy M, Andrys C, et al. Prognostic value of N-terminal pro-B-type natriuretic peptide in patients with severe acute decompensated heart failure. Klin Biochem Metabol. 2008;16(4):244-7. Exclude: Unable to obtain copy.
Pudil R, Tichy M, Andrys C, et al. Plasma interleukin-6 level is associated with NT-proBNP level and predicts short- and long-term mortality in patients with acute heart failure. Acta Med. 2010;53(4):225-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Puls M, Dellas C, Lankeit M, et al. Heart-type fatty acid-binding protein permits early risk stratification of pulmonary embolism. Eur Heart J. Jan. 2007;28(2):224-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17127709].
Puri A, Narain VS, Mehrotra S, et al. N-terminal probrain natriuretic peptide as a predictor of short-term outcomes in acute myocardial infarction. Indian Heart J. Jul. 2005;57(4):304-10. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16350675].
Puri A, Narain VS, Mehrotra S, et al. N-termiznal probrain natriuretic peptide predicts adverse outcomes in acute myocardial infarction even with preserved left ventricular ejection fraction. Indian Heart J. 2006;58(2):138-43. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18989058].
Raab S, Oertel F, Weimann T, et al. Brain natriuretic peptide--a reliable parameter for the effectiveness of cardiac resynchronization therapy after coronary artery bypass grafting. Interact Cardiovasc Thorac Surg. Aug. 2006;5(4):439-43. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17670611].
Racek J, Kralova H, Trefil L, et al. Brain natriuretic peptide and N-terminal proBNP in chronic haemodialysis patients. Nephron. 2006;103(4):c162-72. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16645318].
Radovancevic B, Vrtovec B, Delgado RM III. Predicting mortality in patients with advanced heart failure. Cardiol Rev. 2004;21(2):31-5. Exclude: BNP measure not FDA approved.
Radovanovic M, Vasiljevic Z, Radovanovic N, et al. B-type natriuretic peptide in outpatients after myocardial infarction: Optimized cut-off value for incident heart failure prediction. Peptides. Oct. 2010;31(10):1946-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20600420].
Radvan M, Svoboda P, Radvanova J, et al. Brain natriuretic peptide in decompensation of liver cirrhosis in non-cardiac patients. Hepatogastroenterol. Jan. 2009;56(89):181-5. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Raedle-Hurst TM, Welsch C, Forestier N, et al. Validity of N-terminal propeptide of the brain natriuretic peptide in predicting left ventricular diastolic dysfunction diagnosed by tissue Doppler imaging in patients with chronic liver disease. Eur J Gastroenterol Hepatol. Sep. 2008;20(9):865-73. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18794600].
Rahmutula D, Nakayama T, Soma M, et al. A C2077T polymorphism of the type B human natriuretic peptide receptor gene is not associated with myocardial infarction. Med Sci Monit. 2000;6(6):1056-60. Exclude: BNP measure not FDA approved. [pmid: 11208455].
Rajani R, Rimington H, Chambers J. B-type natriuretic peptide and tissue Doppler for predicting symptoms on treadmill exercise in apparently asymptomatic aortic stenosis. J Heart Valve Dis. Sep. 2009;18(5):565-71. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20099699].
Rame JE, Tam SW, McNamara D, et al. Dysfunctional corin i555(p568) allele is associated with impaired brain natriuretic peptide processing and adverse outcomes in blacks with systolic heart failure: results from the Genetic Risk Assessment in Heart Failure substudy. Circ. Nov. 2009;2(6):541-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Rana BS, Davies JI, Band MM, et al. B-type natriuretic peptide can detect silent myocardial ischaemia in asymptomatic type 2 diabetes. Heart. Jul. 2006;92(7):916-20. Exclude: BNP measure not FDA approved. [pmid: 16339811].
Rana R, Vlahakis NE, Daniels CE, et al. B-type natriuretic peptide in the assessment of acute lung injury and cardiogenic pulmonary edema. Crit Care Med. Jul. 2006;34(7):1941-6. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16691132].
Ranjith N, Pegoraro RJ, Naidoo DP, et al. The role of echocardiography and its comparison with NT-proBNP measurements in patients with acute myocardial infarction. Med Sci Monit. Dec. 2007;13(12):CR574-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18049439].
Rao A, Georgiadou P, Francis DP, et al. Sleep-disordered breathing in a general heart failure population: Relationships to neurohumoral activation and subjective symptoms. J Sleep Res. Mar. 2006;15(1):81-8. Exclude: BNP measure not FDA approved. [pmid: 16490006].
Rao A, Hodgson L, Pearce D, et al. BNP in the community - still work to be done. Int J Cardiol. Feb. 29. 2008;124(2):228-30. Exclude: BNP measure not FDA approved. [pmid: 17363081].
Raposeiras-Roubin S, Rodino-Janeiro BK, Grigorian-Shamagian L, et al. Soluble receptor of advanced glycation end products levels are related to ischaemic aetiology and extent of coronary disease in chronic heart failure patients, independent of advanced glycation end products levels. Eur J Heart Fail. 2010;12(10):1092-100. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20685687].
Rasic S, Hadzovic-Dzuvo A, Tomic M, et al. Impact of hemoglobin concentration on plasma B-type natriuretic peptide level and left ventricle echocardiographics characteristics in chronic kidney disease patients. Coll Antropol. Dec. 2009;33(Suppl 2):141-4. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20120531].
Rasmussen VG, Poulsen SH, Dupont E, et al. Heart valve disease associated with treatment with ergot-derived dopamine agonists: A clinical and echocardiographic study of patients with Parkinson's disease. J Intern Med. Jan. 2008;263(1):90-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18036161].
Rasmussen VG, Poulsen SH, Dupont E, et al. Ergotamine-derived dopamine agonists and left ventricular function in Parkinson patients: systolic and diastolic function studied by conventional echocardiography, tissue Doppler imaging, and two-dimensional speckle tracking. Eur J Echocardiogr. Nov. 2008;9(6):803-8. Exclude: BNP measure not FDA approved. [pmid: 18490274].
Rastan AJ, Bittner HB, Gummert JF, et al. On-pump beating heart versus off-pump coronary artery bypass surgery-evidence of pump-induced myocardial injury. Eur J Cardiothorac Surg. Jun. 2005;27(6):1057-64. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 15896617].
Rathcke CN, Raymond I, Kistorp C, et al. Low grade inflammation as measured by levels of YKL-40: Association with an increased overall and cardiovascular mortality rate in an elderly population. Int J Cardiol. Aug. 6. 2010;143(1):35-42. Exclude: BNP measure not FDA approved. [pmid: 19223085].
Rautureau Y, Baxter GF. Acute actions of natriuretic peptides in coronary vasculature and ischaemic myocardium. Curr Pharm Des. 2004;10(20):2477-82. Exclude: Not a primary study. [pmid: 15320757].
Ray P, Birolleau S, Lefort Y, et al. Acute respiratory failure in the elderly: Etiology, emergency diagnosis and prognosis. Crit Care. 2006;10(3):R82. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16723034].
Raymond I, Groenning BA, Hildebrandt PR, et al. The influence of age, sex and other variables on the plasma level of N-terminal pro brain natriuretic peptide in a large sample of the general population. Heart. Jul. 2003;89(7):745-51. Exclude: BNP measure not FDA approved. [pmid: 12807847].
Rector TS, Anand IS, Cohn JN. Relationships between clinical assessments and patients' perceptions of the effects of heart failure on their quality of life. J Card Fail. 2006;12(2):87-92. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16520254].
Redfield MM, Rodeheffer RJ, Jacobsen SJ, et al. Plasma brain natriuretic peptide concentration: Impact of age and gender. J Am Coll Cardiol. Sep. 4. 2002;40(5):976-82. Exclude: BNP measure not FDA approved. [pmid: 12225726].
Redfield MM, Rodeheffer RJ, Jacobsen SJ, et al. Plasma brain natriuretic peptide to detect preclinical ventricular systolic or diastolic dysfunction: A community-based study. Circ. Jun. 29. 2004;109(25):3176-81. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Reed MJ, Newby DE, Coull AJ, et al. The ROSE (risk stratification of syncope in the emergency department) study. J Am Coll Cardiol. Feb. 23. 2010;55(8):713-21. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20170806].
Reed MJ, Gibson L. The effect of syncope on brain natriuretic peptide. Emerg Med J. Dec. 2011;28(12):1066-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21292790].
Reesink HJ, Tulevski II, Marcus JT, et al. Brain natriuretic peptide as noninvasive marker of the severity of right ventricular dysfunction in chronic thromboembolic pulmonary hypertension. Ann Thorac Surg. 2007;84(2):537-43. Exclude: BNP measure not FDA approved. [pmid: 17643631].
Rehman S, Lloyd-Jones DM, Martinez-Rumayor A, et al. Inflammatory markers, amino-terminal pro-brain natriuretic peptide, and mortality risk in dyspneic patients. Am J Clin Pathol. Aug. 2008;130(2):305-11. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18628102].
Rehman SU, Martinez-Rumayor A, Mueller T, et al. Independent and incremental prognostic value of multimarker testing in acute dyspnea: Results from the ProBNP Investigation of Dyspnea in the Emergency Department (PRIDE) study. Clin Chim Acta. Jun. 2008;392(1-2):41-5. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18387360].
Reichenberger F, Voswinckel R, Steveling E, et al. Sildenafil treatment for portopulmonary hypertension. Eur Respir J. 2006;28(3):563-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16807265].
Reichlin T, Potocki M, Breidthardt T, et al. Diagnostic and prognostic value of uric acid in patients with acute dyspnea. Am J Med. Nov. 2009;122(11):1054.e7-14. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19854335].
Reny JL, Millot O, Vanderecamer T, et al. Admission NT-proBNP levels, renal insufficiency and age as predictors of mortality in elderly patients hospitalized for acute dyspnea. Eur J Intern Med. Jan. 2009;20(1):14-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19237086].
Resic H, Ajanovic S, Kukavica N, et al. Plasma levels of brain natriuretic peptides and cardiac troponin in hemodialysis patients. Bosnian J Basic Med Sci. May. 2009;9(2):137-41. Exclude: BNP measure not FDA approved.
Resl MN. NT-proBNP and cardiac events in older diabetic patients. Eur J Cardiovasc Prev Rehabil. 2011;18(3):399-405. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21450658].
Resnik JL, Hong C, Resnik R, et al. Evaluation of B-type natriuretic peptide (BNP) levels in normal and preeclamptic women. Am J Obstet Gynecol. Aug. 2005;193(2):450-4. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16098869].
Reynolds L, Broadbent E, Ellis CJ, et al. Patients' drawings illustrate psychological and functional status in heart failure. J Psychosom Res. 2007;63(5):525-32. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17980226].
Ribeiro AL, Teixeira MM, Reis AM, et al. Brain natriuretic peptide based strategy to detect left ventricular dysfunction in Chagas disease: A comparison with the conventional approach. Int J Cardiol. Apr. 28. 2006;109(1):34-40. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16023747].
Richards AM, Crozier IG, Yandle TG, et al. Brain natriuretic factor: regional plasma concentrations and correlations with haemodynamic state in cardiac disease. Br Heart J. May. 1993;69(5):414-7. Exclude: BNP measure not FDA approved. [pmid: 8390847].
Richards AM, Crozier IG, Holmes SJ, et al. Brain natriuretic peptide: natriuretic and endocrine effects in essential hypertension. J Hypertens. Feb. 1993;11(2):163-70. Exclude: BNP measure not FDA approved. [pmid: 8385176].
Richards AM, Nicholls MG, Yandle TG, et al. Plasma N-terminal pro-brain natriuretic peptide and adrenomedullin: new neurohormonal predictors of left ventricular function and prognosis after myocardial infarction. Circ. May. 1998;97(19):1921-9. Exclude: BNP measure not FDA approved.
Richards AM, Nicholls MG, Yandle TG, et al. Neuroendocrine prediction of left ventricular function and heart failure after acute myocardial infarction. The Christchurch Cardioendocrine Research Group. Heart. Feb. 1999;81(2):114-20. Exclude: BNP measure not FDA approved. [pmid: 9922344].
Richards AM, Doughty R, Nicholls MG, et al. Neurohumoral prediction of benefit from carvedilol in ischemic left ventricular dysfunction. Australia-New Zealand Heart Failure Group. Circ. Feb. 16. 1999;99(6):786-92. Exclude: BNP measure not FDA approved.
Richards AM, Doughty R, Nicholls MG, et al. Plasma N-terminal pro-brain natriuretic peptide and adrenomedullin: Prognostic utility and prediction of benefit from carvedilol in chronic ischemic left ventricular dysfunction. Australia-New Zealand Heart Failure Group. J Am Coll Cardiol. Jun. 1. 2001;37(7):1781-7. Exclude: BNP measure not FDA approved. [pmid: 11401111].
Richards AM, Nicholls MG, Troughton RW, et al. Antecedent hypertension and heart failure after myocardial infarction. J Am Coll Cardiol. 2002;39(7):1182-8. Exclude: BNP measure not FDA approved. [pmid: 11923044].
Richards AM, Nicholls MG, Espiner EA, et al. B-type natriuretic peptides and ejection fraction for prognosis after myocardial infarction. Circ. Jun. 10. 2003;107(22):2786-92. Exclude: BNP measure not FDA approved.
Richards AM. B-type natriuretic peptide-guided therapy for chronic heart failure reduces all-cause mortality compared with usual care but does not affect all-cause hospitalisation or survival free of hospitalisation. Evid Based Med. 2010;15(5):137-8. Exclude: Not a primary study. [pmid: 20688847].
Richards M, Nicholls MG, Espiner EA, et al. Comparison of B-type natriuretic peptides for assessment of cardiac function and prognosis in stable ischemic heart disease. J Am Coll Cardiol. Jan. 3. 2006;47(1):52-60. Exclude: BNP measure not FDA approved. [pmid: 16386664].
Rickard J, Kumbhani DJ, Popovic Z, et al. Characterization of super-response to cardiac resynchronization therapy. Heart Rhythm. 2010;7(7):885-9. Exclude: BNP measure not FDA approved. [pmid: 20382271].
Riemersma M, Dijkstra PU, van Veldhuisen DJ, et al. Mortality and preoperative cardiac function in vascular amputees: An N-terminal pro-brain natriuretic peptide (NT-proBNP) pilot study. Clin Rehabil. Jan. 2008;22(1):56-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18048481].
Rienstra M, Van Gelder IC, van den Berg MP, et al. Natriuretic peptides in patients with atrial fibrillation and advanced chronic heart failure: Determinants and prognostic value of (NT-)ANP and (NT-pro)BNP. Europace. Jul. 2006;8(7):482-7. Exclude: BNP measure not FDA approved. [pmid: 16798760].
Riezebos RK, Ronner E, de Boer BA, et al. Dynamics in N-terminal pro-brain natriuretic peptide concentration in patients with non-ST-elevation acute coronary syndrome. Am Heart J. Dec. 2005;150(6):1255-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16338268].
Riezebos RK, Ronner E, Tijssen JG, et al. NT-ProBNP serum levels reflect severity and extent of ischemia in patients admitted with non-ST-elevation acute coronary syndrome. Acute Card Care. 2006;8(1):51-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16720429].
Riezebos RKL. The value of N-terminal proB-type natriuretic peptide for early identification of myocardial infarction in patients with high-risk non-ST-elevation acute coronary syndromes. Clin Chem Lab Med. 2011;49(8):1359-65. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21692686].
Rifai L, Winters J, Friedman E, et al. Initial description of cerebral oximetry measurement in heart failure patients. Congest Heart Fail. 2012;18(2):85-90. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 22432554].
Ring M, Persson H, Mejhert M, et al. Post-systolic motion in patients with heart failure--A marker of left ventricular dyssynchrony?. Eur J Echocardiogr. Oct. 2007;8(5):352-9. Exclude: BNP measure not FDA approved. [pmid: 16934532].
Ripa R, Ripa S, Pivi PP, et al. Dyspnoea in obese patient: Utility of B.N.P. assay. Progr Nutr. 2004;6(3):155-61. Exclude: Unable to obtain copy.
Ristow B, Ahmed S, Wang L, et al. Pulmonary regurgitation end-diastolic gradient is a doppler marker of cardiac status: Data from the heart and soul study. J Am Soc Echocardiogr. 2005;18(9):885-91. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16153508].
Rivera Otero JM, Talens-Visconti R, Salvador A, et al. Ventricular hypertrophy increases NT-proBNP in subjects with and without hypertension. Int J Cardiol. Aug. 2004;96(2):265-71. Exclude: BNP measure not FDA approved. [pmid: 15262044].
Rivera M, Cortes R, Salvador A, et al. Obese subjects with heart failure have lower N-terminal pro-brain natriuretic peptide plasma levels irrespective of aetiology. Eur J Heart Fail. Dec. 2005;7(7):1168-70. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16084758].
Rivera OM, Talens-Visconti R, Salvador A, et al. NT-proBNP levels and hypertension. Their importance in the diagnosis of heart failure. Rev Esp Cardiol. 2004;57(5):396-402. Exclude: BNP measure not FDA approved. [pmid: 15151773].
Rivers EP, McCord J, Otero R, et al. Clinical utility of B-type natriuretic peptide in early severe sepsis and septic shock. J Intensive Care Med. Nov. 2007;22(6):363-73. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18051697].
Roberts MA, Srivastava PM, Macmillan N, et al. B-type natriuretic peptides strongly predict mortality in patients who are treated with long-term dialysis. Clin J Am Soc Nephrol. Jul. 2008;3(4):1057-65. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18450924].
Rocca HP, Weilenmann D, Rickli H, et al. Is blood pressure response to the Valsalva maneuver related to neurohormones, exercise capacity, and clinical findings in heart failure?. Chest. Oct. 1999;116(4):861-7. Exclude: BNP measure not FDA approved. [pmid: 10531144].
Rocca HP, Weilenmann D, Follath F, et al. Oxygen uptake kinetics during low level exercise in patients with heart failure: Relation to neurohormones, peak oxygen consumption, and clinical findings. Heart. Feb. 1999;81(2):121-7. Exclude: BNP measure not FDA approved. [pmid: 9922345].
Roch A, Allardet-Servent J, Michelet P, et al. NH_2_ terminal pro-brain natriuretic peptide plasma level as an early marker of prognosis and cardiac dysfunction in septic shock patients. Crit Care Med. 2005;33(5):1001-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 15891328].
Rocha AL, Lombardi F, Costa Rocha MO, et al. Chronotropic incompetence and abnormal autonomic modulation in ambulatory Chagas disease patients. Ann Noninvasive Electrocardiol. Jan. 2006;11(1):3-11. Exclude: BNP measure not FDA approved. [pmid: 16472276].
Rogers RK, Collins SP, Kontos MC, et al. Diagnosis and characterization of left ventricular hypertrophy by computerized acoustic cardiography, brain natriuretic peptide, and electrocardiography. J Electrocardiol. Nov. 2008;41(6):518-25. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18804784].
Rogers RK, May HT, Anderson JL, et al. Prognostic value of B-type natriuretic peptide for cardiovascular events independent of left ventricular end-diastolic pressure. Am Heart J. Nov. 2009;158(5):777-83. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19853697].
Rogowski O, Shnizer S, Wolff R, et al. Increased serum levels of oxidative stress are associated with hospital readmissions due to acute heart failure. Cardiol. 2011;118(1):33-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Roldan V, Marin F, Gimeno JR, et al. Matrix metalloproteinases and tissue remodeling in hypertrophic cardiomyopathy. Am Heart J. Jul. 2008;156(1):85-91. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18585501].
Rolfo C, Bobbio M, Brossa C, et al. One year temporal pattern of neurohumoral factors and natriuretic peptides compared with clinical variables in patients with dilated cardiomyopathy. Minerva Cardioangiol. Dec. 2002;50(6):661-5. Exclude: BNP measure not FDA approved. [pmid: 12473986].
Romano S, Necozione S, Guarracini L, et al. Accuracy of N-terminal pro-brain natriuretic peptide in the identification of left ventricular dysfunction in high-risk asymptomatic patients. J Cardiovasc Med. Mar. 2009;10(3):238-44. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Romano S, Di Mauro M, Fratini S, et al. Early diagnosis of left ventricular diastolic dysfunction in diabetic patients: A possible role for natriuretic peptides. Cardiovasc Diabetol. 2010;9(89). Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Romeo R, Scalisi C, Tafuri L, et al. Different characteristics of chronic heart failure (CHF) in elderly diabetics and non-diabetics. Arch Gerontol Geriatr. Jan. 2010;50(1):101-4. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19371958].
Roongsritong C, Sutthiwan P, Bradley J, et al. Spironolactone improves diastolic function in the elderly. Clin Cardiol. Oct. 2005;28(10):484-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16274097].
Rosello-Lleti E, Calabuig JR, Morillas P, et al. Variability of NT-proBNP and its relationship with inflammatory status in patients with stable essential hypertension: A 2-year follow-up study. PLoS ONE. 2012;7(2). Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Rosenberg J, Gustafsson F, Remme WJ, et al. Effect of beta-blockade and ACE inhibition on B-type natriuretic peptides in stable patients with systolic heart failure. Cardiovasc Drugs Ther. Aug. 2008;22(4):305-11. Exclude: BNP measure not FDA approved. [pmid: 18309461].
Rosenberg J, Schou M, Gustafsson F, et al. Prognostic threshold levels of NT-proBNP testing in primary care. Eur Heart J. Jan. 2009;30(1):66-73. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19029123].
Rosenberg MA, Gottdiener JS, Heckbert SR, et al. Echocardiographic diastolic parameters and risk of atrial fibrillation: The Cardiovascular Health Study. Eur Heart J. Apr. 2012;33(7):904-12. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21990265].
Rosjo H, Varpula M, Hagve TA, et al. Circulating high sensitivity troponin T in severe sepsis and septic shock: Distribution, associated factors, and relation to outcome. Intensive Care Med. 2011;37(1):77-85. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20938765].
Rosjo H, Omland T. Glycosylated natriuretic peptides: The cardiologist's new sweetheart?. Heart. 2012;98(2):95-6. Exclude: Not a primary study. [pmid: 21917656].
Rosolova H, Cech J, Simon J, et al. Short to long term mortality of patients hospitalised with heart failure in the Czech Republic--A report from the EuroHeart Failure Survey. Eur J Heart Fail. Aug. 2005;7(5):780-3. Exclude: BNP measure not FDA approved. [pmid: 16051521].
Rossig L, Fichtlscherer S, Heeschen C, et al. The pro-apoptotic serum activity is an independent mortality predictor of patients with heart failure. Eur Heart J. Sep. 2004;25(18):1620-5. Exclude: BNP measure not FDA approved. [pmid: 15351161].
Rostoker G, Griuncelli M, Loridon C, et al. Left-ventricular diastolic dysfunction as a risk factor for dialytic hypotension. Cardiol. 2009;114(2):142-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Rothenbacher D, Koenig W, Brenner H. Comparison of N-terminal pro-B-natriuretic peptide, C-reactive protein, and creatinine clearance for prognosis in patients with known coronary heart disease. Arch Intern Med. Dec. 11. 2006;166(22):2455-60. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17159010].
Rothenburger M, Stypmann J, Bruch C, et al. Aminoterminal B-type pro-natriuretic peptide as a marker of recovery after high-risk coronary artery bypass grafting in patients with ischemic heart disease and severe impaired left ventricular function. J Heart Lung Transplant. May. 2006;25(5):596-602. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16678040].
Rottlaender D, Motloch LJ, Schmidt D, et al. Clinical impact of atrial fibrillation in patients with pulmonary hypertension. PLoS ONE. 2012;7(3). Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Roueff S, Martin E, Chauffert ML, et al. Brain natriuretic peptide variations are linked to volume status in hemodialysis patients. Clin Nephrol. Dec. 2008;70(6):508-13. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19049708].
Rouleau JL, Pfeffer MA, Stewart DJ, et al. Comparison of vasopeptidase inhibitor, omapatrilat, and lisinopril on exercise tolerance and morbidity in patients with heart failure: IMPRESS randomised trial. Lancet. Aug. 2000;356(9230):615-20. Exclude: BNP measure not FDA approved. [pmid: 10968433].
Rousseau MF, Gurne O, Duprez D, et al. Beneficial neurohormonal profile of spironolactone in severe congestive heart failure: Results from the RALES neurohormonal substudy. J Am Coll Cardiol. Nov. 6. 2002;40(9):1596-601. Exclude: BNP measure not FDA approved. [pmid: 12427411].
Roziakova L, Bojtarova E, Mistrik M, et al. Serial measurements of cardiac biomarkers in patients after allogeneic hematopoietic stem cell transplantation. J Exp Clin Canc Res. 2012;31(1). Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Rubaj A, Ruciski P, Rejdak K, et al. Biventricular versus right ventricular pacing decreases immune activation and augments nitric oxide production in patients with chronic heart failure. Eur J Heart Fail. Oct. 2006;8(6):615-20. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16464636].
Ruberg FL, Appelbaum E, Davidoff R, et al. Diagnostic and prognostic utility of cardiovascular magnetic resonance imaging in light-chain cardiac amyloidosis. Am J Cardiol. Feb. 15. 2009;103(4):544-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19195518].
Rubino AS, Onorati F, Santarpino G, et al. Neurohormonal and echocardiographic results after CorCap and mitral annuloplasty for dilated cardiomyopathy. Ann Thorac Surg. Sep. 2009;88(3):719-25. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19699885].
Rubis PD. The prognostic role of exercise echocardiography in heart failure. Kardiol Pol. 2011;69(7):656-63. Exclude: Not in English. [pmid: 21769781].
Ruck A, Gustafsson T, Norrbom J, et al. ANP and BNP but not VEGF are regionally overexpressed in ischemic human myocardium. Biochem Biophys Res Commun. Sep. 10. 2004;322(1):287-91. Exclude: BNP measure not FDA approved. [pmid: 15313204].
Rudiger A, Gasser S, Fischler M, et al. Comparable increase of B-type natriuretic peptide and amino-terminal pro-B-type natriuretic peptide levels in patients with severe sepsis, septic shock, and acute heart failure. Crit Care Med. Aug. 2006;34(8):2140-4. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16763507].
Rudiger A, Fischler M, Harpes P, et al. In critically ill patients, B-type natriuretic peptide (BNP) and N-terminal pro-BNP levels correlate with C-reactive protein values and leukocyte counts. Int J Cardiol. May. 7. 2008;126(1):28-31. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17477984].
Rudolph V, Rudolph TK, Hennings JC, et al. Activation of polymorphonuclear neutrophils in patients with impaired left ventricular function. Free Radic Biol Med. Oct. 15. 2007;43(8):1189-96. Exclude: BNP measure not FDA approved. [pmid: 17854714].
Ruff CT, Morrow DA, Jarolim P, et al. Evaluation of NT-proBNP and high sensitivity C-reactive protein for predicting cardiovascular risk in patients with arthritis taking longterm nonsteroidal antiinflammatory drugs. J Rheumatol. Jun. 2011;38(6):1071-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21459935].
Ruggiero F, Santini L, Gallagher MM, et al. Changes in brain natriuretic peptide level as a predictor of AF recurrence after electrical cardioversion. Minerva Cardioangiol. Apr. 2011;59(2):135-8. Exclude: BNP measure not FDA approved. [pmid: 21368733].
Rutten FH, Moons KG, Cramer MJ, et al. Recognising heart failure in elderly patients with stable chronic obstructive pulmonary disease in primary care: Cross sectional diagnostic study. BMJ. Dec. 10. 2005;331(7529):1379. Exclude: BNP measure not FDA approved. [pmid: 16321994].
Rutten FH, Cramer MJ, Zuithoff NPA, et al. Comparison of B-type natriuretic peptide assays for identifying heart failure in stable elderly patients with a clinical diagnosis of chronic obstructive pulmonary disease. Eur J Heart Fail. 2007;9(6-7):651-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17347037].
Rutten JH, Steyerberg EW, Boomsma F, et al. N-terminal pro-brain natriuretic peptide testing in the emergency department: Beneficial effects on hospitalization, costs, and outcome. Am Heart J. Jul. 2008;156(1):71-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18585499].
Rutten JH, van d V, van der Cammen TJ, et al. Associations between plasma natriuretic peptides and echocardiographic abnormalities in geriatric outpatients. Arch Gerontol Geriatr. Sep. 2008;47(2):189-99. Exclude: BNP measure not FDA approved. [pmid: 17900714].
Rutten JH, Mattace-Raso FU, Steyerberg EW, et al. Amino-terminal pro-B-type natriuretic peptide improves cardiovascular and cerebrovascular risk prediction in the population: The Rotterdam study. Hypertens. Mar. 2010;55(3):785-91. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Rutten JH, Mattace-Raso FU, Verwoert GC, et al. Arterial stiffness as determinant of increased amino terminal pro-B-type natriuretic peptide levels in individuals with and without cardiovascular disease--the Rotterdam Study. J Hypertens. Oct. 2010;28(10):2061-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20844371].
Rychli K, Niessner A, Hohensinner PJ, et al. Prognostic value of pigment epithelium-derived factor in patients with advanced heart failure. Chest. Sep. 2010;138(3):656-64. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20435653].
Ryder M, Murphy NF, McCaffrey D, et al. Outpatient intravenous diuretic therapy; potential for marked reduction in hospitalisations for acute decompensated heart failure. Eur J Heart Fail. Mar. 2008;10(3):267-72. Exclude: BNP measure not FDA approved. [pmid: 18308632].
Sa LA, Rassi S, Batista MA. Conventional ventricular stimulation effects on patients with normal ventricular function. Arq Bras Cardiol. Aug. 2009;93(2):167-73. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19838495].
Sabatasso S, Vaucher P, Augsburger M, et al. Sensitivity and specificity of NT-proBNP to detect heart failure at post mortem examination. Int J Legal Med. Nov. 2011;125(6):849-56. Exclude: Population aged under 18. [pmid: 21597901].
Sabatine MS, Morrow DA, de Lemos JA, et al. Multimarker approach to risk stratification in non-ST elevation acute coronary syndromes: Simultaneous assessment of troponin I, C-reactive protein, and B-type natriuretic peptide. Circ. Apr. 16. 2002;105(15):1760-3. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Sabatine MS, Morrow DA, Higgins LJ, et al. Complementary roles for biomarkers of biomechanical strain ST2 and N-terminal prohormone B-type natriuretic peptide in patients with ST-elevation myocardial infarction. Circ. Apr. 15. 2008;117(15):1936-44. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Sachdeva A, Horwich TB, Fonarow GC. Comparison of usefulness of each of five predictors of mortality and urgent transplantation in patients with advanced heart failure. Am J Cardiol. Sep. 15. 2010;106(6):830-5. Exclude: BNP measure not FDA approved. [pmid: 20816124].
Sadanaga T, Yoshimura M, Sakamoto T, et al. Enalapril-induced cough is associated with non-severe heart failure. Int J Cardiol. 2009;135(2):275-6. Exclude: BNP measure not FDA approved. [pmid: 18606471].
Sadanaga T, Kohsaka S, Mitamura H, et al. Elevated B-type natriuretic peptide level as a marker of subsequent thromboembolic events in patients with atrial fibrillation. Heart Ves. Sep. 2011;26(5):530-5. Exclude: BNP measure not FDA approved.
Sadanandan S, Cannon CP, Chekuri K, et al. Association of elevated B-type natriuretic peptide levels with angiographic findings among patients with unstable angina and non-ST-segment elevation myocardial infarction. J Am Coll Cardiol. Aug. 4. 2004;44(3):564-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 15358021].
Saeki T, Wakami K, Morimoto K, et al. Combination of low-dose trichlormethiazide with conventional-dose furosemide promotes natriuresis in patients with refractory heart failure. Therapeut Res. 2009;30(1):101-6. Exclude: Not a primary study.
Safranow K, Dziedziejko V, Rzeuski R, et al. Plasma concentrations of TNF-alpha and its soluble receptors sTNFR1 and sTNFR2 in patients with coronary artery disease. Tissue Antigens. Nov. 2009;74(5):386-92. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19845893].
Sahlen A, Winter R, Lind B, et al. Magnitude, reproducibility, and association with baseline cardiac function of cardiac biomarker release in long-distance runners aged > or =55 years. Am J Cardiol. Jul. 15. 2008;102(2):218-22. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18602525].
Sahu A, Gupta T, Kavishwar A, et al. Diagnostic role of NT pro BNP in diabetes type 2 patients associated with cardiovascular disease risk, a study from central India. J Med. 2010;11(1):33-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Sakai H, Tsutamoto T, Tsutsui T, et al. Serum level of uric acid, partly secreted from the failing heart, is a prognostic marker in patients with congestive heart failure. Circ J. Aug. 2006;70(8):1006-11. Exclude: BNP measure not FDA approved. [pmid: 16864933].
Sakai H, Tsutamoto T, Ishikawa C, et al. Direct comparison of brain natriuretic peptide (BNP) and N-terminal pro-BNP secretion and extent of coronary artery stenosis in patients with stable coronary artery disease. Circ J. Apr. 2007;71(4):499-505. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17384449].
Sakakibara M, Sakata Y, Usui K, et al. Effectiveness of short-term treatment with nocturnal oxygen therapy for central sleep apnea in patients with congestive heart failure. J Cardiol. 2005;46(2):53-61. Exclude: BNP measure not FDA approved. [pmid: 16127894].
Sakata K, Iida K, Mochiduki N, et al. Brain natriuretic peptide (BNP) level is closely related to the extent of left ventricular sympathetic overactivity in chronic ischemic heart failure. Intern Med. 2009;48(6):393-400. Exclude: BNP measure not FDA approved. [pmid: 19293536].
Sakatani T, Hadase M, Kawasaki T, et al. Usefulness of the percentage of plasma lymphocytes as a prognostic marker in patients with congestive heart failure. Jpn Heart J. Mar. 2004;45(2):275-84. Exclude: BNP measure not FDA approved. [pmid: 15090704].
Sakr A, Hahn P, Donohue T, et al. Nesiritide in the initial management of acute decompensated congestive heart failure. Connecticut Medicine. Oct. 2008;72(9):517-23. Exclude: BNP measure not FDA approved. [pmid: 18833867].
Sakuma M, Nakamura M, Tanaka F, et al. Plasma B-type natriuretic peptide level and cardiovascular events in chronic kidney disease in a community-based population. Circ J. Mar. 25. 2010;74(4):792-7. Exclude: BNP measure not FDA approved. [pmid: 20160392].
Sakuragi S, Maruo T, Taniguchi M, et al. Radial augmentation index associated with increase in B-type natriuretic peptide in patients with hypertension. Int J Cardiol. Nov. 28. 2008;130(3):414-9. Exclude: BNP measure not FDA approved. [pmid: 18177956].
Sakurai S, Adachi H, Hasegawa A, et al. Brain natriuretic peptide facilitates severity classification of stable chronic heart failure with left ventricular dysfunction. Heart. Jun. 2003;89(6):661-2. Exclude: BNP measure not FDA approved. [pmid: 12748228].
Sallach JA, Tang WHW, Borowski AG, et al. Right atrial volume index in chronic systolic heart failure and prognosis. JACC Cardiovasc Imaging. 2009;2(5):527-34. Exclude: BNP measure not FDA approved. [pmid: 19442936].
Sambanis C, Tziomalos K, Kountana E, et al. Effect of pioglitazone on heart function and N-terminal pro-brain natriuretic peptide levels of patients with type 2 diabetes. Acta Diabetol. Mar. 2008;45(1):23-30. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17768592].
Samuels LE, Holmes EC, Lee L. Nesiritide as an adjunctive therapy in adult patients with heart failure undergoing high-risk cardiac surgery. J Thorac Cardiovasc Surg. Oct. 2004;128(4):627-9. Exclude: BNP measure not FDA approved. [pmid: 15457170].
Sanada S, Asanuma H, Koretsune Y, et al. Long-term oral administration of dipyridamole improves both cardiac and physical status in patients with mild to moderate chronic heart failure: a prospective open-randomized study. Hypertens Res. Oct. 2007;30(10):913-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18049022].
Sanchez O, Trinquart L, Caille V, et al. Prognostic factors for pulmonary embolism: the prep study, a prospective multicenter cohort study. Am J Respir Crit Care Med. Jan. 15. 2010;181(2):168-73. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19910608].
Sanchis J, Bosch X, Bodi V, et al. Combination of clinical risk profile, early exercise testing and circulating biomarkers for evaluation of patients with acute chest pain without ST-segment deviation or troponin elevation. Heart. Mar. 2008;94(3):311-5. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17639094].
Sanderson JE, Chan WW, Hung YT, et al. Effect of low dose beta blockers on atrial and ventricular (B type) natriuretic factor in heart failure: A double blind, randomised comparison of metoprolol and a third generation vasodilating beta blocker. Br Heart J. Nov. 1995;74(5):502-7. Exclude: BNP measure not FDA approved. [pmid: 8562234].
Sandri MT, Salvatici M, Cardinale D, et al. N-terminal pro-B-type natriuretic peptide after high-dose chemotherapy: A marker predictive of cardiac dysfunction?. Clin Chem. Aug. 2005;51(8):1405-10. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 15932966].
Santilli F, Davi G, Basili S, et al. Thromboxane and prostacyclin biosynthesis in heart failure of ischemic origin: Effects of disease severity and aspirin treatment. J Thromb Haemostasis. May. 2010;8(5):914-22. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20180823].
Santosa YP, Tjandrawati A, Noormartany, et al. Comparison of pro B-natriuretic peptide in hypertensive patients with and without diastolic dysfunction. Acta Med Indonesiana. Jan. 2008;40(1):19-23. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Sargento L, Brito D, Matias JS, et al. Evaluation of the clinical, hemodynamic and neurohormonal response to levosimendan administration in decompensated heart failure patients. One-month follow-up. Rev Port Cardiol. Jul. 2007;26(7-8):717-26. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17939581].
Saribulbul O, Alat I, Coskun S, et al. The role of brain natriuretic peptide in the prediction of cardiac performance in coronary artery bypass grafting. Tex Heart Inst J. 2003;30(4):298-304. Exclude: BNP measure not FDA approved. [pmid: 14677740].
Sartipy U, Albage A, Larsson PT, et al. Changes in B-type natriuretic peptides after surgical ventricular restoration. Eur J Cardiothorac Surg. May. 2007;31(5):922-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17321144].
Sarullo FM, Gristina T, Brusca I, et al. Usefulness of N-terminal pro-B-type natriuretic peptide levels in predicting residual myocardial ischemia in patients with ST elevation acute myocardial infarction. Minerva Cardioangiol. 2007;55(2):149-55. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17342035].
Sarullo FM, Fazio G, Puccio D, et al. Impact of “off-Label” Use of ivabradine on exercise capacity, gas exchange, functional class, quality of life, and neurohormonal modulation in patients with ischemic chronic heart failure. J Cardiovasc Pharmacol Ther. 2010;15(4):349-55. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20940450].
Sasaki T, Kubo T, Satomi K. Clinical experience on long-term treatment with pimobendan for chronic moderate heart failure. Effects on quality of life, exercise capacity and neurohormonal factors. Therapeut Res. 1997;18(4):331-9. Exclude: Not in English.
Sasaki T, Miyamoto T, Nakatani D. Clinical experience with application of pimobendan during titration of beta-blocker therapy to four patients with idiopathic dilated cardiomyopathy. Therapeut Res. 1999;20(3):259-66. Exclude: Not in English.
Sasaki T, Kubo T, Komamura K, et al. Effects of long-term treatment with pimobendan on neurohumoral factors in patients with non-ischemic chronic moderate heart failure. J Cardiol. Jun. 1999;33(6):317-25. Exclude: BNP measure not FDA approved. [pmid: 10396705].
Sasaki T, Kubo T, Miyamoto T, et al. Left atrial function preserves pulmonary circulatory pressure during pacing-tachycardia and contributes to exercise capacity in patients with idiopathic dilated cardiomyopathy in sinus rhythm, whose exercise is limited by dyspnea. Circ J. Oct. 2002;66(10):937-42. Exclude: BNP measure not FDA approved. [pmid: 12381089].
Sasaki T, Noda Y, Yasuoka Y, et al. Comparison of the effects of telmisartan and olmesartan on home blood pressure, glucose, and lipid profiles in patients with hypertension, chronic heart failure, and metabolic syndrome. Hypertens Res. May. 2008;31(5):921-9. Exclude: BNP measure not FDA approved. [pmid: 18712048].
Sato A, Hiroe M, Akiyama D, et al. Prognostic value of serum tenascin-C levels on long-term outcome after acute myocardial infarction. J Card Fail. 2012;18(6):480-6. Exclude: BNP measure not FDA approved. [pmid: 22633306].
Sato T, Tsujino I, Ohira H, et al. Right atrial late gadolinium enhancement on cardiac magnetic resonance imaging in pulmonary hypertension. Circ J. 2012;76(1):238-9. Exclude: Not a primary study. [pmid: 21881246].
Sato Y, Nishi K, Taniguchi R, et al. In patients with heart failure and non-ischemic heart disease, cardiac troponin T is a reliable predictor of long-term echocardiographic changes and adverse cardiac events. J Cardiol. Oct. 2009;54(2):221-30. Exclude: BNP measure not FDA approved. [pmid: 19782259].
Sato Y, Miyamoto T, Taniguchi R, et al. The clinical and hemodynamic factors that influence the concentrations of biomarkers of myocyte injury measured by high sensitive assay PATHFAST. J Cardiol. 2009;53(1):20-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19167634].
Satyan S, Light RP, Agarwal R. Relationships of N-terminal pro-B-natriuretic peptide and cardiac troponin T to left ventricular mass and function and mortality in asymptomatic hemodialysis patients. Am J Kidney Dis. Dec. 2007;50(6):1009-19. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18037101].
Sauer J, Rabelo ER, Castro RA, et al. Nurses' performance in classifying heart failure patients based on physical exam: Comparison with cardiologist's physical exam and levels of N-terminal pro-B-type natriuretic peptide. J Clin Nurs. Dec. 2010;19(23/24):3381-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20964749].
Saura D, Marin F, Climent V, et al. Left atrial remodelling in hypertrophic cardiomyopathy: relation with exercise capacity and biochemical markers of tissue strain and remodelling. Int J Clin Pract. Oct. 2009;63(10):1465-71. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19769703].
Sav T, Inanc MT, Dogan A, et al. Two daytime icodextrin exchanges decrease brain natriuretic peptide levels and improve cardiac functions in continuous ambulatory peritoneal dialysis patients. Nephrology. 2010;15(3):307-12. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20470299].
Savioli NF, Magalhaes HM, Batlouni M, et al. ACE inhibitors and plasma B-type natriuretic peptide levels in elderly patients with heart failure. Arq Bras Cardiol. 2009;92(5):320-6. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Sayama H, Nakamura Y, Saito N, et al. Why is the concentration of plasma brain natriuretic peptide in elderly inpatients greater than normal?. Coron Artery Dis. Oct. 1999;10(7):537-40. Exclude: BNP measure not FDA approved. [pmid: 10562924].
Scardovi AB, Coletta C, Aspromonte N, et al. Relationship between B-type natriuretic peptide levels and ventilatory response during cardiopulmonary exercise test in patients with chronic heart failure. Minerva Cardioangiol. Aug. 2005;53(4):313-20. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16177675].
Scardovi AB, De Maria R, Colettat C, et al. Brain natriuretic peptide is a reliable indicator of ventilatory abnormalities during cardiopulmonary exercise test in heart failure patients. Med Sci Monit. May. 2006;12(5):CR191-5. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16641874].
Scardovi AB, Coletta C, Aspromonte N, et al. Brain natriuretic peptide plasma level is a reliable indicator of advanced diastolic dysfunction in patients with chronic heart failure. Eur J Echocardiogr. Jan. 2007;8(1):30-6. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16476572].
Schachner T, Wiedemann D, Fetz H, et al. Influence of preoperative serum N-terminal pro-brain type natriuretic peptide on the postoperative outcome and survival rates of coronary artery bypass patients. Clinics. 2010;65(12):1239-45. Exclude: BNP measure not FDA approved. [pmid: 21340210].
Scharhag J, Herrmann M, Urhausen A, et al. Independent elevations of N-terminal pro-brain natriuretic peptide and cardiac troponins in endurance athletes after prolonged strenuous exercise. Am Heart J. Dec. 2005;150(6):1128-34. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16338248].
Schaub N, Reichlin T, Twerenbold R, et al. Growth differentiation factor-15 in the early diagnosis and risk stratification of patients with acute chest pain. Clin Chem. Feb. 2012;58(2):441-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 22205695].
Schaufelberger M, Bergh CH, Caidahl K, et al. Can brain natriuretic peptide (BNP) be used as a screening tool in general practice?. Scand J Prim Health Care. Sep. 2004;22(3):187-90. Exclude: BNP measure not FDA approved. [pmid: 15370797].
Schenk S, McCarthy PM, Starling RC, et al. Neurohormonal response to left ventricular reconstruction surgery in ischemic cardiomyopathy. J Thorac Cardiovasc Surg. Jul. 2004;128(1):38-43. Exclude: BNP measure not FDA approved. [pmid: 15224019].
Schinkel AF, Vourvouri EC, Bax JJ, et al. Relation between left ventricular contractile reserve during low dose dobutamine echocardiography and plasma concentrations of natriuretic peptides. Heart. Mar. 2004;90(3):293-6. Exclude: BNP measure not FDA approved. [pmid: 14966050].
Schmitt M, Qasem A, McEniery C, et al. Role of natriuretic peptides in regulation of conduit artery distensibility. Am J Physiol Heart Circ Physiol. Sep. 2004;287(3):H1167-71. Exclude: Non-human population. [pmid: 15317675].
Schmitt M, Gunaruwan P, Payne N, et al. Effects of exogenous and endogenous natriuretic peptides on forearm vascular function in chronic heart failure. Arterioscler Thromb Vasc Biol. May. 2004;24(5):911-7. Exclude: BNP measure not FDA approved. [pmid: 15001459].
Schnabel R, Rupprecht HJ, Lackner KJ, et al. Analysis of N-terminal-pro-brain natriuretic peptide and C-reactive protein for risk stratification in stable and unstable coronary artery disease: results from the AtheroGene study. Eur Heart J. Feb. 2005;26(3):241-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 15618051].
Schnabel R, Blankenberg S, Lubos E, et al. Asymmetric dimethylarginine and the risk of cardiovascular events and death in patients with coronary artery disease: Results from the AtheroGene Study. Circ Res. Sep. 2. 2005;97(5):e53-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16100045].
Schnabel R, Lubos E, Rupprecht HJ, et al. B-type natriuretic peptide and the risk of cardiovascular events and death in patients with stable angina: Results from the AtheroGene study. J Am Coll Cardiol. Feb. 7. 2006;47(3):552-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16458135].
Schnabel R, Messow CM, Lubos E, et al. Association of adiponectin with adverse outcome in coronary artery disease patients: Results from the AtheroGene study. Eur Heart J. Mar. 2008;29(5):649-57. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18263867].
Schnabel RB, Larson MG, Yamamoto JF, et al. Relations of biomarkers of distinct pathophysiological pathways and atrial fibrillation incidence in the community. Circ. Jan. 19. 2010;121(2):200-7. Exclude: BNP measure not FDA approved.
Schneider HG, Lam L, Lokuge A, et al. B-type natriuretic peptide testing, clinical outcomes, and health services use in emergency department patients with dyspnea: A randomized trial. Ann Intern Med. 2009;150(6):365-71. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19293069].
Schoen SP, Zimmermann T, Kittner T, et al. NT-proBNP correlates with right heart haemodynamic parameters and volumes in patients with atrial septal defects. Eur J Heart Fail. 2007;9(6-7):660-6. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17347036].
Schou M, Gustafsson F, Kistorp CN, et al. Effects of body mass index and age on N-terminal pro brain natriuretic peptide are associated with glomerular filtration rate in chronic heart failure patients. Clin Chem. Nov. 2007;53(11):1928-35. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17872942].
Schou M, Gustafsson F, Videbaek L, et al. Design and methodology of the NorthStar Study: NT-proBNP stratified follow-up in outpatient heart failure clinics -- A randomized Danish multicenter study. Am Heart J. Oct. 2008;156(4):649-55. Exclude: Not a primary study. [pmid: 18946891].
Schou M, Alehagen U, Goetze JP, et al. Effect of estimated glomerular filtration rate on plasma concentrations of B-type natriuretic peptides measured with multiple immunoassays in elderly individuals. Heart. Sep. 2009;95(18):1514-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19570761].
Schouten O, Hoeks SE, Goei D, et al. Plasma N-terminal pro-B-type natriuretic peptide as a predictor of perioperative and long-term outcome after vascular surgery. J Vasc Surg. 2009;49(2):435-42. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19028043].
Schultz M, Faber J, Kistorp C, et al. N-terminal-pro-B-type natriuretic peptide (NT-pro-BNP) in different thyroid function states. Clin Endocrinol. Jan. 2004;60(1):54-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Schultz M, Kistorp C, Langdahl B, et al. N-terminal-pro-B-type natriuretic peptide in acute hyperthyroidism. Thyroid. Mar. 2007;17(3):237-41. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17381357].
Schultz M, Kistorp C, Raymond I, et al. Cardiovascular events in thyroid disease: A population based, prospective study. Horm Metab Res. Aug. 2011;43(9):653-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21823062].
Schulze PC, Biolo A, Gopal D, et al. Dynamics in insulin resistance and plasma levels of adipokines in patients with acute decompensated and chronic stable heart failure. J Card Fail. Dec. 2011;17(12):1004-11. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 22123363].
Schunemann HJM. Rapid measurement of B-type natriuretic peptides reduced time to discharge and treatment costs in patients with acute dyspnea. ACP J Club. Jan. 2005;142(1):A14. Exclude: Not a primary study.
Schutt RC, Cevik C, Phy MP. Plasma N-terminal prohormone brain natriuretic peptide as a marker for postoperative cardiac events in high-risk patients undergoing noncardiac surgery. Am J Cardiol. Jul. 1. 2009;104(1):137-40. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19576335].
Schwarz ER, Najam S, Akel R, et al. Intermittent outpatient nesiritide infusion reduces hospital admissions in patients with advanced heart failure. J Cardiovasc Pharmacol Ther. Sep. 2007;12(3):232-6. Exclude: BNP measure not FDA approved. [pmid: 17875951].
Schwarzwalder U, Hauk M, Zeller T. RADAR - A randomised, multi-centre, prospective study comparing best medical treatment versus best medical treatment plus renal artery stenting in patients with haemodynamically relevant atherosclerotic renal artery stenosis. Trials. 2009;10(60). Exclude: BNP measure not FDA approved.
Scirica BM, Morrow DA, Cannon CP, et al. Intensive statin therapy and the risk of hospitalization for heart failure after an acute coronary syndrome in the PROVE IT-TIMI 22 study. J Am Coll Cardiol. Jun. 6. 2006;47(11):2326-31. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16750703].
Scirica BM, Cannon CP, Sabatine MS, et al. Concentrations of C-reactive protein and B-type natriuretic peptide 30 days after acute coronary syndromes independently predict hospitalization for heart failure and cardiovascular death. Clin Chem. Feb. 2009;55(2):265-73. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19074516].
Scirica BM, Morrow DA, Bode C, et al. Patients with acute coronary syndromes and elevated levels of natriuretic peptides: The results of the AVANT GARDE-TIMI 43 trial. Eur Heart J. 2010;31(16):1993-2005. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20558431].
Scirica BMS. Assessment of multiple cardiac biomarkers in non-ST-segment elevation acute coronary syndromes: Observations from the MERLIN-TIMI 36 Trial. Eur Heart J. 2011;32(6):697-705. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21183500].
Scolletta S, Ranaldi G, Carlucci F, et al. Relationship between N-terminal pro-B-type natriuretic peptide (Nt-proBNP) and cardiac cycle efficiency in cardiac surgery. Biomed Pharmacother. Oct. 2010;64(8):511-5. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20137881].
Secchiero P, Corallini F, Ceconi C, et al. Potential prognostic significance of decreased serum levels of TRAIL after acute myocardial infarction. PLoS ONE. 2009;4(2):e4442. Exclude: BNP measure not FDA approved. [pmid: 19221598].
Sedlak TL, Chandavimol M, Calleja A, et al. The ability of heart failure specialists to accurately predict NT-proBNP levels based on clinical assessment and a previous NT-proBNP measurement. Open Cardiovasc Med J. 2008;2:36-40. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18949097].
Seed A, Gardner R, McMurray J, et al. Neurohumoral effects of the new orally active renin inhibitor, aliskiren, in chronic heart failure. Eur J Heart Fail. Nov. 2007;9(11):1120-7. Exclude: BNP measure not FDA approved. [pmid: 17945530].
Segawa T, Nakamura M, Itai K, et al. Plasma B-type natriuretic peptide levels and risk factors for congestive heart failure in a Japanese general population. Int Heart J. May. 2005;46(3):465-75. Exclude: BNP measure not FDA approved. [pmid: 16043942].
Seifert M, Schlegl M, Hoersch W, et al. Functional capacity and changes in the neurohormonal and cytokine status after long-term CRT in heart failure patients. Int J Cardiol. Sep. 14. 2007;121(1):68-73. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17582527].
Seiler S, Cremers B, Rebling NM, et al. The phosphatonin fibroblast growth factor 23 links calcium-phosphate metabolism with left-ventricular dysfunction and atrial fibrillation. Eur Heart J. Nov. 2011;32(21):2688-96. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21733911].
Seino Y, Ogawa A, Yamashita T, et al. Application of NT-proBNP and BNP measurements in cardiac care: A more discerning marker for the detection and evaluation of heart failure. Eur J Heart Fail. Mar. 15. 2004;6(3):295-300. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 14987579].
Seki S, Tsurusaki T, Kasai T, et al. Clinical significance of B-type natriuretic Peptide in the assessment of untreated hypertension. Circ J. May. 2008;72(5):770-7. Exclude: BNP measure not FDA approved. [pmid: 18441458].
Sekiguchi Y, Aonuma K, Yamauchi Y, et al. Chronic hemodynamic effects after radiofrequency catheter ablation of frequent monomorphic ventricular premature beats. J Cardiovasc Electrophysiol. Oct. 2005;16(10):1057-63. Exclude: BNP measure not FDA approved. [pmid: 16191115].
Selejan SR, Poss J, Hewera L, et al. Role of receptor for advanced glycation end products in cardiogenic shock. Crit Care Med. May. 2012;40(5):1513-22. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 22430238].
Seljeflot I, Nilsson BB, Westheim AS, et al. The L-arginine-asymmetric dimethylarginine ratio is strongly related to the severity of chronic heart failure. No effects of exercise training. J Card Fail. 2011;17(2):135-42. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21300303].
Selvais PL, Donckier JE, Robert A, et al. Cardiac natriuretic peptides for diagnosis and risk stratification in heart failure: Influences of left ventricular dysfunction and coronary artery disease on cardiac hormonal activation. Eur J Clin Invest. Aug. 1998;28(8):636-42. Exclude: BNP measure not FDA approved. [pmid: 9767358].
Selvais PL, Robert A, Ahn S, et al. Direct comparison between endothelin-1, N-terminal proatrial natriuretic factor, and brain natriuretic peptide as prognostic markers of survival in congestive heart failure. J Card Fail. Sep. 2000;6(3):201-7. Exclude: BNP measure not FDA approved. [pmid: 10997745].
Seo Y, Ishizu T, Kawano S, et al. Combined approach with Doppler echocardiography and B-type natriuretic peptide to stratify prognosis of patients with decompensated systolic heart failure. J Cardiol. Dec. 2008;52(3):224-31. Exclude: BNP measure not FDA approved. [pmid: 19027600].
Serebruany VL, McKenzie ME, Meister AF, et al. Failure of platelet parameters and biomarkers to correlate platelet function to severity and etiology of heart failure in patients enrolled in the EPCOT trial. With special reference to the Hemodyne hemostatic analyzer. Whole Blood Impedance Aggregometry for the Assessment of Platelet Function in Patients with Congestive Heart Failure. Pathophysiol Haemost Thromb. Jan. 2002;32(1):8-15. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 12214158].
Seto E, Leonard KJ, Cafazzo JA, et al. Mobile phone-based telemonitoring for heart failure management: A randomized controlled trial. Journal of Medical Internet Research. 2012;14(1):e31. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 22356799].
Setsuta K, Seino Y, Ogawa T, et al. Use of cytosolic and myofibril markers in the detection of ongoing myocardial damage in patients with chronic heart failure. Am J Med. 2002;113(9):717-22. Exclude: BNP measure not FDA approved. [pmid: 12517360].
Setsuta K, Kitahara Y, Arae M, et al. Elevated cardiac troponin T predicts adverse outcomes in hypertensive patients. Int Heart J. 2011;52(3):164-9. Exclude: BNP measure not FDA approved. [pmid: 21646739].
Severo M, Pereira M, Bettencourt P, et al. B-type natriuretic peptide measured in serum--Calibration using plasma samples for research purposes. Clin Lab. 2011;57(11-12):1015-9. Exclude: Unable to obtain copy. [pmid: 22239036].
Sevimli S, Yilmaz M, Kiziltunc A, et al. The effect of carvedilol on big endothelin, atrial and brain natriuretic peptide levels in patients with congestive heart failure. Turk Kardiyol Dern Ars. 2007;35(7):412-6. Exclude: BNP measure not FDA approved.
Seyfert H, Bohlscheid V, Wendt T. Are troponin measurements in addition to determination of natriuretic peptides useful for assessment of fitness for work and earning capacity in patients with cardiac diseases?. Pravent Rehabil. Jan. 2010;22(1):9-11. Exclude: Not in English.
Seyhan EC, Altin S, Cetinkaya E, et al. The importance of pleural fluid and serum NT-proBNP levels in differentiating pleural effusion due to heart failure from other causes of effusion. Intern Med. 2009;48(5):287-93. Exclude: Not a primary study. [pmid: 19252349].
Sezai A, Hata M, Niino T, et al. Continuous low-dose infusion of human atrial natriuretic peptide in patients with left ventricular dysfunction undergoing coronary artery bypass grafting. The NU-HIT (Nihon University working group study of low-dose Human ANP Infusion Therapy during cardiac surgery) for left ventricular dysfunction. J Am Coll Cardiol. 2010;55(17):1844-51. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20413036].
Shadman R, Allison MA, Criqui MH. Glomerular filtration rate and N-terminal pro-brain natriuretic peptide as predictors of cardiovascular mortality in vascular patients. J Am Coll Cardiol. Jun. 5. 2007;49(22):2172-81. Exclude: BNP measure not FDA approved. [pmid: 17543637].
Shah K, Terracciano GJ, Jiang K, et al. Comparability of results between point-of-care and automated instruments to measure B-type natriuretic peptide. West J Emerg Med. Feb. 2010;11(1):44-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20411075].
Shah KB, Nolan MM, Rao K, et al. The characteristics and prognostic importance of NT-ProBNP concentrations in critically ill patients. Am J Med. Dec. 2007;120(12):1071-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18060928].
Shah KB, Kop WJ, Christenson RH, et al. Post-discharge changes in NT-proBNP and quality of life after acute dyspnea hospitalization as predictors of one-year outcomes. Clin Biochem. 2010;43(18):1405-10. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20850426].
Shah RV, Chen-Tournoux AA, Picard MH, et al. Galectin-3, cardiac structure and function, and long-term mortality in patients with acutely decompensated heart failure. Eur J Heart Fail. 2010;12(8):826-32. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20525986].
Shah SJ, Marcus GM, Gerber IL, et al. High-sensitivity C-reactive protein and parameters of left ventricular dysfunction. J Card Fail. Feb. 2006;12(1):61-5. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16500582].
Shah SJ, Michaels AD. Acute effects of intravenous nesiritide on cardiac contractility in heart failure. J Card Fail. 2010;16(9):720-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20797595].
Shahin HS, Bigi MB, Aslani A, et al. Effect of professional exercises on brain natriuretic peptide. Iran Cardiovasc Res J. 2009;3(4):213-6. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Shapiro M, Moyers B, Marcus GM, et al. Diagnostic characteristics of combining phonocardiographic third heart sound and systolic time intervals for the prediction of left ventricular dysfunction. J Card Fail. Feb. 2007;13(1):18-24. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17338999].
Sharma AH. Choosing the NT-proBNP cut-off for use as part of a community heart failure care pathway. Prim Care Cardiovasc J. 2011;4(1):29-31. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Sharp RP, Gregory A, Mowdy MH, et al. Nesiritide for treatment of heart failure due to right ventricular dysfunction. Pharmacotherapy. Sep. 2004;24(9):1236-40. Exclude: BNP measure not FDA approved. [pmid: 15460186].
Shearer D, Mahon R. Brain natriuretic peptide levels in six basic underwater demolitions/SEAL recruits presenting with swimming induced pulmonary edema (SIPE). J Special Op Med. 2009;9(3):44-50. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Sheen V, Bhalla V, Tulua-Tata A, et al. The use of B-type natriuretic peptide to assess volume status in patients with end-stage renal disease. Am Heart J. Feb. 2007;153(2):244-5. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17239684].
Sheer TA, Joo E, Runyon BA. Usefulness of serum N-terminal-ProBNP in distinguishing ascites due to cirrhosis from ascites due to heart failure. J Clin Gastroenterol. Jan. 2010;44(1):e23-6. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19448570].
Shehab AMA, MacFadyen RJ, McLaren M, et al. Sudden unexpected death in heart failure may be preceded by short term, intraindividual increases in inflammation and in autonomic dysfunction: A pilot study. Heart. 2004;90(11):1263-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 15486117].
Shelton RJ, Clark AL, Goode K, et al. A randomised, controlled study of rate versus rhythm control in patients with chronic atrial fibrillation and heart failure: (CAFE-II Study). Heart. Jun. 2009;95(11):924-30. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19282313].
Shenkman HJ, Zareba W, Bisognano JD. Comparison of prognostic significance of amino-terminal pro-brain natriuretic peptide versus blood urea nitrogen for predicting events in patients hospitalized for heart failure. Am J Cardiol. Apr. 15. 2007;99(8):1143-5. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17437744].
Sherif MA, Abdel-Wahab M, Awad O, et al. Early hemodynamic and neurohormonal response after transcatheter aortic valve implantation. Am Heart J. Nov. 2010;160(5):862-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21095273].
Sheth T, Parker T, Block A, et al. Comparison of the effects of omapatrilat and lisinopril on circulating neurohormones and cytokines in patients with chronic heart failure. Am J Cardiol. Sep. 1. 2002;90(5):496-500. Exclude: BNP measure not FDA approved. [pmid: 12208409].
Shi X, Xu G, Xia T, et al. N-terminal-pro-B-type natriuretic peptide (NT-proBNP): Reference range for Chinese apparently healthy people and clinical performance in Chinese elderly patients with heart failure. Clin Chim Acta. Oct. 2005;360(1-2):122-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16002063].
Shiba N, Watanabe J, Shinozaki T, et al. Analysis of chronic heart failure registry in the Tohoku district: Third year follow-up. Circ J. May. 2004;68(5):427-34. Exclude: BNP measure not FDA approved. [pmid: 15118283].
Shiba N, Matsuki M, Takahashi J, et al. Prognostic importance of chronic kidney disease in Japanese patients with chronic heart failure - Implications of the CHART study. Circ J. 2008;72(2):173-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18219149].
Shibata Y, Watanabe T, Osaka D, et al. Impairment of pulmonary function is an independent risk factor for atrial fibrillation: The Takahata study. Int J Med Sci. 2011;8(7):514-22. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21897765].
Shibazaki K, Kimura K, Okada Y, et al. Heart failure may be associated with the onset of ischemic stroke with atrial fibrillation: A brain natriuretic peptide study. J Neurol Sci. Jun. 15. 2009;281(1-2):55-7. Exclude: BNP measure not FDA approved. [pmid: 19321180].
Shibazaki K, Kimura K, Iguchi Y, et al. Plasma brain natriuretic peptide can be a biological marker to distinguish cardioembolic stroke from other stroke types in acute ischemic stroke. Intern Med. 2009;48(5):259-64. Exclude: BNP measure not FDA approved. [pmid: 19252345].
Shiga T, Hosaka F, Wakaumi M, et al. Amiodarone decreases plasma brain natriuretic peptide level in patients with heart failure and ventricular tachyarrhythmia. Cardiovasc Drugs Ther. Jul. 2003;17(4):325-33. Exclude: BNP measure not FDA approved. [pmid: 14618094].
Shigemitsu M, Nishio K, Kusuyama T, et al. Nocturnal oxygen therapy prevents progress of congestive heart failure with central sleep apnea. Int J Cardiol. Feb. 14. 2007;115(3):354-60. Exclude: BNP measure not FDA approved. [pmid: 16806535].
Shiina Y, Funabashi N, Lee K, et al. Right atrium contractility and right ventricular diastolic function assessed by pulsed tissue Doppler imaging can predict brain natriuretic peptide in adults with acquired pulmonary hypertension. Int J Cardiol. Jun. 12. 2009;135(1):53-9. Exclude: BNP measure not FDA approved. [pmid: 18793807].
Shiina Y, Funabashi N, Lee K, et al. Doppler imaging predicts cardiac events in chronic pulmonary thromboembolism. Int J Cardiol. Apr. 3. 2009;133(2):167-72. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18242738].
Shimabukuro M, Higa N, Oshiro Y, et al. Diagnostic utility of brain-natriuretic peptide for left ventricular diastolic dysfunction in asymptomatic type 2 diabetic patients. Diabetes Obes Metabol. May. 2007;9(3):323-9. Exclude: BNP measure not FDA approved.
Shimada M, Takahashi M, Shimada H. Effect of a new cardiotonic agent olprinone hydrochloride in patients with severe heart failure. Therapeut Res. 1997;18(10):205-10. Exclude: Not in English.
Shimamoto K, Koike N, Mizuochi K, et al. Characteristics of acute congestive heart failure with normal ejection fraction and less elevated B-type natriuretic peptide. BMC Cardiovasc Disord. 2009;9:2. Exclude: BNP measure not FDA approved. [pmid: 19166616].
Shimizu H, Murakami Y, Inoue S, et al. High plasma brain natriuretic polypeptide level as a marker of risk for thromboembolism in patients with nonvalvular atrial fibrillation. Stroke. Apr. 2002;33(4):1005-10. Exclude: BNP measure not FDA approved. [pmid: 11935052].
Shimizu Y, Nishinaga M, Takata J, et al. B-type natriuretic peptide is predictive of hospitalization in community-dwelling elderly without heart diseases. Geriatr Gerontol Int. Jun. 2009;9(2):148-54. Exclude: BNP measure not FDA approved. [pmid: 19740358].
Shimizu Y, Yamada S, Suzuki M, et al. Development of the performance measure for activities of daily living-8 for patients with congestive heart failure: A preliminary study. Gerontol. 2010;56(5):459-66. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Shimoyama M, Ochi H, Takeda SI, et al. Effect of controlled-release nifedipine on left ventricular hypertrophy in Japanese patients with hypertension: An open-label, uncontrolled study. Curr Therapeut Res. 2001;62(11):773-82. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Shimpo M, Morrow DA, Weinberg EO, et al. Serum levels of the interleukin-1 receptor family member ST2 predict mortality and clinical outcome in acute myocardial infarction. Circ. 2004;109(18):2186-90. Exclude: BNP measure not FDA approved.
Shin DI, Jaekel K, Schley P, et al. Plasma levels of NT-pro-BNP in patients with atrial fibrillation before and after electrical cardioversion. Z Kardiol. Dec. 2005;94(12):795-800. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16382379].
Shinohara H, Fukuda N, Soeki T, et al. Effects of angiotensin II receptor antagonists on [(123)I]metaiodobenzylguanidine myocardial imaging findings and neurohumoral factors in chronic heart failure. Heart Ves. Dec. 2002;17(2):47-52. Exclude: BNP measure not FDA approved.
Shinohara H, Fukuda N, Sakabe K, et al. Changes in plasma endothelin levels after administration of angiotensin II receptor blockers in patients with chronic heart failure. Respir Circ. 2004;52(6):639-44. Exclude: Not in English.
Shirakabe A, Hata N, Yokoyama S, et al. Efficacy and safety of nicorandil therapy in patients with acute heart failure. J Cardiol. 2010;56(3):339-47. Exclude: BNP measure not FDA approved. [pmid: 20832994].
Shiue AB, Stancoven AB, Purcell JB, et al. Relation of level of B-type natriuretic peptide with outcomes in patients with infective endocarditis. Am J Cardiol. Oct. 1. 2010;106(7):1011-5. Exclude: BNP measure not FDA approved. [pmid: 20854966].
Shmilovich H, Ben Shoshan J, Tal R, et al. B-type natriuretic peptide enhances vasculogenesis by promoting number and functional properties of early endothelial progenitor cells. Tissue Eng. Sep. 2009;15(9):2741-9. Exclude: Non-human population.
Shor R, Rozenman Y, Bolshinsky A, et al. BNP in septic patients without systolic myocardial dysfunction. Eur J Intern Med. 2006;17(8):536-40. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17142170].
Shuai XX, Chen YY, Lu YX, et al. Diagnosis of heart failure with preserved ejection fraction: Which parameters and diagnostic strategies are more valuable?. Eur J Heart Fail. Jul. 2011;13(7):737-45. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21602549].
Siano M, Lerch E, Negretti L, et al. A phase I-II study to determine the maximum tolerated infusion rate of rituximab with special emphasis on monitoring the effect of rituximab on cardiac function. Clin Cancer Res. Dec. 1. 2008;14(23):7935-9. Exclude: BNP measure not FDA approved. [pmid: 19047125].
Sidik NPS. Effect of aliskiren in patients with heart failure according to background dose of ACE inhibitor: A retrospective analysis of the aliskiren observation of heart failure treatment (ALOFT) trial. Cardiovasc Drugs Ther. 2011;25(4):315-21. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21779784].
Siebenhofer A, Ng LL, Plank J, et al. Plasma N-terminal pro-brain natriuretic peptide in Type 1 diabetic patients with and without diabetic nephropathy. Diabet Med. Jul. 2003;20(7):535-9. Exclude: BNP measure not FDA approved. [pmid: 12823233].
Siebert U, Januzzi JL Jr., Beinfeld MT, et al. Cost-effectiveness of using N-terminal pro-brain natriuretic peptide to guide the diagnostic assessment and management of dyspneic patients in the emergency department. Am J Cardiol. Sep. 15. 2006;98(6):800-5. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16950189].
Sigurdsson A, Eriksson SV, Hall C, et al. Early neurohormonal effects of trandolapril in patients with left ventricular dysfunction and a recent acute myocardial infarction: A double-blind, randomized, placebo-controlled multicentre study. Eur J Heart Fail. 2001;3(1):69-78. Exclude: BNP measure not FDA approved. [pmid: 11163738].
Silver MA, Horton DP, Ghali JK, et al. Effect of nesiritide versus dobutamine on short-term outcomes in the treatment of patients with acutely decompensated heart failure. J Am Coll Cardiol. Mar. 6. 2002;39(5):798-803. Exclude: BNP measure not FDA approved. [pmid: 11869844].
Silver MA, Pisano C. High incidence of elevated B-type natriuretic peptide levels and risk factors for heart failure in an unselected at-risk population (stage A): Implications for heart failure screening programs. Congest Heart Fail. May. 2003;9(3):127-32. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 12826770].
Sim V, Hampton D, Phillips C, et al. The use of brain natriuretic peptide as a screening test for left ventricular systolic dysfunction- cost-effectiveness in relation to open access echocardiography. Fam Pract. Oct. 2003;20(5):570-4. Exclude: BNP measure not FDA approved. [pmid: 14507800].
Simeoni S, Lippi G, Puccetti A, et al. N-terminal pro-BNP in sclerodermic patients on bosentan therapy for PAH. Rheumatol Int. May. 2008;28(7):657-60. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18092166].
Simon T, Becker R, Voss F, et al. Elevated B-type natriuretic peptide levels in patients with nonischemic cardiomyopathy predict occurrence of arrhythmic events. Clin Res Cardiol. May. 2008;97(5):306-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18193374].
Sinclair H, Paterson M, Walker S, et al. Predicting outcome in patients with acute coronary syndrome: Evaluation of B-type natriuretic peptide and the global registry of acute coronary events (GRACE) risk score. Scot Med J. Aug. 2007;52(3):8-13. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17874709].
Singer AJ, Thode HC Jr., Green GB, et al. The incremental benefit of a shortness-of-breath biomarker panel in emergency department patients with dyspnea. Acad Emerg Med. Jun. 2009;16(6):488-94. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19388909].
Singh HS, Bibbins-Domingo K, Ali S, et al. N-terminal pro-B-type natriuretic peptide and inducible ischemia in the Heart and Soul Study. Clin Cardiol. Aug. 2009;32(8):447-53. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19685518].
Sinha AM, Filzmaier K, Stiegler H, et al. Effects of cardiac resynchronization therapy on the brain natriuretic peptide level and the spiroergometry in patients with chronic heart failure. Herzschrittmacherther Elecktrophysiol. 2002;13(Suppl 1):61-2. Exclude: Not in English.
Sinkovic A. Age-related short-term effect of ramipril on N-terminal pro-brain natriuretic peptide and markers of hemostasis in patients after acute myocardial infarction. Wien Klin Wochenschr. May. 2010;122(Suppl 2):74-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20517677].
Sinnaeve PR, Ezekowitz JA, Bogaerts K, et al. Reperfusion before percutaneous coronary intervention in ST-elevation myocardial infarction patients is associated with lower N-terminal pro-brain natriuretic peptide levels during follow-up, irrespective of pre-treatment with full-dose fibrinolysis. Eur Heart J. Sep. 2009;30(18):2213-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19586960].
Sirithunyanont C, Leowattana W, Sukumalchantra Y, et al. Role of the plasma brain natriuretic peptide in differentiating patients with congestive heart failure from other diseases. J Med Assoc Thai. May. 2003;86(Suppl 1):S87-95. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 12866774].
Siriwardena M, Kleffmann T, Ruygrok P, et al. B-type natriuretic peptide signal peptide circulates in human blood: evaluation as a potential biomarker of cardiac ischemia. Circ. Jul. 20. 2010;122(3):255-64. Exclude: BNP measure not FDA approved.
Siswanto BB, Radi B, Kalim H, et al. Heart failure in NCVC Jakarta and 5 hospitals in Indonesia. CVD Prev Control. 2010;5(1):35-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Sivalingam M, Suresh M, Farrington K, et al. Comparison of B-type natriuretic peptide and NT proBNP as predictors of survival in patients on high-flux hemodialysis and hemodiafiltration. Hemodial Int. Jul. 2011;15(3):359-65. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21624043].
Skrzypiec M, Spring A. Plasma levels of atrial and brain natriuretic peptides in patients with Q-wave myocardial infarction. Adv Clin Exp Med. 2004;13(1):49-58. Exclude: Not in English.
Skvortsov AA, Mareev VI, Nasonova SN, et al. Is triple combination of different neurohormonal modulators recommended for treatment of mild-to-moderate congestive heart failure patients? (Results of Sadko-CHF study). Ter Arkh. 2006;78(8):14-20. Exclude: Not in English. [pmid: 17078211].
Skvortsov AA, Mareev VI, Nasonova SN, et al. Is triple combination of different neurohormonal modulators recommended for treatment of mild-to-moderate congestive heart failure patients? (Results of Sadko-CHF study). Part 2. Ter Arkh. 2006;78(9):61-71. Exclude: Not in English. [pmid: 17076227].
Sliwa K, Norton GR, Kone N, et al. Impact of initiating carvedilol before angiotensin-converting enzyme inhibitor therapy on cardiac function in newly diagnosed heart failure. J Am Coll Cardiol. 2004;44(9):1825-30. Exclude: BNP measure not FDA approved. [pmid: 15519014].
Sliwa K, Woodiwiss A, Kone VN, et al. Therapy of ischemic cardiomyopathy with the immunomodulating agent pentoxifylline: Results of a randomized study. Circ. Feb. 17. 2004;109(6):750-5. Exclude: BNP measure not FDA approved.
Smilde TD, Damman K, van der HP, et al. Differential associations between renal function and “modifiable” risk factors in patients with chronic heart failure. Clin Res Cardiol. Feb. 2009;98(2):121-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18979056].
Smilde TDJ, Hillege HL, Navis G, et al. Impaired renal function in patients with ischemic and nonischemic chronic heart failure: Association with neurohormonal activation and survival. Am Heart J. 2004;148(1):165-72. Exclude: BNP measure not FDA approved. [pmid: 15215807].
Smith H, Pickering RM, Struthers A, et al. Biochemical diagnosis of ventricular dysfunction in elderly patients in general practice: Observational study. BMJ. Apr. 1. 2000;320(7239):906-8. Exclude: BNP measure not FDA approved. [pmid: 10741999].
Smolderen KG, Spertus JA, Reid KJ, et al. Association of somatic and cognitive depressive symptoms and biomarkers in acute myocardial infarction: Insights from the translational research investigating underlying disparities in acute myocardial infarction patients' health status registry. Biol Psychiatr. Jan. 1. 2012;71(1):22-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Socrates T, deFilippi C, Reichlin T, et al. Interleukin family member ST2 and mortality in acute dyspnoea. J Intern Med. Nov. 2010;268(5):493-500. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20804518].
Sodeck G, Domanovits H, Schillinger M, et al. Pre-operative N-terminal pro-brain natriuretic peptide predicts outcome in type A aortic dissection. J Am Coll Cardiol. Mar. 18. 2008;51(11):1092-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18342228].
Sodian R, Loebe M, Schmitt C, et al. Decreased plasma concentration of brain natriuretic peptide as a potential indicator of cardiac recovery in patients supported by mechanical circulatory assist systems. J Am Coll Cardiol. Dec. 2001;38(7):1942-9. Exclude: BNP measure not FDA approved. [pmid: 11738298].
Sohne M, ten Wolde M, Boomsma F, et al. Brain natriuretic peptide in hemodynamically stable acute pulmonary embolism. J Thromb Haemostasis. Mar. 2006;4(3):552-6. Exclude: BNP measure not FDA approved. [pmid: 16405522].
Sokoll LJ, Baum H, Collinson PO, et al. Multicenter analytical performance evaluation of the Elecsys proBNP assay. Clin Chem Lab Med. 2004;42(8):965-72. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 15387451].
Soleimani A, Nasiri O, Nikoueinejad H, et al. Prognostic value of B-type natriuretic peptide for assessment of left ventricular function in patients with chronic kidney disease. Iran J Kidney Dis. Jul. 2011;5(4):242-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21725181].
Solus J, Chung CP, Oeser A, et al. Amino-terminal fragment of the prohormone brain-type natriuretic peptide in rheumatoid arthritis. Arthritis Rheum. Sep. 2008;58(9):2662-9. Exclude: BNP measure not FDA approved. [pmid: 18759301].
Sommerer C, Heckele S, Schwenger V, et al. Cardiac biomarkers are influenced by dialysis characteristics. Clin Nephrol. Dec. 2007;68(6):392-400. Exclude: Unable to obtain copy. [pmid: 18184522].
Song BG, Jeon ES, Kim YH, et al. Correlation between levels of N-terminal pro-B-type natriuretic peptide and degrees of heart failure. Korean J Intern Med. Mar. 2005;20(1):26-32. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 15906950].
Song BG, Park SJ, Noh HJ, et al. Clinical characteristics, and laboratory and echocardiographic findings in takotsubo cardiomyopathy presenting as cardiogenic shock. J Crit Care. Jun. 2010;25(2):329-35. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20534335].
Song BG, Chun WJ, Park YH, et al. The clinical characteristics, laboratory parameters, electrocardiographic, and echocardiographic findings of reverse or inverted takotsubo cardiomyopathy: Comparison with mid or apical variant. Clin Cardiol. Nov. 2011;34(11):693-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 22031226].
Song MH, Kobayashi Y, Michi H. Clinical implication of atrial and brain natriuretic Peptide in coronary artery bypass grafting. Asian Cardiovasc Thorac Ann. Mar. 2004;12(1):41-6. Exclude: BNP measure not FDA approved. [pmid: 14977741].
Soon E, Doughty NJ, Treacy CM, et al. Log-transformation improves the prognostic value of serial NT-proBNP levels in apparently stable pulmonary arterial hypertension. Pulm Circ. Apr. 2011;1(2):244-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 22034610].
Sosin MD, Patel JV, Bhatia GS, et al. Effects of white European, African Caribbean and South Asian ethnicity on homocysteine levels in patients with systolic heart failure. Int J Cardiol. Sep. 16. 2008;129(1):69-75. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17719103].
Souza R, Bogossian HB, Humbert M, et al. N-terminal-pro-brain natriuretic peptide as a haemodynamic marker in idiopathic pulmonary arterial hypertension. Eur Respir J. Mar. 2005;25(3):509-13. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 15738296].
Spanaus KS, Kronenberg F, Ritz E, et al. B-type natriuretic peptide concentrations predict the progression of nondiabetic chronic kidney disease: The mild-to-moderate kidney disease study. Clin Chem. 2007;53(7):1264-72. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17478561].
Sparrow N, Adlam D, Cowley A, et al. The diagnosis of heart failure in general practice: Implications for the UK National Service Framework. Eur J Heart Fail. Jun. 2003;5(3):349-54. Exclude: BNP measure not FDA approved. [pmid: 12798834].
Spatenkova V, Bradac O, Kazda A, et al. N-terminal pro-B-type natriuretic peptide with fractional excretion and clearance of sodium in relation to cardiovascular events after elective cervical spine surgery. Neuroendocrinology Letters. 2011;32(6):874-8. Exclude: Unable to locate copy. [pmid: 22286795].
Speranza L, Franceschelli S, Riccioni G, et al. BNP and iNOS in decompensated chronic heart failure: a linear correlation. Frontiers in Bioscience. 2012;4:1255-62. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Spertus J, Peterson E, Conard MW, et al. Monitoring clinical changes in patients with heart failure: A comparison of methods. Am Heart J. 2005;150(4):707-15. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16209970].
Spevack DM, Matros T, Shah A, et al. Clinical improvement with repeated courses of intravenous B-type natriuretic peptide in refractory heart failure. Eur J Heart Fail. Aug. 2004;6(5):611-3. Exclude: Case report. [pmid: 15302009].
Spina GS, Tarasoutchi F, Sampaio RO, et al. Neurohormonal profile of rheumatic patients with significant chronic aortic regurgitation. Arq Bras Cardiol. Feb. 2009;92(2):143-56. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19360248].
Spinar J, Ludka O, Dusek L, et al. Neurohumoral activity, heart failure and prognosis in patients with end-stage renal disease treated by hemodialysis. Kidney Blood Press Res. 2007;30(5):347-57. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17785989].
Sponga S, Ivanitskaia E, Potapov E, et al. Preoperative treatment with levosimendan in candidates for mechanical circulatory support. ASAIO J. Jan. 2012;58(1):6-11. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 22157071].
Squire I, Quinn P, Narayan H, et al. Identification of potential outcome benefit from ACE inhibition after acute coronary syndrome: a biomarker approach using N-terminal proBNP. Heart. Jun. 2010;96(11):831-7. Exclude: BNP measure not FDA approved. [pmid: 20478862].
Squire IB, O'Brien RJ, Demme B, et al. N-terminal pro-atrial natriuretic peptide (N-ANP) and N-terminal pro-B-type natriuretic peptide (N-BNP) in the prediction of death and heart failure in unselected patients following acute myocardial infarction. Clin Sci. Sep. 2004;107(3):309-16. Exclude: BNP measure not FDA approved. [pmid: 15182235].
Squire IB, Evans J, Ng LL, et al. Plasma MMP-9 and MMP-2 following acute myocardial infarction in man: Correlation with echocardiographic and neurohumoral parameters of left ventricular dysfunction. J Card Fail. Aug. 2004;10(4):328-33. Exclude: BNP measure not FDA approved. [pmid: 15309700].
Squire IB, Orn S, Ng LL, et al. Plasma natriuretic peptides up to 2 years after acute myocardial infarction and relation to prognosis: An OPTIMAAL substudy. J Card Fail. Sep. 2005;11(7):492-7. Exclude: BNP measure not FDA approved. [pmid: 16198243].
Srisawasdi P, Vanavanan S, Charoenpanichkit C, et al. The effect of renal dysfunction on BNP, NT-proBNP, and their ratio. Am J Clin Pathol. Jan. 2010;133(1):14-23. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20023254].
Srivastava PM, Thomas MC, Calafiore P, et al. Diastolic dysfunction is associated with anaemia in patients with Type II diabetes. Clin Sci. Jan. 2006;110(1):109-16. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16181149].
St Peter JV, Hartley GG, Murakami MM, et al. B-type natriuretic peptide (BNP) and N-terminal pro-BNP in obese patients without heart failure: Relationship to body mass index and gastric bypass surgery. Clin Chem. Apr. 2006;52(4):680-5. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16497939].
Stanek B, Frey B, Hulsmann M, et al. Prognostic evaluation of neurohumoral plasma levels before and during beta-blocker therapy in advanced left ventricular dysfunction. J Am Coll Cardiol. Aug. 2001;38(2):436-42. Exclude: BNP measure not FDA approved. [pmid: 11499735].
Stanek B, Berger R, Aliabadi A, et al. Association of NT-proBNP levels and physical fitness in long-term heart transplant recipients. Kardiol. 2007;16(6):272-6. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Staniloae C, Dupuis J, White M, et al. Reduced pulmonary clearance of endothelin in congestive heart failure: A marker of secondary pulmonary hypertension. J Card Fail. Oct. 2004;10(5):427-32. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 15470654].
Stankovic S, Asanin M, Majkic-Singh N, et al. The usefulness of myeloperoxidase in prediction of in-hospital mortality in patients with ST-segment elevation myocardial infarction treated by primary percutaneous coronary intervention. Clin Lab. 2012;58(1-2):125-31. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 22372355].
Stanton E, Hansen M, Wijeysundera HC, et al. A direct comparison of the natriuretic peptides and their relationship to survival in chronic heart failure of a presumed non-ischaemic origin. Eur J Heart Fail. Jun. 2005;7(4):557-65. Exclude: BNP measure not FDA approved. [pmid: 15921795].
Starklint J, Bech JN, Nyvad O, et al. Increased urinary aquaporin-2 excretion in response to furosemide in patients with chronic heart failure. Scand J Clin Lab Invest. 2006;66(1):55-66. Exclude: BNP measure not FDA approved. [pmid: 16464787].
Starnes HB. Use of B-type Natriuretic Peptide in heart failure. J Ark Med Soc. Feb. 2006;102(8):222-4. Exclude: Not a primary study. [pmid: 16529286].
Staszewsky L, Wong M, Masson S, et al. Clinical, neurohormonal, and inflammatory markers and overall prognostic role of chronic obstructive pulmonary disease in patients with heart failure: Data from the Val-HeFT heart failure trial. J Card Fail. 2007;13(10):797-804. Exclude: BNP measure not FDA approved. [pmid: 18068611].
Staudt A, Staudt Y, Hummel A, et al. Effects of immunoadsorption on the nt-BNP and nt-ANP plasma levels of patients suffering from dilated cardiomyopathy. Therapeut Apheresis Dial. Feb. 2006;10(1):42-8. Exclude: BNP measure not FDA approved.
Steele IC, McDowell G, Moore A, et al. Responses of atrial natriuretic peptide and brain natriuretic peptide to exercise in patients with chronic heart failure and normal control subjects. Eur J Clin Invest. Apr. 1997;27(4):270-6. Exclude: BNP measure not FDA approved. [pmid: 9134374].
Stein PK, Tereshchenko L, Domitrovich PP, et al. Diastolic dysfunction and autonomic abnormalities in patients with systolic heart failure. Eur J Heart Fail. 2007;9(4):364-9. Exclude: BNP measure not FDA approved. [pmid: 17123863].
Stejskal D, Lacnak B, Andelova K, et al. MCL-1 (myosin light chains-1) in differential diagnosis of dyspnea. Biomed Pap Med Fac Univ Palacky Olomouc Czech Repub. Jun. 2005;149(1):89-91. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16170394].
Stejskal D, Karpisek M, Humenanska V, et al. Macrophage-inhibitory cytokine-1 (mic-1) in differential diagnosis of dyspnea--A pilot study. Clin Biochem. Sep. 2009;42(13-14):1347-51. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19341722].
Stevens TL, Rasmussen TE, Wei C, et al. Renal role of the endogenous natriuretic peptide system in acute congestive heart failure. J Card Fail. Jun. 1996;2(2):119-25. Exclude: Non-human population. [pmid: 8798113].
Stewart D, Waxman K, Brown CA, et al. B-type natriuretic peptide levels may be elevated in the critically injured trauma patient without congestive heart failure. J Trauma Inj Infect Crit Care. Oct. 2007;63(4):747-50. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Stewart KC, Kumar R, Charonko JJ, et al. Evaluation of LV diastolic function from color M-mode echocardiography. JACC Cardiovasc Imaging. 2011;4(1):37-46. Exclude: BNP measure not FDA approved. [pmid: 21232702].
Stolker JM, Rich MW. The combination of B-type natriuretic peptide and C-reactive protein provides incremental prognostic value among older patients referred for cardiac catheterization. Am J Geriatr Cardiol. Jul. 2007;16(4):229-35. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17617749].
Stolker JM, Rich MW. Clinical utility of B-type natriuretic peptide for estimating left ventricular filling pressures in unselected elderly patients undergoing diagnostic coronary angiography. J Invasive Cardiol. Mar. 2010;22(3):107-12. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20197576].
Straburzynska-Migaj E, Szyszka A, Trojnarska O, et al. Restrictive filling pattern predicts pulmonary hypertension and is associated with increased BNP levels and impaired exercise capacity in patients with heart failure. Kardiol Pol. 2007;65(9):1049-55. Exclude: BNP measure not FDA approved. [pmid: 17975752].
Straburzynska-Migaj E, Gwizdala A, Siniawski A, et al. Leptin and inflammation in patients with chronic heart failure. Kardiol Pol. 2010;68(11):1243-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21108202].
Straburzynska-Migaj E, Gwizdala A, Siniawski A, et al. Oxygen uptake efficiency slope correlates with brain natriuretic peptide in patients with heart failure. Cardiol J. 2010;17(4):362-6. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20690091].
Strabuzynska-Migaj E, Szyszka A, Cieslinski A. Prolonged QRS duration in patients with heart failure: relation to exercise tolerance, diastolic function and aetiology. Kardiol Pol. Dec. 2008;66(12):1251-7. Exclude: BNP measure not FDA approved. [pmid: 19169971].
Strametz-Juranek J, Pacher R, Kos T, et al. Sequential big endothelin plasma levels in heart transplant recipients during bridging therapy and after successful heart transplantation. J Heart Lung Transplant. 2003;22(7):731-7. Exclude: BNP measure not FDA approved. [pmid: 12873540].
Strunk A, Bhalla V, Clopton P, et al. Impact of the history of congestive heart failure on the utility of B-type natriuretic peptide in the emergency diagnosis of heart failure: Results from the Breathing Not Properly Multinational Study. Am J Med. Jan. 2006;119(1):69-11. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16431187].
Studler U, Kretzschmar M, Christ M, et al. Accuracy of chest radiographs in the emergency diagnosis of heart failure. Eur Radiol. Aug. 2008;18(8):1644-52. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18369631].
Sturgess DJ, Marwick TH, Joyce C, et al. Prediction of hospital outcome in septic shock: A prospective comparison of tissue Doppler and cardiac biomarkers. Crit Care. 2010;14(2):R44. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20331902].
Sturgess DJ, Venkatesh B. Plasma free cortisol and B-type natriuretic peptide in septic shock. Anaesthesia & Intensive Care. Jan. 2012;40(1):95-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 22313067].
Stypmann J, Schubert A, Welp H, et al. Atorvastatin therapy is associated with reduced levels of N-terminal prohormone brain natriuretic peptide and improved cardiac function in patients with heart failure. Clin Cardiol. Oct. 2008;31(10):478-81. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18855352].
Styron JF, Jois-Bilowich P, Starling R, et al. Initial emergency department systolic blood pressure predicts left ventricular systolic function in acute decompensated heart failure. Congest Heart Fail. 2009;15(1):9-13. Exclude: BNP measure not FDA approved. [pmid: 19187401].
Su W, An T, Zhou Q, et al. Serum albumin is a useful prognostic indicator and adds important information to NT-proBNP in a Chinese cohort of heart failure. Clin Biochem. 2012;45(7-8):561-5. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 22374171].
Suga C, Matsumoto K, Kato R, et al. Does biventricular pacing improve the risk for fatal arrhythmia in patients with heart failure?. Therapeut Res. 2003;24(3):468-72. Exclude: Not in English.
Sugamori T, Ishibashi Y, Shimada T, et al. Increased nitric oxide in proportion to the severity of heart failure in patients with dilated cardiomyopathy: Close correlation of tumor necrosis factor-alpha with systemic and local production of nitric oxide. Circ J. Jul. 2002;66(7):627-32. Exclude: BNP measure not FDA approved. [pmid: 12135128].
Sugi Y, Yasukawa H, Kai H, et al. Reduction and activation of circulating dendritic cells in patients with decompensated heart failure. Int J Cardiol. Mar. 3. 2011;147(2):258-64. Exclude: BNP measure not FDA approved. [pmid: 19923020].
Sugimoto T, Tanigawa T, Onishi K, et al. Serum intact parathyroid hormone levels predict hospitalisation for heart failure. Heart. 2009;95(5):395-8. Exclude: BNP measure not FDA approved. [pmid: 19001003].
Sugisawa T, Kishimoto I, Kokubo Y, et al. Visceral fat is negatively associated with B-type natriuretic peptide levels in patients with advanced type 2 diabetes. Diab Res Clin Pract. Aug. 2010;89(2):174-80. Exclude: BNP measure not FDA approved.
Sugiura S, Fujii E, Senga M, et al. Clinical features of patients with left atrial thrombus undergoing anticoagulant therapy. J Interv Card Electrophysiol. 2012;34(1):59-63. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 22190167].
Sugiura T, Takase H, Toriyama T, et al. Usefulness of Tc-99m methoxyisobutylisonitrile scintigraphy for evaluating congestive heart failure. J Nucl Cardiol. 2006;13(1):64-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16464718].
Suguta M, Hara K, Nakano A, et al. Serum atrial natriuretic peptide concentration is a useful predictor of atrial standstill in patients with heart failure. Jpn Circ J. Jul. 2000;64(7):537-40. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 10929785].
Sultana P, Hoque M, Shafiullah S. Plasma BNP (B-type natriuretic peptide) and heart failure: A case-control study. J Med. 2010;11(1):46-50. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Suma H, Isomura T, Horii T, et al. Left ventriculoplasty for non-ischemic cardiomyopathy with severe heart failure in 70 patients. J Cardiol. 2001;37(1):1-10. Exclude: Not in English. [pmid: 11200650].
Suma H, Isomura T, Horii T, et al. Septal anterior ventricular exclusion procedure for idiopathic dilated cardiomyopathy. Ann Thorac Surg. 2006;82(4):1344-8. Exclude: BNP measure not FDA approved. [pmid: 16996931].
Sumida H, Yasue H, Yoshimura M, et al. Comparison of secretion pattern between A-type and B-type natriuretic peptides in patients with old myocardial infarction. J Am Coll Cardiol. Apr. 1995;25(5):1105-10. Exclude: BNP measure not FDA approved. [pmid: 7897123].
Sun L, Sun Y, Zhao X, et al. Predictive role of BNP and NT-proBNP in hemodialysis patients. Nephron. 2008;110(3):c178-84. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18957868].
Sun T, Wang L, Zhang Y. Prognostic value of B-type natriuretic peptide in patients with acute coronary syndromes. Arch Med Res. May. 2006;37(4):502-5. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16624649].
Sundell J, Engblom E, Koistinen J, et al. The effects of cardiac resynchronization therapy on left ventricular function, myocardial energetics, and metabolic reserve in patients with dilated cardiomyopathy and heart failure. J Am Coll Cardiol. 2004;43(6):1027-33. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 15028362].
Sung EK, Dae GP, Hyun HC, et al. The best predictor for right ventricular dysfunction in acute pulmonary embolism: Comparison between electrocardiography and biomarkers. Korean Circ J. 2009;39(9):378-81. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19949622].
Sung SH, Chuang SY, Sheu WH, et al. Relation of adiponectin and high-sensitivity C-reactive protein to pulse-wave velocity and N-terminal pro-B-type natriuretic peptide in the general population. Am J Cardiol. May. 15. 2009;103(10):1411-6. Exclude: BNP measure not FDA approved. [pmid: 19427438].
Sung SH, Wu TC, Huang CH, et al. Prognostic impact of body mass index in patients undergoing coronary artery bypass surgery. Heart. Apr. 2011;97(8):648-54. Exclude: BNP measure not FDA approved. [pmid: 21330312].
Sung SH, Yu WC, Cheng HM, et al. Pulsatile hemodynamics and clinical outcomes in acute heart failure. Am J Hypertens. Jul. 2011;24(7):775-82. Exclude: BNP measure not FDA approved. [pmid: 21372800].
Sunsaneewitayakul B, Sitthisook S, Sangwatanaroj S, et al. Feasibility, safety, and mid-term efficacy of cardiac resynchronization therapy in patients with severe heart failure and ventricular conduction delay: Chulalongkorn experience. J Med Assoc Thai. Jul. 2007;90(7):1458-66. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17710992].
Susa T, Kobayashi S, Tanaka T, et al. Urinary 8-hydroxy-2'-deoxyguanosine as a novel biomarker for predicting cardiac events and evaluating the effectiveness of carvedilol treatment in patients with chronic systolic heart failure. Circ J. 2012;76(1):117-26. Exclude: BNP measure not FDA approved. [pmid: 22008315].
Sutovsky I, Katoh T, Ohno T, et al. Relationship between brain natriuretic peptide, myocardial wall stress, and ventricular arrhythmia severity. Jpn Heart J. Sep. 2004;45(5):771-7. Exclude: BNP measure not FDA approved. [pmid: 15557718].
Suttner S, Boldt J, Mengistu A, et al. Influence of continuous perioperative beta-blockade in combination with phosphodiesterase inhibition on haemodynamics and myocardial ischaemia in high-risk vascular surgery patients. Br J Anaesth. May. 2009;102(5):597-607. Exclude: BNP measure not FDA approved. [pmid: 19336536].
Suwa M, Ito T. Correlation between cognitive impairment and left ventricular diastolic dysfunction in patients with cardiovascular diseases. Int J Cardiol. Aug. 21. 2009;136(3):351-4. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18684536].
Suwanugsorn S, Yipintsoi T, Geater AF, et al. An equation to explain variations in blood NT-proBNP in ambulatory cardiac subjects. J Med Assoc Thai. Jan. 2009;92(1):1-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19260235].
Suzuki M, Hamada M, Yamamoto K, et al. Brain natriuretic peptide as a risk marker for incident hypertensive cardiovascular events. Hypertens Res. Sep. 2002;25(5):669-76. Exclude: BNP measure not FDA approved. [pmid: 12452317].
Suzuki O, I. Effects of an angiotensin 2 receptor blocker plus diuretic combination drug in chronic heart failure complicated by hypertension. J Int Med Res. 2011;39(4):1420-6. Exclude: BNP measure not FDA approved. [pmid: 21986143].
Suzuki R, Honda H, Niikura K, et al. Olmesartan medoxomil treatment is associated with decreased plasma B-type natriuretic peptide levels in patients on hemodialysis. Clin Exp Hypertens. 2012;34(2):125-31. Exclude: BNP measure not FDA approved. [pmid: 21967019].
Suzuki S, Yoshimura M, Nakayama M, et al. Plasma level of B-type natriuretic peptide as a prognostic marker after acute myocardial infarction: A long-term follow-up analysis. Circ. Sep. 14. 2004;110(11):1387-91. Exclude: BNP measure not FDA approved.
Suzuki T, Yamaoki K, Nakajima O, et al. Screening for cardiac dysfunction in asymptomatic patients by measuring B-type natriuretic peptide levels. Jpn Heart J. Mar. 2000;41(2):205-14. Exclude: BNP measure not FDA approved. [pmid: 10850536].
Svatikova A, Shamsuzzaman AS, Wolk R, et al. Plasma brain natriuretic peptide in obstructive sleep apnea. Am J Cardiol. Aug. 15. 2004;94(4):529-32. Exclude: BNP measure not FDA approved. [pmid: 15325948].
Svensson M, Gorst-Rasmussen A, Schmidt EB, et al. NT-pro-BNP is an independent predictor of mortality in patients with end-stage renal disease. Clin Nephrol. Apr. 2009;71(4):380-6. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19356370].
Svensson P, de Faire U, Niklasson U, et al. Plasma NT-proBNP concentration is related to ambulatory pulse pressure in peripheral arterial disease. Blood Press. 2005;14(2):99-106. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16036487].
Swiatkiewicz I, Grubecki A, Bialoszynski T, et al. Prediction of left ventricular function in patients after acute myocardial infarction treated with primary angioplasty. Folia Cardiol. 2006;13(7):605-19. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Symeonides P, Koulouris S, Vratsista E, et al. Both ramipril and telmisartan reverse indices of early diabetic cardiomyopathy: A comparative study. Eur J Echocardiogr. Dec. 2007;8(6):480-6. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17113349].
Szadkowska I, Goch JH, Polak L, et al. The relationship between early recanalization and serum NT-proBNP levels in patients with a first ST-segment elevation myocardial infarction treated with primary coronary angioplasty. Acta Cardiol. Oct. 2007;62(5):479-84. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17982969].
Szadkowska I, Goch JH, Kawinski J, et al. N-terminal pro-brain natriuretic peptide in the elderly with myocardial infarction. Clin Cardiol. Sep. 2008;31(9):443-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18781605].
Szadkowska I, Pawlicki L, Kowalski J, et al. Left ventricular dysfunction and NT-proBNP levels in patients with one-vessel disease after first ST-elevation myocardial infarction treated with primary coronary angioplasty. Kardiol Pol. Nov. 2009;67(11):1201-6. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20024847].
Sztrymf B, Souza R, Bertoletti L, et al. Prognostic factors of acute heart failure in patients with pulmonary arterial hypertension. Eur Respir J. Jun. 2010;35(6):1286-93. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19897557].
Szulik M, S-D. Echocardiography-based qualification and response assessment to cardiac resynchronisation therapy in patients with chronic heart failure. The matrix metalloproteinase-9 substudy. Kardiol Pol. 2011;69(10):1043-51. Exclude: Not in English. [pmid: 22006606].
Szummer K, Lindahl B, Sylven C, et al. Relationship of plasma erythropoietin to long-term outcome in acute coronary syndrome. Int J Cardiol. Aug. 20. 2010;143(2):165-70. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19269703].
Szymanowska K, Piatkowska A, Nowicka A, et al. Clinical significance of heart rate turbulence assessment in patients with chronic heart failure. Kardiol Pol. Dec. 2008;66(12):1289-95. Exclude: BNP measure not FDA approved. [pmid: 19169975].
Szymanski P, Klisiewicz A, Lubiszewska B, et al. Application of classic heart failure definitions of asymptomatic and symptomatic ventricular dysfunction and heart failure symptoms with preserved ejection fraction to patients with systemic right ventricles. Am J Cardiol. Aug. 1. 2009;104(3):414-8. Exclude: BNP measure not FDA approved. [pmid: 19616677].
Szymanski P, Klisiewicz A, Lubiszewska B, et al. Functional anatomy of tricuspid regurgitation in patients with systemic right ventricles. J Am Soc Echocardiogr. May. 2010;23(5):504-10. Exclude: BNP measure not FDA approved. [pmid: 20189758].
Tacoy G, Acikgoz K, Kocaman SA, et al. Is there a relationship between obesity, heart rate variability and inflammatory parameters in heart failure?. J Cardiovasc Med. Feb. 2010;11(2):118-24. Exclude: BNP measure not FDA approved.
Tada H, Ito S, Shinbo G, et al. Significance and utility of plasma brain natriuretic peptide concentrations in patients with idiopathic ventricular arrhythmias. Pacing Clin Electrophysiol. Dec. 2006;29(12):1395-403. Exclude: BNP measure not FDA approved. [pmid: 17201848].
Tagore R, Ling LH, Yang H, et al. Natriuretic peptides in chronic kidney disease. Clin J Am Soc Nephrol. Nov. 2008;3(6):1644-51. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18632852].
Takagi A, Iwama Y, Yamada A, et al. Estimated glomerular filtration rate is an independent predictor for mortality of patients with acute heart failure. J Cardiol. May. 2010;55(3):317-21. Exclude: BNP measure not FDA approved. [pmid: 20350524].
Takahashi M, Takeda S, Kurokawa S, et al. Cyclic GMP production by ANP, BNP, and NO during worsening and improvement of chronic heart failure. Jpn Heart J. Sep. 2003;44(5):713-24. Exclude: BNP measure not FDA approved. [pmid: 14587653].
Takahashi N, Yamamoto A, Tezuka S, et al. Assessment of left ventricular dyssynchrony during development of heart failure by a novel program using ECG-gated myocardial perfusion SPECT. Circ J. Mar. 2008;72(3):370-7. Exclude: BNP measure not FDA approved. [pmid: 18296831].
Takahashi R, Negishi K, Watanabe A, et al. Serum syndecan-4 is a novel biomarker for patients with chronic heart failure. J Cardiol. May. 2011;57(3):325-32. Exclude: BNP measure not FDA approved. [pmid: 21397460].
Takahashi T, Allen PD, Izumo S. Expression of A-, B-, and C-type natriuretic peptide genes in failing and developing human ventricles. Correlation with expression of the Ca(2+)-ATPase gene. Circ Res. Jul. 1992;71(1):9-17. Exclude: BNP measure not FDA approved. [pmid: 1535030].
Takahashi T, Nakamura M, Onoda T, et al. Predictive value of plasma B-type natriuretic peptide for ischemic stroke: A community-based longitudinal study. Atherosclerosis. Nov. 2009;207(1):298-303. Exclude: BNP measure not FDA approved. [pmid: 19497572].
Takama N, Kurabayashi M, Takama N, et al. Effectiveness of adaptive servo-ventilation for treating heart failure regardless of the severity of sleep-disordered breathing. Circ J. Apr. 25. 2011;75(5):1164-9. Exclude: BNP measure not FDA approved. [pmid: 21378449].
Takama N, Kurabayashi M. Effect of adaptive servo-ventilation on 1-year prognosis in heart failure patients. Circ J. 2012;76(3):661-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 22199136].
Takami Y, Horio T, Iwashima Y, et al. Diagnostic and prognostic value of plasma brain natriuretic peptide in non-dialysis-dependent CRF. Am J Kidney Dis. Sep. 2004;44(3):420-8. Exclude: BNP measure not FDA approved. [pmid: 15332214].
Takamura T, Ishigami T, Uchino K, et al. Potential utility of ambulatory blood pressure monitoring in patients with congestive heart failure. Therapeut Res. 2009;30(7):1167-72. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Takano H, Obata J, Kodama Y, et al. Adiponectin is released from the heart in patients with heart failure. Int J Cardiol. 2009;132(2):221-6. Exclude: BNP measure not FDA approved. [pmid: 18192035].
Takase H, Toriyama T, Sugiura T, et al. Brain natriuretic peptide in the prediction of recurrence of angina pectoris. Eur J Clin Invest. Feb. 2004;34(2):79-84. Exclude: BNP measure not FDA approved. [pmid: 14764069].
Takase H, Toriyama T, Sugiura T, et al. Brain natriuretic peptide detects cardiac abnormalities in mass screening. Eur J Clin Invest. 2007;37(4):257-62. Exclude: BNP measure not FDA approved. [pmid: 17373960].
Takase H, Dohi Y, Toriyama T, et al. B-type natriuretic peptide levels and cardiovascular risk in patients with diastolic dysfunction on chronic haemodialysis: Cross-sectional and observational studies. Nephrol Dial Transplant. 2011;26(2):683-90. Exclude: BNP measure not FDA approved. [pmid: 20624772].
Takatsuka H, Nakajima T, Nomura K, et al. Prognosis value of atrial natriuretic peptide and brain natriuretic peptide for heart failure in patients undergoing allogeneic bone marrow transplantation. Hematol. 2006;11(5-6):351-4. Exclude: BNP measure not FDA approved.
Takeda Y, Fukutomi T, Suzuki S, et al. Effects of carvedilol on plasma B-type natriuretic peptide concentration and symptoms in patients with heart failure and preserved ejection fraction. Am J Cardiol. Aug. 15. 2004;94(4):448-53. Exclude: BNP measure not FDA approved. [pmid: 15325927].
Takeda Y, Takeda Y, Suzuki S, et al. Within-person variation of the plasma concentration of B-type natriuretic peptide: Safety range in stable patients with heart failure. Am Heart J. Jan. 2009;157(1):97-101. Exclude: BNP measure not FDA approved. [pmid: 19081403].
Takeda Y, Takeda Y, Tomimoto S, et al. Bilirubin as a prognostic marker in patients with pulmonary arterial hypertension. BMC Pulm Med. 2010;10:22. Exclude: BNP measure not FDA approved. [pmid: 20412580].
Takeishi Y, Niizeki T, Arimoto T, et al. Serum resistin is associated with high risk in patients with congestive heart failure - A novel link between metabolic signals and heart failure. Circ J. 2007;71(4):460-6. Exclude: BNP measure not FDA approved. [pmid: 17384443].
Takeishi Y, Toriyama S, Takabatake N, et al. Linkage disequilibrium analyses of natriuretic peptide precursor B locus reveal risk haplotype conferring high plasma BNP levels. Biochem Biophys Res Commun. Oct. 19. 2007;362(2):480-4. Exclude: BNP measure not FDA approved. [pmid: 17719005].
Takemura K, Yasumura Y, Hirooka K, et al. Low-dose amiodarone for patients with advanced heart failure who are intolerant of beta-blockers. Circ J. May. 2002;66(5):441-4. Exclude: BNP measure not FDA approved. [pmid: 12030336].
Takeuchi D, Saji T, Takatsuki S, et al. Abnormal tissue doppler images are associated with elevated plasma brain natriuretic peptide and increased oxidative stress in acute Kawasaki disease. Circ J. Mar. 2007;71(3):357-62. Exclude: Population aged under 18. [pmid: 17322635].
Takeuchi I, Inomata T, Nishii M, et al. Clinical characteristics of heart disease patients with a good prognosis in spite of markedly increased plasma levels of type-B natriuretic peptide (BNP): Anomalous behavior of plasma BNP in hypertrophic cardiomyopathy. Circ J. Mar. 2005;69(3):277-82. Exclude: BNP measure not FDA approved. [pmid: 15731531].
Talens-Visconti R, Rivera OM, Sancho-Tello MJ, et al. Left ventricular cavity area reflects N-terminal pro-brain natriuretic peptide plasma levels in heart failure. Eur J Echocardiogr. Jan. 2006;7(1):45-52. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 15939671].
Talens-Visconti R, Rivera M, Climent V, et al. Maximum longitudinal relaxation velocity of the left ventricle: Its clinical value and relationship with NT-proBNP plasma levels in heart failure. Echocardiograph. Apr. 2006;23(4):295-302. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Talha S, Di Marco P, Doutreleau S, et al. Does circulating BNP normalize after heart transplantation in patients with normal hemodynamic and right and left heart functions?. Clin Transplant. Sep. 2008;22(5):542-8. Exclude: BNP measure not FDA approved. [pmid: 18394002].
Talvani A, Rocha MO, Cogan J, et al. Brain natriuretic peptide and left ventricular dysfunction in chagasic cardiomyopathy. Mem Inst Oswaldo Cruz. Oct. 2004;99(6):645-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 15558179].
Talvani A, Rocha MO, Barcelos LS, et al. Elevated concentrations of CCL2 and tumor necrosis factor-alpha in chagasic cardiomyopathy. Clin Infect Dis. Apr. 1. 2004;38(7):943-50. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 15034825].
Tamaki T, Kato K, Arima H, et al. Should we really avoid administration of angiotensin II receptor blockade to the symptomatic heart failure patients despite carvedilol and ACE inhibitor treatment?. Therapeut Res. 2003;24(12):2227-33. Exclude: Not in English.
Tamizifar B, Rismankarzadeh M. Using nt-probnp as a criterion for heart failure hospitalization. J Res Med Sci. 2012;17(1):111-3. Exclude: Not a primary study. [pmid: 23248667].
Tamura A, Kawano Y, Kadota J. Carvedilol reduces the severity of central sleep apnea in chronic heart failure. Circ J. Feb. 2009;73(2):295-8. Exclude: BNP measure not FDA approved. [pmid: 19122306].
Tamura A, Ando S, Goto Y, et al. Washout rate of cardiac iodine-123 metaiodobenzylguanidine is high in chronic heart failure patients with central sleep apnea. J Card Fail. 2010;16(9):728-33. Exclude: BNP measure not FDA approved. [pmid: 20797596].
Tamura K, Takahashi N, Nakatani Y, et al. Prognostic impact of plasma brain natriuretic peptide for cardiac events in elderly patients with congestive heart failure. Gerontol. Jan. 2001;47(1):46-51. Exclude: BNP measure not FDA approved.
Tamura T, Furukawa Y, Taniguchi R, et al. Serum adiponectin level as an independent predictor of mortality in patients with congestive heart failure. Circ J. May. 2007;71(5):623-30. Exclude: BNP measure not FDA approved. [pmid: 17456982].
Tan HW, W X. Congestive heart failure after extensive catheter ablation for atrial fibrillation: Prevalence, characterization, and outcome. J Cardiovasc Electrophysiol. 2011;22(6):632-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21235663].
Tanabe K, Yamamoto A, Suzuki N, et al. Exercise-induced changes in plasma atrial natriuretic peptide and brain natriuretic peptide concentrations in healthy subjects with chronic sleep deprivation. Jpn Circ J. Jun. 1999;63(6):447-52. Exclude: BNP measure not FDA approved. [pmid: 10406584].
Tanaka T, Hasegawa K, Fujita M, et al. Marked elevation of brain natriuretic peptide levels in pericardial fluid is closely associated with left ventricular dysfunction. J Am Coll Cardiol. Feb. 1998;31(2):399-403. Exclude: BNP measure not FDA approved. [pmid: 9462585].
Tanaka T, Tsutamoto T, Sakai H, et al. Effect of atrial natriuretic peptide on adiponectin in patients with heart failure. Eur J Heart Fail. Apr. 2008;10(4):360-6. Exclude: BNP measure not FDA approved. [pmid: 18353720].
Tanaka T, Tsutamoto T, Nishiyama K, et al. Impact of oxidative stress on plasma adiponectin in patients with chronic heart failure. Circ J. Apr. 2008;72(4):563-8. Exclude: BNP measure not FDA approved. [pmid: 18362426].
Taner ED, Yavuz B, Okhan AK, et al. An obesity drug sibutramine reduces brain natriuretic peptide (BNP) levels in severely obese patients. Int J Clin Pract. 2010;64(4):518-22. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20456197].
Tang TT, Ding YJ, Liao YH, et al. Defective circulating CD4CD25+Foxp3+CD127(low) regulatory T-cells in patients with chronic heart failure. Cell Physiol Biochem. 2010;25(4-5):451-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20332626].
Tang WH, Girod JP, Lee MJ, et al. Plasma B-type natriuretic peptide levels in ambulatory patients with established chronic symptomatic systolic heart failure. Circ. Dec. 16. 2003;108(24):2964-6. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Tang WH, Brennan ML, Philip K, et al. Plasma myeloperoxidase levels in patients with chronic heart failure. Am J Cardiol. Sep. 15. 2006;98(6):796-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16950188].
Tang WH, Tong W, Troughton RW, et al. Prognostic value and echocardiographic determinants of plasma myeloperoxidase levels in chronic heart failure. J Am Coll Cardiol. Jun. 19. 2007;49(24):2364-70. Exclude: BNP measure not FDA approved. [pmid: 17572253].
Tang WH, Steinhubl SR, Van Lente F, et al. Risk stratification for patients undergoing nonurgent percutaneous coronary intervention using N-terminal pro-B-type natriuretic peptide: A Clopidogrel for the Reduction of Events During Observation (CREDO) substudy. Am Heart J. Jan. 2007;153(1):36-41. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17174634].
Tang WH, Shrestha K, Mullens W, et al. Impact of left ventricular remodeling on diagnostic and prognostic value of tissue Doppler indices in chronic systolic heart failure. J Card Fail. Feb. 2011;17(2):128-34. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21300302].
Tang WHW, Francis GS. Plasma B-type natriuretic peptide levels in chronic heart failure. Cardiol Rev. 2004;21(12):41-3. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Tang WHW, Wu Y, Nicholls SJ, et al. Plasma myeloperoxidase predicts incident cardiovascular risks in stable patients undergoing medical management for coronary artery disease. Clin Chem. 2011;57(1):33-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21059827].
Taniguchi R, Sato Y, Nishio Y, et al. Measurements of baseline and follow-up concentrations of cardiac troponin-T and brain natriuretic peptide in patients with heart failure from various etiologies. Heart Ves. Nov. 2006;21(6):344-9. Exclude: BNP measure not FDA approved.
Tanino Y, Shite J, Paredes OL, et al. Whole body bioimpedance monitoring for outpatient chronic heart failure follow up. Circ J. Jun. 2009;73(6):1074-9. Exclude: BNP measure not FDA approved. [pmid: 19372625].
Tanner H, Mohacsi P, Fuller-Bicer GA, et al. Cytokine activation and disease progression in patients with stable moderate chronic heart failure. J Heart Lung Transplant. 2007;26(6):622-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17543787].
Tanner MA, Galanello R, Dessi C, et al. Myocardial iron loading in patients with thalassemia major on deferoxamine chelation. J Cardiovasc Magn Reson. 2006;8(3):543-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16755844].
Tanous D, Siu SC, Mason J, et al. B-type natriuretic peptide in pregnant women with heart disease. J Am Coll Cardiol. Oct. 5. 2010;56(15):1247-53. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20883932].
Tapolyai M, Uysal A, Maeweathers G, et al. B-Type natriuretic peptide-directed ultrafiltration improves care in acutely hospitalized dialysis patients. Congest Heart Fail. 2009;15(3):131-5. Exclude: BNP measure not FDA approved. [pmid: 19522962].
Tarnow L, Hildebrandt P, Hansen BV, et al. Plasma N-terminal pro-brain natriuretic peptide as an independent predictor of mortality in diabetic nephropathy. Diabetol. Jan. 2005;48(1):149-55. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Tarnow L, Gall MA, Hansen BV, et al. Plasma N-terminal pro-B-type natriuretic peptide and mortality in type 2 diabetes. Diabetol. Oct. 2006;49(10):2256-62. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Tarquini R, Guerra CT, Porciani MC, et al. Effects of cardiac resynchronization therapy on systemic inflammation and neurohormonal pathways in heart failure. Cardiol J. 2009;16(6):545-52. Exclude: BNP measure not FDA approved. [pmid: 19950091].
Tasevska-Dinevska G, Kennedy LM, Cline-Iwarson A, et al. Gender differences in variables related to B-natriuretic peptide, left ventricular ejection fraction and mass, and peak oxygen consumption, in patients with heart failure. Int J Cardiol. Jun. 16. 2011;149(3):364-71. Exclude: BNP measure not FDA approved. [pmid: 20202706].
Taskapan MC, Taskapan H, Ulutas O, et al. Relationships between brain natriuretic peptide, troponin I and QT dispersion in asymptomatic dialysis patients. Ren Fail. 2007;29(2):221-5. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17365940].
Tasouli A, Papadopoulos K, Antoniou T, et al. Efficacy and safety of perioperative infusion of levosimendan in patients with compromised cardiac function undergoing open-heart surgery: Importance of early use. Eur J Cardiothorac Surg. Oct. 2007;32(4):629-33. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17702589].
Tassone F, Gianotti L, Rolfo F, et al. B-type natriuretic peptide levels and insulin resistance in patients with severe ischemic myocardial dysfunction. J Endocrinol Invest. Nov. 2009;32(10):805-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19468263].
Taub PR, Ramirez-Sanchez I, Ciaraldi TP, et al. Alterations in skeletal muscle indicators of mitochondrial structure and biogenesis in patients with type 2 diabetes and heart failure: Effects of Epicatechin rich cocoa. Clin Translat Sci. 2012;5(1):43-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Tavakol M, Hassan KZ, Abdula RK, et al. Utility of brain natriuretic peptide as a predictor of atrial fibrillation after cardiac operations. Ann Thorac Surg. Sep. 2009;88(3):802-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19699901].
Taylor JA, Christenson RH, Rao K, et al. B-type natriuretic peptide and N-terminal pro B-type natriuretic peptide are depressed in obesity despite higher left ventricular end diastolic pressures. Am Heart J. Dec. 2006;152(6):1071-6. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17161055].
Tchou I, Margeli A, Tsironi M, et al. Growth-differentiation factor-15, endoglin and N-terminal pro-brain natriuretic peptide induction in athletes participating in an ultramarathon foot race. Biomarkers. Sep. 2009;14(6):418-22. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19563304].
Tedeschi S, Pilotti E, Parenti E, et al. Serum adipokine zinc alpha2-glycoprotein and lipolysis in cachectic and noncachectic heart failure patients: Relationship with neurohormonal and inflammatory biomarkers. Metabolism. Jan. 2012;61(1):37-42. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21696792].
Teerlink JR, Metra M, Felker GM, et al. Relaxin for the treatment of patients with acute heart failure (Pre-RELAX-AHF): A multicentre, randomised, placebo-controlled, parallel-group, dose-finding phase IIb study. Lancet. Apr. 25. 2009;373(9673):1429-39. Exclude: BNP measure not FDA approved. [pmid: 19329178].
Tekten T, Yenisey C, Ceyhan C, et al. Correlation between N-terminal pro B-natriuretic peptide and ultrasonic backscatter: Implications for diastolic dysfunction in hypertension. Echocardiograph. Sep. 2007;24(8):837-42. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Tello-Montoliu A, Marin F, Roldan V, et al. A multimarker risk stratification approach to non-ST elevation acute coronary syndrome: Implications of troponin T, CRP, NT pro-BNP and fibrin D-dimer levels. J Intern Med. Dec. 2007;262(6):651-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17986200].
Tepper D, Harris S, Ip R. The role of N-terminal pro-brain natriuretic peptide and echocardiography for screening asymptomatic left ventricular dysfunction in a population at high risk for heart failure: The PROBE-HF study. Congest Heart Fail. 2009;15(6):296. Exclude: Not a primary study.
Terasaki F, Okamoto H, Onishi K, et al. Higher serum tenascin-C levels reflect the severity of heart failure, left ventricular dysfunction and remodeling in patients with dilated cardiomyopathy. Circ J. 2007;71(3):327-30. Exclude: BNP measure not FDA approved. [pmid: 17322629].
Thackray SD, Witte K, Ghosh J, et al. N-terminal brain natriuretic peptide as a screening tool for heart failure in the pacemaker population. Eur Heart J. Feb. 2006;27(4):447-53. Exclude: BNP measure not FDA approved. [pmid: 16299020].
Tharaux PL, Dussaule JC, Hubert-Brierre J, et al. Plasma atrial and brain natriuretic peptides in mitral stenosis treated by valvulotomy. Clin Sci. Dec. 1994;87(6):671-7. Exclude: BNP measure not FDA approved. [pmid: 7874858].
Themudo RE, Lindahl B, Johansson L, et al. Unrecognized myocardial scars detected by delayed-enhanced MRI are associated with increased levels of NT-proBNP. Coron Artery Dis. May. 2011;22(3):158-64. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21200318].
Theuns DAMJ, Smith T, Szili-Torok T, et al. Prognostic role of high-sensitivity C-reactive protein and B-type natriuretic peptide in implantable cardioverter-defibrillator patients. PACE. 2012;35(3):275-82. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 22150371].
Thomas MD, Fox KF, Wood DA, et al. Echocardiographic features and brain natriuretic peptides in patients presenting with heart failure and preserved systolic function. Heart. May. 2006;92(5):603-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16159966].
Thomopoulou S, Manginas A, Cokkinos DV. Initial experience with the Impella Recover LP 2.5 micro-axial pump in patients undergoing high-risk coronary angioplasty. HJC Hell J Cardiol. Nov. 2008;49(6):382-7. Exclude: BNP measure not FDA approved.
Thompson LO, Skrabal CA, Loebe M, et al. Plasma neurohormone levels correlate with left ventricular functional and morphological improvement in LVAD patients. J Surg Res. Jan. 2005;123(1):25-32. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 15652947].
Tietge WJ, de Heer LM, van Hessen MWJ, et al. Early mitral valve repair versus watchful waiting in patients with severe asymptomatic organic mitral regurgitation; Rationale and design of the Dutch AMR trial, a multicenter, randomised trial. Neth Heart J. 2012;20(3):94-101. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 22354529].
Tigen K, Karaahmet T, Kahveci G, et al. N-terminal pro brain natriuretic peptide to predict prognosis in dilated cardiomyopathy with sinus rhythm. Heart Lung Circ. 2007;16(4):290-4. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17403613].
Tigen K, Karaahmet T, Tanalp AC, et al. Value of clinical, electrocardiographic, echocardiographic and neurohumoral parameters in non-ischaemic dilated cardiomyopathy. Acta Cardiol. Apr. 2008;63(2):207-12. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18468202].
Tigen K, Karaahmet T, Cevik C, et al. Prognostic utility of anemia and pro-B-type natriuretic peptide in patients with nonischemic dilated cardiomyopathy and normal renal function. Am J Med Sci. Feb. 2009;337(2):109-15. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19214026].
Tildesley HD, Aydin CM, Ignaszewski A, et al. Sulfonylurea therapy is associated with increased NT-proBNP levels in the treatment of type 2 diabetes. Int J Cardiol. Feb. 14. 2007;115(3):312-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16824633].
Timoteo AT, Toste A, Ramos R, et al. Does admission NT-proBNP increase the prognostic accuracy of GRACE risk score in the prediction of short-term mortality after acute coronary syndromes?. Acute Card Care. 2009;11(4):236-42. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19742352].
Tingberg E, Roijer A, Thilen U, et al. Neurohumoral changes in patients with left ventricular dysfunction following acute myocardial infarction and the effect of nitrate therapy: A randomized, double-blind, placebo-controlled long-term study. J Cardiovasc Pharmacol. Oct. 2006;48(4):166-72. Exclude: BNP measure not FDA approved. [pmid: 17086095].
Tjeerdsma G, van Wijk LM, Molhoek GP, et al. Autonomic and hemodynamic effects of a new selective dopamine agonist, CHF1035, in patients with chronic heart failure. Cardiovasc Drugs Ther. 2001;15(2):139-45. Exclude: BNP measure not FDA approved. [pmid: 11669407].
Tjeerdsma G, de Boer RA, Boomsma F, et al. Rapid bedside measurement of brain natriuretic peptide in patients with chronic heart failure. Int J Cardiol. Dec. 2002;86(2-3):143-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 12419550].
Toblli JE, Lombrana A, Duarte P, et al. Intravenous iron reduces NT-pro-brain natriuretic peptide in anemic patients with chronic heart failure and renal insufficiency. J Am Coll Cardiol. Oct. 23. 2007;50(17):1657-65. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17950147].
Toda G, Shibata S, Nakamizo R, et al. Effect of physical exercise training on health-related quality of life and exercise tolerance in patients with left ventricular dysfunction. J Cardiol. 2004;44(5):179-87. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 15584249].
Toda K, Sato Y, Hara T, et al. Correlates of NT-proBNP concentration in patients with essential hypertension in absence of congestive heart failure. J Clin Lab Anal. 2010;24(1):12-6. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20087954].
Todd J, Austwick T, Berridge D, et al. B-type natriuretic peptide in lymphedema. Lymphol. Mar. 2011;44(1):29-34. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Togashi K, Kameya T, Ando K, et al. Brain natriuretic peptides in human plasma, spinal cord and cerebrospinal fluid. Clin Chim Acta. Sep. 30. 1991;201(3):193-200. Exclude: BNP measure not FDA approved. [pmid: 1756592].
Togashi K, Ando K, Hasegawa N, et al. Concentrations of brain natriuretic peptide in treated congestive heart failure. Clin Chem. May. 1991;37(5):765. Exclude: BNP measure not FDA approved. [pmid: 1827759].
Toggweiler S, Borst O, Enseleit F, et al. NT-proBNP provides incremental prognostic information in cardiac outpatients with and without echocardiographic findings. Clin Cardiol. Mar. 2011;34(3):183-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21400546].
Tomasi L, Zanotto G, Zanolla L, et al. Physiopathologic correlates of intrathoracic impedance in chronic heart failure patients. Pacing Clin Electrophysiol. Apr. 2011;34(4):407-13. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21091745].
Tomcsanyi J, Nagy E, Somloi M, et al. NT-brain natriuretic peptide levels in pleural fluid distinguish between pleural transudates and exudates. Eur J Heart Fail. Oct. 2004;6(6):753-6. Exclude: BNP measure not FDA approved. [pmid: 15542412].
Tomita H, Takamuro M, Soda W, et al. Increased serum high-sensitivity C-reactive protein is related to hypoxia and brain natriuretic peptide in congenital heart disease. Pediatr Int. Aug. 2008;50(4):436-40. Exclude: BNP measure not FDA approved. [pmid: 19143963].
Tomova GS, Nimbal V, Horwich TB. Relation between hemoglobin A1c and outcomes in heart failure patients with and without diabetes mellitus. Am J Cardiol. 2012;109(12):1767-73. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 22459300].
Topcuoglu C, Yilmaz FM, Sahin D, et al. Total-and lipid-associated sialic acid in serum and thrombocytes in patients with chronic heart failure. Clin Biochem. 2010;43(4-5):447-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19962973].
Torralba-Cabeza MA, Olivera S, Hughes DA, et al. Cystatin C and NT-proBNP as prognostic biomarkers in Fabry disease. Mol Genet Metabol. Nov. 2011;104(3):301-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Tosa S, Watanabe H, Iino K, et al. Usefulness of plasma BNP levels as a marker of left ventricular wall stress in obese individuals. Int Heart J. Mar. 2009;50(2):173-82. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19367028].
Totsuka N, Awata N, Takahashi K, et al. A single-center, open-label, randomized, parallel-group study assessing the differences between an angiotensin II receptor antagonist and an angiotensin-converting enzyme inhibitor in hypertensive patients with congestive heart failure: The research for efficacy of angiotensin II receptor antagonist in hypertensive patients with congestive heart failure study. Curr Therapeut Res. 2003;64(2):81-94. Exclude: BNP measure not FDA approved.
Totsune K, Takahashi K, Murakami O, et al. Elevated plasma C-type natriuretic peptide concentrations in patients with chronic renal failure. Clin Sci. 1994;87(3):319-22. Exclude: BNP measure not FDA approved. [pmid: 7955908].
Trape J, Perez A, Naval I, et al. Nt-proBNP in haemodialysis patients: A preliminary study. Scand J Clin Lab Invest. 2008;68(5):415-20. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19172698].
Travers B, O'Loughlin C, Murphy NF, et al. Fluid restriction in the management of decompensated heart failure: No impact on time to clinical stability. J Card Fail. Mar. 2007;13(2):128-32. Exclude: BNP measure not FDA approved. [pmid: 17395053].
Treggiari MM, Bendjelid K, Yanez ND, et al. Atrial and brain natriuretic peptide concentrations and the response to inhaled nitric oxide in patients with acute respiratory distress syndrome. J Crit Care. Mar. 2010;25(1):23-9. Exclude: BNP measure not FDA approved. [pmid: 19327320].
Tretjak M, Verovnik F, Benko D, et al. Tissue Doppler velocities of mitral annulus and NT-proBNP in patients with heart failure. Eur J Heart Fail. Jun. 2005;7(4):520-4. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 15921789].
Triepels RH, Busscher S, Meer-Tinnemeier M, et al. N-terminal pro-brain natriuretic peptide (NT-proBNP) as early diagnostic marker for exclusion of the diagnose heart failure. Nederlands Tijdschrift Klin Chem Lab. 2004;29(1):29-32. Exclude: Not in English.
Tripepi G, Mattace-Raso F, Mallamaci F, et al. Biomarkers of left atrial volume: A longitudinal study in patients with end stage renal disease. Hypertens. Oct. 2009;54(4):818-24. Exclude: BNP measure not FDA approved.
Trivax JE, Franklin BA, Goldstein JA, et al. Acute cardiac effects of marathon running. J Appl Physiol. May. 2010;108(5):1148-53. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20150567].
Troisi F, Greco S, Brunetti ND, et al. Right heart dysfunction assessed with echography, B-type natriuretic peptide and cardiopulmonary test in patients with chronic heart failure. J Cardiovasc Med. Jul. 2008;9(7):672-6. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Trojnarska O, Gwizdala A, Katarzynski S, et al. Evaluation of exercise capacity with cardiopulmonary exercise test and B-type natriuretic peptide in adults with congenital heart disease. Cardiol J. 2009;16(2):133-41. Exclude: BNP measure not FDA approved. [pmid: 19387960].
Trojnarska O, Gwizdala A, Katarzynski S, et al. The BNP concentrations and exercise capacity assessment with cardiopulmonary stress test in cyanotic adult patients with congenital heart diseases. Int J Cardiol. Mar. 18. 2010;139(3):241-7. Exclude: BNP measure not FDA approved. [pmid: 19042041].
Troughton RW, Frampton CM, Yandle TG, et al. Treatment of heart failure guided by plasma aminoterminal brain natriuretic peptide (N-BNP) concentrations. Lancet. Apr. 1. 2000;355(9210):1126-30. Exclude: BNP measure not FDA approved. [pmid: 10791374].
Troughton RW, Richards AM, Nicholls MG. Individualized treatment of heart failure. Intern Med J. Apr. 2001;31(3):138-41. Exclude: Not a primary study. [pmid: 11478341].
Troughton RW, Frampton CM, Yandle TG, et al. Plasma amino-terminal B-type natriuretic peptide measured by Elecsys 2010 assay in a trial of hormone-guided treatment for heart failure. Clin Chem. Jul. 2003;49(7):1212-5. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 12816929].
Troughton RW, Prior DL, Pereira JJ, et al. Plasma B-type natriuretic peptide levels in systolic heart failure: Importance of left ventricular diastolic function and right ventricular systolic function. J Am Coll Cardiol. Feb. 4. 2004;43(3):416-22. Exclude: BNP measure not FDA approved. [pmid: 15013124].
Truong QA, Siegel E, Karakas M, et al. Relation of natriuretic peptides and midregional proadrenomedullin to cardiac chamber volumes by computed tomography in patients without heart failure: from the ROMICAT Trial. Clin Chem. Apr. 2010;56(4):651-60. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20185624].
Tschope C, Kasner M, Westermann D, et al. Elevated NT-ProBNP levels in patients with increased left ventricular filling pressure during exercise despite preserved systolic function. J Card Fail. Jun. 2005;11(5 Suppl):S28-33. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 15948097].
Tschope C, Kasner M, Westermann D, et al. The role of NT-proBNP in the diagnostics of isolated diastolic dysfunction: Correlation with echocardiographic and invasive measurements. Eur Heart J. Nov. 2005;26(21):2277-84. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16014646].
Tsuchida K, Tanabe K. Plasma brain natriuretic peptide concentrations and the risk of cardiovascular events and death in general practice. J Cardiol. Dec. 2008;52(3):212-23. Exclude: BNP measure not FDA approved. [pmid: 19027599].
Tsuda E, Uchiyama T, Abe T. Management of acute myocardial dysfunction with disturbed consciousness due to Kawasaki disease. Pediatr Int. 2012;54(3):e10-e14. Exclude: Population aged under 18. [pmid: 22631582].
Tsuji H, Nishino N, Kimura Y, et al. Haemoglobin level influences plasma brain natriuretic peptide concentration. Acta Cardiol. Oct. 2004;59(5):527-31. Exclude: BNP measure not FDA approved. [pmid: 15529559].
Tsutamoto T, Wada A, Maeda K, et al. Attenuation of compensation of endogenous cardiac natriuretic peptide system in chronic heart failure: Prognostic role of plasma brain natriuretic peptide concentration in patients with chronic symptomatic left ventricular dysfunction. Circ. Jul. 15. 1997;96(2):509-16. Exclude: BNP measure not FDA approved.
Tsutamoto T, Wada A, Maeda K, et al. Digitalis increases brain natriuretic peptide in patients with severe congestive heart failure. Am Heart J. Nov. 1997;134(5 Pt 1):910-6. Exclude: BNP measure not FDA approved. [pmid: 9398103].
Tsutamoto T, Wada A, Maeda K, et al. Plasma brain natriuretic peptide level as a biochemical marker of morbidity and mortality in patients with asymptomatic or minimally symptomatic left ventricular dysfunction. Comparison with plasma angiotensin II and endothelin-1. Eur Heart J. Dec. 1999;20(24):1799-807. Exclude: BNP measure not FDA approved. [pmid: 10581138].
Tsutamoto T, Wada A, Hisanaga T, et al. Relationship between endothelin-1 extraction in the peripheral circulation and systemic vascular resistance in patients with severe congestive heart failure. J Am Coll Cardiol. Feb. 1999;33(2):530-7. Exclude: BNP measure not FDA approved. [pmid: 9973035].
Tsutamoto T, Wada A, Maeda K, et al. Angiotensin II type 1 receptor antagonist decreases plasma levels of tumor necrosis factor alpha, interleukin-6 and soluble adhesion molecules in patients with chronic heart failure. J Am Coll Cardiol. Mar. 1. 2000;35(3):714-21. Exclude: BNP measure not FDA approved. [pmid: 10716475].
Tsutamoto T, Wada A, Maeda K, et al. Effect of spironolactone on plasma brain natriuretic peptide and left ventricular remodeling in patients with congestive heart failure. J Am Coll Cardiol. Apr. 2001;37(5):1228-33. Exclude: BNP measure not FDA approved. [pmid: 11300427].
Tsutamoto T, Wada A, Maeda K, et al. Relationship between plasma levels of cardiac natriuretic peptides and soluble Fas: Plasma soluble Fas as a prognostic predictor in patients with congestive heart failure. J Card Fail. Dec. 2001;7(4):322-8. Exclude: BNP measure not FDA approved. [pmid: 11782855].
Tsutamoto T, Wada A, Maeda K, et al. Transcardiac gradient of aldosterone before and after spironolactone in patients with congestive heart failure. J Cardiovasc Pharmacol. Jan. 2003;41(Suppl 1):S19-22. Exclude: BNP measure not FDA approved. [pmid: 12688391].
Tsutamoto T, Wada A, Sakai H, et al. Relationship between renal function and plasma brain natriuretic peptide in patients with heart failure. J Am Coll Cardiol. Feb. 7. 2006;47(3):582-6. Exclude: BNP measure not FDA approved. [pmid: 16458140].
Tsutamoto T, Sakai H, Tanaka T, et al. Comparison of active renin concentration and plasma renin activity as a prognostic predictor in patients with heart failure. Circ J. 2007;71(6):915-21. Exclude: BNP measure not FDA approved. [pmid: 17526990].
Tsutamoto T, Asai S, Tanaka T, et al. Plasma level of cardiotrophin-1 as a prognostic predictor in patients with chronic heart failure. Eur J Heart Fail. Oct. 2007;9(10):1032-7. Exclude: BNP measure not FDA approved. [pmid: 17766177].
Tsutamoto T, Sakai H, Ishikawa C, et al. Direct comparison of transcardiac difference between brain natriuretic peptide (BNP) and N-terminal pro-BNP in patients with chronic heart failure. Eur J Heart Fail. 2007;9(6-7):667-73. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17360233].
Tsutamoto T, Tanaka T, Sakai H, et al. Beneficial effect of perindopril on cardiac sympathetic nerve activity and brain natriuretic peptide in patients with chronic heart failure: comparison with enalapril. Circ J. May. 2008;72(5):740-6. Exclude: BNP measure not FDA approved. [pmid: 18441453].
Tsutamoto T, Yamaji M, Kawahara C, et al. Effect of simvastatin vs. rosuvastatin on adiponectin and haemoglobin A1c levels in patients with non-ischaemic chronic heart failure. Eur J Heart Fail. Dec. 2009;11(12):1195-201. Exclude: BNP measure not FDA approved. [pmid: 19889690].
Tsutamoto TS. Effect of atorvastatin vs. rosuvastatin on cardiac sympathetic nerve activity in non-diabetic patients with dilated cardiomyopathy. Circ J. 2011;75(9):2160-6. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21737951].
Tsutsui T, Tsutamoto T, Maeda K, et al. Comparison of neurohumoral effects of short-acting and long-acting loop diuretics in patients with chronic congestive heart failure. J Cardiovasc Pharmacol. 2001;38(Suppl 1):S81-5. Exclude: BNP measure not FDA approved. [pmid: 11811366].
Tsutsui T, Tsutamoto T, Wada A, et al. Plasma oxidized low-density lipoprotein as a prognostic predictor in patients with chronic congestive heart failure. J Am Coll Cardiol. Mar. 20. 2002;39(6):957-62. Exclude: BNP measure not FDA approved. [pmid: 11897436].
Tulevski II, ten Wolde M, van Veldhuisen DJ, et al. Combined utility of brain natriuretic peptide and cardiac troponin T may improve rapid triage and risk stratification in normotensive patients with pulmonary embolism. Int J Cardiol. Mar. 20. 2007;116(2):161-6. Exclude: BNP measure not FDA approved. [pmid: 16814410].
Tung PP, Olmsted E, Kopelnik A, et al. Plasma B-type natriuretic peptide levels are associated with early cardiac dysfunction after subarachnoid hemorrhage. Stroke. Jul. 2005;36(7):1567-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 15947264].
Tung RH, Garcia C, Morss AM, et al. Utility of B-type natriuretic peptide for the evaluation of intensive care unit shock. Crit Care Med. Aug. 2004;32(8):1643-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 15286538].
Turkmen KY, Guvener DN, Yildirir A, et al. Effects of rosiglitazone on plasma brain natriuretic peptide levels and myocardial performance index in patients with type 2 diabetes mellitus. Acta Diabetol. Sep. 2007;44(3):149-56. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17721754].
Turner KL, Moore LJ, Todd SR, et al. Identification of cardiac dysfunction in sepsis with B-type natriuretic peptide. J Am Coll Surg. Jul. 2011;213(1):139-46. Exclude: BNP measure not FDA approved. [pmid: 21514182].
Tutarel O, Denecke A, Bode-Boger SM, et al. Asymmetrical dimethylarginine - More sensitive than NT-proBNP to diagnose heart failure in adults with congenital heart disease. PLoS ONE. 2012;7(3). Exclude: BNP measure not FDA approved.
Tutarel O, Meyer GP, Bertram H, et al. Safety and efficiency of chronic ACE inhibition in symptomatic heart failure patients with a systemic right ventricle. Int J Cardiol. 2012;154(1):14-6. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20843567].
Tuttolomondo A, Pinto A, Di RD, et al. Changes in natriuretic peptide and cytokine plasma levels in patients with heart failure, after treatment with high dose of furosemide plus hypertonic saline solution (HSS) and after a saline loading. Nutr Metab Cardiovasc Dis. May. 2011;21(5):372-9. Exclude: BNP measure not FDA approved. [pmid: 20346637].
Tveit A, Seljeflot I, Grundvold I, et al. Candesartan, NT-proBNP and recurrence of atrial fibrillation after electrical cardioversion. Int J Cardiol. Jan. 9. 2009;131(2):234-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18201783].
Uchiyama T, Suga C, Matsumoto K, et al. QRS width does not reveal the indication for biventricular pacemaker. Therapeut Res. 2003;24(8):1516-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Uchiyama T, Matsumoto K, Suga C, et al. QRS width does not reflect ventricular dyssynchrony in patients with heart failure. J Artif Organs. 2005;8(2):100-3. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16094514].
Udelson JE, Pressler SJ, Sackner-Bernstein J, et al. Adherence with once daily versus twice daily Carvedilol in patients with heart failure: The compliance and quality of life study comparing once-daily controlled-release Carvedilol CR and twice-daily immediate-release Carvedilol IR in patients with heart failure (CASPER) trial. J Card Fail. 2009;15(5):385-93. Exclude: BNP measure not FDA approved. [pmid: 19477398].
Udelson JE, Feldman AM, Greenberg B, et al. Randomized, double-blind, multicenter, placebo-controlled study evaluating the effect of aldosterone antagonism with eplerenone on ventricular remodeling in patients with mild-to-moderate heart failure and left ventricular systolic dysfunction. Circ. May. 2010;3(3):347-53. Exclude: BNP measure not FDA approved.
Ueda R, Yokouchi M, Suzuki T, et al. Prognostic value of high plasma brain natriuretic peptide concentrations in very elderly persons. Am J Med. Mar. 2003;114(4):266-70. Exclude: BNP measure not FDA approved. [pmid: 12681452].
Ueland T, Jemtland R, Godang K, et al. Prognostic value of osteoprotegerin in heart failure after acute myocardial infarction. J Am Coll Cardiol. 2004;44(10):1970-6. Exclude: BNP measure not FDA approved. [pmid: 15542278].
Ueland T, Dahl CP, Gullestad L, et al. Circulating levels of non-phosphorylated undercarboxylated matrix Gla protein are associated with disease severity in patients with chronic heart failure. Clin Sci. Aug. 1. 2011;121(3):119-27. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21294711].
Ueland TA. Osteoprotegerin levels predict mortality in patients with symptomatic aortic stenosis. J Intern Med. 2011;270(5):452-60. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21623962].
Ueno A, Murasaki K, Hagiwara N, et al. Increases in circulating T lymphocytes expressing HLA-DR and CD40 ligand in patients with dilated cardiomyopathy. Heart Ves. Sep. 2007;22(5):316-21. Exclude: BNP measure not FDA approved.
Ueno H, Nakayama M, Kojima S, et al. The synergistic combined effect of anemia with high plasma levels of B-type natriuretic peptide significantly predicts an enhanced risk for major adverse cardiac events. Heart Ves. Jul. 2008;23(4):243-8. Exclude: BNP measure not FDA approved.
Ueno H, Yoshimura M, Nakayama M, et al. Clinical factors affecting serum potassium concentration in cardio-renal decompensation syndrome. Int J Cardiol. Jan. 21. 2010;138(2):174-81. Exclude: BNP measure not FDA approved. [pmid: 18804879].
Ueno S, Ikeda U, Hojo Y, et al. Serum hepatocyte growth factor levels are increased in patients with congestive heart failure. J Card Fail. 2001;7(4):329-34. Exclude: BNP measure not FDA approved. [pmid: 11782856].
Ugwu O, Chrysochoou G, Ashok M, et al. Assigning patients with heart failure to observation status: B-type natriuretic peptide, ejection fraction, or physician judgment. Congest Heart Fail. Jan. 2006;12(1):26-31. Exclude: BNP measure not FDA approved. [pmid: 16470089].
Ulimoen SR, Enger S, Tveit A. Impact of atrial fibrillation on NT-proBNP levels in a 75-year-old population. Scand J Clin Lab Invest. 2009;69(5):579-84. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19391062].
Ulrich S, Speich R, Domenighetti G, et al. Bosentan therapy for chronic thromboembolic pulmonary hypertension. Swiss Med Wkly. 2007;137(41-42):573-80. Exclude: BNP measure not FDA approved. [pmid: 17990150].
Uretsky BF, Thygesen K, Daubert JC, et al. Predictors of mortality from pump failure and sudden cardiac death in patients with systolic heart failure and left ventricular dyssynchrony: results of the CARE-HF trial. J Card Fail. Oct. 2008;14(8):670-5. Exclude: BNP measure not FDA approved. [pmid: 18926439].
Uriel N, Torre-Amione G, Milo O, et al. Echocardiographic ejection fraction in patients with acute heart failure: Correlations with hemodynamic, clinical, and neurohormonal measures and short-term outcome. Eur J Heart Fail. Aug. 2005;7(5):815-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16087136].
Ushijima A, Fukuma N, Kato Y, et al. Sympathetic excitation during exercise as a cause of attenuated heart rate recovery in patients with myocardial infarction. J Nippon Med Sch. Apr. 2009;76(2):76-83. Exclude: BNP measure not FDA approved. [pmid: 19443992].
Usuku H, Nakayama M, Sumida H, et al. Pump failure death and sudden cardiac death in patients with cardiac dysfunction: A search for prognostic predictive factors--A long-term follow-up study. J Cardiol. Jan. 2010;55(1):55-64. Exclude: BNP measure not FDA approved. [pmid: 20122549].
Uthamalingam S, Kandala J, Daley M, et al. Serum albumin and mortality in acutely decompensated heart failure. Am Heart J. 2010;160(6):1149-55. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21146671].
Uthoff HB. Central venous pressure and impaired renal function in patients with acute heart failure. Eur J Heart Fail. 2011;13(4):432-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21097472].
Vaes B, Delgado V, Bax J, et al. Diagnostic accuracy of plasma NT-proBNP levels for excluding cardiac abnormalities in the very elderly. BMC Geriatr. 2010;10:85. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21070664].
Valdes L, Jose ES, Pose A, et al. Diagnostic value of N-terminal pro-brain natriuretic peptide in pleural effusions of cardiac origin. Arch Bronconeumol. May. 2011;47(5):246-51. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21474229].
Valente S, Lazzeri C, Chiostri M, et al. NT-proBNP on admission for early risk stratification in STEMI patients submitted to PCI. Relation with extension of STEMI and inflammatory markers. Int J Cardiol. Feb. 6. 2009;132(1):84-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18207587].
Valle R, Prevaldi C, D'Eri A, et al. B-type natriuretic peptide predicts postdischarge prognosis in elderly patients admitted due to cardiogenic pulmonary edema. Am J Geriatr Cardiol. Jul. 2006;15(4):202-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16849885].
Valle R, Bagolin E, Canali C, et al. The BNP assay does not identify mild left ventricular diastolic dysfunction in asymptomatic diabetic patients. Eur J Echocardiogr. Jan. 2006;7(1):40-4. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 15886060].
Valli N, Georges A, Corcuff JB, et al. Assessment of brain natriuretic peptide in patients with suspected heart failure: Comparison with radionuclide ventriculography data. Clin Chim Acta. Apr. 2001;306(1-2):19-26. Exclude: BNP measure not FDA approved. [pmid: 11282090].
Valli N, Georges A, Mendes PA, et al. Effect of biventricular pacing on brain natriuretic peptide (BNP) in patient with dilated cardiomyopathy. Immuno. 2002;17(6):382-6. Exclude: Not in English.
Valzania C, Gadler F, Eriksson MJ, et al. Electromechanical effects of cardiac resynchronization therapy during rest and stress in patients with heart failure. Eur J Heart Fail. 2007;9(6-7):644-50. Exclude: BNP measure not FDA approved. [pmid: 17347041].
van Beers EJ, Nur E, Schaefer-Prokop CM, et al. Cardiopulmonary imaging, functional and laboratory studies in sickle cell disease associated pulmonary hypertension. Am J Hematol. Nov. 2008;83(11):850-4. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18819095].
Van Belle E, Dallongeville J, Vicaut E, et al. Ischemia-modified albumin levels predict long-term outcome in patients with acute myocardial infarction. The French Nationwide OPERA study. Am Heart J. 2010;159(4):570-6. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20362714].
Van Beneden R, Gurne O, Selvais PL, et al. Superiority of big endothelin-1 and endothelin-1 over natriuretic peptides in predicting survival in severe congestive heart failure: A 7-year follow-up study. J Card Fail. Dec. 2004;10(6):490-5. Exclude: BNP measure not FDA approved. [pmid: 15599839].
Van Berendoncks AM, Beckers P, Hoymans VY, et al. Exercise training reduces circulating adiponectin levels in patients with chronic heart failure. Clin Sci. Feb. 2010;118(4):281-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19656085].
Van Berendoncks AMB. Beta-blockers modify the prognostic value of adiponectin in chronic heart failure. Int J Cardiol. 2011;150(3):296-300. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20488568].
Van Bockel EAP, Lind JS, Zijlstra JG, et al. Cardiac assessment of patients with late stage Duchenne muscular dystrophy. Neth Heart J. 2009;17(6):232-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19789685].
Van Cheng BS, Kazanagra R, Garcia A, et al. A rapid bedside test for B-type peptide predicts treatment outcomes in patients admitted for decompensated heart failure: A pilot study. J Am Coll Cardiol. Feb. 2001;37(2):386-91. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 11216951].
Van Craenenbroeck EM, Pelle AJ, Beckers PJ, et al. Red cell distribution width as a marker of impaired exercise tolerance in patients with chronic heart failure. Eur J Heart Fail. Jan. 2012;14(1):54-60. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 22027082].
van de Pol AC, Frenken LA, Moret K, et al. An evaluation of blood volume changes during ultrafiltration pulses and natriuretic peptides in the assessment of dry weight in hemodialysis patients. Hemodial Int. Jan. 2007;11(1):51-61. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17257357].
van de Wal RM, Asselbergs FW, Plokker HW, et al. High prevalence of microalbuminuria in chronic heart failure patients. J Card Fail. Oct. 2005;11(8):602-6. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16230263].
van den Berg MP, Tjeerdsma G, Lefrandt JD, et al. Effect of lower body negative pressure in patients with mild congestive heart failure. Am J Cardiol. 2003;91(6):759-62. Exclude: BNP measure not FDA approved. [pmid: 12633820].
van den Hurk K, Reijmer YD, van den Berg E, et al. Heart failure and cognitive function in the general population: The Hoorn Study. Eur J Heart Fail. Dec. 2011;13(12):1362-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21990341].
van den HK, Alssema M, Kamp O, et al. Slightly elevated B-type natriuretic peptide levels in a non-heart failure range indicate a worse left ventricular diastolic function in individuals with, as compared with individuals without, type 2 diabetes: the Hoorn Study. Eur J Heart Fail. Sep. 2010;12(9):958-65. Exclude: BNP measure not FDA approved. [pmid: 20667891].
van der Burg-de Graauw, Cobbaert CM, Middelhoff CJ, et al. The additive value of N-terminal pro-B-type natriuretic peptide testing at the emergency department in patients with acute dyspnoea. Eur J Intern Med. May. 2009;20(3):301-6. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19393498].
Van Der Zee PMC. N-terminal pro B-type natriuretic peptide identifies patients with chest pain at high long-term cardiovascular risk. Am J Med. 2011;124(10):961-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21962317].
van der HP, de Boer RA, Samani NJ, et al. Telomere length and outcome in heart failure. Ann Med. 2010;42(1):36-44. Exclude: BNP measure not FDA approved. [pmid: 19941413].
van der MP, Voors AA, Lipsic E, et al. Prognostic value of plasma erythropoietin on mortality in patients with chronic heart failure. J Am Coll Cardiol. Jul. 7. 2004;44(1):63-7. Exclude: BNP measure not FDA approved. [pmid: 15234408].
van der MP, Lok DJ, Januzzi JL, et al. Adequacy of endogenous erythropoietin levels and mortality in anaemic heart failure patients. Eur Heart J. Jun. 2008;29(12):1510-5. Exclude: BNP measure not FDA approved. [pmid: 18495690].
van der ZJ, Oosterhof T, Tulevski II, et al. Comparison of segmental and global systemic ventricular function at rest and during dobutamine stress between patients with transposition and congenitally corrected transposition. Cardiol Young. 2005;15(2):148-53. Exclude: BNP measure not FDA approved. [pmid: 15845157].
van Gestel YR, Goei D, Hoeks SE, et al. Predictive value of NT-proBNP in vascular surgery patients with COPD and normal left ventricular systolic function. J Chron Obstruct Pulm Dis. Feb. 2010;7(1):70-5. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
van Hateren KJ, Alkhalaf A, Kleefstra N, et al. Comparison of midregional pro-A-type natriuretic peptide and the N-terminal pro-B-type natriuretic peptide for predicting mortality and cardiovascular events. Clin Chem. Jan. 2012;58(1):293-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21948291].
van Heur LM, Baur LH, Tent M, et al. Evaluation of an open access echocardiography service in the Netherlands: A mixed methods study of indications, outcomes, patient management and trends. BMC Health Serv Res. 2010;10:37. Exclude: BNP measure not FDA approved. [pmid: 20144244].
van Kimmenade RR, Pinto YM, Bayes-Genis A, et al. Usefulness of intermediate amino-terminal pro-brain natriuretic peptide concentrations for diagnosis and prognosis of acute heart failure. Am J Cardiol. Aug. 1. 2006;98(3):386-90. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16860029].
van Kimmenade RR, Mohammed AA, Uthamalingam S, et al. Red blood cell distribution width and 1-year mortality in acute heart failure. Eur J Heart Fail. Feb. 2010;12(2):129-36. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20026456].
Van Pelt NC, Stewart RA, Legget ME, et al. Longitudinal left ventricular contractile dysfunction after exercise in aortic stenosis. Heart. Jun. 2007;93(6):732-8. Exclude: BNP measure not FDA approved. [pmid: 17090563].
Van Tassell BW, Bhardwaj HL, Grizzard JD, et al. Right ventricular systolic dysfunction in patients with reperfused ST-segment elevation acute myocardial infarction. Int J Cardiol. 2012;155(2):314-6. Exclude: Not a primary study. [pmid: 22197216].
van Veldhuisen DJ, Genth-Zotz S, Brouwer J, et al. High- versus low-dose ACE inhibition in chronic heart failure: A double-blind, placebo-controlled study of imidapril. J Am Coll Cardiol. Dec. 1998;32(7):1811-8. Exclude: BNP measure not FDA approved. [pmid: 9857856].
van dH I, de Boer RA, Hillege HL, et al. Neurohormonal profile of patients with heart failure and diabetes. Neth Heart J. 2010;18(4):190-6. Exclude: BNP measure not FDA approved. [pmid: 20428417].
van WS, Jacobs L, Eurlings LW, et al. Troponin T measurements by high-sensitivity vs conventional assays for risk stratification in acute dyspnea. Clin Chem. Jan. 2012;58(1):284-92. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 22100806].
Vander Werf BD, Watt J, Joseph B, et al. Can plasma B-type natriuretic peptide levels predict need for mechanical ventilation after injury?. Am J Surg. 2010;200(6):845-50. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21146031].
Vanderheyden M, Bartunek, Claeys G, et al. Head to head comparison of N-terminal pro-B-type natriuretic peptide and B-type natriuretic peptide in patients with/without left ventricular systolic dysfunction. Clin Biochem. Jun. 2006;39(6):640-5. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16516185].
Vanderheyden M, Mullens W, Delrue L, et al. Myocardial gene expression in heart failure patients treated with cardiac resynchronization therapy responders versus nonresponders. J Am Coll Cardiol. Jan. 15. 2008;51(2):129-36. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18191736].
Vanzetto G, Jacon P, Calizzano A, et al. N-terminal pro-brain natriuretic peptide predicts myocardial ischemia and is related to postischemic left-ventricular dysfunction in patients with stable coronary artery disease. J Nucl Cardiol. Nov. 2007;14(6):835-42. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18022110].
Varpula M, Pulkki K, Karlsson S, et al. Predictive value of N-terminal pro-brain natriuretic peptide in severe sepsis and septic shock. Crit Care Med. May. 2007;35(5):1277-83. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17414731].
Vartany E, Imevbore M, O'Malley M, et al. N-terminal pro-brain natriuretic peptide for detection of cardiovascular stress in patients with obstructive sleep apnea syndrome. J Sleep Res. Dec. 2006;15(4):424-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17118099].
Vasan RS, Benjamin EJ, Larson MG, et al. Plasma natriuretic peptides for community screening for left ventricular hypertrophy and systolic dysfunction: The Framingham heart study. JAMA. Sep. 11. 2002;288(10):1252-9. Exclude: BNP measure not FDA approved. [pmid: 12215132].
Vassalle C, Andreassi MG, Prontera C, et al. Influence of ScaI and natriuretic peptide (NP) clearance receptor polymorphisms of the NP System on NP concentration in chronic heart failure. Clin Chem. Nov. 2007;53(11):1886-90. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17890443].
Vavera Z, Vojaceka J, Pudil R, et al. NT-proBNP levels on admission predicts pulmonary hypertension persistence in patients with acute pulmonary embolism. Cor et Vasa. 2012;54(1):e27-e31. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Vaz PA, Doehner W, von Haehling S, et al. The relationship between tumor necrosis factor-, brain natriuretic peptide and atrial natriuretic peptide in patients with chronic heart failure. Int J Cardiol. May. 14. 2010;141(1):39-43. Exclude: BNP measure not FDA approved. [pmid: 19155075].
Vazir A, Hastings PC, Dayer M, et al. A high prevalence of sleep disordered breathing in men with mild symptomatic chronic heart failure due to left ventricular systolic dysfunction. Eur J Heart Fail. 2007;9(3):243-50. Exclude: BNP measure not FDA approved. [pmid: 17030014].
Velagaleti RS, Gona P, Larson MG, et al. Multimarker approach for the prediction of heart failure incidence in the community. Circ. Oct. 26. 2010;122(17):1700-6. Exclude: BNP measure not FDA approved.
Velazquez-Cecena JL, Sharma S, Nagajothi N, et al. Left ventricular end diastolic pressure and serum brain natriuretic peptide levels in patients with abnormal impedance cardiography parameters. Arch Med Res. May. 2008;39(4):408-11. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18375252].
Venge P, James S, Jansson L, et al. Clinical performance of two highly sensitive cardiac troponin I assays. Clin Chem. Jan. 2009;55(1):109-16. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18988756].
Venge P, Arnlov J, Zethelius B. Seemingly healthy 71-year-old men with minor elevations of cardiac troponin I and at risk of premature death in CVD have elevated levels of NT-proBNP: Report from the ULSAM study. Scand J Clin Lab Invest. 2009;69(3):418-24. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19221927].
Verdiani V, Nozzoli C, Bacci F, et al. Pre-discharge B-type natriuretic peptide predicts early recurrence of decompensated heart failure in patients admitted to a general medical unit. Eur J Heart Fail. Jun. 2005;7(4):566-71. Exclude: BNP measure not FDA approved. [pmid: 15921796].
Vergaro G, Emdin M, Iervasi A, et al. Prognostic value of plasma renin activity in heart failure. Am J Cardiol. Jul. 15. 2011;108(2):246-51. Exclude: BNP measure not FDA approved. [pmid: 21545993].
Verges B, Zeller M, Beer JC, et al. Plasma N-terminal Pro-Brain Natriuretic Peptide (Nt-proBNP) level and prognosis after myocardial infarction in diabetes. Diabetes Metab. Feb. 2008;34:Suppl-5. Exclude: BNP measure not FDA approved.
Verma A, Kilicaslan F, Martin DO, et al. Preimplantation B-type natriuretic peptide concentration is an independent predictor of future appropriate implantable defibrillator therapies. Heart. Feb. 2006;92(2):190-5. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 15923278].
Vickery S, Price CP, John RI, et al. B-type natriuretic peptide (BNP) and amino-terminal proBNP in patients with CKD: Relationship to renal function and left ventricular hypertrophy. Am J Kidney Dis. Oct. 2005;46(4):610-20. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16183415].
Vila G, Resl M, Stelzeneder D, et al. Plasma NT-proBNP increases in response to LPS administration in healthy men. J Appl Physiol. Dec. 2008;105(6):1741-5. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18845786].
Vilas-Boas F, Feitosa GS, Soares MB, et al. Invasive and noninvasive correlations of B-type natriuretic peptide in patients with heart failure due to Chagas cardiomyopathy. Congest Heart Fail. May. 2008;14(3):121-6. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18550922].
Villacorta J, Oddoze C, Giorgi R, et al. Postoperative treatment with angiotensin-converting enzyme inhibitors in patients with preoperative reduced left ventricular systolic function. J Cardiothorac Vasc Anesth. Apr. 2008;22(2):187-91. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18375318].
Villacorta J, De Castro IS, Godinho M, et al. B-type natriuretic peptide is predictive of postoperative events in orthopedic surgery. Arq Bras Cardiol. 2010;95(6):743-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20857042].
Vinch CS, Aurigemma GP, Hill JC, et al. Usefulness of clinical variables, echocardiography, and levels of brain natriuretic peptide and norepinephrine to distinguish systolic and diastolic causes of acute heart failure. Am J Cardiol. May. 1. 2003;91(9):1140-3. Exclude: BNP measure not FDA approved. [pmid: 12714167].
Vinch CS, Rashkin J, Logsetty G, et al. Brain natriuretic peptide levels fall rapidly after cardioversion of atrial fibrillation to sinus rhythm. Cardiol. 2004;102(4):188-93. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Vinereanu D, Lim PO, Frenneaux MP, et al. Reduced myocardial velocities of left ventricular long-axis contraction identify both systolic and diastolic heart failure-A comparison with brain natriuretic peptide. Eur J Heart Fail. Jun. 2005;7(4):512-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 15921788].
Vitlianova KD, Donova TI, Apostolova MD, et al. Predictive factors for high brain (B-type) natriuretic peptide at discharge in properly treated heart failure patients. Folia Med. Jan. 2011;53(1):19-27. Exclude: BNP measure not FDA approved.
Vitturi NS. Thoracic ultrasonography: A new method for the work-up of patients with dyspnea. J Ultrasound. 2011;14(3):147-51. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 23396858].
Vogelsang TW, Jensen RJ, Monrad AL, et al. Independent effects of both right and left ventricular function on plasma brain natriuretic peptide. Eur J Heart Fail. Sep. 2007;9(9):892-6. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17613272].
Voigt A, Bartel K, Egerer K, et al. Humoral anti-proteasomal autoimmunity in dilated cardiomyopathy. Basic Res Cardiol. Jan. 2010;105(1):9-18. Exclude: Non-human population. [pmid: 19760349].
Volpicelli G, Caramello V, Cardinale L, et al. Bedside ultrasound of the lung for the monitoring of acute decompensated heart failure. Am J Emerg Med. Jun. 2008;26(5):585-91. Exclude: BNP measure not FDA approved. [pmid: 18534289].
von Eynatten M, Hamann A, Twardella D, et al. Relationship of adiponectin with markers of systemic inflammation, atherogenic dyslipidemia, and heart failure in patients with coronary heart disease. Clin Chem. May. 2006;52(5):853-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16556684].
von Haehling S, von Bardeleben RS, Kramm T, et al. Inflammation in right ventricular dysfunction due to thromboembolic pulmonary hypertension. Int J Cardiol. Oct. 8. 2010;144(2):206-11. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19411119].
Voors AA, Petrie CJ, Petrie MC, et al. Low pulse pressure is independently related to elevated natriuretic peptides and increased mortality in advanced chronic heart failure. Eur Heart J. Sep. 2005;26(17):1759-64. Exclude: BNP measure not FDA approved. [pmid: 15833758].
Voors AA, von Haehling S, Anker SD, et al. C-terminal provasopressin (copeptin) is a strong prognostic marker in patients with heart failure after an acute myocardial infarction: Results from the OPTIMAAL study. Eur Heart J. May. 2009;30(10):1187-94. Exclude: BNP measure not FDA approved. [pmid: 19346228].
Voors AA, van de Wal RM, Hartog JW, et al. Effects of eprosartan on diastolic function and neurohormones in patients with hypertension and diastolic dysfunction. Cardiovasc Drugs Ther. Feb. 2010;24(1):33-40. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20229056].
Vorlat A, Claeys MJ, Snoep L, et al. The determinants of B-type natriuretic peptide release in acute, non-ST-segment elevation myocardial infarction. Acta Cardiol. Jun. 2011;66(3):281-5. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21744696].
Voroneanu L, Cusai C, Hogas S, et al. The relationship between chronic volume overload and elevated blood pressure in hemodialysis patients: Use of bioimpedance provides a different perspective from echocardiography and biomarker methodologies. Int Urol Nephrol. 2010;42(3):789-97. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20521167].
Vorovich EE, Chuai S, Li M, et al. Comparison of matrix metalloproteinase 9 and brain natriuretic peptide as clinical biomarkers in chronic heart failure. Am Heart J. Jun. 2008;155(6):992-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18513509].
Voskaridou E, Tsetsos G, Tsoutsias A, et al. Pulmonary hypertension in patients with sickle cell/beta thalassemia: Incidence and correlation with serum N-terminal pro-brain natriuretic peptide concentrations. Haematol. Jun. 2007;92(6):738-43. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Vrijland E, Brienen J, Vrijland E, et al. Treatment of heart failure at home. Int J Integr Care. 2010;10:e114. Exclude: BNP measure not FDA approved. [pmid: 21289995].
Vuilleumier N, Righini M, Perrier A, et al. Correlation between cardiac biomarkers and right ventricular enlargement on chest CT in non massive pulmonary embolism. Thromb Res. 2008;121(5):617-24. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17716710].
Vuilleumier N, Le Gal G, Verschuren F, et al. Cardiac biomarkers for risk stratification in non-massive pulmonary embolism: A multicenter prospective study. J Thromb Haemostasis. Mar. 2009;7(3):391-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19087222].
Vural M, Akbas B, Acer M, et al. Blood B-type natriuretic peptide level increases in patients who complain shortness of breath and chest pain in the course of panic attack. Int J Cardiol. Apr. 25. 2007;117(2):e82-3. Exclude: BNP measure not FDA approved. [pmid: 17346817].
Wada Y, Kobayashi D, Murakami S, et al. Cardiac AA amyloidosis in a patient with rheumatoid arthritis and systemic sclerosis: The therapeutic potential of biological reagents. Scand J Rheumatol. 2011;40(5):402-4. Exclude: Not a primary study. [pmid: 21639824].
Wagner DR, Delagardelle C, Ernens I, et al. Matrix metalloproteinase-9 is a marker of heart failure after acute myocardial infarction. J Card Fail. Feb. 2006;12(1):66-72. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16500583].
Wagner DR, Roesch N, Harpes P, et al. Relationship between pulse transit time and blood pressure is impaired in patients with chronic heart failure. Clin Res Cardiol. 2010;99(10):657-64. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20473677].
Wagner FD, Buz S, Zais H, et al. Humoral and hemodynamic responses after left ventricular assist device implantation and heart transplantation. Exp Biol Med. Jun. 2006;231(6):861-4. Exclude: BNP measure not FDA approved.
Waku S, Iida N, Ishihara T. Significance of brain natriuretic peptide measurement as a diagnostic indicator of cardiac function. Methods Inf Med. Aug. 2000;39(3):249-53. Exclude: BNP measure not FDA approved. [pmid: 10992754].
Wallaschofski H, Saller B, Spilcke-Liss E, et al. Effects of growth hormone treatment on B-type natriuretic peptide as a marker of heart failure in adults with growth hormone deficiency. Horm Metab Res. Oct. 2006;38(10):656-61. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17075774].
Wallen T, Landahl S, Hedner T, et al. Brain natriuretic peptide in an elderly population. J Intern Med. Oct. 1997;242(4):307-11. Exclude: BNP measure not FDA approved. [pmid: 9366809].
Wallen T, Landahl S, Hedner T, et al. Brain natriuretic peptide predicts mortality in the elderly. Heart. Mar. 1997;77(3):264-7. Exclude: BNP measure not FDA approved. [pmid: 9093047].
Walter T, Brueckmann M, Lang S, et al. Comparison of long-term prognostic value of N-terminal-proBNP and midregional-pro-adrenomedullin in patients with acute myocardial infarction. Clin Lab. 2010;56(7-8):303-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20857894].
Wand O, Perles Z, Rein AJ, et al. Clinical, echocardiographic and humoral status of patients following repair of tetralogy of Fallot: Comparison of the second to the first decade. Isr Med Assoc J. Dec. 2007;9(12):843-6. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18210921].
Wang AY, Lam CW, Yu CM, et al. N-terminal pro-brain natriuretic peptide: An independent risk predictor of cardiovascular congestion, mortality, and adverse cardiovascular outcomes in chronic peritoneal dialysis patients. J Am Soc Nephrol. Jan. 2007;18(1):321-30. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17167121].
Wang AY, Lam CW, Wang M, et al. Diagnostic potential of serum biomarkers for left ventricular abnormalities in chronic peritoneal dialysis patients. Nephrol Dial Transplant. Jun. 2009;24(6):1962-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19237403].
Wang AY, Lam CW, Chan IH, et al. Sudden cardiac death in end-stage renal disease patients: A 5-year prospective analysis. Hypertens. Aug. 2010;56(2):210-6. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Wang DJ, Dowling TC, Meadows D, et al. Nesiritide does not improve renal function in patients with chronic heart failure and worsening serum creatinine. Circ. 2004;110(12):1620-5. Exclude: BNP measure not FDA approved.
Wang F, Xu ZM, Wang L, et al. Beneficial neurohormonal profiles of beta-blockades in chronic left heart failure. Chin J Intern Med. Jul. 2005;44(7):490-4. Exclude: Not in English.
Wang F, Pan W, Pan S, et al. Usefulness of N-terminal pro-brain natriuretic peptide and C-reactive protein to predict ICU mortality in unselected medical ICU patients: A prospective, observational study. Crit Care. 2011;15(1):R42. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21272380].
Wang F, Pan W, Wang H, et al. Relationship between thyroid function and ICU mortality: A prospective observation study. Crit Care. 2012;16(1). Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Wang HY, Xu QF, Xiao Y. Cardiac response to exercise in mild-to-moderate chronic obstructive pulmonary disease. J Geriatr Cardiol. 2009;6(3):147-50. Exclude: BNP measure not FDA approved.
Wang HY, Xu QF, Xiao Y, et al. Cardiac response and N-terminal-pro-brain natriuretic peptide kinetics during exercise in patients with COPD. Respir Care. Jun. 2011;56(6):796-9. Exclude: BNP measure not FDA approved. [pmid: 21333081].
Wang L, Lu L, Zhang F, et al. Polymorphisms of beta-adrenoceptor and natriuretic peptide receptor genes influence the susceptibility to and the severity of idiopathic dilated cardiomyopathy in a Chinese cohort. J Card Fail. 2010;16(1):36-44. Exclude: BNP measure not FDA approved. [pmid: 20123316].
Wang L, Geng J, Li J, et al. The biomarker N-terminal pro-brain natriuretic peptide and liver diseases. Clin Invest Med. 2011;34(1):E30-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21291633].
Wang LJ, Lu L, Zhang FR, et al. Increased serum high-mobility group box-1 and cleaved receptor for advanced glycation endproducts levels and decreased endogenous secretory receptor for advanced glycation endproducts levels in diabetic and non-diabetic patients with heart failure. Eur J Heart Fail. Apr. 2011;13(4):440-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21266376].
Wang R, Li X, Jang W, et al. Blood B-type natriuretic peptide changes in different periods and different cardiac pacing modes. Int Heart J. Nov. 2005;46(6):1015-22. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16394597].
Wang TJ, Larson MG, Levy D, et al. Impact of age and sex on plasma natriuretic peptide levels in healthy adults. Am J Cardiol. Aug. 1. 2002;90(3):254-8. Exclude: BNP measure not FDA approved. [pmid: 12127613].
Wang TJ, Larson MG, Levy D, et al. Heritability and genetic linkage of plasma natriuretic peptide levels. Circ. Jul. 8. 2003;108(1):13-6. Exclude: BNP measure not FDA approved.
Wang TJ, Larson MG, Levy D, et al. Impact of obesity on plasma natriuretic peptide levels. Circ. Feb. 10. 2004;109(5):594-600. Exclude: BNP measure not FDA approved.
Wang TJ, Larson MG, Levy D, et al. Plasma natriuretic peptide levels and the risk of cardiovascular events and death. N Engl J Med. Feb. 12. 2004;350(7):655-63. Exclude: BNP measure not FDA approved. [pmid: 14960742].
Wang TJ, Larson MG, Keyes MJ, et al. Association of plasma natriuretic peptide levels with metabolic risk factors in ambulatory individuals. Circ. Mar. 20. 2007;115(11):1345-53. Exclude: BNP measure not FDA approved.
Wang Y, Zhou Y, Meng L, et al. Inflammatory mediators in Chinese patients with congestive heart failure. J Clin Pharmacol. May. 2009;49(5):591-9. Exclude: BNP measure not FDA approved. [pmid: 19398605].
Wang Y, Moreira MC, Heringer-Walther S, et al. Amino-terminal fragment of C-type natriuretic peptide precursor and C-type natriuretic peptide do not correlate in patients with Chagas disease: Role for neutral endopeptidase. J Cardiovasc Pharmacol. Jan. 2010;55(1):62-6. Exclude: BNP measure not FDA approved. [pmid: 20090473].
Wang Y, Moreira MC, Heringer-Walther S, et al. Plasma ACE2 activity is an independent prognostic marker in Chagas' disease and equally potent as BNP. J Card Fail. Feb. 2010;16(2):157-63. Exclude: BNP measure not FDA approved. [pmid: 20142028].
Wang YL, Hua Q, Bai CR, et al. Relationship between red cell distribution width and short-term outcomes in acute coronary syndrome in a Chinese population. Intern Med. 2011;50(24):2941-5. Exclude: BNP measure not FDA approved. [pmid: 22185983].
Wang Z, Liang D, Fu Q, et al. Perioperative brain natriuretic peptide in off-pump coronary artery bypass. Acta Cardiol. Jun. 2010;65(3):297-301. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20666267].
Washio T, Nomoto K, Watanabe I, et al. Relationship between plasma homocysteine levels and congestive heart failure in patients with acute myocardial infarction. Homocysteine and congestive heart failure. Int Heart J. 2011;52(4):224-8. Exclude: BNP measure not FDA approved. [pmid: 21828948].
Wasywich CA, Webster MW, Richards AM, et al. Coronary sinus and ascending aortic levels of aldosterone, angiotensin II, and B-type natriuretic peptide in patients with aortic stenosis and in patients with coronary heart disease. Am J Cardiol. Apr. 1. 2006;97(7):1068-72. Exclude: BNP measure not FDA approved. [pmid: 16563918].
Wasywich CA, Whalley GA, Walsh HA, et al. The relationship between BNP and E/Ea in patients hospitalized with acute heart failure. Int J Cardiol. Apr. 10. 2008;125(2):280-2. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18035438].
Wasywich CA, Whalley GA, Walsh HA, et al. Changes in tissue-Doppler echocardiographic assessment of left ventricular filling during NT-proBNP guided heart failure treatment titration: a pilot study. Heart Lung Circ. Feb. 2009;18(1):38-44. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18818124].
Watanabe D, Shizuka K, Koyama S, et al. Plasma brain natriuretic peptide levels indicating thromboembolism in very elderly patients with non-valvular atrial fibrillation. Circ J. Sep. 2007;71(9):1446-51. Exclude: BNP measure not FDA approved. [pmid: 17721026].
Watanabe E, Matsuda N, Shiga T, et al. Significance of 8-hydroxy-2'-deoxyguanosine levels in patients with idiopathic dilated cardiomyopathy. J Card Fail. Sep. 2006;12(7):527-32. Exclude: BNP measure not FDA approved. [pmid: 16952786].
Watanabe H, Okamura K, Chinushi M, et al. Clinical characteristics, treatment, and outcome of tachycardia induced cardiomyopathy. Int Heart J. Jan. 2008;49(1):39-47. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18360063].
Watanabe I, Tani S, Washio T, et al. Relationship between the plasma levels of brain natriuretic peptide and left ventricular ejection fraction in asymptomatic patients with previous myocardial infarction. Int Heart J. Nov. 2005;46(6):1007-14. Exclude: BNP measure not FDA approved. [pmid: 16394596].
Watanabe J, Shiba N, Shinozaki T, et al. Prognostic value of plasma brain natriuretic peptide combined with left ventricular dimensions in predicting sudden death of patients with chronic heart failure. J Card Fail. Feb. 2005;11(1):50-5. Exclude: BNP measure not FDA approved. [pmid: 15704064].
Watanabe J, Shinozaki T, Shiba N, et al. Accumulation of risk markers predicts the incidence of sudden death in patients with chronic heart failure. Eur J Heart Fail. 2006;8(3):237-42. Exclude: BNP measure not FDA approved. [pmid: 16185924].
Watanabe M, Egi K, Hasegawa S, et al. Significance of serum atrial and brain natriuretic peptide release after coronary artery bypass grafting. Surg Today. 2003;33(9):671-3. Exclude: BNP measure not FDA approved. [pmid: 12928843].
Watanabe M, Kawaguchi S, Nakahara H, et al. The roles of natriuretic peptides in pericardial fluid in patients with heart failure. Clin Cardiol. Mar. 2009;32(3):159-63. Exclude: BNP measure not FDA approved. [pmid: 19301292].
Watanabe S, Shite J, Takaoka H, et al. Myocardial stiffness is an important determinant of the plasma brain natriuretic peptide concentration in patients with both diastolic and systolic heart failure. Eur Heart J. Apr. 2006;27(7):832-8. Exclude: BNP measure not FDA approved. [pmid: 16464912].
Watanabe S, Tamura T, Ono K, et al. Insulin-like growth factor axis (insulin-like growth factor-I/insulin-like growth factor-binding protein-3) as a prognostic predictor of heart failure: Association with adiponectin. Eur J Heart Fail. 2010;12(11):1214-22. Exclude: BNP measure not FDA approved. [pmid: 20851819].
Watanabe S, Shite J, Takaoka H, et al. Predictive importance of left ventricular myocardial stiffness for the prognosis of patients with congestive heart failure. J Cardiol. Nov. 2011;58(3):245-52. Exclude: BNP measure not FDA approved. [pmid: 21862290].
Watanabe T, Iwai-Takano M, Oikawa M, et al. Optimal noninvasive assessment of diastolic heart failure in patients with atrial fibrillation: Comparison of tissue doppler echocardiography, left atrium size, and brain natriuretic peptide. J Am Soc Echocardiogr. Jun. 2008;21(6):689-96. Exclude: BNP measure not FDA approved. [pmid: 17904810].
Watson CJ, Ledwidge MT, Phelan D, et al. Proteomic analysis of coronary sinus serum reveals leucine-rich alpha2-glycoprotein as a novel biomarker of ventricular dysfunction and heart failure. Circ. Mar. 1. 2011;4(2):188-97. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Weber CS. Novel biomarkers do not correlate with severity of vascular stiffness in ckd patients with severe co-morbid disease. Nephron. 2011;119(3):c261-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21921638].
Weber M, Arnold R, Rau M, et al. Relation of N-terminal pro-B-type natriuretic peptide to severity of valvular aortic stenosis. Am J Cardiol. Sep. 15. 2004;94(6):740-5. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 15374777].
Weber M, Dill T, Deetjen A, et al. Left ventricular adaptation after atrial septal defect closure assessed by increased concentrations of N-terminal pro-brain natriuretic peptide and cardiac magnetic resonance imaging in adult patients. Heart. May. 2006;92(5):671-5. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16216861].
Weber M, Hausen M, Arnold R, et al. Prognostic value of N-terminal pro-B-type natriuretic peptide for conservatively and surgically treated patients with aortic valve stenosis. Heart. Nov. 2006;92(11):1639-44. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16740919].
Weber M, Burian M, Dragutinovic I, et al. Genetic polymorphism of the type A human natriuretic peptide receptor (NPR-A) gene contributes to the interindividual variability in the BNP system. Eur J Heart Fail. May. 2008;10(5):482-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18436476].
Weber M, Bazzino O, Navarro Estrada JL, et al. N-terminal B-type natriuretic peptide assessment provides incremental prognostic information in patients with acute coronary syndromes and normal troponin T values upon admission. J Am Coll Cardiol. Mar. 25. 2008;51(12):1188-95. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18355657].
Weber T, Auer J, O'Rourke MF, et al. Prolonged mechanical systole and increased arterial wave reflections in diastolic dysfunction. Heart. 2006;92(11):1616-22. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16709696].
Weber U, Reitinger A, Erdeii T, et al. Effects of high-urgency ambulance transportation on pro-B-type natriuretic peptide levels in patients with heart failure. Am J Emerg Med. Jun. 2010;28(5):568-76. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20579551].
Wegrzynowska-Teodorczyk K, Rudzinska E, Jankowska E, et al. Determinants of physical fitness in males with systolic heart failure. Kardiol Pol. Feb. 2010;68(2):146-54. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20301023].
Wei CM, Heublein DM, Perrella MA, et al. Natriuretic peptide system in human heart failure. Circ. Sep. 1993;88(3):1004-9. Exclude: BNP measure not FDA approved.
Wei M, Ren S, Liu J, et al. Perioperative plasma brain natriuretic peptide and cardiotrophin-1 in off-pump coronary artery bypass. Scand Cardiovasc J. Dec. 2008;42(6):399-404. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18609050].
Wei S, Loyo-Berrios NI, Haigney MC, et al. Elevated B-type natriuretic peptide is associated with increased in-hospital mortality or cardiac arrest in patients undergoing implantable cardioverter-defibrillator implantation. Circ. May. 1. 2011;4(3):346-54. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Wei T, Zeng C, Tian Y, et al. B-type natriuretic peptide in patients with clinical hyperthyroidism. J Endocrinol Invest. Jan. 2005;28(1):8-11. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 15816364].
Wei T, Zeng C, Chen Q, et al. Plasma BNP levels are determined by the severity of left ventricular systolic dysfunction but not the types of underlying heart disease. Acta Cardiol. Jun. 2005;60(3):303-6. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 15999470].
Wei T, Zeng C, Chen L, et al. Systolic and diastolic heart failure are associated with different plasma levels of B-type natriuretic peptide. Int J Clin Pract. Aug. 2005;59(8):891-4. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16033608].
Wei TM, Jin L, Lv LC, et al. Changes in plasma B-type natriuretic peptide after allograft renal transplantation. Nephrology. Feb. 2007;12(1):102-6. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17295669].
Weinberg EO, Shimpo M, Hurwitz S, et al. Identification of serum soluble ST2 receptor as a novel heart failure biomarker. Circ. Feb. 11. 2003;107(5):721-6. Exclude: BNP measure not FDA approved.
Weir RA, Balmain S, Steedman T, et al. Tissue plasminogen activator antigen predicts medium-term left ventricular end-systolic volume after acute myocardial infarction. J Thromb Thrombolysis. May. 2010;29(4):421-8. Exclude: BNP measure not FDA approved. [pmid: 19662337].
Weir RA, Tsorlalis IK, Steedman T, et al. Aldosterone and cortisol predict medium-term left ventricular remodelling following myocardial infarction. Eur J Heart Fail. Dec. 2011;13(12):1305-13. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21940729].
Wellenius GA, Yeh GY, Coull BA, et al. Effects of ambient air pollution on functional status in patients with chronic congestive heart failure: A repeated-measures study. Environ Health. 2007;6:26. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17845720].
Wendelboe Nielsen O, Kirk V, Bay M, et al. Value of N-terminal pro brain natriuretic peptide in the elderly: Data from the prospective Copenhagen Hospital Heart Failure study (CHHF). Eur J Heart Fail. Mar. 15. 2004;6(3):275-9. Exclude: BNP measure not FDA approved. [pmid: 14987576].
Wermuth J, Staub D, Laule-Kilian K, et al. Neurohormonal activation and left ventricular ejection fraction in patients with suspected myocardial ischemia. Int J Cardiol. 2007;120(2):248-53. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17182131].
West MJ, Nestel PJ, Kirby AC, et al. The value of N-terminal fragment of brain natriuretic peptide and tissue inhibitor of metalloproteinase-1 levels as predictors of cardiovascular outcome in the LIPID study. Eur Heart J. Apr. 2008;29(7):923-31. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18296678].
Westhoff-Bleck MG. Pulmonary valve replacement in chronic pulmonary regurgitation in adults with congenital heart disease: Impact of preoperative QRS-duration and NT-proBNP levels on postoperative right ventricular function. Int J Cardiol. 2011;151(3):303-6. Exclude: BNP measure not FDA approved. [pmid: 20598759].
Westhoff M, Arzt M, Litterst P. Prevalence and treatment of central sleep apnoea emerging after initiation of continuous positive airway pressure in patients with obstructive sleep apnoea without evidence of heart failure. Sleep Breath. 2012;16(1):71-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21347650].
Whalley GA, Wright SP, Pearl A, et al. Prognostic role of echocardiography and brain natriuretic peptide in symptomatic breathless patients in the community. Eur Heart J. Feb. 2008;29(4):509-16. Exclude: BNP measure not FDA approved. [pmid: 18276620].
Whellan DJ, Cox M, Hernandez AF, et al. Utilization of hospice and predicted mortality risk among older patients hospitalized with heart failure: Findings from GWTG-HF. J Card Fail. 2012;18(6):471-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 22633304].
Whellan DJZ. Predictors of hospital length of stay in heart failure: Findings from get with the guidelines. J Card Fail. 2011;17(8):649-56. Exclude: BNP measure not FDA approved. [pmid: 21807326].
White M, Yusuf S, McKelvie RS, et al. Effects of metoprolol CR in patients with ischemic and dilated cardiomyopathy: The randomized evaluation of strategies for left ventricular dysfunction pilot study. Circ. 2000;101(4):378-84. Exclude: BNP measure not FDA approved.
White M, Lepage S, Lavoie J, et al. Effects of combined candesartan and ACE inhibitors on BNP, markers of inflammation and oxidative stress, and glucose regulation in patients with symptomatic heart failure. J Card Fail. Mar. 2007;13(2):86-94. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17395047].
White M, Rouleau JL, Afzal R, et al. Effects of enalapril, candesartan or both on neurohumoral activation and LV volumes and function in patients with heart failure not treated with a beta-blocker. Therapeut Adv Cardiovasc Dis. Apr. 2009;3(2):113-21. Exclude: BNP measure not FDA approved.
Whiteley W, Wardlaw J, Dennis M, et al. Blood biomarkers for the diagnosis of acute cerebrovascular diseases: A prospective cohort study. Cerebrovasc Dis. 2011;32(2):141-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21778711].
Widera C, Pencina MJ, Meisner A, et al. Adjustment of the GRACE score by growth differentiation factor 15 enables a more accurate appreciation of risk in non-ST-elevation acute coronary syndrome. Eur Heart J. 2012;33(9):1095-104. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 22199121].
Wieczorek SJ, Wu AH, Christenson R, et al. A rapid B-type natriuretic peptide assay accurately diagnoses left ventricular dysfunction and heart failure: A multicenter evaluation. Am Heart J. Nov. 2002;144(5):834-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 12422152].
Wieczorek SJ, Hager D, Barry MB, et al. Correlation of B-type natriuretic peptide level to 6-min walk test performance in patients with left ventricular systolic dysfunction. Clin Chim Acta. Feb. 2003;328(1-2):87-90. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 12559602].
Wieshammer S, Dreyhaupt J, Basler B, et al. NT-proBNP for pulmonologists: Not only a rule-out test for systolic heart failure but also a global marker of heart disease. Respiration. 2009;77(4):370-80. Exclude: BNP measure not FDA approved. [pmid: 19325226].
Wieshammer S, Dreyhaupt J, Basler B. A link between impaired lung function and increased cardiac stress. Respiration. 2010;79(5):355-62. Exclude: BNP measure not FDA approved. [pmid: 20016119].
Wieshammer S, Dreyhaupt J, Basler B. Theophylline and cardiac stress in patients with dyspnea: An observational study. Pharmacology. 2010;86(4):189-95. Exclude: BNP measure not FDA approved. [pmid: 20814224].
Wijbenga JA, Balk AH, Boomsma F, et al. Cardiac peptides differ in their response to exercise. Implications for patients with heart failure in clinical practice. Eur Heart J. Oct. 1999;20(19):1424-8. Exclude: BNP measure not FDA approved. [pmid: 10487803].
Wijeysundera HC, Hansen MS, Stanton E, et al. Neurohormones and oxidative stress in nonischemic cardiomyopathy: Relationship to survival and the effect of treatment with amlodipine. Am Heart J. Aug. 2003;146(2):291-7. Exclude: BNP measure not FDA approved. [pmid: 12891198].
Wikstrom G, Blomstrom-Lundqvist C, Andren B, et al. The effects of aetiology on outcome in patients treated with cardiac resynchronization therapy in the CARE-HF trial. Eur Heart J. Apr. 2009;30(7):782-8. Exclude: BNP measure not FDA approved. [pmid: 19168870].
Wild PS, Schnabel RB, Lubos E, et al. Midregional proadrenomedullin for prediction of cardiovascular events in coronary artery disease: Results from the AtheroGene study. Clin Chem. Jan. 2012;58(1):226-36. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 22065157].
Wiley CL, Switzer SP, Berg RL, et al. Association of B-type natriuretic Peptide levels with estimated glomerular filtration rate and congestive heart failure. Clin Med Res. Mar. 2010;8(1):7-12. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19920165].
Wilinski JC. Clinical and classic echocardiographic features of patients with, and without, left ventricle reverse remodeling following the introduction of cardiac resynchronization therapy. Cardiol J. 2011;18(2):157-64. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21432822].
Wilkins MA, Su XL, Palayew MD, et al. The effects of posture change and continuous positive airway pressure on cardiac natriuretic peptides in congestive heart failure. Chest. Apr. 1995;107(4):909-15. Exclude: BNP measure not FDA approved. [pmid: 7705152].
Wilkins MR, Paul GA, Strange JW, et al. Sildenafil versus Endothelin Receptor Antagonist for Pulmonary Hypertension (SERAPH) study. Am J Respir Crit Care Med. Jun. 1. 2005;171(11):1292-7. Exclude: BNP measure not FDA approved. [pmid: 15750042].
Williams SG, Ng LL, O'Brien RJ, et al. Comparison of plasma N-brain natriuretic peptide, peak oxygen consumption, and left ventricular ejection fraction for severity of chronic heart failure. Am J Cardiol. Jun. 15. 2004;93(12):1560-1. Exclude: BNP measure not FDA approved. [pmid: 15194038].
Williams SG, Ng LL, O'Brien RJ, et al. Is plasma N-BNP a good indicator of the functional reserve of failing hearts? The FRESH-BNP study. Eur J Heart Fail. Dec. 2004;6(7):891-900. Exclude: BNP measure not FDA approved. [pmid: 15556051].
Williams SG, Ng LL, O'Brien RJ, et al. Complementary roles of simple variables, NYHA and N-BNP, in indicating aerobic capacity and severity of heart failure. Int J Cardiol. Jul. 10. 2005;102(2):279-86. Exclude: BNP measure not FDA approved. [pmid: 15982497].
Williams SG, Jackson M, Ng LL, et al. Exercise duration and peak systolic blood pressure are predictive of mortality in ambulatory patients with mild-moderate chronic heart failure. Cardiol. 2005;104(4):221-6. Exclude: BNP measure not FDA approved.
Willis MS, Lee ES, Grenache DG. Effect of anemia on plasma concentrations of NT-proBNP. Clin Chim Acta. Aug. 2005;358(1-2):175-81. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 15878465].
Wilson Tang WHW. Diminished antioxidant activity of high-density lipoprotein-associated proteins in systolic heart failure. Circ. 2011;4(1):59-64. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Wilson SRS. Assessment of adiponectin and the risk of recurrent cardiovascular events in patients presenting with an acute coronary syndrome: Observations from the Pravastatin or atorVastatin Evaluation and Infection Trial-Thrombolysis in Myocardial Infarction 22 (PROVE IT-TIMI 22). Am Heart J. 2011;161(6):1147-55. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21641362].
Windram JD, Loh PH, Rigby AS, et al. Relationship of high-sensitivity C-reactive protein to prognosis and other prognostic markers in outpatients with heart failure. Am Heart J. Jun. 2007;153(6):1048-55. Exclude: BNP measure not FDA approved. [pmid: 17540208].
Winkler K, Hoffmann MM, Winkelmann BR, et al. Lipoprotein-associated phospholipase A_2_ predicts 5-year cardiac mortality independently of established risk factors and adds prognostic information in patients with low and medium high-sensitivity C-reactive protein (The Ludwigshafen Risk and Cardiovascular Health Study). Clin Chem. 2007;53(8):1440-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17573419].
Winter MM, Bouma BJ, van Dijk AP, et al. Relation of physical activity, cardiac function, exercise capacity, and quality of life in patients with a systemic right ventricle. Am J Cardiol. Nov. 1. 2008;102(9):1258-62. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18940303].
Wintgens KF, Dschietzig T, Stoeva S, et al. Plasma myostatin measured by a competitive ELISA using a highly specific antiserum. Clin Chim Acta. 2012;413(15-16):1288-94. Exclude: BNP measure not FDA approved. [pmid: 22561185].
Wirtz PH, Redwine LS, Hong S, et al. Increases in B-type natriuretic peptide after acute mental stress in heart failure patients are associated with alcohol consumption. J Stud Alcohol. Sep. 2010;71(5):786-94. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Wita K, Filipecki A, Wrobel W, et al. NT-proBNP level in the diagnosis of isolated left ventricular diastolic dysfunction in patients with documented coronary artery disease. Folia Cardiol. 2006;13(7):620-5. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Wita K, Filipecki A, Szydlo K, et al. Prediction of long-term outcome after primary percutaneous coronary intervention for acute anterior myocardial infarction. Kardiol Pol. Apr. 2010;68(4):393-400. Exclude: BNP measure not FDA approved. [pmid: 20425697].
Witham MD, Gillespie ND, Hutcheon SD, et al. B-type natriuretic peptide is associated with mortality in older functionally impaired patients. J Am Geriatr Soc. Nov. 2005;53(11):1991-5. Exclude: BNP measure not FDA approved. [pmid: 16274384].
Witham MD, Crighton LJ, Gillespie ND, et al. The effects of vitamin D supplementation on physical function and quality of life in older patients with heart failure: A randomized controlled trial. Circ. Mar. 2010;3(2):195-201. Exclude: BNP measure not FDA approved.
Witthaut R, Busch C, Fraunberger P, et al. Plasma atrial natriuretic peptide and brain natriuretic peptide are increased in septic shock: Impact of interleukin-6 and sepsis-associated left ventricular dysfunction. Intensive Care Med. Oct. 2003;29(10):1696-702. Exclude: BNP measure not FDA approved. [pmid: 12915939].
Wiviott SD, Cannon CP, Morrow DA, et al. Differential expression of cardiac biomarkers by gender in patients with unstable angina/non-ST-elevation myocardial infarction: A TACTICS-TIMI 18 (Treat Angina with Aggrastat and determine Cost of Therapy with an Invasive or Conservative Strategy-Thrombolysis In Myocardial Infarction 18) substudy. Circ. Feb. 10. 2004;109(5):580-6. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Wizner B, Dubiel JS, Opolski G, et al. Access to selected diagnostic procedures in the management of heart failure patients in Poland - POLKARD 2005. Kardiol Pol. Mar. 2010;68(3):265-72. Exclude: BNP measure not FDA approved. [pmid: 20411450].
Wojnicz R, Nowak J, Szygula-Jurkiewicz B, et al. Adjunctive therapy with low-molecular-weight heparin in patients with chronic heart failure secondary to dilated cardiomyopathy: One-year follow-up results of the randomized trial. Am Heart J. Oct. 2006;152(4):713-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16996844].
Wolber T, Maeder M, Weilenmann D, et al. Integration of B-type natriuretic peptide levels with clinical data and exercise testing for predicting coronary artery disease. Am J Cardiol. Sep. 15. 2006;98(6):764-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16950181].
Wold KC, Vik-Mo H, Omland T. Blood haemoglobin is an independent predictor of B-type natriuretic peptide (BNP). Clin Sci. Jul. 2005;109(1):69-74. Exclude: BNP measure not FDA approved. [pmid: 15755257].
Wolk R, Johnson BD, Somers VK. Leptin and the ventilatory response to exercise in heart failure. J Am Coll Cardiol. 2003;42(9):1644-9. Exclude: BNP measure not FDA approved. [pmid: 14607453].
Wolk R, Somers VK, Gibbons RJ, et al. Pathophysiological characteristics of heart rate recovery in heart failure. Med Sci Sports Exerc. Aug. 2006;38(8):1367-73. Exclude: BNP measure not FDA approved. [pmid: 16888447].
Wong KY, McSwiggan S, Kennedy NS, et al. B-type natriuretic peptide identifies silent myocardial ischaemia in stroke survivors. Heart. Apr. 2006;92(4):487-9. Exclude: BNP measure not FDA approved. [pmid: 16216865].
Wong LSM, Huzen J, van der HP, et al. Anaemia is associated with shorter leucocyte telomere length in patients with chronic heart failure. Eur J Heart Fail. 2010;12(4):348-53. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20335352].
Woo JJ, Koh YY, Kim HJ, et al. N-terminal pro B-type natriuretic peptide and the evaluation of cardiac dysfunction and severity of disease in cirrhotic patients. Yonsei Med J. Aug. 30. 2008;49(4):625-31. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18729306].
Woods PR, Taylor BJ, Frantz RP, et al. A pulmonary hypertension gas exchange severity (PH-GXS) score to assist with the assessment and monitoring of pulmonary arterial hypertension. Am J Cardiol. Apr. 1. 2012;109(7):1066-72. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 22245407].
Wozakowska-Kaplon B, Opolski G, Herman Z, et al. Natriuretic peptides in patients with atrial fibrillation. Cardiol J. 2008;15(6):525-9. Exclude: BNP measure not FDA approved. [pmid: 19039756].
Wozakowska-Kaplon B, Opolski G. Effects of exercise testing on natriuretic peptide secretion in patients with atrial fibrillation. Kardiol Pol. Mar. 2009;67(3):254-61. Exclude: BNP measure not FDA approved. [pmid: 19378231].
Wozakowska-Kaplon B, Bartkowiak R, Grabowska U, et al. B-type natriuretic peptide level after sinus rhythm restoration in patients with persistent atrial fibrillation - clinical significance. Kardiol Pol. Jul. 2010;68(7):781-6. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20648436].
Wright SP, Doughty RN, Pearl A, et al. Plasma amino-terminal pro-brain natriuretic peptide and accuracy of heart-failure diagnosis in primary care: A randomized controlled trial. J Am Coll Cardiol. Nov. 2003;42(10):1793-800. Exclude: BNP measure not FDA approved. [pmid: 14642690].
Wright SP, Prickett TC, Doughty RN, et al. Amino-terminal pro-C-type natriuretic peptide in heart failure. Hypertens. Jan. 2004;43(1):94-100. Exclude: BNP measure not FDA approved.
Wu AH, Packer M, Smith A, et al. Analytical and clinical evaluation of the Bayer ADVIA Centaur automated B-type natriuretic peptide assay in patients with heart failure: A multisite study. Clin Chem. May. 2004;50(5):867-73. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 15010423].
Wu AH, Smith A, Apple FS. Optimum blood collection intervals for B-type natriuretic peptide testing in patients with heart failure. Am J Cardiol. Jun. 15. 2004;93(12):1562-3. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 15194039].
Wu AH, Harrison A, Maisel AS. Reduced readmission rate for alternating diagnoses of heart failure and pulmonary disease after implementation of B-type natriuretic peptide testing. Eur J Heart Fail. Mar. 15. 2004;6(3):309-12. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 14987581].
Wu AH, Smith A. Biological variation of the natriuretic peptides and their role in monitoring patients with heart failure. Eur J Heart Fail. Mar. 15. 2004;6(3):355-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 14987588].
Wu AH, Omland T, Wold KC, et al. Relationship of B-type natriuretic peptide and anemia in patients with and without heart failure: A substudy from the Breathing Not Properly (BNP) Multinational Study. Am J Hematol. Nov. 2005;80(3):174-80. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16247751].
Wu CJ, Chang HW, Hung WC, et al. N-terminal pro-brain natriuretic peptide is a biomarker of congestive heart failure and predictive of 30-day untoward clinical outcomes in patients with acute myocardial infarction undergoing primary percutaneous coronary intervention. Circ J. Feb. 2006;70(2):163-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16434809].
Wu ET, Akagi T, Taniguchi M, et al. Differences in right and left ventricular remodeling after transcatheter closure of atrial septal defect among adults. Cathet Cardiovasc Interv. May. 1. 2007;69(6):866-71. Exclude: BNP measure not FDA approved.
Wu HY, W X. Testosterone level and mortality in elderly men with systolic chronic heart failure. Asian J Androl. 2011;13(5):759-63. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21685923].
Wu S, Fu SY, Liu FQ, et al. Clinical observation of high thoracic epidural anesthesia therapy for patients with congestive heart failure secondary to ischemic cardiomyopathy. Chin J Med Genet. Jul. 2007;87(25):1752-4. Exclude: Not in English.
Wu X, Zhu R, Jiang H, et al. Different treatment interventions affect plasma NT-ProBNP levels and early exercise tolerance in patients with acute ST-segment elevation myocardial infarction. Postgrad Med. 2012;124(2):58-63. Exclude: BNP measure not FDA approved. [pmid: 22437216].
Wylie JV, Murphy SA, Morrow DA, et al. Validated risk score predicts the development of congestive heart failure after presentation with unstable angina or non-ST-elevation myocardial infarction: results from OPUS-TIMI 16 and TACTICS-TIMI 18. Am Heart J. Jul. 2004;148(1):173-80. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 15215808].
Wynne J, Narveson SY, Littmann L. Cardiorenal syndrome. Heart and Lung: Journal of Acute and Critical Care. 2012;41(2):157-60. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Xin X, Ren AJ, Zheng X, et al. Disturbance of circulating ghrelin and obestatin in chronic heart failure patients especially in those with cachexia. Peptides. 2009;30(12):2281-5. Exclude: BNP measure not FDA approved. [pmid: 19666068].
Xu Y, Liu M, Shi XG, et al. Correlation between heart function and neurohormone-cytokine level in patients with chronic heart failure. Chin J Clin Rehabil. 2004;8(24):5001-3. Exclude: Not in English.
Xu Y, Gao CY, Liu YH, et al. Effect evaluation of autologous bone marrow mononuclear cell transplantation for the treatment of chronic heart failure. J Clin Rehab Tissue Engineer Res. 2009;13(27):5371-4. Exclude: Not in English.
Yalta K. Serum copeptin/NT-proBNP ratio: A more reliable index of absolute endogenous stress and prognosis during the course of Tako-tsubo cardiomyopathy?. Int J Cardiol. 2012;154(3):376-7. Exclude: Not a primary study. [pmid: 22204853].
Yamada T, Node K, Mine T, et al. Long-term effect of atorvastatin on neurohumoral activation and cardiac function in patients with chronic heart failure: A prospective randomized controlled study. Am Heart J. Jun. 2007;153(6):1055-8. Exclude: BNP measure not FDA approved. [pmid: 17540209].
Yamada Y, Goto J, Yokota M, et al. Brain natriuretic peptide is a sensitive indicator of impaired left-ventricular function in elderly patients with cardiovascular disease. Cardiol. Sep. 1997;88(5):401-7. Exclude: BNP measure not FDA approved.
Yamaguchi H, Yoshida J, Yamamoto K, et al. Elevation of plasma brain natriuretic peptide is a hallmark of diastolic heart failure independent of ventricular hypertrophy. J Am Coll Cardiol. Jan. 7. 2004;43(1):55-60. Exclude: BNP measure not FDA approved. [pmid: 14715184].
Yamaguchi H, Komamura K, Choraku M, et al. Impact of serum insulin-like growth factor-1 on early prognosis in acute myocardial infarction. Intern Med. 2008;47(9):819-25. Exclude: BNP measure not FDA approved. [pmid: 18451573].
Yamahara K, Min KD, Tomoike H, et al. Pathological role of angiostatin in heart failure: An endogenous inhibitor of mesenchymal stem-cell activation. Heart. Feb. 2009;95(4):283-9. Exclude: BNP measure not FDA approved. [pmid: 19095709].
Yamaji M, Tsutamoto T, Tanaka T, et al. Effect of carperitide on plasma adiponectin levels in acute decompensated heart failure patients with diabetes mellitus. Circ J. Dec. 2009;73(12):2264-9. Exclude: BNP measure not FDA approved. [pmid: 19797823].
Yamaji M, Tsutamoto T, Tanaka T, et al. Effect of carvedilol on plasma adiponectin concentration in patients with chronic heart failure. Circ J. Jun. 2009;73(6):1067-73. Exclude: BNP measure not FDA approved. [pmid: 19367012].
Yamaji M, Tsutamoto T, Kawahara C, et al. Serum cortisol as a useful predictor of cardiac events in patients with chronic heart failure: The impact of oxidative stress. Circ. Nov. 2009;2(6):608-15. Exclude: BNP measure not FDA approved.
Yamamoto A, Mankumo M, Kawaguchi A, et al. Leg edema, ST-T abnormalities, and high BNP values are important signs of heart failure in the elderly. Arch Gerontol Geriatr. 2001;33(1):37-52. Exclude: BNP measure not FDA approved. [pmid: 11461720].
Yamamoto K, Burnett JC Jr., Jougasaki M, et al. Superiority of brain natriuretic peptide as a hormonal marker of ventricular systolic and diastolic dysfunction and ventricular hypertrophy. Hypertens. Dec. 1996;28(6):988-94. Exclude: BNP measure not FDA approved.
Yamamoto K, Burnett JC Jr., Bermudez EA, et al. Clinical criteria and biochemical markers for the detection of systolic dysfunction. J Card Fail. Sep. 2000;6(3):194-200. Exclude: BNP measure not FDA approved. [pmid: 10997744].
Yamamoto T, Sato N, Yasutake M, et al. B-type natriuretic peptide as an integrated risk marker in non-ST elevation acute coronary syndromes. Int J Cardiol. Aug. 10. 2006;111(2):224-30. Exclude: BNP measure not FDA approved. [pmid: 16185779].
Yamamoto U, Mohri M. The influence of renal insufficiency on sleep-disordered breathing in patients with symptomatic chronic heart failure. Exp Clin Cardiol. 2010;15(3):33-6. Exclude: BNP measure not FDA approved. [pmid: 20959888].
Yamaoka-Tojo M, Tojo T, Inomata T, et al. Circulating levels of interleukin 18 reflect etiologies of heart failure: Th1/Th2 cytokine imbalance exaggerates the pathophysiology of advanced heart failure. J Card Fail. 2002;8(1):21-7. Exclude: BNP measure not FDA approved. [pmid: 11862579].
Yamashita T, Seino Y, Ogawa A, et al. N-terminal pro-BNP is a novel biomarker for integrated cardio-renal burden and early risk stratification in patients admitted for cardiac emergency. J Cardiol. May. 2010;55(3):377-83. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20350516].
Yamazaki T, Lee JD, Shimizu H, et al. Circulating matrix metalloproteinase-2 is elevated in patients with congestive heart failure. Eur J Heart Fail. Jan. 2004;6(1):41-5. Exclude: BNP measure not FDA approved. [pmid: 15012917].
Yambe M, Tomiyama H, Hirayama Y, et al. Arterial stiffening as a possible risk factor for both atherosclerosis and diastolic heart failure. Hypertens Res. 2004;27(9):625-31. Exclude: BNP measure not FDA approved. [pmid: 15750255].
Yambe M, Tomiyama H, Koji Y, et al. B-type natriuretic peptide and arterial stiffness in healthy Japanese men. Am J Hypertens. May. 2006;19(5):443-7. Exclude: BNP measure not FDA approved. [pmid: 16647611].
Yan AT, Yan RT, Spinale FG, et al. Relationships between plasma levels of matrix metalloproteinases and neurohormonal profile in patients with heart failure. Eur J Heart Fail. Feb. 2008;10(2):125-8. Exclude: BNP measure not FDA approved. [pmid: 18234554].
Yan JC, Liu PJ, Du RZ, et al. Relationship between CD40 ligand expression and B type natriuretic peptide levels in patients with chronic heart failure. Clin Chim Acta. Jun. 2008;392(1-2):17-20. Exclude: BNP measure not FDA approved. [pmid: 18339317].
Yan RT, White M, Yan AT, et al. Usefulness of temporal changes in neurohormones as markers of ventricular remodeling and prognosis in patients with left ventricular systolic dysfunction and heart failure receiving either candesartan or enalapril or both. Am J Cardiol. Sep. 1. 2005;96(5):698-704. Exclude: BNP measure not FDA approved. [pmid: 16125499].
Yan RT, Fernandes V, Yan AT, et al. Fibrinogen and left ventricular myocardial systolic function: The Multi-Ethnic Study of Atherosclerosis (MESA). Am Heart J. Sep. 2010;160(3):479-86. Exclude: BNP measure not FDA approved. [pmid: 20826256].
Yanagisawa R, Kataoka M, Taguchi H, et al. Impact of first-line sildenafil monotreatment for pulmonary arterial hypertension. Circ J. 2012;76(5):1245-52. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 22333215].
Yancy CW, Saltzberg MT, Berkowitz RL, et al. Safety and feasibility of using serial infusions of nesiritide for heart failure in an outpatient setting (from the FUSION I trial). Am J Cardiol. Sep. 1. 2004;94(5):595-601. Exclude: BNP measure not FDA approved. [pmid: 15342289].
Yandle TG, Richards AM, Gilbert A, et al. Assay of brain natriuretic peptide (BNP) in human plasma: Evidence for high molecular weight BNP as a major plasma component in heart failure. J Clin Endocrinol Metab. Apr. 1993;76(4):832-8. Exclude: BNP measure not FDA approved. [pmid: 8473392].
Yang JW, Kim MS, Kim JS, et al. Relationship between serum brain natriuretic peptide and heart function in patients with chronic kidney disease. Korean J Intern Med. Dec. 2008;23(4):191-200. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19119256].
Yang SS, Li WM, Zhou LJ, et al. The efficacy of percutaneous coronary intervention combined percutaneous thrombectomy on coronary thrombotic lesions in patients with acute myocardial infarction. Chin J Cardiovasc Dis. Dec. 2007;35(12):1136-40. Exclude: Not in English.
Yano Y, Ohmori T, Hoshide S, et al. Determinants of thrombin generation, fibrinolytic activity, and endothelial dysfunction in patients on dual antiplatelet therapy: Involvement of factors other than platelet aggregability in Virchow's triad. Eur Heart J. 2008;29(14):1729-38. Exclude: BNP measure not FDA approved. [pmid: 18270211].
Yardan T, Altintop L, Baydin A, et al. B-type natriuretic peptide as an indicator of right ventricular dysfunction in acute pulmonary embolism. Int J Clin Pract. Aug. 2008;62(8):1177-82. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17537186].
Yarlagadda S, Rajendran P, Miss JC, et al. Cardiovascular predictors of in-patient mortality after subarachnoid hemorrhage. Neurocrit Care. 2006;5(2):102-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17099255].
Yasue H, Yoshimura M, Sumida H, et al. Localization and mechanism of secretion of B-type natriuretic peptide in comparison with those of A-type natriuretic peptide in normal subjects and patients with heart failure. Circ. Jul. 1994;90(1):195-203. Exclude: BNP measure not FDA approved.
Yasue H, Yoshimura M, Yasue H, et al. Natriuretic peptides in the treatment of heart failure. J Card Fail. Dec. 1996;2(4 Suppl):S277-85. Exclude: BNP measure not FDA approved. [pmid: 8951590].
Yasumura Y, Takemura K, Sakamoto A, et al. Changes in myocardial gene expression associated with beta-blocker therapy in patients with chronic heart failure. J Card Fail. Dec. 2003;9(6):469-74. Exclude: BNP measure not FDA approved. [pmid: 14966788].
Yasumura Y, Miyatake K, Okamoto H, et al. Rationale for the use of combination angiotensin-converting enzyme inhibitor and angiotensin II receptor blocker therapy in heart failure. Circ J. Apr. 2004;68(4):361-6. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 15056835].
Yasutake H, Seino Y, Kashiwagi M, et al. Detection of cardiac sarcoidosis using cardiac markers and myocardial integrated backscatter. Int J Cardiol. Jul. 10. 2005;102(2):259-68. Exclude: BNP measure not FDA approved. [pmid: 15982494].
Ybarra J, Planas F, Pou JM. Aminoterminal pro-brain natriuretic peptide (NT-proBNP) and sleep-disordered breathing in morbidly obese females: A cross-sectional study. Diab Vasc Dis Res. Mar. 2008;5(1):19-24. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18398808].
Ybarra J, Planas F, Navarro-Lopez F, et al. Association between sleep-disordered breathing, aminoterminal pro-brain natriuretic peptide (NT-proBNP) levels and insulin resistance in morbidly obese young women. Eur J Intern Med. Mar. 2009;20(2):174-81. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19327608].
Yeh GY, Wood MJ, Lorell BH, et al. Effects of tai chi mind-body movement therapy on functional status and exercise capacity in patients with chronic heart failure: A randomized controlled trial. Am J Med. Oct. 15. 2004;117(8):541-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 15465501].
Yeh GY, Wayne PM, Phillips RS. T'ai Chi exercise in patients with chronic heart failure. Med Sport Sci. 2008;52:195-208. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18487899].
Yeh HM, Lau HP, Lin JM, et al. Preoperative plasma N-terminal pro-brain natriuretic peptide as a marker of cardiac risk in patients undergoing elective non-cardiac surgery. Br J Surg. 2005;92(8):1041-5. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 15997451].
Yen CH, T. Change of body surface electrocardiogram is linked to left ventricular geometric alteration from normal, pre-hypertension to hypertension: Comparison of NT-ProBNP and hs-CRP in determining ventricular remodeling. Acta Cardiol Sin. 2011;27(1):29-37. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Yi S, Contreras G, Miller ER, et al. Correlates of N-terminal prohormone brain natriuretic peptides in African Americans with hypertensive chronic kidney disease: The African American Study of Kidney Disease and Hypertension. Am J Nephrol. 2009;29(4):292-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18824845].
Yi W, Liang W, Li P, et al. Application of a Fab fragment of monoclonal antibody specific to N-terminal pro-brain natriuretic peptide for the detection based on regeneration-free electrochemical immunosensor. Biotechnol Lett. Aug. 2011;33(8):1539-43. Exclude: Non-human population. [pmid: 21452014].
Yildirir A, Acikel S, Ertan C, et al. Value of peri-procedural B-type natriuretic peptide levels in predicting cardiac events after elective percutaneous coronary intervention. Acta Cardiol. Feb. 2008;63(1):47-52. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18372580].
Yildiz R, Yildirim B, Karincaoglu M, et al. Brain natriuretic peptide and severity of disease in non-alcoholic cirrhotic patients. J Gastroenterol Hepatol. Jul. 2005;20(7):1115-20. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 15955223].
Yip GW, Wang M, Wang T, et al. The Hong Kong diastolic heart failure study: A randomised controlled trial of diuretics, irbesartan and ramipril on quality of life, exercise capacity, left ventricular global and regional function in heart failure with a normal ejection fraction. Heart. May. 2008;94(5):573-80. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18208835].
Yip HK, Sun CK, Chang LT, et al. Time course and prognostic value of plasma levels of N-terminal pro-brain natriuretic peptide in patients after ischemic stroke. Circ J. Apr. 2006;70(4):447-52. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16565563].
Yndestad A, Ueland T, Oie E, et al. Elevated levels of activin A in heart failure: Potential role in myocardial remodeling. Circ. Mar. 23. 2004;109(11):1379-85. Exclude: BNP measure not FDA approved.
Yoneyama A, Koyama J, Tomita T, et al. Relationship of plasma brain-type natriuretic peptide levels to left ventricular longitudinal function in patients with congestive heart failure assessed by strain Doppler imaging. Int J Cardiol. Oct. 30. 2008;130(1):56-63. Exclude: BNP measure not FDA approved. [pmid: 18068244].
Yoon CH, Zo JH, Kim YJ, et al. B-type natriuretic Peptide in isolated severe tricuspid regurgitation: Determinants and impact on outcome. J Cardiovasc Ultrasound. Dec. 2010;18(4):139-45. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21253363].
Yorgancioglu AOA. Serum and pleural fluid N-Terminal-Pro-B-Type natriuretic peptide concentrations in the differential diagnosis of pleural effusions. Tuberkuloz ve Toraks. 2011;59(1):1-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21554224].
Yoshihara F, Horio T, Nakamura S, et al. Adrenomedullin reflects cardiac dysfunction, excessive blood volume, and inflammation in hemodialysis patients. Kidney Int. Sep. 2005;68(3):1355-63. Exclude: BNP measure not FDA approved. [pmid: 16105071].
Yoshihisa A, Shimizu T, Owada T, et al. Adaptive servo ventilation improves cardiac dysfunction and prognosis in chronic heart failure patients with Cheyne-Stokes respiration. Int Heart J. 2011;52(4):218-23. Exclude: BNP measure not FDA approved. [pmid: 21828947].
Yoshimura M, Yasue H, Morita E, et al. Hemodynamic, renal, and hormonal responses to brain natriuretic peptide infusion in patients with congestive heart failure. Circ. Oct. 1991;84(4):1581-8. Exclude: BNP measure not FDA approved.
Yoshimura M, Yasue H, Okumura K, et al. Different secretion patterns of atrial natriuretic peptide and brain natriuretic peptide in patients with congestive heart failure. Circ. Feb. 1993;87(2):464-9. Exclude: BNP measure not FDA approved.
Yoshimura M, Yasue H, Tanaka H, et al. Responses of plasma concentrations of A type natriuretic peptide and B type natriuretic peptide to alacepril, an angiotensin-converting enzyme inhibitor, in patients with congestive heart failure. Br Heart J. Dec. 1994;72(6):528-33. Exclude: BNP measure not FDA approved. [pmid: 7857734].
Yoshimura M, Yasue H. Hemodynamic and hormonal effects of the angiotensin II antagonist, candesartan cilexetil, in patients with congestive heart failure. Cardiol. 2000;93(3):175-82. Exclude: BNP measure not FDA approved.
Yoshimura M, Mizuno Y, Harada E, et al. Interaction on metabolic clearance between A-type and B-type natriuretic peptides in patients with heart failure. Metabolism. Sep. 2000;49(9):1228-33. Exclude: BNP measure not FDA approved. [pmid: 11016910].
Yoshimura M, Mizuno Y, Nakayama M, et al. B-type natriuretic peptide as a marker of the effects of enalapril in patients with heart failure. Am J Med. Jun. 15. 2002;112(9):716-20. Exclude: BNP measure not FDA approved. [pmid: 12079712].
Yoshitomi Y, Nishikimi T, Kojima S, et al. Plasma levels of adrenomedullin in patients with acute myocardial infarction. Clin Sci. Feb. 1998;94(2):135-9. Exclude: BNP measure not FDA approved. [pmid: 9536921].
Yoshitomi Y, Nishikimi T, Kojima S, et al. Plasma natriuretic peptides as indicators of left ventricular remodeling after myocardial infarction. Int J Cardiol. Apr. 1. 1998;64(2):153-60. Exclude: BNP measure not FDA approved. [pmid: 9688434].
Yoshizawa A, Yoshikawa T, Nakamura I, et al. Brain natriuretic peptide response is heterogeneous during beta-blocker therapy for congestive heart failure. J Card Fail. Aug. 2004;10(4):310-5. Exclude: BNP measure not FDA approved. [pmid: 15309697].
Yousufuddin M, Henein MY, Flather M, et al. Incremental importance of peak-exercise plasma levels of endothelin-1 and natriuretic peptides in chronic heart failure. J Cardiovasc Pharmacol. Sep. 2001;38(3):468-73. Exclude: BNP measure not FDA approved. [pmid: 11486251].
Yu CM, Sanderson JE, Shum IO, et al. Diastolic dysfunction and natriuretic peptides in systolic heart failure. Higher ANP and BNP levels are associated with the restrictive filling pattern. Eur Heart J. Nov. 1996;17(11):1694-702. Exclude: BNP measure not FDA approved. [pmid: 8922918].
Yu CM, Sanderson JE. Plasma brain natriuretic peptide--An independent predictor of cardiovascular mortality in acute heart failure. Eur J Heart Fail. Mar. 1999;1(1):59-65. Exclude: BNP measure not FDA approved. [pmid: 10937981].
Yu H, Oswald H, Gardiwal A, et al. Comparison of N-terminal pro-brain natriuretic peptide versus electrophysiologic study for predicting future outcomes in patients with an implantable cardioverter defibrillator after myocardial infarction. Am J Cardiol. Aug. 15. 2007;100(4):635-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17697820].
Yuan W, Gu YY, Zhang DF. Measurement of serum soluble ST2 in patients with heart failure and its diagnostic value. Acad J Second Military Med U. 2012;33(2):175-8. Exclude: Not in English.
Yufu K, Takahashi N, Nakagawa M, et al. Brain natriuretic peptide and cardiac autonomic function in type 2 diabetic patients. Diab Res Clin Pract. Apr. 2006;72(1):12-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Yukiiri K, Hosomi N, Naya T, et al. Plasma brain natriuretic peptide as a surrogate marker for cardioembolic stroke. BMC Neurology. 2008;8:45. Exclude: BNP measure not FDA approved. [pmid: 19077217].
Yun KH, Jeong MH, Oh SK, et al. Preoperative plasma N-terminal pro-brain natriuretic peptide concentration and perioperative cardiovascular risk in elderly patients. Circ J. Feb. 2008;72(2):195-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18219153].
Zafarullah H, Shahbaz AU, Alturkmani R, et al. Elevated serum cobalamin in patients with decompensated biventricular failure. Am J Med Sci. Nov. 2008;336(5):383-8. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19011393].
Zamora E, Simo R, Lupon J, et al. Serum myostatin levels in chronic heart failure. Rev Esp Cardiol. Aug. 2010;63(8):992-6. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20738945].
Zanchi A, Maillard M, Jornayvaz FR, et al. Effects of the peroxisome proliferator-activated receptor (PPAR)-gamma agonist pioglitazone on renal and hormonal responses to salt in diabetic and hypertensive individuals. Diabetol. Aug. 2010;53(8):1568-75. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Zaninotto M, Mion MM, Di Serio F, et al. PATHFAST NT-proBNP (N-terminal-pro B type natriuretic peptide): A multicenter evaluation of a new point-of-care assay. Clin Chem Lab Med. Jul. 2010;48(7):1029-34. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20406130].
Zapata L, Vera P, Roglan A, et al. B-type natriuretic peptides for prediction and diagnosis of weaning failure from cardiac origin. Intensive Care Med. Mar. 2011;37(3):477-85. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21152896].
Zdrenghea D, Pop D, Ilea M, et al. The acute effect of Metoprolol upon NT-proBNP level in patients with congestive heart failure. Rom J Intern Med. 2009;47(1):35-40. Exclude: BNP measure not FDA approved. [pmid: 19886067].
Zeller M, Cottin Y, Laurent Y, et al. N-terminal pro-brain natriuretic peptide levels in patients with non-ST-elevation myocardial infarction. Cardiol. 2004;102(1):37-40. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Zemljic G, Bunc M, Yazdanbakhsh AP, et al. Levosimendan improves renal function in patients with advanced chronic heart failure awaiting cardiac transplantation. J Card Fail. Aug. 2007;13(6):417-21. Exclude: BNP measure not FDA approved. [pmid: 17675054].
Zeng C, Wei T, Jin L, et al. Value of B-type natriuretic peptide in diagnosing left ventricular dysfunction in dialysis-dependent patients. Intern Med J. Sep. 2006;36(9):552-7. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 16911545].
Zeng QX, Wei MF, Zhang W, et al. Level of natriuretic peptide determines outcome in atrial fibrillation. J Atrial Fibrillation. 2010;1(10):559-68. Exclude: BNP measure not FDA approved.
Zhang J, Fu X, Jia X, et al. B-type natriuretic peptide for prevention of contrast-induced nephropathy in patients with heart failure undergoing primary percutaneous coronary intervention. Acta Radiol. Jul. 2010;51(6):641-8. Exclude: BNP measure not FDA approved. [pmid: 20438292].
Zhao Q, Wu TG, Lin Y, et al. Low-dose nesiritide improves renal function in heart failure patients following acute myocardial infarction. Heart Ves. Mar. 2010;25(2):97-103. Exclude: BNP measure not FDA approved.
Zhao SQ, Hu YM, Li Q, et al. The clinical value of rapid assay for plasma B-type natriuretic peptide in differentiating congestive heart failure from pulmonary causes of dyspnoea. Int J Clin Pract. Feb. 2008;62(2):214-20. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 18081799].
Zhao YT, Shao L, Teng LL, et al. Effects of n-3 polyunsaturated fatty acid therapy on plasma inflammatory markers and N-terminal pro-brain natriuretic peptide in elderly patients with chronic heart failure. J Int Med Res. Nov. 2009;37(6):1831-41. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 20146881].
Zhao ZH, Liu ZH, Luo Q, et al. The effects of noninvasive positive pressure ventilation treatment on plasma concentration of amino terminal-pro brain natriuretic peptide in congestive heart failure in patients with sleep apnea. Chin J Intern Med. May. 2006;45(5):386-8. Exclude: Not in English.
Zhao ZH, Liu ZH, Luo Q, et al. Positive pressure ventilation treatment reduces plasma levels of amino terminal-pro brain natriuretic peptide in congestive heart failure patients with sleep apnea. Circ J. May. 2006;70(5):572-4. Exclude: BNP measure not FDA approved. [pmid: 16636492].
Zhou B, Yang J, Yang X, et al. Usefulness of the Echocardiographic Multi-Parameter Score (EMPS) in evaluating left ventricular global heart function. Tex Heart Inst J. 2011;38(1):27-34. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 21423465].
Zhou J, Shi H, Zhang J, et al. Rationale and design of the beta-blocker in heart failure with normal left ventricular ejection fraction (beta-PRESERVE) study. Eur J Heart Fail. Feb. 2010;12(2):181-5. Exclude: Not a primary study. [pmid: 20083625].
Zhou L, Giacherio D, Cooling L, et al. Use of B-natriuretic peptide as a diagnostic marker in the differential diagnosis of transfusion-associated circulatory overload. Transfusion. Jul. 2005;45(7):1056-63. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 15987348].
Zhu BL, Ishikawa T, Michiue T, et al. Postmortem pericardial natriuretic peptides as markers of cardiac function in medico-legal autopsies. Int J Legal Med. Jan. 2007;121(1):28-35. Exclude: BNP measure not FDA approved. [pmid: 16741745].
Zhu D, Wang F, Yu H, et al. Catestatin is useful in detecting patients with stage B heart failure. Biomarkers. Dec. 2011;16(8):691-7. Exclude: BNP measure not FDA approved. [pmid: 22050388].
Zhubrina ES, Ovchinnikov AG, Seredenina EM, et al. Optimization of use of beta-adrenoblockers in the treatment of chronic heart failure in the outpatient setting. Ter Arkh. 2009;81(11):35-40. Exclude: Not in English. [pmid: 20141011].
Zielinski T, Sobieszczanska-Malek M, Browarek A, et al. The influence of the recipient's body weight on the probability to obtain a heart transplant-POLKARD HF registry. Transplant Proc. Oct. 2009;41(8):3166-70. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19857703].
Zile MR, DeSantis SM, Baicu CF, et al. Plasma biomarkers that reflect determinants of matrix composition identify the presence of left ventricular hypertrophy and diastolic heart failure. Circ. May. 1. 2011;4(3):246-56. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria.
Zimmermann O, Bienek-Ziolkowski M, Wolf B, et al. Myocardial inflammation and non-ischaemic heart failure: Is there a role for C-reactive protein?. Basic Res Cardiol. Sep. 2009;104(5):591-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19343415].
Zoccali C, Mallamaci F, Benedetto FA, et al. Cardiac natriuretic peptides are related to left ventricular mass and function and predict mortality in dialysis patients. J Am Soc Nephrol. Jul. 2001;12(7):1508-15. Exclude: BNP measure not FDA approved. [pmid: 11423580].
Zoccali C, Tripepi G, Mallamaci F. Predictors of cardiovascular death in ESRD. Semin Nephrol. 2005;25(6):358-62. Exclude: Not a primary study. [pmid: 16298255].
Zondag W, Agterof MJ, Schutgens RE, et al. Repeated NT-proBNP testing and risk for adverse outcome after acute pulmonary embolism. Thromb Haemost. Dec. 2011;106(6):1226-7. Exclude: Not a primary study. [pmid: 22012299].
Zuber M, Kipfer P, Attenhofer Jost CH. Usefulness of acoustic cardiography to resolve ambiguous values of B-type natriuretic Peptide levels in patients with suspected heart failure. Am J Cardiol. Sep. 1. 2007;100(5):866-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 17719335].
Zuber M, Cuculi F, Attenhofer Jost CH, et al. Value of brain natriuretic peptides in primary care patients with the clinical diagnosis of chronic heart failure. Scand Cardiovasc J. 2009;43(5):324-9. Exclude: Does not meet prognosis, diagnosis, or treatment inclusion criteria. [pmid: 19247872].
Zugck C, Gerhards A, Kell R, et al. Brain natriuretic peptide (BNP) is superior to atrial natriuretic peptide (ANP), endothelin and norepinephrine as prognostic indicator in patients with congestive heart failure. J Kardiol. 2001;8(7-8):286-92. Exclude: Not in English.
Zugck C, Haunstetter A, Kruger C, et al. Impact of beta-blocker treatment on the prognostic value of currently used risk predictors in congestive heart failure. J Am Coll Cardiol. May. 15. 2002;39(10):1615-22. Exclude: BNP measure not FDA approved. [pmid: 12020488].
Zver S, Zadnik V, Bunc M, et al. Cardiac toxicity of high-dose cyclophosphamide in patients with multiple myeloma undergoing autologous hematopoietic stem cell transplantation. Int J Hematol. Jun. 2007;85(5):408-14. Exclude: BNP measure not FDA approved. [pmid: 17562616].