# Quality Assessment Forms

Newcastle Ottawa Scale, Case-Control Studies

Newcastle Ottawa Scale -Cohort Studies

QA: Modified Jadad Scale

QA: Cross-Sectional Design

QA Prognosis: Hayden Criteria

QA: Diagnostic -QUADAS II

Hayden Criteria Reference Sheet

QUADAS II Reference Sheet

Quality Assessment Study Design Description Reference Sheet