# Extraction Forms

General Data Extraction Form

Key Question: 1 & 2 Data Extraction Form

Key Question: 3, 4, & 5 Data Extraction Form