# Study Selection and Criteria Forms

Title & Abstract level 1

Title & Abstract Level 2

Title & Abstract level 3 - keyword screen

Full Text Screen Level 4

KQ 1 & 2 Investigators Screening

KQ 3 & 4 Investigators Screening

KQ 5 Investigators Screening

KQ 6 Investigators Screening

KQ 7 Investigators Screening

KQ 1B & 2B Investigators Screening

KQ 3B & 4B Investigators Screening

KQ 5B Investigators Screening