# FDA Cleared Devices

Table B-1 Details of FDA approved BNP tests characteristics

Test/Instrument Name | Company Name | 510(k) Number
Abbott AxSYM^®^ B-Type Natriuretic Peptide (BNP) Microparticle Enzyme Immunoassay (MEIA) | Axis-Shield Diagnostics | k033606
ADVIA Centaur^®^ B -Type Natriuretic Peptide (BNP) Assay | Bayer HealthCare LLC | k031038
Bayer Diagnostics ADVIA^®^ Centaur^®^ BNP Assay, Bayer Diagnostics ACS:180^®^ BNP Assay | Bayer HealthCare LLC | k043228 k040425
B-type Natriuretic Peptide (BNP) Assay for the ADVIA IMS | Bayer HealthCare LLC | k051265
Triage^®^ B-Type Natriuretic Peptide (BNP) Test | Biosite Incorporated | k051787 k032235 k021317 k010266 k003475
Triage^®^ B-Type Natriuretic Peptide (BNP) Test for the Beckman Coulter Immunoassay Systems | Biosite Incorporated | k052789 k033383
Dimension^®^ NT-proBNP (PBNP) Flex^®^ reagent cartridge method | Dade Behring, Inc. | k071767 k042347 k041417
ARCHITECT BNP Reagent Kit | Fujirebio Diagnostics, Inc. | k060964
i-STAT BNP test | i-STAT Corporation | k053597
StatusFirst™ CHF NT-proBNP | Nanogen, Inc. | k051596
Triage^®^ CardioProfilER® Panel | Biosite Incorporated | k080269 k030286
Triage^®^ Profiler S.O.B. ™ (Shortness of Breath Panel) | Biosite Incorporated | k080269 k042723 k040437

Table B-2 Details of FDA approved NT-proBNP tests characteristics

Test/Instrument Name | Company Name | 510(k) Number
VIDAS^®^ NT-proBNP | bioMerieux, Inc | k073091
Dimension^®^ Vista™ NT-proBNP (PBNP) Flex® reagent cartridge method (K6423) | Dade Behring, Inc. | k061795
Stratus CS^®^ Acute Care™ NT-proBNP (pBNP) TestPak assay | Dade Behring, Inc. | k071834 k060548 k043476
PATHFAST NTproBNP test | Mitsubishi Kagaku Iatron Inc. c/o Polymedco Inc. | k072189
VITROS Immunodiagnostic NT-proBNP Reagent Pack | Ortho-Clinical Diagnostics, Inc. | k060632
RAMP NT-proBNP Assay | Response Biomedical Corporation | k063662
Elecsys^®^ proBNP II Immunoassay | Roche Diagnostics Corporation | k072437
Elecsys^®^ proBNP II STAT Immunoassay | Roche Diagnostics Corporation | k092649
Elecsys^®^ proBNP Immunoassay | Roche Diagnostics Corporation | k051382 k032646 k022516
Dimension® EXLTm N-termninal Pro-Brain Natriuretic Peptide (NTP) Flex^®^ Reagent Cartridge (RF623) | Siemens Healthcare Diagnostics Inc. | k082645
Dimension Vista^®^ N-terminal Pro-Brain Natriuretic Peptide (PBNP) Flex^®^ Reagent Cartridge (K6423A) | Siemens Healthcare Diagnostics, Inc. | k080578