# Search Strategies

## Medline-OVID

### June 25 2012

1. natriuretic peptide, brain/
2. bnp.mp. [mp=protocol supplementary concept, rare disease supplementary concept, title, original title, abstract, name of substance word, subject heading word, unique identifier]
3. nt-probnp.mp.
4. brain-type natriuretic peptide.mp.
5. bnp1-32.mp.
6. bnp-32.mp.
7. bnp77-108.mp.
8. probnp.mp.
9. nt-probnp1-76.mp.
10. natriuretic factor-32.mp.
11. natriuretic peptide type-b.mp.
12. type-b natriuretic peptide.mp.
13. ventricular natriuretic peptide.mp.
14. 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13
15. 14
16. limit 14 to ed=19890101-20110309
17. human/
18. animal/
19. 17 and 18
20. 18 not 19
21. 16 not 20
22. 16 and 17
23. 21 not 22
24. limit 23 to english language

## EMBASE

### June 25 2012

1. Brain Natriuretic Peptide/ct, ec, an, dv [Clinical Trial, Endogenous Compound, Drug Analysis, Drug Development]
2. bnp.tw.
3. nt-probnp.tw.
4. brain-type natriuretic peptide.tw.
5. bnp 1-32.tw.
6. bnp1-32.tw.
7. bnp-32.tw.
8. bnp77-108.tw.
9. bnp 77-108.tw.
10. probnp.tw.
11. nt-probnp1-76.tw.
12. nt-probnp 1-76.tw.
13. natriuretic factor-32.tw.
14. natriuretic peptide type-b.tw.
15. type-b natriuretic peptide.tw.
16. ventricular natriuretic peptide.tw.
17. or/1-16
18. (“1989$” or “1990$” or “1991$” or “1992$” or “1993$” or “1994$” or “1995$” or “1996$” or “1997$” or “1998$” or “1999$” or “2000$” or “2001$” or “2002$” or “2003$” or “2004$” or “2005$” or “2006$” or “2007$” or “2008$” or “2009$” or “2010$” or “2011$”).ew.
19. 17 and 18
20. limit 19 to (human and english language)
21. limit 20 to “review”
22. 20 not 21
23. Brain Natriuretic Peptide/ct, ec, an, dv [Clinical Trial, Endogenous Compound, Drug Analysis, Drug Development]
24. bnp.tw.
25. nt-probnp.tw.
26. brain-type natriuretic peptide.tw.
27. bnp 1-32.tw.
28. bnp1-32.tw.
29. bnp-32.tw.
30. bnp77-108.tw.
31. bnp 77-108.tw.
32. probnp.tw.
33. nt-probnp1-76.tw.
34. nt-probnp 1-76.tw.
35. natriuretic factor-32.tw.
36. natriuretic peptide type-b.tw.
37. type-b natriuretic peptide.tw.
38. ventricular natriuretic peptide.tw.
39. or/23-38
40. (“1989$” or “1990$” or “1991$” or “1992$” or “1993$” or “1994$” or “1995$” or “1996$” or “1997$” or “1998$” or “1999$” or “2000$” or “2001$” or “2002$” or “2003$” or “2004$” or “2005$” or “2006$” or “2007$” or “2008$” or “2009$” or “2010$” or “2011$”).ew.
41. 39 and 40
42. human/
43. animal/
44. animal experiment/
45. 43 or 44
46. 42 and 45
47. 45 not 46
48. 41 and 47
49. 41 not 48
50. 49 not 22
51. limit 50 to english language

## Cochrane-EBM Reviews

(Cochrane Central Register of Controlled Trials (CCRT), Cochrane Database of Systematic Reviews (CDSR)

### June 25, 2012

1. Natriuretic Peptide, Brain/me, bi, bl, se, du [Metabolism, Biosynthesis, Blood, Secretion, Diagnostic Use]
2. bnp.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
3. nt-probnp.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
4. brain-type natriuretic peptide.tw.
5. bnp1-32.tw.
6. bnp-32.tw.
7. bnp77-108.tw.
8. probnp.tw.
9. nt-probnp1-76.tw.
10. natriuretic factor-32.tw.
11. natriuretic peptide type-b.tw.
12. type-b natriuretic peptide.tw.
13. ventricular natriuretic peptide.tw.
14. or/1-13
15. limit 14 to yr=1989-Current

## AMED

### June 25, 2012

1. exp peptides/
2. bnp.tw.
3. nt-probnp.tw.
4. brain-type natriuretic peptide.tw.
5. bnp 1-32.tw.
6. bnp-32.tw.
7. bnp77-108.tw.
8. probnp.tw.
9. nt-probnp1-76.tw.
10. natriuretic factor-32.tw.
11. natriuretic peptide type-b.tw.
12. type-b natriuretic peptide.tw.
13. ventricular natriuretic peptide.tw.
14. or/1-13
15. limit 14 to yr=1989-Current

## CINAHL

### June 25, 2012

1. exp Peptides/an, me, bl, ph, st, df, du, ur [Analysis, Metabolism, Blood, Physiology, Standards, Deficiency, Diagnostic Use, Urine]
2. nt-probnp.tw.
3. brain-type natriuretic peptide.tw.
4. bnp 1-32.tw.
5. bnp-32.tw.
6. bnp77-108.tw.
7. probnp.tw.
8. nt-probnp1-76.tw.
9. natriuretic factor-32.tw.
10. natriuretic peptide type-b.tw.
11. type-b natriuretic peptide.tw.
12. ventricular natriuretic peptide.tw.
13. or/1-12
14. limit 13 to yr=1989-2011