# Acknowledgments

The researchers at the McMaster EPC would like to acknowledge the following people for their contributions.

We are grateful to our Task Order Officers, Nahed El-Kassar, Mary Nix, and Gurvaneet Randhawa, for their support and guidance.

We would also like to thank those who worked so conscientiously, retrieving and screening citations, abstracting data, preparing figures, and editing the report: Julianna Beckett, Lynda Booker, Bryan Cheeseman, Roxanne Cheeseman, Mary Gauld, Mahbubul Haq, Yun Huang, Nofisah Ismaila, Meghan Kenny, Michael Knauer, Homa Keshavarz, Leah Macdonald, Maureen Rice, Karina Rodriguez-Capote, Meghan Schnurr, Marroon Thabane, and Kate Walker.