# Abbreviations

°C: Degrees Celsius
ACC: American College of Cardiology
ACC/AHA: American College of Cardiology/American Heart Association
ACE: Angiotensin Converting Enzyme
ACEI/ARB: angiotensin receptor blocker
aCHF: Acute congestive heart failure
ACID: Automatic Implantable Cardiac Defibrillator
ACS: Acute Coronary Syndrome
ADHF: Acute decompensated heart failure
ADM: admission mean
AF: atrial fibrillation
AHA: American Heart Association
AHF: acute heart failure
AHRQ: Agency for Healthcare Research Quality
AMED: Allied and Complementary Medicine
AMI: Acute myocardial infarction
ANP: A-Type Natriuretic Peptide
AR: Aortic Regurgitation
ARB: Angiotensin receptor blockers
AS: Aortic Stenosis
AUC: Area Under the Curve
AVLD: Asymptomatic Left Ventricular Dysfunction
BACH: Biomarkers in Acute Heart Failure
BASEL: B-Type Natriuretic Peptide for Acute Shortness of Breath Evaluation
BMI: body mass index
BMod: Behavior modification
BNP: B-Type Natriuretic Peptide
BP: Blood pressure
BUN: blood urea nitrogen
CA125: carbohydrate antigen 125
CABG: Coronary Artery Bypass Graft
CAD: coronary artery disease
CCS: Canadian Cardiovascular Society
CES-D: Center for Epidemiologic Studies Depression
cGMP: Cyclic guanosine mononucleotide phosphate
CHD: Chronic heart disease
CHF: congestive heart failure
CI: Confidence Interval
CKD: chronic kidney disease
COPD: chronic obstructive pulmonary disease
CP: cutpoint
CPE: Cardiogenic pulmonary edema
CRF: Chronic renal failure
CRP: C-reactive protein
CRT: Cardiac Resynchronization Therapy
CT: Computerized Tomography
cTnT: cardiac troponin T
CT-proET-1: C-terminal pro-endothelin-1 precursor fragment
CV: Cardiovascular
CVD: Cardiovascular Disease
CXR: Chest radiograph
d: days
D/C: discharge mean
DD: diastolic dysfunction
DIAST-CHF: Diastolic congestive heart failure
DM: diabetes mellitus
DOR: Diagnostic Odds Ratio
Dx: diagnosis
E/A: Early to late (atrial) echocardiographic phases of ventricular filling
ECG: Electrocardiogram
ECHO: Echocardiogram/echocardiography
ECHOES: Echocardiographic Heart of England Screening
ECP: Enhanced Counterpulsation
ED: emergency department
EDTA: Ethylenediaminetetraacetic acid
EF: Ejection Fraction
eGFR: Estimated glomerular filtration rate
ELISA: Enzyme Linked ImmunoSorbent Assay
EPIDASA: Epidemiological study of acute dyspnea in elderly patients
ER: Emergency room
ESC: European Society of Cardiology
F/U: followup
FDA: Food and Drug Administration
FN: False Negative
FPR: False-Positive Rates
g/dl: grams per deciliter
G-CSF: granulocyte colony-stimulating factor
G-CSF: granulocyte colony-stimulating factor
GDF-15: Growth differentiation factor 15
glow: Lower gray zone
GP: General practitioner
gup: Upper gray zone
Hb: Hemoglobin
HbA1c: Hemoglobin A1c
HD: heart disease
HEARD-IT: Heart Failure and Audicor technology for Rapid Diagnosis and Initial Treatment
HF: heart failure
HFnEFESC: Heart failure with normal ejection fraction recommended by European Society of Cardiology
HFrEF Grp: Heart failure with reduced ejection fraction group
HGF: hepatocyte growth factor
HID: Heart ischemic disease
HO: History of
HO HF: history of heart failure
HO of MI: history of myocardial infraction
HR: Hazard ratio
HR: heart rate
hsCRP: high-sensitivity c-reactive protein LVEF
HT: hypertension
IABP: Intra-Aortic Balloon Pump
ICON: International Collaboration of NT‐proBNP
ICU: intensive care unit
IDD: Isolated diastolic dysfunction
IDI: integrated risk improvement
IHD: Idiopathic Heart Disease
IL-6: interleukin-6
IMPROVE-CHF: Improved Management of Patients with Congestive Heart Failure
IQR: Interquartile range
JVP: Jugular Venous Pressure
KCCQ: Kansas City Cardiomyopathy Questionnaire
KD: Kidney disease
kg/m2: kilograms per meter squared
LAD: Left Anterior Descending
LR: Likelihood Ratio
LR-: negative likelihood ratio
LR+: positive likelihood ratio
LV: Left ventricle
LVD: Left Ventricular Dysfunction
LVDD: Left ventricular diastolic dysfunction
LVEDD: Left Ventricular End Diastolic Diameter
LVEF: left ventricular ejection fraction
LVESD: Left Ventricular End Systolic Dimension
LVSD: Left ventricular systolic dysfunction
LVSF: left ventricular systolic function
m: months
M/F: Male or female
MANPRO: Mannheim NT-proBNP Study
MCP-1: monocyte chemoattractant protein 1
M-CSF: macrophage colony-stimulating factor
MEIA: Microparticle enzyme immunoassay
mg/dL: Milligram per deciliter
MI: Myocardial Infarction
MIBG 123: I-metaiodobenzylguanidine
Min: Minutes
ml/min: millimeter per minute
mmol/L: milli mol per Liter
mol/L: mol per Liter
MPO: myeloperoxidase
MRI: Magnetic Resonance Imaging
MRNA: Myocardial Radionuclide Angiogram
MR-proADM: midregional proad- renomedullin
MRproANP: Midregional Pro-A-Type Natriuretic Peptide
MS: Mitral Stenosis
MSHD: Major structural heart disease
MSHD-AF: Major structural heart disease atrial fibrillation
MSHD-SR: Major structural heart disease sinus rhythm
n: number
NA: not applicable
ng/L: Nanogram per liter
NHANES: National Health and Nutrition Examination Survey
NPV: Negative Predictive Value
NR: Not reported
NS: Not stated
NSTEMI: Non ST-Elevation Myocardial Infarction
NT: N-Terminal
NTproBNP: N-terminal pro-B-type natriuretic peptide
NYHA: New York Heart Association
OR: odds ratio
PANAMA: Patients with suspected heart failure in primary care
PCI: Percutaneous coronary intervention
PCWP: Pulmocapillary wedge pressure
PEDF: pigment epithelium-derived factor
pg/ml: Picograms per milliliter
pmol/L: Picomol per liter
PPV: Positive predictive value
PRIDE: Pro-BNP investigation of dyspnea in the emergency department
PRIMA: PRo-brain-natriuretic peptide guided therapy of chronic heart failure IMprove heart fAilure morbidity and mortality
PROTECT: NT-proBNP Testing to Guide Heart Failure Therapy in the Outpatient Setting
PTCA: Percutaneous Transluminal Coronary Angioplasty
pts: patients
PVB: Premature Ventricular Beat
QoL: quality of life
QRS: Quick release system
QUADS: Quality Assessment of Diagnostic Accuracy Studies
RCT: Randomized controlled trial
RDW: Red blood cell distribution width
RNA: Radionuclide Angiogram
ROC: rate of change
ROC: Receiver operating characteristic
RR: Relative Risk
RV: right ventricular
RVD: Right ventricular dysplasia
S3 gallop: heart sounds, rhythm
SBP: Systolic blood pressure
SD: Standard deviation
Serum TC: serum total cholesterol
sFAS: soluble apoptosis-stimulating fragment
SIGNAL-HF: Swedish Intervention study –Guidelines and NT-proBNP Analysis in Heart Failure
SR: Sinus rhythm
SROC: Summary Receiver Operator Characteristic
SRS: Systematic Review Software
ST2: a gene product
STARBRITE: Strategies for Tailoring Advanced Heart Failure Regimens in the outpatient setting
STEMI: ST-Elevation Myocardial Infarction
sTweak: soluble tumour necrosis factor-like weak inducer of apoptosis
TC: Tetracycline
TDI: tissue Doppler imaging
TEP: Technical Expert Panel
TGF beta: Transforming growth factor beta
TIA: Transient ischemic attack
TIME-CHF: Trial of Intensified vs standard Medical therapy in Elderly patients with Congestive Heart Failure
TN: True Negative
TOO: Task Order Officer
TP: True Positive
TPR: True-Positive Rates
Type D: type-D personality
UHFO-IA: Utrecht Heart Failure Organisation – Initial Assessment
UKNPS: United Kingdom Natriuretic Peptide Study
umol/L: Micromol per liter
UPSTEP: Use of PeptideS in Tailoring hEart failure Project
USA: United States of America
VAD: Ventricular Assist Device
VHD: Valvular heart disease
vs: versus
y: years