# Results

The literature search yielded 10,475 citations (10,374 from electronic databases; 77 from submission information packages; and 24 from hand-searching; Figure 2). Of these, 1419 articles were reviewed in full text. After full text review, 326 were judged to have met the inclusion criteria for one or more Key Questions. The most common reason for exclusion of articles was that the results of the genetic or phenotypic tests studied were not used for prediction of intermediate or clinical outcomes or physician/patient decisionmaking. Other common reasons for exclusion were that the tests, populations, or outcomes studied were not of interest to this review; that the sample size was too small to yield useful estimates (n<50 for Key Question 1a or 2a about analytic validity or n<10 for Key Question 1b, 2b, or 3 about clinical utility or decisionmaking); that no primary data were reported; or that the full text was written in a language other than English. See Appendix B for a list of the excluded studies with the reason for exclusion. Appendix C contains a list of FDA documents that we reviewed. The summary tables for the 325 accepted studies are in Appendixes D through F.

Figure 2 Literature flow diagram

Abbreviations: KQ = Key Question; SIP = scientific information packet. A single article may report information on more than one study. Detailed reasons for exclusion of studies reviewed in full text but not considered further are presented in Appendix B.

Figure 2 is a literature flow diagram that outlines the study retrieval and selection process. It begins with the total number of citations retrieved from the literature searches and ends with the number of studies that satisfied the inclusion criteria of the report. Thie figure is described further in the Section entitled “Results” as follows: “The literature search yielded 10,374 citations. Of these, 1419 articles were reviewed in full text. After full text review, 325 were judged to have met the inclusion criteria for one or more of the four Key Questions. The most common reason for exclusion of articles was that the results of the genetic or phenotypic tests studied were not used for prediction of intermediate or clinical outcomes or physician/patient decisionmaking. Other common reasons for exclusion were that the tests, populations, or outcomes studied were not of interest (i.e., were not those specified in the eligibility criteria given in the Methods section); that the sample size was too small to yield useful estimates (n<50 for Key Question 1a or 2a about analytic validity or n<10 for Key Question 1b, 2b, or 3 about clinical utility or decisionmaking); that no primary data were reported; or that the full text was written in a language other than English.”

## Key Question 1a What is the analytic validity (technical test performance) of the various assays used for CYP2C19 genetic testing?

### Eligible Studies for Key Question 1a

We identified 11 studies29,78-87 reporting information on the analytic validity of genotyping methods for detecting CYP2C19 variants. Information on the patient populations, assays evaluated, test timing, and study designs used is presented in Appendix D. Studies reported limited information regarding the methods used to assess technical test performance, possibly reflecting their focus on clinical (rather than analytic) validity. Three of the studies were conducted by the same team of investigators and reported laboratory and clinical findings on patients identified at a single center in Germany (typically, these were participants in ongoing clinical trials); thus, at least partial overlap is likely. We also reviewed four FDA 510(k) summaries on genetic testing assays (see Appendix C).

Eight studies included patients undergoing PCI for coronary artery disease;29,78-83,86 one included a mixed population of patients with MI or undergoing PCI;84 one included patients with chronic cardiovascular disease;87 and one included a mixed population of vascular patients (coronary, cerebrovascular or peripheral artery disease) along with patients at high risk for the development of vascular disase.85 Seven studies assessed test–retest reliability (repeat testing of samples for the detection of CYP2C19 polymorphisms); three assessed agreement between alternative genotyping methods;82,83,87 and one study assessed the analytic sensitivity and specificity against a reference standard.86 Among the seven studies assessing test-retest reliability four reported the proportion of retested samples (20% in three cases; 11% in the fourth study), corresponding to 305 samples (in each of two studies), 497 samples (in the third study), and 535 samples in the fourth study. In the remaining two studies, the proportion of retested samples was not reported (and could not be calculated). Among the three studies assessing agreement between alternative genotyping methods, one reported the number of tested samples (333 samples). The study assessing analytic test performance against a reference standard reported results on 187 samples.

### Summary of Findings on Analytic Validity

Among the seven clinical studies providing information on analytic validity for CYP2C19 genotyping presenting results on test–retest reliability six reported that the concordance rate on repeat genotyping was 100 percent; and two reported that the rate was “higher than 98%.” Four of the seven studies genotyped more than one variant; however, it was unclear whether agreement was assessed for all variants, and results were not reported for each variant separately.

All three studies assessing agreement between alternative genotyping methods reported perfect agreement.82,83,87 Two of the three studies genotyped more than one variant; however, it was unclear whether agreement was assessed for all variants.

The study assessing analytic test performance compared a point-of-care assay (Spartan RX CYP2C19; the index test) versus direct sequencing (the reference standard). One sample identified as a *2 carrier by the index test was a non-carrier based on the reference standard, resulting in an estimated analytic sensitivity of 100% and analytic specificity of 99.3%.86 This comparison of analytic performance is noteworthy because it was conducted in the setting of randomized trial of testing versus no-testing (results on intermediate and clinical endpoints from this trial have been summarized under Key Questions 2-4).

FDA 510(k) summaries did not report analyses on samples from populations and gene of interest in our review. However, the documents provided evidence that genotyping methods have high test–retest reliability and indicated that rates of interassay agreement were high (based on fairly extensive studies of test-retest reliability and inter-assay agreement).

### Risk of Bias and Completeness of Reporting for Studies Reviewed for Key Question 1a

We evaluated risk of bias and completeness of reporting based on 11 predefined questions. Studies reported limited information on the methods they used to assess analytic validity. This probably reflects the fact that the primary focus of all included publications was not the tests' analytic validity (but rather their clinical utility). Generally, studies provided adequate information on the genotyping methods used. However, they provided little information on the use of positive or negative control samples, the handling of uninterpretable results, and the test detection limits. Four studies reported information on the reproducibility of genotyping across different genotyping methods, but no study assessed reproducibility across operators. No study was conducted as part of an interlaboratory standardization project. Appendix D summarizes our assessment of risk of bias and completeness of reporting for studies of genetic testing for CYP2C19 variants.

## Key Question 1b What is the clinical validity (predictive accuracy) of genetic testing for predicting intermediate and clinical outcomes in patients who are receiving clopidogrel therapy?

### Eligible Studies for Key Question 1b

The studies included for this Key Question enrolled patients on clopidogrel-based antiplatelet therapy. Of the 106 studies addressing Key Question 1b (in 98 publications; 8 publications described 2 studies each), the vast majority (100 [94 percent]) were of patients with ischemic heart disease; three studies enrolled patients with different forms of vascular disease (coronary, cerebrovascular, or peripheral arterial); one enrolled patients with cerebrovascular disease; one enrolled a mixed population of patients with manifest atherothrombotic disease along with patients at high risk for atherothrombotic disease; and one enrolled patients with atrial fibrillation who were not candidates for vitamin K antagonist therapy. In 81 studies (76 percent), 80 percent or more patients were undergoing PCI; 4 studies (4 percent) included patients undergoing angiography; and 21 (20 percent) included populations in which less than 80 percent of patients were undergoing a procedure or did not provide information on the proportion of patients undergoing revascularization. The majority of studies were of patients receiving dual antiplatelet therapy with clopidogrel in combination with aspirin. Detailed information on the selection criteria, settings, and treatment strategies (including adjunctive treatments) is presented in Appendix D.

The 106 studies had intermediate to large sample sizes (median number of enrolled individuals=277; 25th percentile=98; 75th percentile=802; minimum=30; maximum=5148). They were conducted recently (median year of start of enrollment was 2006, with 75 percent beginning enrollment after 2004), reflecting the relatively recent widespread availability of genetic testing for CYP2C19 variants. Across studies, men represented the majority of enrolled patients (median proportion across studies was 75 percent; men were the majority sex in 95 of the 97 studies noting the sex of participants). In 98 studies providing information on patient age, the median of the average age reported in each study was 64 years; average age was equal to or older than 65 years in 37 of the studies. Patients had a relatively high burden of risk factors for coronary artery disease (which are associated with adverse cardiovascular outcomes): the median proportion of patients with dyslipidemia was 61 percent (in the 74 studies with data; 25th percentile=49 percent; 75th percentile=76 percent); hypertension, 68 percent (in 86 studies; 25th percentile=56 percent; 75th percentile=81 percent); diabetes mellitus, 28 percent (in 95 studies; 25th percentile=21 percent; 75th percentile=35 percent); and tobacco use, 32 percent (in 88 studies; 25th percentile=16 percent; 75th percentile=42 percent). Detailed information about patient characteristics and preexisting vascular disease is summarized in Appendix D.

A total of 100 of the 106 studies (94 percent) had a longitudinal (cohort) design; 5 were case–control studies; and 1 was a case-cohort study. Of the longitudinal studies, 11 were genetic substudies consisting of prospectively followed clopidogrel-treated groups from randomized trials. (When appropriate, possible modification of the relative treatment effect by genotype status has been considered under Key Questions 3 and 4 of this report.)

Overall studies had moderate risk of bias (12 studies were rated as quality “A”; 88 studies were rated as quality “B”; and 6 were rated as quality “C”). We caution that this aggregate risk-of-bias rating can be misleading, especially in the presence of poor reporting. A more detailed discussion of risk of bias, focusing on the individual items assessed is presented later in this chapter.

### Genotyping Methods, Hardy–Weinberg Equilibrium, Variant Allele Frequencies

The 106 studies addressing Key Question 1b used a variety of genotyping methods for identifying CYP2C19 variants. The two most common were TaqMan genotyping (44 studies; 42 percent) and PCR-RFLP (13 studies; 12 percent). In the majority of cases analyses were conducted on genetic material isolated from blood (92 studies; 87 percent). Among the 56 studies that reported the genotyping success rate, the median was 100 percent (minimum=74 percent; maximum=100 percent). The vast majority of studies genotyped samples for the CYP2C19 *2 allele; additional alleles were genotyped in a minority of studies and were rare in the sampled population. Detailed information on the genotyping methods used and the distribution of observed genotypes for each study are presented in Appendix D.

Seventy-five of the eligible studies provided information adequate to calculate goodness-of-fit p-values for Hardy–Weinberg equilibrium (using an exact test); some studies reported information on more than one patient group and more than one genetic variant. Table 2 shows summary results across studies, and Figure 3 shows a quantile–quantile plot of p-values for deviations from Hardy–Weinberg equilibrium against the uniform distribution, for the *2 allele.

Table 2 P-values for deviation from Hardy–Weinberg equilibrium

CYP2C19 Allele | No. of Studies Reporting Genotype Distributions | Median P-Value [25th, 75th percentile] | No. of Studies With p<0.05 (%)
*2 | 77 | 0.50 [0.25, 0.81] | 5 (6%)
*3 | 28 | 1.00 [0.70, 1.00] | 0 (0%)
*17 | 29 | 0.64 [0.19, 0.84] | 2 (7%)
Other | 14 | 1.00 [1.00,1.00] | 0 (0%)
Total | 148 | 0.69 [0.30, 1.00] | 7 (5%)

Studies not reporting the complete genotype distribution (n=12) have not been included in the table. The 44 studies included could have reported genotype distributions for more than one allele. For the two case–control studies and the one case-cohort study, we assessed violations for Hardy–Weinberg equilibrium (HWE) for the control group only. Variants other than *2, *3, and *17 were fairly uncommon, leading to p-values for HWE violation equal to 1 in many cases.

Figure 3 Quantile–quantile plot (observed vs. uniform distribution) of p-values for deviation from Hardy–Weinberg violation in studies reporting the genotype distribution for the CYP2C19*2 allele

Abbreviations: HWE=Hardy–Weinberg equilibrium. P-values are from an exact test.

Figure 3 shows a quantile–quantile plot of P values for deviations from Hardy-Weinberg equilibrium (HWE) against the uniform distribution, for the *2 allele. The figure illustrates that statistically significant deviations from the HWE were uncommon (n=7 across all genotyped alleles), and at the 0.05 alpha level, four or five significant results would be expected by chance alone.

Figure 4 presents forest plots of the CYP2C19*2 allele frequency (number of *2 alleles over total number of alleles in the population) and the prevalence of homozygotes for the rare variant (*2/*2 individuals over total number of study participants) from eligible studies. The graph highlights that the allele frequency and the prevalence of *2/*2 homozygotes is higher among East Asian populations (white circles) as compared to populations of European ancestry (black circles). Less information was available for black populations (black squares) and populations of mixed (or not reported) ancestry (white squares).

Figure 4 *2 Allele frequency and *2/*2 genotype prevalence in eligible studies

*2 allele frequency (left panel) and *2/*2 genotype prevalence (right panel) in eligible studies providing relevant information. Black circles = European ancestry; white circles = East Asian populations; black squares = black populations; white squares = population of other/mixed ancestry or not reported. Extending lines denote exact (binomial) 95% confidence intervals.

Figure 4 presents forest plots of the CYP2C19*2 allele frequency (number of *2 alleles over total number of alleles in the population) and the prevalence of homozygotes for the rare variant (*2/*2 individuals over total number of study participants) from eligible studies. The graph highlights that the allele frequency and the prevalence of *2/*2 homozygotes is higher among East Asian populations (white circles) as compared to populations of European ancestry (black circles). Less information was available for black populations (black squares) and populations of mixed (or not reported) ancestry (white squares). There is heterogeneity both within and across etnic/racial groups.

Overall, statistically significant deviations were uncommon (n=7 across all genotyped alleles), and at the 0.05 alpha level, roughly seven significant results would be expected by chance alone (= 0.05 × 148). In addition, these results need to be interpreted with caution given that patients were selected for inclusion in the studies on the basis of the presence of ischemic heart disease (or other atherosclerotic vascular disease).

Of the 106 eligible studies, 57 provided information on the predictive value of genetic testing for CYP2C19 variants for predicting clinical outcomes, and 74 reported data appropriate for predicting on-clopidogrel platelet reactivity. In the following section we discuss studies according to the outcomes reported for each population of interest. Because the study designs and outcome definitions used across studies of ischemic coronary artery disease were considered sufficiently similar, we performed meta-analyses if at least three studies provided information for an outcome of interest. We synthesized findings across studies, on the assumption that their patient populations were nonoverlapping. (Please see the Methods section for additional details on how we assessed potential population overlap.) Subgroup and effect modification analyses for the same set of studies are presented in the next section (results for Key Question 1c).

### Summary of Findings on the Predictive Value of CYP2C19 Variants for Patients on Clopidogrel-Based Antiplatelet Therapy

Table 3 summarizes our findings on the predictive value of CYP2C19 variants for clinical outcomes across studies reporting on nonoverlapping of clopidogrel-treated patient populations included in meta-analyses or synthesized quantitatively in patient populations with ischemic heart disease. We performed meta-analyses when at least three studies reported on the comparison of interest and the occurrence of at least one outcome event. Three studies enrolled mixed patient populations with different forms of vascular disease (coronary, cerebrovascular, or peripheral arterial); one enrolled patients with cerebrovascular disease; one enrolled a mixed population of patients with manifest atherothrombotic disease along with patients at high risk for atherothrombotic disease; and one enrolled patients with atrial fibrillation. Results from these studies are summarized separately below. As we discuss in subsequent sections, results regarding platelet reactivity (when used as an outcome) were not amenable to quantitative synthesis.

Table 3 Summary of results on the predictive value of CYP2C19 variants for clinical outcomes among clopidogrel-treated patients with ischemic heart disease

Exposure | Outcome | No. of Studies with Nonoverlapping Populations | Summary of Findings | P-Value for Small-Study Effects
LOF vs. no LOF | All-cause mortality | 7 | RR=1.00 (95% CI, 0.64 to 1.55) P_Q_=0.403; I^2^=3% | 0.163
LOF vs. no LOF | Cardiovascular mortality | 7 | RR=1.98 (95% CI, 1.13 to 3.46) P_Q_=0.936; I^2^=0% | 0.719
LOF vs. no LOF | ACS | 9 | RR=1.35 (95% CI, 0.91 to 2.00) P_Q_=0.828; I^2^=0% | 0.092
LOF vs. no LOF | Stent thrombosis | 17 | RR=1.52 (95% CI, 1.17 to 1.97) P_Q_=0.772; I^2^=0% | <0.001
LOF vs. no LOF | Stroke | 7 | RR=2.07 (95% CI, 0.68 to 6.33) P_Q_=0.374; I^2^=7% | 0.950
LOF vs. no LOF | MACE | 25 | RR=1.20 (95% CI, 1.04 to 1.39) P_Q_=0.076; I^2^=31% | 0.002
LOF vs. no LOF | Bleeding events | 6 | RR=1.02 (95% CI, 0.86 to 1.21) P_Q_=0.701; I^2^=0% | 0.049
LOF vs. no LOF | Other clinical outcomes | 4 studies (5 outcomes) | Studies suggested that revascularization outcomes and “net clinical” benefit are more common among carriers of loss-of-function alleles. | NA
GOF vs. no GOF | All-cause mortality | 3 | RR=1.28 (95% CI, 0.81 to 2.02) P_Q_=0.505; I^2^=0% | 0.351
GOF vs. no GOF | Cardiovascular mortality | 0 | NA
GOF vs. no GOF | ACS | 2 | Both studies reported non–statistically significant results. Confidence intervals were wide; the two point estimates for the RR differed by >0.3. | NA
GOF vs. no GOF | Stent thrombosis | 5 | RR=0.83 (95% CI, 0.52 to 1.32) P_Q_=0.754; I^2^=0% | 0.399
GOF vs. no GOF | Stroke | 1 | The study did not find a statistically significant association. | NA
GOF vs. no GOF | MACE | 7 | RR=0.82 (95% CI, 0.74 to 0.92) P_Q_=0.966; I^2^=0% | 0.882
GOF vs. no GOF | Bleeding events | 6 | RR=1.51 (95% CI, 1.08 to 2.11) P_Q_=0.088; I^2^=48% | 0.046
GOF vs. no GOF | Revascularization | 0 | NA | NA

Abbreviations: ACS = acute coronary syndromes; CI = confidence interval; GOF = gain-of-function alleles; LOF = loss-of-function alleles; MACE = major adverse cardiovascular events; NA = not applicable; RR = relative risk.

Significant p-values are in bold type.

#### Studies of Patients With Ischemic Heart Disease

##### Clinical Outcomes

Fifty-seven of the 106 studies eligible for Key Question 1b reported information on the predictive value of CYP2C19 genotyping for predicting clinical outcomes in patients with ischemic heart disease. Eligible studies were fairly large (median number of genotyped individuals=428) and recent (median year enrollment started=2005).

###### All-Cause Mortality

Seven studies with nonoverlapping populations of patients with ischemic heart disease reported information on the predictive value of loss-of-function alleles for all-cause mortality (and reported the occurrence of at least one outcome event).78,84,88-93 The studies were large (minimum sample size=160) but represented a minority of all 57 studies reporting clinical outcomes. The summary RR for all-cause mortality comparing carriers of any loss-of-function allele with noncarriers was 1.00 (95% CI, 0.64 to 1.55; p=0.988). Overall, there was little between-study heterogeneity (P_Q_ = 0.403; I^2^ = 3 percent). Figure 5 presents the meta-analysis results, along with study-specific event rates.

Figure 5 Meta-analysis of all-cause mortality comparing carriers and noncarriers of loss-of-function CYP2C19 alleles

Abbreviations: CI = confidence interval; LOF = loss-of-function; RR = relative risk.

The solid squares (and horizontal lines) indicate the RR of all-cause mortality (and the corresponding 95% CI) for individual studies. The affected numbers of carriers or noncarriers are shown to the right of the plot. The size of the squares is proportional to the weight of each study in the meta-analysis. The dashed vertical line represents the summary RR, with the open diamond showing the corresponding CI. The solid line indicates an RR of 1.

Figure 5 presents the results from the meta-analysis of all-cause mortality comparing carriers and noncarriers of loss-of-function CYP2C19 alleles, along with study-specific event rates. The figure is described further in the section entitled “Studies of Patients with Ischemic Heart Disease, All-Cause Mortality” as follows: “Seven studies with nonoverlapping populations of patients with ischemic heart disease reported information on the predictive value of loss-of-function alleles for all-cause mortality (and reported the occurrence of at least one outcome event). The studies were large (minimum sample size=160) but represented a minority of all 57 studies reporting clinical outcomes. The summary RR for all-cause mortality comparing carriers of any loss-of-function allele with noncarriers was 1.00 (95 percent CI 0.64, 1.55; P=0.988). Overall, there was little between-study heterogeneity (PQ=0.403; I2=3 percent).

The summary RR for all-cause mortality comparing carriers of any gain-of-function allele versus noncarriers (based on only three studies reporting relevant data79,88,91) was 1.28 (95% CI, 0.81 to 2.02; p=0.288). Overall, there was little between-study heterogeneity (P_Q_ = 0.505; I^2^ = 0 percent). Figure 6 presents the meta-analysis results, along with study-specific event rates.

Figure 6 Meta-analysis of all-cause mortality comparing carriers and noncarriers of gain-of-function CYP2C19 alleles

Abbreviations: CI = confidence interval; GOF = gain-of-function; RR = relative risk.

The solid squares (and horizontal lines) indicate the RR of all-cause mortality (and the corresponding 95% CI) for individual studies. The affected numbers of carriers or noncarriers are shown to the right of the plot. The size of the squares is proportional to the weight of each study in the meta-analysis. The dashed vertical line represents the summary RR, with the open diamond showing the corresponding CI. The solid line indicates an RR of 1.

Figure 6 presents the results from the meta-analysis of all-cause mortality comparing carriers and noncarriers of gain-of-function CYP2C19 alleles, along with study-specific event rates. The figure is described further in the section entitled “Studies of Patients with Ischemic Heart Disease, All-Cause Mortality” as follows: “The summary RR for all-cause mortality comparing carriers of any gain-of-function allele versus noncarriers (based on only three studies reporting relevant data) was 1.28 (95 percent CI 0.81, 2.02; P=0.288). Overall, there was little between-study heterogeneity (PQ=0.505; I2=0 percent).”

###### Cardiovascular Mortality

Information on the predictive value of genetic testing for mortality due to cardiovascular causes was reported in seven studies with nonoverlapping populations of patients with ischemic heart disease (in which at least one event was observed).92-98 Studies were fairly large (minimum sample size=105) but represented a minority of the 57 studies reporting clinical outcomes. The summary RR for cardiovascular mortality comparing carriers of any loss-of-function allele and noncarriers was 1.98 (95% CI, 1.13 to 3.46; p=0.017). Overall, there was little between-study heterogeneity (P_Q_ = 0.936; I^2^ = 0 percent). Figure 7 presents the meta-analysis results, along with study-specific event rates.

Figure 7 Meta-analysis of cardiovascular mortality comparing carriers and noncarriers of loss-of-function CYP2C19 alleles

Abbreviations: CI = confidence interval; LOF = loss-of-function; RR = relative risk.

The solid squares (and horizontal lines) indicate the RR of cardiovascular mortality (and the corresponding 95% CI) for individual studies. The affected numbers of carriers or noncarriers are shown to the right of the plot. The size of the squares is proportional to the weight of each study in the meta-analysis. The dashed vertical line represents the summary RR, with the open diamond showing the corresponding CI. The solid line indicates an RR of 1.

Figure 7 presents the results from the meta-analysis of cardiovascular mortality comparing carriers and noncarriers of loss-of-function CYP2C19 alleles, along with study-specific event rates. The figure is described further in the section entitled “Studies of Patients with Ischemic Heart Disease, Cardiovascular Mortality” as follows: “Information on the predictive value of genetic testing for mortality due to cardiovascular causes was reported in seven studies with nonoverlapping populations of patients withischemic heart disease (in which at least one event was observed). Studies were fairly large (minimum sample size=105) but represented a minority of the 57 studies reporting clinical outcomes. The summary RR for cardiovascular mortality comparing carriers of any loss-of-function allele and noncarriers was 1.98 (95 percent CI 1.13, 3.46; P=0.017).”

No studies provided information on the impact of gain-of-function alleles on risk of cardiovascular mortality.

###### Acute Coronary Syndromes

Information on the predictive value of genetic testing for acute coronary syndromes (including myocardial infarction) was reported in nine studies with nonoverlapping populations of patients with ischemic heart disease.78,84,91,93,94,96,97,97-99 Studies were large (minimum sample size=105) but represented a minority of the 57 studies reporting clinical outcomes in patients with ischemic heart disease. The summary RR for acute coronary syndromes comparing carriers of any loss-of-function allele versus noncarriers was 1.35 (95% CI, 0.91 to 2.00; p=0.136). Overall, there was little between-study heterogeneity (P_Q_ = 0.828; I^2^ = 0 percent). Figure 8 presents the meta-analysis results, along with study-specific event rates.

Figure 8 Meta-analysis of acute coronary syndromes comparing carriers and noncarriers of loss-of-function CYP2C19 alleles

Abbreviations: CI = confidence interval; LOF = loss-of-function; RR = relative risk.

One study (Mega et al. 2009^99^) did not report the number of observed events.

The solid squares (and horizontal lines) indicate the RR of acute coronary syndromes (and the corresponding 95% CI) for individual studies. The affected numbers of carriers or noncarriers are shown to the right of the plot. The size of the squares is proportional to the weight of each study in the meta-analysis. The dashed vertical line represents the summary RR, with the open diamond showing the corresponding CI. The solid line indicates an RR of 1.

Figure 8 presents the results from the meta-analysis of acute coronary syndromes comparing carriers and noncarriers of loss-of-function CYP2C19 alleles, along with study-specific event rates. The figure is described further in section “Information on the predictive value of genetic testing for acute coronary syndromes (including myocardial infarction) was reported in nine studies with nonoverlapping populations of patients with ischemic heart disease. Studies were large (minimum sample size=105) but represented a minority of the 57 studies reporting clinical outcomes in patients with ischemic heart disease. The summary RR for acute coronary syndromes comparing carriers of any loss-of-function allele versus noncarriers was 1.35 (95 percent CI 0.91, 2.00; P=0.136). Overall, there was little between-study heterogeneity (PQ=0.828; I2=0 percent).”

Only two studies78,91 reported information on the impact of gain-of-function alleles on the risk of acute coronary syndromes. Both studies did not find a statistically significant association between carriage of gain-of-function alleles and acute coronary syndromes, but the CIs were wide (RR=1.05; 95% CI, 0.34 to 3.29 and RR=0.73; 95% CI 0.30 to 1.76, respectivelly), indicating substantial uncertainty in the estimates.

###### Stent Thrombosis

Information on the predictive value of loss-of-function alleles for stent thrombosis (definite or probable, based on study-specific definitions when available) was reported in 17 studies with nonoverlapping populations of patients with ischemic heart disease (in which at least one outcome event was observed).78,82,84,88,90-92,94-96,98-106 Studies were large (minimum sample size=60; median sample size=596). The summary RR for stent thrombosis comparing carriers of any loss-of-function allele versus noncarriers was 1.52 (95% CI, 1.17 to 1.97; p=0.002). Overall, there was little between-study heterogeneity (P_Q_ = 0.772; I^2^ = 0 percent). Figure 9 presents the meta-analysis results, along with study-specific event rates.

Figure 9 Meta-analysis of stent thrombosis comparing carriers and noncarriers of loss-of-function CYP2C19 alleles

Abbreviations: CI = confidence interval; LOF = loss-of-function; RR = relative risk.

One study (Mega et al. 2009^99^) did not report the number of observed events; one study (Delaney et al. 2012^84^) reported only an effect size.

The solid squares (and horizontal lines) indicate the RR of stent thrombosis (and the corresponding 95% CI) for individual studies. The affected numbers of carriers or noncarriers are shown to the right of the plot. The size of the squares is proportional to the weight of each study in the meta-analysis. The dashed vertical line represents the summary RR, with the open diamond showing the corresponding CI. The solid line indicates an RR of 1.

Figure 9 presents results from the meta-analysis of stent thrombosis comparing carriers and noncarriers of loss-of-function CYP2C19 alleles, along with study-specific event rates. The figure is described further in section “Information on the predictive value of loss-of-function alleles for stent thrombosis (definite or probable, based on study-specific definitions when available) was reported in 17 studies with nonoverlapping populations of patients with ischemic heart disease (in which at least one outcome event was observed). Studies were large (minimum sample size=60; median sample size=596). The summary RR for stent thrombosis comparing carriers of any loss-of-function allele versus noncarriers was 1.52 (95 percent CI 1.17, 1.97; P=0.002). Overall, there was little between-study heterogeneity (PQ=0.772; I2=0 percent).”

Figure 10 presents an analysis of predictive accuracy for the same group of studies (14 of 17 studies provided the needed data) under a dominant genetic model. The summary sensitivity was 0.47 (95% CI, 0.39 to 0.56) and the average specificity was 0.69 (95% CI, 0.66 to 0.72) using a random effects model.

Figure 10 Prognostic performance of CYP2C19 genetic testing for stent thrombosis

Bivariate meta-analysis of sensitivity and specificity for predicting stent thrombosis. The black solid line shows the fitted summary receiver operating characteristic curve; the gray solid line is the chance diagonal. Individual studies are shown as bubbles with size proportional to study size.

Figure 10 presents an analysis of predictive accuracy for the same group of studies (14 of 17 studies provided the needed data) under a dominant genetic model. The summary sensitivity was 0.47 (95 percent CI 0.39, 0.56) and the average specificity was 0.69 (95 percent CI 0.66, 0.72) using a random effects model.

Information on the predictive value of gain-of-function alleles for stent thrombosis (definite or probable) was reported in five studies with nonoverlapping populations of patients with ischemic heart disease.78,88,91,101,107 Studies were large (minimum sample size=300); however, they represented a minority of the 17 studies reporting stent thrombosis. The summary RR for stent thrombosis comparing carriers of any gain-of-function allele versus noncarriers was 0.83 (95% CI, 0.52 to 1.32; p=0.425). Overall, there was little between-study heterogeneity (P_Q_ = 0.754; I^2^ = 0.0 percent). Figure 11 presents the meta-analysis results, along with study-specific event rates.

Figure 11 Meta-analysis of stent thrombosis comparing carriers and noncarriers of gain-of-function CYP2C19 alleles

Abbreviations: CI = confidence interval; GOF = gain-of-function; RR = relative risk.

The solid squares (and horizontal lines) indicate the RR of stent thrombosis (and the corresponding 95% CI) for individual studies. The affected numbers of carriers or noncarriers are shown to the right of the plot. The size of the squares is proportional to the weight of each study in the meta-analysis. The dashed vertical line represents the summary RR, with the open diamond showing the corresponding CI. The solid line indicates an RR of 1.

Figure 11 presents the results from the meta-analysis of stent thrombosis comparing carriers and noncarriers of gain-of-function CYP2C19 alleles, along with study-specific event rates. The figure is described further in the section entitled “Studies of Patients with Ischemic Heart Disease, Stent Thrombosis” as follows: “The summary RR for stent thrombosis comparing carriers of any loss-of-function allele versus noncarriers was 2.07 (95 percent CI 0.68, 6.33); P=0.201. Overall, there was limited evidence of between-study heterogeneity (PQ=0.374; I2=7 percent).”

###### Stroke

Information on the predictive value of loss-of-function alleles for stroke was reported in seven studies with nonoverlapping populations of patients with ischemic heart disease.78,91,97-100,108 Studies had heterogeneous sample sizes (minimum sample size = 201; maximum = 2,485) and represented a minority of the 57 studies reporting clinical outcomes. The summary RR for stent thrombosis comparing carriers of any loss-of-function allele versus noncarriers was 2.07 (95% CI 0.68, 6.33); p=0.201. Overall, there was limited evidence of between-study heterogeneity (P_Q_ = 0.374; I^2^ = 7 percent). Figure 12 presents the meta-analysis results, along with study-specific event rates.

Figure 12 Meta-analysis of stroke comparing carriers and noncarriers of loss-of-function CYP2C19 alleles

Abbreviations: CI = confidence interval; LOF = loss-of-function; RR = relative risk.

One study (Mega et al. 2009^99^) did not report the number of observed events.

The solid squares (and horizontal lines) indicate the RR of stroke (and the corresponding 95% CI) for individual studies. The affected numbers of carriers or noncarriers are shown to the right of the plot. The size of the squares is proportional to the weight of each study in the meta-analysis. The dashed vertical line represents the summary RR, with the open diamond showing the corresponding CI. The solid line indicates an RR of 1.

Figure 12 presents the results from the meta-analysis of stroke comparing carriers and noncarriers of gain-of-function CYP2C19 alleles, along with study-specific event rates. The figure is described further in section “Studies of Patients with Ischemic Heart Disease, Stroke” as follows: “Information on the predictive value of loss-of-function alleles for stroke was reported in seven studies with nonoverlapping populations of patients with ischemic heart disease. Studies had heterogeneous sample sizes (minimum sample size=201; maximum=2485) and represented a minority of the 57 studies reporting clinical outcomes. The summary RR for stent thrombosis comparing carriers of any loss-of-function allele versus noncarriers was 2.07 (95 percent CI 0.68, 6.33); P=0.201. Overall, there was limited evidence of between-study heterogeneity (PQ=0.374; I2=7 percent).”

Only a single study91 reported information on the association between gain-of-function alleles (*17) and stroke risk. The study reported a non-statistically significant RR of 0.93 (95% CI, 0.23 to 3.88), suggesting that there is substantial uncertainty regarding the effect of gain-of-function alleles on stroke risk.

###### MACE

Composite clinical outcomes, often called MACE, were the most commonly reported clinical outcome across the eligible studies. Although definitions of these composite outcomes were somewhat variable, we reasoned that the most inclusive definition used by each study (i.e., the one including as many events as possible) would provide an estimate of the cardiovascular morbidity experienced by individuals in each study. (This is also common practice in meta-analyses in cardiovascular disease topics.) Details about the exposure and outcome definitions used in the eligible studies are presented in Appendix D.

Of the studies reporting on MACE, 25 were considered to have included nonoverlapping patient populations and compared event rates among patients with at least one loss-of-function allele versus those with no loss-of function alleles.29,79,82,84,88,91-93,95-97,99,100,104,105,108-117 Studies were fairly large (minimum sample size=86; median sample size=428). The summary RR comparing carriers of any loss-of-function allele versus noncarriers was 1.20 (95% CI 1.04, 1.39; p=0.015). Overall, there was moderate between-study heterogeneity (P_Q_ = 0.076; I^2^ = 31 percent). Figure 13 presents the meta-analysis results, along with study-specific event rates.

Figure 13 Meta-analysis of MACE comparing carriers and noncarriers of loss-of-function CYP2C19 alleles

Abbreviations: CI = confidence interval; LOF = loss-of-function; MACE = major adverse cardiovascular events; RR = relative risk.

The solid squares (and horizontal lines) indicate the RR of MACE (and the corresponding 95% CI) for individual studies. The affected numbers of carriers or noncarriers are shown to the right of the plot. The size of the squares is proportional to the weight of each study in the meta-analysis. The dashed vertical line represents the summary RR, with the open diamond showing the corresponding CI. The solid line indicates an RR of 1.

Figure 13 presents the results from the meta-analysis of major adverse cardiovascular events comparing carriers and noncarriers of loss-of-function CYP2C19 alleles, along with study-specific event rates. The figure is described further in section “Studies of Patients with Ischemic Heart Disease, MACE” as follows: “Of the studies reporting on MACE, 25 were considered to have included nonoverlapping patient populations and compared event rates among patients with at least one loss-of-function allele versus those with no loss-of function alleles. Studies were fairly large (minimum sample size=86; median sample size=428). The summary RR comparing carriers of any loss-of-function allele versus noncarriers was 1.20 (95 percent CI 1.04, 1.39; P=0.015). Overall, there was moderate between-study heterogeneity (PQ=0.076; I2=31 percent).”

Figure 14 presents an analysis of predictive accuracy for the same group of studies (22 of 25 studies provided the necessary data) under a dominant genetic model. The summary sensitivity was 0.44 (95% CI 0.33, 0.56) and the average specificity was 0.67 (95% CI 0.61, 0.72) using a random effects model.

Figure 14 Prognostic performance of CYP2C19 genetic testing for MACE

Bivariate meta-analysis of sensitivity and specificity for predicting MACE. The black solid line shows the fitted summary receiver operating characteristic curve; the gray solid line is the chance diagonal. Individual studies are shown as bubbles with size proportional to study size. MACE = major adverse cardiovascular events.

Figure 14 presents an analysis of predictive accuracy for the same group of studies (22 of 25 studies provided the necessary data) under a dominant genetic model. The summary sensitivity was 0.44 (95 percent CI 0.33, 0.56) and the average specificity was 0.67 (95 percent CI 0.61, 0.72) using a random effects model.

Information on the predictive value of gain-of-function alleles for major adverse cardiovascular events was reported in seven studies with nonoverlapping populations of patients with ischemic heart disease.79,84,91,109,110,113,115 Studies were large (minimum sample size=428); however, they represented a minority of the 25 studies reporting on MACE outcomes. The summary RR for all-cause mortality comparing carriers of any gain-of-function allele versus noncarriers was 0.82 (95% CI 0.74, 0.92; p<0.001). Overall, there was little between-study heterogeneity (P_Q_ = 0.966; I^2^ = 0 percent). Figure 15 presents the meta-analysis results, along with study-specific event rates.

Figure 15 Meta-analysis of MACE comparing carriers and noncarriers of gain-of-function CYP2C19 alleles

Abbreviations: CI = confidence interval; CURE = Clopidogrel in Unstable Angina to Prevent Recurrent Events trial; GOF = gain-of-function; MACE = major adverse cardiovascular events; RR = relative risk.

The solid squares (and horizontal lines) indicate the RR of MACE (and the corresponding 95% CI) for individual studies. The affected numbers of carriers or noncarriers are shown to the right of the plot. The size of the squares is proportional to the weight of each study in the meta-analysis. The dashed vertical line represents the summary RR, with the open diamond showing the corresponding CI. The solid line indicates an RR of 1.

Figure 15 presents the results from the meta-analysis of major adverse cardiovascular events comparing carriers and noncarriers of gain-of-function CYP2C19 alleles, along with study-specific event rates. The figure is described further in the section entitled “Studies of Patients with Ischemic Heart Disease,MACE” as follows: “Studies were large (minimum sample size=428); however, they represented a minority of the 25 studies reporting on MACE outcomes. The summary RR for all-cause mortality comparing carriers of any gain-of-function allele versus noncarriers was 0.82 (95 percent CI 0.74, 0.92; P<0.001). Overall, there was little between-study heterogeneity (PQ=0.966; I2=0 percent).”

###### Bleeding Events

Of the studies reporting on bleeding events, six were considered to have included nonoverlapping patient populations and compared event rates among patients with at least one loss-of-function allele versus those with no loss-of function alleles.88,98,100,104,109,114 Studies were large (minimum sample size=266). The summary RR comparing carriers of any loss-of-function allele versus noncarriers was 1.02 (95% CI 0.86, 1.21; p=0.81). Overall, there was little between-study heterogeneity (P_Q_ = 0.701; I^2^ = 0 percent). Figure 16 presents the meta-analysis results, along with study-specific event rates.

Figure 16 Meta-analysis of bleeding events comparing carriers and noncarriers of loss-of-function CYP2C19 alleles

Abbreviations: CI = confidence interval; LOF = loss-of-function; RR = relative risk.

The solid squares (and horizontal lines) indicate the RR of bleeding events (and the corresponding 95% CI) for individual studies. The affected numbers of carriers or noncarriers are shown to the right of the plot. The size of the squares is proportional to the weight of each study in the meta-analysis. The dashed vertical line represents the summary RR, with the open diamond showing the corresponding CI. The solid line indicates an RR of 1.

Figure 16 presents the results from the meta-analysis of of bleeding events comparing carriers and noncarriers of loss-of-function CYP2C19 alleles, along with study-specific event rates. The figure is described further in section “Studies of Patients with Ischemic Heart Disease, Bleeding Events” as follows: “Of the studies reporting on bleeding events, six were considered to have included nonoverlapping patient populations and compared event rates among patients with at least one loss-of-function allele versus those with no loss-of function alleles. Studies were large (minimum sample size=266). The summary RR comparing carriers of any loss-of-function allele versus noncarriers was 1.02 (95 percent CI 0.86, 1.21; P=0.81). Overall, there was little between-study heterogeneity (PQ=0.701; I2=0 percent).”

Information on the predictive value of gain-of-function alleles for bleeding events was reported in six studies with nonoverlapping populations of patients with ischemic heart disease.79,88,109,118-120Studies were large (minimum sample size = 300); however, they represented a minority of the 57 studies reporting clinical outcomes. The summary RR for all bleeding events comparing carriers of any loss-of-function allele versus noncarriers was 1.51 (95% CI 1.08, 2.11); p=0.016. Overall, there was moderate (and statistically significant) between-study heterogeneity (P_Q_ = 0.088; I^2^ = 48 percent). Figure 17 presents the meta-analysis results, along with study-specific event rates.

Figure 17 Meta-analysis of bleeding events comparing carriers and noncarriers of gain-of-function CYP2C19 alleles

Abbreviations: CI = confidence interval; GOF = gain-of-function; RR = relative risk.

The solid squares (and horizontal lines) indicate the RR of bleeding events (and the corresponding 95% CI) for individual studies. The affected numbers of carriers or noncarriers are shown to the right of the plot. The size of the squares is proportional to the weight of each study in the meta-analysis. The dashed vertical line represents the summary RR, with the open diamond showing the corresponding CI. The solid line indicates an RR of 1.

Figure 17 presents the results from the meta-analysis of of bleeding events comparing carriers and noncarriers of gain-of-function CYP2C19 alleles, along with study-specific event rates. The figure is described further in the section entitled “Studies of Patients with Ischemic Heart Disease, Bleeding Events” as follows: “Information on the predictive value of gain-of-function alleles for bleeding events was reported in six studies with nonoverlapping populations of patients with ischemic heart disease. Studies were large (minimum sample size=300); however, they represented a minority of the 57 studies reporting clinical outcomes. The summary RR for all bleeding events comparing carriers of any loss-of-function allele versus noncarriers was 1.51 (95 percent CI 1.08, 2.11); P=0.016. Overall, there was moderate (and statistically significant) between-study heterogeneity (PQ=0.088; I2=48 percent).”

###### Other Clinical Outcomes

Seven studies reported information on five additional clinical outcomes (1 on urgent revascularization of any vessel and on a composite of “ischemic endpoints related to stent thrombosis”121; 1 on urgent revascularization (no additional details provided) 100; 3 on target vessel revascularization throughout the study period90; 1 on any revascularization; and one on a composite of benefits and harms, termed “net clinical benefit” 118). All studies assessed the effect of loss-of-function alleles; one also assessed gain of function alleles. Generally event rates were higher among carriers of loss-of-function alleles (results were statistically significant only in 3 cases121,). These outcomes were not considered adequately homogeneous for further quantitative synthesis; study specific results have been summarized in Appendix D.

###### Sensitivity Analyses to Alternative Genetic Models

The majority of studies presented results only under a dominant genetic model. To evaluate the robustness of our findings to alternative genetic models, when possible, we repeated the analyses assuming a recessive or additive genetic model. Such analyses were possible for the outcomes of stent thrombosis and MACE and only for the effect of LOF alleles. Table 4 summarizes our findings. Generally, these results are supportive of the analyses using a dominant model, because they also indicate significant association between LOF alleles and adverse clinical outcomes. Effect sizes using both models are larger than those under the additive model, however this observation alone does not imply that any one model is more likely to be true. Further, I^2^ values were higher under the recessive and additive models, suggesting that the average effect is less representative of the individual studies. Of particular note is also the very limited number of studies providing evidence for comparisons under a recessive or additive model (maximum of 9 and 11 as compared to a total of 25 and 17 nonoverlapping studies providing data on MACE and stent thrombosis for the dominant model, respectively).

Table 4 Sensitivity analysis to alternative genetic models

Genetic model | Outcome | Number of studies | RR (95% CI) | p-value | P_Q_; I^2^
Recessive | MACE | 9 | 1.85 (1.19 to 2.86) | 0.006 | 0.152; 33.3%
Recessive | Stent thrombosis | 11 | 2.40 (1.61 to 3.57) | <0.001 | 0.215; 24.0%
Additive | MACE | 6 | 1.54 (1.11 to 2.14) | 0.010 | 0.001; 77.1%
Additive | Stent thrombosis | 9 | 1.77 (1.44 to 2.18) | <0.001 | 0.135; 35.4%

Additive model estimates for each individuals study were obtained from studies reporting at least one event in each genotype category using generalized linear models with an appropriate link function (logit for case-control studies and log for longitudinal studies) and binomial variance. Meta-analysis estimates were then obtained using a random effects model.

Abbreviations: CI = confidence interval; MACE = major adverse cardiovascular event; RR = relative risk.

For LOF alleles, under a recessive genetic model, we also evaluated prognostic performance using bivariate meta-analysis of sensitivity and specificity (Figure 18). For MACE the summary sensitivity was 0.10 (95% CI 0.04, 0.24) and the summary specificity was 0.94 (95% CI 0.90, 0.97). For stent thrombosis the summary sensitivity was 0.10 (95% CI 0.06, 0.17) and the summary specificity was 0.96 (95% CI 0.93, 0.97). The estimates for sensitivity are lower and the estimates for specificity are higher compared to those obtained under the dominant model, for both outcomes.

Figure 18 Prognostic performance under a recessive model for CYP2C19*2 LOF variants

Bivariate meta-analysis of sensitivity and specificity for predicting MACE (left panel) and stent thrombosis (right panel). Black solid lines show the fitted summary receiver operating characteristic curves for each meta-analysis; gray solid lines indicate the chance diagonal. Individual studies are shown as bubbles with size proportional to sample size.

Abbreviations: LOF = loss-of-function alleles; MACE = major adverse cardiovascular events.

Figure 18 presents an analysis of the prognostic value of LOF alleles, under a recessive genetic model, using bivariate meta-analysis of sensitivity and specificity. For MACE the summary sensitivity was 0.10 (95 percent CI 0.04, 0.24) and the summary specificity was 0.94 (95 percent CI 0.90, 0.97). For stent thrombosis the summary sensitivity was 0.10 (95 percent CI 0.06, 0.17) and the summary specificity was 0.96 (95 percent CI 0.93, 0.97). The estimates for sensitivity were lower and the estimates for specificity are higher compared to those obtained under the dominant model, for both outcomes.

##### Intermediate Outcome: Platelet Reactivity

Seventy-four studies used the results of CYP2C19 genetic testing to predict intermediate outcomes of platelet reactivity, either as a continuous variable or according to a threshold of reactivity (e.g., high vs. low). The assays used to measure platelet reactivity are described in detail later in the Results section (see Key Question 2a and Appendix D). Several studies used more than one assay as a method for outcome ascertainment, with platelet reactivity measured with light-transmission aggregometry (LTA) in 43 studies (58 percent), VerifyNow P2Y12 in 33 (45 percent), the VASP assay in 17 (23 percent), and other assays in 10 studies (14 percent). All studies used ADP as the agonist of interest. Detailed information about the assays used and study-level results of platelet reactivity as a continuous outcome are presented in Appendix D.

###### Platelet Reactivity as a Continuous Outcome

Sixty-one studies reported on the effect of genotype on platelet reactivity as a continuous outcome. Reactivity was commonly assessed using LTA, the VASP assay, or VerifyNow P2Y12.

Studies generally showed that the mean or median reactivity was higher among clopidogrel-treated patients with one or two loss-of-function alleles compared to those with no loss-of-function alleles. The followup periods differed across the studies (from a few hours to more than 1 year after clopidogrel loading) and measurements were obtained using different assays and different calculation methods (e.g., absolute within-patient change from baseline, percent change within patient, or absolute value at last followup). Furthermore, the genotype groupings employed were also variable. Finally, the studies used different statistical tests and made different parametric assumptions for their comparisons. Because of the extensive differences among studies and the often incomplete reporting of numerical information we did not perform meta-analyses for studies using continuous measurements of reactivity as the outcome of interest.

###### Platelet Reactivity as a Categorical Outcome

Thirty-nine studies reported on the effect of genotype on platelet reactivity as a categorical outcome. Reactivity was commonly assessed using LTA, the VASP assay, or VerifyNow P2Y12.

Studies generally showed that platelet reactivity above the threshold used (or in higher quantiles compared to lower quantiles of reactivity) was more common in clopidogrel-treated patients with one or two loss-of-function alleles than those with no loss-of-function alleles. As was true for studies assessing reactivity as a continuous outcome, results in studies of categories of reactivity were reported with different followup periods and measurements were obtained using different assays and different calculation methods (i.e., by discretizing absolute within-patient change from baseline, percent change within patient, or absolute reactivity values at last followup). Furthermore, genotype grouping was also variable. Because of these extensive differences among studies, we did not perform meta-analyses for studies using categorical measurements of reactivity as the outcome of interest.

#### Patient Populations Other Than Those With Ischemic Heart Disease

Only six studies reported results on the predictive value of CYP2C19 genotyping for clinical or intermediate outcomes in non–ischemic heart disease populations (three of mixed populations of coronary, cerebrovascular, and peripheral arterial disease; one of patients with cerebrovascular disease; one of a mixed population of patients with manifest atherothrombotic disease along with asymptomatic patients at high risk for atherothrombotic disease; one of patients with atrial fibrillation at risk for stroke). Detailed information on these studies is presented in Appendix D. These studies included very different clinical populations and reported information on diverse outcomes [2 clinical outcomes; 2 intermediate outcomes (platelet reactivity); 2 both].

### Comparisons Between Genetic Testing for CYP2C19 Variants and Phenotypic Testing for Platelet Reactivity

Only four studies provided extractable information regarding the relative prognostic ability of genetic testing for CYP2C19 loss-of-function variants and phenotypic testing of platelet reactivity for MACE (4 studies) or stent thrombosis (3 studies).82,88,95,111 These studies have been considered with regards to the prognostic value of genetic testing in the preceding sections of this chapter. To avoid duplication, the comparative data have been summarized qualitatively under Key Question 2b.

### Risk of Bias for Studies Reviewed for Key Question 1b

The detailed assessment of 11 risk-of-bias items for studies evaluating the predictive ability of genetic testing regarding clinical outcomes or platelet reactivity is presented in Appendix D. Briefly, most studies used a longitudinal design (not case–control) and no studies had substantial loss-to-followup. Inappropriate exclusions were uncommon however information on blinding was often not reported (particularly for the index test) or not used. Using the arbitrary cutoff values based on the number of adequately addressed risk of bias items 12 studies were rated as quality “A,” 88 studies were rated as quality “B,” and 6 were rated as quality “C.”

For outcomes for which we performed meta-analysis, we assessed differences between more precise (larger) and less precise (smaller) studies using the Egger regression-based test for small-study effects. Overall, we found a statistically significant difference between smaller and larger studies on the effect size for stent thrombosis, MACE, and bleeding events for loss-of-function carriers (see “P-Value” column in Table 3). Smaller studies had more extreme (larger) effect sizes as compared to larger studies. Although publication bias (i.e., selective publication of positive or extreme findings) is a potential explanation for these associations, other factors, such as “true” heterogeneity between smaller and larger studies, outcome reporting bias (in the case of stent thrombosis), chance, or other sources of bias could explain these results. Nonetheless, these results suggest that selective publication may have affected the available data and limits somewhat the strength of the conclusions that can be drawn (e.g., it contributed to our decision to grade the strength of evidence on MACE as moderate, rather than high).

## Key Question 1c What is the impact of modifying factors on the association between genetic test results and clinical outcomes?

We reviewed studies to identify any evidence that patient- or system-level factors or test characteristics could modify the predictive ability of genetic testing for CYP2C19 variants. Evidence of effect modification by person-level characteristics (e.g., age, sex, disease severity) is best obtained from comparisons within a given study (i.e., among subgroups of the patient population that were selected using the same criteria and managed in a similar way). Additional evidence on effect modification can be derived from exploratory comparisons across studies, by assessing study-level characteristics (e.g., the setting of care or study design characteristics) or characteristics of the overall patient population (e.g., populations selected on the basis of ancestry).^d^ In the following sections we discuss each of these sources of information regarding effect modification separately.

d We refer to the information obtained from cross-study comparisons as “exploratory” because comparisons for a given characteristics across studies may be confounded (by other study features). Our ability to statistically “control” for such differences is typically limited by the relatively small number of available studies available for meta-analysis.

### Effect Modification Within Studies

In total, 20 studies (see Table 5) reported information on modification of the predictive effect of the genetic test by various factors. Eight of the studies used platelet reactivity as the outcome of interest and 12 reported information on clinical outcomes (adverse cardiovascular outcomes or bleeding events). We caution that, because only a small subset of the eligible studies provided information adequate to statistically assess effect modification, selective reporting is highly likely.

Table 5 Studies reporting information on effect modification

Author Year Country PMID Study Name (when available) | Patient Population | Antiplatelet Regimen | Effect Modifier | Summary of Findings^*^
Fernando122 2011 21696537 Australia NR | Patients with ACS treated with PCI with stent implantation; all patients were participants in a randomized cross-over trial of esomeprazole 40 mg vs. placebo | Aspirin (100 mg/d) and clopidogrel (75 mg/d) | Esomeprazole (40 mg/d) [the study drug] | After 6 w of exposure to each study drug, extensive metabolizers (those with no LOF alleles, i.e., no CYP2C19*2 allele) showed a significant mean reduction from baseline (−8% for PRI by VASP assay, −8.5 AUC units by aggregometry, −37 PRU by VerifyNow; p<0.01 for all comparisons) in platelet reactivity with esomeprazole vs. placebo. In poor or intermediate metabolizers (with at least one CYP2C19*2 allele) the mean reduction was nonsignificant (−8.73% for PRI, p=0.157; −3 AUC units for aggregometry, p=0.566; 39 PRU by VerifyNow, p=0.139) with esomeprazole vs. placebo.
Harmsze125 2010 19934793 Netherlands NR | Patients with CAD undergoing PCI with stent implantation | Clopidogrel “maintenance therapy” and aspirin (80 mg/d) | Indication for PCI with stent placement: ACS or stable angina | ORs for stent thrombosis: For patients undergoing PCI for ACS Carrier of *2 vs. not, OR=2.0 (95% CI, 1.1 to 4.5) Carrier of *3 vs. not, OR=2.9 (95% CI, 1.0 to 9.3) For patients undergoing PCI for stable angina Carrier of *2 vs. not, OR=1.7 (95% CI, 0.9 to 4.1) Carrier of *3 vs. not, OR=1.2 (95% CI, 0.4 to 6.5) Interaction p-value for the effect of *2 over PCI indication=0.97 Interaction p-value for the effect of *3 over PCI indication=0.18
Harmsze103 2010 20833683 Netherlands NR | Patients undergoing elective stent implantation | All patients received aspirin (80–100 mg/d); 297 patients were on chronic clopidogrel (maintenance dose of 75 mg/d) and 131 patients received a clopidogrel loading dose of 300 mg upon study entry | Clopidogrel treatment status (maintenance treatment vs. loading dose); assessment of gene–gene interaction | Mean difference between carriers and noncarriers of CYP2C19*2 allele stratified by clopidogrel treatment group, using different assays (unadjusted results): Clopidogrel maintenance treatment LTA ADP 5 μmol/L: 6.7 (95% CI, 3.6 to 9.8) LTA ADP 20 μmol/L: 6.3 (95% CI, 3.4 to 9.3) VerifyNow PRU: 35.1 (95% CI, 17.2 to 53.0) Clopidogrel loading dose LTA ADP 5 μmol/L: 7.8 (95% CI, 3.9 to 12.6) LTA ADP 20 μmol/L: 7.4 (95% CI, 3.3 to 11.6) VerifyNow PRU: 37.5 (95% CI, 16.5 to 58.5) z-score p-values for effect modification (calculated): nonsignificant for all comparisons OR for *2 carriers vs. noncarriers for predicting poor response (>70% aggregation on LTA ADP 20 μmol/L) to antiplatelet treatment (unadjusted results): Maintenance treatment, LTA ADP 20μmol/L OR=3.7 (95% CI, 2.0, 6.9) Loading, LTA ADP 20μmol/L OR=3.7 (95% CI, 2.0, 6.9) z-score p-value for interaction: >0.99 Multiplicative interaction between *2 and *3 variants for poor response: LTA ADP 20μmol/L 0.1 (95% CI, 0.004 to 0.79); p=0.033 VerifyNow PRU 0.1 (95% CI, 0.002 to 0.7); p=0.035
Liu126 2010 21163112 China NR | Patients undergoing elective stent implantation for stable angina | Clopidogrel (300 mg loading dose and 75 mg/d maintenance dose) and aspirin (300 mg/d) | Smoking status (≥10 cigarettes/d) | p=0.671 for interaction between smoking status and *2 carrier status for predicting poor response by LTA (≤10% reduction in baseline aggregation at 24 h) in a logistic regression model
Maeda123 2011 21178986 Japan NR | Patients with CAD undergoing PCI | Aspirin (100 mg/d) and clopidogrel (75 mg/d) for >4 w | PPI treatment vs. not; BMI≥25 kg/m^2^ | CYP2C19 genotype effect (mean residual % on-clopidogrel reactivity) stratified by PPI status: On PPI Two LOF alleles: n=2, mean=36.0, SD=8.5 One LOF allele: n=13, mean=27.5, SD=9.9 No LOF allele: n=14, mean=22.7, SD=7.6 Not on PPI Two LOF alleles: n=14, mean=33.5, SD=8.0 One LOF allele: n=33, mean=25.7, SD=9.0 No LOF allele: n=25, mean=17.7, SD=8.4 Interaction p-values (calculated with inverse variance-weighted least-squares regression): for one LOF allele × PPI=0.466 for two LOF alleles × PPI=0.724 CYP2C19 genotype effect (mean residual % on-clopidogrel reactivity) stratified by BMI status: BMI≥25 kg/m^2^ Two LOF alleles: n=4, mean=36.0, SD=8.7 One LOF allele: n=16, mean=25.9, SD=9.8 No LOF allele: n=9, mean=24.4, SD=7.4 BMI<25 kg/m^2^ Two LOF alleles: n=14, mean=33.1, SD=4.3 One LOF allele: n=14, mean=26.4, SD=8.5 No LOF allele: n=14, mean=17.1, SD=8.9 Interaction p-values (calculated with inverse variance-weighted least-squares regression): for one LOF allele × PPI=0.071 for two LOF alleles × PPI=0.347
Pare109 2010 20979470 Multiple countries CURE | Patients with NSTE ACS in the clopidogrel-treated arm of the CURE randomized trial | Aspirin and clopidogrel (75 mg/d) | Race/ethnicity (European ancestry vs. Latin American Ancestry) | Interaction p-value for the predictive value of genotype group (intermediate/poor metabolizer vs. extensive/ultra metabolizer) between ancestry groups (calculated with chi-square test for heterogeneity): For the first primary composite outcome (cardiovascular death, nonfatal MI, or stroke)=0.682 For another first primary composite outcome (cardiovascular death, nonfatal MI, stroke, recurrent ischemia, or hospitalization for unstable angina)=0.722 For major bleeding=0.678
Simon124 2011 21262992 France FAST-MI | Patients admitted to intensive care unit for definite AMI within 48 h after symptom onset with available DNA; patients had to be PPI-naïve at study entry for the main analysis | Clopidogrel-based treatment | PPI therapy (yes vs. no) | Estimate for PPI group vs. no-PPI group (adjusted for GRACE score, sex, and cardiovascular risk factors) OR for in-hospital death, MI, or stroke No variant allele, OR=0.68 (95% CI, 0.37 to 1.25) One variant allele, OR=0.34 (95% CI, 0.11 to 1.08) Two variant alleles, OR=1.05 (95% CI, 0.03 to 34.6) Interaction p-value across groups=0.547 [calculated with chi-square test for heterogeneity] HR for death, MI, or stroke in hospital survivors receiving clopidogrel at 1 year No variant allele, 1.13 (95% CI, 0.74 to 1.74 One variant allele, 1.02 (95% CI, 0.44 to 2.40) Two variant alleles, 0.25 (95% CI, 0.02 to 3.58) Interaction p-value across groups=0.527 calculated with chi-square test for heterogeneity] Overall interaction effect: For the short-term outcome, p=0.57 For the 1-year outcome, p=0.64
Simon110 2009 19106083 France FAST-MI | Patients admitted to intensive care unit for definite AMI within 48 h after symptom onset with available DNA | Clopidogrel-based treatment (mean clopidogrel loading dose 300 mg; mean maintenance dose 75 mg/d) | ABCB1 genotype (rs1045642) [carrier of at least one T allele vs. none] | p=0.99 for interaction between CYP2C19 and ABCB1 for the composite outcome of death, nonfatal MI, or stroke at 1 yr
Trenk111 2008 18482659 Germany EXCELSIOR | Patients undergoing elective PCI with stent placement | Clopidogrel (600 mg loading dose) and aspirin (100 mg) for ≥5 d before the procedure | Stent type (BMS vs. DES) | OR for CYP2C19*2 carriers vs. noncarriers for death or MI at 1 yr Patients with ≥ 1 DES OR=1.60 (95% CI, 0.35 to 7.32) Patients with BMS only OR=0.30 (95% CI, 0.07 to 1.34) Interaction p-value=0.118 [calculated with chi-square test for heterogeneity]
Yamamoto97 2011 21168310 Japan NR | Patients undergoing cardiac catheterization at time of diagnosis of stable CAD | Aspirin (100 mg/d) and clopidogrel (75 mg/d) | Days on clopidogrel-based therapy (<7 vs. ≥7) | CYP2C19 genotype effect (on-clopidogrel reactivity in AU*min by LTA ADP 20 mol/L) stratified by days on treatment: <7 d Two LOF alleles: n=12, mean=3186, SD=1595 One LOF allele: n=32, mean=4655, SD=1380 No LOF allele: n=25, mean=5663, SD=1385 ≥7 d Two LOF alleles: n=13, mean=3007, SD=1541 One LOF allele: n=19, mean=3490, SD=1392 No LOF allele: n=22, mean=4674, SD=824 Interaction p-value [calculated with inverse variance-weighted least-squares regression] For one LOF allele × PPI=0.106 For two LOF alleles × PPI=0.212
Bhatt85 2012 22450429 Multinational CHARISMA | Patients with manifest atherothrombotic disease (coronary, cerebrovascular, or peripheral artery) or patients at high risk for atherothrombotic disease | Aspirin (75 to 162 mg/d) and clopidogrel (75 mg/d) | Ethnicity (Asian vs. non-Asian) PCI subcohort vs. non-PCI subcohort “CAPRIE-like” cohort vs. others (CAPRIE-like was defined as the subgroup of patients with MI, ischemic stroke, or symptomatic PAD) | Prognostic effect under dominant model for LOF alleles for the MACE (defined as first occurrence of non-fatal or fatal MI, non-fatal or fatal stroke, or cardiovascular death):; - European ancestry: OR=1.28 (95% CI, 0.89 to 1.83); - Asian or African ancestry: OR=1.80 (95% CI, 0.55 to 5.92); Interaction p-value=0.58; - CAPRIE-like cohort (only among patients of European ancestry): OR=1.38 (95% CI, 0.88 to 2.17); - Others (only among patients of European ancestry):; OR=1.14 (95% CI, 0.63 to 2.07); Interaction p-value=0.61; - PCI-subcohort (only among patients of European ancestry): OR=0.72 (95% CI, 0.28 to 1.80); - Non-PCI subcohort: OR=1.43 (95% CI, 0.96 to 2.13); Interaction p-value=0.18
Bhatt85 2012 22450429 Multinational CHARISMA | Patients with manifest atherothrombotic disease (coronary, cerebrovascular, or peripheral artery) or patients at high risk for atherothrombotic disease | Aspirin (75 to 162 mg/d) and clopidogrel (75 mg/d) | Ethnicity (Asian vs. non-Asian) PCI subcohort vs. non-PCI subcohort “CAPRIE-like” cohort vs. others (CAPRIE-like was defined as the subgroup of patients with MI, ischemic stroke, or symptomatic PAD) | Prognostic effect under dominant model for LOF alleles for the MACE (defined as first occurrence of non-fatal or fatal MI, non-fatal or fatal stroke, cardiovascular death, hospitalization for unstable angina, TIA, or revascularization procedure):; - European ancestry: OR=1.06 (95% CI, 0.83 to 1.34); - Asian or African ancestry: OR=1.18 (95% CI, 0.49 to 2.85); Interaction p-value=0.82; - CAPRIE-like cohort (only among patients of European ancestry): OR=1.17 (95% CI, 0.86 to 1.59); - Others (only among patients of European ancestry):; OR= 0.92 (95% CI, 0.64 to 1.35); Interaction p-value=0.35; - PCI-subcohort (only among patients of European ancestry): OR=0.80 (95% CI, 0.51 to 1.26); - Non-PCI subcohort: OR=1.20 (95% CI, 0.90 to 1.59); Interaction p-value=0.14
Bhatt85 2012 22450429 Multinational CHARISMA | Patients with manifest atherothrombotic disease (coronary, cerebrovascular, or peripheral artery) or patients at high risk for atherothrombotic disease | Aspirin (75 to 162 mg/d) and clopidogrel (75 mg/d) | Ethnicity (Asian vs. non-Asian) PCI subcohort vs. non-PCI subcohort “CAPRIE-like” cohort vs. others (CAPRIE-like was defined as the subgroup of patients with MI, ischemic stroke, or symptomatic PAD) | Prognostic effect under dominant model for LOF alleles for major GUSTO bleeding:; - European ancestry: OR=1.13 (95% CI, 0.71 to 1.79); - Asian or African ancestry: OR=0.85 (95% CI, 0.15 to 4.81); Interaction p-value=0.76; - CAPRIE-like cohort (only among patients of European ancestry): OR=1.70 (95% CI, 0.97 to 2.98); - Others (only among patients of European ancestry):; OR=0.55 (95% CI, 0.24 to 1.28); Interaction p-value=0.03; - PCI-subcohort (only among patients of European ancestry): OR=1.81 (95% CI, 0.68 to 4.83); - Non-PCI subcohort: OR=0.99 (95% CI, 0.59 to 1.67); Interaction p-value=0.29
Bhatt85 2012 22450429 Multinational CHARISMA | Patients with manifest atherothrombotic disease (coronary, cerebrovascular, or peripheral artery) or patients at high risk for atherothrombotic disease | Aspirin (75 to 162 mg/d) and clopidogrel (75 mg/d) | Ethnicity (Asian vs. non-Asian) PCI subcohort vs. non-PCI subcohort “CAPRIE-like” cohort vs. others (CAPRIE-like was defined as the subgroup of patients with MI, ischemic stroke, or symptomatic PAD) | Prognostic effect under dominant model for LOF alleles for all GUSTO bleeding:; - European ancestry: OR=0.76 (95% CI, 0.63 to 0.92); - Asian or African ancestry: OR=0.82 (95% CI, 0.36 to 1.86); Interaction p-value=0.87; - CAPRIE-like cohort (only among patients of European ancestry): OR=0.76 (95% CI, 0.59 to 0.98); - Others (only among patients of European ancestry): OR=0.76 (95% CI, 0.57 to 1.00); Interaction p-value=0.97; - PCI-subcohort (only among patients of European ancestry): OR=0.84 (95% CI, 0.59 to 1.20); - Non-PCI subcohort: OR= 0.74 (95% CI, 0.59 to 0.92); Interaction p-value= 0.54
Bhatt85 2012 22450429 Multinational CHARISMA | Patients with manifest atherothrombotic disease (coronary, cerebrovascular, or peripheral artery) or patients at high risk for atherothrombotic disease | Aspirin (75 to 162 mg/d) and clopidogrel (75 mg/d) | Ethnicity (Asian vs. non-Asian) PCI subcohort vs. non-PCI subcohort “CAPRIE-like” cohort vs. others (CAPRIE-like was defined as the subgroup of patients with MI, ischemic stroke, or symptomatic PAD) | Prognostic effect under dominant model for GOF alleles for the MACE (defined as first occurrence of non-fatal or fatal MI, non-fatal or fatal stroke, or cardiovascular death):; - European ancestry: OR=0.94 (95% CI, 0.66 to 1.34); - Asian or African ancestry: OR=0.58 (95% CI, 0.15 to 2.25); Interaction p-value=0.50; - CAPRIE-like cohort (only among patients of European ancestry): OR= 0.82 (95% CI, 0.53 to 1.29); - Others (only among patients of European ancestry):; OR=1.17 (95% CI, 0.66 to 2.07); Interaction p-value=0.35; - PCI-subcohort (only among patients of European ancestry): OR= 0.58 (95% CI, 0.24 to 1.38); - Non-PCI subcohort: OR=1.04 (95% CI, 0.71 to 1.54); Interaction p-value=0.23
Bhatt85 2012 22450429 Multinational CHARISMA | Patients with manifest atherothrombotic disease (coronary, cerebrovascular, or peripheral artery) or patients at high risk for atherothrombotic disease | Aspirin (75 to 162 mg/d) and clopidogrel (75 mg/d) | Ethnicity (Asian vs. non-Asian) PCI subcohort vs. non-PCI subcohort “CAPRIE-like” cohort vs. others (CAPRIE-like was defined as the subgroup of patients with MI, ischemic stroke, or symptomatic PAD) | Prognostic effect under dominant model for GOF alleles for the MACE (defined as first occurrence of non-fatal or fatal MI, non-fatal or fatal stroke, cardiovascular death, hospitalization for unstable angina, TIA, or revascularization procedure):; - European ancestry: OR=0.98 (95% CI, 0.78 to 1.23); - Asian or African ancestry: OR= 1.55 (95% CI, 0.64 to 3.74); Interaction p-value=0.32; - CAPRIE-like cohort (only among patients of European ancestry): OR= 0.87 (95% CI, 0.64 to 1.16); - Others (only among patients of European ancestry):; OR= 1.17 (95% CI, 0.82 to 1.66); Interaction p-value=0.95; - PCI-subcohort (only among patients of European ancestry): OR=1.02 (95% CI, 0.68 to 1.52); - Non-PCI subcohort: OR= 0.97 (95% CI, 0.74 to 1.27); Interaction p-value=0.86
Bhatt85 2012 22450429 Multinational CHARISMA | Patients with manifest atherothrombotic disease (coronary, cerebrovascular, or peripheral artery) or patients at high risk for atherothrombotic disease | Aspirin (75 to 162 mg/d) and clopidogrel (75 mg/d) | Ethnicity (Asian vs. non-Asian) PCI subcohort vs. non-PCI subcohort “CAPRIE-like” cohort vs. others (CAPRIE-like was defined as the subgroup of patients with MI, ischemic stroke, or symptomatic PAD) | Prognostic effect under dominant model for GOF alleles for major GUSTO bleeding:; - European ancestry: OR= 0.91 (95% CI, 0.59 to 1.42); - Asian or African ancestry: OR=0.35 (95% CI, 0.04 to 3.09); Interaction p-value=0.40; - CAPRIE-like cohort (only among patients of European ancestry): OR=0.80 (95% CI, 0.45 to 1.42); - Others (only among patients of European ancestry):; OR=1.11 (95% CI, 0.56 to 2.20); Interaction p-value=0.47; - PCI-subcohort (only among patients of European ancestry): OR=0.91 (95% CI, 0.33, 2.51); - Non-PCI subcohort: OR=0.90 (95% CI, 0.55, 1.48); Interaction p-value=0.98
Bhatt85 2012 22450429 Multinational CHARISMA | Patients with manifest atherothrombotic disease (coronary, cerebrovascular, or peripheral artery) or patients at high risk for atherothrombotic disease | Aspirin (75 to 162 mg/d) and clopidogrel (75 mg/d) | Ethnicity (Asian vs. non-Asian) PCI subcohort vs. non-PCI subcohort “CAPRIE-like” cohort vs. others (CAPRIE-like was defined as the subgroup of patients with MI, ischemic stroke, or symptomatic PAD) | Prognostic effect under dominant model for GOF alleles for all GUSTO bleeding:; - European ancestry: OR= 1.10 (95% CI, 0.93 to 1.31); - Asian or African ancestry: OR=0.61 (95% CI, 0.26 to 1.45); Interaction p-value=0.19; - CAPRIE-like cohort (only among patients of European ancestry): OR= 1.02 (95% CI, 0.81 to 1.28); - Others (only among patients of European ancestry):; OR=1.23 (95% CI, 0.95 to 1.60); Interaction p-value=0.29; - PCI-subcohort (only among patients of European ancestry): OR=1.13 (95% CI, 0.81 to 1.56); - Non-PCI subcohort: OR=1.10 (95% CI, 0.90 to 1.34); Interaction p-value=0.89 [all results were calculated; data to evaluate effect modification under other genetic models were NR]
Cayla 2011 22028352 France ONASSIT | Case-control study of patients with definite stent thrombosis and controls identified in a local PCI database (1:2 matched for age and sex) | Cases and controls were on dual antiplatelet therapy | Interactions were tested between “independent clinical and angiographic factors” (acute PCI, complex lesions, LVEG <40%, DM, use of PPI, clopidogrel loading dose) and genetic variants (CYP2C19) Gene-gene interaction (CYP2C19 variants with. ABCB1 and ITGB3) | All analyses were for the outcome of stent thrombosis. None of the interactions were statistically significant (all p>0.05). The exact p-value was reported only for the interaction of CYP2C19 and high-clopidogrel dose: p=0.46.
Collet 2011 21511218 France CLOVIS-2 | Patients with MI before the age of 45, screened from the AFIJI multicenter registry. | Patients were on maintenance aspirin (75 mg/d) and/or clopidogrel (75 mg/d) for ≥3 mo. They were randomized to an open-label loading dose of 300 or 900 mg of clopidogrel in a 2-period crossover fashion. Clopidogrel maintenance treatment (75 mg) was continued for ≥21 d before patients were crossed over to the alternate loading dose of clopidogrel. | Clopidogrel pre-treatment status (naïve vs. pre-treated) | The p-value for interaction between pre-treatment status and CYP2C19*2 carriage was not statistically significant for the relative reduction in residual platelet aggregation after both loading doses (p=0.76 for the 300 mg loading dose and p=0.62 for the 900 mg loading dose).
Delaney 2011 22190063 USA BioVU biobank | Patients started on antiplatelet therapy after MI or PCI with stent placement | Patients receiving clopidogrel on discharge | Ethnicity (European American vs. African American) | Prognostic effect under dominant model for the *2 allele for MACE (defined as all-cause mortality, MI, revascularization, or stroke) European Americans, OR=1.39 (95% CI, 0.96 to 2.01) African Americans, OR=2.46 (95% CI, 0.86 to 7.07) Others, OR=3.00 (95% CI, 0.14 to 64.26) P-for interaction = 0.55 [calculated] Prognostic effect under dominant model for the *17 allele for MACE (defined as all-cause mortality, MI, revascularization, or stroke) European Americans, OR=0.85 (95% CI, 0.60 to 1.21) African Americans, OR=1.31 (95% CI, 0.46 to 3.79) Others, OR=0.54 (95% CI, 0.02 to 14.35) P-for interaction = 0.72 [calculated]
Gajos 2012 22623230 Poland NR | Patients with stable CAD who underwent successful PCI with stent placement | Clopidogrel (600 mg loading dose; 75 mg/d maintenance) + aspirin 75 mg/d for 1 mo | 1000 mg of omega-3 PUFA (460 mg of eicosapentaenoic acid + 380 mg docosahexaenoic acid) vs. 1000 mg of soybean oil in a single capsule (placebo); exposure to the effect modifier was randomized | Interaction p-value at 30 d (maximum followup) using LTA ADP 5 μmol/L to assess outcomes=0.17 [calculated] Interaction p-value at 30 d (maximum followup) using LTA ADP 20 μmol/L to assess platelet reactivity=0.36 [calculated]
Harmsze 2011 21854540 Netherlands POPular | Patients with established coronary artery disease scheduled for elective PCI with stent implantation | Prior to PCI, all patients were pretreated with clopidogrel (75 mg/d therapy for >5 days or a loading dose of 300mg >24h before PCI or 600 mg >4h before PCI) + aspirin (80-100 mg/d for >10 d. Maintenance treatment was with clopidogrel (75 mg/d) + aspirin (80-100 mg/d) | Calcium channel blockers (yes vs. not) PPIs (yes vs. not) CCB + PPIs (yes vs. not) | For predicting MACE, defined as all-cause death, non-fatal MI, stent thrombosis, or ischemic stroke at 1 yr) [all results were calculated]:; - Interaction p-value comparing the effect of *2 carriership among patients receiving CCBs vs. not=0.16; - Interaction p-value comparing the effect of *2 carriership among patients receiving PPIs vs. not=0.30; - Interaction p-value comparing the effect of *2 carriership among patients receiving CCBs + PPIs vs. not=0.69
Hsu 2011 21144850 Taiwan NR | Patients with atherosclerotic disease (ischemic heart disease or stroke) and gastroduodenal ulcer who underwent endoscopy for dyspeptic symptoms while receiving clopidogrel | Patients had received clopidogrel for ≥2 wk (75 mg/d or 37.5 mg/d) and required long term antiplatelet therapy; during the study all patients received clopidogrel 75 mg/d; patients with H. pylori infection also received antibiotic treatment following a standardized scheme | PPI administration (20 mg/d esomeprazole vs. no PPI) for 6 mo; exposure to the modifier was randomized | Prognostic effect (dominant model for *2 allele) for MACE (defined as unstable angina, acute MI, ischemic stroke, or vascular death):; - among patients in the esomeprazole group: OR=4.23 (95% CI, 0.20 to 91.92); - among patients in the control group: OR=7.00 (95% CI, 0.35 to 141.00); Interaction p-value=0.82 [calculated results]
Hulot 2011 21972404 France CLOVIS-2 | Patients with MI before the age of 45, screened from the AFIJI multicenter registry. A total of 292 male patients were genotyped for CYP2C19*2. *2/*2 and *2/*1 patients were asked to participate in the trial. Age- and gender-matched CYP2C19 *1/*1 (noncarriers) from the AFIJI program were then recruited with a 1:1 ratio for each *2/*1 and a 2:1 ratio for each *2/*2 patient who was willing to participate. | Clopidogrel loading dose of 300 or 900 mg (crossover RCT). Clopidogrel maintenance treatment (75 mg) was continued for ≥21 days before patients were crossed over to the alternate loading dose group | Gene-gene interaction (CYP2C19 *2 carrier effect by PON1 variants; 2 variants were genotyped, Q192R and L55M) | The study reported that “no significant interactions between the tested CYP2C19 and PON1 genetic variants were observed” for pharmacodynamic endpoints. No additional results were reported.
Jaitner 2012 22298798 Germany NR | Patients undergoing PCI with stent placement and receiving dual antiplatelet therapy; 2 cohorts, a prospective PCI cohort and a registry of stent thrombosis cases were analyzed | Patients received clopidogrel (600 mg) and aspirin (500 mg) loading doses; post-PCI patients received clopidogrel (2 × 75 mg/d for the remainder of hospitalization, up to three days, followed by clopidogrel 75 mg/d for 6 to 12 mo) + aspirin (2 × 100 mg/d indefinitely) | Gene-gene interaction (CYP2C19 *2 carrier effect by ABCB1 3435TT genotype) | The p-value for interaction for the outcome of stent thrombosis was 0.51 in multivariate analyses that adjusted for multiple clinical and procedural factors. No additional results were reported.
Jeong 2011 22045970 S. Korea NR | Patients with AMI admitted to a single academic center who did not experience in-hospital death and did not need emergent bypass operation | Patients received loading with aspirin (300 mg) + clopidogrel (600 mg); maintenance therapy was with aspirin (200 mg/d for 1 mo, followed by 100-200 mg/d indefinitely) + clopidogrel (75 mg/d for ≥1 yr); patients on intensified antiplatelet therapy (cilostazol or high-dose clopidogrel) were excluded | MI subtype (STEMI vs. NSTE-MI) | Prognostic effect under dominant mode for the LOF alleles (*2 or *3) for MACE (defined as cardiovascular death, MI, or stroke): NSTE-MI, OR= 2.63 (95% CI, 0.29 to 24.25) STEMI, OR= 4.85 (95% CI, 0.58 to 40.53) Interaction p-value=0.697 [calculated results] Prognostic effect under dominant mode for LOF alleles (*2 or *3) for TIMI major or minor bleeding: NSTE-MI, OR=1.95 (95% CI, 0.20 to 19.26) STEMI, OR=0.64 (95% CI, 0.09 to 4.67) Interaction p-value=0.472 [calculated results]

* The description “calculated values” indicates that the results are based on statistical procedures we conducted in cases where studies provided sufficient statistics for the assessment of effect modification but did not assess its statistical significance.

Abbreviations: ACS = acute coronary syndromes; ADP = adenosine diphosphate; AU = aggregation units; AUC = area under the curve; BMI = body-mass index; BMS = bare-metal stent; CAD = coronary artery disease; CI = confidence interval; CURE = Clopidogrel in Unstable Angina to Prevent Recurrent Events trial; d = day(s); DES = drug-eluting stent; EXCELSIOR = Impact of Extent of Clopidogrel-Induced Platelet Inhibition During Elective Stent Implantation on Clinical Event Rate; FAST-MI = French Registry on Acute ST-elevation and non ST-elevation Myocardial Infarction; GOF = gain-of-function; GRACE = Global Registry of Acute Coronary Events; h = hours; LOF = loss-of-function; LTA = light-transmission aggregometry; MI = myocardial infarction; NA = not applicable; NR = not reported; NSTE = non–ST-elevation; OR = odds ratio; PCI = percutaneous coronary intervention; PPI = proton-pump inhibitor; PRI = platelet reactivity index; PRU = platelet reactivity units; SD = standard deviation; PUFA = polyunsaturated fatty acids; VASP = vasodilator-stimulated phosphoprotein; w = weeks.

“Calculated” indicates that the result was not reported by the article's authors; rather, we derived the result from reported raw data.

The 10 studies assessed a diverse set of potential modifiers. Five studied effect modification by proton-pump inhibitors122-124; three by ancestry (European vs. Latin American;109European vs. non-European; and European American vs. African American vs. other), five assessed gene–gene interactions (CYP2C19*2 and an ABCB1 variants;110 CYP2C19*2 and *3 variants;103 CYP2C19 *2 carrier status with PON1 variants in one; and multiple CYP2C19 variants and ITGB3 variants). The following modifiers were also evaluated: indication for clopidogrel use (acute coronary syndrome vs. stable angina),125 whether patients were clopidogrel pre-treated or naïve upon study entry, whether patients required a loading dose or not (because they were on chronic clopidogrel therapy),103 the duration of clopidogrel therapy,97 smoking status (number of cigarettes per day),126 body-mass index (≥25 kg/m^2^ vs. <25 kg/m^2^),123 and stent type (bare metal vs. drug eluting)111; myocardial infarction subtype (ST-elevation or non-ST-elevation); clinical presentation (comparing a cohort of patients with myocardial infarction, ischemic stroke, or peripheral arterial disease vs. asymptomatic patients at high-risk for atherothrombotic events); history of PCI (yes vs. not); interactions with a large set of clinical and procedural factors; administration of polyunsaturated fatty acids; whether patients were on calcium channel blockers or their combination with PPIs; (five studies assessed more than two potential effect modifiers103,123).

Only two of the effects assessed was statistically significant (a multiplicative interaction between the *2 and *3 CYP2C19 alleles on on-clopidogrel platelet reactivity103 and an interaction between symptomatic patients (CAPRIE-like cohort) and asymptomatic patients in the CHARISMA genetics substudy). Overall, the reported findings do not provide sufficient evidence to support (or exclude) a differential effect of CYP2C19 variants across any of the factors assessed in the studies we reviewed. The statistically significant findings are unlikely to indicate true effect medication, given the number of comparisons performed and potential for selective reporting across studies.

### Effect Modification Across Studies

On the basis of the availability of data from studies considered eligible for Key Question 1b, we assessed the following characteristics as potential modifiers of the predictive effect of genetic testing for CYP2C19 by performing comparisons across studies using subgroup analysis: disease subtype (acute coronary syndromes vs. mixed coronary artery disease populations), setting of care (PCI vs. other), race or ethnicity (white vs. East Asian), duration of followup (≤30 days vs. >30 days); and year when enrollment was started (continuous variable). Meta-regressions were performed for only the two outcomes that were reported in 10 or more studies—major adverse cardiovascular events and stent thrombosis—and for only carriers versus noncarriers of CYP2C19 loss-of-function alleles.

Table 6 summarizes the findings of our meta-regression analyses for the outcome of stent thrombosis and Table 7 summarizes findings for the composite endpoint of MACE.

Table 6 Meta-regression results for study-level effect modifiers of the predictive value of genetic testing for CYP2C19 variants in patients with ischemic heart disease: stent thrombosis

Effect Modifier | Groups Compared | No. of Studies | RR (95% CI) Within Subgroup | rRR (95% CI); P-Value
All studies | NA | 17 | 1.52 (1.17 to 1.97) | NA
ACS vs. ischemic heart disease | Other ischemic heart disease or mixed | 10 | 1.54 (1.07, 2.20) | 0.98 (0.58 to 1.65); 0.936
ACS vs. ischemic heart disease | ACS | 7 | 1.51 (1.03 to 2.19) | 0.98 (0.58 to 1.65); 0.936
Race or ethnicity | Whites | 14 | 1.44 (1.10 to 1.88) | 3.49 (1.00 to 12.19); 0.050
Race or ethnicity | East Asians | 3 | 5.02 (1.48 to 17.03) | 3.49 (1.00 to 12.19); 0.050
Followup | Longitudinal | 13 | 1.62 (1.15 to 2.27) | 0.86 (0.51 to 1.46); 0.579
Followup | Case–control or case-cohort | 4 | 1.39 (0.93 to 2.09) | 0.86 (0.51 to 1.46); 0.579
Duration of followup | >30 d | 12 | 1.41 (1.07 to 1.86) | 2.73 (0.39 to 19.19); 0.313
Duration of followup | ≤30 d | 1 | 3.86 (0.56 to 26.63) | 2.73 (0.39 to 19.19); 0.313
Enrollment start year | (continuous variable) | 14 | NA | 0.96 (0.87 to 1.06); 0.472

Abbreviations: ACS = acute coronary syndromes; CI = confidence interval; d = day(s); NA = not applicable; RR = relative risk; rRR = relative RR (between groups).

Results across all studies are provided for comparison. For stent thrombosis, all patients had to undergo percutaneous coronary intervention, so results by setting of care are not presented. One study did not report the year enrollment was started.

Table 7 Meta-regression results for study-level effect modifiers of the predictive value of genetic testing for CYP2C19 variants in patients with ischemic heart disease: MACE

Effect Modifier | Groups Compared | No. of Studies | RR (95% CI) Within Subgroup | rRR (95% CI); P-Value
All studies | NA | 25 | 1.20 (1.04 to 1.39) | NA
ACS vs. ischemic heart disease | Other ischemic heart disease or mixed | 13 | 1.44 (1.08 to 1.92) | 0.80 (0.58 to 1.10); 0.175
ACS vs. ischemic heart disease | ACS | 12 | 1.11 (0.95 to 1.30) | 0.80 (0.58 to 1.10); 0.175
PCI vs. other clinical settings | Other | 15 | 1.25 (1.03 to 1.52) | 0.91 (0.65 to 1.29); 0.599
PCI vs. other clinical settings | PCI | 10 | 1.13 (0.88 to 1.46) | 0.91 (0.65 to 1.29); 0.599
Race or ethnicity | Whites | 19 | 1.10 (0.97 to 1.24) | 1.96 (1.21 to 3.18); 0.006
Race or ethnicity | East Asians | 5 | 2.54 (1.45 to 4.44) | 1.96 (1.21 to 3.18); 0.006
Duration of follow-up | >30 d | 22 | 1.21 (1.03 to 1.41) | 0.93 (0.42 to 2.06); 0.859
Duration of follow-up | ≤30 d | 1 | 1.14 (0.60 to 2.17) | 0.93 (0.42 to 2.06); 0.859
Enrollment start year | (continuous variable) | 17 | NA | 1.06 (0.99, 1.13); 0.109

Abbreviations: ACS = acute coronary syndromes; CI = confidence interval; d = days; NA = not applicable; PCI = percutaneous coronary intervention; RR = relative risk; rRR = relative RR (between groups).

Results across all studies are provided for comparison. All eligible studies were longitudinal (cohort studies), so results by study design are not presented.

For all factors other than ethnicity, considering both within-study and across studies analyses, there is insufficient information to support or exclude the presence of substantial modification of the predictive effect of CYP2C19 variants by any of the investigated factors. Meta-regression analyses (both for stent thrombosis and MACE) suggested that the effect of LOF alleles may be more extreme among individuals of East Asian Ethnicity; however, this finding needs to be interpreted with caution given the relatively small number of publications reporting on individual of East Asian ethnicity and the potential for confounding by other factors that differ between studies conducted in populations of different ethnicities.

## Key Question 2a What is the analytic validity (technical test performance) of the various assays used in phenotypic testing of platelet reactivity?

### Eligible Studies for Key Question 2a

We identified 105 studies reporting information on the analytic validity of assays for measuring platelet reactivity; details about the design and results of individual studies are provided in Appendix E. We also reviewed 20 FDA 510(k) summaries on phenotypic testing assays (see Appendix C). Studies had intermediate sample sizes (median sample size=120; 25th percentile=93; 75th percentile=255) and were published between 2002 and 2012 (median publication year=2009). Seventeen studies (16 percent) were conducted in the United States, 58 (55 percent) in Europe, and 30 (29 percent) elsewhere. All studies enrolled patients with ischemic (atherothrombotic) vascular disease. The six most commonly assessed assays (with some studies assessing more than one) were LTA (in 71 studies; 68 percent), the VerifyNow P2Y12 assay (in 46 studies, 44 percent), the VASP assay (in 37 studies, 35 percent), the Multiplate analyzer (in 18 studies; 17 percent), the PFA device (in 10 studies; 10 percent), and thromboelastography (in 6 studies; 6 percent). The vast majority of studies used ADP as the agonist to stimulate platelets (in order to assess reactivity).

None of the 20 FDA 510(k) summaries on phenotypic tests of platelet reactivity reported relevant analyses (either no data were reported or the population or agonist used in test was not of interest, the analytic validity results were not reported for clopidogrel [rather, for a comedication], or the sample size was <10).

We organized studies reporting information relevant to analytic validity into four groups: analytic performance, interassay agreement, test reliability and assay variation, and correlations between assays applied to the same sample. No other aspect of analytic validity was evaluated in studies considered eligible for this review. Table 8 summarizes the information provided by each study type and the number of relevant publications included in our report. In subsequent sections we summarize key findings pertaining to each of these outcomes.

Table 8 Studies reporting information relevant to analytic validity

Analytic Validity Category | Relevant Information | Assays Evaluated (no. of studies; % of total studies)
Analytic performance (analytic accuracy, sensitivity, specificity) | These studies used a reference standard test against which the analytic performance of one or more index tests is assessed. In theory, the reference standard test can also be considered to have non-negligible measurement error (i.e., to be a “tarnished” reference standard); however, in all the studies we reviewed, the analytic reference standards were considered to be “gold standards” (i.e., to have no measurement error). | Total=12 studies LTA (9; 75%) VASP assay (4; 33%) VerifyNow P2Y12 (6; 50%) Multiplate analyzer (4; 33%) PFA (3; 25%) TEG (1; 8%) Plateletworks (0; 0%) Others (3; 25%)
Interassay agreement | These studies assessed the amount of agreement (concordance) between measurements of the same sample obtained with different assays. Agreement can be assessed between continuous measurements or using nominal or ordinal classifications (e.g., by discretizing continuous measurements by applying a threshold). | Total=40 studies LTA (31; 78%) VASP assay (16; 40%) VerifyNow P2Y12 (23; 58%) Multiplate analyzer (11; 28%) PFA (7; 18%) TEG (2; 5%) Plateletworks (2; 5%) Others (7; 18%)
Assay reliability (variability) | These studies assessed the reliability of assays during repeat testing and provided estimates of the variation of results when testing was repeated across different batches of analytes or portions of the same sample. The studies we reviewed typically expressed results as coefficients of variation.^*^ | Total=43 studies LTA (24; 56%) VASP assay (16; 37%) VerifyNow P2Y12 (12; 28%) Multiplate analyzer (5; 12%) PFA (6; 14%) TEG (1; 2%) Plateletworks (0; 0%) Others (6; 14%)
Correlation between measurements obtained by different assays | Many of these studies reported correlations (typically Spearman or Pearson) between measurements obtained from the same sample. (These correlations were reported to support claims regarding interassay agreement; we discuss in the text why some methods for calculating correlations are not appropriate for this purpose.) | Total=72 studies LTA (58; 81%) VASP assay (31; 43%) VerifyNow P2Y12 (36; 50%) Multiplate analyzer (16; 22%) PFA (6; 8%) TEG (5; 7%) Plateletworks (4; 6%) Others (18; 25%)

* The coefficient of variation is generally defined as the ratio of a measure of dispersion over a measure of central tendency. 127 The most commonly used definition is the ratio of the estimated standard deviation (SD) over the sample mean ( x¯ ) : CoV = (SD)/(x^π^) .

Abbreviations: LTA = light-transmission aggregometry; PFA = Platelet Function Analyzer; TEG = thromboelastography; VASP = vasodilator-stimulated phosphoprotein assay using flow cytometry. “Other” denotes less commonly assessed assay types. See Appendix E for a complete list of assays used in the included studies. Studies could have used more than one assay.

Overall there appeared to be low to moderate agreement between assays. Agreement was generally greater between measurements obtained with the same assay using different agonist concentrations than between different assays. Studies were generally of low methodological quality and poorly reported. Only 1 of the 11 items capturing risk of bias and completeness of reporting (“providing adequate details on the testing method” to allow for replication of test results) was satisfactorily addressed across studies. Detailed results regarding the quality items are presented at the end of this section.

Figure 19 presents an evidence map (a weighted scatter plot of tests and outcomes considered in the eligible studies) of studies assessing pairs of tests for analytic accuracy, agreement, or correlation (studies of these outcomes need to assess at least two tests). Only a minority of these studies reported information on analytic performance or test agreement, whereas a large number provided correlation results. Most of the studies reported test agreement or correlations between measurements obtained with different assays (e.g., LTA versus the VASP assay, VerifyNow, or the Multiplate analyzer); comparisons between measurements performed using the same assay with different agonist concentrations were also commonly reported.

Figure 19 Evidence map of studies reporting information on the analytic validity of phenotypic assays

Abbreviations: Acc = accuracy; LTA = light-transmission aggregometry; MPA = Multiplate analyzer; PFA = Platelet Function Analyzer; TEG = thromboelastography; VASP = vasodilator-stimulated phosphoprotein. “Other” denotes pairs of assays where at least one of the assays was used in fewer than five studies or comparisons between measurements obtained with the same assay (e.g., using different agonist concentrations). Each circle represents a study; the size of the circle increases with increasing sample size, and location of circles within boxes is random. The assays used are described in detail in Appendix E.

Figure 19 presents an evidence map (a weighted scatter plot of tests and outcomes considered in the eligible studies) of studies assessing pairs of tests for analytic accuracy, agreement, or correlation (studies of these outcomes need to assess at least two tests). The figure is described further in the section entitled “Eligible Studies for Key Question 2a” as follows: “Only a minority of these studies reported information on analytic performance or test agreement, whereas a large number provided correlation results. Most of the studies reported test agreement or correlations between measurements obtained with LTA versus the VASP assay, VerifyNow, or the Multiplate analyzer; comparisons between measurements performed using the same assay with different agonist concentrations were also commonly reported.”

### Findings on the Analytic Validity of Platelet Reactivity Assays

#### Analytic Performance

Only a small number of studies (n=12) provided information on analytic performance. In these studies, LTA (eight studies), the VASP assay (two studies), or the Multiplate analyzer (one study) was considered as “gold standard” tests. In one study the reference standard test was platelet-receptor expression after ADP stimulation, assessed by flow cytometry. Reported analytic sensitivities ranged between 0.35 and 1.00; reported specificities ranged between 0.42 and 0.95. In studies reporting results across multiple cutoff values, a tradeoff between sensitivity and specificity was apparent (as expected). Overall, results were indicative of poor agreement between classifications (e.g., “high reactivity” vs. “low reactivity”) obtained by the pairs of tests assessed when one of the tests was considered a gold standard. We did not perform meta-analyses of test performance metrics because only a few studies were available for each index test–reference standard pair and because studies used different thresholds to define positive and negative results. Detailed information on the populations included, assays used, analyses performed, and study results are presented in Appendix E.

#### Interassay Agreement

Forty studies provided information on interassay agreement. The most commonly assessed pairs of tests were LTA and VerifyNow (14 studies), LTA and the VASP assay (9 studies), and LTA and the Multiplate analyzer (7 studies). Information on the included populations, assays used, thresholds applied, and study results are presented in Appendix E.

Fourteen studies evaluated interassay agreement on the basis of continuous measurements by various assays (using valid methods, such as Bland–Altman analyses128 or Lin's concordance correlation coefficient129—i.e., major axis regression). Thirty-three of the studies reported agreement on the basis of dichotomizing platelet reactivity values using various thresholds; 29 of these reported or allowed for the calculation of kappa statistics (98 estimates in total). Across all comparisons reported, the median kappa value was 0.40 (25th percentile=0.23; 75th percentile=0.53). Only four (4 percent) of the reported kappa values were higher than 0.8 (a commonly used threshold for “excellent” agreement130), 15 (15 percent) of the values were between 0.6 and 0.8 (considered indicative of “substantial” agreement), 28 (29 percent) were between 0.4 and 0.6 (considered to indicate “moderate” agreement), and 51 (53 percent) were lower than 0.4 (indicating “poor to fair” agreement). Overall these results indicate that disagreements are relatively common between measurements obtained by different assays or by using different agonist concentrations within the same assays.

Figure 20 presents histograms of reported kappa values (chance corrected agreement statistics), suggesting that overall, agreement was somewhat lower between LTA and the VASP assay than between LTA and the VerifyNow P2Y12 assay. Quantitative synthesis of kappa statistics was not performed because only a few studies were available for each index test–reference standard pair and because studies used different thresholds to define positive and negative results.

Figure 20 Histograms of kappa values between methods for measurement of platelet reactivity

Abbreviations: LTA = light-transmission aggregometry; VASP = vasodilator-stimulated phosphoprotein.

“Frequency” refers to the number of studies. Black solid lines are kernel densities fitted over the distribution of kappa values. Each panel shows at least 10 reported kappa values.

Figure 20 presents histograms of reported kappa values (chance corrected agreement statistics), suggesting that overall, agreement was somewhat lower between light-transmission aggregometry (LTA) and the vasodilator-stimulated phosphoprotein (VASP) assay than between LTA and the VerifyNow P2Y12 assay.

#### Assay Reliability

Forty-three studies reported information on assay variability. The information reported about the experimental designs used to obtain the reported results was limited (e.g., >90 percent of the studies did not report the number of replicate samples). Variability or coefficient-of-variation results were less than 10 percent in all but two studies. One study used the intraclass correlation coefficient for repeat measurements to assess the reliability of measurements using LTA, the VASP assay, the Multiplate analyzer, and the INNOVANCE assay.

All extracted assay reliability results are presented in Appendix E. These results need to be interpreted with caution, give the poor reporting of study methods and the fact that multiple studies were published by a limited number of investigative teams (there was no way to ascertain whether the studied populations are the same or similar).

#### Correlation Between Measurements Used as a Method To Assess Agreement

Pearson or Spearman correlation coefficients are poor metrics for assessing agreement between measurements.^e^ Correlation values are informative only in extreme cases: for example, a Pearson correlation coefficient very close to 1 (or −1) indicates that the values of one assay can be linearly transformed to those of the other. More appropriate methods for assessing agreement between continuous measurements are available, such as the Bland–Altman approach128 and Lin's concordance correlation coefficient.129 Studies using the Bland–Altman method have been discussed above (see Interassay Agreement).

e Briefly, these coefficients are suboptimal for assessing agreement because: (1) correlations measure association and not agreement; (2) correlations are independent of scale of measurement, whereas agreement is not; (3) significant correlation results are likely when the range of measurements is wide, regardless of agreement; (4) the test for the null hypothesis of no correlation is irrelevant to the question of agreement; and (5) even high correlation values (>0.95) do not imply good agreement. For additional discussion, see Bland and Altman 1986^128^.

Of the 72 studies reporting correlation values, only one used Lin's concordance correlation coefficient,131 reporting a high correlation (ρ=0.97) between observed and estimated platelet inhibition for the VerifyNow assay (comparing the change between pre- and post-treatment measurements with the change between post-treatment measurements and those from the TRAP channel of the device). The vast majority of the remaining studies reported Spearman or Pearson correlation coefficients, used linear regression (which in the simple bivariate case of two measurements is equivalent to the Pearson correlation), or did not report the calculation method employed. Detailed results from each comparison reported in the reviewed studies are presented in Appendix E. Given that the majority of correlation estimates reported had an absolute value lower than 0.9 (90% percent of the 290 values reported) the results indicate that the association between measurements obtained using different methods is relatively poor. However, given the inappropriateness of the methods used (for the purpose of assessing agreement), even high correlation values would not be considered indicative of good agreement. Figure 21 presents histograms of reported correlation values.

Figure 21 Histogram of reported correlation values between methods for measurement of platelet reactivity

Abbreviations: LTA = light-transmission aggregometry; VASP = vasodilator-stimulated phosphoprotein.

“LTA-LTA” denotes comparisons between LTA assays using different agonists or different agonist concentrations. “Frequency” refers to the number of studies. Black solid lines are kernel densities fitted over the distribution of correlation values. Each panel shows at least 20 reported correlation values.

Figure 21 presents histograms of reported correlation values between methods for measurement of platelet reactivity. The majority of correlation estimates reported had an absolute value lower than 0.9 (90 percent of the 290 values reported).

### Risk of Bias and Completeness of Reporting for Studies Reviewed for Key Question 2a

Studies reporting on assay variability were extremely poorly reported (in all but three studies, no information was provided on the study design, selection criteria, or measurement methods used; in over 90 percent of the studies, the number of replicate samples used for analyses was not reported). Thus it was impossible to assess the risk of bias of these studies. In addition, as mentioned in the preceding section, correlation estimates are practically uninformative for assessing agreement between assays. For these reasons, we limited the assessment of study quality to the 43 studies that reported information on analytic test performance or interassay agreement.

Appendix D includes our assessment of 11 items related to risk of bias and completeness of reporting of studies presenting information on test agreement or analytic performance (including the single study reporting Lin's concordance correlation coefficient131 and studies using the Bland-Altman method). All but 1 of the 35 studies (a study published as a letter to the editor132) provided adequate descriptions of the assays used. Information on the use of positive or negative controls was poorly reported. About half the studies did not report the criteria for positive, negative, or indeterminate results; no study reported the limits of detection or assay linearity range. Only a minority of studies assessed reproducibility of results on repeat testing, and no study assessed reproducibility across operators, instruments, reagent lots, or over time. Only one study was conducted as part of a multilaboratory collaboration133; however, it did not provide details on the standardization procedures followed.

## Key Question 2b What is the clinical validity (predictive accuracy) of phenotypic testing for predicting intermediate and clinical outcomes in patients who are receiving clopidogrel therapy?

### Eligible Studies for Key Question 2b

The studies included in our review all involved administration of clopidogrel, although the populations varied in their indications for use of the drug. Of the 128 studies addressing Key Question 2b, the vast majority (122 studies) were of patients with ischemic heart disease; four studies enrolled patients with cerebrovascular disease, one study enrolled patients with peripheral artery disease; and one study enrolled a mix of patients with ischemic heart disease cerebrovascular disease and peripheral arterial disease. Among studies of patients with ischemic heart disease, 43 enrolled patients with acute coronary syndromes; the remaining either included patients with chronic stable coronary artery disease (71 studies) or mixed populations with chronic and acute presentations (8 studies). Of the 122 studies enrolling patients with ischemic heart disease, 113 (93 percent) included predominantly (>80 percent of the included population) patients undergoing PCI; 2 (2 percent), patients undergoing angiography; 5 (4 percent), patients undergoing a combination of PCI, CABG and medical treatments; and 2 (2 percent), patients being treated with medical therapy without undergoing a procedure. The majority of studies were of patients receiving dual antiplatelet therapy with clopidogrel in combination with aspirin; when loading doses were used, the aspirin loading dose ranged between 250 and 500 mg and the clopidogrel loading dose ranged between 300 mg and 900 mg. Maintenance doses were between 81 mg and 325 mg for aspirin and 75 mg and 150 mg for clopidogrel. Detailed information on the selection criteria, settings, and treatment strategies (including adjunctive treatments) is presented under subsequent sections addressing each test for platelet reactivity separately.

Overall, studies had intermediate to large sample sizes (median=205, 25^th^ percentile=97, 75th percentile=606, minimum=15, maximum=2849). They had been conducted in recent years (median year of enrollment start was 2006). In 120 studies providing relevant information the median of the mean or median age was 65 years (range 47 to 83 years). Patients had a relatively high burden of risk factors for coronary artery disease (which are associated with adverse cardiovascular outcomes): the median proportion of patients with dyslipidemia was 60 percent (in 98 studies; range 11 - 100 percent); with hypertension, 67 percent (in 108 studies; range 18 - 92 percent); with diabetes mellitus, 29 percent (in 113 studies; range 0 -100 percent); who used tobacco, 31 percent (in 108 studies; range 6 - 75 percent). All studies were longitudinal cohort studies (as per our inclusion criteria for this Key Question).

Studies reported information on a variety of tests for measuring platelet reactivity. The prognostic ability of a single platelet reactivity assay was evaluated in 107 of the 128 studies, whereas 21 studies evaluated two or more assays (15 studies evaluated two assays, 5 studies evaluated three assays, and 1 study evaluated four assays). The assays used included those based on the principle of LTA (55 studies; 43 percent), the VerifyNow P2Y12 assay (38 studies; 30 percent), the VASP assay (19 studies; 15 percent), the Multiplate analyzer assay (18 studies; 14 percent), the PFA-100 assay (11 studies; 9 percent), thromboelastography (6 studies; 5 percent), and other tests (9 studies; 7 percent). Detailed information on each test is presented separately under the discussion of individual tests for platelet reactivity.

Overall, studies were of moderate quality. Based on our assessment of 11 items derived from the QUADAS-2 instrument and using arbitrary thresholds based on the number of items considered as adequately addressed, 35 of the studies were rated “A,” 81 were rated “B,” and 12 were rated “C.” We caution that this aggregate risk-of-bias rating can be misleading, especially in the presence of poor reporting. A more detailed discussion of risk of bias, focusing on the individual items assessed, is presented later in this chapter.

In the following sections we discuss studies by outcomes reported, for each individual test, grouped by the patient populations enrolled. When study designs, assays, and outcome definitions were considered sufficiently similar across three or more studies, we performed meta-analyses to synthesize findings (using data from nonoverlapping populations). (Please see the Methods section for additional details on how we assessed potential population overlap.) Based on the results of our review on the analytic validity of assays for measuring platelet reactivity (presented under Key Question 2a of this report), we did not combine information across different assays or different agonist concentrations.

Results from subgroup and effect-modification analyses for studies relevant to Key Question 2b are presented under Key Question 2c. Table 9 summarizes information on the patient populations and outcomes assessed in the studies considered eligible for Key Question 2b.

Table 9 Populations and outcomes in studies for Key Question 2b, according to test used

Test Used (Total Number of Studies; Studies by Patient Population) | All-Cause Death | CV Death | ACS | ST | Stroke | Bleeding | MACE | Other Clinical Outcomes | Platelet Reactivity
LTA (total = 55; IHD = 53; PAD = 1; IHD, CVD, PAD = 1) | IHD = 13 [low] | IHD = 9 [low] | IHD = 18 [low] | IHD = 19 [low] | IHD = 12 [low] | IHD = 7 [insufficient] | IHD = 37 [low] IHD, CVD, PAD = 1 [insufficient] | IHD = 8 [insufficient] | IHD = 11 [insufficient] PAD = 1 [insufficient]
VerifyNow P2Y12 (total = 38; IHD = 35; CVD = 3) | IHD = 10 [low] | IHD = 7 [moderate] | IHD = 19 [low] | IHD = 15 [low] | IHD = 8 [insufficient] | IHD = 12 [low] | IHD = 24 [moderate] | IHD = 7 [insufficient] CVD = 3 [insufficient] | IHD = 4 [insufficient]
VASP (total = 19; IHD = 18; IHD, CVD, PAD = 1) | IHD = 4 [insufficient] | IHD = 6 [insufficient] | IHD = 6 [low] | IHD = 10 [low] | IHD = 1 [insufficient] | IHD = 1 [insufficient] | IHD = 8 [low] IHD, CVD, PAD = 1 [insufficient] | IHD = 4 [insufficient] | IHD = 7 [insufficient]
Multiplate analyzer (total = 18; IHD = 17; CVD = 1) | IHD = 6 [insufficient] | IHD = 5 [insufficient] | IHD = 9 [insufficient] | IHD = 10 [insufficient] | IHD = 3 [insufficient] | IHD = 9 [insufficient] | IHD = 13 [insufficient] CVD = 1 [insufficient] | IHD = 6 [insufficient] | IHD = 2 [insufficient]
TEG (total = 6; IHD = 6) | IHD = 2 [insufficient] | No studies | IHD = 2 [insufficient] | IHD = 1 [insufficient] | IHD = 1 [insufficient] | IHD = 3 [insufficient] | IHD = 4 [insufficient] | No studies | No studies
PFA-100 (total = 11; IHD = 10; IHD, CVD, PAD = 1) | IHD = 2 [insufficient] | IHD = 2 [insufficient] | IHD = 5 [insufficient] | IHD = 3 [insufficient] | IHD = 1 [insufficient] | IHD = 1 [insufficient] | IHD = 9 [low] IHD, CVD, PAD = 1 [insufficient] | IHD = 2 [insufficient] | IHD = 1 [insufficient]
Other (total = 9; IHD = 9) | IHD = 3 [insufficient] | No studies | IHD = 3 [insufficient] | IHD = 1 [insufficient] | IHD =1 [insufficient] | IHD = 2 [insufficient] | IHD = 6 [insufficient] | IHD = 3 [insufficient] | IHD = 3 [insufficient]

Abbreviations: ACS = acute coronary syndromes; CV = cardiovascular; CVD = cerebrovascular disease; IHD = ischemic heart disease, LTA = light-transmission aggregometry, MACE = major adverse cardiovascular events; PAD = peripheral arterial disease; PFA = Platelet Function Analyzer, ST = stent thrombosis, TEG = thromboelastography, VASP = vasodilator-stimulated phosphoprotein.

Numbers indicate the number of available studies for each test–outcome combination in the population specified. (Studies could have involved more than one combination.) The ratings in brackets reflect our assessment of the strength of evidence for each test–outcome association.

#### LTA

Fifty-five studies reported information on the predictive ability of platelet reactivity measured by LTA. Of these, 53 included patients with ischemic heart disease, one included patients with peripheral arterial disease, and one included a mix of patients with ischemic heart disease and peripheral artery disease. None of the studies included patients with cerebrovascular disease. Detailed information on selection criteria, settings, and treatment strategies (including adjunctive treatments) used in these studies is presented in Appendix E.

Overall, studies using LTA to measure platelet reactivity employed variable metrics, such as percent change of reactivity within a patient (termed “inhibition of platelet aggregation”) or absolute values of on-clopidogrel reactivity at a single timepoint (termed “residual platelet reactivity”). Furthermore, the cutoff values for defining increased reactivity varied across studies, even among studies using the same metric. We decided not to perform meta-analyses for studies assessing platelet reactivity using LTA because for all outcomes considered, the heterogeneity in metrics and cutoff values would result in the inclusion of only a select subset of studies for each comparison. Instead, we narratively summarized study results and performed qualitative synthesis for each reported outcome.

##### Ischemic Heart Disease

Fifty-three studies included patients with ischemic heart disease and reported information on the predictive value of platelet reactivity measured by LTA.134,135,95,111,117,136-182 Of these, 47 studies assessed the value of the test for predicting clinical outcomes; and 11, for predicting platelet reactivity during followup (4 studies reported both clinical and intermediate outcomes). Thirty-eight of the 53 studies enrolled patients with chronic stable coronary artery disease, 12 enrolled patients with acute coronary syndromes, and three studies enrolled mixed populations with chronic and acute presentations.

###### Clinical Outcomes

###### All-Cause Mortality

Thirteen studies reported information on the ability of platelet reactivity measured by LTA to predict all-cause mortality.111,137,140,141,143,150,156,160,163,165,180-182 Most studies used ADP as the agonist to assess reactivity. One study used ADP in combination with arachidonic acid (AA) to assess the response to both clopidogrel and aspirin.141 Thresholds for defining “positive” results were based on prior literature (or other sources external to the study) in 8 studies; derived from the observed study data in two studies; and not explicitly reported in three studies. Studies had variable sample sizes, ranging from 100 to 1058 enrolled patients. Of the 13 studies reporting relevant information on all-cause mortality, 10 did not report statistically significant results (6 studies reported higher rates of death in patients with higher reactivity and four did not report any deaths); additionally, three studies reported statistically significantly higher risk of deaths due to any cause in patients with high reactivity compared to those with low reactivity. In summary, reviewed studies suggested an association between increased platelet reactivity by LTA and all-cause mortality in patients with ischemic heart disease; however, results were inconclusive as heterogeneity between the studies prevents pooling of results.

###### Cardiovascular Mortality

Nine studies reported information on the ability of platelet reactivity measured by LTA to predict cardiovascular mortality.142,150,153,155,167,173,174,182,183 All studies used ADP as the agonist for measuring platelet reactivity. One study used ADP in combination with AA to assess the response to both clopidogrel and aspirin.155 Thresholds for defining “positive” results were based on prior literature (or other sources external to the study) in seven studies, derived from the observed study data in one study,142 and not explicitly reported in one study.153 Studies had variable sample sizes, ranging from 106 to 1058 patients. Of the nine studies reporting relevant information, five reported a statistically significantly higher risk of death among patients with high platelet reactivity and four found no significant association when comparing patients with high reactivity versus those with low reactivity. In summary, reviewed studies suggest an association between increased platelet reactivity by LTA and cardiovascular death in patients with ischemic heart disease; however, results were inconclusive, as heterogeneity between the studies prevented our pooling the results.

###### Acute Coronary Syndromes

Eighteen studies reported information on the ability of platelet reactivity measured by LTA to predict acute coronary syndromes.111,137,140-143,150,153,156,160,165,167,172-175,182,184 All studies used ADP as the agonist to assess platelet reactivity. One study used ADP in combination with AA to assess the response to both clopidogrel and aspirin.141 Thresholds for defining “positive” results were based on prior literature (or other sources external to the study) in 11 studies, derived from the observed study data in three studies, and were not explicitly reported in four studies. Studies had variable sample sizes, enrolling 26 to 1058 patients. Of the 18 studies reporting relevant information, ten reported statistically significant associations between increased reactivity and myocardial infarction and eight did not reach statistical significance. In summary, results were inconclusive regarding the association between increased platelet reactivity as measured by LTA and acute coronary syndrome risk in patients with ischemic heart disease.

###### Stent Thrombosis

Nineteen studies reported information on the ability of platelet reactivity measured by LTA to predict stent thrombosis.95,111,138,140-142,148,153-156,160,167,169,170,173,174,180,183 Three publications report data from the same population.95,154,155 The longest available followup was considered for these studies. All studies used ADP as the agonist; two studies used ADP in combination with AA to assess the response to both clopidogrel and aspirin.141,155 Thresholds for defining high platelet reactivity were based on prior literature (or other sources external to the study) in nine studies, were derived from the observed study data in four studies, and were not explicitly reported in six studies. The numbers of patients included in the studies ranged from 105 to 1058. Of the 16 studies reporting relevant information, 12 reported statistically significant associations between increased reactivity and stent thrombosis; 4 did not report statistically significant results; one did not report any stent thrombosis events. Taken together, studies suggested an association between increased platelet reactivity (as measured by LTA) and increased risk of stent thrombosis in patients with ischemic heart disease.

###### MACE

Thirty-seven studies reported information on the ability of platelet reactivity measured by LTA to predict composites of major adverse cardiovascular events for clopidogrel-treated patients with ischemic heart disease. Three studies reported data from the same population.95,154,155 The longest followup was considered for these studies. All studies used ADP as the agonist to measure platelet reactivity; two studies used ADP in combination with AA to assess the response to both clopidogrel and aspirin.141,155 Thresholds for defining “positive” results were based on prior literature (or other sources external to the study) in 17 studies, were derived from the observed study data in 13 studies, and were not explicitly reported in 7 studies. Studies had variable sample sizes, ranging from 90 to 1335 enrolled patients. Of the 33 studies reporting relevant information, 30 reported statistically significant associations between increased platelet reactivity and risk of MACE; only 3 did not find a statistically significant association. In summary, the majority of reviewed studies suggested an association between increased platelet reactivity by LTA and MACE in patients with ischemic heart disease.

###### Stroke

Twelve studies reported information on the ability of platelet reactivity measured by LTA to predict stroke.137,140,141,150,153,156,160,165,167,174,182,183 All studies used ADP as the agonist to measure reactivity. One study also used ADP in combination with AA to assess the response to both clopidogrel and aspirin.141 Thresholds for defining “positive” results were based on prior literature (or other sources external to the study) in nine studies, were derived from the observed study data in two studies, and were not explicitly reported in one study.153 Sample sizes ranged from 100 to 1058 patients. Of the 12 studies reporting relevant information on stroke, 10 did not report statistically significant results. One study reported that clopidogrel nonresponders had higher stroke risk than patients who were low responders or normal responders.167 One study reported a significantly higher stroke risk in patients who were either clopidogrel nonresponders or clopidogrel and aspirin nonresponders than responders to both drugs or to aspirin alone.141 In summary, reviewed studies did not suggest an association between increased platelet reactivity as measured by LTA and stroke in patients with ischemic heart disease; however, results were inconclusive, as heterogeneity in reactivity measurements prevented our conducting quantitative synthesis and study specific estimates had wide CIs, indicating considerable uncertainty.

###### Bleeding Events

Seven studies reported information on the ability of platelet reactivity measured by LTA to predict bleeding events.137,145,148,163,167,181,183 All studies used ADP as the agonist for measuring reactivity. Thresholds for defining “positive” results were based on prior literature (or other sources external to the study) in four studies and were not explicitly reported in two studies. Sample sizes ranged from 100 to 1058 patients. Of the seven studies reporting relevant information on bleeding events, five did not report statistically significant associations; one study did not report any events;181 one study reported significantly higher bleeding rate in “hyper-responders” (i.e., patients with ADP-induced aggregation <40%).148 In summary, the studies did not suggest an association between increased platelet reactivity as measured by LTA and bleeding events in patients with ischemic heart disease; however, results were considered inconclusive because of between-study heterogeneity in reactivity measurements that precluded quantitative synthesis.

###### Other Clinical Outcomes

Eight studies reported information on the ability of platelet reactivity measured by LTA to predict other clinical outcomes.111,137,143,156,160,167,173,181 Seven studies reported target-vessel revascularization as an outcome,111,137,143,156,160,173,181 two reported non–target-vessel revascularization as an outcome,137,160, one reported on recurrent ischemia,167 and two reported on rehospitalization for ischemia.137,160 All studies used ADP as the assay to measure platelet reactivity. Thresholds for defining “positive” results were based on prior literature (or other sources external to the study) in six studies, were derived from the observed study data in one study,160 and were not explicitly reported in one study.143 Sample sizes were variable, ranging from 96 to 802 patients. Of the seven studies reporting information on target-vessel revascularization, four did not report statistically significant associations; one study did not report any events;181 and, two reported significantly higher event rates of target-vessel revascularization among patients with increased platelet reactivity. Two studies on non–target-vessel revascularization and two studies on recurrent ischemia also reported significantly higher event rates among patients with increased platelet reactivity. In summary, reviewed studies did not provide sufficient evidence for an association between increased platelet reactivity as measured by LTA and target-vessel revascularization, non–target-vessel revascularization, or recurrent ischemia.

###### Intermediate Outcome: Platelet Reactivity During Followup

###### Reactivity as a Continuous Outcome

Eight studies134,136,144,167,168,171,176,177 reported on the predictive value of baseline on-clopidogrel platelet reactivity measured by LTA on platelet reactivity as a continuous outcome assessed during subsequent followup timepoints. In these studies reactivity was assessed using LTA in six studies (75 percent); the VASP assay in one (12.5 percent); and flow cytometry in one (12.5 percent).

Five of the studies enrolled patients with acute coronary syndromes,136,144,168,171,177 whereas three studies134,167,176 enrolled patients with chronic ischemic heart disease. Seven studies were conducted in the setting of interventional cardiac procedures (four with PCI and two with PCI with stenting); one study treated patients with medical therapy.

Studies generally showed that the mean or median reactivity was higher among clopidogrel-treated patients who were classified either as nonresponders or as slow responders at baseline, as compared to responders. Results were reported for different followup periods (ranging from a few hours post clopidogrel loading to a followup of 1 year) and measurements were obtained using different assays and different calculation methods (percent change within a patient or absolute value at last followup). All of the six studies reported that platelet reactivity during followup was statistically significantly higher among patients with high baseline reactivity compared to those with low or normal baseline reactivity. Because of the extensive between-study differences we did not perform meta-analyses for studies using reactivity as the outcome of interest.

###### Reactivity as a Categorical Outcome

Three studies157,162,164 reported information on the association between baseline reactivity measured by LTA and platelet reactivity during followup reported as a categorical outcome. In two studies reactivity (during followup) was assessed using LTA only157,164; in one study it was assessed using 3 different assays (LTA, VASP and VerifyNow P2Y12).162 Cutoff values for assessing reactivity were variable (among studies using the same assay). Two studies explicitly provided the rationale for selecting a specific cutoff.162,164 In both, the cutoff value was based on prior literature (i.e., information external to the dataset where the cutoff value was applied). All studies enrolled patients with chronic ischemic heart disease. Two studies were conducted in the setting of interventional cardiac procedures,162,164 whereas one included patients managed medically.157 One of the studies reported data in graphical form which was not amenable to quantitative analysis.164 When 20 μmol/L ADP was used as an agonist at baseline measurement, response status was not significantly associated with platelet reactivity after 30 days of followup (using LTA or VerifyNow). Increased baseline reactivity by LTA was significantly associated with platelet reactivity during followup measured by the VASP assay. When 5 μmol/L ADP was used as an agonist at baseline measurement, platelet reactivity by LTA was significantly associated with reactivity after 30 days of followup.

In summary, while studies suggested an association between increased platelet reactivity at baseline (measured by LTA) and subsequent platelet reactivity measurements (with different assays), the results are inconclusive due to sparseness of the data.

##### Patients With Peripheral Arterial Disease

###### Intermediate Outcome: Platelet Reactivity During Followup

###### Reactivity as a Categorical Outcome

One study185 reported on the effect using LTA on platelet reactivity as a categorical outcome for clopidogrel-treated patients with peripheral artery disease. In this study, both baseline and follow up measurements were performed with LTA. The cutoff value used to assess nonresponsiveness was based on prior literature (i.e., information external to the dataset where the cutoff value was applied). The study showed that baseline LTA reactivity was statistically significantly associated with the of responding patients after a median followup of 17.5 months.

##### Mixed Patient Population With Ischemic Heart Disease and Peripheral Arterial Disease

One study included a mix of patients with ischemic heart disease and peripheral arterial disease and reported information on the predictive value of platelet reactivity measured by LTA.186 The study recruited 534 patients with chronic stable coronary artery disease on clopidogrel and assessed the value of the test for predicting the first occurrence of MACE. The study also assessed the value of the VASP and PFA-100 test for predicting the first occurrence of the same outcome. The results from these tests are reported under the respective sections.

###### Clinical Outcomes

###### MACE

The study reported information on the ability of platelet reactivity measured by LTA to predict MACE (defined as acute myocardial infarction, unstable angina, hospitalization for revascularization, acute limb ischemia, ischemic stroke, transient ischemic attack, or cardiovascular death.186 The study reported results for LTA using two ADP concentrations (5 μmol/L and 20 μmol/L) with different cut-offs (>42 percent and >55 percent, respectively) to identify high reactivity. The thresholds for defining “positive” results were based on prior literature. Of the 771 enrolled patients, 534 were taking clopidogrel at the time of platelet testing. Increased reactivity did not adversely affect MACE-free survival (for ADP 5 μmol/L, HR=1.40; 95% CI=0.88, 2.23; p-value=0.16; for ADP 20 μmol/L ADP, HR=1.29; 95% CI=0.86, 1.94; p-value=0.22). In summary, the study did not suggest an association between increased platelet reactivity as measured by LTA and MACE in a mixed population of patients with ischemic heart disease and peripheral artery disease. This result is inconclusive because of the limited available data.

#### VerifyNow P2Y12

Thirty-eight studies reported information on the predictive ability of the VerifyNow P2Y12 assay. Of these, 35 studies included patients with ischemic heart disease and three studies included patients with cerebrovascular disease. None of the studies included patients with peripheral arterial disease or other populations receiving clopidogrel-based antiplatelet therapy. Detailed information on the selection criteria, settings, and treatment strategies (including adjunctive treatments) is presented in Appendix E.

##### Patients With Ischemic Heart Disease

Thirty-five studies included patients with ischemic heart disease and reported information on the predictive value of the VerifyNow P2Y12 assay (this assay uses ADP as the agonist to assess reactivity).88,140,141,180,183,187-216 Of these, 33 assessed the value of the test for predicting clinical outcomes and four for predicting platelet reactivity during followup (two studies reported both clinical and platelet reactivity outcomes). Of the 35 studies, 21 enrolled patients with chronic stable coronary artery disease, 12 enrolled patients with acute coronary syndromes, and two enrolled mixed populations with chronic and acute presentations.

###### Clinical Outcomes

###### All-Cause Mortality

Ten studies reported information on the ability of the VerifyNow P2Y12 assay to predict all-cause mortality for patients receiving clopidogrel-based treatment.88,140,141,180,187,203,209,211-213 One study used a combination of ADP and AA (in different assays) to define a population of combined clopidogrel and aspirin responders.141 Thresholds for defining “positive” results were based on prior literature (or other sources external to the study) in six of the studies and derived from the observed study data in two of the studies (two of the studies used both approaches). Studies were generally large; sample sizes ranged from 181 to 2849 patients. Seven of the 10 studies did not report a statistically significant association between platelet reactivity (measured by the VerifyNow assay) and all-cause mortality; two studies did not report any events; and, one study reported a significant association between platelet reactivity (measured by the VerifyNow assay) and all-cause mortality.

Figure 22 presents a meta-analysis of the five studies that used ADP as the agonist and defined high platelet reactivity based on platelet reactivity units. The summary RR was 1.21 (95% CI, 0.83 to 1.77); p=0.313, indicating no significant association between high platelet reactivity and all-cause mortality. There was little evidence of between study heterogeneity (P_Q_ = 0.902; I^2^ = 0 percent). The five studies not included in the meta-analysis did not report a significant association between higher platelet reactivity and increased all-cause mortality.

Figure 22 Meta-analysis of all-cause mortality comparing patients with high versus low reactivity measured using the VerifyNow P2Y12 assay

Abbreviations: CI = confidence interval; ROC curve = receiver-operating-characteristic curve analysis; RR = relative risk.

Cutoff values, expressed in platelet reactivity units, are shown for high (above the cutoff) and low (below the cutoff) reactivity; the source of the cutoff value is also shown. The solid squares (and horizontal lines) indicate the RR of all-cause mortality (and the corresponding 95% CI) for individual studies. The size of the squares is proportional to the weight of each study in the meta-analysis. The dashed vertical line represents the summary RR, with the open diamond showing the corresponding CI. The solid line indicates an RR of 1.

Figure 22 presents a meta-analysis of analysis of all-cause mortality comparing patients with high vs. low reactivity measured using the the VerifyNow P2Y12 assay. The summary RR was 1.21 (95% CI 0.83, 1.77); P=0.313, indicating no significant association between high platelet reactivity and all-cause mortality. There was little evidence of between study heterogeneity (PQ=0.902; I2=0 percent).

###### Cardiovascular Mortality

Seven studies reported information on the ability of the VerifyNow P2Y12 assay to predict cardiovascular mortality for patients receiving clopidogrel-based treatment.183,193,195,199,202,203,210 The assay uses ADP as the agonist to assess reactivity. Thresholds for defining “positive” results were based on prior literature (or other sources external to the study) in five of the 7 studies and derived from the observed study data in two of the studies. Studies had moderate to large sample sizes, ranging from 110 to 1691 included patients.

Figure 23 presents a meta-analysis of the four studies that used cutoff values based on platelet reactivity units (meta-analysis was not performed for three other studies using percent platelet inhibition to define reactivity and two of the studies using platelet reactivity units were considered to overlap). The summary RR was 2.50 (95% CI, 1.28 to 4.87); p=0.007, indicating a significant association between high platelet reactivity and cardiovascular mortality. There was little evidence of between study heterogeneity (P_Q_ = 0.527; I^2^ = 0 percent). The three studies not included in the meta-analysis did not report a significant association between higher platelet reactivity and increased cardiovascular mortality.

Figure 23 Meta-analysis of all-cause mortality comparing patients with high versus low reactivity measured using the VerifyNow P2Y12 assay

Abbreviations: CI = confidence interval; ROC curve = receiver-operating-characteristic curve analysis; RR = relative risk.

Cutoff values, expressed in platelet reactivity units, are shown for high (above the cutoff) and low (below the cutoff) reactivity; the source of the cutoff value is also shown. The solid squares (and horizontal lines) indicate the RR of cardiovascular mortality (and the corresponding 95% CI) for individual studies. The size of the squares is proportional to the weight of each study in the meta-analysis. The dashed vertical line represents the summary RR, with the open diamond showing the corresponding CI. The solid line indicates an RR of 1.

Figure 23 presents a meta-analysis of analysis of cardiovascular mortality comparing patients with high vs. low reactivity measured using the the VerifyNow P2Y12 assay. The summary RR was 2.50 (95% CI 1.28, 4.87); P=0.007, indicating a significant association between high platelet reactivity and cardiovascular mortality. There was little evidence of between study heterogeneity (PQ=0.527; I2=0 percent).

###### Acute Coronary Syndromes

Nineteen studies reported information on the ability of the VerifyNow P2Y12 assay to predict myocardial infarction189,194,196-198,206,209-213 or acute coronary syndromes over a longer followup140,141,183,187,193,199,202,203 for patients receiving clopidogrel-based treatment. One study used a combination of ADP and AA (in different assays) to define a population of combined clopidogrel and aspirin responders.141 Thresholds for defining “positive” results were based on prior literature (or other sources external to the study) in 10 studies; derived from the observed study data in 7 studies; and it was not explicitly reported in two studies. Studies were generally large; sample sizes ranged from 110 to 2849. Because of heterogeneity in the study populations, and the metrics and thresholds used to define increased platelet reactivity, we did not perform meta-analyses of predictive ability for this group of studies. Of the six studies reporting information on periprocedural myocardial infarctions, four studies reported a statistically significant association between higher reactivity levels and periprocedural events and two did not report statistically significant results. Of the eight studies reporting information on acute coronary syndromes during followup, four reported a statistically significant association between increased reactivity and risk of acute coronary syndromes, two did not report statistically significant results, and one reported that patients with low response to both aspirin and clopidogrel had significantly higher risks compared to patients with adequate response. Taken together, studies suggested an association between increased platelet reactivity by VerifyNow and both periprocedural and non-periprocedural acute coronary syndromes in patients with ischemic heart disease.

###### Stent Thrombosis

Fifteen studies reported information on the ability of the VerifyNow P2Y12 assay to predict stent thrombosis for patients receiving clopidogrel-based treatment.88,140,141,180,183,187,193,195,202,203,209-213 Thresholds for defining “positive” results were based on prior literature (or other sources external to the study) in 11 of the 15 studies and derived from the observed study data in four of the studies. Studies were generally large; sample sizes ranged from 110 to 2849. Of the 15 studies reporting relevant information, 11 did not report statistically significant results and produced relatively wide CIs, indicating substantial uncertainty around estimates of the RR; four studies reported statistically significant associations between high reactivity with risk of stent thrombosis. Because of heterogeneity in the metrics used to define platelet reactivity meta-analysis was possible only for six studies that use the same metrics and cut-offs for reactivity (Figure 24). The summary RR was 1.67 (95% CI, 0.80 to 3.47); p=0.172. There was some evidence of between study heterogeneity (P_Q_ = 0.159; I^2^ = 37 percent). Considering all studies, there was weak evidence to support an association between increased platelet reactivity by VerifyNow and stent thrombosis in patients with ischemic heart disease; more definitive results could not be reached because of heterogeneity in metrics used that precluded further synthesis of all studies.

Figure 24 Meta-analysis of stent thrombosis comparing patients with high versus low reactivity measured using the VerifyNow P2Y12 assay

Abbreviations: CI = confidence interval; ROC curve = receiver-operating-characteristic curve analysis; RR = relative risk.

Cutoff values, expressed in platelet reactivity units, are shown for high (above the cutoff) and low (below the cutoff) reactivity; the source of the cutoff value is also shown. The solid squares (and horizontal lines) indicate the RR of cardiovascular mortality (and the corresponding 95% CI) for individual studies. The size of the squares is proportional to the weight of each study in the meta-analysis. The dashed vertical line represents the summary RR, with the open diamond showing the corresponding CI. The solid line indicates an RR of 1.

Figure 24 presents a meta-analysis of analysis of stent thrombosis comparing patients with high vs. low reactivity measured using the the VerifyNow P2Y12 assay. The summary RR was 1.67 (95% CI 0.80, 3.47); P=0.172. There was some evidence of between study heterogeneity (PQ=0.159; I2=37 percent).

###### MACE

Twenty-four studies reported information regarding the ability of the VerifyNow P2Y12 assay to predict MACE for patients receiving clopidogrel-based treatment. One study used a combination of ADP and AA (different assays) to define a population of combined clopidogrel and aspirin responders141. Of the 23 remaining studies, 13 enrolled nonoverlapping patients populations and used cutoff values for platelet reactivity based on platelet reactivity units (the 10 studies not included in meta-analysis used other metrics to define platelet reactivity, had overlapping patient populations, or did not provide adequate data for inclusion). The summary RR was 2.48 (95% CI, 1.86 to 3.32); p<0.001 with evidence of moderate heterogeneity (P_Q_ = 0.045; I^2^ = 44 percent). Results from the meta-analysis are presented in Figure 25. Among the 10 studies not included in the meta-analysis, five used percentage of platelet inhibition to define platelet reactivity, two used substantially different cutoffs, two did not provide adequate data for inclusion, and one overlapped with another publication that had larger sample size. Among the five studies that used percentage of platelet inhibition to define platelet reactivity, four studies reported significantly higher rates of MACE at 6 months to a year in those with a low response to clopidogrel; one study reported lower rates of MACE at 30 days in those with a low response to clopidogrel.

Figure 25 Meta-analysis of major adverse cardiovascular events comparing patients with high versus low reactivity measured using the VerifyNow P2Y12 assay

Abbreviations: CI = confidence interval; MACE = major adverse cardiovascular events; NR = not reported; ROC curve = receiver-operating-characteristic curve analysis; RR = relative risk.

Cutoff values, expressed in platelet reactivity units, are shown for high (above the cutoff) and low (below the cutoff) reactivity; the source of the cutoff value is also shown. The solid squares (and horizontal lines) indicate the RR of major adverse cardiovascular events (and the corresponding 95% CI) for individual studies. The size of the squares is proportional to the weight of each study in the meta-analysis. The dashed vertical line represents the summary RR, with the open diamond showing the corresponding CI. The solid line indicates an RR of 1.

Figure 25 presents the results from the meta-analysis of major adverse cardiovascular events comparing patients with high vs. low reactivity measured using the VerifyNow P2Y12 assay. The summary RR was 2.48 (95% CI 1.86, 3.32); P<0.001 with evidence of moderate heterogeneity (PQ=0.045; I2=44 percent).

###### Stroke

Eight studies reported information on the ability of the VerifyNow P2Y12 assay to predict strokes for patients receiving clopidogrel-based treatment.140,141,183,187,193,211-213 One study used a combination of ADP and AA (different assays) to define a population of combined clopidogrel and aspirin responders.141 Thresholds for defining “positive” results were based on prior literature (or other sources external to the study) in six of the eight studies; and derived from the observed study data in two studies.140,212 Studies were generally large; sample sizes ranged from 110 to 1069. Because of heterogeneity in the metrics used to define platelet reactivity we did not perform meta-analyses of predictive ability for this group of studies. Seven studies using ADP as the agonist did not report statistically significant associations. The eighth study did not find a statistically significant difference in the risk of stroke between patients with low response to both aspirin and clopidogrel compared to patients with adequate response.

###### Bleeding Events

Thirteen studies reported information regarding the ability of the VerifyNow P2Y12 assay to predict bleeding events for patients receiving clopidogrel-based treatment. Of these, five studies reported results based on percent inhibition or used different cutoff values for reactivity; thus they were not considered adequately similar for meta-analysis. Of the remaining seven studies one reported that no events were observed (regardless of reactivity status), leaving six nonoverlapping studies for meta-analysis (four reported information on bleeding events regardless of severity and four reported information on major bleeding events).

Figure 26 presents meta-analysis results for all bleeding events combined. The summary RR was 1.09 (95% CI, 0.88 to 1.37); p=0.421, with little evidence for heterogeneity (P_Q_ = 0.738; I^2^ =0 percent). Figure 27 presents meta-analysis results for major bleeding events. The summary RR was 0.85 (95% CI, 0.32 to 2.25); p=0.738, with evidence of moderate heterogeneity (P_Q_ = 0.074; I^2^ = 57 percent).

Figure 26 Meta-analysis of bleeding events comparing patients with high versus low reactivity measured using the VerifyNow P2Y12 assay

Abbreviations: CI = confidence interval; ROC curve = receiver-operating-characteristic curve analysis; RR = relative risk.

Cutoff values, expressed in platelet reactivity units, are shown for high (above the cutoff) and low (below the cutoff) reactivity; the source of the cutoff value is also shown. The solid squares (and horizontal lines) indicate the RR of bleeding events (and the corresponding 95% CI) for individual studies. The size of the squares is proportional to the weight of each study in the meta-analysis. The dashed vertical line represents the summary RR, with the open diamond showing the corresponding CI. The solid line indicates an RR of 1.

Figure 26 presents meta-analysis results for all bleeding events combined comparing patients with high vs. low reactivity measured using the VerifyNow P2Y12 assay. The summary RR was 1.09 (95% CI 0.88, 1.37); P=0.421, with little evidence for heterogeneity (PQ=0.738; I2=0 percent).

Figure 27 Meta-analysis of major bleeding events comparing patients with high versus low reactivity measured using the VerifyNow P2Y12 assay

Abbreviations: CI = confidence interval; ROC curve = receiver-operating-characteristic curve analysis; RR = relative risk.

Cutoff values, expressed in platelet reactivity units, are shown for high (above the cutoff) and low (below the cutoff) reactivity; the source of the cutoff value is also shown. The solid squares (and horizontal lines) indicate the RR of major bleeding events (and the corresponding 95% CI) for individual studies. The size of the squares is proportional to the weight of each study in the meta-analysis. The dashed vertical line represents the summary RR, with the open diamond showing the corresponding CI. The solid line indicates an RR of 1.

Figure 27 presents meta-analysis results for major bleeding events comparing patients with high vs. low reactivity measured using the VerifyNow P2Y12 assay. The summary RR was 0.85 (95% CI 0.32, 2.25); P=0.738, with evidence of moderate heterogeneity (PQ=0.074; I2=57 percent).

###### Other Clinical Outcomes

Seven studies reported information on the ability of the VerifyNow P2Y12 assay to predict other clinical outcomes.193,199,201,209-212 Five studies reported information on target level revascularization,193,199,209-212 and two studies on a composite of PCI entry-site complications such as hematoma, pseudoaneurysm, arteriovenous fistula, and bleeding201 or hematoma >10 cms.209 Thresholds for defining “positive” results were derived from the observed study data in four of the studies and based on prior literature (or other sources external to the study) in four studies (one study used both approaches). The metrics used to define positive results were calculated differently across studies. Studies were generally large; sample sizes ranged from 110 to 2849. Because of heterogeneity in the outcomes and thresholds used, we did not perform meta-analyses of predictive ability for this group of studies. Two studies did not report any statistically significant associations; one study reported a statistically significant association between increased platelet reactivity and risk of PCI entry-site complications.

###### Intermediate Outcome: Platelet Reactivity During Followup

###### Reactivity as a Continuous Outcome

One study188 reported information on the predictive value of baseline platelet reactivity status (ascertained with the VerifyNow P2Y12) on platelet reactivity during followup measured as a continuous outcome. In this study, baseline reactivity was assessed using the VerifyNow assay. The study enrolled patients with acute coronary syndromes188 and was conducted in the setting of interventional cardiac procedures—a mix of PCI and PCI with stenting.188 The study reported that patients with poor response at baseline had significantly higher reactivity 1 month after PCI compared to those with adequate response.

###### Reactivity as a Categorical Outcome

Three studies88,191,215 reported information on the value of baseline platelet reactivity status (ascertained using VerifyNow P2Y12) for predicting platelet reactivity during followup as a categorical outcome. In both studies, baseline reactivity was assessed using the VerifyNow assay. Cutoff values and metrics for defining reactivity were variable; two studies study used absolute reactivity as the metric with a cutoff value derived from literature.88,215 The other study used the percent within-patient change to define reactivity.191 Two studies enrolled patients with chronic ischemic heart disease; one study enrolled patients with acute MI;215 and all were conducted in the setting of interventional cardiac procedures.

Results were reported for different followup periods (ranging from a 7 days to 6 months). Response status during followup in all studies was measured by the same assays that were used at baseline. One of the studies reported a 100 percent sensitivity of baseline response status in predicting status at 7 day status;191 two other studies reported a statistically significant difference in platelet reactivity during followup comparing nonresponders and responders at baseline.88,215

In summary, while suggested an association between platelet reactivity at baseline and measurement obtained during followup, results were inconclusive due to the small number of available studies.

##### Patients With Cerebrovascular Disease

Three studies217-219 included patients with cerebrovascular disease and reported information on the predictive value of the VerifyNow assay on clinical outcomes. No studies reported information on the predictive value of the VerifyNow assay on platelet reactivity during followup. All three studies were conducted in the setting of interventional procedures (stent implantation and coil embolization).

###### Clinical Outcomes

Studies reported information on the ability of the VerifyNow P2Y12 assay to predict only clinical outcomes for clopidogrel-treated patients with cerebrovascular disease. No studies reported information on the ability of the VerifyNow P2Y12 assay to predict platelet reactivity as a continuous or categorical outcome for clopidogrel-treated patients with cerebrovascular disease.

Three studies217-219 reported information on the ability of the VerifyNow P2Y12 assay to predict various clinical outcomes. One study reported outcomes such as intraprocedural thrombosis, thromboembolic event, good function score on modified Rankin Scale, good function Glasgow Outcome Score;219 another reported procedure-related thromboembolism and procedure-related aneurysm perforation218; the third study reported thromboembolic complications of the procedure.217 Thresholds for defining “positive” results were not explicitly reported in any of the studies. The metrics used to define positive results were calculated differently across studies. Studies were small; sample sizes ranged from 52 to 186. Because of heterogeneity in the thresholds used, we did not perform meta-analyses of predictive ability for this group of studies. The results from two studies indicated that increased reactivity was statistically significantly associated with increased event rates of the outcomes being studied; another study reported 75 percent sensitivity for clopidogrel resistance to predict thromboembolic events.

#### VASP Assay With Flow Cytometry

Nineteen studies reported information on the predictive ability of the VASP assay.82,138,149,180,186,220-233 Eighteen studies included patients with ischemic heart disease; and one included a mixed population of patients with ischemic heart disease and peripheral artery disease. Detailed information on the selection criteria, settings, and treatment strategies (including adjunctive treatments) is presented in Appendix E.

##### Patients With Ischemic Heart Disease

Eighteen studies included patients with ischemic heart disease and reported information on the predictive value of the VASP assay. Of these, 13 assessed the value of the test for predicting clinical outcomes and six for predicting platelet reactivity during followup (1 study reported both clinical and platelet reactivity outcomes). Of the 18 studies, eight enrolled patients with acute coronary syndromes, five enrolled patients with chronic stable coronary artery disease, and five enrolled mixed populations with chronic and acute presentations.

###### All-Cause Mortality

Four studies reported information on the ability of the VASP assay to predict all-cause mortality for patients receiving clopidogrel-based treatment.180,223,224,227 The assay uses ADP as the agonist to assess reactivity. Thresholds for defining “positive” results were based on prior literature (or other sources external to the study) in three of the studies;180,224,227 and derived from the observed study data in one study.223 Studies were generally large; sample sizes ranged from 200 to 460. Three studies reported statistically significant association of higher mortality with high platelet reactivity or low response to clopidogrel (however, we assumed that all of the studies enrolled overlapping patient populations on the basis of their population base and enrollment periods); one study reported no events.180 In summary, data suggested an association between increased platelet reactivity by VASP and all-cause mortality in patients with ischemic heart disease; however, results were inconclusive due to limited effective information size.

###### Cardiovascular Mortality

Six studies reported information on the ability of the VASP assay to predict all-cause mortality for patients receiving clopidogrel-based treatment. Two of the studies were conducted in overlapping patient populations (on the basis of study base and enrollment periods). Figure 28 presents a meta-analysis of the remaining four studies that used cutoff values based on platelet reactivity units (meta-analysis was not performed for the other two studies using percent platelet inhibition to define reactivity). The summary RR was 2.42 (95% CI, 0.86 to 6.82); p=0.095. There was little evidence of between study heterogeneity (P_Q_ = 0.616; I^2^ = 0 percent). Even though the test for heterogeneity was not statistically significant, studies produced point estimates that ranged from protective effects to very large increases in risk. Results were imprecise and confidence intervals could not exclude a clinically significant predictive effect.

Figure 28 Meta-analysis of cardiovascular mortality comparing patients with high versus low reactivity measured using the VASP assay with flow cytometry

Abbreviations: CI = confidence interval; CV = cardiovascular; ROC curve = receiver-operating-characteristic curve analysis; RR = relative risk; VASP = vasodilator-stimulated phosphoprotein.

Cutoff values, expressed in platelet reactivity units, are shown for high (above the cutoff) and low (below the cutoff) reactivity; the source of the cutoff value is also shown. The solid squares (and horizontal lines) indicate the RR of CV mortality (and the corresponding 95% CI) for individual studies. The size of the squares is proportional to the weight of each study in the meta-analysis. The dashed vertical line represents the summary RR, with the open diamond showing the corresponding CI. The solid line indicates an RR of 1.

Figure 28 presents a meta-analysis of cardiovascular mortality comparing patients with high vs. low reactivity measured using the VASP assay with flow cytometry. Data are shown for four studies that used cutoff values based on platelet reactivity units (meta-analysis was not performed for the other two studies using percent platelet inhibition to define reactivity). The summary RR was 2.09 (95% CI 0.74, 5.88); P=0.164. There was little evidence of between study heterogeneity (PQ=0.448; I2=0 percent).

###### Acute Coronary Syndromes

Six studies reported information on the ability of the VASP assay to predict acute coronary syndromes for patients receiving clopidogrel-based treatment. One study reported that no events occurred regardless of platelet reactivity status. Of the remaining five studies, three reported on overlapping populations (on the basis of study base and enrollment periods). Figure 29 presents a meta-analysis of the three studies (one study contributed separate estimates by diabetes status). The summary RR was 1.47 (95%, CI 0.77 to 2.79); p=0.246, indicating that the association between high platelet reactivity and acute coronary syndromes was not statistically significant. There was little evidence of between-study heterogeneity (P_Q_ = 0.372; I^2^= 0 percent).

Figure 29 Meta-analysis of acute coronary syndromes comparing patients with high versus low reactivity measured using the VASP assay with flow cytometry

Abbreviations: CI = confidence interval; ROC curve = receiver-operating-characteristic curve analysis; RR = relative risk, VASP = vasodilator-stimulated phosphoprotein.

Cutoff values, expressed in platelet reactivity units, are shown for high (above the cutoff) and low (below the cutoff) reactivity; the source of the cutoff value is also shown. The solid squares (and horizontal lines) indicate the RR of acute coronary syndromes (and the corresponding 95% CI) for individual studies. The size of the squares is proportional to the weight of each study in the meta-analysis. The dashed vertical line represents the summary RR, with the open diamond showing the corresponding CI. The solid line indicates an RR of 1.

Figure 29 presents a meta-analysis of acute coronary syndromes comparing patients with high vs. low reactivity measured using the VASP assay with flow cytometry. Data are shown for three studies (one study contributed separate estimates by diabetes status). The summary RR was 1.47 (95% CI 0.77, 2.79); P=0.246, indicating that the association between high platelet reactivity and acute coronary syndromes was not statistically significant. There was little evidence of between-study heterogeneity (PQ=0.372; I2=0 percent).

###### Stent Thrombosis

Ten studies provided information on stent thrombosis (definite or probable, when study definitions were available). Two studies reported that no events were observed (regardless of platelet reactivity status). Of the remaining eight studies, one reported test performance data; and, three studies enrolled overlapping populations (on the basis of study base and enrollment periods; we used data from the publication reporting the largest number of events). Figure 30 presents a meta-analysis of the four nonoverlapping studies. The summary RR was 3.37 (95% CI, 1.59 to 7.11); p=0.015, indicating a significant association between high platelet reactivity and stent thrombosis. There was little evidence of between-study heterogeneity (P_Q_ = 0.487; I^2^ = 0 percent).

Figure 30 Meta-analysis of stent thrombosis comparing patients with high versus low reactivity measured using the VASP assay with flow cytometry

Abbreviations: CI = confidence interval; ROC curve = receiver-operating-characteristic curve analysis; RR = relative risk, VASP = vasodilator-stimulated phosphoprotein.

The solid squares (and horizontal lines) indicate the RR of stent thrombosis (and the corresponding 95% CI) for individual studies. The size of the squares is proportional to the weight of each study in the meta-analysis. The dashed vertical line represents the summary RR, with the open diamond showing the corresponding CI. The solid line indicates an RR of 1.

Figure 30 presents a meta-analysis of stent thrombosis comparing patients with high vs. low reactivity measured using the VASP assay with flow cytometry. Data are shown for four nonoverlapping studies. The summary RR was 3.37 (95% CI 1.59, 7.11); P=0.015, indicating a significant association between high platelet reactivity and stent thrombosis. There was little evidence of between-study heterogeneity (PQ=0.487; I2=0 percent).

###### MACE

Eight studies reported information on the ability of the VASP assay to predict MACE for patients receiving clopidogrel-based treatment. One study reported test performance data; and, two studies reported on overlapping patient populations based on source population and enrollment periods (in meta-analyses we included the publication reporting on the largest total number of cardiovascular events). Figure 31 presents a meta-analysis of the six nonoverlapping studies (one study contributed separate estimates by diabetes status). The summary RR was 2.57 (95% CI, 1.21 to 5.47); p=0.015, indicating a significant association between high platelet reactivity and major adverse cardiovascular events. There was evidence of moderate between-study heterogeneity (P_Q_ = 0.044; I^2^ = 56 percent).

Figure 31 Meta-analysis of MACE comparing patients with high versus low reactivity measured using the VASP assay with flow cytometry

Abbreviations: CI = confidence interval; MACE = major adverse cardiovascular events; ROC curve = receiver-operating-characteristic curve analysis; RR = relative risk; VASP = vasodilator-stimulated phosphoprotein.

Cutoff values, expressed in platelet reactivity units, are shown for high (above the cutoff) and low (below the cutoff) reactivity; the source of the cutoff value is also shown. The solid squares (and horizontal lines) indicate the RR of major adverse cardiovascular events (and the corresponding 95% CI) for individual studies. The size of the squares is proportional to the weight of each study in the meta-analysis. The dashed vertical line represents the summary RR, with the open diamond showing the corresponding CI. The solid line indicates an RR of 1.

Figure 31 presents a meta-analysis of major adverse cardiovascular events comparing patients with high vs. low reactivity measured using the VASP assay with flow cytometry. Data are shown for six nonoverlapping studies (one study contributed separate estimates by diabetes status). The summary RR was 2.57 (95% CI 1.21, 5.47); P=0.015, indicating a significant association between high platelet reactivity and major adverse cardiovascular events. There was evidence of moderate between-study heterogeneity (PQ=0.044; I2=56 percent).

###### Stroke

One study reported information on the ability of the VASP assay to predict strokes for patients receiving clopidogrel-based treatment.229 The study used ADP as an agonist to assess reactivity and the thresholds for defining “positive” results were derived from both the observed study data and from literature. The study enrolled 54 patients with acute ST elevation myocardial infarction admitted for a coronary intervention with a followup time of 12 months. This suggests an association between increased platelet reactivity by the VASP assay and stroke, but the result is inconclusive owing to insufficient information.

###### Other Clinical Outcomes

Four studies reported information on the ability of the VASP assay to predict other clinical outcomes for patients receiving clopidogrel-based treatment.221,222,224,229 Target lesion revascularization was studied in three studies; other outcomes that were reported were the rates of followup interventions such as PCI and CABG surgery. All the studies used ADP as an agonist to assess reactivity. Thresholds for defining “positive” results were based on prior literature (or other sources external to the study) in two studies; they were not explicitly reported in one study; and they were derived from the observed study data and literature in the one study. Study sample sizes ranged from 54 to 436; followup time ranged from 6 to 12 months. Because of clinical heterogeneity across studies we did not perform meta-analyses of predictive ability. Of the three studies reporting information on target-vessel revascularization, two did not report statistically significant results and one study reported that no events occurred (regardless of reactivity status). The studies reporting on followup interventions documented statistically significantly increased rates of the intervention with increased reactivity.

###### Bleeding

One study reported information on the ability of the VASP assay to predict bleeding outcomes for patients receiving clopidogrel-based treatment.233 The study used ADP as an agonist to assess reactivity with the thresholds for defining “positive” results being based on prior literature (or other sources external to the study). No bleeding events were observed, regardless of platelet reactivity status.

###### Intermediate Outcome: Platelet Reactivity During Followup

###### Reactivity as a Continuous Outcome

Two studies226,232 reported information on the value of the VASP assay for predicting platelet reactivity during followup as a continuous outcome. In these two studies, reactivity at baseline was assessed using LTA with different concentrations of ADP as an agonist. Platelet reactivity was also assessed using P-selectin expression, platelet/monocyte conjugates, and platelet/neutrophil conjugates after ADP stimulation. The studies enrolled patients with acute coronary syndromes and was conducted in the setting of interventional cardiac procedures (PCI). The study showed that the patients with a poor response at baseline had significantly higher reactivity one month after PCI, compared to patients with adequate response at baseline, irrespective of the methods used to assess reactivity.

###### Reactivity as a Categorical Outcome

Five studies220,222,226,228,230 reported information on the value of the VASP assay for predicting platelet reactivity during followup as a continuous outcome. In these studies reactivity during followup was assessed using the VASP assay in four studies and by LTA in one study. Three of the five studies enrolled patients with acute coronary syndromes,220,222,228 whereas two studies226,230 enrolled patients with chronic ischemic heart disease. All five studies were conducted in the setting of interventional cardiac procedures—three, in patients with PCI226,228,230; one, in patients with PCI with stenting222; and one, in patients with coronary angiography.220

Of the four studies with available data, three studies showed that the VASP assay was not a significant predictor of future platelet reactivity.222,228,230 In one study, baseline reactivity measured with the VASP assay was significantly associated with response status at 1 month.226 One study did not allow for conclusions because none of the patients at baseline could be categorized as nonresponders.220

##### Mixed Patient Population With Ischemic Heart Disease and Peripheral Artery Disease

One study included a mixed population of patients with ischemic heart disease and peripheral arterial disease and reported information on the predictive value of platelet reactivity measured by VASP.186 The study recruited 534 chronic stable coronary artery disease patients treated with clopidogrel and assessed the value of the test for predicting the first occurrence of MACE. The study also assessed the value of the LTA and PFA-100 test for predicting the first occurrence of the same outcome. The results from these tests are reported under the respective sections.

###### Clinical Outcomes

###### MACE

One study reported information on the ability of platelet reactivity measured by VASP to predict MACE as defined by a composite of acute myocardial infarction, unstable angina, hospitalization for revascularization, acute limb ischemia, ischemic stroke, transient ischemic attack, or cardiovascular death.186 ADP was used as the agonist to assess reactivity, with a cutoff >50 percent to indicate high reactivity.

The thresholds for defining “positive” results were based on prior literature. Of the 771 enrolled patients, 534 were taking clopidogrel at the time of platelet testing. The test results did not impact on MACE-free survival and the multivariate Cox regression did not report a significant higher risk of MACE with reactivity as measured by the VASP assay (HR = 1.06; 95% CI=0.73 to1.53; p-value = 0.77). In summary, the study does not suggest an association between increased platelet reactivity by VASP and MACE in a mixed population of patients with ischemic heart disease and peripheral artery disease; however, results were inconclusive due to paucity of data.

#### Multiplate Analyzer

Eighteen studies reported information on the predictive ability of the Multiplate analyzer assay. Of these, 17 included patients with ischemic heart disease and one included patients with cerebrovascular disease. No study enrolled patients with peripheral arterial disease. Detailed information on the selection criteria, settings, and treatment strategies (including adjunctive treatments) is presented in Appendix E.

##### Patients With Ischemic Heart Disease

Seventeen studies included patients with ischemic heart disease and reported information on the predictive value of the Multiplate analyzer assay.82,194,215,225,230,231,234-244 Sixteen studies assessed the value of the test for predicting clinical outcomes and one for predicting platelet reactivity during followup. Ten of the 17 enrolled patients with chronic stable coronary artery disease; four studies enrolled patients with acute coronary syndrome; and the remaining included mixed populations with chronic coronary disease and acute coronary syndromes.

###### Clinical Outcomes

###### All-Cause Mortality

Six studies reported information on the ability of the Multiplate analyzer assay to predict all-cause mortality for patients receiving clopidogrel-based treatment.234,236,237,240,242,243 Three studies appear to have been based on the same patient populations, reporting results at 30 days,^237^6 months,240 and 1 year of followup.236 One study reported all cause death in two arms of the trial, where patients in each arm got different drugs (bivalirudin and abciximab) in addition to clopidogrel; these two arms are regarded as independent populations.242 All the studies used ADP as an agonist to assess reactivity. One study also used ADP in combination with AA to assess the response to both clopidogrel and aspirin.234 Thresholds for defining “positive” results were based on prior literature (or other sources external to the study) in the three studies of the same patient population236,237,240; they were derived from the observed study data and literature in the other three studies.234,242,243 The three studies of the same patient population enrolled 1608 patients; the sample size in the other three studies ranged from 219 to 290 patients. Followup durations were in hospital to 12 months. Because of the limited number of studies in nonoverlapping populations we did not perform meta-analyses of predictive ability. Of the three studies conducted in the same patients, the study with the longest followup did not find a statistically significant difference in the risk of all-cause mortality among patients with high platelet reactivity;236 one study with two independent trial arms242 and one study in ACS patients243 did not report a higher risk of all-cause mortality with higher reactivity. One study, reporting on groups stratified by a combination of high reactivity to both clopidogrel (using ADP as the agonist) and aspirin (using AA as the agonist), also did not report statistically significantly higher event rates in patient groups having high reactivity to clopidogrel only or to both clopidogrel and aspirin, as compared to the other groups.234 In summary, the reviewed studies do not suggest an association between increased platelet reactivity by the Multiplate analyzer assay and all-cause mortality in patients with ischemic heart disease; however, results were inconclusive due to the limited number of studies in nonoverlapping patient populations providing information.

###### Cardiovascular Mortality

Five studies reported information on the ability of the Multiplate analyzer assay to predict cardiovascular mortality for patients receiving clopidogrel-based treatment.82,225,235,236,240 Two studies reported information from the same patient population, with one reporting outcomes at 6 months of followup240 and the other at 1 year.236 All studies used ADP as the agonist to assess reactivity. One study also used ADP in combination with AA to evaluate both clopidogrel and aspirin.235 Thresholds for defining “positive” results were based on prior literature (or other sources external to the study) in four studies;82,225,236,240 they were not explicitly reported in the other study.235 Study sample sizes ranged from 182 to 1608; followup time ranged from 6 to 14 months. Because of limited number of studies reporting on nonoverlapping population and the diversity of metrics used to define high platelet reactivity we did not perform meta-analyses of predictive ability. Of the two studies reporting information on the same patient population, the study with the longest followup did not find a statistically significant effect of platelet reactivity on the odds of cardiovascular mortality.236 Two studies reported a significantly higher number of deaths in patients with high platelet reactivity.82,225 The study that assessed both clopidogrel and aspirin response status reported a lower risk of death among clopidogrel nonresponders than among responders to at least one of the drugs, but the difference was not statistically significant.235 In summary, reviewed studies do not provide sufficient evidence of an association between increased platelet reactivity by the Multiplate analyzer assay and cardiovascular mortality in patients with ischemic heart disease.

###### Acute Coronary Syndromes

Nine studies reported information on the ability of the Multiplate analyzer assay to predict myocardial infarction or other acute coronary syndromes for patients receiving clopidogrel-based treatment.194,225,234-237,240,242,243 Three studies reported information from the same patient population over different followup durations.236,237,240 One study reported MIs in two arms of the trial, where patients in each arm got different drugs (bivalirudin and abciximab) in addition to clopidogrel; these two arms are regarded as independent populations.242 All studies used ADP as the agonist to assess reactivity. Two studies used ADP in combination with AA to assess response to both clopidogrel and aspirin.234,235 Thresholds for defining “positive” results were based on prior literature (or other sources external to the study) in six studies,225,236,240,242,243 were not explicitly reported in one study,235 and in one study used both external sources and the observed study data.234 Sample sizes ranged from 182 to 1608; followup time ranged from 6 to 14 months. Because of the limited number of nonoverlapping studies using similar metrics and cutoff values to define high platelet reactivity, we did not perform meta-analyses of predictive ability. Of the six studies reporting information on acute coronary syndrome risk stratified by reactivity status (using ADP as the agonist), four did not report statistically significant results and two reported that the risk myocardial infarction was higher in the group with low reactivity. Additionally, both studies that evaluated combined response to clopidogrel and aspirin reported that the association between dual nonresponsiveness and myocardial infarction risk was not statistically significant.234,235} In summary, reviewed studies did not provide sufficient evidence of an association between increased platelet reactivity as measured by the Multiplate analyzer assay and myocardial infarction in patients with ischemic heart disease.

###### Stent Thrombosis

Ten studies reported information on the ability of the Multiplate analyzer assay to predict stent thrombosis for patients receiving clopidogrel-based treatment.82,231,234,236-240,242,243 Two sets of studies appear to each have been based on one population–with three studies reporting results for the same population at different time points236,237,240 and two other studies reporting on two different classifications of reactivity in another population.238,239 One study reported stent thrombosis in two arms of the trial, where patients in each arm got different drugs (bivalirudin and abciximab) in addition to clopidogrel; these two arms are regarded as independent populations.242

The results of the studies with the longest followup were considered. All the studies used ADP as an agonist to assess reactivity. One study used ADP in combination with AA to assess the response to both clopidogrel and aspirin.234 Thresholds for defining “positive” results were based on prior literature (or other sources external to the study) in seven studies82,231,236,240,242,243 and were derived from the observed study data in two studies238,239; one study used both approaches.234 Study sample sizes were variable, ranging from 30 to 2533 patients. Followup time was 1 day to 14 months. Because of the diversity of the metrics and cutoffs used to define high platelet reactivity, and substantial variability in followup durations, we did not perform meta-analyses of predictive ability.

In five of the seven studies, high on-clopidogrel platelet reactivity was significantly associated with a higher risk of stent thrombosis. In the study reported stent thrombosis in two arms of the trial, there was a significantly higher risk of stent thrombosis in both the arms, (bivalirudin and abciximab in addition to clopidogrel).242One study reported no events.243 Overall, the studies provided weak evidence of an association between increased platelet reactivity (as measured by the Multiplate analyzer) and stent thrombosis in patients with ischemic heart disease; however, given the substantial clinical heterogeneity, the results are inconclusive.

###### MACE

Thirteen studies reported information on the ability of the Multiplate analyzer assay to predict MACE for patients receiving clopidogrel-based treatment.82,194,225,234-242,244 Two sets of studies reported on overlapping patient populations: one set comprised three studies reporting results on the same population over different followup durations236,237,240; the second set comprised two studies employing two different classifications of reactivity on the same population.238,239 In both cases, we based our conclusions on the studies with the longest followup duration. One study reported stent thrombosis in two arms of the trial, where patients in each arm got different drugs (bivalirudin and abciximab) in addition to clopidogrel; these two arms are regarded as independent populations.242The definitions of composite outcomes were variable across studies. All studies used ADP as the agonist to assess reactivity. Three studies used ADP in combination with AA to assess response to both clopidogrel and aspirin.234,235,244 Thresholds for defining “positive” results were based on prior literature (or other sources external to the study) in six studies and not explicitly reported in two studies; they were derived from the observed study data and literature in six studies. Study sample sizes were variable, ranging from 106 to 2533 patients; followup durations ranged from 1 month to 14 months. Because of the diversity of the metrics and cutoff values used to define high platelet reactivity, and the substantial variability in followup durations, we did not perform meta-analyses of predictive ability for this group of studies.

Four studies reporting information on the predictive value of on-clopidogrel platelet reactivity (using ADP as the agonist) did not report statistically significant results; one study did reported no events. Among the three studies that evaluated a combination of clopidogrel and aspirin responders, both reported significantly higher rates of composite outcome events in patient groups with dual clopidogrel and aspirin nonresponse.234,235,244 In summary, there was insufficient evidence to support an association between increased platelet reactivity measured by the Multiplate analyzer assay and composite clinical outcomes in patients with ischemic heart disease; however, given the heterogeneity in the studies, the results were inconclusive.

###### Stroke

Three studies reported information on the ability of the Multiplate analyzer assay to predict strokes for patients receiving clopidogrel-based treatment.236,237,240 All three studies were based on the same patient population (1608 patients) and reported results over different followup durations. ADP was the agonist used to assess reactivity. Thresholds for defining “positive” results were based on prior literature (or other sources external to the study) in all studies. Followup duration ranged from 30 days to 12 months. The study reporting followup results at one year documented a statistically significant association between high platelet reactivity and ischemic stroke; the association was not statistically significant for hemorrhagic or overall stroke.236

###### Bleeding Events

Nine studies reported information on the ability of the Multiplate analyzer assay to predict bleeding events for patients receiving clopidogrel-based treatment.82,236-243 Two sets of studies reported on overlapping patient populations: one set comprised three studies reporting results on the same population over different followup durations236,237,240; the second set comprised two studies employing two different classifications of reactivity on the same population.238,239 In both cases we based our conclusions on the studies with the longest followup duration. One study reported stent thrombosis in two arms of the trial, where patients in each arm got different drugs (bivalirudin and abciximab) in addition to clopidogrel; these two arms are regarded as independent populations.242 ADP was used as the agonist to assess reactivity. Thresholds for defining “positive” results were based on prior literature (or other sources external to the study) in six studies; they were derived from the observed study data and literature in three studies. Study sample sizes ranged from 106 to 2533 patients. Followup duration ranged from 30 days to 1 year. Because of the limited number of studies on nonoverlapping patient populations and diversity of the metrics and cutoff values used to define high platelet reactivity, we did not perform meta-analyses of predictive ability. Two studies reported no bleeding events in the study. Three studies did not find a statistically significant association between platelet reactivity measured by the Multiplate analyzer and risk of bleeding; the abciximab arm of the trial242 and one other study reported that major bleeding risk was significantly higher in the group of patient with high on-clopidogrel reactivity.

###### Other Clinical Outcomes

Six studies reported information on the ability of the Multiplate analyzer assay to predict target lesion revascularization for patients receiving clopidogrel-based treatment235-237,240,242,243 Three of the four studies reported results based on the same patient population at different followup durations.236,237,240 We based our conclusions on the study with the longest followup duration. One study reported MIs in two arms of the trial, where patients in each arm got different drugs (bivalirudin and abciximab) in addition to clopidogrel; these two arms are regarded as independent populations.242 All studies used ADP as an agonist to assess reactivity. One study also used ADP in combination with AA to assess the response to both clopidogrel and aspirin.235 Thresholds for defining “positive” results were based on prior literature (or other sources external to the study) in five studies; they were not explicitly reported in one study. Study sample sizes ranged from 182 to 1608; followup time ranged from 1 to 14 months. Because of limited number of studies with nonoverlapping patient populations, we did not perform meta-analyses of predictive ability. One study reported no revascularization events in the study population.243 Two studies did not find a statistically significant association between increased platelet reactivity and target lesion revascularization (using ADP as the agonist).236,242 The study that assessed the impact of combined response to clopidogrel and aspirin on target lesion revascularization found a higher risk among patients exhibiting nonresponse (to both drugs).235

###### Intermediate Outcome: Platelet Reactivity During Followup

###### Reactivity as a Continuous Outcome

No studies reported information on the ability of the Multiplate analyzer assay to predict platelet reactivity as a continuous outcome for clopidogrel-treated patients with ischemic heart disease.

###### Reactivity as a Categorical Outcome

Two studies 215,230 reported on the effect of tests using the Multiplate analyzer assay on platelet reactivity as a categorical outcome. In this study, reactivity during followup was assessed using LTA with ADP as an agonist230 and the other study used the Multiplate analyzer assay to assess platelet reactivity.215 One study enrolled patients with chronic ischemic heart disease230 and one study enrolled patients who had an MI.215 Both studies were conducted in the setting of interventional cardiac procedures, specifically PCI. One study reported inadequate quantitative data to assess the predictive value of the Multiplate analyzer assay on platelet reactivity as a categorical outcome. One study reported a statistically significant difference in platelet reactivity during followup comparing nonresponders and responders at baseline.215

In summary, while suggestive of an association between platelet reactivity at baseline and measurement obtained during followup, results were inconclusive due to the small number of available studies.

##### Patients With Cerebrovascular Disease

One study reported information on the predictive value of the Multiplate analyzer assay for composite clinical outcomes among clopidogrel-treated patients with cerebrovascular disease.245 No studies reported on the test's ability to predict platelet reactivity.

###### MACE

The study reported information on the ability of the Multiplate analyzer assay to predict composite MACE (transient intra-interventional thrombosis, transient ischemic attack, or cerebral infarction for clopidogrel-treated patients with cerebrovascular disease).245 ADP was used as the agonist to assess reactivity. The rationale for selecting the threshold for defining a “positive” result was not explicitly reported in the study. This small study (n=50) reported that increased reactivity was statistically significantly associated with increased risk of the composite outcome.

#### Thromboelastography

Six studies reported information on the predictive ability of thromboelastography as an assay for measuring platelet reactivity. All five studies included patients with ischemic heart disease. No studies reporting information on this assay were conducted in other patient populations. Detailed information on the selection criteria, settings, and treatment strategies (including adjunctive treatments) is presented in Appendix E.

##### Patients With Ischemic Heart Disease

Six studies included patients with ischemic heart disease and reported information on the predictive value of thromboelastography.137,159,161,188,246,247 Five studies assessed the value of the test for predicting clinical outcomes (all-cause mortality, acute coronary syndromes, composite cardiovascular outcomes, and bleeding events); one study assessed the value of the test for predicting platelet reactivity during followup.247 Of the six studies, five enrolled patients with chronic stable coronary artery disease; the remaining study included patients with acute coronary syndromes.

###### Clinical Outcomes

###### All-Cause Mortality

Two studies reported on the predictive value of thromboelastography to predict all-cause mortality for patients receiving clopidogrel-based treatment.137,247 In one study, reactivity was assessed using ADP as agonist137 while the other study used ADP in combination with AA to assess the response to both clopidogrel and aspirin. Both studies enrolled patients with chronic stable coronary artery disease and was conducted in the setting of interventional cardiac procedures (PCI). One study reported that no deaths occurred (regardless of reactivity status) while the other study reported higher deaths in the group of people who exhibited higher reactivity to both clopidogrel and aspirin. There is insufficient information to assess the predictive ability of TEG for the outcome of all-cause mortality.

###### Acute Coronary Syndromes

Two studies reported on using thromboelastography to predict myocardial infarction for patients receiving clopidogrel-based therapy137,247 In one study reactivity was assessed using ADP as agonist;137 in the other study ADP was used in combination with in combination with AA to assess the response to both clopidogrel and aspirin. Both studies study enrolled patients with chronic stable coronary artery disease and was conducted in the setting of interventional cardiac procedures (PCI). Over a course of one year, both studies reported a higher risk of myocardial infarction among patients with high platelet reactivity; this difference was not statistically significant in one study137 but was statistically significant in the other. 247

###### Stent Thrombosis

One study reported information on using thromboelastography to predict stent thrombosis for patients receiving clopidogrel-based therapy137,247 The study used ADP in combination with AA to assess the response to both clopidogrel and aspirin. The study enrolled 60 patients with chronic stable coronary artery disease. Over a course of one year, the study reported a significantly higher rate of stent thrombosis among patients with high platelet reactivity. This suggests an association between increased platelet reactivity by the TEG assay and stent thrombosis, but the result is inconclusive owing to insufficient information.

###### MACE

Four studies reported information on the ability of thromboelastography to predict MACE in patients receiving clopidogrel-based treatment.137,159,161,188 Two of the studies reported information on the same patient population, with the one study reporting information after 6 months of followup159 and the other after 36 months of followup.161 We based our conclusions on the study with the longest followup. Definitions of composite clinical outcomes were different across studies. The studies conducted on the same population used thrombin and ADP as agonists159,161; the other two used ADP. Thresholds for defining “positive” results were based on prior literature (or other sources external to the study) in two studies and were derived from the observed study data in two studies. Study sample sizes ranged from 49 to 225 patients and followup time ranged from 6 months to 36 months. Because of the limited number of studies reporting on nonoverlapping patient population and the diversity of the cutoff values used to define high platelet reactivity, we did not perform meta-analyses of predictive ability. Two of the three studies reported that the risk of composite cardiovascular events was statistically significantly higher in groups identified as having high platelet reactivity when both ADP and thrombin were used as agonists.137,161 The third study also reported significantly higher event rates in groups having high reactivity (using ADP as the agonist).188 In summary, reviewed studies suggested an association between increased platelet reactivity by thromboelastography and composite adverse cardiovascular events in patients with ischemic heart disease; however, the evidence was limited by clinical heterogeneity across the few available studies.

###### Stroke

One study reported information on using thromboelastography to predict myocardial infarction for patients receiving clopidogrel-based therapy137,247 The study used ADP in combination with AA to assess the response to both clopidogrel and aspirin. The study enrolled 60 patients with chronic stable coronary artery disease. Over a course of one year, the study reported no events regardless of the platelet reactivity status. This suggests no association between increased platelet reactivity by the TEG assay and stent thrombosis, but the result is inconclusive owing to insufficient information.

###### Bleeding Events

Three studies reported on using thromboelastography to predict bleeding events for patients receiving clopidogrel-based treatment.137,246,247 In two studies, reactivity was assessed by thromboelastography using collagen and ADP as agonists137,246 while the other study used ADP in combination with AA to assess the response to both clopidogrel and aspirin.247 All studies enrolled patients with chronic stable coronary artery disease and were conducted in the setting of interventional cardiac procedures: PCI in one137 and CABG surgery in the other.246 One study assessed rates of intracranial hemorrhage in patients with high and low reactivity, and reported no events.247 One study assessed major and minor bleeding events;137 one study assessed post-operative transfusion requirement as an indicator for loss from bleeding.246 The postoperative transfusion requirement was significantly higher with increased platelet reactivity246; the bleeding events did not differ statistically significantly between groups in the other study.137 Overall, there was insufficient information to evaluate the predictive value of platelet reactivity as measured by thromboelastography and bleeding events in patients with ischemic heart disease.

#### PFA-100

Eleven studies reported information on the predictive ability of PFA-100 assay. Ten of the studies included patients with ischemic heart disease and one included a mix of patients with ischemic heart disease and peripheral artery disease. No relevant studies of this assay enrolled patients with cerebrovascular or peripheral arterial disease. Detailed information on the selection criteria, settings, and treatment strategies (including adjunctive treatments) is presented in Appendix E.

##### Patients With Ischemic Heart Disease

Ten studies included patients with ischemic heart disease and reported information on the predictive value of the PFA-100 assay.82,140,154,230,248-253 One also assessed a variation of the PFA-100 assay called the INNOVANCE PFA P2Y assay.140 Nine studies assessed the value of the test for predicting clinical outcomes and one for predicting platelet reactivity during followup. Of the ten studies, five enrolled patients with acute coronary syndromes248-251,253; the remaining five enrolled patients with chronic stable coronary artery disease.82,140,154,230,252

###### Clinical Outcomes

###### All-Cause Mortality

Two studies reported information on the ability of the PFA-100 and the INNOVANCE PFA P2Y assay to predict all-cause mortality for patients receiving clopidogrel-based treatment.140,249 One study evaluated both assays;140 the other study used only PFA-100.^249^ All assays used collagen and ADP as agonists to assess reactivity. Thresholds for defining “positive” results were based on prior literature (or other sources external to the study) in one study; they were derived from the observed study data in the other. Study sample sizes were 612 and 1069 patients. Because of the limited number of available studies, we did not perform meta-analyses of predictive ability for this group of studies. Both studies reporting information on reactivity as measured by PFA-100 did not report statistically significant associations between reactivity status and all-cause mortality;140,249 High on-treatment platelet reactivity as measured by INNOVANCE PFA P2Y assay was statistically significantly associated with risk of death.140 The reviewed studies did not suggest an association between increased platelet reactivity by PFA-100 assay and all-cause mortality; however, data were very limited. Similarly, the association between increased platelet reactivity measured by the INNOVANCE PFA P2Y assay and all-cause mortality was supported by only a single study.

###### Cardiovascular Mortality

Two studies reported information on the ability of the PFA-100 assay to predict cardiac mortality for patients receiving clopidogrel-based treatment.249,251 One study used two agonist combinations: collagen and epinephrine, and collagen and ADP to assess both aspirin and clopidogrel nonresponsiveness, respectively.251 The other study used collagen and ADP as agonists.249 Thresholds for defining “positive” results were based on prior literature (or other sources external to the study) in both studies. Study sample sizes were 125 and 612. Because of the limited number of available studies, we did not perform meta-analyses of predictive ability for this group of studies. One study reported that the risk of cardiac death was significantly higher among patients with high platelet reactivity while assessing clopidogrel responsiveness.249 The other study, which assessed combined aspirin and clopidogrel responsiveness, reported that the risk of cardiac death was statistically significantly higher among patients with dual nonresponsiveness.251 In summary, reviewed studies suggested an association between increased platelet reactivity by PFA-100 assay and cardiac mortality in patients with ischemic heart disease; however, results were inconclusive due to the limited number of publications and heterogeneity in the methods for reactivity assessment.

###### Acute Coronary Syndromes

Five studies reported information on the ability of the PFA-100 assay to predict acute coronary syndromes for patients receiving clopidogrel-based treatment.140,248,249,251,252 One study used a combination of collagen and epinephrine, and collagen and ADP, to assess both aspirin and clopidogrel nonresponsiveness, respectively.251 The other studies used collagen and ADP as agonists. Thresholds for defining “positive” results were based on prior literature (or other sources external to the study) in three studies; they were derived from the observed study data in one study; and not explicitly reported in one study. Study sample sizes ranged from 91 to 1069 patients. Because of the heterogeneity in the cutoff values used, we did not perform meta-analyses of predictive ability for this group of studies. Three studies did not report a statistically significant association between high reactivity as measured by PFA-100 and risk of myocardial infarction; the remaining two studies reported a statistically significantly higher risk of myocardial infarction among patients with high platelet reactivity. One study assessing high on-treatment platelet reactivity as measured by INNOVANCE PFA P2Y assay did find a statistically significant difference in the risk of myocardial infarction between groups.140 In summary, studies did not suggest an association between increased platelet reactivity as measured by PFA-100 assay and acute coronary syndromes outcomes in patients with ischemic heart disease; however, results were inconclusive due to heterogeneity in the methods used to assess reactivity that precluded quantitative synthesis.

###### Stent Thrombosis

Three studies reported information on the ability of the PFA-100 and the INNOVANCE PFA P2Y assays to predict stent thrombosis for patients receiving clopidogrel-based treatment.82,140,154 One study used measurements of platelet reactivity from both assays (used separately)140; one study used a combination of collagen and epinephrine, and collagen and ADP, to assess aspirin and clopidogrel nonresponsiveness, respectively;154 the other study used ADP to assess clopidogrel responsiveness.82 Thresholds for defining “positive” results were based on prior literature (or other sources external to the study) in two studies; they were derived from the observed study data in the other. Study sample sizes ranged from 402to 1069 patients. Because of the limited number of available studies, we did not perform meta-analyses of predictive ability. One study reported 100 percent sensitivity of PFA-100 assay to predict stent thrombosis;154 one study reported a sensitivity of 0.7 to predict stent thrombosis;82 the other study did not report a statistically significant association between platelet reactivity and stent thrombosis.140The association between high on-treatment platelet reactivity as measured by the INNOVANCE PFA P2Y assay with stent thrombosis was not statistically significant.140 In summary, reviewed studies did not provide adequate evidence to support the association between increased platelet reactivity as measured by PFA-100 assay and stent thrombosis in patients with ischemic heart disease.

###### MACE

Nine studies reported information on the ability of the PFA-100 and the INNOVANCE PFA P2Y assays to predict MACE in patients receiving clopidogrel-based treatment.82,140,154,248-253 Only one study used measurements of platelet reactivity from both assays (used separately)140; the other studies used combinations of collagen and epinephrine and collagen and ADP to assess platelet reactivity. Thresholds for defining “positive” results were based on prior literature (or other sources external to the study) in four studies and were derived from the observed study data in three studies; one study used both approaches; and one did not explicitly report the rationale for selecting a cutoff value. Study sample sizes ranged between 71 and 1069 patients. Because of the limited number of available studies and heterogeneity in the methods used to define high platelet reactivity, we did not perform meta-analyses of predictive ability.

Seven of the nine studies using the PFA-100 assay reported statistically significant associations between increased platelet reactivity and increased risk of composite outcome events; the remaining two studies did not report statistically significant associations but produced effect sizes in the same direction (i.e., indicating an association between increased reactivity and higher risk of events). The association between high on-treatment platelet reactivity as measured by the INNOVANCE PFA P2Y assay with stent thrombosis was statistically significant indicating increased risk among patients with high on-clopidogrel reactivity.140 In summary, the reviewed studies supported an association between increased platelet reactivity as measured by the PFA-100 assay and composite outcome events among patients with ischemic heart disease; however, the strength of these findings was limited by heterogeneity in definitions of increased reactivity that precluded quantitative synthesis.

###### Stroke

One study reported information on the ability of the PFA-100 assay to predict strokes for patients receiving clopidogrel-based treatment.140 The study used collagen and ADP as an agonist. Thresholds for defining “positive” results were derived from the observed study data. The study enrolled 1069 patients who were undergoing PCI with stent implantation. This study did not report a statistically significant association between high reactivity as measured by PFA-100 and stroke at one year of followup. The result did not suggest an association between increased platelet reactivity by PFA-100 assay and stroke; however, results were inconclusive due to paucity of relevant information.

###### Bleeding Events

One study reported on the ability of the PFA-100 assay to predict bleeding events for patients receiving clopidogrel-based treatment.248 In this study, reactivity was assessed using collagen and ADP as agonists. The study enrolled patients with acute coronary syndromes and was conducted in the setting of interventional cardiac procedures (PCI). The study reported that no bleeding events occurred (regardless of reactivity status).

###### Other Clinical Outcomes

Two studies reported information on the ability of the PFA-100 assay to predict miscellaneous clinical outcomes for patients receiving clopidogrel-based treatment.248,251 The outcomes included: recurrent angina, arrhythmia, pulmonary edema, cardiogenic shock,248 and rehospitalization for congestive heart failure.251 One study used ADP and collagen as the agonist to assess reactivity248; the other used a combination of collagen and epinephrine, and collagen and ADP to assess both aspirin and clopidogrel nonresponsiveness.251 The studies generally showed that higher reactivity was associated with higher risk of outcome events; however, the strength of evidence was limited by the small number of available studies and the heterogeneity in reactivity measurement methods.

###### Intermediate Outcome: Platelet Reactivity During Followup

###### Reactivity as a Continuous Outcome

No studies reported information on the ability of the PFA-100 assay to predict platelet reactivity as a continuous outcome among clopidogrel-treated patients with ischemic heart disease.

###### Reactivity as a Categorical Outcome

One study230 reported on ability of the PFA-100 assay to predict platelet reactivity as a categorical outcome. In this study, reactivity at baseline was assessed using collagen and ADP as agonists. The study enrolled patients with chronic ischemic heart disease and was conducted in the setting of interventional cardiac procedures (PCI). Reactivity status, as measured by the PFA-100 assay at baseline, was not statistically significantly associated with response status during followup.

#### Mixed Patient Population With Ischemic Heart Disease and Peripheral Artery Disease

One study included a mixed population of patients with ischemic heart disease and peripheral artery disease and reported information on the predictive value of platelet reactivity measured by PFA-100.^186^ The study recruited 534 chronic stable coronary artery disease patients treated with clopidogrel and assessed the value of the test for predicting the first occurrence of MACE. The study also assessed the value of the LTA and VASP test for predicting the first occurrence of the same outcome. The results from these tests are reported under the respective sections.

##### Clinical Outcomes

###### MACE

One study reported information on the ability of platelet reactivity measured by PFA-100 to predict MACE (defined as acute myocardial infarction, unstable angina, hospitalization for revascularization, acute limb ischemia, ischemic stroke, transient ischemic attack, or cardiovascular death).186 ADP was used as the agonist to assess reactivity, with a cutoff <190s of closing time to indicate high reactivity.

The thresholds for defining “positive” results were based on prior literature. Of the 771 enrolled patients, 534 were taking clopidogrel at the time of platelet testing. The test results did not impact on MACE-free survival and the multivariate Cox regression did not report a significant higher risk of MACE with reactivity measured by the PFA-100 assay (HR = 0.82; 95% CI = 0.57,1.19; p=0.30). In summary, the study does not suggest an association between increased platelet reactivity by PFA-100 and MACE in a mixed population of patients with ischemic heart disease and peripheral artery disease; however, results were inconclusive due to paucity of data.

#### Other Tests for Measuring Platelet Reactivity

Nine studies evaluated the predictive value of platelet reactivity by a diverse group of tests: one study used iron as an agonist250; two studies used the Plateletworks assay to measure reactivity254,255; one study used two separate assays (the Ichor Plateletworks and the Impact-R assay with ADP)140; one study only the Ichor Platelet works assay;256 two studies used flow cytometry to assess ADP-stimulated P-selectin expression157,179; one study used a the results of two assays assessed jointly (LTA and the VerifyNow assay) to define platelet response183; and one study used a combination of three assays (conventional LTA, thromboelastography and Plateletworks assay).257 All nine studies included patients with ischemic heart disease. None were conducted on other patient populations. Detailed information on the selection criteria, settings, and treatment strategies (including adjunctive treatments) is presented in Appendix E.

##### Patients With Ischemic Heart Disease

All nine studies using diverse tests for reactivity included patients with ischemic heart disease. Five of the seven studies assessed the value of the test for predicting clinical outcomes, and two for predicting platelet reactivity during followup. Four enrolled patients with acute coronary syndromes250,254-256; four included patients with chronic stable coronary artery disease140,157,179,257; and one enrolled mixed populations with chronic and acute presentations.183

###### Clinical Outcomes

###### All-Cause Mortality

Three studies reported information on all-cause mortality. One study used measurements of platelet reactivity from two assays—the Ichor Plateletworks and the Impact-R assay;140; one study used measure of reactivity by only the Plateletworks assay.254 One study used the Ichor Plateletworks assay to predict clinical outcomes in two arms of the trial, where patients in each arm got different drugs (tirofiban and abciximab) in addition to clopidogrel; these two arms are regarded as independent populations.256In all cases ADP was the agonist used to assess reactivity. Thresholds for defining “positive” results were based on prior literature (or other sources external to the study) in one study; they were derived from the observed study data in the other. Study sample sizes were 31 and 1069 patients. Because of limited number of available studies we did not perform meta-analyses of predictive ability. Of the three studies reporting relevant information on reactivity as measured by Plateletworks, one did not report a statistically significant association between platelet reactivity status and risk of death.140 The second study reported that no deaths occurred, regardless of reactivity.254 The third study did not report any events in the tirofiban and abciximab arms of the study.256 The result did not suggest an association between increased platelet reactivity by the PlateletWorks assay and death. Platelet reactivity as measured by the Impact R assay was also not statistically significantly associated with risk of death.140

###### Acute Coronary Syndromes

Three studies reported information on acute coronary syndromes among patients receiving clopidogrel-based treatment. One study used the measure of platelet reactivity from two assays—the Ichor Plateletworks and the Impact-R assay140; one study used measure of reactivity by only the Plateletworks assay.254 One study used the Ichor Plateletworks assay to predict clinical outcomes in two arms of the trial, where patients in each arm got different drugs (tirofiban and abciximab) in addition to clopidogrel; these two arms are regarded as independent populations.256In all cases ADP was the agonist used to assess reactivity. Thresholds for defining “positive” results were based on prior literature (or other sources external to the study) in one study; they were derived from the observed study data in one study. Study sample sizes were 31 and 1069 patients. Because of the limited number of available studies we did not perform meta-analyses. Of the three studies reporting information on reactivity as measured by the Plateletworks assay, two reported that not myocardial infarctions occurred, regardless of reactivity.254,256 The other study reported that the risk of myocardial infarction was significantly higher among patients with high on-treatment platelet reactivity.140 The result did not suggest an association between increased platelet reactivity by the PlateletWorks assay and myocardial infarction. Platelet reactivity as measured by Impact R ADP was not statistically significantly associated with myocardial infarction at 1 year.140

###### Stent Thrombosis

One study including 1069 patients reported information on stent thrombosis. The study used measurements of platelet reactivity from two assays—the Ichor Plateletworks and the Impact-R assay.140 Both the assays used ADP as the agonist to assess reactivity. The threshold for defining “positive” results was derived from the observed study data. The study reported that the high platelet reactivity as measured by either Plateletworks or Impact R was not statistically significantly associated with stent thrombosis.

###### MACE

Six studies reported information on composite MACE (of varying definitions). One study used iron as an agonist in LTA and also used the Plateletworks assay250; one measured platelet reactivity using two assays—the Ichor Plateletworks and the Impact-R140; one study only the Ichor Platelet works assay;256 one study used flow cytometry to assess ADP-stimulated P-selectin expression;179one study used a the joint results of two assays, conventional LTA and VerifyNow, to define platelet response; and one study used a combination of three assays—conventional LTA, thromboelastography, and Plateletworks—to categorize response to clopidogrel. Apart from the study using iron as an agonist, the other three studies used ADP as the agonist to assess reactivity. Thresholds for defining “positive” results were based on prior literature (or other sources external to the study) in one study, were derived from the observed study data in two study, and were not explicitly reported in three studies. Study sample sizes ranged from 30 to 1069 patients and followup durations ranged from 1 month to a year. Because of limited number of studies evaluating each test, we did not perform meta-analyses of predictive ability for this group of studies. Of the three studies reporting information on the predictive value of reactivity as measured by Plateletworks, one did not report any events regardless of the reactivity status;256 one did not report a statistically significant difference between reactivity groups;250 and one reported significantly higher risk the composite cardiovascular event among patients with high on-treatment platelet reactivity.140 Platelet reactivity as measured by the Impact R assay was not statistically significant associated with outcome events.140 Increased reactivity based on combined assay results (LTA and VerifyNow or LTA, thromboelastography, and PlateletWorks) was not significantly associate with increased event rates.

###### Stroke

One study reported information on the ability of Plateletworks and the Impact-R assay to predict strokes for patients receiving clopidogrel-based treatment. All the assays used ADP as the agonist to assess reactivity. Thresholds for defining “positive” results were derived from the observed study data in one study. The study enrolled 1069 patients undergoing PCI with stent implantation. This study did not find a statistically significant association between high reactivity as measured by either the Impact R or Plateletworks assay with stroke at 1 year of followup.

###### Bleeding Events

Two studies reported information on bleeding events for patients receiving clopidogrel-based treatment. One study used measurements of reactivity by the Plateletworks assay254 and the other used two assays jointly—conventional LTA and VerifyNow assay—to assess platelet reactivity.183 In all cases ADP was used as the agonist to assess reactivity. One study reported information on hematoma development as an outcome254 while the other reported bleeding events. 183 Neither platelet reactivity as measured by the Plateletworks assay nor combined assessment with LTA and VerifyNow were statistically significantly associated with hematomas or bleeding events, respectively.

###### Other Clinical Outcomes

Three studies reported information on the ability of the different platelet function tests to predict bleeding events for patients receiving clopidogrel-based treatment. Two study used measurements of reactivity by the Plateletworks assay254,256 and one used a combination of three assays—conventional LTA, thromboelastography, and Plateletworks assay—to categorize response to clopidogrel.257 In all cases ADP was used as the agonist to assess reactivity. One study reported angina recurrence as an outcome254; one study reported rehospitalization rates for ischemia; one study reported rates of followup intervention, both PCI and CABG surgery.257 Platelet reactivity measured with the Plateletworks assay and combined assessment with LTA, thromboelastography, and Plateletworks assays were not statistically significantly associated with the outcomes assessed.

###### Intermediate Outcome: Platelet Reactivity During Followup

###### Reactivity as a Continuous Outcome

No studies reported information on the ability of other tests of platelet reactivity to predict platelet reactivity as a continuous outcome for clopidogrel-treated patients with ischemic heart disease.

###### Reactivity as a Categorical Outcome

Three studies evaluated the predictive value of baseline platelet reactivity on platelet reactivity as a continuous outcome.157,254,255 Two studies used the Plateletworks assay254,255 and one study used flow cytometry to assess P-selectin expression.157 Two of the three studies enrolled patients with acute coronary syndromes254,255 while one study157 enrolled patients with chronic ischemic heart disease. All three studies were conducted in the setting of interventional cardiac procedures—one PCI254, one PCI with stent implantation,157 and one CABG surgery.255

Results were reported with different followup periods (ranging from a one day to 30 days). Because of differences in the tests used, we did not perform meta-analyses for this group of studies. Baseline reactivity measured with Plateletworks and ADP-stimulated P-selectin expression was not statistically significantly associated with reactivity status during followup.

#### Studies Reporting Comparative Information on Test Performance

##### Comparisons Between Alternative Platelet Reactivity Tests

Several studies reported the application of two or more tests applied to the same population. However, no study was specifically designed and analyzed in a way to allow formal comparisons between tests. All studies evaluating multiple tests have been considered with regards to the individual tests they evaluated in the preceding sections of this chapter. Their risk of bias is discussed in the next section; overall, they did not differ substantially (in terms of risk of bias) from studies assessing only a single test. Twelve studies reported extractable information on clinical outcomes for at least two of the assessed tests. Complete information for the populations included, assays used, and study results are presented in Appendix E. Here, we focus on outcomes that were addressed by at least three comparative studies: major adverse cardiovascular events (composite outcome, ten studies) and stent thrombosis (four studies).82,137,140,154,159,161,178,183,186,225 All studies were conducted in ischemic heart disease populations.

For each of these outcomes, we plotted the predictive effect sizes reported for each of the tests evaluated (grouped by study), along with information on the assay and threshold used (results have been organized by study to facilitate direct within-study, cross-assay comparisons). Unfortunately the data cannot be quantitatively synthesized, because when multiple assays are applied to the same patient population results for are likely to be correlated (because the population is shared and assays applied to the same sample produce correlated—if not identical—results) and because the within-study correlation of results cannot be accounted for using aggregate data extracted from the available published studies. Similar problems would be encountered for other measures of test performance, again due to the within-study correlation of reported effect sizes. In the Discussion section of the report we provide suggestions on how future research studies could provide additional information regarding comparative test performance.

###### MACE

Ten studies reported comparative information regarding the ability of assays for measuring platelet reactivity to predict major adverse cardiovascular events.82,137,140,154,159,161,178,183,186,225 The most commonly used test was LTA, which was compared to various comparator tests (thromboelastography and VerifyNow P2Y12 were the most commonly used comparators). Results have been summarized in Figure 32. Overall, point estimates were similar between alternative test methods (within each study) and CIs were overlapping, suggesting that the predictive ability of the compared tests is fairly similar (i.e., the tests have similar abilities to discriminate between patients who will and those who will not experience events).

Figure 32 Comparative studies assessing the predictive ability of platelet-reactivity assays for major adverse cardiovascular events

Abbreviations: ADP = adenosine diphosphate; CI = confidence interval; CT = closure time; EPI = epinephrine; LTA = light-transmission aggregometry; max = maximum; MEA = Multiplate analyzer; PFA = Platelet Function Analyzer; PRU = platelet reactivity units; RR = relative risk; TEG = thromboelastography; U = units; VASP = vasodilator-stimulated phosphoprotein.

RRs compare event rates among patients with high versus low platelet reactivity (as defined by each study, for each test employed). Solid squares (and horizontal lines) indicate the RR of acute coronary syndromes (and the corresponding 95% CI) for individual studies. The vertical line indicates an RR of 1.

Figure 32 presents results from comparative studies assessing the predictive ability of platelet-reactivity assays for major adverse cardiovascular events. Overall, point estimates were similar between alternative test methods (within each study) and confidence intervals were overlapping, suggesting that the predictive ability of the compared tests is fairly similar.

###### Stent Thrombosis

Four studies reported comparative information regarding the ability of assays for measuring platelet reactivity to predict stent thrombosis for patients undergoing PCI with stent implantation (Figure 33).82,140,154,183 LTA was used in three studies and the VerifyNow P2Y12 assay and the PFA-100 assays were each used in two studies; other tests are shown in the figure. Overall, point estimates for the predictive ability of alternative test methods were variable (within each study); however, CIs were extremely wide (and overlapping), suggesting that there is substantial uncertainty regarding the relative predictive ability of the compared tests for stent thrombosis and that there is insufficient evidence on comparative test performance for this outcome.

Figure 33 Comparative studies assessing the predictive ability of platelet-reactivity assays for stent thrombosis

Abbreviations: ADP = adenosine diphosphate; CI = confidence interval; CT = closure time; EPI = epinephrine; LTA = light-transmission aggregometry; max = maximum; PFA = Platelet Function Analyzer; PRU = platelet reactivity units; RR = relative risk; U = units.

RRs compare event rates among patients with high versus low platelet reactivity (as defined by each study, for each test employed). The solid squares (and horizontal lines) indicate the RR of stent thrombosis (and the corresponding 95% CI) for individual studies. The vertical line indicates an RR of 1.

Figure 33 presents results from comparative studies assessing the predictive ability of platelet-reactivity assays for acute coronary syndromes. Overall, point estimates were similar between alternative test methods (within each study) and confidence intervals were fairly wide and overlapping.

##### Comparisons Between Genetic Testing for CYP2C19 Variants and Phenotypic Testing for Platelet Reactivity

Only four studies82,88,95,111 provided extractable information regarding the relative prognostic ability of genetic testing for CYP2C19 loss-of-function variants and phenotypic testing of platelet reactivity for MACE (4 studies) or stent thrombosis (3 studies). These studies have been considered with regards to the individual tests they evaluated in the preceding sections of the report (Key Question 1b or 2b, as applicable). Data that would allow us to formally compare the tests while accounting for the within-person correlation induced by applying multiple tests to the same patient were not reported. Below, for each outcome and each study separately, we have plotted the prognostic sensitivity and prognostic specificity of the tests in the receiver operating characteristic space. Given that these studies represent a very small subset of the studies reporting information on genetic or phenotypic testing, no firm conclusions can be drawn from their results.

###### MACE

Four studies reported information on the prognostic value of genetic and phenotypic tests for MACE.82,88,95,111 Test performance was generally limited, however the paucity of the data does not allow firm conclusions. The specific tests compared are described in the legend of Figure 34.

Figure 34 Comparative studies assessing the predictive ability of genetic testing for CYP2C19 variants and platelet-reactivity assays for MACE

*2/*2 denotes homozygote for the CYP2C19 *2 allele; *2 carrier denotes the combination of *2/*2 and *2/*1 individuals; av. size = average size; ADP = adenosine diphosphate; BL = baseline; CPA = cone and plate analyzer; LTA = light transmission aggregometry; MACE = major adverse cardiovascular event; MEA = Multiplate analyzer; mo = month; PFA = platelet function analyzer; PGE1 = prostaglandin E1; PRU = platelet reactivity unit; RPA = residual platelet aggregation; surf. cov. = surface coverage; VASP = vasodilator-stimulated phosphoprotein phosphorylation; VN = VerifyNow P2Y12 assay. Details regarding the study designs, populations, and outcomes are presented in Appendix E.

Figure 34 presents results from comparative studies assessing the predictive ability of platelet-reactivity assays for MACE. Four studies reported information on the prognostic value of genetic and phenotypic tests for MACE. Test performance was generally limited, however the paucity of the data does not allow firm conclusions.

###### Stent Thrombosis

Three studies reported information on the prognostic value of genetic and phenotypic tests for stent thrombosis.82,88,95 Test performance was generally limited, however the paucity of the data does not allow firm conclusions. The specific tests compared are described in the legend of Figure 35.

Figure 35 Comparative studies assessing the predictive ability of genetic testing for CYP2C19 variants and platelet-reactivity assays for stent thrombosis

*2/*2 denotes homozygote for the CYP2C19 *2 allele; *2 carrier denotes the combination of *2/*2 and *2/*1 individuals; av. size = average size; ADP = adenosine diphosphate; BL = baseline; CPA = cone and plate analyzer; LTA = light transmission aggregometry; MACE = major adverse cardiovascular event; MEA = Multiplate analyzer; mo = month; PFA = platelet function analyzer; PGE1 = prostaglandin E1; PRU = platelet reactivity unit; RPA = residual platelet aggregation; surf. cov. = surface coverage; VASP = vasodilator-stimulated phosphoprotein phosphorylation; VN = VerifyNow P2Y12 assay. Details regarding the study designs, populations, and outcomes are presented in Appendix E.

Figure 35 presents results from comparative studies assessing the predictive ability of platelet-reactivity assays for stent thrombosis. Three studies reported information on the prognostic value of genetic and phenotypic tests for stent thrombosis. Test performance was generally limited, however the paucity of the data does not allow firm conclusions.

### Risk of Bias for Studies Reviewed for Key Question 2b

The detailed assessment of 11 risk-of-bias items for studies evaluating the predictive ability of phenotypic testing regarding clinical outcomes or platelet reactivity (during followup) is presented in Appendix E. Briefly, all studies used a longitudinal design (not case–control; per our inclusion criteria) and no studies had substantial loss-to-followup. Inappropriate exclusions were uncommon however information on blinding was often not reported (particularly for the index test) or not used. Using the arbitrary cutoffs based on the number of adequately addressed risk of bias items 35 studies were rated as quality “A,” 80 studies were rated as quality “B,” and 12 were rated as quality “C.”

#### Assessing Small-Study Effects

For the two assays (VerifyNow P2Y12 and VASP) and for outcomes for which we performed meta-analyses of predictive value we assessed differences between more precise (larger) and less precise (smaller) studies using the Egger regression-based test for small study effects. Table 10 summarizes our key findings.

Table 10 Small study effects in meta-analyses of the value of platelet reactivity for predicting clinical outcomes among clopidogrel-treated patients with ischemic heart disease

Assay | Outcome | P-Value for Small-Study Effects
VerifyNow P2Y12 | All-cause mortality | 0.147
VerifyNow P2Y12 | Cardiovascular mortality | 0.383
VerifyNow P2Y12 | MACE | 0.001
VerifyNow P2Y12 | Stent thrombosis | 0.048
VerifyNow P2Y12 | Bleeding events (all severity levels) | 0.764
VerifyNow P2Y12 | Bleeding events (major) | 0.611
VASP assay | MACE | 0.230
VASP assay | Cardiovascular mortality | 0.113
VASP assay | Stent thrombosis | 0.769
VASP assay | Acute coronary syndromes | 0.311

MACE = major adverse cardiovascular events, VASP = vasodilator-stimulated phosphoprotein.

Significant p-values are in bold type.

Statistically significant “small study effects” were identified among studies of the VerifyNow P2Y12 assay included in meta-analyses of MACE and stent thrombosis. Again, we caution that these statistically significant results should not be overinterpreted as proof for the presence of publication bias given both the statistical properties of the Egger test and the fact that alternative causes (true heterogeneity between smaller and larger studies, chance, or other biases) can also produce significant results. Nonetheless, these results suggest that selective publication of more extreme results in smaller studies may have affected the available data and limits somewhat the strength of the conclusions that can be drawn (e.g., it contributed to our decision to grade the strength of evidence on MACE as moderate, rather than high).

## Key Question 2c What is the impact of modifying factors on the association between phenotypic test results and clinical outcomes?

We reviewed studies to identify any evidence that patient- or system-level factors or test characteristics could modify the predictive ability of phenotypic testing for platelet reactivity. Evidence of effect modification by person-level characteristics (e.g., age, sex, disease severity) is best obtained from comparisons within a given study (i.e., among subgroups of the patient population that were selected using the same criteria and managed in a similar way). Additional evidence on effect modification can be derived from exploratory comparisons across studies, by assessing study-level characteristics (e.g., the setting of care or study design characteristics) or characteristics of the overall patient population (e.g., populations selected on the basis of ancestry).^f^ In the following sections we discuss each of these sources of information regarding effect modification separately.

f We refer to the information obtained from cross-study comparisions as "exploratory" because comparisons for a given characteristic across studies may be confounded (by other study features). Our ability to statistically "control" for such differences is typically limited by the relatively small number of available studies available for meta-analysis.

### Effect Modification Within Studies

In total, seven studies reported information on effect modification of the predictive effect of platelet reactivity. All studies reported information on clinical outcomes. Relevant results have been summarized in Table 11; however, we caution that because only a small subset of the eligible studies provided adequate information to statistically assess effect modification, selective reporting is highly likely.

Table 11 Studies reporting information on effect modification

Author Year Country PMID Study name (when available) | Patient Population | Antiplatelet Regimen | Platelet Reactivity Measurement Method (agonist) [assay and manufacturer] Threshold Definition | Effect Modifier | Summary of Findings^*^
Bliden137 2007 US 17291930 NR | Patients on clopidogrel-based therapy for ≥1 mo undergoing scheduled PCI | Aspirin ≥81 mg/d for ≥7 d before PCI; clopidogrel 75 mg/d for ≥1 mo | LTA (ADP 5 μmol/L) [Chronolog Lumi-Aggregometer; Model 490-4D; Chronolog, Havertown, PA] ≥50% on-clopidogrel reactivity [based on prior literature] | IIb/IIIa inhibitor treatment (used vs. not) | Predictive effect of on-treatment reactivity stratified by IIb/IIIa inhibitor treatment for the composite outcome of death, MI, TVR, stroke, non-TVR, or rehospitalization for ischemia [calculated values] IIb/IIIa inhibitor used: high reactivity vs. normal reactivity OR=29.33 (95% CI, 2.40 to 357.85) IIb/IIIa inhibitor not used: high reactivity vs. normal reactivity OR=32.67 (95% CI, 7.12 to 149.79) P for interaction=0.94 [chi-square test for heterogeneity]
Campo187 2010 Multinational 20951320 3T/2R ancillary study | Patients undergoing PCI were screened for aspirin and clopidogrel responsiveness (poor-responders were randomized to tirofiban or placebo^†^); the current study reported on long term outcomes regardless of baseline response status | Aspirin 100 mg/d indefinitely; clopidogrel 75 mg/d for ≥1 mo for patients with stable CAD receiving BMS, or for ≥1 yr for patients with UA or receiving DES | VerifyNow Aspirin (AA agonist) for aspirin responsiveness; VerifyNow P2Y12 (ADP agonist) for clopidogrel responsiveness [Accumetrics, San Diego, CA] For VerifyNow Aspirin ARU ≤550 and VerifyNow P2Y12 % platelet inhibition ≥40% were considered indicative of full response to aspirin and clopidogrel, respectively [cutoff values were those used in the 3T/2R study] | IIb/IIIa inhibitor treatment (used vs. not); in poor responders at baseline, use of IIb/IIIa inhibitor was randomized; the choice was “operator's choice” in responders | Predictive effect of “nonresponder status” stratified by IIb/IIIa inhibitor treatment [calculated values]. Periprocedural ischemic events (up to 3 d post-PCI). IIb/IIIa inhibitor used: high reactivity vs. normal reactivity OR=1.63 (95% CI, 0.54 to 4.92).IIb/IIIa inhibitor not used: high reactivity vs. normal reactivity OR=2.76 (95% CI, 1.42 to 5.36). P for interaction =0.42 [chi-square test for heterogeneity] Periprocedural MI (up to 3 d post-PCI). IIb/IIIa inhibitor used: high reactivity vs. normal reactivity OR=4.20 (95% CI, 1.77 to 9.93) IIb/IIIa inhibitor not used: high reactivity vs. normal reactivity OR=7.72 (95% CI, 4.60 to 13.04). P for interaction=0.22 [chi-square test for heterogeneity].Death, MI, or stroke (3 d–1 yr post-PCI) IIb/IIIa inhibitor used: high reactivity vs. normal reactivity OR=2.97 (95% CI, 0.95 to 9.28) IIb/IIIa inhibitor not used: high reactivity vs. normal reactivity OR=3.59 (95% CI, 1.74 to 7.39) P for interaction=0.78 [chi-square test for heterogeneity]
El Ghannudi224 2011 France 21524751 NR | Patients undergoing PCI with stent placement for ACS or stable CAD | Clopidogrel (various loading doses); all patients were on aspirin treatment | VASP assay (ADP ± PGE1) [Diagnostica Stago (Biocytex), Asnieres, France] using flow cytometry Poor response was defined as VASP PRI>61% [based on prior literature] | Diabetes mellitus (yes vs. no) | Results from univariate analyses (platelet reactivity was not a significant predictor of outcomes in nondiabetic patients and adjusted results were NR) Diabetic patients HR for PRI >61% vs. ≤61% for CV death=5.798 (95% CI, 1.25 to 26.86) HR for PRI >61% vs. ≤61% for all-cause mortality=3.84 (95% CI, 1.04 to 14.23) HR for PRI >61% vs. ≤61% for MACE=2.01 (95% CI, 0.96 to 4.23) Non-diabetic patients HR for PRI >61% vs. ≤61% for CV death=1.74 (95% CI, 0.43 to 7.00) HR for PRI >61% vs. ≤61% for all-cause mortality=1.53 (95% CI, 0.47 to 5.04) HR for PRI >61% vs. ≤61% for MACE=1.06 (95% CI, 0.55 to 2.03) Interaction p-value [diabetic vs. nondiabetic] for CV death=0.26; for all-cause mortality=0.31; for MACE=0.20 [calculated values, chi-square test for heterogeneity]
Mangiacapra196 2010 Multinational 20723634 NR | Patients undergoing elective PCI with stent implantation for stable angina or NSTE ACS | Pre-PCI: clopidogrel loading dose 600 mg or on-clopidogrel chronic treatment (75 mg/d for ≥5 d); post-PCI: clopidogrel maintenance (75 mg/d for ≥1 mo after BMS implantation or 12 mo after DES implantation or patients with ACS) All patients received aspirin (100 mg/d) pre-PCI and continued with the same maintenance dose indefinitely | VerifyNow P2Y12 (ADP) [Accumetrics, San Diego, CA] High platelet reactivity was defined as VerifyNow PRU >240 [based on prior literature] | Diabetes mellitus (yes vs. no) | Effect of high vs. low platelet reactivity, stratified by diabetes status (calculated values) on periprocedural MI Diabetic patients: OR=5.89 (95% CI, 1.46 to 23.81) Nondiabetic patients, OR=1.82 (95% CI, 0.44 to 7.65) Interaction p-value [diabetic vs. nondiabetic]=0.25 [chi-square test for heterogeneity]
Morel227 2011 France 21251579 NR | Patients undergoing PCI for stable CAD or ACS | Clopidogrel loading dose (300 or 600 mg); all patients received aspirin | VASP assay (ADP ± PGE1) [Biocytex, Diagnostica Stago, Asnieres, France] using flow cytometry Poor response was defined as VASP PRI >61% [based on prior work from the same authors] | CKD (present vs. not) | Effect of nonresponse to clopidogrel (vs. response), stratified by CKD status (calculated values) Patients with CKD All-cause mortality, OR=12.145 (95% CI, 2.604 to 56.647) Cardiac death, OR=10.923 (95% CI, 2.325 t0 51.314) STE MI, OR=1.449 (95% CI, 0.197 to 10.637) NSTE MI, OR=2.219 (95% CI, 0.357 to 13.780) TVR, OR=1.157 (95% CI, 0.295 to 4.538) Definite stent thrombosis, OR=1.440 (95% CI, 0.088 to 23.567) Probable stent thrombosis, OR=6.128 (95% CI, 0.664 to 56.528) Definite/probable stent thrombosis, OR=3.859 (95% CI, 0.718 to 20.730) Possible stent thrombosis, OR=17.387 (95% CI, 0.939 to 321.819) All types of stent thrombosis, OR=8.659 (95% CI, 1.808 to 41.457) MACE, OR=3.556 (95% CI, 1.433 to 8.822) Patients without CKD All-cause mortality, OR=0.648 (95% CI, 0.164 to 2.557) Cardiac death, OR=0.762 (95% CI, 0.138 to 4.228) STE MI, OR=0.507 (95% CI, 0.052 to 4.930) NSTE MI, OR=1.242 (95% CI, 0.476 to 3.241) TVR, OR=1.146 (95% CI, 0.552 to 2.382) Definite stent thrombosis, OR=2.079 (95% CI, 0.457 to 9.456) Probable stent thrombosis, OR=0.764 (95% CI, 0.069 to 8.523) Definite/probable stent thrombosis, OR=1.556 (95% CI, 0.441 to 5.490) Possible stent thrombosis, OR=0.507 (95% CI, 0.021 to 12.559) All types of stent thrombosis, OR=1.289 (95% CI, 0.385 to 4.321) MACE, OR=1.026 (95% CI, 0.538 to 1.956) Interaction p-values [chi-square tests for heterogeneity], by outcome (CKD vs. no CKD) All-cause mortality, p=0.005; cardiac death, p=0.023; STE MI, p=0.495; NSTE MI, p=0.581; TVR, p=0.990; definite stent thrombosis, p=0.821; probable stent thrombosis, p=0.213; definite/probable stent thrombosis, p=0.396; possible stent thrombosis, p=0.107; all types of stent thrombosis, p=0.057; MACE, p=0.029
Park211 2011 S. Korea 22152948 NR | Patients who had undergone PCI with DES implantation for stable angina or ischemia, or NSTE-MI | Aspirin loading (200 mg) followed by maintenance therapy (100-200 mg); clopidogrel “optimal treatment” (defined as maintenance therapy with 75 mg/d for ≥5 d or a loading dose of 300 or 600 mg ≥12 h pre-PCI) | VerifyNow P2Y12 (ADP) [Accumetrics, San Diego, CA] Poor response was defined as PRU >235 or %inhibition <15% [cutoffs were chosen to be “similar” to previous studies] | CRP levels (≥3 mg/L vs. <3 mg/L) | Among patients with elevated CRP levels, high on-clopidogrel platelet reactivity was associated with increased risk for the primary outcome (MACE, defined as all-cause death, nonfatal MI, stent thrombosis, and stroke) compared to low reactivity; “these findings were not observed in patients with non-elevated CRP”; interaction p-value=0.02.
Siller-Matula244 2012 Austria 22305813 NR | Patients undergoing PCI with stent implantation | Loading with clopidogrel (600 mg) + aspirin (100 mg); maintenance with clopidogrel (75 mg/d) + aspirin (100 mg/d) | Multiplate analyzer (ADP) [Verum Diagnostica GmbH, Munich, Germany] Poor response was defined as reactivity ≥48U [chosen on the basis of data, to maximize the sum of sensitivity and specificity] | Diabetes (present vs. not) | For MACE (stent thrombosis, acute coronary syndrome, death, stroke, or repeat revascularization by PCI or CABG): prognostic ability of high on-clopidogrel platelet reactivity among patients with diabetes: OR=2.18 (95% CI, 1.20 to 3.95); p=0.04. Prognostic ability of high on-clopidogrel platelet reactivity among patients without diabetes: OR=1.86 (95% CI, 1.03 to 3.37); p=0.048. Interaction p=0.923

* The description “calculated values” indicates that the results are based on statistical procedures we conducted in cases where studies provided sufficient statistics for the assessment of effect modification but did not assess its statistical significance.

† Information from the randomized comparison has been reviewed in the section of this report relevant to Key Question 3.

3T/2R = Tailoring Treatment with Tirofiban in patients showing Resistance to aspirin and/or Resistance to clopidogrel; AA = arachidonic acid; ACS = acute coronary syndromes; ADP = adenosine diphosphate; ARU = aspirin reactivity units; BMS = bare metal stent; CAD = coronary artery disease; CI = confidence interval, CKD = chronic kidney disease; CV = cardiovascular, d = days, DES = drug eluting stent; HR = hazard ratio, LTA = light-transmission aggregometry, MACE = major adverse cardiovascular events; MI = myocardial infarction; mo=months, NR = not reported; NSTE = non–ST-elevation; OR = odds ratio; PCI = percutaneous coronary intervention; PGE1 = prostaglandin E1, PRI = platelet reactivity index, PRU = platelet reactivity units, STE = ST-elevation; TVR = target-vessel revascularization; UA = unstable angina, VASP = vasodilator-stimulated phosphoprotein; yr = years.

Studies assessed the following factors as potential modifiers: IIb/IIIa inhibitor as an adjunct treatment for PCI (two studies), diabetes mellitus (three studies), and chronic kidney disease (one study). Two studies used the VASP assay to assess platelet reactivity, three used the VerifyNow P2Y12 assay (one of which also used VerifyNow ASA^g^), one used LTA (with ADP as the agonist), and one used the Multiplate analyzer. Statistically significant interaction effects were reported only in two studies. The first study227 assessed whether the predictive value of the VASP assay is different among patients with coronary artery disease who have coexisting chronic kidney disease versus those who do not. The study found statistically significant interaction effects for several clinical outcomes (all-cause mortality, cardiac death, and a composite outcome of all-cause mortality, myocardial infarction, or target-lesion revascularization), in all cases suggesting that the prognostic effect of high on-clopidogrel platelet reactivity was stronger among patients with chronic kidney disease. The second study assessed whether the prognostic effect of the VerifyNow P2Y12 assay is different among patients with high (≥3 mg/L) versus low (<3 mg/L) CRP levels. The study reported a statistically significant interaction effect, suggesting that high on-clopidogrel platelet reactivity was associated with increased risk for the primary outcome (MACE, defined as all-cause death, nonfatal MI, stent thrombosis, and stroke) compared to low reactivity among patients with diabetes but not among non-diabetic patients.

g This assay uses arachidonic acid as the agonist, to measure "aspirn resistance."

### Effect Modification Across Studies

On the basis of our protocol and the availability of data from studies considered eligible for Key Question 2b, we assessed the following characteristics as potential modifiers of the predictive effect of platelet reactivity by performing comparisons across studies using subgroup analysis: disease subtype (acute coronary syndromes vs. mixed coronary artery disease populations), setting of care (PCI vs. other), duration of followup (≤30 days vs. >30 days); and year when enrollment was started (continuous variable). For setting of care (PCI versus not) there was no variability across studies (all were conducted in the setting of interventional procedures); as such no meta-analysis was performed. Meta-regressions were performed only for one outcome (MACE) reported in more than 10 studies and for high versus low reactivity measured with the VerifyNow assay (all other assays had less than 10 studies considered sufficiently similar for meta-analysis for all outcomes assessed). Table 12 summarizes the findings of our meta-regression analyses.

Table 12 Meta-regression results for study-level effect modifiers of the predictive value of phenotypic testing for platelet reactivity using the VerifyNow P2Y12 assays in patients with ischemic heart disease: major adverse cardiovascular events

Effect Modifier | Groups Compared | No. of Studies | RR (95% CI) Within Subgroup | rRR (95% CI); P-Value
All studies | NA | 13 | 2.48 (1.86 to 3.32) | NA
ACS vs. ischemic heart disease | Other ischemic heart disease or mixed | 8 | 2.10 (1.55 to 2.86) | 1.86 (0.99 to 3.52); 0.055
ACS vs. ischemic heart disease | ACS | 5 | 3.68 (2.26 to 6.00) | 1.86 (0.99 to 3.52); 0.055
Duration of followup | >30 d | 11 | 2.29 (1.72 to 3.05) | 2.63 (0.83 to 8.32); 0.101
Duration of followup | ≤30 d | 2 | 6.03 (2.13 to 17.10) | 2.63 (0.83 to 8.32); 0.101
Enrollment start year | (continuous variable) | 12 | NA | 1.06 (0.82 to 1.38); 0.649

ACS = acute coronary syndromes; CI = confidence interval; d = days; NA = not applicable; RR = relative risk; rRR = relative RR (between groups).

Results across all studies are provided for comparison. One study did not report the year of start of enrollment.

Taken together, analyses of effect modification within-studies and across studies did not provide sufficient evidence that any factor substantially modifies the predictive effect of platelet reactivity.

## Key Questions 3a and 3b Regarding Alternative Testing Strategies

The overarching question of the impact of testing (genetic or phenotypic) on outcomes can be answered by comparative studies of alternative test-and treat strategies. Direct comparisons of testing strategies, particularly those in which assignment to a specific test-based strategy is random, are generally very rare. However, other study designs can provide information on the clinical utility of the tests of interest to this review. We grouped the studies we identified for this Key Question into three categories:

1. Randomized trials of test-and-treat strategies: These studies randomize patients to alternative management strategies, at least one of which is based on a test of interest. Patients are then followed up for intermediate or clinical outcomes. Random treatment assignment provides an unconfounded estimate of the effect of test-based management compared to alternative therapeutic strategies on outcomes.
2. Randomized treatment trials that evaluate treatment-effect modification: These are randomized studies in which patients in all groups undergo the test of interest at baseline. Treatment assignment is based on randomization and thus is independent of test results. Because these studies include both test-positive and test-negative patients in each treatment arm, they can be used to assess test result × treatment interactions. The presence of an interaction effect indicates that the relative treatment benefits (or harms) differ by test status; the results can also be used to infer whether improved outcomes should be expected if treatment choice were guided by test results.
3. Randomized trials with test-based selection: These studies select patients on the basis of baseline test results and then randomize them into non–test-based treatment groups. When properly randomized and conducted, these studies can provide unconfounded estimates of the treatment effect conditional on a particular test result but do not provide information on whether the treatment effect is modified by the test results.

Key Question 3 focused on efficacy outcomes (platelet reactivity as an intermediate marker of response and patient-relevant clinical outcomes). Information on harms is summarized later in the Results section, under Key Question 4. In the following sections, we discuss studies belonging to each of three designs—studies of test-and-treat strategies, studies of treatment-effect modification, and studies with test-based selection—separately for genetic testing (CYP2C19 variants) and for phenotypic testing (platelet reactivity). Table 13 summarizes the number of studies and outcomes assessed for each of the designs we reviewed for Key Question 3.

Table 13 Number of studies relevant to Key Question 3a or 3b and outcomes assessed, by study design and test used

Study Design | Genetic Testing for CYP2C19 Variants | Phenotypic Testing for Platelet Reactivity
Comparative studies of test-and-treat strategies (testing vs. no testing or comparisons between alternative test-and-treat strategies) | 1 RCT (clinical and intermediate outcomes) | 6 RCTs + 1 NRCS (4 for clinical outcomes; 3 both for clinical and intermediate outcomes)
RCTs of treatment-effect modification by test results (difference in treatment effects across levels of the biomarkers) | 12 (5 for clinical outcomes; 6 for intermediate outcomes; 1 for both) | 3 (1 for clinical outcomes; 2 for intermediate outcomes)
RCTs with test-based selection (comparison of treatments among patients selected on the basis of biomarker level) | 1 (clinical and intermediate outcomes) | 14 (4 for clinical outcomes only; 4 for intermediate outcomes only; 6 for both)

NRCS = nonrandomized comparative study; RCT = randomized controlled trial.

### Key Question 3a What is the comparative effectiveness of genetic testing for CYP2C19 variants and phenotypic testing for platelet reactivity for therapeutic decisionmaking?

#### Genetic Testing for CYP2C19 Variants

##### Study of Test-and-Treat Strategies

We identified a single-center, “pilot study” (as described by the authors) comparing a strategy of testing for CYP2C19 variants versus no testing strategy to guide treatment decisionmaking in a predominantly white population (95 percent). Table 14 summarizes information on the comparators and patient population of the study; Table 15 summarizes information on the design of the trial; and Table 16 summarizes test-related information. Of note, the trial used a point-of-care genotyping assay (Spartan RX CYP2C19) to obtain genotyping results for the CYP2C19 *2 allele rapidly (within ∼1 hour after sampling).

Table 14 Descriptive characteristics of studies of test-and-treat strategies using genetic testing of CYP2C19 variants

Author Year Country PMID Study Name (if available) | Selected Population | Total N Enrolled Male (%) Age^*^ Dyslipidemia (%) Current smokers (%) HTN (%) Diabetes (%) | Initial and Compared Treatment Strategies
Roberts86 2012 Canada 22464343 RAPID-GENE | Adult patients undergoing PCI for the treatment of NSTE-ACS or stable CAD; patients who had been administered antiplatelet treatment other than aspirin + clopidogrel, or anticoagulation, were excluded | N=200 (187 with complete followup) 146 (78%) 60 (9) 152 (81%) 58 (31%) 119 (64%) 39 (21%) | All patients were treated with a loading dose of clopidogrel (600 mg) ≥24 h pre-PCI; adjuvant pharmacotherapy during PCI was restricted to bivalirudin. Patients were then randomized to 1 of 2 treatment strategies: CYP2C19 genotyping-guided treatment: Genotyping was performed for identifying *2 carrier status at the time of randomization. Carriers of the *2 allele (i.e., *2/*1 and *2/*2) were given prasugrel 10 mg/d, with the first dose immediately after PCI. Non-carriers received clopidogrel 75 mg/d. Control treatment: maintenance clopidogrel (75 mg/d)

* Mean (standard deviation), unless otherwise stated.

ACS = acute coronary syndrome; CAD = coronary artery disease; d = day; HTN = hypertension; NSTE = non-ST elevation; PCI = percutaneous coronary intervention.

Table 15 Study design characteristics of studies of test-and-treat strategies using genetic testing of CYP2C19 variants

Author Year Country PMID Study Name (if available) | Enrollment period | Randomization Procedure | Blinding | Number of Participating Centers | Followup Duration | Setting | Target Enrollment from a priori power analysis | Procedure for Multiple Comparisons | Funding
Roberts86 2012 Canada 22464343 RAPID-GENE | August 2012 – July 2011 | Randomization sequence was computer generated and blocked in randomly selected block sizes of 4 and 6; patients were allocated to trial groups using opaque, serially numbered, sealed envelopes. | Interventional cardiologists and data analysts were masked to genetic carrier status and subsequent treatment for the duration of the study. Patients were not masked to treatment allocation. | Single center | For pharmacodynamics outcomes 7 d; for clinical outcomes 30 d | Cardiology institute of university hospital | Targeted 200; enrolled 200; analyzed 187 [powered to detect a difference in the treatment effect among *2 carriers] | Not used | Industry only (manufacturer of genotyping assay)

d = days.

Table 16 Test information in studies of test-and-treat strategies using genetic testing of CYP2C19 variants

Author Year Country PMID Study Name (if available) | Assay for Genetic Testing (Manufacturer) | Test Time Point Interval Between Sampling and Genotyping Results Interval Between Collection and DNA Extraction | N Tested Test Success Rate (%) | Alleles Genotyped | Genotype Grouping | Rationale for Grouping Alleles
Roberts86 2012 Canada 22464343 RAPID-GENE | Spartan RX CYP2C19 point-of-care testing device; please see the section on Key Question 1a for additional information on analytic validity from this trial (Spartan Biosciences, Ottawa, ON, Canada) | All patients were tested “at the time of randomization” Acquisition of samples and initiation of analysis = 8 min; *2 genotyping results within 60 min of activation | 200 patients were tested Results were obtained from all patients; erroneous results (as compared to sequencing) were obtained in 1 patient (misclassified as carrier) | *2 [rs4244285] | Carriers=*2/*2 or *2/*1 or *3/*3 Non-carriers=*1/*1 | Unclear

min = minutes.

###### Clinical Outcomes

The study reported monitoring the following clinical outcomes: a composite outcome of cardiovascular death, non-fatal myocardial infarction, readmission to hospital, and stent thrombosis. Twenty-three of 91 patients (25 percent) assigned to the rapid genotyping group were CYP2C19 *2 carriers (4 were homozygotes); 23 of 96 (24 percent) in the standard therapy group were CYP2C19 *2 carriers (3 were homozygotes). No clinical adverse ischemic outcomes were observed in either group, at 7 or 30 days of followup.

###### Intermediate Outcome: Platelet Reactivity During Followup

Intermediate outcomes were assessed with the VerifyNow P2Y12 assay (Accumetrics, San Diego, CA). The primary study endpoint was the proportion of CYP2C19*2 carriers with a P2Y12 reactivity value of more than 234 units (PRU) after 1 week of dual antiplatelet therapy. The cut-off for high reactivity was derived from previous published studies. All patients underwent platelet-function testing immediately after PCI and at 7 days after randomization. Table 17 summarizes the key findings regarding intermediate outcomes.

Table 17 Summary of intermediate outcomes in studies of test-and-treat strategies using genetic testing of CYP2C19 variants

Author Year Country PMID Study Name (if available) | Treatment Groups (sample size) | Followup Duration | Summary of Findings
Roberts86 2012 Canada 22464343 RAPID-GENE | CYP2C19 genotyping-guided treatment: prasugrel for *2 carriers; clopidogrel for non-carriers (102 randomized; 91 included in analyses; 23 of whom were *2 carriers) Control treatment: clopidogrel (98 randomized; 96 included in analyses; 23 of whom were *2 carriers) | 1 wk after randomization | Among *2 carriers only Proportion with high on-treatment platelet reactivity (PRU >234) = 0% in the genotyping-guided group vs. 30% in the control treatment group (p=0.009) Proportion with high on-treatment platelet reactivity (PRU >208) = 1% in the genotyping-guided group vs. 48% in the control treatment group (p=0.002) Change in PRU from baseline to d 7 among *2 carriers in the genotyping-guided group=-123.09 (SD=77.2) vs. -8.48 (SD=74.0) in the control treatment group (p<0.001) Platelet inhibition = 73.3% (SD=20.3) in the genotyping-guided group vs. 27.0% (SD=13.4) in the control treatment group (p<0.001) In the whole trial population Proportion with high on-treatment platelet reactivity (PRU >234) = 10% in the genotyping-guided group vs. 17% in the control treatment group (p=0.067) Proportion with high on-treatment platelet reactivity (PRU >208) = 15% in the genotyping-guided group vs. 31% in the control treatment group (p<0.001) Platelet inhibition = 56.5% (SD=24.5) in the genotyping-guided group vs. 43.9% (SD=22.9) in the control treatment group (p<0.001)

PRU = platelet reactivity unit; SD = standard deviation; wk = week.

###### Assessment of Risk of Bias of the Study

A detailed assessment of risk of bias for this trial is presented in Appendix F. Briefly, this was a well-conducted, single-center, pilot study that was based on an a priori power analysis and met its accrual target. Although approximately 6.5 percent of enrolled patients were excluded from the analyses, the reasons for exclusion do not appear to have introduced bias. The procedure for generating the randomized sequence was appropriate for obtaining random allocation of participants. Interventional cardiologists and data analysts were masked to genotype information and treatment assignment; however, patients were not masked to treatment allocation. Statistical analyses were preplanned and results (summarized above) were reported in adequate detail, for all pre-specified outcomes (both primary and secondary).

##### Randomized Trials Reporting Information on Treatment-Effect Modification by CYP2C19 Genotype Status

We identified 12 studies (reported in 13 publications) describing randomized controlled trials that provide information on effect modification by CYP2C19 variants. Six studies (reported in seven publications)^h^ provided information on clinical outcomes, five on intermediate outcomes (platelet reactivity during followup), and one on both types of outcome.

h These publications reported information on a single population each and on publication reported information on two independent populations.

Information on the genetic assays used, the specific variants genotyped, and the grouping of genotypes for analysis is presented Table 18 for all studies of treatment-effect modification by CYP2C19 variants. In most cases, authors claimed to have based the classification of genotypes on prior published literature; however, studies genotyped different variants, resulting in heterogeneous exposure groupings.

Table 18 Test information for studies of treatment-effect modification by CYP2C19 genotype status

Author Year Country PMID Study Name (if available) | Assay for Genetic Testing (Manufacturer) | Test Time Point Interval Between Sampling and Genotyping Results Interval Between Collection and DNA Extraction | N Tested Test Success Rate (%) | Alleles Genotyped | Genotype Grouping | Rationale for Grouping Alleles
Pare109 2010 Multinational 20979470 ACTIVE A | TaqMan assays [no additional information provided] | NR NR NR | Not estimable (data presented only on the successfully genotyped patients) | *2 [rs4244285]; *3 [rs4986893]; *4 [rs12248560] | Poor metabolizers=*2/*2 or *2/*3 or *3/*3 Intermediate metabolizers=*2/*1 or *3/*1 Extensive metabolizers=*1/*1 Ultra metabolizers=*17/*1 or *17/*17 Unknown metabolizers=*2/*17 or *3/*17 | Based on prior literature; however, results from an alternative classification were presented as Appendix material
Pare109 2010 Multinational 20979470 CURE | TaqMan assays [no additional information provided] | NR NR NR | Not estimable (data presented only on the successfully genotyped patients) | *2 [rs4244285]; *3 [rs4986893]; *4 [rs12248560] | Poor metabolizers=*2/*2 or *2/*3 or *3/*3 Intermediate metabolizers=*2/*1 or *3/*1 Extensive metabolizers=*1/*1 Ultra metabolizers=*17/*1 or *17/*17 Unknown=*2/*17 or *3/*17 | Based on prior literature; however, results from an alternative classification were presented as Appendix material
Mega99,258 2009 Multinational 19106084 19414633 TRITON-TIMI 38 | 98% of the genotyping procedures were performed with the Targeted Human DMET 1.0 Assay [Affymetrix, no additional details provided]; for the *17 allele and for no-call samples on the DMET chip (2% of samples) genotyping was performed with bi-directional sequencing or exon-specific PCR | NR NR NR | Not estimable (data presented only on the successfully genotyped patients) | *1A, *2A, *3, *4, *5A, *6, *7, *8, *9, *10, *12, *13, *14 | Noncarriers=*1A/*1A Carriers=*1/*2A, *1A/*3, *1A/*4, *1A/*8, *2A/*2A, *2A/*3, *2A/*4, *2A/*5A, *2A/*8 Unknown=*1A/*9, *1A/*10, *2A/*17, *6/*17 | Based on prior literature
Mega259 2010 Multinational 20801494 TRITON-TIMI 38 | Detailed information not provided in the paper however the study by Mega et al. 2009^99^ (see above row) was cited for the genotyping methods and grouping of genotypes. | NR NR NR | Not estimable (data presented only on the successfully genotyped patients) | For CYP2C19: as above In addition, genotyping was performed for ABCB1 C3435T (rs1045642) and results by combining both tests were reported | For CYP2C19: as above For ABCB1 C3435T: TT carriers vs. CC or CT carriers^*^ Combined results were presented by grouping patients with CYP2C19 reduced-function alleles and ABCB1 TT carriers vs. CYP2C19 loss-of-function allele noncarriers and ABCB1 CC/CT carriers^*^ | Based on prior literature
Kim260 2011 S. Korea 21511217 ACCELAMI2C19 | Single base primer extension assay (SNaPshot kit, Applied Biosystems, Foster City, CA) on the ABI 3100 genetic analyzer (Applied Biosystems, Foster City, CA) | NR NR NR | 140 MI patients were identified; CYP2C19 genotype could be determined in 126 (88.6%) | *2 [rs4244285]; *3 [rs4986893] | Carriers=*2/*1 or *3/*1 or *3/*3 Noncarriers=*1/*1 | Not explicitly reported
Wallentin104 2010 Multinational 20801498 PLATO | TaqMan assays [Applied Biosystems, Life Technologies, Pleasanton CA] | Blood samples were obtained “as close to [time of] randomization as possible” NR NR | 10,285 98.8–99.5% | CYP2C19*1–*8, *17 In addition, genotyping was performed for ABCB1 C3435T (rs1045642) and results by combining both tests were reported | For CYP2C19: Any LOF allele (*2–*8) No LOF allele (*1 or *17) For major bleeding only: Any LOF allele (*2–*8) but no GOF allele (not *17) No LOF or GOF allele (*1) Any GOF allele (*17) For ABCB1 C3435T:^*^ High expression (C/C) Intermediate expression (C/T) Low expression (T/T) Combined results were presented by grouping patients with any CYP2C19 loss-of-function allele and ABCB1 TT carriers vs. all other patients | Based on prior literature
Varenhorst261 2009 Sweden 19429918 TABR | Targeted Human DMET 1.0 Assay (Affymetrix, Santa Clara, CA) for all alleles except *17; *17 was genotyped using PCR-RFLP methods | NR NR NR | For CYP2C19 variants: 98 (100% success rate) | *1A, *2A, *3, *4, *5A, *6, *7, *8, *9, *10, *12, *13, *14, *17 | Extensive metabolizers=*17/*17, *1A/*17, *1A/*1A Reduced metabolizers=*1A/*2A, *1A/*8, *2A/*2A Uncertain functional status=*2A/*17 | Based on prior literature
Tantry262 2010 USA and UK 21079055 ONSET/OFFSET and RESPOND Genotype Studies | TaqMan Assay (Life Technologies, Pleasanton, CA) | NR NR NR | NR (results reported only on successfully genotyped individuals) | *2 [rs4244285]; *3 [rs4986893]; *4 [rs28399504]; *5 [rs56337013]; *6 [rs72558184]; *7 [rs72558186]; *8 [rs41291556]; *17 [rs12248560] | 3 genotype grouping schemes were used: Grouping 1 Ultra metabolizers=*17/*17 or *17/*1 Extensive metabolizers=*1/*1 Intermediate metabolizers=*2-*8/*1 or *2-*8/*17 Poor metabolizers=*2-*8/*2-*8 Grouping 2 Loss-of-function carriers=*2-*8/*1 or *2-*8/*17 or *2-*8/*2-*8 Loss-of-function noncarriers=*1/*1 or *17/*17 or *17/*1 Grouping 3 Gain-of-function carriers=*17/*17 or *17/*1 Extensive metabolizers=*1/*1 Loss-of-function carriers=*2-*8/*1 or *2-*8/*17 or *2-*8/*2-*8 Results were also presented separately for the observed diplotypes. | Not explicitly reported
Hwang263 2010 S. Korea 20823393 ACCEL-RESISTANCE, DM, and COMPLEX trials | Single base primer extension assay (SNaPshot kit, Applied Biosystems, Foster City, CA) on the ABI 3100 genetic analyzer (Applied Biosystems, Foster City, CA) | NR NR NR | 140 patients undergoing PCI in the 3 RCTs were identified; CYP2C19 genotype could be determined in 114 (76%) | *2 [rs4244285]; *3 [rs4986893] | Carriers=*2/*1 or *3/*1 or *3/*3 Noncarriers=*1/*1 | Not explicitly reported (however the authors cite a previous study from the same center)
Gladding191 2008 New Zealand 19463375 PRINC | TaqMan assay (Applied Biosystems, Foster City, CA) on ABI PRISM 7000 Sequence Detection System (Applied Biosystems, Foster City, CA) | NR NR NR | 60 patients participating in the PRINC study; analyses relevant to this KQ only included 43 patients (the genotyping success rate was not estimable) | *2 [rs4244285]; *4 [rs28399504]; *17 [rs12248560]; results on the *17 variant allele were not reported in analyses relevant to this KQ | Carriers=*2/*2 or *2/*4 or *4/*4 or *2/*1 or *4/*1 Noncarriers=*1/*1 | Not explicitly reported (results relevant to this KQ were not reported for all genotyped alleles)
Park264 2011 S. Korea 21345843 CILON-T | TaqMan fluorogenic 5' nuclease assay (ABI, Foster City, CA) for *2 and *3 SNaPshot multiplex kit (ABI PRISM) for *17 | NR NR NR | 483 (successful in 474/483=98.1%) [in 5 patients, the DNA amount was not enough to carry out the genotyping of all 3 SNPs, and genotyping of *2 failed in 3 patients and of *3 in 1 patient] | CYP2C19*2 [rs4244285]; *3 [rs4986893]; *17 [rs12248560] | Carriers of CYP2C19 LOF allele (*2 or *3 with any other allele) Noncarriers (*1/*1, *17/*17, or *1/*17) | NR
Bhatt85 2012 Multinational 22450429 CHARISMA | PCR-RFLP for *2 and *17 [no additional details reported]; TaqMan allelic discrimination assay for *3 | NR NR NR | 4924 samples were collected; 4862 had adequate DNA for analysis of which 4819 had “defined ancestry”; 4537 patients comprised the study population in main analysi | CYP2C19*2 [rs4244285]; *3 [rs4986893]; *17 [rs12248560 and rs11188072] | Poor metabolizers=*2/*2 or *2/*3 or *3/*3 Intermediate metabolizers=*2/*1 or *3/*1 Extensive metabolizers=*1/*1 Ultra metabolizers=*17/*1 or *17/*17 Unknown metabolizers=*2/*17 or *3/*17 | NR; results are presented for alternative classifications
Collet265 2011 France 21511218 CLOVIS-2 | TaqMan Validated SNP assays (900HT sequence Detection System; Applied Biosystems, Courtaboeuf, France) | NR NR NR | 43 heterozygous carriers were matched 1:1 with 43 wild-type homozygous patients; 8 homozygous carriers were matched 1:2 ratio with 16 wild-type homozygous patients (110 randomized patients); 106 patients completed both periods of the crossover study | *2, *3, *4, *5, *6 No *3, *5, or *6 alleles were detected in the sample | Carriers=*2/*1 or *2/*2 Noncarriers=*1/*1 | NR

* ABCB1 is a gene that encodes a protein involved in the intestinal absorption of clopidogrel.266

CURE = Clopidogrel in Unstable Angina to Prevent Recurrent Events; DM = diabetes mellitus; DMET = Drug Metabolizing Enzyme and Transporter; KQ = Key Question; NR = not reported; ONSET/OFFSET and RESPOND; PCI = percutaneous coronary intervention; PCR = polymerase chain reaction; PLATO = Platelet Inhibition and Patient Outcomes; PRINC = Plavix Response in Coronary Intervention; RCT = randomized controlled trial; RFLP = restriction fragment length polymorphism; TRITON-TIMI 38 = Trial to Assess Improvement in Therapeutic Outcomes by Optimizing Platelet Inhibition With Prasugrel–Thrombolysis in Myocardial Infarction 38; UK = United Kingdom.

###### Clinical Outcomes

Of the six studies (reported in seven publications) providing clinical outcome information, five85,99,104,109,258 were large (>1000 participants), multicenter, randomized trials of clopidogrel-based treatment versus alternative treatments (three compared aspirin plus clopidogrel vs. aspirin monotherapy, one compared aspirin plus clopidogrel vs. aspirin plus prasugrel, and one compared aspirin plus clopidogrel vs. aspirin plus ticagrelor); each of these had at least one outcome event. The sixth study260 was a small (126 patients) short-duration (30 days) trial comparing dual-antiplatelet therapy (aspirin plus clopidogrel) versus triple antiplatelet therapy (aspirin, clopidogrel, and cilostazol) for patients with myocardial infarction treated with “uneventful PCI.” Because of the short followup period and small sample size, no clinical events were observed in this study.

Of the five larger studies, one included patients with non–ST-elevation acute coronary syndromes (the CURE [Clopidogrel in Unstable Angina to Prevent Recurrent Events] trial), one involved patients with ST-elevation or non–ST-elevation acute coronary syndromes (the PLATO [Platelet inhibition and patient Outcomes] trial), one included those with moderate-to-high-risk acute coronary syndromes who were undergoing PCI (TRITON-TIMI 38 [Trial to Assess Improvement in Therapeutic Outcomes by Optimizing Platelet Inhibition with Prasugrel–Thrombolysis in Myocardial Infarction 38]), one included a mixed population of patients with manifest thrombotic disease (coronary, cerebrovascular, and peripheral artery disease) along with individuals at high risk for developing atherothrombotic disease (CHARISMA [Clopidogrel for High Atherothrombotic Risk and Ischemic Stabilization, Management and Avoidance] trial), and one enrolled patients with atrial fibrillation who were not candidates for vitamin K antagonist therapy (ACTIVE A).

CURE, CHARISMA, and ACTIVE A compared aspirin plus clopidogrel (at standard doses) with aspirin monotherapy; TRITON-TIMI 38 compared aspirin plus clopidogrel versus aspirin plus prasugrel; and the PLATO trial compared aspirin plus clopidogrel versus aspirin plus ticagrelor. All trials were designed and powered to detect the main effect of antiplatelet therapies but were not specifically powered to detect heterogeneity of treatment effects and included only a subsample of the overall study population in the genetic substudy. Furthermore, these studies were conducted in predominantly or exclusively white populations (>90 percent in all cases), who have a relatively low prevalence of CYP2C19 loss-of-function alleles, possibly limiting the applicability of the findings to non-white individuals. Perhaps more importantly, the relatively low prevalence of loss-of-function alleles in white populations limits the studies' power to detect associations of small or moderate magnitude, particularly under a recessive genetic model.

The genetic substudy of the CURE trial (of patients with non–ST-elevation acute coronary syndromes) reported treatment-effect estimates (for dual-antiplatelet therapy vs. aspirin monotherapy) among poor, intermediate, extensive, and ultra-metabolizers, as well as patients with genotypes of unknown functional status.109 (See Table 13 for definitions of genotype groups as implemented in the study.) Detailed results from time-to-event analyses for the two primary composite outcomes assessed in the study (cardiovascular death, nonfatal myocardial infarction, or stroke; and cardiovascular death, nonfatal myocardial infarction, stroke, recurrent ischemia, or hospitalization for unstable angina) are presented in Table 14. Overall, there was no statistically significant heterogeneity of treatment effects across genotype groups (p=0.12 and p=0.29 for the first and second composite outcomes, respectively) when patients were grouped into five genotype-defined categories (poor, intermediate, extensive, ultra, or unknown status). However, an analysis assessing effect modification between gain-of-function carrier status under a dominant model (i.e., one or two *17 alleles vs. none) and treatment (clopidogrel plus aspirin vs. aspirin monotherapy) produced a statistically significant result, such that *17 carriers had a larger reduction in cardiovascular events with clopidogrel, as compared with placebo, than did non-carriers (p=0.02 and p=0.03 for the first and second composite outcomes, respectively).

The genetic substudy of TRITON-TIMI 38 enrolled patients with moderate-to-high–risk acute coronary syndromes who underwent PCI.99 The substudy reported treatment-effect estimates (for clopidogrel plus aspirin vs. prasugrel plus aspirin) among carriers and noncarriers of reduced-function CY2C19 alleles (see Table 13 for definitions of genotype groups as implemented in the study). Detailed results on the study's primary efficacy endpoint (a composite of cardiovascular death, myocardial infarction, or stroke) at 15 months of followup are presented in Table 14. The study reported that there was statistically significant treatment-effect heterogeneity among genotype groups (p=0.046). Using the events reported in the study, we calculated that the odds ratio for the primary efficacy outcome among carriers of reduced-function alleles was 1.45 (95% CI 0.91, 2.31), compared with 0.81 (95% CI 0.60, 1.10) among noncarriers (p=0.04 for the difference between estimates). These results suggest that there was statistically significant treatment-effect heterogeneity between carriers and noncarriers in this study. The combined grouping of CYP2C19 and ABCB1^i^ genotypes was a statistically significant predictor of outcomes among patients receiving clopidogrel-based therapy (p=0.0018) but not among patients receiving prasugrel-based therapy (p=0.485). The study did not report results of a test of interaction between treatment and genotype groups defined jointly by CYP2C19 and ABCB1 status.

i ABCB1 is a gene that encodes a protein involved in the intestinal absorption of clopidogrel.266

The genetic substudy of the PLATO trial enrolled patients with acute coronary syndromes.118 The substudy reported treatment-effect estimates (for clopidogrel plus aspirin vs. ticagrelor plus aspirin) among carriers and noncarriers of loss-of-function CY2C19 alleles (see Table 18 for definitions of genotype groups as implemented in the study). Detailed results on the study's primary efficacy endpoint (a composite of cardiovascular death, myocardial infarction, or stroke) at 12 months of followup are presented in Table 19; there was no statistically significant treatment-effect heterogeneity between carriers of any loss-of-function allele and those without a loss-of-function allele (p=0.46). Neither were the results statistically significant for subcomponents of the primary outcome (cardiovascular death or myocardial infarction; interaction p=0.30). For definite stent thrombosis, the study did not provide an interaction p-value (because the number of events was too low); however, the treatment effect was similar in both genotype groups (same direction and magnitude; assuming normality for the log hazard ratio of each group defined by genotype, we calculated a z-score p-value of 0.76 for the relative hazard ratio). In addition, the combined grouping of CYP2C19 and ABCB1 genotypes did not yield a statistically significant interaction for the primary outcome between treatment group and genotype group (p=0.13).

Table 19 Clinical outcomes in studies of treatment-effect modification by CYP2C19 genotype status

Author Year Country PMID Study name (if available) | Outcome Definition (timing) | Subgroup defined by genotype | Treatment group | Number with outcome/total number within phenotype-treatment group | Comparison between treatments, within genotype groups ES (95% CI); p-value [statistical test] | Comparison of treatment effects across genotype groups
Pare109^*^ 2010 Multinational 20979470 CURE | First primary composite outcome=CV death, nonfatal MI, or stroke | Poor metabolizers | Dual antiplatelet therapy | 4/61 | HR=0.44 (95% CI, 0.12 to 1.61) [Cox proportional hazards model; adjusted for age, sex, ancestry] | p=0.12
Pare109^*^ 2010 Multinational 20979470 CURE | First primary composite outcome=CV death, nonfatal MI, or stroke | Poor metabolizers | Aspirin monotherapy | 6/55 | HR=0.44 (95% CI, 0.12 to 1.61) [Cox proportional hazards model; adjusted for age, sex, ancestry] | p=0.12
Pare109^*^ 2010 Multinational 20979470 CURE | First primary composite outcome=CV death, nonfatal MI, or stroke | Intermediate metabolizers | Dual antiplatelet therapy | 37/437 | HR=0.72 (95% CI, 0.48 to 1.10) [Cox proportional hazards model; adjusted for age, sex, ancestry] | p=0.12
Pare109^*^ 2010 Multinational 20979470 CURE | First primary composite outcome=CV death, nonfatal MI, or stroke | Intermediate metabolizers | Aspirin monotherapy | 54/442 | HR=0.72 (95% CI, 0.48 to 1.10) [Cox proportional hazards model; adjusted for age, sex, ancestry] | p=0.12
Pare109^*^ 2010 Multinational 20979470 CURE | First primary composite outcome=CV death, nonfatal MI, or stroke | Extensive metabolizers | Dual antiplatelet therapy | 112/1033 | HR=0.92 (95% CI, 0.71 to 1.19) [Cox proportional hazards model; adjusted for age, sex, ancestry] | p=0.12
Pare109^*^ 2010 Multinational 20979470 CURE | First primary composite outcome=CV death, nonfatal MI, or stroke | Extensive metabolizers | Aspirin monotherapy | 121/987 | HR=0.92 (95% CI, 0.71 to 1.19) [Cox proportional hazards model; adjusted for age, sex, ancestry] | p=0.12
Pare109^*^ 2010 Multinational 20979470 CURE | First primary composite outcome=CV death, nonfatal MI, or stroke | Ultra metabolizers | Dual antiplatelet therapy | 66/847 | HR=0.53 (95% CI, 0.39 to 0.72) [Cox proportional hazards model; adjusted for age, sex, ancestry] | p=0.12
Pare109^*^ 2010 Multinational 20979470 CURE | First primary composite outcome=CV death, nonfatal MI, or stroke | Ultra metabolizers | Aspirin monotherapy | 112/826 | HR=0.53 (95% CI, 0.39 to 0.72) [Cox proportional hazards model; adjusted for age, sex, ancestry] | p=0.12
Pare109^*^ 2010 Multinational 20979470 CURE | First primary composite outcome=CV death, nonfatal MI, or stroke | Unknown metabolizers | Dual antiplatelet therapy | 11/152 | HR=0.69 (95% CI, 0.33 to 1.47) [Cox proportional hazards model; adjusted for age, sex, ancestry] | p=0.12
Pare109^*^ 2010 Multinational 20979470 CURE | First primary composite outcome=CV death, nonfatal MI, or stroke | Unknown metabolizers | Aspirin monotherapy | 18/176 | HR=0.69 (95% CI, 0.33 to 1.47) [Cox proportional hazards model; adjusted for age, sex, ancestry] | p=0.12
Pare109^*^ 2010 Multinational 20979470 CURE | Second primary composite outcome=CV death, nonfatal MI, or stroke, recurrent ischemia, or hospitalization for UA | Poor metabolizers | Dual antiplatelet therapy | 13/61 | HR=0.93 (95% CI, 0.41 to 2.11) [Cox proportional hazards model; adjusted for age, sex, ancestry] | p=0.29
Pare109^*^ 2010 Multinational 20979470 CURE | Second primary composite outcome=CV death, nonfatal MI, or stroke, recurrent ischemia, or hospitalization for UA | Poor metabolizers | Aspirin monotherapy | 11/55 | HR=0.93 (95% CI, 0.41 to 2.11) [Cox proportional hazards model; adjusted for age, sex, ancestry] | p=0.29
Pare109^*^ 2010 Multinational 20979470 CURE | Second primary composite outcome=CV death, nonfatal MI, or stroke, recurrent ischemia, or hospitalization for UA | Intermediate metabolizers | Dual antiplatelet therapy | 70/437 | HR=0.87 (95% CI, 0.63 to 1.19) [Cox proportional hazards model; adjusted for age, sex, ancestry] | p=0.29
Pare109^*^ 2010 Multinational 20979470 CURE | Second primary composite outcome=CV death, nonfatal MI, or stroke, recurrent ischemia, or hospitalization for UA | Intermediate metabolizers | Aspirin monotherapy | 84/442 | HR=0.87 (95% CI, 0.63 to 1.19) [Cox proportional hazards model; adjusted for age, sex, ancestry] | p=0.29
Pare109^*^ 2010 Multinational 20979470 CURE | Second primary composite outcome=CV death, nonfatal MI, or stroke, recurrent ischemia, or hospitalization for UA | Extensive metabolizers | Dual antiplatelet therapy | 193/1033 | HR=0.90 (95% CI, 0.74 to 1.10) [Cox proportional hazards model; adjusted for age, sex, ancestry] | p=0.29
Pare109^*^ 2010 Multinational 20979470 CURE | Second primary composite outcome=CV death, nonfatal MI, or stroke, recurrent ischemia, or hospitalization for UA | Extensive metabolizers | Aspirin monotherapy | 206/987 | HR=0.90 (95% CI, 0.74 to 1.10) [Cox proportional hazards model; adjusted for age, sex, ancestry] | p=0.29
Pare109^*^ 2010 Multinational 20979470 CURE | Second primary composite outcome=CV death, nonfatal MI, or stroke, recurrent ischemia, or hospitalization for UA | Ultra metabolizers | Dual antiplatelet therapy | 123/847 | HR=0.68 (95% CI, 0.53 to 0.85) [Cox proportional hazards model; adjusted for age, sex, ancestry] | p=0.29
Pare109^*^ 2010 Multinational 20979470 CURE | Second primary composite outcome=CV death, nonfatal MI, or stroke, recurrent ischemia, or hospitalization for UA | Ultra metabolizers | Aspirin monotherapy | 167/826 | HR=0.68 (95% CI, 0.53 to 0.85) [Cox proportional hazards model; adjusted for age, sex, ancestry] | p=0.29
Pare109^*^ 2010 Multinational 20979470 CURE | Second primary composite outcome=CV death, nonfatal MI, or stroke, recurrent ischemia, or hospitalization for UA | Unknown metabolizers | Dual antiplatelet therapy | 19/152 | HR=0.63 (95% CI, 0.36 to 1.11) [Cox proportional hazards model; adjusted for age, sex, ancestry] | p=0.29
Pare109^*^ 2010 Multinational 20979470 CURE | Second primary composite outcome=CV death, nonfatal MI, or stroke, recurrent ischemia, or hospitalization for UA | Unknown metabolizers | Aspirin monotherapy | 34/176 | HR=0.63 (95% CI, 0.36 to 1.11) [Cox proportional hazards model; adjusted for age, sex, ancestry] | p=0.29
Pare109 2010 Multinational 20979470 ACTIVE A | Primary efficacy outcome=any major vascular event (stroke, systemic embolism outside the CNS, MI, death from vascular causes) | Poor metabolizers | Dual antiplatelet therapy | 1/9 | HR=0.74 (95% CI, 0.05 to 12.04) [Cox proportional hazards model; adjusted for age, sex] | p=0.32
Pare109 2010 Multinational 20979470 ACTIVE A | Primary efficacy outcome=any major vascular event (stroke, systemic embolism outside the CNS, MI, death from vascular causes) | Poor metabolizers | Aspirin monotherapy | 1/12 | HR=0.74 (95% CI, 0.05 to 12.04) [Cox proportional hazards model; adjusted for age, sex] | p=0.32
Pare109 2010 Multinational 20979470 ACTIVE A | Primary efficacy outcome=any major vascular event (stroke, systemic embolism outside the CNS, MI, death from vascular causes) | Intermediate metabolizers | Dual antiplatelet therapy | 21/93 | HR=0.85 (95% CI, 0.47 to 1.54) [Cox proportional hazards model; adjusted for age, sex] | p=0.32
Pare109 2010 Multinational 20979470 ACTIVE A | Primary efficacy outcome=any major vascular event (stroke, systemic embolism outside the CNS, MI, death from vascular causes) | Intermediate metabolizers | Aspirin monotherapy | 24/92 | HR=0.85 (95% CI, 0.47 to 1.54) [Cox proportional hazards model; adjusted for age, sex] | p=0.32
Pare109 2010 Multinational 20979470 ACTIVE A | Primary efficacy outcome=any major vascular event (stroke, systemic embolism outside the CNS, MI, death from vascular causes) | Extensive metabolizers | Dual antiplatelet therapy | 34/199 | HR=0.55 (95% CI, 0.36 to 0.83) [Cox proportional hazards model; adjusted for age, sex] | p=0.32
Pare109 2010 Multinational 20979470 ACTIVE A | Primary efficacy outcome=any major vascular event (stroke, systemic embolism outside the CNS, MI, death from vascular causes) | Extensive metabolizers | Aspirin monotherapy | 68/235 | HR=0.55 (95% CI, 0.36 to 0.83) [Cox proportional hazards model; adjusted for age, sex] | p=0.32
Pare109 2010 Multinational 20979470 ACTIVE A | Primary efficacy outcome=any major vascular event (stroke, systemic embolism outside the CNS, MI, death from vascular causes) | Ultra metabolizers | Dual antiplatelet therapy | 49/222 | HR=0.97 (95% CI, 0.65 to 1.45) [Cox proportional hazards model; adjusted for age, sex] | p=0.32
Pare109 2010 Multinational 20979470 ACTIVE A | Primary efficacy outcome=any major vascular event (stroke, systemic embolism outside the CNS, MI, death from vascular causes) | Ultra metabolizers | Aspirin monotherapy | 50/200 | HR=0.97 (95% CI, 0.65 to 1.45) [Cox proportional hazards model; adjusted for age, sex] | p=0.32
Pare109 2010 Multinational 20979470 ACTIVE A | Primary efficacy outcome=any major vascular event (stroke, systemic embolism outside the CNS, MI, death from vascular causes) | Unknown metabolizers | Dual antiplatelet therapy | 7/37 | HR=0.55 (95% CI, 0.21 to 1.47) [Cox proportional hazards model; adjusted for age, sex] | p=0.32
Pare109 2010 Multinational 20979470 ACTIVE A | Primary efficacy outcome=any major vascular event (stroke, systemic embolism outside the CNS, MI, death from vascular causes) | Unknown metabolizers | Aspirin monotherapy | 10/35 | HR=0.55 (95% CI, 0.21 to 1.47) [Cox proportional hazards model; adjusted for age, sex] | p=0.32
Mega99,258^†^ 2009 Multinational 19106084 19414633 TRITON-TIMI 38 | Primary efficacy outcome=CV death, MI, or stroke; analysis for this outcome was performed base on intention-to-treat (as assigned) | Carriers of a reduced function allele | Clopidogrel + aspirin | 46/395 | OR=1.45 (95% CI, 0.91 to 2.31) [calculated values] | p=0.046 based on a test-for-interaction; p=0.04 [calculated from z-test between odds ratios]
Mega99,258^†^ 2009 Multinational 19106084 19414633 TRITON-TIMI 38 | Primary efficacy outcome=CV death, MI, or stroke; analysis for this outcome was performed base on intention-to-treat (as assigned) | Carriers of a reduced function allele | Prasugrel + aspirin | 34/407 | OR=1.45 (95% CI, 0.91 to 2.31) [calculated values] | p=0.046 based on a test-for-interaction; p=0.04 [calculated from z-test between odds ratios]
Mega99,258^†^ 2009 Multinational 19106084 19414633 TRITON-TIMI 38 | Primary efficacy outcome=CV death, MI, or stroke; analysis for this outcome was performed base on intention-to-treat (as assigned) | Noncarriers | Clopidogrel + aspirin | 83/1064 | OR=0.81 (95% CI, 0.60 to 1.10) [calculated values] | p=0.046 based on a test-for-interaction; p=0.04 [calculated from z-test between odds ratios]
Mega99,258^†^ 2009 Multinational 19106084 19414633 TRITON-TIMI 38 | Primary efficacy outcome=CV death, MI, or stroke; analysis for this outcome was performed base on intention-to-treat (as assigned) | Noncarriers | Prasugrel + aspirin | 99/1048 | OR=0.81 (95% CI, 0.60 to 1.10) [calculated values] | p=0.046 based on a test-for-interaction; p=0.04 [calculated from z-test between odds ratios]
Mega99,258 2010 Multinational 20801494 TRITON-TIMI 38 | Primary efficacy outcome=CV death, MI, or stroke; analysis for this outcome was performed base on intention-to-treat (as assigned) at 15 mo | CYP2C19 reduced-function alleles and ABCB1 TT carriers^††^ | Clopidogrel + aspirin | 17/125 | OR for the treatment effect among CYP2C19 reduced-function allele noncarriers and ABCB1 CC/CT carriers^††^=NR [not possible to calculate] OR for the treatment effect among CYP2C19 reduced-function allele carriers or ABCB1 TT carriers=NR [not possible to calculate] | p-value for the genotype effect across genotypes=0.0018 (clopidogrel-treated); 0.485 (prasugrel-treated)
Mega99,258 2010 Multinational 20801494 TRITON-TIMI 38 | Primary efficacy outcome=CV death, MI, or stroke; analysis for this outcome was performed base on intention-to-treat (as assigned) at 15 mo | CYP2C19 reduced-function alleles and ABCB1 TT carriers^††^ | Prasugrel + aspirin | NR/110 | | p-value for the genotype effect across genotypes=0.0018 (clopidogrel-treated); 0.485 (prasugrel-treated)
Mega99,258 2010 Multinational 20801494 TRITON-TIMI 38 | Primary efficacy outcome=CV death, MI, or stroke; analysis for this outcome was performed base on intention-to-treat (as assigned) at 15 mo | CYP2C19 reduced-function allele noncarriers and ABCB1 TT carriers^††^ | Clopidogrel + aspirin | 35/288 | | p-value for the genotype effect across genotypes=0.0018 (clopidogrel-treated); 0.485 (prasugrel-treated)
Mega99,258 2010 Multinational 20801494 TRITON-TIMI 38 | Primary efficacy outcome=CV death, MI, or stroke; analysis for this outcome was performed base on intention-to-treat (as assigned) at 15 mo | CYP2C19 reduced-function allele noncarriers and ABCB1 TT carriers^††^ | Prasugrel + aspirin | NR/278 | | p-value for the genotype effect across genotypes=0.0018 (clopidogrel-treated); 0.485 (prasugrel-treated)
Mega99,258 2010 Multinational 20801494 TRITON-TIMI 38 | Primary efficacy outcome=CV death, MI, or stroke; analysis for this outcome was performed base on intention-to-treat (as assigned) at 15 mo | CYP2C19 reduced-function alleles and ABCB1 CC/CT carriers^††^ | Clopidogrel + aspirin | 29/268 | | p-value for the genotype effect across genotypes=0.0018 (clopidogrel-treated); 0.485 (prasugrel-treated)
Mega99,258 2010 Multinational 20801494 TRITON-TIMI 38 | Primary efficacy outcome=CV death, MI, or stroke; analysis for this outcome was performed base on intention-to-treat (as assigned) at 15 mo | CYP2C19 reduced-function alleles and ABCB1 CC/CT carriers^††^ | Prasugrel + aspirin | NR/296 | | p-value for the genotype effect across genotypes=0.0018 (clopidogrel-treated); 0.485 (prasugrel-treated)
Mega99,258 2010 Multinational 20801494 TRITON-TIMI 38 | Primary efficacy outcome=CV death, MI, or stroke; analysis for this outcome was performed base on intention-to-treat (as assigned) at 15 mo | CYP2C19 reduced-function allele noncarriers and ABCB1 CC/CT carriers^††^ | Clopidogrel + aspirin | 48/773 | | p-value for the genotype effect across genotypes=0.0018 (clopidogrel-treated); 0.485 (prasugrel-treated)
Mega99,258 2010 Multinational 20801494 TRITON-TIMI 38 | Primary efficacy outcome=CV death, MI, or stroke; analysis for this outcome was performed base on intention-to-treat (as assigned) at 15 mo | CYP2C19 reduced-function allele noncarriers and ABCB1 CC/CT carriers^††^ | Prasugrel + aspirin | NR/767 | | p-value for the genotype effect across genotypes=0.0018 (clopidogrel-treated); 0.485 (prasugrel-treated)
Kim260 2011 S. Korea 21511217 ACCELAMI2C19 | Major cardiovascular events=death, nonfatal MI, or urgent target vessel revascularization | Carriers | Triple therapy (adjunctive cilostazol) | 0/39 | OR not estimable | NA
Kim260 2011 S. Korea 21511217 ACCELAMI2C19 | Major cardiovascular events=death, nonfatal MI, or urgent target vessel revascularization | Carriers | High-maintenance dose clopidogrel | 0/38 | OR not estimable | NA
Kim260 2011 S. Korea 21511217 ACCELAMI2C19 | Major cardiovascular events=death, nonfatal MI, or urgent target vessel revascularization | Noncarriers | Triple therapy (adjunctive cilostazol) | 0/25 | OR not estimable | NA
Kim260 2011 S. Korea 21511217 ACCELAMI2C19 | Major cardiovascular events=death, nonfatal MI, or urgent target vessel revascularization | Noncarriers | High-maintenance dose clopidogrel | 0/24 | OR not estimable | NA
Wallentin104 2010 Multinational 20801498 PLATO | Primary composite outcome: CV death, MI, or stroke: 30 d | Any CYP2C19 LOF allele (*2–*8) | Ticagrelor + aspirin | NR/1384 | HR=0.73 (95% CI, 0.52 to 1.03) [Cox regression with adjustment for ethnic group, sex, use of PPI, aspirin dose, smoking status, and diabetes] | 0.20
Wallentin104 2010 Multinational 20801498 PLATO | Primary composite outcome: CV death, MI, or stroke: 30 d | Any CYP2C19 LOF allele (*2–*8) | Clopidogrel+ aspirin | NR/1388 | HR=0.73 (95% CI, 0.52 to 1.03) [Cox regression with adjustment for ethnic group, sex, use of PPI, aspirin dose, smoking status, and diabetes] | 0.20
Wallentin104 2010 Multinational 20801498 PLATO | Primary composite outcome: CV death, MI, or stroke: 30 d | No CYP2C19 LOF allele (*1 or *17) | Ticagrelor + aspirin | NR/3554 | HR=0.96 (95% CI, 0.76 to 1.22) [Cox regression with adjustment for ethnic group, sex, use of PPI, aspirin dose, smoking status, and diabetes] | 0.20
Wallentin104 2010 Multinational 20801498 PLATO | Primary composite outcome: CV death, MI, or stroke: 30 d | No CYP2C19 LOF allele (*1 or *17) | Clopidogrel+ aspirin | NR/3516 | HR=0.96 (95% CI, 0.76 to 1.22) [Cox regression with adjustment for ethnic group, sex, use of PPI, aspirin dose, smoking status, and diabetes] | 0.20
Wallentin104 2010 Multinational 20801498 PLATO | Primary composite outcome: CV death, MI, or stroke: 12 mo | Any CYP2C19 LOF allele (*2–*8) | Ticagrelor + aspirin | 115/1384 | HR=0.77 (95% CI, 0.60 to 0.99) [Cox regression with adjustment for ethnic group, sex, use of PPI, aspirin dose, smoking status, and diabetes] | 0.46
Wallentin104 2010 Multinational 20801498 PLATO | Primary composite outcome: CV death, MI, or stroke: 12 mo | Any CYP2C19 LOF allele (*2–*8) | Clopidogrel+ aspirin | 149/1388 | HR=0.77 (95% CI, 0.60 to 0.99) [Cox regression with adjustment for ethnic group, sex, use of PPI, aspirin dose, smoking status, and diabetes] | 0.46
Wallentin104 2010 Multinational 20801498 PLATO | Primary composite outcome: CV death, MI, or stroke: 12 mo | No CYP2C19 LOF allele (*1 or *17) | Ticagrelor + aspirin | 296/3554 | HR=0.86 (95% CI, 0.74 to 1.01) [Cox regression with adjustment for ethnic group, sex, use of PPI, aspirin dose, smoking status, and diabetes] | 0.46
Wallentin104 2010 Multinational 20801498 PLATO | Primary composite outcome: CV death, MI, or stroke: 12 mo | No CYP2C19 LOF allele (*1 or *17) | Clopidogrel+ aspirin | 332/3515 | HR=0.86 (95% CI, 0.74 to 1.01) [Cox regression with adjustment for ethnic group, sex, use of PPI, aspirin dose, smoking status, and diabetes] | 0.46
Wallentin104 2010 Multinational 20801498 PLATO | Primary composite outcome: CV death, MI, or stroke: 12 mo | Any CYP2C19 LOF allele (*2–*8) + ABCB1 C/C^††^ | Ticagrelor + aspirin | NR/2253 | HR=0.75 (95% CI, 0.62 to 0.91) [Cox regression with adjustment for ethnic group, sex, use of PPI, aspirin dose, smoking status, and diabetes] | 0.13
Wallentin104 2010 Multinational 20801498 PLATO | Primary composite outcome: CV death, MI, or stroke: 12 mo | Any CYP2C19 LOF allele (*2–*8) + ABCB1 C/C^††^ | Clopidogrel+ aspirin | NR/2248 | HR=0.75 (95% CI, 0.62 to 0.91) [Cox regression with adjustment for ethnic group, sex, use of PPI, aspirin dose, smoking status, and diabetes] | 0.13
Wallentin104 2010 Multinational 20801498 PLATO | Primary composite outcome: CV death, MI, or stroke: 12 mo | No CYP2C19 LOF allele (*1 or *17) + ABCB1 C/T or T/T^††^ | Ticagrelor + aspirin | NR/2710 | HR=0.92 (95% CI, 0.77 to 1.11) [Cox regression with adjustment for ethnic group, sex, use of PPI, aspirin dose, smoking status, and diabetes] | 0.13
Wallentin104 2010 Multinational 20801498 PLATO | Primary composite outcome: CV death, MI, or stroke: 12 mo | No CYP2C19 LOF allele (*1 or *17) + ABCB1 C/T or T/T^††^ | Clopidogrel+ aspirin | NR/2698 | HR=0.92 (95% CI, 0.77 to 1.11) [Cox regression with adjustment for ethnic group, sex, use of PPI, aspirin dose, smoking status, and diabetes] | 0.13
Wallentin104 2010 Multinational 20801498 PLATO | CV death or MI | Any CYP2C19 LOF allele (*2–*8) | Ticagrelor + aspirin | 102/1384 | HR=0.73 (95% CI, 0.57 to 0.95) [Cox regression with adjustment for ethnic group, sex, use of PPI, aspirin dose, smoking status, and diabetes] | 0.30
Wallentin104 2010 Multinational 20801498 PLATO | CV death or MI | Any CYP2C19 LOF allele (*2–*8) | Clopidogrel+ aspirin | 138/1388 | HR=0.73 (95% CI, 0.57 to 0.95) [Cox regression with adjustment for ethnic group, sex, use of PPI, aspirin dose, smoking status, and diabetes] | 0.30
Wallentin104 2010 Multinational 20801498 PLATO | CV death or MI | No CYP2C19 LOF allele (*1 or *17) | Ticagrelor + aspirin | 273/3554 | HR=0.86 (95% CI, 0.74 to 1.01) [Cox regression with adjustment for ethnic group, sex, use of PPI, aspirin dose, smoking status, and diabetes] | 0.30
Wallentin104 2010 Multinational 20801498 PLATO | CV death or MI | No CYP2C19 LOF allele (*1 or *17) | Clopidogrel+ aspirin | 306/3516 | HR=0.86 (95% CI, 0.74 to 1.01) [Cox regression with adjustment for ethnic group, sex, use of PPI, aspirin dose, smoking status, and diabetes] | 0.30
Wallentin104 2010 Multinational 20801498 PLATO | Definite stent thrombosis (in patients who underwent stenting) | Any CYP2C19 LOF allele (*2–*8) | Ticagrelor + aspirin | 15/943 | HR=0.71 (95% CI, 0.36 to 1.37) [Cox regression with adjustment for ethnic group, sex, use of PPI, aspirin dose, smoking status, and diabetes] | NR (no. of events too low to calculate)
Wallentin104 2010 Multinational 20801498 PLATO | Definite stent thrombosis (in patients who underwent stenting) | Any CYP2C19 LOF allele (*2–*8) | Clopidogrel+ aspirin | 21/934 | HR=0.71 (95% CI, 0.36 to 1.37) [Cox regression with adjustment for ethnic group, sex, use of PPI, aspirin dose, smoking status, and diabetes] | NR (no. of events too low to calculate)
Wallentin104 2010 Multinational 20801498 PLATO | Definite stent thrombosis (in patients who underwent stenting) | No CYP2C19 LOF allele (*1 or *17) | Ticagrelor + aspirin | 22/2341 | HR=0.62 (95% CI, 0.36 to 1.05) [Cox regression with adjustment for ethnic group, sex, use of PPI, aspirin dose, smoking status, and diabetes] | NR (no. of events too low to calculate)
Wallentin104 2010 Multinational 20801498 PLATO | Definite stent thrombosis (in patients who underwent stenting) | No CYP2C19 LOF allele (*1 or *17) | Clopidogrel + aspirin | 35/2300 | HR=0.62 (95% CI, 0.36 to 1.05) [Cox regression with adjustment for ethnic group, sex, use of PPI, aspirin dose, smoking status, and diabetes] | NR (no. of events too low to calculate)
Bhatt85 2012 Multinational 22450429 CHARISMA | Primary composite outcome: first occurrence of non-fatal or fatal MI, non-fatal or fatal stroke, or cardiovascular death | Poor metabolizers | Clopidogrel + aspirin | 7/52 | HR=1.86 (95% CI, 0.53 to 6.55) [Cox regression with adjustment for age, sex, inclusion criteria (symptomatic vs. asymptomatic), use of statins, use of calcium channel blockers, and cigarette usage] | 0.621
Bhatt85 2012 Multinational 22450429 CHARISMA | Primary composite outcome: first occurrence of non-fatal or fatal MI, non-fatal or fatal stroke, or cardiovascular death | Poor metabolizers | Aspirin + placebo | 4/48 | HR=1.86 (95% CI, 0.53 to 6.55) [Cox regression with adjustment for age, sex, inclusion criteria (symptomatic vs. asymptomatic), use of statins, use of calcium channel blockers, and cigarette usage] | 0.621
Bhatt85 2012 Multinational 22450429 CHARISMA | Primary composite outcome: first occurrence of non-fatal or fatal MI, non-fatal or fatal stroke, or cardiovascular death | Intermediate metabolizers | Clopidogrel + aspirin | 29/458 | HR=1.31 (95% CI, 0.75 to 2.30) [Cox regression with adjustment for age, sex, inclusion criteria (symptomatic vs. asymptomatic), use of statins, use of calcium channel blockers, and cigarette usage] | 0.621
Bhatt85 2012 Multinational 22450429 CHARISMA | Primary composite outcome: first occurrence of non-fatal or fatal MI, non-fatal or fatal stroke, or cardiovascular death | Intermediate metabolizers | Aspirin + placebo | 21/445 | HR=1.31 (95% CI, 0.75 to 2.30) [Cox regression with adjustment for age, sex, inclusion criteria (symptomatic vs. asymptomatic), use of statins, use of calcium channel blockers, and cigarette usage] | 0.621
Bhatt85 2012 Multinational 22450429 CHARISMA | Primary composite outcome: first occurrence of non-fatal or fatal MI, non-fatal or fatal stroke, or cardiovascular death | Extensive metabolizers | Clopidogrel + aspirin | 52/886 | HR=1.16 (95% CI, 0.78 to 1.71) [Cox regression with adjustment for age, sex, inclusion criteria (symptomatic vs. asymptomatic), use of statins, use of calcium channel blockers, and cigarette usage] | 0.621
Bhatt85 2012 Multinational 22450429 CHARISMA | Primary composite outcome: first occurrence of non-fatal or fatal MI, non-fatal or fatal stroke, or cardiovascular death | Extensive metabolizers | Aspirin + placebo | 49/920 | HR=1.16 (95% CI, 0.78 to 1.71) [Cox regression with adjustment for age, sex, inclusion criteria (symptomatic vs. asymptomatic), use of statins, use of calcium channel blockers, and cigarette usage] | 0.621
Bhatt85 2012 Multinational 22450429 CHARISMA | Primary composite outcome: first occurrence of non-fatal or fatal MI, non-fatal or fatal stroke, or cardiovascular death | Ultra metabolizers | Clopidogrel + aspirin | 40/716 | HR=0.82 (95% CI, 0.54 to 1.24) [Cox regression with adjustment for age, sex, inclusion criteria (symptomatic vs. asymptomatic), use of statins, use of calcium channel blockers, and cigarette usage] | 0.621
Bhatt85 2012 Multinational 22450429 CHARISMA | Primary composite outcome: first occurrence of non-fatal or fatal MI, non-fatal or fatal stroke, or cardiovascular death | Ultra metabolizers | | 48/715 | HR=0.82 (95% CI, 0.54 to 1.24) [Cox regression with adjustment for age, sex, inclusion criteria (symptomatic vs. asymptomatic), use of statins, use of calcium channel blockers, and cigarette usage] | 0.621
Bhatt85 2012 Multinational 22450429 CHARISMA | Primary composite outcome: first occurrence of non-fatal or fatal MI, non-fatal or fatal stroke, or cardiovascular death | Unknown metabolizers | Clopidogrel + aspirin | 12/156 | HR=1.30 (95% CI, 0.56 to 3.04) [Cox regression with adjustment for age, sex, inclusion criteria (symptomatic vs. asymptomatic), use of statins, use of calcium channel blockers, and cigarette usage] | 0.621
Bhatt85 2012 Multinational 22450429 CHARISMA | Primary composite outcome: first occurrence of non-fatal or fatal MI, non-fatal or fatal stroke, or cardiovascular death | Unknown metabolizers | Aspirin + placebo | 10/145 | HR=1.30 (95% CI, 0.56 to 3.04) [Cox regression with adjustment for age, sex, inclusion criteria (symptomatic vs. asymptomatic), use of statins, use of calcium channel blockers, and cigarette usage] | 0.621
Bhatt85 2012 Multinational 22450429 CHARISMA | Secondary composite outcome: first occurrence of non-fatal or fatal MI, non-fatal or fatal stroke, cardiovascular death, hospitalization for unstable angina, TIA, or revascularization procedure | Poor metabolizers | Clopidogrel + aspirin | 12/52 | HR=1.04 (95% CI, 0.45 to 2.43) [Cox regression with adjustment for age, sex, inclusion criteria (symptomatic vs. asymptomatic), use of statins, use of calcium channel blockers, and cigarette usage] | 0.895
Bhatt85 2012 Multinational 22450429 CHARISMA | Secondary composite outcome: first occurrence of non-fatal or fatal MI, non-fatal or fatal stroke, cardiovascular death, hospitalization for unstable angina, TIA, or revascularization procedure | Poor metabolizers | Aspirin + placebo | 10/48 | HR=1.04 (95% CI, 0.45 to 2.43) [Cox regression with adjustment for age, sex, inclusion criteria (symptomatic vs. asymptomatic), use of statins, use of calcium channel blockers, and cigarette usage] | 0.895
Bhatt85 2012 Multinational 22450429 CHARISMA | Secondary composite outcome: first occurrence of non-fatal or fatal MI, non-fatal or fatal stroke, cardiovascular death, hospitalization for unstable angina, TIA, or revascularization procedure | Intermediate metabolizers | Clopidogrel + aspirin | 82/458 | HR=1.09 (95% CI, 0.80 to 1.50) [Cox regression with adjustment for age, sex, inclusion criteria (symptomatic vs. asymptomatic), use of statins, use of calcium channel blockers, and cigarette usage] | 0.895
Bhatt85 2012 Multinational 22450429 CHARISMA | Secondary composite outcome: first occurrence of non-fatal or fatal MI, non-fatal or fatal stroke, cardiovascular death, hospitalization for unstable angina, TIA, or revascularization procedure | Intermediate metabolizers | Aspirin + placebo | 73/445 | HR=1.09 (95% CI, 0.80 to 1.50) [Cox regression with adjustment for age, sex, inclusion criteria (symptomatic vs. asymptomatic), use of statins, use of calcium channel blockers, and cigarette usage] | 0.895
Bhatt85 2012 Multinational 22450429 CHARISMA | Secondary composite outcome: first occurrence of non-fatal or fatal MI, non-fatal or fatal stroke, cardiovascular death, hospitalization for unstable angina, TIA, or revascularization procedure | Extensive metabolizers | Clopidogrel + aspirin | 145/886 | HR=0.95 (95% CI, 0.76 to 1.19) [Cox regression with adjustment for age, sex, inclusion criteria (symptomatic vs. asymptomatic), use of statins, use of calcium channel blockers, and cigarette usage] | 0.895
Bhatt85 2012 Multinational 22450429 CHARISMA | Secondary composite outcome: first occurrence of non-fatal or fatal MI, non-fatal or fatal stroke, cardiovascular death, hospitalization for unstable angina, TIA, or revascularization procedure | Extensive metabolizers | | 161/920 | HR=0.95 (95% CI, 0.76 to 1.19) [Cox regression with adjustment for age, sex, inclusion criteria (symptomatic vs. asymptomatic), use of statins, use of calcium channel blockers, and cigarette usage] | 0.895
Bhatt85 2012 Multinational 22450429 CHARISMA | Secondary composite outcome: first occurrence of non-fatal or fatal MI, non-fatal or fatal stroke, cardiovascular death, hospitalization for unstable angina, TIA, or revascularization procedure | Ultra metabolizers | Clopidogrel + aspirin | 124/716 | HR=1.01 (95% CI, 0.79 to 1.30) [Cox regression with adjustment for age, sex, inclusion criteria (symptomatic vs. asymptomatic), use of statins, use of calcium channel blockers, and cigarette usage] | 0.895
Bhatt85 2012 Multinational 22450429 CHARISMA | Secondary composite outcome: first occurrence of non-fatal or fatal MI, non-fatal or fatal stroke, cardiovascular death, hospitalization for unstable angina, TIA, or revascularization procedure | Ultra metabolizers | Aspirin + placebo | 121/715 | HR=1.01 (95% CI, 0.79 to 1.30) [Cox regression with adjustment for age, sex, inclusion criteria (symptomatic vs. asymptomatic), use of statins, use of calcium channel blockers, and cigarette usage] | 0.895
Bhatt85 2012 Multinational 22450429 CHARISMA | Secondary composite outcome: first occurrence of non-fatal or fatal MI, non-fatal or fatal stroke, cardiovascular death, hospitalization for unstable angina, TIA, or revascularization procedure | Unknown metabolizers | Clopidogrel + aspirin | 23/156 | HR=0.83 (95% CI, 0.47 to 1.45) [Cox regression with adjustment for age, sex, inclusion criteria (symptomatic vs. asymptomatic), use of statins, use of calcium channel blockers, and cigarette usage] | 0.895
Bhatt85 2012 Multinational 22450429 CHARISMA | Secondary composite outcome: first occurrence of non-fatal or fatal MI, non-fatal or fatal stroke, cardiovascular death, hospitalization for unstable angina, TIA, or revascularization procedure | Unknown metabolizers | Aspirin + placebo | 27/145 | HR=0.83 (95% CI, 0.47 to 1.45) [Cox regression with adjustment for age, sex, inclusion criteria (symptomatic vs. asymptomatic), use of statins, use of calcium channel blockers, and cigarette usage] | 0.895

* The authors reported extensive subgroup and sensitivity analyses across different genotype groupings and after including or excluding subgroups of patients by race or ethnicity. The results relevant to treatment effect heterogeneity from these analyses are presented in the text of this section.

† Patients with genotypes of “unclear” functional significance were excluded.

†† ABCB1 is a gene that encodes a protein involved in the intestinal absorption of clopidogrel.266

ACTIVE A Trial = Atrial Fibrillation Clopidogrel Trial with Irbesartan for Prevention of Vascular Events A trial; CABG = coronary artery bypass grafting; CHARISMA = Clopidogrel for High Atherothrombotic Risk and Ischemic Stabilization, Management, and Avoidance; CI = confidence interval; CNS = central nervous system; CURE Trial = Clopidogrel in Unstable Angina to Prevent Recurrent Events trial; CV = cardiovascular; d = day; ES = effect size; GOF = gain of function; HR = hazard ratio; LOF = loss of function; MI = myocardial infarction; mo = month; NA = not applicable; NR = not reported; OR = odds ratio; PLATO trial = PLATelet inhibition and patient Outcomes trial; PPI = proton-pump inhibitor; TIA = transient ischemic attack; TRITON TIMI 38 = Trial to Assess Improvement in Therapeutic Outcomes by Optimizing Platelet Inhibition with Prasugrel–Thrombolysis In Myocardial Infarction 38.

The genetic substudy of the CHARISMA trial enrolled patients with known atherothrombotic disease (including coronary, cerebrovascular, and peripheral artery disease), along with individuals at high risk for developing atherothrombotic disease.85 Patients were randomized to receive clopidogrel plus aspirin or aspirin plus placebo. Results from time-to-event analyses were reported for the treatment effect among poor, intermediate, extensive, and ultra-metabolizers, as well as patients with genotypes of unknown functional status (see Table 18 for definitions of genotype groups as implemented in the study). Detailed results regarding the primary composite outcome of myocardial infarction (non-fatal or fatal), stroke (non-fatal or fatal), or cardiovascular death are presented in Table 19. Overall, there was no significant heterogeneity of treatment effects across genotype groups (p=0.21). Similar results were obtained for the secondary outcome (p=0.55; for the composite outcome of myocardial infarction (non-fatal or fatal), stroke (non-fatal or fatal), cardiovascular death, hospitalization for unstable angina, transient ischemic attack, or revascularization procedure).

Finally, the genetic substudy of the ACTIVE A trial enrolled patients with atrial fibrillation and at least one additional risk factor for stroke who were not considered appropriate candidates for vitamin K–antagonist therapy. Patients were randomized to aspirin monotherapy or dual-antiplatelet therapy with aspirin and clopidogrel. Results from time-to-event analyses were reported for the treatment effect among poor, intermediate, extensive, and ultra-metabolizers, as well as patients with genotypes of unknown functional status (see Table 18 for definitions of genotype groups as implemented in the study). Detailed results regarding the composite outcome of any major vascular event (stroke, systemic embolism outside the central nervous system, myocardial infarction, or death from vascular causes) are presented in Table 19. Overall, there was no significant heterogeneity of treatment effects across genotype groups (p=0.32).

Because of the large differences in included populations, treatments compared, and exposure and outcome definitions among studies reporting on treatment-effect modification by CYP2C19 variants on clinical outcomes, we did not perform a meta-analysis. Given that the drugs compared (clopidogrel, prasugrel, and ticagrelor) have different mechanisms of action, it is plausible that interaction effects could have different magnitudes or directions across studies. For purposes of illustration, we used the counts reported in the studies to compare the treatment effect among carriers of CYP2C19 loss-of-function alleles versus noncarriers. Figure 36 presents the results for the five studies in which at least one composite cardiovascular outcome occurred (see Table 14 for definitions of outcomes) and with the results stratified by genotype group, under two genetic models (dominant and recessive). The figure also demonstrates the relative treatment effect (i.e., the relative odds ratio) across the genotype groups—the equivalent of the genotype × treatment interaction. The relative treatment effect was statistically significant in only one study, and only under a dominant genetic model. In generally, effects were more imprecise under a recessive genetic model, due to the scarcity of homozygote individuals in the study populations.

Figure 36 Results from large randomized trials assessing effect modification by CYP2C19 variants on MACE

The top set of panels presents forest plots of treatment effects (odds ratios) on major adverse cardiovascular events (MACE) among carriers of at least one loss-of-function (LOF) allele (top left panel); treatment effects among noncarriers of LOF alleles (top middle panel); and relative effects (relative odds ratios [rOR]) comparing the treatment effect among LOF carriers and LOF noncarriers (top right panel). The bottom set of panels presents forest plots of treatment effects on MACE among homozygotes for two LOF alleles (bottom left panel); treatment effects among non-homozygotes of LOF alleles (bottom middle panel); and relative effects (relative odds ratios [rOR]) comparing the treatment effect among homozygotes and non-homozygotes of LOF alleles (bottom right panel). Two studies did not provide adequate data for the comparisons of homozygotes and non-homozygotes. The CURE, CHARISMA, and ACTIVE A trials compared aspirin plus clopidogrel versus aspirin monotherapy; the TRITON-TIMI 38 trial compared aspirin plus clopidogrel versus aspirin plus prasugrel; the PLATO trial compared aspirin plus clopidogrel versus aspirin plus ticagrelor. Point estimates for treatment effects are shown as black circles (carriers) or white circles (noncarriers); point estimates for relative treatment effects are shown as black squares. For all symbols, size is inversely proportional to the standard error of each estimate. Horizontal lines denote 95% confidence intervals for all estimates. Vertical dashed lines denote no effect. Please see Tables 18 and 19 for full definitions of the genotype categories and outcomes reported by each study. References to individual studies are provided in Table 5.

ACTIVE A = Atrial Fibrillation Clopidogrel Trial with Irbesartan for Prevention of Vascular Events A; Clopidogrel for High Atherothrombotic Risk and Ischemic Stabilization, Management and Avoidance; CURE = Clopidogrel in Unstable Angina to Prevent Recurrent Events trial; homoz = homozygotes; PLATO = Platelet inhibition and patient Outcomes trial; TRITON-TIMI 38 = Trial to Assess Improvement in Therapeutic Outcomes by Optimizing Platelet Inhibition with Prasugrel–Thrombolysis in Myocardial Infarction; Tx = treatment.

Figure 36 displays forest plots of treatment effects on major adverse cardiovascular events among carriers of at least one loss-of-function (LOF) allele and among noncarriers of LOF alleles and relative effects comparing the treatment effect among carriers and noncarriers. The relative treatment effect across the genotype groups was statistically significant in only one study: the genetic substudy of the Trial to Assess Improvement in Therapeutic Outcomes by Optimizing (TRITON-TIMI 38); it was not significant in the Clopidogrel for High Atherothrombotic Risk and Ischemic Stabilization, Management and Avoidance (CHARISMA) trial, Clopidogrel in Unstable Angina to Prevent Recurrent Events (CURE) trial, the Platelet inhibition and patient Outcomes (PLATO) trial, or the Atrial Fibrillation Clopidogrel Trial with Irbesartan for Prevention of Vascular Events A (ACTIVE A). Results were similar in three studies that reported results under a recessive model.

Overall the available studies do not suggest that CYP2C19 genotype status is a strong modifier of the treatment effects evaluated in the studies. However, none of these studies were specifically designed to assess effect modification by genotype, they were conducted in heterogeneous populations and compared different pairs of treatments. Further, the studies included only small subsets (in all cases <50 percent of the original trial populations) suggesting that selection bias may have affected their results. This was a concern particularly for the CHARISMA trial,85 where differences in baseline characteristics and outcome rates were observed between the patients included and those not included in the genetic substudy. Furthermore, details were not provided regarding the timing of obtaining samples for genetic analyses (but samples were generally not obtained at the trial baseline). In such cases, survivor bias (another form of selection bias) may also affect study results.

###### Intermediate Outcome: Platelet Reactivity During Followup

Seven studies assessing treatment-effect modification by CYP2C19 variants provided information on platelet reactivity during followup as an intermediate outcome (Table 20 and 21).191,260-264 All seven were based on randomized trials comparing clopidogrel-based treatment to alternative therapies, had small to moderate sample sizes (range, 60 to 474 participants), and enrolled heterogeneous populations: two included patients with stable coronary artery disease, one included patients with myocardial infarction undergoing PCI, one included patients undergoing elective PCI, one enrolled patients with coronary artery disease receiving drug-eluting stents, one included “high-risk” patients undergoing PCI, and one included male patients who had experienced a myocardial infarction before age 45. All had short followup periods (<7 days to 6 weeks).

Table 20 Study characteristics in studies of treatment-effect modification by CYP2C19 genotype status with intermediate outcomes

Author Year Country PMID Study Name (if available) | Selection Criteria | Study Design | N Enrolled Male (%) Age^* ^ Dyslipidemia (%) Smokers (%) HTN (%) Diabetes (%) Race/Ethnicity (%) | Treatments Compared | Followup Duration
Varenhorst261^†^ 2009 Sweden 19429918 TABR | Patients with stable coronary artery disease; patients were participants in a 2-center, double-blind, double-dummy RCT | Pre-specified genetic substudy of an RCT | 98 89 (91%) 63.8 (6.0) NR 12 (12%) [unclear definition] NR 19 (19%) White=98 (100%) | All study subjects received aspirin 75 mg/d for 5–21 days prior to randomization and continued throughout the study. Following the open-label aspirin run-in period, subjects continuing to meet enrolment criteria were assigned to two groups: Aspirin + prasugrel: prasugrel loading dose 60 mg, followed by prasugrel 10 mg/d maintenance dose Aspirin + clopidogrel: clopidogrel 600 mg loading dose; clopidogrel 75 mg/d maintenance dose | 30 d
Tantry^††^262 2010 USA and UK 21079055 ONSET/OFFSET and RESPOND Genotype Studies | Patients with documented stable coronary artery disease; patients were participants in the double-blind, double-blind, parallel arm multicenter ONSET-OFFSET study or the double-blind, double-blind, crossover multicenter RESPOND study | Genetic substudies based on 2 RCTs [data from both were combined] | 174 129 (74%) 63.9 (8.6) 164 (94%) 15 (9%) [current smokers] 137 (79%) 39 (22%) White=153 (88%); Black=15 (7%); other NR | In the ONSET/OFSET trial: Ticagrelor group: ticagrelor (180 mg) loading dose; ticagrelor maintenance (90 mg) in the evening with a 12-hour interval between dosing, followed by ticagrelor maintenance 90 mg BID for 6 w Clopidogrel group: clopidogrel (600 mg) loading dose; clopidogrel maintenance (90 mg) in the evening with a 12-hour interval between dosing, followed by clopidogrel maintenance 75 mg/d for 6 w Placebo group: placebo (no treatment) loading dose; followed by placebo administration for 6 w In the RESPOND trial, previously identified responsive or nonresponsive to clopidogrel 300 mg loading dose (cut-off ≤10% absolute change of reactivity to LTA) patients were randomized into two groups for the first trial period: Clopidogrel group: 600 mg clopidogrel loading dose, followed by 75 mg/d maintenance dose for 2 w Ticagrelor group: 80 mg ticagrelor loading dose, followed by 90 mg BID maintenance dose Period 2 data for the RESPOND trial were not used in the pharmacodynamic investigation. | 6 w for ONSET/OFFSET participants; 2 w for RESPOND participants
Kim260 2011 S. Korea 21511217 ACCELAMI2C19 | Consecutive MI patients admitted to a single university hospital treated with “uneventful PCI”; patients were participants in the genetic expanded study of ACCEL-AMI | Genetic substudy of RCT | 126 [with available genotyping information] 92 (73%) 61.7 (12.3) 35 (28%) 75 (60%) [current smokers] 59 (47%) 35 (28%) East Asian=126 (100%) | All patients received clopidogrel loading (600 mg) upon admission; followed by 75 mg/d maintenance dose. High-maintenance dose clopidogrel: clopidogrel 150 mg/d maintenance Triple therapy (adjunctive cilostazol): cilostazol 100 mg BID + clopidogrel 75/d maintenance All patients received aspirin 300 mg loading dose, followed by 200 mg/d maintenance dose for the duration of the study. | 30 d
Hwang263 2010 S. Korea 20823393 ACCEL-RESISTANCE, DM, and COMPLEX trials (ACEL-POLYMORPHISM) | High-risk patients undergoing PCI; patients were participants in the ACELL trials (patients in the RESISTANCE trial had HPPR; in the DM trial had diabetes mellitus; and in the COMPLEX trial had complex lesions for stent placement)^†††^ | Prespecified genetic substudy of 3 RCTs | 114 [with available genotyping information] 88 (77%) 63.2 (9.5) 33 (29%) 51 (45%) [current smokers] 76 (67%) 37 (32%) East Asian=114 (100%) | All patients received clopidogrel loading dose of 300 mg upon ≥12 h before PCI or where on chronic clopidogrel treatment (75 mg/d for ≥7 d); followed by 75 mg/d maintenance dose. High-maintenance dose clopidogrel: clopidogrel 150 mg/d maintenance Triple therapy (adjunctive cilostazol): cilostazol 100 mg BID + clopidogrel 75/d maintenance All patients received aspirin 300 mg loading dose, followed by 200 mg/d maintenance dose for the duration of the study. | 30 d
Gladding191^**^ 2008 New Zealand 19463375 PRINC | Patients undergoing elective PCI who were on aspirin treatment; patients were participants In the randomized PRINC trial | Genetic substudy of RCT | 60 50 (83%) 68 (10) NR 6 (10%) [current smokers] 34 (57%) 11 (18%) White=57 (95%); others NR | The PRINC study design had 2 phases: a 2×2 factorial, randomized, placebo-controlled, double-blind study over the first 24 h, followed by a 1 w randomized, placebo-controlled, double-blind study. Patients were first randomized in a 2 × 2 manner to receive either 5 mg verapamil or placebo at baseline and either placebo or 600 mg clopidogrel, 2 h from baseline. All patients received 600 mg clopidogrel at the start of the PCI procedure, 10 min after administration of verapamil or placebo. The next day, patients were separately randomized to receive clopidogrel 75 or 150 mg once daily for 1 week, followed by 75 mg once daily thereafter. | 7 d
Park264 2011 S. Korea 21345843 CILON-T | Patients undergoing implantation of drug-eluting stents; patients were participants in the CILON-T randomized trial | Genetic substudy of RCT | 474 330 (70%) 63.3 (8.7) 220 (46%) 98 (21%) 322 (68%) 159 (34%) Korean = 474 (100%) | Patients who had not taken aspirin or clopidogrel before PCI were given a loading dose of aspirin (300 mg) and clopidogrel (300–600 mg) and then were randomized to: Dual-antiplatelet therapy: Aspirin (100 mg daily) and clopidogrel (75 mg daily) Triple-antiplatelet therapy: Aspirin (100 mg daily), clopidogrel (75 mg daily), and cilostazol (200 mg loading dose + 100 mg twice daily) | NR (“at discharge”)
Collet265 2011 France 21511218 CLOVIS-2 | Patients with MI before the age of 45, screened from the AFIJI multicenter registry. A total of 292 male patients were genotyped for CYP2C19*2. *2/*2 and *2/*1 patients were asked to participate in the trial. Age- and gender-matched CYP2C19 *1/*1 (noncarriers) from the AFIJI program were then recruited with a 1:1 ratio for each *2/*1 and a 2:1 ratio for each *2/*2 patient who was willing to participate. | Genetic substudy of crossover RCT | 106 included in analyses 106 (100%) 40.1 (4.8) 73 (69%) NR 30 (28%) 16 (15%) European = 86 (81%); North African = 13 (12%); Black = 1 (1%); Asian = 6 (6%) | Patients were on maintenance aspirin (75 mg/d) and/or clopidogrel (75 mg/d) for ≥3 mo. They were randomized to an open-label loading dose of 300 or 900 mg of clopidogrel in a 2-period crossover fashion. Clopidogrel maintenance treatment (75 mg) was continued for ≥21 d before patients were crossed over to the alternate loading dose of clopidogrel. Measurements were obtained at baseline and 1, 2, 4, and 6 h post-loading in each study period. | At least 42 d (time on maintenance after each loading dose)

* Mean (standard deviation), unless otherwise stated.

† Some information extracted from Wallentin et al. 2008.^267^

†† Some information extracted from Gurbel et al. 2009^268^ and Gurbel et al. 2010.^162^

** Although the HPPR study required presence of resistance to antiplatelet therapy, ascertained by reactivity testing, we included the study by Hwang et al. in this section (and not in the section on studies randomizing patients after selection with reactivity testing) because the paper did not report separate results for patients in the ACCEL-RESISTANCE study, and such criteria were not used in the ACCEL-DM or ACCEL-COMPLEX trials.

††† Some information extracted from Gladding et al. 2008.^269^

AFIJI = Appraisal of risk Factors in young Ischemic patients Justifying aggressive Intervention; BID = twice daily; d = day; h = hours; NR = not reported; PCI = percutaneous coronary intervention; PRINC = Plavix Response in Coronary Intervention; RCT = randomized clinical trial; weeks

Table 21 Effect modification on the outcome of platelet reactivity in randomized trials stratifying patients by CYP2C19 genotype status

Author Year Country UID Study name (if available) | Treatment group | Subgroups defined by genotype | N | Assay (agonist) [manufacturer] for the assessment of platelet reactivity | Summary of results
Varenhorst261 2009 Sweden 19429918 TABR | Aspirin + prasugrel | Extensive metabolizers Reduced metabolizers Uncertain functional status | 35 15 1 | VASP assay (ADP ±PGE1) [Biocytex, Marseille, France] VerifyNow P2Y12 (ADP) [Accumetrics, San Diego, CA] | By PRI VASP: at 24 h, 14 d, and 29 d, the difference between extensive and reduced metabolizers was p<0.05 in clopidogrel treated patients but p=NS for prasugrel treated patients. By PRU VerifyNow: at 24 h, 14 d, and 29 d, the difference between extensive and reduced metabolizers was p<0.05 in clopidogrel treated patients but p=NS for prasugrel treated patients. Exact p-values were not reported; additional information provided only in graphical form (Figure 3 of the paper).
Varenhorst261 2009 Sweden 19429918 TABR | Aspirin + clopidogrel | Extensive metabolizers Reduced metabolizers Uncertain functional status | 37 9 1 | VASP assay (ADP ±PGE1) [Biocytex, Marseille, France] VerifyNow P2Y12 (ADP) [Accumetrics, San Diego, CA]
Tantry^*^262 2010 USA and UK 21079055 ONSET/OFFSET and RESPOND Genotype Studies | Ticagrelor group | Ultra metabolizers Extensive metabolizers Intermediate metabolizers Poor metabolizers | 27 28 35 2 | LTA (ADP 5 or 20 μmo/L) [Chronolog Optical Aggregometer, model 490-4D, no additional information provided]; VASP assay (ADP ±PGE1) [Biocytex, Marseille, France]; VerifyNow P2Y12 (ADP) [Accumetrics, San Diego, CA] | LTA (ADP 5 μM); p-value for the treatment effect within genotype group (ticagrelor vs. clopidogrel) Ultra metabolizers, p=0.0016 Extensive metabolizers, p=0.0004 Intermediate metabolizers, p<0.0001 Poor metabolizers, p=0.149
Tantry^*^262 2010 USA and UK 21079055 ONSET/OFFSET and RESPOND Genotype Studies | Clopidogrel group | Ultra metabolizers Extensive metabolizers Intermediate metabolizers Poor metabolizers | 28 31 20 3 | | LTA (ADP 20 μM); p-value for the treatment effect within genotype group (ticagrelor vs. clopidogrel) Ultra metabolizers, p=0.001 Extensive metabolizers, p=0.0001 Intermediate metabolizers, p<0.0001 Poor metabolizers, p=0.139
Tantry^*^262 2010 USA and UK 21079055 ONSET/OFFSET and RESPOND Genotype Studies | Ticagrelor group | LOF carriers LOF noncarriers GOF carriers | 27 28 37 | | VerifyNow; p-value for the treatment effect within genotype group (ticagrelor vs. clopidogrel) Ultra metabolizers, p<0.0001 Extensive metabolizers, p<0.0001 Intermediate metabolizers, p<0.0001 Poor metabolizers, p=0.138
Tantry^*^262 2010 USA and UK 21079055 ONSET/OFFSET and RESPOND Genotype Studies | Clopidogrel group | LOF carriers LOF noncarriers GOF carriers | 28 31 23 | | VASP assay; p-value for the treatment effect within genotype group (ticagrelor vs. clopidogrel) Ultra metabolizers, p<0.0001 Extensive metabolizers, p<0.0001 Intermediate metabolizers, p<0.0001 Poor metabolizers, p=0.149 P-values from Wilcoxon rank-sum test. In all groups reactivity was lower in the ticagrelor group. Additional information provided only in graphical form (Figures 3-5).
Tantry^*^262 2010 USA and UK 21079055 ONSET/OFFSET and RESPOND Genotype Studies | Clopidogrel group | LOF carriers LOF noncarriers GOF carriers | 28 31 23 | | LTA (ADP 5 μM); p-value for the treatment effect within genotype group (ticagrelor vs. clopidogrel) Loss-of-function carriers, p<0.0001 Loss-of-function noncarriers, p<0.0001 Gain-of-function carriers, p=0.0016
Tantry^*^262 2010 USA and UK 21079055 ONSET/OFFSET and RESPOND Genotype Studies | Clopidogrel group | LOF carriers LOF noncarriers GOF carriers | 28 31 23 | | LTA (ADP 20 μM); p-value for the treatment effect within genotype group (ticagrelor vs. clopidogrel) Loss-of-function carriers, p<0.0001 Loss-of-function noncarriers, p=0.0001 Gain-of-function carriers, p=0.001 VerifyNow; p-value for the treatment effect within genotype group (ticagrelor vs. clopidogrel) Loss-of-function carriers, p<0.0001 Loss-of-function noncarriers, p<0.0001 Gain-of-function carriers, p<0.0001
Tantry^*^262 2010 USA and UK 21079055 ONSET/OFFSET and RESPOND Genotype Studies | Clopidogrel group | LOF carriers LOF noncarriers GOF carriers | 28 31 23 | | VASP assay; p-value for the treatment effect within genotype group (ticagrelor vs. clopidogrel) Loss-of-function carriers, p<0.0001 Loss-of-function noncarriers, p<0.0001 Gain-of-function carriers, p<0.0001 P-values from Wilcoxon rank-sum test. In all groups reactivity was lower in the ticagrelor group. Additional information provided only in graphical form (Figures 3-5).
Kim^†^260 2011 S. Korea 21511217 ACCELAMI2C19 | High-maintenance dose clopidogrel | Carriers Noncarriers | 38 24 | LTA (ADP 5 and 20 μmol/L) [AggRAM aggregometer, Helena Laboratories Corp., Beaumont, TX] VerifyNow P2Y12 (ADP) [Accumetrics, San Diego, CA] | Maximal platelet aggregation by LTA 5μmol/L at 30 d Carriers Mean reactivity in high-maintenance dose clopidogrel group=37.6 (SD=16.0) Mean reactivity in triple therapy group=24.9 (SD=14.3) P-valuefor the treatment effect among carriers, <0.001 Noncarriers Mean reactivity in high-maintenance dose clopidogrel group=30.1 (SD=10.1) Mean reactivity in triple therapy group=28.2 (SD=11.5) P-value for the treatment effect among noncarriers=0.547
Kim^†^260 2011 S. Korea 21511217 ACCELAMI2C19 | Triple therapy (adjunctive cilostazol) | Carriers Noncarriers | 25 39 | | Maximal platelet aggregation by LTA 20μmol/L at 30 d (mean reactivity) Carriers: High-maintenance dose clopidogrel group, 52.3 (SD=17.5) Triple therapy group=35.0 (SD=19.3) P for the treatment effect among carriers <0.001 Noncarriers Mean reactivity in high-maintenance dose clopidogrel group=38.6 (SD=12.0) Mean reactivity in triple therapy group=37.5 (SD=13.2) P for the treatment effect among noncarriers=0.752
Kim^†^260 2011 S. Korea 21511217 ACCELAMI2C19 | Triple therapy (adjunctive cilostazol) | Carriers Noncarriers | 25 39 | | Late platelet aggregation by LTA 5μmol/L at 30 d Carriers Mean reactivity in high-maintenance dose clopidogrel group=26.7 (SD=16.5) Mean reactivity in triple therapy group=15.2 (SD=12.4) P for the treatment effect among carriers=0.001 Noncarriers Mean reactivity in high-maintenance dose clopidogrel group=16.4 (SD=9.2) Mean reactivity in triple therapy group=13.6 (SD=11.7) P for the treatment effect among noncarriers=0.347
Kim^†^260 2011 S. Korea 21511217 ACCELAMI2C19 | Triple therapy (adjunctive cilostazol) | Carriers Noncarriers | 25 39 | | Late platelet aggregation by LTA 20μmol/L at 30 d Carriers Mean reactivity in high-maintenance dose clopidogrel group=40.6 (SD=22.2) Mean reactivity in triple therapy group=23.5 (SD=19.2) P for the treatment effect among carriers=0.0001 Noncarriers Mean reactivity in high-maintenance dose clopidogrel group=21.8 (SD=14.8) Mean reactivity in triple therapy group=19.7 (SD=16.8) P for the treatment effect among noncarriers=0.649
Kim^†^260 2011 S. Korea 21511217 ACCELAMI2C19 | Triple therapy (adjunctive cilostazol) | Carriers Noncarriers | 25 39 | | VerifyNow PRU at 30 d Carriers Mean reactivity in high-maintenance dose clopidogrel group=184.2 (SD=80.6) Mean reactivity in triple therapy group=171.9 (SD=86.3) P for the treatment effect among carriers=0.518 Noncarriers Mean reactivity in high-maintenance dose clopidogrel group=152.2 (SD=70.4) Mean reactivity in triple therapy group=136.6 (SD=70.0) P for the treatment effect among noncarriers=0.441
Kim^†^260 2011 S. Korea 21511217 ACCELAMI2C19 | Triple therapy (adjunctive cilostazol) | Carriers Noncarriers | 25 39 | | VerifyNow %inhibition at 30 d Carriers Mean reactivity in high-maintenance dose clopidogrel group=40.3 (SD=23.5) Mean reactivity in triple therapy group=48.0 (SD=24.0) P for the treatment effect among carriers=0.157 Noncarriers Mean reactivity in high-maintenance dose clopidogrel group=54.7 (SD=22.3) Mean reactivity in triple therapy group=56.4 (SD=20.7) P for the treatment effect among noncarriers=0.783
Kim^†^260 2011 S. Korea 21511217 ACCELAMI2C19 | Triple therapy (adjunctive cilostazol) | Carriers Noncarriers | 25 39 | | HPR (cut-off >59% using LTA with ADP 20μmol/L) at 30 d Carriers N (%) among high-maintenance dose clopidogrel group=17 (44.7%) N (%) among triple therapy group=6 (15.4%) P for the treatment effect among carriers=0.005 Noncarriers N (%) among high-maintenance dose clopidogrel group=2 (8.3%) N (%) among triple therapy group=0 (0%) P for the treatment effect among noncarriers=0.235
Gladding191 2008 New Zealand 19463375 PRINC | 1200 mg clopidogrel loading | Carriers Noncarriers | 11 15 | VerifyNow P2Y12 (ADP) [Accumetrics, San Diego, CA] | % inhibition (Mann-Whitney U test) among carriers at 4 h (600 mg vs. 1200 mg): median=14% vs. 37%; p=0.002 % inhibition (Mann-Whitney U test) among noncarriers at 4 h (600 mg vs. 1200 mg): median=35% vs. 43%; p=0.3
Gladding191 2008 New Zealand 19463375 PRINC | 600 mg clopidogrel loading | Carriers Noncarriers | 8 9 | | % inhibition (Mann-Whitney U test) among carriers at 7 h (600 mg vs. 1200 mg): median=22% vs. 42%; p=0.09 % inhibition (Mann-Whitney U test) among noncarriers at 7 h (600 mg vs. 1200 mg): median=29% vs. 63%; p=0.05 % inhibition (Mann-Whitney U test) among carriers at 7 d (150 mg vs. 75 mg): median=14% vs. 51%; p=0.042 % inhibition (Mann-Whitney U test) among noncarriers at 7 d (150 mg vs. 75 mg): median=32% vs. 51%; p=0.2
Gladding191 2008 New Zealand 19463375 PRINC | 150 mg clopidogrel maintenance | Carriers Noncarriers | 5 12
Gladding191 2008 New Zealand 19463375 PRINC | 75 mg clopidogrel maintenance | Carriers Noncarriers | 9 6
Hwang^†^263 2010 S. Korea 20823393 ACCEL-RESISTANCE, DM, and COMPLEX trials | High-maintenance dose clopidogrel | Carriers Noncarriers | 43 22 | LTA (ADP 5 and 20 μmol/L) [AggRAM aggregometer, Helena Laboratories Corp., Beaumont, TX] VerifyNow P2Y12 (ADP) [Accumetrics, San Diego, CA] | Maximal platelet aggregation by LTA 5μmol/L at 30 d Carriers Mean reactivity in high-maintenance dose clopidogrel group=42.9 (SD=18.1) Mean reactivity in triple therapy group=28.4 (SD=13.9) P-value for the treatment effect among carriers<0.001 Noncarriers Mean reactivity in high-maintenance dose clopidogrel group=31.1 (SD=12.9) Mean reactivity in triple therapy group=26.7 (SD=15.2) P-value for the treatment effect among noncarriers=0.304
Hwang^†^263 2010 S. Korea 20823393 ACCEL-RESISTANCE, DM, and COMPLEX trials | Triple therapy (adjunctive cilostazol) | Carriers Noncarriers | 47 22 | LTA (ADP 5 and 20 μmol/L) [AggRAM aggregometer, Helena Laboratories Corp., Beaumont, TX] VerifyNow P2Y12 (ADP) [Accumetrics, San Diego, CA] | Maximal platelet aggregation by LTA 20μmol/L at 30 d Carriers Mean reactivity in high-maintenance dose clopidogrel group=55.4 (SD=15.9) Mean reactivity in triple therapy group=40.5 (SD=16.7) P-value for the treatment effect among carriers<0.001 Noncarriers Mean reactivity in high-maintenance dose clopidogrel group=41.9 (SD=16.4) Mean reactivity in triple therapy group=36.0 (SD=19.2) P-value for the treatment effect among noncarriers=0.276
Hwang^†^263 2010 S. Korea 20823393 ACCEL-RESISTANCE, DM, and COMPLEX trials | Triple therapy (adjunctive cilostazol) | Carriers Noncarriers | 47 22 | LTA (ADP 5 and 20 μmol/L) [AggRAM aggregometer, Helena Laboratories Corp., Beaumont, TX] VerifyNow P2Y12 (ADP) [Accumetrics, San Diego, CA] | Late platelet aggregation by LTA 5μmol/L at 30 d Carriers Mean reactivity in high-maintenance dose clopidogrel group=30.7 (SD=22.2) Mean reactivity in triple therapy group=16.7 (SD=11.5) P-value for the treatment effect among carriers<0.001 Noncarriers Mean reactivity in high-maintenance dose clopidogrel group=19.0 (SD=13.4) Mean reactivity in triple therapy group=14.9 (SD=13.4) P-value for the treatment effect among noncarriers=0.318
Hwang^†^263 2010 S. Korea 20823393 ACCEL-RESISTANCE, DM, and COMPLEX trials | Triple therapy (adjunctive cilostazol) | Carriers Noncarriers | 47 22 | LTA (ADP 5 and 20 μmol/L) [AggRAM aggregometer, Helena Laboratories Corp., Beaumont, TX] VerifyNow P2Y12 (ADP) [Accumetrics, San Diego, CA] | Late platelet aggregation by LTA 20μmol/L at 30 d Carriers Mean reactivity in high-maintenance dose clopidogrel group=43.2 (SD=22.0) Mean reactivity in triple therapy group=26.4 (SD=17.4) P-value for the treatment effect among carriers<0.001 Noncarriers Mean reactivity in high-maintenance dose clopidogrel group=26.9 (SD=18.8) Mean reactivity in triple therapy group=21.2 (SD=19.0) P-value for the treatment effect among noncarriers=0.321
Hwang^†^263 2010 S. Korea 20823393 ACCEL-RESISTANCE, DM, and COMPLEX trials | Triple therapy (adjunctive cilostazol) | Carriers Noncarriers | 47 22 | LTA (ADP 5 and 20 μmol/L) [AggRAM aggregometer, Helena Laboratories Corp., Beaumont, TX] VerifyNow P2Y12 (ADP) [Accumetrics, San Diego, CA] | VerifyNow PRU at 30 d Carriers Mean reactivity in high-maintenance dose clopidogrel group=214.1 (SD=68.5) Mean reactivity in triple therapy group=191.6 (SD=78.4) P-value for the treatment effect among carriers=0.153 Noncarriers Mean reactivity in high-maintenance dose clopidogrel group=149.7 (SD=65.4) Mean reactivity in triple therapy group=129.4 (SD=76.4) P-value for the treatment effect among noncarriers=0.348
Hwang^†^263 2010 S. Korea 20823393 ACCEL-RESISTANCE, DM, and COMPLEX trials | Triple therapy (adjunctive cilostazol) | Carriers Noncarriers | 47 22 | LTA (ADP 5 and 20 μmol/L) [AggRAM aggregometer, Helena Laboratories Corp., Beaumont, TX] VerifyNow P2Y12 (ADP) [Accumetrics, San Diego, CA] | VerifyNow %inhibition at 30 d Carriers Mean reactivity in high-maintenance dose clopidogrel group=33.5 (SD=19.2) Mean reactivity in triple therapy group=45.8 (SD=21.2) P-value for the treatment effect among carriers=0.005 Noncarriers Mean reactivity in high-maintenance dose clopidogrel group=65.2 (SD=12.8) Mean reactivity in triple therapy group=70.5 (SD=7.6) P-value for the treatment effect among noncarriers=0.317
Hwang^†^263 2010 S. Korea 20823393 ACCEL-RESISTANCE, DM, and COMPLEX trials | Triple therapy (adjunctive cilostazol) | Carriers Noncarriers | 47 22 | LTA (ADP 5 and 20 μmol/L) [AggRAM aggregometer, Helena Laboratories Corp., Beaumont, TX] VerifyNow P2Y12 (ADP) [Accumetrics, San Diego, CA] | HPR (cut-off >50% using LTA with ADP 5 μmol/L) at 30 d Carriers N (%) among high-maintenance dose clopidogrel group=16 (37.2%) N (%) among triple therapy group=3 (6.4%) P-value for the treatment effect among carriers<0.001 Noncarriers N (%) among high-maintenance dose clopidogrel group=3 (13.6%) N (%) among triple therapy group=1 (4.5%) P-value for the treatment effect among noncarriers=0.607
Park264 2011 S. Korea 21345843 CILON-T | Dual-antiplatelet therapy: | LOF carriers Noncarriers | 132 104 | VerifyNow P2Y12 (ADP) [Accumetrics, San Diego, CA] | Mean on-treatment platelet reactivity (in PRU) Dual therapy, carrier (254±7) vs. noncarrier (208±7), p<0.001 Triple therapy, carrier (215±7) vs. noncarrier (199±9), p=0.167 Noncarrier, dual therapy (211±8) vs. triple therapy (196±9), p=0.242 Carrier, dual therapy (256±7) vs. triple therapy (213±6), p<0.001 High on-treatment platelet reactivity (>240 PRU): Dual therapy, carrier (60.8%) vs. noncarrier (36.5%), p<0.001 Triple therapy, carrier (43.7%) vs. noncarrier (33.3%), p=0.115 Noncarriers, triple therapy (33.3%) vs. dual therapy (36.5%), p=0.241 Carriers, triple therapy (43.7%) vs. dual therapy (60.8%), p<0.001 p=0.241 for proportion of high on-treatment platelet reactivity among triple therapy noncarrier, triple therapy carrier, and dual therapy noncarrier Multivariate analysis for independent predictors of high on-treatment platelet reactivity (adjusted for decade of age, sex, smoking, diabetes, CKD, and treatment group): OR (95% CI) [p-value] vs. dual therapy, noncarrier: Dual therapy, carrier 2.93 (1.64 to 5.21) [<0.001] Triple therapy, noncarrier 0.75 (0.39 to 1.44) [0.388] Triple therapy, carrier 1.19 (0.68 to 2.05) [0.545]
Park264 2011 S. Korea 21345843 CILON-T | Triple-antiplatelet therapy (adjunctive cilostazol) | LOF carriers Noncarriers | 151 87 | VerifyNow P2Y12 (ADP) [Accumetrics, San Diego, CA]
Collet265 2011 France 21511218 CLOVIS-2 | Clopidogrel loading dose of 300 or 900 mg (crossover RCT). Clopidogrel maintenance treatment (75 mg) was continued for ≥21 days before patients were crossed over to the alternate loading dose group | *2/*2 *2/*1 1/1 | 7 41 58 | LTA (ADP 20 μmol/L) [Model 490-4D, Chrono-Log Corporation, Kordia, Netherlands] VerifyNow P2Y12 (ADP) [Accumetrics, San Diego, CA] | There was a stepwise decrease of the relative reduction in residual platelet aggregation from wild-type/wild-type to *2/*2 patients, with a significant gene-dose effect following the 300 mg loading dose. The 300 mg loading dose resulted in a significant reduction in platelet aggregation in wild-type/wild-type and wild-type/*2 patients, but had no detectable effect on platelet activation in *2/*2 carriers (residual/maximal platelet aggregation[%]: 65.43 ±11.23 and 67.27 ±10.60 before vs. 60.10 ±28.75 and 66.97 ±23.91 after loading, respectively) The 900 mg loading dose blunted the effect of the CYP2C19*2 variant on relative reduction in residual platelet aggregation in wild-type/*2, which did not differ from wild-type/wild-type. The increased dose had little effect on *2/*2 carriers. The prevalence of high on-clopidogrel platelet reactivity (measured by LTA 20 μmol/L ADP with a cut-off of 64.5%) increased with the number of *2 alleles, although this effect was blunted after administration of the 900 mg loading dose in patients carrying a single *2 allele. High on-treatment reactivity was less frequent when measured by VerifyNow (PRU ≥235) with no significant gene-dose effect.

* Results were extracted for the longest followup reported (2–6 weeks); results for each diplotype not presented.

† Results were extracted for the longest followup reported (30 d)

ADP = adenosine diphosphate; CI = confidence interval; CKD = chronic kidney disease; d = day(s); GOF = gain-of-function; HPR = high platelet reactivity; LOF = loss-of-function; LTA = light-transmission aggregometry; PRINC = Plavix Response in Coronary Intervention; PRU = platelet reactivity units; RCT = randomized controlled trial; VASP = vasodilator-stimulated phosphoprotein.

Table 20 describes the assays used, alleles genotyped, and genotype groupings used in the seven studies. Four of the six did not provide a rationale for the genotype grouping; one study used an enrichment design whereby patients with *2/*2 and *2/*1 genotype where matched to patients with *1/*1 genotype. The studies differed in the alleles genotyped and the genotype groupings used, leading to heterogeneity in the exposure definition. Platelet reactivity during followup was assessed by the VerifyNow P2Y12 assay in all seven studies, as well as by LTA in four studies and the VASP assay (with flow cytometry) in two studies. Key findings from these studies are summarized in Table 21. The overall results were variable and incomplete reporting sometimes precluded the quantitative assessment of test × treatment interactions. Because of the differences in designs, populations, treatments compared, and followup durations among the included studies, we did not perform a meta-analysis.

###### Assessment of Risk of Bias of Individual Studies

A detailed assessment of 17 risk-of-bias items for studies providing information on effect modification by CYP2C19 variants is presented in Appendix F (the table includes both studies reporting on clinical and those reporting on intermediate outcomes). Overall, the risk of bias of individual studies was variable. Generally, studies reporting on clinical outcomes (which were generally larger and had longer followup than those with platelet reactivity as an outcome) used robust methods for randomization and allocation concealment. However, these studies included only a small proportion of the patients enrolled in the corresponding parent trials (15 to 40 percent in trials reporting clinical followup of more than a month). In large RCTs providing information on treatment effect modification by genotype status, genetic analyses were not conducted at baseline, raising further concerns regarding selection bias. In contrast, in studies reporting information on laboratory outcomes (which tended to be smaller with short followup periods), 79 to 100 percent of the patients enrolled in the parent RCTs were also included in the genetic substudies. These smaller studies provided adequate descriptions of the methods used for generating the randomization sequence but did not provide sufficient information to assess methods of allocation concealment.

##### Study With Genetic Test–Based Selection of Patients

We identified a single multicenter trial (ELEVATE-TIMI 56) using genetic test–based selection of patients and then randomizing them to alternative antiplatelet treatments. The study enrolled 335 patients with known cardiovascular disease (57.1 percent with a history of myocardial infarction; 97.3 percent with a history of PCI) on maintenance clopidogrel therapy (75 mg daily). Table 22 presents the descriptive characteristics of the trial.

Table 22 Descriptive characteristics of the study with genetic test–based selection of patients

Author, Year Country PMID Study name | Selected Population | Study Design Treatment Strategies Compared | Assay [model, manufacturer] | Total N Enrolled Male (%) Age^*^, Dyslipidemia (%), Smokers (%), HTN (%), Diabetes (%)
Mega87 2011 USA 22088980 ELEVATE-TIMI 56 | Patients receiving clopidogrel maintenance therapy (75 mg/d); eligible patients had to have an indication for clopidogrel therapy (either AMI or PCI, within ≥4 wk and ≤6 mo prior to enrollment) | Crossover RCT, double-blind (patients + outcome assessors) Patients on dual antiplatelet therapy (clopidogrel 75 mg/d + aspirin 81-325 mg/d) were genotyped for the presence of CYP2C19 *2 alleles and were then allocated to treatment on the basis of genotype: Patients with at least one *2 allele (carriers) were randomized to various sequences of receiving clopidogrel at doses of 75, 150, 225, and 300 mg/d. Patients with no *2 alleles (non-carriers) were randomized to doses of 75 or 150 mg (2 periods at each dose). All patients were asked to keep their aspirin dose stable during the study. | For selecting patients before randomization: pyrosequencing assay [Nanosphere Verigene 2C19/CBS nucleic acid research-use- only assay] | 333 patients were genotyped and randomized to different dosing schemes 249 (75%) 60 (10) 315 (95%) NR 287 (86%) 118 (35%)

* Mean (standard deviation), unless otherwise stated.

d = day; HTN = hypertension; NR = not reported; PCI = percutaneous coronary intervention; RCT = randomized controlled trial; SD = standard deviation; wk = week.The study reported results both regarding clinical outcomes and the intermediate outcome of platelet reactivity, which are summarized below.

###### Clinical Outcomes

Table 23 summarizes information on clinical outcomes from the ELEVATE-TIMI 56 study.

Table 23 Key findings of studies with phenotypic test–based selection of patients and clinical outcomes

Author Year Country PMID Study Name | Treatment Groups (sample size) | Followup Duration | Summary of Findings
Mega87 2011 USA 22088980 ELEVATE-TIMI 56 | Patients with at least one *2 allele (carriers = 86 patients) randomized to various sequences of receiving clopidogrel at doses of 75, 150, 225, and 300 mg/d (each for 14 d ±3 d) + aspirin Patients with no *2 alleles (non-carriers = 247) were randomized to doses of 75 or 150 mg (2 periods of 14 d ±3 d at each dose) + aspirin | ∼ 2 mo on treatment | There were no deaths or cerebrovascular events. Among CYP2C19*2 noncarriers, 2 patients had cardiac ischemic events while taking the 75 mg dose and 3 with the 150 mg dose. Among carriers of a CYP2C19*2 allele, 1 patient experienced a cardiac ischemic event while taking the 75 mg clopidogrel dose.

mo = months.

###### Intermediate Outcome: Platelet Reactivity During Followup

Table 24 summarizes information on the intermediate outcome of platelet reactivity from the ELEVATE-TIMI 56 study.

Table 24 Key findings of the study with genetic test–based selection of patients and intermediate outcomes

Author Year Country PMID Study Name | Treatment Groups (sample size) | Followup Duration | Summary of Findings
Mega87 2011 USA 22088980 ELEVATE-TIMI 56 | Patients with at least one *2 allele (carriers = 86 patients) randomized to various sequences of receiving clopidogrel at doses of 75, 150, 225, and 300 mg/d (each for 14 d ±3 d) + aspirin Patients with no *2 alleles (non-carriers = 247 patients) were randomized to doses of 75 or 150 mg (2 periods of 14 d ±3 d at each dose) + aspirin | ∼ 2 mo on treatment | Results were assessed with the VASP assay (primary analysis) and the VerifyNow assay (secondary analysis). When treated with a standard clopidogrel maintenance dose of 75 mg/d, both CYP2C19*2 heterozygotes and homozygotes had significantly higher on-treatment platelet reactivity than did noncarrier patients (p<0.001 for both pair-wise comparisons). Among CYP2C19*2 heterozygotes, higher clopidogrel maintenance doses (up to 300 mg) produced significant reductions in platelet reactivity (p<0.001 for trend). Each increase of 75 mg of the clopidogrel dose resulted in ∼8% to 9% absolute reduction in VASP PRI. Pairwise comparisons between the higher daily doses of clopidogrel (150, 225, and 300 mg) and the 75 mg dose were all statistically significant (p<0.001). Results with the VerifyNow assay were similar to the VASP data across dose and genotype. Among CYP2C19*2 homozygotes, there was a trend toward less platelet reactivity with higher maintenance doses of clopidogrel; however, even with 300 mg daily of clopidogrel, these individuals had increased reactivity by VASP and VerifyNow. In CYP2C19*2 heterozygotes, 150 mg resulted in platelet reactivity that tended to be higher than that seen in noncarrier patients treated with 75 mg daily. The 225 mg dose resulted in platelet reactivity similar to that observed in response to standard clopidogrel dosing in noncarriers. The 300 mg dose resulted in superior reductions in platelet reactivity as compared with 75 mg dosing in noncarrier patients as measured both by VASP PRI and PRU (p<0.001 for both). For CYP2C19*2 homozygotes, even 300 mg daily of clopidogrel did not result in platelet reactivity levels similar to standard clopidogrel dosing in noncarriers.

d = day; mo = month; PRI = platelet reactivity index; PRU = platelet reactivity unit.

###### Assessment of Risk of Bias of Individual Studies

A detailed assessment of 17 risk-of-bias items for the ELEVATE-TIMI 56 trial is presented in Appendix F. Overall, the trial was well conducted, with centralized randomization and blinding of both patients and outcome assessors (both for clinical and intermediate outcomes) to the treatments assessment. The sample size was based on a priori power analysis for platelet reactivity outcomes and the recruitment target was attained (333 patients randomized with a minimum of 254 required on the basis of the power calculation). There were minimal dropouts and losses to followup. However, the study was not powered for, and did not have adequate followup to provide robust evidence on, clinical outcomes.

#### Testing for Platelet Reactivity

##### Studies of Test-and-Treat Strategies

We identified seven studies directly comparing alternative test-and-treat strategies.270-274 Six of the seven studies had a randomized design and one was a nonrandomized comparative study of test-and-treat strategies. Four compared VASP assay–guided therapy and non–test-guided therapy; two compared Multiplate analyzer-guided therapy and non–test-guided therapy (1 RCT and 1 nonrandomized comparative study); and one compared VerifyNow P2Y12–guided therapy versus non–test-guided therapy. The four studies evaluating the use of the VASP assay were of moderate size (the smallest enrolled 153 patients; the largest, 429 patients). The RCT evaluating the use of the Multiplate analyzer enrolled 192 patients and the nonrandomized comparative study evaluating the same assay enrolled 798 patients. The single study assessing VerifyNow was smaller (60 patients).

The six RCTs directly comparing alternative test-and-treat strategies assessed patients undergoing PCI; 4 enrolled patients with stable coronary artery disease or acute coronary syndromes and 1 enrolled exclusively patients undergoing elective stenting. The average patient age was equal to or older than 65 years in all RCTs. Patients had a relatively high burden of risk factors for cardiovascular disease. Four studies selected patients on the basis of a baseline assessment of platelet reactivity (enrolling only those with reactivity above a predetermined threshold); the fifth study included all patients, regardless of baseline reactivity.

The single nonrandomized comparative study also included patients undergoing PCI with stent implantation and did not use platelet reactivity as a selection criterion. Of note, the group receiving test-guided treatment was enrolled and followed up in a different research center than the group receiving non-test guided treatment (the Medical University of Vienna and the Kaiser Franz Josef Hospital, respectively). This renders the study results highly susceptible to confounding and selection bias. Our detailed assessment of the risk of bias of all seven studies comparing alternative test-and-treat strategies is presented at the end of this section.

The test-guided treatment groups in five studies (three using the VASP assay, one using the VerifyNow assay, and one using the Multiplate analyzer) employed repeat reactivity monitoring at multiple time points with modification of the administered clopidogrel dose on the basis of test results. The other two studies performed only a single assessment of platelet reactivity, with subsequent treatment modification in patients found to have reactivity values above a predefined threshold. Control groups were given clopidogrel-based therapy at standard doses.

Table 25 summarizes the selection criteria, population characteristics, and treatments compared in the five test-and-treat studies involving phenotypic testing.

Table 25 Descriptive characteristics of studies of test-and-treat strategies using phenotypic testing of platelet reactivity

Author Year Country PMID Study Name (if available) | Selected Population | Total N Enrolled Male (%), Age^*^, Dyslipidemia (%), Current smokers (%), HTN (%), Diabetes (%) | Study design Initial and Compared Treatment Strategies
Wang270 2011 China 21538380 | Patients with VASP PRI >50% 1 mo after undergoing PCI for refractory angina pectoris, silent ischemia on thallium scintigraphy, or NSTE ACS | N=306 214 (70%) 67 (11) 156 (51%) 118 (39%) 188 (61%) 132 (43%) | RCT All patients underwent angiography after a loading dose of aspirin (100 mg) and clopidogrel (300 mg); maintenance doses were 100 mg/d for aspirin and 75–375 mg/d for clopidogrel. One mo after PCI patients were randomized to 2 groups: VASP-guided treatment: VASP PRI was ascertained at 3, 6, 9, and 12 mo after the first analysis (1 mo post-PCI), when patients with PRI >50% received clopidogrel at a dose of 150 mg/d. At each subsequent monitoring visit the dose was increased by 75 mg/d if PRI remained >50% (for a maximum dose of 375 mg/d at 1 yr). If PRI was <25% at the 12-mp visit, the dose was decreased to 75mg/d. For PRI between 25% and 50%, the dose was not changed. Control treatment: A maintenance regimen of clopidogrel 75 mg/d was used.
Bonello271 2009 France 19101221 | Patients with VASP PRI >50% undergoing nonemergent PCI for refractory angina pectoris under “optimal medical therapy,” silent ischemia on thallium scintigraphy or NSTE ACS | N=429 345 (80%) 66 (11) 255 (59%) 238 (55%) 264 (62%) 155 (36%) | RCT All patients received a clopidogrel loading dose of 600 mg. Patients with PRI >50% afterward were randomized to 2 groups: VASP-guided treatment: Clopidogrel pretreatment was adjusted individually (pre-PCI) to obtain a VASP PRI <50% by prescribing up to 3 additional boluses of clopidogrel 600 mg 24 h after the previous dose; PRI was assessed 12 h after each administration until the value was <50%. If PRI remained >50% after the 3 additional loading doses, PCI was performed. Control treatment: PCI was carried out without an additional clopidogrel loading dose.
Bonello272 2008 France 18387444 | Patients with VASP PRI >50% undergoing nonemergent PCI for refractory angina pectoris under “optimal medical therapy” or having silent ischemia on thallium scintigraphy or NSTE ACS | N=162 126 (78%) 66 (11) 86 (53%) 62 (38%) 98 (60%) 67 (41%) | RCT All patients received a clopidogrel loading dose of 600 mg. Patients with PRI >50% afterward were randomized to 2 groups: VASP-guided treatment: Clopidogrel pretreatment was adjusted individually (pre-PCI) to obtain a VASP PRI <50% by prescribing up to 3 additional boluses of clopidogrel 600 mg 24 h after the previous dose; PRI was assessed 12 h after each administration until the value was <50%. If PRI remained >50% after the 3 additional loading doses, PCI was performed. Control treatment: PCI was carried out without an additional clopidogrel loading dose.
Tousek273 2011 Czech Republic 21663983 | Patients with VerifyNow PRU >240 undergoing PCI for stable angina, STE or NSTE MI, or UA | N=60 45 (75%) 66 (12) NR 22 (37%) 40 (67%) 18 (30%) | RCT All patients received a clopidogrel loading dose of 600 mg. Patients with VerifyNow PRU >240 afterward were randomized to 2 groups: VerifyNow-guided treatment: clopidogrel up-titration to 150 mg/d with further dose increases according to VerifyNow results every 7 days; the target PRU was <240 by 30 d. Control treatment: Standard clopidogrel maintenance dose of 75 mg/d.
Aleil274 2008 France 19463377 VASP-02 | Patients undergoing elective PCI with coronary stenting | N=153 126 (82%) 64.9 (9.7) 100 (65%) 24 (16%) 97 (63%) 37 (24%) | RCT The day before PCI patients received clopidogrel (300 to 600 mg) loading dose and were then randomized into 2 groups (3:2 ratio): VASP-guided treatment: Clopidogrel maintenance dose of 75 mg/d for 2 wk. At 2 wk, VASP analysis was performed; patients with PRI ≥69% were administered a maintenance dose of 150 mg/d, and those with PRI <69% were kept on 75 mg/d, for an additional 2 wk. Control treatment: Clopidogrel maintenance dose of 150 mg/d for 4 wk.
Hazarbasanov275 2012 Bulgaria 22249353 | Patients undergoing PCI | N=192 126 (66%) 64.5 (9.3) 129 (67%) 89 (46%) 170 (89%) 48 (25%) | RCT Patients with stable angina received clopidogrel loading (300 mg) 24 h before PCI. Patients presenting with ACS received clopidogrel loading (600 mg). Patients already on long-term clopidogrel therapy received an additional loading dose of 300 mg or 600 mg clopidogrel according to the clinical presentation. Patients were then randomized into 2 groups (1:1 ratio): Multiplate analyzer-guided treatment: patients with HPR received a 2^nd^ loading dose of 600 mg clopidogrel and a doubled maintenance dose (150 mg/d) for 1 mo after PCI. Clopidogrel 75 mg/d was resumed after 30 d in all patients and continued for ≥3 mo post BMS placement or ≥12 mo post DES placement. Control treatment: clopidogrel 75 mg/d for ≥3 mo post BMS placement or ≥12 mo post DES placement.
Siller-Matula276 2012 Austria 22656044 MADONNA | Patients undergoing PCI with stent implantation for STEMI or NSTE-ACS | N=798 585 (73%) 65.0 (12.0) 608 (76%) 419 (53%) 676 (85%) 273 (34%) | NRCS The following treatment approaches were compared: Multiplate analyzer-guided treatment: patients received an initial loading dose of clopidogrel (600 mg) followed by measurement of on-treatment platelet reactivity (post PCI). Patients with high on-treatment platelet reactivity (≥50 U) were reloaded with clopidogrel (600 mg) and platelet reactivity was measured the day after re-loading. In case of high on-treatment platelet reactivity after a 2nd or 3rd clopidogrel loading, patients were re-loaded with clopidogrel 600 mg for the 4th time. After prasugrel became available, clopidogrel non-responders were loaded with prasugrel (in the absence of contraindications). For maintenance treatment, patients received the antiplatelet therapy matching with the last loading dose they received (clopidogrel responders received clopidogrel; clopidogrel non-responders - clopidogrel or prasugrel). Non-responders were hospitalized during the period of tailored antiplatelet therapy. Control treatment: a single clopidogrel loading dose (600 mg) followed by clopidogrel maintenance. All patients received 250 mg of acetylsalicylic acid intravenously during PCI followed by 100 mg per so a day. Patients were “matched” according to the indication for PCI (no details were reported on the matching methods). Patients in the non-guided group were included at the Medical University of Vienna whereas patients in the guided group at the Kaiser Franz Josef Hospital in Vienna.

* Age is given as mean years (standard deviation), unless otherwise stated.

ACS = acute coronary syndrome; BMS = bare metal stent; d = day(s); DES = drug eluting stent; h = hours; HTN = hypertension; MI = myocardial infarction; mo = month; NR = not reported; NSTE = non-STEMI; PCI = percutaneous coronary intervention; PRI = platelet reactivity index; PRU = platelet reactivity units (arbitrary units); STE = ST-elevation; UA = unstable angina; VASP = vasodilator-stimulated phosphoprotein; wk = weeks.

The seven studies are relatively recent (with enrollment started between 2005 and 2009), and had relatively short followup durations (four had maximum followup of 30 days; two, 6 months; and one, a year). Four studies reported a prospective power calculation (and all had attained the enrollment goal). Table 26 summarizes the study design of included studies. Information on the assays used, test timing, and the number of patients screened for inclusion is presented in Table 27.

Table 26 Study design characteristics of studies of test-and-treat strategies using phenotypic testing of platelet reactivity

Author Year Country PMID Study Name (if available) | Enrollment period | Randomization procedure | Blinding | Number of participating centers | Followup duration | Setting | Target enrollment from a priori power analysis | Procedure for multiple comparisons | Funding
Wang270 2011 China 21538380 | August 2008–October 2009 | NR | Endpoints were recorded by an investigator who was not aware of treatment assignment or patient characteristics | Single center | 1 yr | Cardiology department of university hospital | NR | Not used | Nonindustry only
Bonello271 2009 France 19101221 | August 2007–March 2008 | NR | Endpoints were recorded by an investigator who was not aware of treatment assignment or patient characteristics | Multicenter | 30 d | 4 cardiology centers | 400 (429 actually enrolled) | Not used | NR
Bonello272 2008 France 18387444 | March 2007–July 2007 | NR | Endpoints were recorded by an investigator who was not aware of treatment assignment or patient characteristics | Multicenter | 30 d | 4 cardiology centers | 160 (162 actually enrolled) | Not used | Nonindustry only
Tousek273 2011 Czech Republic 21663983 | May 2009–July 2010 | NR | NR | Single center | 6 mo | Cardiology department of university hospital | NR | Not used | Nonindustry only
Aleil274 2008 France 19463377 VASP-02 | April 2005–December 2007 | Centralized randomization; no additional details reported | NR | Multicenter | 30 d^*^ | Multiple cardiology departments | NR | Not used | Partly industry; also assays provided by the manufacturer
Hazarbasanov275 2012 Bulgaria 22249353 | May 2008–June 2009 | NR | Open-label | Single center | 6 mo | Cardiology department of university hospital | 189 (192 actually enrolled) | Not used | Assays provided by the manufacturer
Siller-Matula276 2012 Austria 22656044 MADONNA | March 2007–November 2010 | Not randomized | No blinding | 2 centers; each center applied one of the compared approaches | 30 d | The test-guided treatment group was treated in a university hospital; no details were provided for the center where the non-guided group was treated | 351 patients per group (403 and 395 were actually enrolled) | Not used | NR

* We extracted information at 30 d because this is the only time point when outcomes could have been affected by testing (in the VASP-guided group).

d = days; mo = months; NR = not reported; yr = years.

Table 27 Test information in studies of test-and-treat strategies using phenotypic testing of platelet reactivity

Author Year Country PMID Study Name (if available) | Platelet Reactivity Assay (Manufacturer) | Timing of Test Interval Between Sample Collection and Analysis Interval Between Sampling and Assay Results | N Tested; N Included Test Success Rate | Rationale for the Platelet Reactivity Threshold Chosen
Wang270 2011 China 21538380 | VASP assay (VASP kit; Becton Dickinson, Franklin Lakes, NJ) using flow cytometry (Coulter EPICS XL cytometer, FACSCalibur, Becton Dickinson) | 1 mo post-PCI for all patients; at 3, 6, 9, and 12 mo for patients in the VASP-guided treatment group NR NR | 538 patients screened for inclusion; 306 had PRI >50% and fulfilled all other inclusion criteria NR | Not explicitly provided
Bonello271 2009 France 19101221 | VASP assay (VASP kit; Diagnostica Stago, Asnieres, France) using flow cytometry (Coulter EPICS XL cytometer, Beckman Coulter Inc., Fullerton, CA) | ≥6 h and within 24 h after the initial clopidogrel bolus; in the VASP-guided group, 12 h after each additional clopidogrel bolus NR NR | 1122 patients screened for inclusion; 429 had PRI ≥50% and fulfilled all other inclusion criteria | Statement (in the introduction section) that measurements above the cut-off threshold are associated with higher risk of adverse cardiovascular outcomes; also, a previous randomized study from the same team of investigators.
Bonello272 2008 France 18387444 | VASP assay (VASP kit; Diagnostica Stago, Asnieres, France) using flow cytometry (Coulter EPICS XL cytometer, Beckman Coulter Inc., Fullerton, CA) | 24 h after the initial clopidogrel bolus; in the VASP-guided group, 12 h after each additional clopidogrel bolus NR NR | 406 patients screened for inclusion; 162 had PRI ≥50% and fulfilled all other inclusion criteria | A previous study by the same team of investigators where a threshold of 50% could predict adverse cardiovascular outcomes with a sensitivity of 100%
Tousek273 2011 Czech Republic 21663983 | VerifyNow P2Y12 assay (Accumetrics, San Diego, CA) | 24-48 h after PCI (post–clopidogrel loading); in the VerifyNow-guided group, every 7 days thereafter for up to 30 d NR NR | 378 patients screened for inclusion; 134 had PRU ≥240 and fulfilled all other inclusion criteria; and 60 patients were randomized | Not explicitly provided
Aleil274 2008 France 19463377 VASP-02 | VASP assay (VASP kit; Diagnostica Stago/Biocytex, Asnieres, France) using flow cytometry (FACS Calibur, Becton Dickinson, Plymouth, UK) | Before clopidogrel administration, 10-12 h post clopidogrel dosing, at 2 wk (to identify responders and switch nonresponders in the group originally assigned to 75 mg/d maintenance dose), and at 4 wk (to assess outcomes) | Inclusion was not based on baseline testing; 153 patients were included | Previous studies by the same team of investigators
Hazarbasanov275 2012 Bulgaria 22249353 | Multiplate analyzer (ADP 6.4 μM) (Verum Diagnostica GmBH, Munich, Germany) | 24 h after clopidogrel loading; in patients with high-platelet reactivity measurements were repeated 24 h after the second loading dose and at day 30 during the maintenance phase on 150 mg clopidogrel | Inclusion was not based on baseline testing; 192 patients were included | Consensus recommendations for the definition of high platelet reactivity
Siller-Matula276 2012 Austria 22656044 MADONNA | Multiplate analyzer (ADP 6.4 μM) (Verum Diagnostica GmbH, Munich, Germany) | Measurements were performed the day after PCI, ≥12 h post clopidogrel loading | Inclusion was not based on baseline testing; 798 patients were included | Previous published studies

ADP = adenosine diphosphate; h = hour(s); mo = month(s); NR = not reported; PCI = percutaneous coronary intervention; VASP = vasodilator-stimulated phosphoprotein; PRU = platelet reactivity unit; wk = week(s).

###### Clinical Outcomes

All seven studies comparing alternative test-and-treat strategies reported information on cardiovascular mortality; six also reported on MACE (composite outcomes), five on stent thrombosis, three on acute coronary syndromes (myocardial infarction or unstable angina), three on myocardial infarction alone, two on all-cause mortality, and two on repeat revascularization. Overall, the studies had short followup durations and small to intermediate sample sizes; thus, the outcome rates were low and relative effect estimates (when possible to calculate) were often extreme (e.g., odds ratios <0.5) and had substantial uncertainty (wide CIs). Studies generally indicated that the groups with test-based monitoring had better outcomes (lower event rates) than the groups without test-based monitoring; however, the differences were often not statistically significant. For the outcome of cardiovascular mortality the study by Siller-Matula produced results in the opposite direction of all other studies (indicating worse outcomes with test-based treatment strategies). This may be attributable to potential confounding factors (because the Siller-Matula et al. study was not randomized) or may be a chance finding (confidence intervals were generally broad indicating substantial uncertainty around estimates of effect). Regardless of the reason for the observed inconsistency, it contributed to our decision to grade the strength of evidence for this outcome as insufficient. Detailed outcome information is summarized in Tables 28–33. To facilitate qualitative synthesis, we present forest plots of study estimates for outcomes assessed by at least six studies: cardiovascular mortality (Figure 37), stent thrombosis (Figure 38), and MACE (Figure 39). Meta-analyses were not performed owing to the differences in the populations included, interventions compared, and durations of followup used.

Table 28 Cardiovascular mortality in studies of test-and-treat strategies using phenotypic testing of platelet reactivity

Author Year Country PMID Study Name (if available) | Treatment Group Sample Size | No. with Outcome (%) | Time Point | Comparative Metric | 95% CI | p-value [statistical test]
Wang270 2011 China 21538380 | VASP-guided treatment N=150 | 6 (4.0%) | 1 yr | OR=0.50 (calculated) | 0.18 to 1.37 (calculated) | p=0.003^*^ [unclear]
Wang270 2011 China 21538380 | Control N=156 | 12 (7.7%) | 1 yr | OR=0.50 (calculated) | 0.18 to 1.37 (calculated) | p=0.003^*^ [unclear]
Bonello271 2009 France 19101221 | VASP-guided treatment N=215 | 0 (0%) | 30 d | OR=0.11 (calculated) | 0.01 to 2.03 (calculated) | p=0.06 [Fisher exact test]
Bonello271 2009 France 19101221 | Control N=214 | 4 (1.8%) | 30 d | OR=0.11 (calculated) | 0.01 to 2.03 (calculated) | p=0.06 [Fisher exact test]
Bonello272 2008 France 18387444 | VASP-guided treatment N=78 | 0 (0%) | 30 d | OR=0.21 (calculated) | 0.01 to 4.45 (calculated) | p=0.498 [Fisher exact test; calculated]
Bonello272 2008 France 18387444 | Control N=84 | 2 (2.4%) | 30 d | OR=0.21 (calculated) | 0.01 to 4.45 (calculated) | p=0.498 [Fisher exact test; calculated]
Tousek273 2011 Czech Republic 21663983 | VerifyNow-guided treatment N=30 | 0 (0%) | 6 mo | Not defined | Not defined | NA
Tousek273 2011 Czech Republic 21663983 | Control N=30 | 0 (%) | 6 mo | Not defined | Not defined | NA
Aleil274 2008 France 19463377 VASP-02 | VASP-guided treatment N=95 (93 included in analyses) | 0 (0%) | 30 d | Not defined | Not defined | NA
Aleil274 2008 France 19463377 VASP-02 | Control N=58 | 0 (0%) | 30 d | Not defined | Not defined | NA
Hazarbasanov275 2012 Bulgaria 22249353 | Multiplate analyzer-guided treatment N=97 | 0 (0%) | 6 mo | OR=0.136 | 0.007 to 2.660 (calculated) | p=0.12 [Fisher exact test]
Hazarbasanov275 2012 Bulgaria 22249353 | Control N=95 | 3 (3.2%) | 6 mo | OR=0.136 | 0.007 to 2.660 (calculated) | p=0.12 [Fisher exact test]
Siller-Matula276 2012 Austria 22656044 MADONNA | Multiplate analyzer-guided treatment N=403 | 8 (2%) | 30 d | OR=1.58 (calculated) | 0.51 to 4.87 (calculated) | p=0.422 [statistical test unclear]; p=0.58 (2-sided Fisher exact test; calculated)
Siller-Matula276 2012 Austria 22656044 MADONNA | Control N=395 | 5 (1.3%) | 30 d | OR=1.58 (calculated) | 0.51 to 4.87 (calculated) | p=0.422 [statistical test unclear]; p=0.58 (2-sided Fisher exact test; calculated)

* Although p=0.003 was the reported p-value, recalculation using a chi-square test gives a p-value of 0.170 and recalculation using the Fisher exact test gives a p-value of 0.225. It is unclear how the reported p-value was calculated.

CI = confidence interval; d = days; mo = months; NA = not applicable; NR = not reported; OR = odds ratio; VASP = vasodilator-stimulated phosphoprotein; yr = year.

“Calculated” indicates that the result was not reported by the article's authors; rather, we derived the result from reported raw data.

Table 29 All-cause mortality in studies assessing test-and-treat strategies

Author Year Country PMID Study Name (if available) | Treatment Group Sample Size | No. with Outcome (%) | Time Point | Comparative Metric | 95% CI | p-value [statistical test]
Wang270 2011 China 21538380 | VASP-guided treatment N=150 | NR | 1 yr | NR | NR | p<0.01 [log-rank test
Wang270 2011 China 21538380 | Control N=156 | NR | 1 yr | NR | NR | p<0.01 [log-rank test
Tousek273 2011 Czech Republic 21663983 | VerifyNow-guided treatment N=30 | 0 (0%) | 6 mo | Not defined | Not defined | NA
Tousek273 2011 Czech Republic 21663983 | Control N=30 | 0 (0%) | 6 mo | Not defined | Not defined | NA

CI = confidence interval; mo = months; NA = not applicable; NR = not reported; VASP = vasodilator-stimulated phosphoprotein; yr = year.

Table 30 Stent thrombosis in studies of test-and-treat strategies using phenotypic testing of platelet reactivity

Author Year Country PMID Study Name (if available) | Treatment Group Sample Size | No. with Outcome (%) | Outcome Definition | Time Point | Comparative Metric | 95% CI | p-value [statistical test]
Wang270 2011 China 21538380 | VASP-guided treatment N=150 | 3 (2.0%) | Angiographically confirmed late ST | 1 yr | OR=0.51 (calculated) | 0.13 to 2.08 (calculated) | p=0.03^*^ [unclear]
Wang270 2011 China 21538380 | Control N=156 | 6 (3.8%) | Angiographically confirmed late ST | 1 yr | OR=0.51 (calculated) | 0.13 to 2.08 (calculated) | p=0.03^*^ [unclear]
Bonello271 2009 France 19101221 | VASP-guided treatment N=215 | 1 (0.5%) [subacute thrombosis] | Early definite ST = total occlusion originating in or within 5 mm of the stent or visible thrombus within the stent or within 5 mm of the stent associated with ≥1 of the following signs present within 48 h: new onset of ischemic symptoms at rest; recent changes suggestive of acute ischemia on ECG at rest; typical increase and decrease in cardiac biomarkers according to Academic Research Consortium criteria | 30 d | OR=0.10 (calculated) | 0.01 to 0.75 (calculated) | p<0.01 for early definite stent thrombosis (p=0.25 for acute thrombosis; p=0.02 for subacute thrombosis) [Fisher exact test] p<0.01 [log-rank test]
Bonello271 2009 France 19101221 | Control N=214 | 10 (4.7%) [8 subacute; 2 acute] | | 30 d | OR=0.10 (calculated) | 0.01 to 0.75 (calculated) | p<0.01 for early definite stent thrombosis (p=0.25 for acute thrombosis; p=0.02 for subacute thrombosis) [Fisher exact test] p<0.01 [log-rank test]
Bonello272 2008 France 18387444 | VASP-guided treatment N=78 | 0 (0%) | Early definite ST = angiographic confirmation of ST associated with at least 1 of the following signs present within 48 h: new onset of ischemic symptoms at rest; recent changes suggestive of acute ischemia on ECG at rest; typical increase and decrease in cardiac biomarkers according to Academic Research Consortium criteria | 30 d | OR=0.11 (calculated) | 0.01 to 2.15 (calculated) | p=0.121 [Fisher exact test; calculated]
Bonello272 2008 France 18387444 | Control N=84 | 4 (4.8%) [3 subacute; 1 acute] | | 30 d | OR=0.11 (calculated) | 0.01 to 2.15 (calculated) | p=0.121 [Fisher exact test; calculated]
Hazarbasanov275 2012 Bulgaria 22249353 | Multiplate analyzer-guided treatment N=97 | 0 (0%) | Definite, probable, or possible ST according to Academic Research Consortium criteria | 6 mo | OR=0.104 (calculated) | 0.006 to 1.964 (calculated) | p=0.06 [Fisher exact test]
Hazarbasanov275 2012 Bulgaria 22249353 | Control N=95 | 4 (4.2%) | Definite, probable, or possible ST according to Academic Research Consortium criteria | 6 mo | OR=0.104 (calculated) | 0.006 to 1.964 (calculated) | p=0.06 [Fisher exact test]
Siller-Matula276 2012 Austria 22656044 MADONNA | Multiplate analyzer-guided treatment N=403 | 1 (<1%) | Definite and probable ST = ACS with either angiographic or pathological confirmation of thrombosis, or any unexplained death within 30 days or target vessel MI without angiographic confirmation of thrombosis or other identified culprit lesion, according to Academic Research Consortium criteria | 30 d | OR=0.14 (calculated) | 0.02 to 1.13 (calculated) | p=0.027 [statistical test unclear]; p=0.048 in multivariable adjusted Cox proportional hazards regression; p=0.04 [two-sided Fisher exact test; calculated]
Siller-Matula276 2012 Austria 22656044 MADONNA | Control N=395 | 7 (1.8%) | | 30 d | OR=0.14 (calculated) | 0.02 to 1.13 (calculated) | p=0.027 [statistical test unclear]; p=0.048 in multivariable adjusted Cox proportional hazards regression; p=0.04 [two-sided Fisher exact test; calculated]

* Although p=0.03 was the reported p-value, recalculation using a chi-square test gives a p-value of 0.339 and recalculation using the Fisher exact test gives a p-value of 0.502. It is unclear how the reported p-value was calculated.

ACS = acute coronary syndrome; CI = confidence interval; d = days; ECG = electrocardiogram; h = hour(s); OR = odds ratio; ST = stent thrombosis; VASP = vasodilator-stimulated phosphoprotein; yr = year.

“Calculated” indicates that the result was not reported by the article's authors; rather, we derived the result from reported raw data.

Table 31 Major adverse cardiovascular events (composite) in studies of test-and-treat strategies using phenotypic testing of platelet reactivity

Author Year Country PMID Study Name (if available) | Treatment Group Sample Size | No. with Outcome (%) | Outcome Definition | Time Point | Comparative Metric | 95% CI | p-value [statistical test]
Wang270 2011 China 21538380 | VASP-guided treatment N=150 | 14 (9.3%) | Cardiovascular death, angiographically confirmed ST, recurrent ACS, or recurrent revascularization | 1 yr | OR=0.43 (calculated) | 0.22 to 0.85 (calculated) | p=0.008^*^ [unclear]
Wang270 2011 China 21538380 | Control N=156 | 30 (19.2%) | Cardiovascular death, angiographically confirmed ST, recurrent ACS, or recurrent revascularization | 1 yr | OR=0.43 (calculated) | 0.22 to 0.85 (calculated) | p=0.008^*^ [unclear]
Bonello271 2009 France 19101221 | VASP-guided treatment N=215 | 1 (0.5%) | Cardiovascular death, MI, or urgent repeat revascularization | 30 d | OR=0.05 (calculated) | 0.01 to 0.36 (calculated) | p<0.001 [Fisher exact test]
Bonello271 2009 France 19101221 | Control N=214 | 19 (8.9%) | Cardiovascular death, MI, or urgent repeat revascularization | 30 d | OR=0.05 (calculated) | 0.01 to 0.36 (calculated) | p<0.001 [Fisher exact test]
Bonello272 2008 France 18387444 | VASP-guided treatment N=78 | 0 (0%) | Cardiovascular death, angiographically confirmed ST, recurrent ACS, or repeat revascularization | 30 d | OR=0.06 (calculated) | <0.01 to 1.01 (calculated) | p=0.007 [Fisher exact test] p<0.005 [log-rank p-value; log-rank statistic=7.75]
Bonello272 2008 France 18387444 | Control N=84 | 8 (9.5%) | Cardiovascular death, angiographically confirmed ST, recurrent ACS, or repeat revascularization | 30 d | OR=0.06 (calculated) | <0.01 to 1.01 (calculated) | p=0.007 [Fisher exact test] p<0.005 [log-rank p-value; log-rank statistic=7.75]
Tousek273 2011 Czech Republic 21663983 | VerifyNow-guided treatment N=30 | 1 (3.3%) | Death, MI, or stroke | 6 mo | OR=0.48 | 0.04 to 5.6 | p=0.55 [chi-square test]
Tousek273 2011 Czech Republic 21663983 | Control N=30 | 2 (6.7%) | Death, MI, or stroke | 6 mo | OR=0.48 | 0.04 to 5.6 | p=0.55 [chi-square test]
Aleil274 2008 France 19463377 VASP-02 | VASP-guided treatment N=95 (93 included in analyses) | 1 (1%) [patient was a nonresponder] | CV death, stroke, MI, documented ischemia requiring target-vessel revascularization, or “improvement” of medical treatment | 30 d | OR=1.90 (calculated) | 0.08 to 47.36 (calculated) | p>0.99 [Fisher exact test; calculated]
Aleil274 2008 France 19463377 VASP-02 | Control N=58 | 0 (0%) | CV death, stroke, MI, documented ischemia requiring target-vessel revascularization, or “improvement” of medical treatment | 30 d | OR=1.90 (calculated) | 0.08 to 47.36 (calculated) | p>0.99 [Fisher exact test; calculated]
Hazarbasanov275 2012 Bulgaria 22249353 | Multiplate analyzer-guided treatment N=97 | 0 (0%) | CV death, MI, definite or probable stent thrombosis, or ischemic stroke | 6 mo | OR=0.084 (calculated) | 0.005 to 1.548 | p=0.03 [Fisher exact test]
Hazarbasanov275 2012 Bulgaria 22249353 | Control N=95 | 5 (5.3%) | CV death, MI, definite or probable stent thrombosis, or ischemic stroke | 6 mo | OR=0.084 (calculated) | 0.005 to 1.548 | p=0.03 [Fisher exact test]

* Although p=0.008 was the reported p-value, recalculation using a chi-square test gives a p-value of 0.014 and recalculation using the Fisher exact test gives a p-value of 0.015 (or 0.010 for a one-sided test). It is unclear how the reported p-value was calculated.

ACS = acute coronary syndrome; CI = confidence interval; CV cardiovascular; d = days; mo = months; MI = myocardial infarction; OR = odds ratio; ST = stent thrombosis; VASP = vasodilator-stimulated phosphoprotein; yr=year.

“Calculated” indicates that the result was not reported by the article's authors; rather, we derived the result from reported raw data.

Table 32 Repeat revascularization in studies of test-and-treat strategies using phenotypic testing of platelet reactivity

Author Year Country PMID Study Name (if available) | Treatment Group Sample Size | No. with Outcome (%) | Outcome Definition | Time Point | Comparative Metric | 95% CI | p-value [statistical test]
Wang270 2011 China 21538380 | VASP-guided treatment N=150 | 3 (2.0%) | Recurrent revascularization by coronary angioplasty or CABG | 1 yr | OR=0.33 (calculated) | 0.09 to 1.26 (calculated) | p=0.027^*^ [unclear]
Wang270 2011 China 21538380 | Control N=156 | 9 (5.8%) | Recurrent revascularization by coronary angioplasty or CABG | 1 yr | OR=0.33 (calculated) | 0.09 to 1.26 (calculated) | p=0.027^*^ [unclear]
Bonello271 2009 France 19101221 | VASP-guided treatment N=215 | 0 (0%) | Recurrent revascularization by urgent coronary angioplasty or CABG | 30 d | OR=0.09 (calculated) | <0.01 to 1.61 (calculated) | p=0.06 [unclear]
Bonello271 2009 France 19101221 | Control N=214 | 5 (2.3%) | Recurrent revascularization by urgent coronary angioplasty or CABG | 30 d | OR=0.09 (calculated) | <0.01 to 1.61 (calculated) | p=0.06 [unclear]

* Although p=0.027 was the reported p-value, recalculation using a chi-square test gives a p-value of 0.089 and recalculation using the Fisher exact test gives a p-value of 0.139. It is unclear how the reported p-value was calculated.

CABG = coronary artery bypass grafting; CI = confidence interval; d = days; OR = odds ratio; VASP = vasodilator-stimulated phosphoprotein; yr = year.

“Calculated” indicates that the result was not reported by the article's authors; rather, we derived the result from reported raw data.

Table 33 Recurrent ACS in studies of test-and-treat strategies using phenotypic testing of platelet reactivity

Author Year Country PMID Study Name (if available) | Treatment Group Sample Size | No. with Outcome (%) | Outcome Definition | Time Point | Comparative Metric | 95% CI | p-value [statistical test]
Wang270 2011 China 21538380 | VASP-guided treatment N=150 | 2 (1.3%) | Recurrent ACS | 1 yr | OR=0.69 (calculated) | 0.11 to 4.18 (calculated) | p=0.1^*^ [unclear]
Wang270 2011 China 21538380 | Control N=156 | 3 (2.1%) | Recurrent ACS | 1 yr | OR=0.69 (calculated) | 0.11 to 4.18 (calculated) | p=0.1^*^ [unclear]
Bonello271 2009 France 19101221 | VASP-guided treatment N=215 | 1 (0.5%) | MI | 30 d | OR=0.10 (calculated) | 0.01 to 0.75 (calculated) | p=0.01 [unclear]
Bonello271 2009 France 19101221 | Control N=214 | 10 (4.8%) | MI | 30 d | OR=0.10 (calculated) | 0.01 to 0.75 (calculated) | p=0.01 [unclear]
Bonello272 2008 France 18387444 | VASP-guided treatment N=78 | 0 (0%) | Recurrent ACS | 30 d | OR=0.21 (calculated) | 0.01 to 4.45 (calculated) | p=0.498 [Fisher exact test; calculated]
Bonello272 2008 France 18387444 | Control N=84 | 2 (2.4%) | Recurrent ACS | 30 d | OR=0.21 (calculated) | 0.01 to 4.45 (calculated) | p=0.498 [Fisher exact test; calculated]
Tousek273 2011 Czech Republic 21663983 | VerifyNow-guided treatment N=30 | 1 (3.3%) | MI | 6 mo | OR=0.48 | 0.04 to 5.6 | p=0.55 [unclear]
Tousek273 2011 Czech Republic 21663983 | Control N=30 | 2 (6.7%) | MI | 6 mo | OR=0.48 | 0.04 to 5.6 | p=0.55 [unclear]
Hazarbasanov275 2012 Bulgaria 22249353 | Multiplate analyzer-guided treatment N=97 | 0 (0%) | MI | 6 mo | OR=0.136 | 0.007 to 2.660 (calculated) | p=0.12 [Fisher exact test]
Hazarbasanov275 2012 Bulgaria 22249353 | Control N=95 | 3 (3.2%) | MI | 6 mo | OR=0.136 | 0.007 to 2.660 (calculated) | p=0.12 [Fisher exact test]
Siller-Matula276 2012 Austria 22656044 MADONNA | Multiplate analyzer-guided treatment N=403 | 0 (0%) | ACS = MI or unstable angina | 30 d | OR=0.05 | 0.003 to 0.78 | p=0.001 [unclear statistical test]; p=0.001 [two-sided Fisher exact test; calculated]
Siller-Matula276 2012 Austria 22656044 MADONNA | Control N=395 | 10 (2.5%) | ACS = MI or unstable angina | 30 d | OR=0.05 | 0.003 to 0.78 | p=0.001 [unclear statistical test]; p=0.001 [two-sided Fisher exact test; calculated]

† Although p=0.1 was the reported p-value, recalculation using a chi-square test gives a p-value of 0.684 and recalculation using the Fisher exact test gives a p-value of 1.00. It is unclear how the reported p-value was calculated.

ACS = acute coronary syndrome; CI = confidence interval; d = days; mo = months; MI = myocardial infprction; OR = odds ratio; VASP = vasodilator-stimulated phosphoprotein; yr = year.

“Calculated” indicates that the result was not reported by the article's authors; rather, we derived the result from reported raw data.

Figure 37 Cardiovascular mortality in studies of test-and-treat strategies using phenotypic testing for platelet reactivity

CI = confidence interval; OR = odds ratio. See Table 25 for details on the strategies compared and the definitions of outcomes employed in each study.

Figure 37 is a forest plot depicting cardiovascular mortality in five studies of test-and-treat strategies using phenotypic testing for platelet reactivity. Studies generally indicated that the test-based monitoring study groups had improved outcomes (lower event rates) compared to the non–test-based management groups; however, the differences were often not statistically significant.

Figure 38 Stent thrombosis in studies of test-and-treat strategies using phenotypic testing for platelet reactivity

CI = confidence interval; OR = odds ratio. See Table 25 for details on the strategies compared and the definitions of outcomes employed in each study

Figure 38 is a forest plot depicting stent thrombosis in five studies of test-and-treat strategies using phenotypic testing for platelet reactivity. Studies generally indicated that the test-based monitoring study groups had improved outcomes (lower event rates) compared to the non–test-based management groups; however, the differences were often not statistically significant.

Figure 39 Major adverse cardiovascular events in studies of test-and-treat strategies using phenotypic testing of platelet reactivity

CI = confidence interval; MACE = major adverse cardiovascular events; OR = odds ratio. See Table 25 for details on the strategies compared.

Figure 39 is a forest plot depicting major adverse cardiovascular events in studies of test-and-sreat strategies using phenotypic testing of platelet reactivity. Studies generally indicated that the test-based monitoring study groups had improved outcomes (lower event rates) compared to the non–test-based management groups; however, the differences were often not statistically significant.

###### Intermediate Outcome: Platelet Reactivity During Followup

Four of the seven studies directly comparing alternative test-and-treat strategies reported information on platelet reactivity as an intermediate outcome (Appendix F). Although results generally indicated that platelet reactivity at the last followup assessment was lower in the groups that received test-based treatment than in those that received standard treatment, reporting was often incomplete and precluded statistical comparisons between groups. Furthermore, studies had short followup periods and it was unclear whether the observed differences in reactivity affected clinical outcomes.

###### Assessment of Risk of Bias of Individual Studies

A detailed assessment of 17 risk-of-bias items for studies comparing alternative test-and-treat strategies based on phenotypic testing for platelet reactivity is presented in Appendix F. Generally, the RCTs had moderate risk of bias. Because studies were prospectively conducted and because phenotypic testing is performed immediately after sample collection, the index test was assessed without knowledge of clinical or intermediate outcomes in all cases. However, information to judge whether outcomes were assessed without knowledge of the index-test result was often not reported. Subjects and personnel were not blinded and reporting was incomplete regarding the methods of generating the randomization sequence and concealing allocation. In one study270 we observed substantial discrepancies between the statistical results provided by the authors and results from analyses that we performed using the reported event counts (despite using the same statistical procedures described in the paper's methods section). The single nonrandomized comparative study had high risk of bias because the two groups being compared (test-guided treatment and non-test guided treatment) were enrolled in different research institutions, increasing the probability that results were affected by confounding or selection bias.

One concern about test-and-treat studies conducted in the interventional setting pertains to delaying PCI until a particular level of reactivity is reached (particularly, in studies that perform repeat testing and modify treatment accordingly over the course of several weeks): the time to PCI tends to be longer in the experimental group than in the control group, although only one of the included studies provided relevant data (indicating that the time-to-PCI was indeed longer in patients assigned to test-based monitoring). This delay is potentially of concern because several studies have shown that delayed PCI may adversely impact clinical outcomes.

##### Studies of Treatment-Effect Modification by Baseline Platelet Reactivity

We identified three studies reporting information on effect modification by baseline platelet reactivity in patients randomized to alternative antiplatelet therapies.242,277,278 Detailed information about the patient selection and patient characteristics is summarized in Table 34. Information about the assays used, test timing, and thresholds for platelet reactivity is presented in Table 35.

Table 34 Descriptive characteristics of the study of treatment-effect modification using phenotypic testing of platelet reactivity

Author Year Country PMID Study Name (if available) | Selection Criteria | Study Design | N Enrolled Male (%) Age^*^ Dyslipidemia (%) Smokers (%) HTN (%) Diabetes (%) | Treatments Compared | Followup Duration
Montalescot277 2009 France 20062936 ACAPULCO | Patients with UA or NSTE MI who were to receive clopidogrel 900 mg loading dose | RCT comparing antiplatelet treatments in patients who were assed for platelet reactivity after a run-in period, before randomization | N=56 47 (84%) 61 (12) 9 (16%) 17 (30%) [current smokers] 37 (66%) 11 (20%) | Patients received clopidogrel 900 mg loading dose (single dose or cumulative dose when <900 mg had been previously admitted and aspirin (250-500 mg IV loading dose). They were then randomized to 2 groups: Prasugrel +aspirin group: prasugrel 10 mg maintenance dose + aspirin (maximum 100 mg/d) + placebo (instead of clopidogrel) Clopidogrel + aspirin group: clopidogrel 150 mg maintenance + aspirin (maximum 100 mg/d) + placebo (instead of prasugrel) After 2 wk patients were switched to the other group (crossover design) for another 2 wk. | Total study duration was 29 d; patients were on each treatment for 2 w (crossover design)
Capranzano278 2012 USA 22431415 | Stable CAD patients on maintenance therapy with aspirin (81 mg/d) and clopidogrel (75 mg/d) | Crossover RCT comparing dual antiplatelet therapy (aspirin + clopidogrel) to triple therapy (aspirin + clopidogrel + cilostazol) | N=79 53 (67%) 60.8 (8.5) 77 (98%) 30 (38%) 72 (91%) 40 (51%) | Patients on aspirin + clopidogrel treatment and were randomized to receive cilostazol (100 mg twice daily) or placebo for 14 days. Patients then crossed over to the alternative treatment for an additional 4 days. | Total study duration was 28 d; patients were on each treatment for 2 w (crossover design)
Sibbing242 Germany 2012 22682553 ISAR-REACT 4 | Patients undergoing PCI for NSTE-MI | Parallel arm RCT comparing abciximab with heparin vs. bivalirudin antithrombotic treatment for PCI | N=564 438 (78%) 67.7 (10.8) 176 (31%) 124 (22%) 504 (89%) 176 (31%) | Patients received clopidogrel loading dose (600 mg) + aspirin (500 mg) pre-PCI; post-PCI treatment consisted of clopidogrel 2 × 75 mg/d for 3 days, followed by 75 mg/d for a recommended duration of 12 mo. Aspirin 2 × 100 mg/d indefinitely was also recommended. During PCI patients were randomized into 2 groups: Abciximab + UFH: bolus of 0.25 mg abciximab as well as a bolus dose of 70 units UFH per kilogram body weight, followed by a continuous infusion of abciximab 0.125 μg/kg body weight per minute for 12 h Bivalirudin: bolus bivalirudin 0.75 mg/kg, followed by a continuous infusion of 1.75 mg/kg per hour during PCI | 30 d post randomization

* Mean (standard deviation), unless otherwise stated.

CAD = coronary artery disease; d = day(s); HTN = hypertension; MI = myocardial infarction; NSTE = non–ST-elevation; PCI = percutaneous coronary intervention; RCT = randomized controlled trial; UA = unstable angina; UFH = unfractionated heparin; wk = week(s).

Table 35 Test information in the study of treatment-effect modification using phenotypic testing of platelet reactivity

Author Year Country PMID Study Name (if available) | Assay for Phenotypic Testing (agonist) [manufacturer] | Test Timepoint Interval Between Sampling and Genotyping Results Interval Between Collection and DNA extraction | N Tested Test Success Rate (%) | Threshold Used | Rationale for Threshold
Montalescot277 2009 France 20062936 ACAPULCO | LTA (ADP 5 and 20 μM) [Model 490-4D aggregometer, Chrono-Log Corporation, Kordia, Netherlands] VerifyNow P2Y12 (ADP) [Accumetrics, San Diego, CA] VASP assay (VASP kit; Biocytex, Marseilles, France) using flow cytometry (no additional details provided) | Pre-loading dose, 6-18 h after the 900 mg loading dose, and 16-28 h after the last maintenance dose at 2 w and 4 w | 54 subjects received maintenance dose; 41 subjects completed the study; test success rate was not estimable | For maximal platelet reactivity by LTA ADP 20 μM: >50% For residual platelet aggregation by LTA ADP 5 μM: >14% For VASP PRI: ≥50% For VerifyNow PRU: ≥240 units | Based on prior literature (citations provided for each threshold)
Capranzano278 2012 USA 22431415 | For assessing effect modification and outcomes: VerifyNow P2Y12 (ADP) [Accumetrics, San Diego, CA] For assessing outcomes only: LTA (ADP 5 and 20 μM) [Model 490 aggregometer, Chrono-Log Corporation, Havertown, PA] VASP assay (VASP kit; Biocytex, Marseilles, France) using flow cytometry (no additional details provided) | Blood samples were collected 2–4 h after intake of antiplatelet medications at the following time-points: before randomization; 14 d after randomization; 14 d after crossover | Analyses were reported on 79 patients who completed the trial and had reactivity measurements; the parent trial enrolled 111 patients of whom 23.4% withdrew within 48-72 h due to adverse effects | For maximal platelet reactivity by LTA ADP 20 μM: >50% For residual platelet aggregation by LTA ADP 5 μM: >14% For VASP PRI: ≥50% For VerifyNow PRU: >240 units | Based on prior literature (citations provided for the threshold)
Sibbing242 Germany 2012 22682553 ISAR-REACT 4 | Multiplate analyzer (ADP) [Verum Diagnostica, Munich, Germany) | Samples for the assessment of platelet reactivity were obtained before PCI and prior to the administration of study drug treatment | The platelet substudy was conducted in 2 centers enrolling 1195 (of the total 1721 included in the trial) of these 564 had platelet reactivity measurements available | ≥468 AU × min | Based on prior literature and a consensus document (citations provided for the threshold)

ADP = adenosine triphosphate; AU = arbitrary units; h = hours; LTA = light-transmission aggregometry; PRI = platelet reactivity index; PRU = platelet reactivity units; VASP = vasodilator-stimulated phosphoprotein; wk = week(s).

###### Clinical Outcomes

One study (based on the ISAR-REACT 4 trial) reported information on clinical outcomes. In the platelet reactivity sub-cohort of this trial, 205 patients (36 percent) had high on-clopidogrel platelet reactivity at the time of PCI (35.0 percent in the abciximab + heparin group vs. 37.6 percent in the bivalirudin group). A significant interaction was observed between study treatment arm and platelet aggregation regarding the combined efficacy endpoint (death, MI, or urgent target vessel revascularization; P for interaction = 0.037). Table 36 summarizes the findings for other clinical outcomes assessed in the study; significant effect modification was also observed for recurrent MI and a composite of recurrent myocardial infarction and death.

Table 36 Descriptive characteristics of the study of treatment-effect modification using phenotypic testing of platelet reactivity

Author, Year Country PMID Study name (if available) | Outcome | Abciximab + UFH (high platelet reactivity) N=96 | Abciximab + UFH (normal platelet reactivity) N=178 | Bivalirudin (normal platelet reactivity) N=109 | Bivalirudin (High platelet reactivity) N=181 | Interaction p-value
Sibbing242 2012 Germany 22682553 ISAR-REACT 4 | MACE = death, MI, or urgent TVR | 9 | 12 | 24 | 9 | p=0.037 [reported]; p=0.032 [calculated]
Sibbing242 2012 Germany 22682553 ISAR-REACT 4 | Death | 1 | 3 | 1 | 1 | p=0.586 [calculated]
Sibbing242 2012 Germany 22682553 ISAR-REACT 4 | Any recurrent MI | 8 | 11 | 22 | 8 | p=0.034 [calculated]
Sibbing242 2012 Germany 22682553 ISAR-REACT 4 | Death or any recurrent MI | 9 | 12 | 23 | 9 | p=0.040 [calculated]
Sibbing242 2012 Germany 22682553 ISAR-REACT 4 | Urgent TVR | 0 | 1 | 2 | 0 | p=0.246 [calculated]
Sibbing242 2012 Germany 22682553 ISAR-REACT 4 | Definite stent thrombosis | 0 | 1 | 1 | 0 | p=0.364 [calculated]

When needed, a continuity correction of 0.5 was used. P-values are calculated for a z-score comparison between log-odds ratios for the reactivity effect within each treatment group.

MACE = major adverse cardiovascular events; MI = myocardial infarction; TVR = target vessel revascularization; UFH = unfractionated heparin.

The remaining two studies did not report patient-relevant clinical outcomes stratified by platelet reactivity status at baseline. In one of them, one death (due to cancer) was observed and was not considered treatment related.

###### Intermediate Outcome: Platelet Reactivity During Followup

Two studies reported information on platelet reactivity during followup. The first278 was a post-hoc evaluation based on a crossover RCT comparing triple therapy (aspirin, clopidogrel, and cilostazol) to double therapy (aspirin + clopidogrel + placebo) for patients with stable coronary artery disease. Among patients with high-platelet reactivity the mean change in platelet reactivity pre- and post-cilostazol (as assessed with the VerifyNow assay) was 53.4 platelet reactivity units (95% CI 24.7 to 82.1). Among patients with normal platelet reactivity the mean change in reactivity was 40.8 platelet reactivity units (95% CI 28.7 to 52.8). Based on these results we calculated that the p-value for interaction was 0.428 indicating that baseline platelet reactivity did not modify the effect of cilostazol on subsequent measurements.

The second study277 reported the response rate among “poor responders” to the clopidogrel loading dose during prasugrel-based therapy and during clopidogrel-based therapy. Generally the response rates were higher during prasugrel therapy, regardless of the assay used to assess platelet reactivity. However, the study did not report the response status during followup for patients who were “responders” to the clopidogrel loading dose. Thus, the interaction between post–loading dose response to clopidogrel and treatment assignment could not be assessed.

###### Assessment of Risk of Bias

One study was considered to have a high risk of bias because outcome information was incompletely reported and information on the generation of the randomized sequence and allocation concealment was unclear. Another study was considered to have high risk of bias because it was a post hoc assessment based on a convenience sample enrolled in a crossover trial and because the parent trial had a large withdrawal rate (23 percent). The third study (the one reporting on clinical outcomes) had a moderate risk of bias. This study was based on a large randomized trial; however, only 564 (of a total of 1721) patients were included, representing a convenience sample of patients treated at centers where platelet reactivity testing was available. Furthermore, patients were included only if they attended the study locations at “core times” when the laboratory was operational. These aspects of the design render the study susceptible to selection bias; this concern was substantiated by the presence of differences in the distribution of several risk factors between patients included in the parent trial and those included in the platelet reactivity substudy.

Detailed information for each item considered in the risk-of-bias assessment is given in Appendix F.

##### Studies With Phenotypic Test–Based Selection of Patients

Fourteen studies met our inclusion criteria and reported information on the comparative effectiveness of treatments administered to patients selected on the basis of baseline platelet reactivity. The sample sizes ranged from 21 to more than 2000 participants and all 14 studies were relatively recent (published in 2008–2012). Eleven studies were performed mainly or exclusively in the PCI setting, two studies included patients with stable coronary artery disease (non-interventional setting), and one study enrolled patients on chronic hemodialysis receiving clopidogrel treatment. On-clopidogrel platelet reactivity was used as a selection criterion in all studies; it was assessed using the VerifyNow P2Y12 assay in nine studies, LTA in three studies, the VASP assay with flow cytometry in two studies; other assays in two studies (one study combined measurements from three assays to define high on-treatment reactivity). The treatment comparisons were between standard-dose clopidogrel-based therapy and high-dose clopidogrel in six studies, prasugrel in four studies, ticagrelor in two studies, and addition of a glycoprotein IIb/IIIa inhibitor in two studies.

Detailed information on patient selection, study design, patient characteristics, and assays used is summarized in Table 37.

Table 37 Descriptive characteristics of the studies with phenotypic test–based selection of patients

Author, Year Country PMID Study name (if available) | Selected Population | Study Design Treatment Strategies Compared | Assay (agonist) [model, manufacturer] | Total N Enrolled Male (%) Age^*^ Dyslipidemia (%), Smokers (%), HTN (%), Diabetes (%)
Price203^†^ 2011 Multinational 21406646 GRAVITAS | Patients who had PCI with ≥1 drug-eluting stent for treating stable CAD or NSTE ACS; after protocol amendment, enrollment was expanded to include patients with STE MI. Patients on IIb/IIIa inhibitors were excluded. In patients with no prior exposure to clopidogrel, a dose of 600 mg had to have been administered ≤2 h post-PCI; patients already on clopidogrel must have received 75 mg/d for ≥7 d, or, if <7 d, a loading dose ≥300 mg when clopidogrel was started. | Double-blind, placebo-controlled RCT, multicenter Platelet reactivity was measured 12-24 h post-PCI. Patients with high-on treatment reactivity (PRU≥230) were randomized (central randomization, double-blind design) to two groups (standard- and high-dose clopidogrel). Also included a nonrandomized comparator arm of randomly selected patients among those without high on-clopidogrel reactivity (PRU <230); information on this group of patients has been summarized in the report section on Key Question 2b. High-dose clopidogrel: total 1st day dose 600 mg, followed by 6-mo maintenance dose 150 mg/d Standard-dose clopidogrel: loading dose of placebo, followed by a dose of 75 mg/d + a placebo tablet Aspirin treatment (75-162 mg/d) was required for both groups. | For selecting patients and for assessing reactivity as an outcome: VerifyNow P2Y12 (ADP) [Accumetrics, San Diego, CA] | 2214 (with PRU≥230) in the randomized groups; 586 (with PRU <230) in the randomly selected comparator group^†^ 1441 (65%) 64.1 (10.5) 1934 (87%) 313 (14%) [current smokers] 1886 (85%) 1004 (45%)
Palmerini228 2010 Italy 19604542 DOUBLE | Patients with STE MI referred to a single center for PCI within 12 h of symptom onset | Randomized, single-center All patients received clopidogrel loading (300 mg); periprocedural abciximab and BMS were mandatory. Platelet reactivity was measured at baseline (after a loading dose of 300 mg and the first maintenance dose of 75 mg) and patients with PRI VASP <30% were excluded. Patients had been randomized before the first reactivity assessment into two groups (high- and standard-dose maintenance clopidogrel) High-dose clopidogrel maintenance: 150 mg/d for 1 mo Standard-dose clopidogrel maintenance: 75 mg/d for 1 mo All patients were on aspirin treatment (160 mg/d) | For selecting patients: Platelet VASP kit (ADP± PGE1) [Biocytex, Marseille, France] For assessing reactivity as an outcome: Platelet VASP kit (ADP± PGE1) [Biocytex, Marseille, France], LTA (NR) [Chronolog 700; no additional details provided], VerifyNow P2Y12 (ADP) [NR], whole blood impedance aggregometry (NR) [NR] | 52 eligible (with VASP PRI ≥30%); 48 included in analyses (7.7% excluded) 43 (90%) 63 (12.2) 21 (44%) 32 (67%) [current or former smokers] 23 (48%) 8 (17%)
Valgimigli206 2009 Multinational (Italy, Belgium, France, Spain) 19528337 3T/2R | Patients scheduled for coronary angiography, PCI, or both; presenting with stable or troponin-negative NSTE ACS were screened for inclusion; patients with evidence of myocardial damage or ongoing MI were excluded. | Patients were eligible for aspirin response evaluation (cut-off 550 units) if they were taking aspirin orally at doses of ≥80 mg/d for ≥5 days or received intravenous 500 mg aspirin ≥15 minutes before and did not receive clopidogrel or ticlopidine in the previous 7 days. Patients with aspirin poor responsiveness qualified for randomization before PCI only when clopidogrel screening requirements were met. Screening for clopidogrel response (cut-off: 40% inhibition) was undertaken in patients at steady state for aspirin provided ≥1 of the following requirements was fulfilled: the patient received a 600- or 300-mg loading dose ≥2 or 6 hours before, respectively, or the patient received a 75-mg maintenance clopidogrel dose for ≥7 consecutive days. Patients who were poor responders to both aspirin and clopidogrel followed the aspirin poor-responders randomization scheme. IIb/IIIa inhibitor group: tirofiban 50 mL diluted in 200 mL of 0.9% NaCl solution Placebo group: 50 mL of 0.9% NaCl was injected in 200 mL of 0.9% NaCl solution by an unblinded research study nurse (all other personnel were blinded to treatment assignment). Tirofiban was given as a bolus of 25 μg kg^-1^ 3 min^-1^, followed by an infusion of 0.15 μg kg^-1^ min^-1^ for 14 to 24 h. Intravenous aspirin at the time of PCI in patients at steady state for the treatment was allowed and left to the discretion of the treating physician. Anticoagulation during PCI was with heparin or bivalirudin. Rescue use of tirofiban was allowed (without unblinding). | VerifyNow P2Y12 (ADP) [Accumetrics, San Diego, CA] VerifyNow Aspirin (AA) [Accumetrics, San Diego, CA] | 337 patients were poor responders to aspirin or clopidogrel; 174 were poor responders to clopidogrel alone; 26 were poor responders to both; 73 patients were excluded pre-randomization; 263 patients were randomized (147 were exclusively clopidogrel poor responders). For all randomized patients: 193 (73%) 68.2 (9.7) 141 (54%) 40 (15%) [current smokers] 188 (71%) 69 (26%)
Cuisset279 2008 France 19463379 | Patients with stable angina or a positive functional study with planned PCI with stent implantation of a de novo lesion in a native coronary artery; all patients were on chronic aspirin therapy (75 mg/d) and none were on clopidogrel | Blood samples were obtained ≥12 h after the loading dose of aspirin and clopidogrel; clopidogrel nonresponders (>70% on-clopidogrel reactivity used as the cut-off) were randomized to a IIb/IIIa inhibitor group or a conventional treatment group. Loading dose of clopidogrel (600 mg) and aspirin (250 mg) were administered the day before the procedure. Response was assessed ≥12 h after the loading dose of aspirin and clopidogrel; nonresponders were then randomized into the following groups: IIb/IIIa inhibitor group: systematic administration of abciximab to all patients. Conventional treatment group: use of IIb/IIIa agonists left at the discretion of physicians. Abciximab was administered with a 0.25 mg/kg of body weight bolus, followed by a 0.125 μg/kg/min [maximum, 10 μg/min] infusion for 12 h).Anticoagulation during the procedure was with heparin (50 U/kg in the IIb/IIIa group vs. 70 U/kg in the conventional treatment group). After discharge all patients received aspirin (75 mg) and clopidogrel (150 mg) maintenance doses for at least 1 mo. | LTA (ADP) [PAP4 aggregometer; Biodata Corporation; Wellcome, Paris, France] | 149 nonresponders to clopidogrel 113 (76%) 65 (8.6) 111 (74%) 58 (39%) 93 (62%) 56 (38%)
Gurbel162^††^ 2010 Multinational (N. America and Europe) 20194878 RESPOND | Patients with documented stable CAD who were on aspirin therapy (75-100 mg/d) | All patients received a loading dose of clopidogrel (300 mg) and response was assessed at 6-8 h post-loading. Nonresponse was defined as absolute change post-loading ≤10%; response status was confirmed 2-4 w before the first dose of study drug Both responders and nonresponders were randomized to 2 groups during period 1: Clopidogrel: clopidogrel 600 mg loading dose, followed by clopidogrel 75 mg/d maintenance for 14 d Ticagrelor: ticagrelor 180 mg loading dose, followed ticagrelor 90 mg BID maintenance dose In period 2, all nonresponders switched treatment, whereas half of the responders continued the same treatment, and the other half of the responders switched to the other treatment; both groups were treated for an additional 14 d. Patients continuing on the same treatments in both study periods did not receive loading doses of study drug during period 2. Switching patients received loading doses of the new drug. In addition to study drug, all patients received concomitant aspirin therapy (75 to 100 mg/d). | For assigning patients to randomized groups: LTA (ADP 20 μmol/L) [Chronolog Optical Aggregometer, model 490-4D; no other details] For response assessment: LTA (ADP 5 and 20 μmol/L, and collagen 2 μg/mL) [Chronolog Optical Aggregometer, model 490-4D; no other details], VerifyNow P2Y12 (ADP) [Accumetrics, San Diego, CA], Platelet VASP kit (ADP± PGE1) [Biocytex, Marseille, France], ADP-stimulated glycoprotein IIb/IIIa and P-selectin expression by flow cytometry [no other details] | 98 76 (78%) 65 (8) 92 (94%) 17 (17%) [current smokers] 79 (81%) 25 (26%)
Alexopoulos280 2012 Greece 22789884 | Consecutive patients with ACS undergoing PCI with stent implantation; patients receiving IIb/IIIa inhibitors were excluded | Single-blind, crossover RCT, single center At the time of PCI, clopidogrel-naive patients and those on clopidogrel 75 mg for <7 days without initial loading dose received a 600-mg clopidogrel. Patients on clopidogrel <7 days but with 300-mg loading or those on clopidogrel for >7 days did not receive any additional loading. All patients received an intra-arterial dose of 70 international units (IU)/kg heparin. After PCI, all patients received aspirin 100 mg/day indefinitely. Patients with HTPR were then randomized in a 1:1 ratio to ticagrelor 90 mg, 2 × daily or prasugrel 10 mg/d, until d 15 post-randomization. At 15 ±2 d platelet reactivity was assessed and patients crossed-over directly to the alternate therapy for an additional 15 days (no washout) | VerifyNow P2Y12 (ADP) [Accumetrics, San Diego, CA] | 44 (with PRU ≥235) 37 (84%) 60 (9) 22 (50%) 28 (64%) 25 (57%) 10 (23%)
Gremmel281 2011 Austria 21546102 | Patients undergoing angioplasty with stenting for CAD | With the exception of 2 patients (4.5%), who were already on continuous clopidogrel therapy, all patients received a loading dose of 300 (n = 33, 75%) or 600 mg (n = 9, 20.5%) clopidogrel prior to PCI. All patients received daily acetylsalicylic acid therapy (100 mg/d). Patients were then randomized into the following groups: High maintenance dose group: 100 mg aspirin and 150 mg clopidogrel per day for 3 mo post-PCI Standard dose group: aspirin 100 mg/d and clopidogrel 75 mg/d | VerifyNow P2Y12 (ADP) [Accumetrics, San Diego, CA], Platelet VASP (ADP± PGE1) [Diagnostica Stago, Biocytex, Marseille, France], Multiplate analyzer impedance aggregometry (ADP+PGE1) [Dynabyte, Munich, Germany] | 44 patients (46 enrolled with 2 excluded due to non-adherence) with high reactivity on at least one of the 3 tests (PRU >235 or PRI >50% or AU ≥47) 30 (68) 68 (12) NR 18 (41%) NR 20 (45%)
Alexopoulos282 2011 Greece 21985070 | Patients on regular maintenance hemodialysis (>6 mo) | Single-blind, crossover RCT, single center Hemodialysis patients who were receiving clopidogrel 75 mg/d maintenance treatment (>2 mo) underwent platelet reactivity testing. Those with high on-clopidogrel platelet reactivity were randomized in a 1:1 ratio to clopidogrel (150 mg/d) or prasugrel (10 mg/d), until d 15 post-randomization. At 15 ±2 d platelet reactivity was assessed again and patients crossed-over directly to the alternate therapy for an additional 15 d (no washout) | VerifyNow P2Y12 (ADP) [Accumetrics, San Diego, CA] | 21 patients with PRU ≥ 235 14 (67%) 61.2 (12) 15 (71%) 5 (24%) 18 (86%) 10 (48%)
Alexopoulos283 2011 Greece 21982667 | Consecutive patients on clopidogrel treatment (75/d) for >12 mo | Single-blind, crossover RCT, single center Patients had been receiving clopidogrel 75 mg/d for >12 mo when they underwent platelet reactivity testing. Those with high on-clopidogrel reactivity were randomized in a 1:1 ratio to clopidogrel (150 mg/d) or prasugrel (10 mg/d), until d 14 post-randomization. At 14 ±2 d platelet reactivity was assessed again and patients crossed-over directly to the alternate therapy for an additional 15 d (no washout) | VerifyNow P2Y12 (ADP) [Accumetrics, San Diego, CA] | 31 patients with PRU ≥235 24 (86%) 69 (9) 27 (96%) 4 (14%) 24 (86%) 12 (43%)
Ari216 2012 Turkey EFFICIENT 21239075 | Patients undergoing elective PCI | Non-blinded, active-control RCT, 2 centers Patients were taking aspirin (100 mg/d) for ≥ 5 d and clopidogrel (75 mg/d) for ≥ 3 d before intervention. Platelet reactivity was measured “just before” PCI. Patients with clopidogrel resistance (platelet inhibition <40%) were randomized to two treatment groups; patients with adequate response to clopidogrel (platelet inhibition ≥40%) were included as a non-randomize comparator arm treated with clopidogrel (75 mg/d); information on this group of patients is summarized in the report section on Key Question 2b. Randomized patients were assigned to the following two groups: High-dose clopidogrel: clopidogrel 150 mg/d for 1 mo + aspirin (100 mg/d) Standard-dose clopidogrel: clopidogrel 75 mg/d for 1 mo + aspirin (100 mg/d) | For selecting patients to randomize: VerifyNow P2Y12 (ADP) [Accumetrics, San Diego, CA] The VerifyNow Aspirin (AA) [Accumetrics, San Diego, CA] test was also used but not as a method for selecting patients | 94 patients with platelet inhibition <40% included in the randomized comparison 72 (77%) 58 (10) NR 62 (66%) 47 (50%) 27 (29%)
Trenk284 2012 Multinational (North America and Europe) 22520250 TRIGGER-PCI | Consecutive patients with stable CAD and clinical indications for PCI, who had undergone successful, elective coronary placement of at least 1 DES, were screened for inclusion. To be eligible for screening patients had to have been pre-treated with a loading dose of clopidogrel (600 mg) with aspirin (≥250 mg) within 24 h of the PCI; patients who had received IIb/IIIa inhibitors were excluded | Single-blind (assessors); placebo-controlled, multicenter Patients were pre-treated with a loading dose of clopidogrel (600 mg) + aspirin (≥250 mg) within 24 h of PCI. Reactivity testing was performed between 2-7 h after the first clopidogrel 75 mg maintenance dose the morning after PCI. Patients with high on-clopidogrel reactivity were randomized 1:1 to the following two groups: Prasugrel + placebo: prasugrel (60 mg) loading dose within 9 h after administration of the non-study-related clopidogrel maintenance dose (75 mg), followed by maintenance treatment of prasugrel 10 mg/d + placebo, starting the day after the loading dose of the study drug Clopidogrel + placebo: placebo loading dose within 9 h after administration of the non-study-related clopidogrel maintenance dose (75 mg), followed by maintenance treatment of clopidogrel (75 mg) + placebo, starting the day after the loading dose of the study drug | VerifyNow P2Y12 (ADP) [Accumetrics, San Diego, CA] | 625 patients with PRU >208; 423 randomized for whom descriptive characteristics were reported (202 declined) 307 (73%) 66 (8) NR 61 (14%) 376 (89%) 177 (42%)
Aradi181 2012 Hungary 21902692 DOSER | Clopidogrel-naïve patients with stable angina and significant de novo coronary stenosis amenable to ad hoc coronary stent implantation | Double-blind; placebo-controlled; single center Immediately after coronary angiography and before PCI, patients received a clopidogrel loading dose (600 mg) + aspirin (300 mg). Use of glycoprotein IIb/IIIa inhibitors was prohibited. Reactivity assessment was performed 12-24 h after clopidogrel loading. Patients with high on-clopidogrel reactivity were randomized into 2 groups: Standard dose clopidogrel: clopidogrel maintenance at a dose of 75 mg/d for 1 mo High-dose clopidogrel: clopidogrel maintenance 150 mg/d for 1 mo After 28 days, all patients returned to 75 mg maintenance dose of clopidogrel until 1 year. The study also included a non-randomized comparator arm consisting of all patients with normal platelet reactivity; information on this group of patients has been summarized in the report section on Key Question 2b. | For selecting patients to randomize: LTA (ADP) [CARAT TX4 four-channel light transmission aggregometer; Carat Diagnostics, Budapest, Hungary] For response assessment: LTA (ADP) [CARAT TX4 four-channel light transmission aggregometer; Carat Diagnostics, Budapest, Hungary]; Platelet VASP (ADP ± PGE1) [Biocytex, Marseilles, France], | 74 patients with LTA maximal aggregation >= 46% were randomized 39 (53%) 62 (8) 41 (55%) 37 (50%; current + past) 63 (85%) 32 (43%)
Tang247 2012 China 22490487 | Patients admitted for PCI who underwent successful coronary stenting | All patients received 300 mg of clopidogrel and aspirin at least 12 hours before the stenting. In the following three days after coronary stenting, patients received 100 mg of aspirin and 75 mg of clopidogrel per day. Three days after implantation of the stenting, peripheral venous blood samples for TEG were obtained. Patients with high-on treatment reactivity (to aspirin and clopidogrel) were randomized into 2 treatment groups: Standard dual antiplatelet treatment: aspirin 100 mg/d + clopidogrel (75 mg/d) High dose dual antiplatelet therapy: aspirin (200 mg/d) + clopidogrel (150 mg/d) The study also included a non-randomized comparator arm consisting of all patients with normal platelet reactivity; information on this group of patients has been summarized in the report section on Key Question 2b. | TEG analyzer (the device uses 4 channels: kaolin, activating agent A, arachidonic acid, and ADP) [Haemoscope Corporation, Niles, Illinois, USA] | 60 patients had platelet inhibition <50% and were randomized 29 (48%) 63 (14) 13 (22%) 38 (63%; current) 31 (52%) 14 (23%)
Alexopoulos285 2011 Greece 21511219 | Consecutive patients undergoing PCI with stent implantation | Single-blind, crossover RCT, single center At the time of PCI, clopidogrel-naive patients and those on clopidogrel 75 mg for <7 days without initial loading dose received clopidogrel (600 mg). Patients on clopidogrel <7 days but with 300 mg loading or those on clopidogrel for >7 days did not receive any additional loading. All patients received an intra-arterial dose of 70 IU/kg heparin. After PCI, all patients received aspirin 325 mg/d for 1 mo followed by 100 mg/d indefinitely. Patients with HTPR were then randomized in a 1:1 ratio to prasugrel 10 mg/d or clopidogrel 150 mg/d, until d 30 post-randomization. At 30 ±2 d platelet reactivity was assessed and patients crossed-over directly to the alternate therapy for an additional 30 days (no washout) | VerifyNow P2Y12 (ADP) [Accumetrics, San Diego, CA] | 71 patients with PRU ≥235 were randomized but 64 considered in analyses (2 dropouts for side effects; 5 for non-compliance) 57 (89%) 65 (11) 41 (64%) 30 (47%) 43 (67%) 23 (36%)

* Mean (standard deviation), unless otherwise stated.

† Patient characteristics extracted only for patients in the randomized groups (i.e., patients with PRU ≥ 230 randomly assigned to high- or low-dose clopidogrel strategies).

†† Despite including both responders and nonresponders, this study was categorized as a study of randomized treatment after test-based selection because patients were assigned to different treatments during the course of the study based on their original response status.

AA = arachidonic acid; ACS = acute coronary syndrome; ADP = adenosine diphosphate; BMS = bare-metal stent; CAD = coronary artery disease; d = day; h = hour; HTN = hypertension; HTPR = high on-treatment platelet reactivity; IU = international units; LTA = light-transmission aggregometry; MI = myocardial infarction; mo = month; NR = not reported; NSTE = non–ST-elevation; PCI = percutaneous coronary intervention; PGE1 = prostaglandin E1; PMID = PubMed identification number; PRI = platelet reactivity index; PRU = platelet reactivity units; RCT = randomized controlled trial; SD = standard deviation; STE = ST-elevation; TEG = thromboelastography; VASP = vasodilator-stimulated phosphoprotein; w = week(s).

###### Clinical Outcomes

Clinical outcome comparisons between the randomized treatment groups were reported in 10 of the 14 studies. Only two trials (the GRAVITAS [Gauging Responsiveness with a VerifyNow Assay—Impact on Thrombosis and Safety] and the TRIGGER-PCI [Testing Platelet Reactivity In Patients Undergoing Elective Stent Placement on Clopidogrel to Guide Alternative Therapy With Prasugrel] trials) reported data from more than 100 randomized patients; we briefly discuss their key results here.

The GRAVITAS trial,203 enrolling 2214 randomized patients—included patients who had undergone PCI for stable coronary artery disease or non–ST-elevation acute coronary syndrome and showed increased on-clopidogrel reactivity on the VerifyNow P2Y12 assay. The patients were randomized to high-dose clopidogrel or standard-dose clopidogrel, both in combination with aspirin. After 6 months of followup, there was no statistically significant difference between the randomized groups in the rate of cardiovascular death, nonfatal myocardial infarction, stent thrombosis, all-cause mortality, or composite cardiovascular outcomes (either cardiovascular death or nonfatal myocardial infarction, or cardiovascular death, nonfatal myocardial infarction, or stent thrombosis). The study also included followup information for a randomly selected group of patients with low platelet reactivity at baseline who were treated with standard-dose clopidogrel (see the Results section for Key Question 1b for details).

The TRIGGER-PCI study284 compared prasugrel versus standard dose clopidogrel in 423 patients with high on-clopidogrel platelet reactivity (as measured by the VerifyNow P2Y12 assay). After 236 patients had completed the planned 6 month followup, a blinded interim review identified that a single primary endpoint event had been observed. Because of the very low event rate the trial was terminated early for futility. As such, for all outcomes, event rates were very low and differences in event rates between groups were not statistically significant.

The remaining 12 studies smaller sample sizes (ranging from 21 to 159 patients) and also had relatively short followup durations. Detailed information on clinical outcomes from all studies is presented in Table 38. Because the patient populations were heterogeneous, selected on the basis of different inclusion criteria, and assessed using different therapeutic regimens, we did not perform meta-analyses for any of the outcomes reported.

Table 38 Key findings of studies with phenotypic test–based selection of patients and clinical outcomes

Author Year Country PMID Study Name (if available) | Treatment Groups (sample size) | Followup Duration | Summary of Findings
Price203 2011 Multinational 21406646 GRAVITAS | High-dose clopidogrel (n=1109): total first day dose 600 mg, followed by a maintenance dose of 150 mg/d for 6 mo Standard-dose clopidogrel (n=1105): loading dose of placebo, followed by a dose of 75 mg/d + a placebo tablet | 6 mo | Randomized comparison^*^: CV death, nonfatal MI, or stent thrombosis: HR=1.01 (95% CI, 0.58 to 1.76); p=0.97 CV death: HR=0.38 (95% CI, 0.10 to 1.43); p=0.14 Nonfatal MI: HR=1.12 (95% CI, 0.59 to 2.12); p=0.72 Stent thrombosis: HR=0.63 (95% CI, 0.21 to 1.93); p=0.42 CV death or nonfatal MI: HR=0.93 (95% CI, 0.53 to 1.64); p=0.80 All-cause death: HR=0.70 (95% CI, 0.27 to 1.85); p=0.48 Absolute difference in change of platelet reactivity from baseline at 30 d: -22% (95% CI, -26% to -18%); p<0.001 Absolute difference in change of platelet reactivity at 6 mo: -24% (95% CI, -28% to -20%); p<0.001
Valgimigl206i^†^ 2009 Italy 19528337 3T/2R | IIb/IIIa inhibitor group (n=68, clopidogrel-only nonresponders): tirofiban 50 mL diluted in 200 mL of 0.9% NaCl solution Placebo group (n=79, clopidogrel-only nonresponders): 50 mL of 0.9% NaCl injected in 200 mL of 0.9% NaCl solution by an unblinded research study nurse (all other personnel were blinded to treatment assignment). | 1 mo | Periprocedural MI (based on “the universal definition” of MI286) among clopidogrel-only nonresponders: 16.5% (11 events) in the tirofiban group vs. 30.8% in the placebo group (24 events); OR=0.44 (95% CI, 0.2 to 0.99); p=0.05 [calculated results] Periprocedural MI (based on “the universal definition” of MI286) among clopidogrel and aspirin nonresponders: 0% (0 events) in the tirofiban group vs. 25.0% (event count and denominator NR) in the placebo group [no effect size could be calculated] Among clopidogrel-only nonresponders no deaths were observed. No other outcome was reported separately for clopidogrel nonresponders. Among clopidogrel-only nonresponders a subgroup analysis by inhibition status (≥21% vs. <21%) on the effect of treatment on periprocedural MI was performed. The p-value for the interaction test was 0.35. The sample size of the compared groups was not extractable.
Cuisset279 2008 France 19463379 | IIb/IIIa inhibitor group (n=74): systematic administration of abciximab to all patients Conventional treatment group (n=75): use of IIb/IIIa agonists left at the discretion of physicians | 1 mo | Time-to-event analysis for CV-event free survival: log-rank statistic=7.5; p=0.006 Death from any cause, per procedural myonecrosis, acute or subacute definite or probable stent thrombosis and recurrent ACS: 14 events in the IIb/IIIa inhibitor group vs. 30 events in the conventional treatment group; OR=0.35 (95% CI, 0.17 to 0.74); p=0.006 [calculated results] Death: 0 events in the IIb/IIIa inhibitor group vs. 1 event in the conventional treatment group; OR=0.33 (95% CI, 0.01 to 8.32); p=0.50 [calculated results] Stent thrombosis: 0 events in the IIb/IIIa inhibitor group vs. 1 events in the conventional treatment group; OR=0.33 (95% CI, 0.01 to 8.32); p=0.50 [calculated results] Recurrent ACS: 1 event in the IIb/IIIa inhibitor group vs. 2 events in the conventional treatment group; OR=0.50 (95% CI, 0.04 to 5.64); p=0.57 [calculated results] Periprocedural myonecrosis: 13 events in the IIb/IIIa inhibitor group vs. 26 events in the conventional treatment group; OR=0.40 (95% CI, 0.19 to 0.86); p=0.02 [calculated results]
Alexopoulos280 2012 Greece 22789884 | Ticagrelor 90 mg, 2 × daily vs. prasugrel 10 mg/d (crossover RCT) Total N = 44 (43 completed the study) | 1 mo (total duration) | No patient exhibited a major adverse cardiovascular event or a major bleeding event at either treatment group.
Gremmel281 2011 Austria 21546102 | High-dose group: 100 mg aspirin and 150 mg clopidogrel per day for 3 mo post-PCI (N=21) Standard-dose group: aspirin 100 mg/d and clopidogrel 75 mg/d (N=23) | 3 mo | One patient from each treatment group suffered stent thrombosis, and one patient from the standard treatment group exhibited an in-stent restenosis of the target lesion within the follow-up period of 3 months.
Ari216 2012 Turkey EFFICIENT 21239075 | High-dose clopidogrel: clopidogrel 150 mg/d for 1 mo + aspirin (100 mg/d) (N=47) Standard-dose clopidogrel: clopidogrel 75 mg/d for 1 mo + aspirin (100 mg/d) (N = 47) | 6 mo | MACE: 2 events in the high-dose group vs. 8 in the standard-dose group; absolute risk difference = 12.7% (7.5 to 39.7); p=0.045
Trenk284 2012 Multinational (North America and Europe) 22520250 TRIGGER-PCI | Prasugrel + placebo: prasugrel (60 mg) loading dose within 9 h after administration of the non-study-related clopidogrel maintenance dose (75 mg), followed by maintenance treatment of prasugrel 10 mg/d + placebo, starting the day after the loading dose of the study drug (N=212; 136 completed the study) Clopidogrel + placebo: placebo loading dose within 9 h after administration of the non-study-related clopidogrel maintenance dose (75 mg), followed by maintenance treatment of clopidogrel (75 mg) + placebo, starting the day after the loading dose of the study drug (N=211; 137 completed the study) | 6 mo (early termination for futility) | MACE (CV death or MI): 0 events in the prasugrel-treated group vs. 1 event in the clopidogrel treated group; OR=0.33 (95% CI, 0.013 to 8.15); p=0.50 [calculated results] CV death: 0 events in the prasugrel-treated group vs. 0 events in the clopidogrel treated group; OR and p-value not estimable MI: 0 events in the prasugrel-treated group vs. 1 event in the clopidogrel treated group; OR=0.33 (95% CI, 0.013 to 8.15); p=0.50 [calculated results] Definite or probable stent thrombosis: 0 events in the prasugrel-treated group vs. 0 events in the clopidogrel treated group; OR and p-value not estimable Urgent TVR: 2 events in the prasugrel-treated group vs. 1 event in the clopidogrel treated group; OR=2.0 (95% CI, 0.18 to 22.23); p=0.57 [calculated results] CV death, MI, or TVR: 2 events in the prasugrel-treated group vs. 2 events in the clopidogrel treated group; OR=1.0 (95% CI, 0.14 to 7.13); p>0.99 [calculated results] CV death, MI, stroke, or rehospitalization for cardiac ischemic events: 2 events in the prasugrel-treated group vs. 6 events in the clopidogrel treated group; OR=0.33 (95% CI, 0.065, 1.63); p=0.17 [calculated results]; HR=0.40 (95% CI 0.09 to 2.69) Non-CV death: 0 events in the prasugrel-treated group vs. 1 event in the clopidogrel treated group; OR=0.33 (95% CI, 0.013 to 8.15); p=0.50 [calculated results]
Aradi181 2012 Hungary 21902692 DOSER | High-dose clopidogrel: clopidogrel maintenance 150 mg/d for 1 mo After 28 days, all patients returned to 75 mg maintenance dose of clopidogrel until 1 year. (N=36) Standard-dose clopidogrel: clopidogrel maintenance at a dose of 75 mg/d for 1 mo (N=38) | 12 mo | CV death: 0 events in the high-dose group vs. 1 event in the standard dose group; OR=0.34 (95% CI, 0.01 to 8.68); p=0.52 [calculated results]; p= 0.31 [log-rank test] MI: 0 events in the high-dose group vs. 3 events in the standard dose group; OR=0.14 (95% CI, 0.01 to 2.79); p=0.20 [calculated results]; p=0.08 [log-rank test] TVR: 1 event in the high-dose group vs. 5 events in the standard dose group; OR=0.19 (95% CI, 0.02 to 1.70); p=0.14 [calculated results]; p=0.09 [log-rank test] CV death or MI: 0 events in the high-dose group vs. 4 events in the standard dose group; OR=0.11 (95% CI, 0.01 to 2.02); p=0.14 [calculated results]; p=0.04 [log-rank test] CV death, MI, or TVR: 1 event in the high-dose group vs. 8 events in the standard dose group; OR=0.11 (95% CI, 0.01 to 0.91); p=0.04 [calculated results]; p=0.01 [log-rank test]
Tang247 2012 China 22490487 | High-dose dual antiplatelet therapy: aspirin (200 mg/d) + clopidogrel (150 mg/d) (N=30) Standard-dose dual antiplatelet treatment: aspirin 100 mg/d + clopidogrel (75 mg/d) (N=30) | 12 mo | Data extracted at 12 mo CV death: 0 events in the high-dose group vs. 1 events in the standard dose group; OR=0.32 (95% CI, 0.01 to 8.24); p=0.49 [calculated results] Stent thrombosis: 3 events in the high-dose group vs. 7 events in the standard dose group; OR=0.37 (95% CI, 0.09 to 1.58); p=0.18 [calculated results] Recurrent unstable angina: 7 events in the high-dose group vs. 13 events in the standard dose group; OR=0.40 (95% CI, 0.13 to 1.21); p=0.11 [calculated results] MI: 7 events in the high-dose group vs. 6 events in the standard dose group; OR=0.44 (95% CI, 0.10 to 1.97); p=0.29 [calculated results]
Alexopoulos285 2011 Greece 21511219 | Prasugrel 10 mg/d or clopidogrel 150 mg/d (crossover RCT) Total N=71 | 2 mo | No deaths or strokes occurred in either treatment period.

* Detailed results on the comparison of patients with high versus low platelet reactivity receiving standard dose clopidogrel (i.e., the nonrandomized comparison) has been summarized in the results section on Key Question 2b.

† Outcome data were extracted only for patients with poor response to clopidogrel or clopidogrel and aspirin (i.e., we did not extract data on patients who were poor responders to aspirin alone).

ACS = acute coronary syndrome; CI = confidence interval; CV = cardiovascular; d = day; HR = hazard ratio; LTA = light-transmission aggregometry; MACE = major adverse cardiovascular events; MI = myocardial infarction; mo = month; OR = odds ratio; PMID = PubMed identification number; PRI = platelet reactivity index; TIMI = Thrombolysis In Myocardial Infarction Study Group; TVR = target vessel revascularization.

###### Intermediate Outcome: Platelet Reactivity During Followup

Ten studies reported information on intermediate outcomes. Eight studies had a total duration of 3 months or less; five studies had a crossover design. The outcomes were assessed using different assays and were heterogeneously reported. The key findings are summarized in Table 39. Generally, patients on higher dose clopidogrel regimens or those receiving prasugrel showed greater responses in platelet reactivity compared to those receiving standard dose clopidogrel regimens.

Table 39 Key findings of studies with phenotypic test–based selection of patients and intermediate outcomes

Author Year Country PMID Study Name (if available) | Treatment Groups (sample size) | Followup Duration | Summary of Findings
Paltering228 2010 Italy 19604542 DOUBLE | High-dose clopidogrel maintenance (n=24): 150 mg/d for 1 mo Standard-dose clopidogrel maintenance (n=24): 75 mg/d for 1 mo | 1 mo, assessments performed at 1 we | Mean change of PRI from baseline based on a random effects linear model in the high-dose group at 1 w: -27.8 (95% CI, -33.7 to -21.9); p=0.0001 Mean change of PRI from baseline based on a random effects linear model in the low-dose group at 1 w: -7.9 (95% CI, -14.1 to 1.8); p=0.11 Mean change of PRI from baseline based on a random effects linear model in the high-dose group at 30 d: -31.6 (95% CI, -37.6 to -25.7); p=0.0001 Mean change of PRI from baseline based on a random effects linear model in the low-dose group at 30 d: -18.7 (95% CI, -24.8 to -12.6); p=0.0001 Overall mean difference of PRI between groups (from the random effects linear model)=-15.4 (95% CI, -23.0 to -7.8); p=0.0001 Rate of poor response (defined as PRI>50%) in the high-dose group at 1 mo: 21% Rate of poor response (defined as PRI>50%) in the high-dose group at 1 mo: 71% (p=0.001 for the difference between groups) Mean difference between-groups by LTA (from the random effects linear model; unclear timepoint)=-13.1 (95% CI, -19.8 to -6.4); p=0.0001 Mean difference between-groups by VerifyNow (from the random effects linear model; unclear timepoint)=-57.1 (95% CI, -97.1 to -17.1); p=0.005 Mean difference between-groups by whole blood aggregometry (from the random effects linear model; unclear timepoint)=-1.3 (95% CI, -2.6 to -0.1); p=0.04 Adverse events (study-defined as such): 2 in the high dose group (1 epistaxis; 1 thrombocytopenia); 2 in the low-dose group (1 subacute stent thrombosis; 1 thrombocytopenia) Additional results are presented in Figures 1-3 of the paper.
Gurbel162l^*^ 2010 Multinational (N. America and Europe) 20194878 RESPOND | Clopidogrel: clopidogrel 600 mg loading dose, followed by clopidogrel 75 mg/d maintenance Ticagrelor: ticagrelor 180 mg loading dose, followed ticagrelor 90 mg BID maintenance dose Nonresponders=41 Responders=57 (crossover RCT) | 1 mo | NONRESPONDER COHORT The proportion of patients who responded to ticagrelor was higher than those who responded to clopidogrel; - using a cut-off of 10% absolute change; risk difference 0.25 (95% CI, 0.08 to 0.41); p=0.005 [McNemar test]; - using a cut-off of 30% absolute change; risk difference 0.62 (95% CI, 0.42 to 0.79); p<0.001 [McNemar test]; - using a cut-off of 50% absolute change; risk difference 0.13 (95% CI, 0.01 to 0.23); p=0.046[McNemar test]; Inhibition of platelet aggregation (LTA ADP 20 μmol/L) was higher at all times with ticagrelor, compared to clopidogrel (P≤0.05); similar results were observed with LTA ADP 5 μmol/L and LTA collagen 2 μg/mL VerifyNow PRU was significantly lower with ticagrelor versus clopidogrel at all timepoints except the initial crossover-period (P≤0.05) During both treatment periods, VASP PRI was significantly lower in ticagrelor-treated patients. ADP-induced IIb/IIIa and P-selectin expression were lower at steady state in ticagrelor-treated patients. RESPONDER COHORT Platelet aggregation (LTA ADP 20 μmol/L) was lower after ticagrelor compared with clopidogrel therapy in period 1 and after crossing over in period 2. In patients who continued on the same therapy platelet aggregation was significantly lower at all timepoints after steady state with ticagrelor (p<0.05) Inhibition of platelet aggregation (LTA ADP 20 μmol/L) was higher after loading and maintenance ticagrelor therapy (p<0.05) except at period 2, day 15, 0 hours. Loading with ticagrelor after patients switched from clopidogrel was similar to the inhibition in patients treated with ticagrelor in period 1. In patients who did not switch, inhibition was greater with ticagrelor after steady state was reached (p<0.05). Similar results at steady state were obtained with LTA ADP 5 μmol/L and collagen 2 μg/mL (p<0.001). VerifyNow PRU was significantly lower with ticagrelor versus clopidogrel at all timepoints except the initial crossover-period up to 1 h (P≤0.05). Similar results were observed in patients who continued on the same therapy and those who switched. For comparisons at steady state VASP PRI was lower during ticagrelor treatment compared to clopidogrel. After treatments were switched, PRI was significantly lower with ticagrelor at all timepoints except on day 15 (in patients who crossed over; presumably due to carryover). PRI in patients who did not switch was lower during steady state ticagrelor therapy at “nearly all timepoints”. ADP-induced IIb/IIIa and P-selectin expression were lower at steady state in ticagrelor-treated patients (p<0.001).
Alexopoulos280 2012 Greece 22789884 | Ticagrelor 90 mg, 2 × daily vs. prasugrel 10 mg/d (crossover RCT) Total N = 44 (43 completed the study) | 1 mo | Least squares mean difference = −68.3 PRU (95% CI, -88.6 to -48.1); p<0.001 [combined data throughout the study] Least squares mean difference = -56.7 PRU (95% CI, -83.3 to -30.2); p<0.001 [pre-crossover] Least squares mean difference = -79.3 PRU (95% CI, -110.6 to -48.0); p<0.001 [post-crossover]
Gremmel281 2011 Austria 21546102 | High-dose group: 100 mg aspirin and 150 mg clopidogrel per day for 3 mo post-PCI (N=21) Standard-dose group: aspirin 100 mg/d and clopidogrel 75 mg/d (N=23) | 3 mo | VerifyNow: high dose group mean = 190 ±78 PRU vs. standard dose mean = 262 ±74 PRU VASP assay: high dose group mean = 36.1 ±16.8 % vs. standard dose mean = 59.9 ±21.3 % Multiplate analyzer: high dose group mean = 26 ±16 AU vs. standard dose mean = 46 ±19 AU All p-values for the differences in means between treatment groups were p<0.003 [exact p-value not provided]
Alexopoulos287 2011 Greece 21985070 | Clopidogrel 150 mg/d or prasugrel 10 mg/d (crossover RCT) Total N = 21 | 1 mo | Least squares mean difference = −123.2 PRU (95% CI, -157.8 to -88.7); p<0.001 [combined data throughout the study] High on-treatment platelet reactivity rates: prasugrel, n=4/21 (19%) vs. clopidogrel, n=18/21 (85.7%); p<0.001
Alexopoulos283 2011 Greece 21982667 | Clopidogrel 150 mg/d or prasugrel 10 mg/d (crossover RCT) Total N = 28 | 1 mo | Least squares mean difference = −71.7 PRU (95% CI, -101.5 to -41.8); p<0.001 [combined data throughout the study] Least squares mean difference = -61.6 PRU (95% CI, -105.9 to -17.3); p=0.008 [pre-crossover] Least squares mean difference = -81.9 PRU (95% CI, -123.8 to -40.2); p<0.001 [post-crossover] High on-treatment platelet reactivity rates: prasugrel, n=3/26 (11.5%) vs. clopidogrel, n=12/26 (46.3%); p=0.003 [combined data throughout the study] High on-treatment platelet reactivity rates: prasugrel, n=2/13 (15.4%) vs. clopidogrel, n=8/15 (53.3%); p=0.06 [pre-crossover] High on-treatment platelet reactivity rates: prasugrel, n=1/14 (7.1%) vs. clopidogrel, n=4/12 (36.4%); p=0.1 [post-crossover]
Trenk284 2012 Multinational (North America and Europe) 22520250 TRIGGER-PCI | Prasugrel + placebo: prasugrel (60 mg) loading dose within 9 h after administration of the non-study-related clopidogrel maintenance dose (75 mg), followed by maintenance treatment of prasugrel 10 mg/d + placebo, starting the day after the loading dose of the study drug (N=212; 136 completed the study) Clopidogrel + placebo: placebo loading dose within 9 h after administration of the non-study-related clopidogrel maintenance dose (75 mg), followed by maintenance treatment of clopidogrel (75 mg) + placebo, starting the day after the loading dose of the study drug (N=211; 137 completed the study) | 6 mo | After a median of 90 d median PRU on prasugrel was significantly lower than that on clopidogrel; p<0.001. The difference remained statistically significant at a median of 176 d. The between-treatment group difference in change for baseline was statistically significant at 90 d (p=0.001); the between-treatment group difference in change between 90 and 176 d was non-significant (p=0.338). 176 (94.1%) patients of the prasugrel group vs. 56 (29.6%) patients of the clopidogrel group had a PRU ≤208; p<0.001).
Aradi181 2012 Hungary 21902692 DOSER | High-dose clopidogrel: clopidogrel maintenance 150 mg/d for 1 mo After 28 days, all patients returned to 75 mg maintenance dose of clopidogrel until 1 year (N=36) Standard dose clopidogrel: clopidogrel maintenance at a dose of 75 mg/d for 1 mo (N=38) | 1 mo (for reactivity measurements) | LTA maximal aggregation: high-dose clopidogrel group 33.8 ±15.1 vs. standard dose clopidogrel 37.0 ±13.5 LTA late aggregation: high-dose clopidogrel group 13.8 ±18.0 vs. standard dose clopidogrel 21.7 ±17.9 LTA disaggregation: high-dose clopidogrel group 64.9 ±31.2 vs. standard dose clopidogrel 49.9 ±32.1 LTA AUC: high-dose clopidogrel group 84.8 ±55.3 vs. standard dose clopidogrel 102.0 ±52.7 VASP PRI: high-dose clopidogrel group 37.2 ±17.1 vs. standard dose clopidogrel 60.8 ±17.2
Tang247 2012 China 22490487 | High dose dual antiplatelet therapy: aspirin (200 mg/d) + clopidogrel (150 mg/d) (N=30) Standard dual antiplatelet treatment: aspirin 100 mg/d + clopidogrel (75 mg/d) (N=30) | 12 mo | The inhibition rate of clopidogrel in the high dose group was 60.2% ±7.4, vs. 45.9% ±4.3 in the standard dose group; p<0.01. The difference remained statistically significant at 12 mo.
Alexopoulos285 2011 Greece 21511219 | Prasugrel 10 mg/d or clopidogrel 150 mg/d (crossover RCT) Total N=71 | 2 mo | Least squares mean difference = −72.3 PRU (95% CI, -98.3 to -46.4); p<0.001 [combined data throughout the study] High on-treatment platelet reactivity was less frequent in the prasugrel group (4 of 53, 7.5%) compared to the clopidogrel group (19 of 53, 35.8%); p<0.001

* Despite including both responders and nonresponders, this study was categorized as a study of randomized treatment after test-based selection because patients were assigned to different treatments during the course of the study on the basis of their original response status.

ADP = adenosine diphosphate; AUC = area under the curve; BID = twice daily; CI = confidence interval; d = day; LTA = light-transmission aggregometry; mo = month; PRI = platelet reactivity index; PRU = platelet reactivity units; RCT = randomized controlled trial; VASP = vasodilator-stimulated phosphoprotein; w = week(s).

#### Combined Genetic Testing for CYP2C19 Variants and Phenotypic Testing To Guide Antiplatelet Treatment

We identified four studies that provided information on treatment comparisons among patients selected on the basis of platelet reactivity and also provided information on the CYP2C19 genotype of participants.285,287-289 The parent studies, their inclusion criteria, study designs, and outcomes are summarized in the immediately preceding section of this chapter. Briefly, two of these genetic sub-studies were conducted in the setting of small (21 and 64 patients) crossover RCTs of short duration (30 and 60 days),287,288 one was based on a short-term parallel arm trial (2 weeks of followup),283 and one study (GIFT [Genotype Information and Functional Testing]) was conducted in the setting of the large GRAVITAS trial with a followup of 6 months.289 Analyses stratified by treatment and genotype status were not reported for clinical outcomes and all four studies reported results for the intermediate outcome of platelet reactivity. Studies did not report significant effect modification by genotype for this outcome (all analyses assumed a dominant model for loss-of-function alleles). However, analyses were inconclusive because studies were small and none had been prospectively powered specifically to assess effect modification by genotype.

##### Assessment of Risk of Bias of Individual Studies

A detailed assessment of 17 risk-of-bias items for studies comparing treatment effects in patients selected on the basis of phenotypic testing for platelet reactivity is presented in Appendix F. Overall, the risk of bias varied across the randomized studies. The large, multicenter GRAVITAS trial had low risk of bias, both regarding aspects related to the index test of interest as well as general aspects of randomized trial design (e.g., generation of the randomization sequence and allocation concealment).203 The TRIGGER-PCI trial did not provide adequate information about the randomization procedure and allocation concealment or blinding of patients to treatment assignment; however outcomes assessors were blinded to treatment assignment.284 Smaller studies (typically with short-term followup) were generally considered to have a higher risk of bias, owing to problems in the application of the tests of interest (e.g., an unclear rationale for the thresholds used) or incomplete reporting of outcomes. Furthermore, these studies often did not provide information sufficient to judge their risk of bias regarding general aspects of randomized trial design.

### Key Question 3b How do modifying factors affect the association of alternative test-and-treat strategies and patient outcomes?

Only four of the studies considered relevant to Key Question 3a provided information about the use of testing for clinical decisionmaking with data stratified by patient characteristics.

The first study reported results from the genetic substudy of the CURE trial comparing clopidogrel plus aspirin (dual-antiplatelet) and placebo plus aspirin in patients with non–ST-elevation myocardial infarction.109 The study reported modification of the treatment effect by genotype status, stratified by ancestry. There was no significant interaction between genotype group and treatment (p=0.12 for the composite outcome of death from cardiovascular causes, nonfatal myocardial infarction, or stroke; p=0.28 for the composite outcome of death from cardiovascular causes, nonfatal myocardial infarction, stroke, recurrent ischemia, or hospitalization for unstable angina) among individuals of “European ancestry” and individuals of “Latin American ancestry” (p=0.81 and p=0.71, respectively, for the same outcomes).

The second study reported results from the genetic substudy of the CHARISMA trial, comparing clopidogrel plus aspirin versus placebo plus aspirin in patients with established atherothrombotic vascular disease (coronary, cerebrovascular, or peripheral artery disease).85 The study reported information on the modification of the treatment effect by genotype status, stratified by ancestry (European vs. non-European), history of percutaneous coronary intervention (performed vs. not), and symptomatic atherothrombosis on entry into the trial (present vs. absent). In all cases, the genotype-by-treatment interaction was not statistically significant in any patient subpopulation.

The third study reporting relevant information compared conventional dual-antiplatelet therapy (aspirin plus clopidogrel) with adjunctive use of a glycoprotein IIb/IIIa inhibitor (aspirin plus clopidogrel plus abciximab) in 149 clopidogrel nonresponders (by LTA) undergoing PCI, angiography, or both.206 Treatment-effect modification by baseline percent inhibition (≥21 percent vs. <21 percent) was assessed for the outcome of periprocedural myocardial infarction. An interaction test indicated that effect modification was not statistically significant (p=0.35); the reported data did not allow for the calculation of treatment-effect size stratified by baseline platelet reactivity.

The fourth study evaluated the interaction effect of baseline platelet reactivity and treatment, in a crossover RCT comparing dual antiplatelet therapy (aspirin plus clopidogrel) versus triple therapy (dual therapy plus cilostazol), stratified by diabetes status.278 We performed a test for interaction comparing the mean difference (between treatments) among the four groups defined by diabetes status (present vs. absent) and high on-clopidogrel platelet reactivity (present vs. absent). The p-value was 0.356, suggesting that the treatment effect is not statistically significantly different between the four groups.

Information on the risk of bias of these studies is summarized in the preceding section, because they were also included in Key Question 3a. We caution that studies did not use any procedure to adjust for multiple statistical testing in their subgroup analyses of effect modification.

## Key Question 4 What are the potential adverse effects or harms from genetic or phenotypic testing per se or from test-directed treatments?

Key Question 4 aimed to address the potential harms of test-guided treatment as well as the harms of the testing process itself.

### Harms of Test-Directed Treatment

For harms of test-directed treatment, Table 40 summarizes the number of studies and adverse events or harms assessed for each of the designs we reviewed for Key Question 4. We discuss studies belonging to each of three designs—studies of test-and-treat strategies, studies of treatment-effect modification, and studies with test-based selection—separately for genetic testing (for CYP2C19 variants) and for phenotypic testing (of platelet reactivity). (Please see the Methods section for more information.)

Table 40 Number of studies relevant to Key Question 4 and harms assessed, by study design and test used

Study Design | Genetic Testing for CYP2C19 Variants | Phenotypic Testing for Platelet Reactivity
Comparative studies of test-and-treat strategies | 1 RCT (bleeding events) | 7 (6 RCTs + 1 NRCS; bleeding events)
RCTs of treatment-effect modification by test results | 6 (bleeding events) | 2 (bleeding events and treatment discontinuations)
RCTs with test-based selection | 1 (bleeding and non-bleeding events) | 12 (bleeding events, treatment discontinuations, non-bleeding events)

See the Methods section for details on the relevant study designs.

NRCS = nonrandomized comparative study; RCT = randomized controlled trial.

### Genetic Testing for CYP2C19 Variants

#### Studies of Test-and-Treat Strategies

We identified a single study comparing testing for CYP2C19 variants against a no-testing strategy to guide treatment decisionmaking.86 The study monitored major and minor bleeding (using the TIMI classification) over 30 days of followup. Detailed information regarding the study design and patient population enrolled is provided in the corresponding section under Key Question 3. Briefly, the study assigned patients to a genotype-guided strategy (whereby *2 carriers were treated with prasugrel and non-carriers were treated with clopidogrel-based dual antiplatelet treatment) or to a control treatment strategy (whereby all patients received clopidogrel-based dual antiplatelet treatment).

All patients who underwent PCI were included in the analysis of safety outcomes. The frequency of minor and major bleeding was not different between the study groups: 5 (6 percent) of 91 patients in the genotype-guided group versus 2 (2 percent) of 96 in the control treatment group experienced TIMI minor bleeding (p=0.269); two (2.2 percent) patients in the genotype-guided group versus one (1 percent) in the control treatment group (p=0.613) experienced TIMI major bleeding.

Results regarding the risk of bias assessment for this study are presented in Appendix F and discussed under Key Question 3.

#### Studies of Treatment-Effect Modification by CYP2C19 Genotype Status

Six studies (reported in five publications85,99,104,109,258,260) provided information on treatment-effect modification of bleeding outcomes by CYP2C19 status. Five were based on large randomized trials of clopidogrel-based therapy that included more than 1000 patients in their genetic substudies. Of these, one study enrolled patients with non–ST-elevation acute coronary syndromes, one enrolled those with acute coronary syndromes undergoing PCI, one involved patients with ST-elevation or non–ST-elevation acute coronary syndromes,104 one enrolled a mixed population of patients with manifest atherothrombotic disease (coronary, cerebrovascular, and peripheral artery disease) along with individuals at high risk for developing atherothrombotic disease,85 and one enrolled persons with atrial fibrillation who were not appropriate candidates for vitamin K–antagonist treatment.109 The sixth study was a small genetic substudy of 126 patients with myocardial infarction who were randomized to either aspirin plus high-dose maintenance clopidogrel or to triple-antiplatelet therapy (aspirin, clopidogrel, and cilostazol).260 With a followup of only 30 days, the study reported that no major bleeding events by TIMI criteria were observed in either group. Details about the selection criteria, patient characteristics, and study design are under Key Question 3a results.

Results from the five larger studies comparing the effect of alternative treatment strategies (stratified by CYP2C19 genotype) on safety outcomes (in all five studies, bleeding events) are summarized in Table 41. The test for interaction (i.e., a test for heterogeneity of treatment effects across genotype groups) was not statistically significant for the reported comparisons. This indicates that the impact of the compared treatments on bleeding events was not significantly different across patient groups defined by CYP2C19 genotype.

Table 41 Bleeding events in studies of treatment-effect modification by CYP2C19 genotype status

Author Year Country PMID Study name (if available) | Outcome Definition (timing) | Subgroup defined by genotype | Treatment group | Number with outcome/total number within phenotype-treatment group | Comparison between treatments, within genotype groups ES (95% CI); p-value [statistical test] | Comparison of treatment effects across genotype groups
Pare109,* 2010 Multinational 20979470 CURE | Major bleeding (definition NR) | Poor metabolizers | Dual antiplatelet therapy | 0/61 | NA | p=0.64
Pare109,* 2010 Multinational 20979470 CURE | Major bleeding (definition NR) | Poor metabolizers | Aspirin monotherapy | 1/55 | NA | p=0.64
Pare109,* 2010 Multinational 20979470 CURE | Major bleeding (definition NR) | Intermediate metabolizers | Dual antiplatelet therapy | 19/437 | HR=1.61 (95% CI, 0.79 to 3.28) [Cox proportional hazards model; adjusted for age, sex, ancestry] | p=0.64
Pare109,* 2010 Multinational 20979470 CURE | Major bleeding (definition NR) | Intermediate metabolizers | Aspirin monotherapy | 13/442 | HR=1.61 (95% CI, 0.79 to 3.28) [Cox proportional hazards model; adjusted for age, sex, ancestry] | p=0.64
Pare109,* 2010 Multinational 20979470 CURE | Major bleeding (definition NR) | Extensive metabolizers | Dual antiplatelet therapy | 42/1033 | HR=1.43 (95% CI, 0.89 to 2.30) [Cox proportional hazards model; adjusted for age, sex, ancestry] | p=0.64
Pare109,* 2010 Multinational 20979470 CURE | Major bleeding (definition NR) | Extensive metabolizers | Aspirin monotherapy | 29/987 | HR=1.43 (95% CI, 0.89 to 2.30) [Cox proportional hazards model; adjusted for age, sex, ancestry] | p=0.64
Pare109,* 2010 Multinational 20979470 CURE | Major bleeding (definition NR) | Ultra metabolizers | Dual antiplatelet therapy | 39/847 | HR=1.19 (95% CI, 0.74 to 1.91) [Cox proportional hazards model; adjusted for age, sex, ancestry] | p=0.64
Pare109,* 2010 Multinational 20979470 CURE | Major bleeding (definition NR) | Ultra metabolizers | Aspirin monotherapy | 31/826 | HR=1.19 (95% CI, 0.74 to 1.91) [Cox proportional hazards model; adjusted for age, sex, ancestry] | p=0.64
Pare109,* 2010 Multinational 20979470 CURE | Major bleeding (definition NR) | Unknown metabolizers | Dual antiplatelet therapy | 2/152 | HR=1.77 (95% CI, 0.15 to 20.33) [Cox proportional hazards model; adjusted for age, sex, ancestry] | p=0.64
Pare109,* 2010 Multinational 20979470 CURE | Major bleeding (definition NR) | Unknown metabolizers | Aspirin monotherapy | 1/176 | HR=1.77 (95% CI, 0.15 to 20.33) [Cox proportional hazards model; adjusted for age, sex, ancestry] | p=0.64
Pare109 2010 Multinational 20979470 ACTIVE A | Major hemorrhage=overt bleeding requiring transfusion of at least 2 units of blood or any overt bleeding meeting the criteria for severe hemorrhage | Poor metabolizers | Dual antiplatelet therapy | 0/9 | NA | p=0.08
Pare109 2010 Multinational 20979470 ACTIVE A | Major hemorrhage=overt bleeding requiring transfusion of at least 2 units of blood or any overt bleeding meeting the criteria for severe hemorrhage | Poor metabolizers | Aspirin monotherapy | 2/12 | NA | p=0.08
Pare109 2010 Multinational 20979470 ACTIVE A | Major hemorrhage=overt bleeding requiring transfusion of at least 2 units of blood or any overt bleeding meeting the criteria for severe hemorrhage | Intermediate metabolizers | Dual antiplatelet therapy | 10/93 | HR=5.84 (95% CI, 1.26 to 27.06) [Cox proportional hazards model; adjusted for age, sex] | p=0.08
Pare109 2010 Multinational 20979470 ACTIVE A | Major hemorrhage=overt bleeding requiring transfusion of at least 2 units of blood or any overt bleeding meeting the criteria for severe hemorrhage | Intermediate metabolizers | Aspirin monotherapy | 2/92 | HR=5.84 (95% CI, 1.26 to 27.06) [Cox proportional hazards model; adjusted for age, sex] | p=0.08
Pare109 2010 Multinational 20979470 ACTIVE A | Major hemorrhage=overt bleeding requiring transfusion of at least 2 units of blood or any overt bleeding meeting the criteria for severe hemorrhage | Extensive metabolizers | Dual antiplatelet therapy | 10/199 | HR=0.91 (95% CI, 0.38 to 2.18) [Cox proportional hazards model; adjusted for age, sex] | p=0.08
Pare109 2010 Multinational 20979470 ACTIVE A | Major hemorrhage=overt bleeding requiring transfusion of at least 2 units of blood or any overt bleeding meeting the criteria for severe hemorrhage | Extensive metabolizers | Aspirin monotherapy | 11/235 | HR=0.91 (95% CI, 0.38 to 2.18) [Cox proportional hazards model; adjusted for age, sex] | p=0.08
Pare109 2010 Multinational 20979470 ACTIVE A | Major hemorrhage=overt bleeding requiring transfusion of at least 2 units of blood or any overt bleeding meeting the criteria for severe hemorrhage | Ultra metabolizers | Dual antiplatelet therapy | 8/222 | HR=1.24 (95% CI, 0.43 to 3.59) [Cox proportional hazards model; adjusted for age, sex] | p=0.08
Pare109 2010 Multinational 20979470 ACTIVE A | Major hemorrhage=overt bleeding requiring transfusion of at least 2 units of blood or any overt bleeding meeting the criteria for severe hemorrhage | Ultra metabolizers | Aspirin monotherapy | 6/200 | HR=1.24 (95% CI, 0.43 to 3.59) [Cox proportional hazards model; adjusted for age, sex] | p=0.08
Pare109 2010 Multinational 20979470 ACTIVE A | Major hemorrhage=overt bleeding requiring transfusion of at least 2 units of blood or any overt bleeding meeting the criteria for severe hemorrhage | Unknown metabolizers | Dual antiplatelet therapy | 4/37 | HR=1.84 (95% CI, 0.34 to 10.08) [Cox proportional hazards model; adjusted for age, sex] | p=0.08
Pare109 2010 Multinational 20979470 ACTIVE A | Major hemorrhage=overt bleeding requiring transfusion of at least 2 units of blood or any overt bleeding meeting the criteria for severe hemorrhage | Unknown metabolizers | Aspirin monotherapy | 2/35 | HR=1.84 (95% CI, 0.34 to 10.08) [Cox proportional hazards model; adjusted for age, sex] | p=0.08
Mega99,258,† 2009 Multinational 19106084 19414633 TRITON-TIMI 38 | Safety outcome=major or minor bleeding (TIMI criteria); analysis for this outcome was performed on an “as-treated” basis | Carriers of a reduced function allele | Clopidogrel + aspirin | 11/393 | OR=0.66 (95% CI, 0.30 to 1.42) [calculated values] | p=0.73 [calculated from z-test between odds ratios]
Mega99,258,† 2009 Multinational 19106084 19414633 TRITON-TIMI 38 | Safety outcome=major or minor bleeding (TIMI criteria); analysis for this outcome was performed on an “as-treated” basis | Carriers of a reduced function allele | Prasugrel + aspirin | 17/405 | OR=0.66 (95% CI, 0.30 to 1.42) [calculated values] | p=0.73 [calculated from z-test between odds ratios]
Mega99,258,† 2009 Multinational 19106084 19414633 TRITON-TIMI 38 | Safety outcome=major or minor bleeding (TIMI criteria); analysis for this outcome was performed on an “as-treated” basis | Noncarriers | Clopidogrel + aspirin | 30/1061 | OR=0.77 (95% CI, 0.48 to 1.26) [calculated values] | p=0.73 [calculated from z-test between odds ratios]
Mega99,258,† 2009 Multinational 19106084 19414633 TRITON-TIMI 38 | Safety outcome=major or minor bleeding (TIMI criteria); analysis for this outcome was performed on an “as-treated” basis | Noncarriers | Prasugrel + aspirin | 38/1047 | OR=0.77 (95% CI, 0.48 to 1.26) [calculated values] | p=0.73 [calculated from z-test between odds ratios]
Kim260 2011 S. Korea 21511217 ACCELAMI2C19 | Major bleeding events (based on TIMI criteria) | Carriers | Triple therapy (adjunctive cilostazol) | 0/39 | OR not estimable | NA
Kim260 2011 S. Korea 21511217 ACCELAMI2C19 | Major bleeding events (based on TIMI criteria) | Carriers | High-maintenance dose clopidogrel | 0/38 | OR not estimable | NA
Kim260 2011 S. Korea 21511217 ACCELAMI2C19 | Major bleeding events (based on TIMI criteria) | Noncarriers | Triple therapy (adjunctive cilostazol) | 0/25 | OR not estimable | NA
Kim260 2011 S. Korea 21511217 ACCELAMI2C19 | Major bleeding events (based on TIMI criteria) | Noncarriers | High-maintenance dose clopidogrel | 0/24 | OR not estimable | NA
Wallentin104 2010 Multinational 20801498 PLATO | Major bleeding | Any CYP2C19 LOF allele (*2–*8) | Ticagrelor + aspirin | 149/1380 | HR =1.04 (95% CI, 0.82 to 1.30) [Cox regression with adjustment for ethnic group, sex, use of PPI, aspirin dose, smoking status, and diabetes] | 0.60
Wallentin104 2010 Multinational 20801498 PLATO | Major bleeding | Any CYP2C19 LOF allele (*2–*8) | Clopidogrel+ aspirin | 143/1380 | HR =1.04 (95% CI, 0.82 to 1.30) [Cox regression with adjustment for ethnic group, sex, use of PPI, aspirin dose, smoking status, and diabetes] | 0.60
Wallentin104 2010 Multinational 20801498 PLATO | Major bleeding | No CYP2C19 LOF allele (*1 or *17) | Ticagrelor + aspirin | 331/3547 | HR =0.96 (95% CI, 0.83 to 1.12) [Cox regression with adjustment for ethnic group, sex, use of PPI, aspirin dose, smoking status, and diabetes] | 0.60
Wallentin104 2010 Multinational 20801498 PLATO | Major bleeding | No CYP2C19 LOF allele (*1 or *17) | Clopidogrel+ aspirin | 340/3506 | HR =0.96 (95% CI, 0.83 to 1.12) [Cox regression with adjustment for ethnic group, sex, use of PPI, aspirin dose, smoking status, and diabetes] | 0.60
Wallentin104 2010 Multinational 20801498 PLATO | Major bleeding | No CYP2C19 LOF or GOF allele (*1) | Ticagrelor + aspirin | 176/1846 | HR =1.12 (95% CI, 0.90 to 1.38) [Cox regression with adjustment for ethnic group, sex, use of PPI, aspirin dose, smoking status, and diabetes] | 0.19
Wallentin104 2010 Multinational 20801498 PLATO | Major bleeding | No CYP2C19 LOF or GOF allele (*1) | Clopidogrel+ aspirin | 161/1856 | HR =1.12 (95% CI, 0.90 to 1.38) [Cox regression with adjustment for ethnic group, sex, use of PPI, aspirin dose, smoking status, and diabetes] | 0.19
Wallentin104 2010 Multinational 20801498 PLATO | Major bleeding | Any CYP2C19 LOF allele (*2–*8) but no GOF allele (not *17) | Ticagrelor + aspirin | 108/1011 | HR =1.03 (95% CI, 0.79 to 1.34) [Cox regression with adjustment for ethnic group, sex, use of PPI, aspirin dose, smoking status, and diabetes] | 0.19
Wallentin104 2010 Multinational 20801498 PLATO | Major bleeding | Any CYP2C19 LOF allele (*2–*8) but no GOF allele (not *17) | Clopidogrel+ aspirin | 108/1053 | HR =1.03 (95% CI, 0.79 to 1.34) [Cox regression with adjustment for ethnic group, sex, use of PPI, aspirin dose, smoking status, and diabetes] | 0.19
Wallentin104 2010 Multinational 20801498 PLATO | Major bleeding | Any CYP2C19 GOF allele (*17) | Ticagrelor + aspirin | 196/2070 | HR =0.86 (95% CI, 0.71 to 1.05) [Cox regression with adjustment for ethnic group, sex, use of PPI, aspirin dose, smoking status, and diabetes] | 0.19
Wallentin104 2010 Multinational 20801498 PLATO | Major bleeding | Any CYP2C19 GOF allele (*17) | Clopidogrel+ aspirin | 214/1977 | HR =0.86 (95% CI, 0.71 to 1.05) [Cox regression with adjustment for ethnic group, sex, use of PPI, aspirin dose, smoking status, and diabetes] | 0.19
Wallentin104 2010 Multinational 20801498 PLATO | Major bleeding not related to CABG | Any CYP2C19 LOF allele (*2–*8) | Ticagrelor + aspirin | 56/1380 | HR =1.39 (95% CI, 0.93 to 2.08) [Cox regression with adjustment for ethnic group, sex, use of PPI, aspirin dose, smoking status, and diabetes] | 0.31
Wallentin104 2010 Multinational 20801498 PLATO | Major bleeding not related to CABG | Any CYP2C19 LOF allele (*2–*8) | Clopidogrel+ aspirin | 41/1380 | HR =1.39 (95% CI, 0.93 to 2.08) [Cox regression with adjustment for ethnic group, sex, use of PPI, aspirin dose, smoking status, and diabetes] | 0.31
Wallentin104 2010 Multinational 20801498 PLATO | Major bleeding not related to CABG | No CYP2C19 LOF allele (*1 or *17) | Ticagrelor + aspirin | 121/3547 | HR =1.08 (95% CI, 0.84 to 1.40) [Cox regression with adjustment for ethnic group, sex, use of PPI, aspirin dose, smoking status, and diabetes] | 0.31
Wallentin104 2010 Multinational 20801498 PLATO | Major bleeding not related to CABG | No CYP2C19 LOF allele (*1 or *17) | Clopidogrel+ aspirin | 110/3506 | HR =1.08 (95% CI, 0.84 to 1.40) [Cox regression with adjustment for ethnic group, sex, use of PPI, aspirin dose, smoking status, and diabetes] | 0.31
Wallentin104 2010 Multinational 20801498 PLATO | Major bleeding related to CABG | Any CYP2C19 LOF allele (*2–*8) | Ticagrelor + aspirin | 96/1380 | HR =0.87 (95% CI, 0.66 to 1.14) [Cox regression with adjustment for ethnic group, sex, use of PPI, aspirin dose, smoking status, and diabetes] | 0.93
Wallentin104 2010 Multinational 20801498 PLATO | Major bleeding related to CABG | Any CYP2C19 LOF allele (*2–*8) | Clopidogrel+ aspirin | 107/1380 | HR =0.87 (95% CI, 0.66 to 1.14) [Cox regression with adjustment for ethnic group, sex, use of PPI, aspirin dose, smoking status, and diabetes] | 0.93
Wallentin104 2010 Multinational 20801498 PLATO | Major bleeding related to CABG | No CYP2C19 LOF allele (*1 or *17) | Ticagrelor + aspirin | 218/3547 | HR =0.88 (95% CI, 0.73 to 1.05) [Cox regression with adjustment for ethnic group, sex, use of PPI, aspirin dose, smoking status, and diabetes] | 0.93
Wallentin104 2010 Multinational 20801498 PLATO | Major bleeding related to CABG | No CYP2C19 LOF allele (*1 or *17) | Clopidogrel+ aspirin | 246/3506 | HR =0.88 (95% CI, 0.73 to 1.05) [Cox regression with adjustment for ethnic group, sex, use of PPI, aspirin dose, smoking status, and diabetes] | 0.93
Bhatt85 2012 Multinational 22450429 CHARISMA | Major bleed (GUSTO criteria) | Poor metabolizers | Clopidogrel + aspirin | 0/52 | NA | 0.055
Bhatt85 2012 Multinational 22450429 CHARISMA | Major bleed (GUSTO criteria) | Poor metabolizers | Aspirin + placebo | 1/48 | NA | 0.055
Bhatt85 2012 Multinational 22450429 CHARISMA | Major bleed (GUSTO criteria) | Intermediate metabolizers | Clopidogrel + aspirin | 22/458 | HR=5.32 (95% CI, 1.83 to 15.44) [Cox regression with adjustment for age, sex, inclusion criteria (symptomatic vs. asymptomatic), use of statins, use of calcium channel blockers, and cigarette usage] | 0.055
Bhatt85 2012 Multinational 22450429 CHARISMA | Major bleed (GUSTO criteria) | Intermediate metabolizers | Aspirin + placebo | 4/445 | HR=5.32 (95% CI, 1.83 to 15.44) [Cox regression with adjustment for age, sex, inclusion criteria (symptomatic vs. asymptomatic), use of statins, use of calcium channel blockers, and cigarette usage] | 0.055
Bhatt85 2012 Multinational 22450429 CHARISMA | Major bleed (GUSTO criteria) | Extensive metabolizers | Clopidogrel + aspirin | 34/886 | HR=1.31 (95% CI, 0.80 to 2.15) [Cox regression with adjustment for age, sex, inclusion criteria (symptomatic vs. asymptomatic), use of statins, use of calcium channel blockers, and cigarette usage] | 0.055
Bhatt85 2012 Multinational 22450429 CHARISMA | Major bleed (GUSTO criteria) | Extensive metabolizers | Aspirin + placebo | 30/920 | HR=1.31 (95% CI, 0.80 to 2.15) [Cox regression with adjustment for age, sex, inclusion criteria (symptomatic vs. asymptomatic), use of statins, use of calcium channel blockers, and cigarette usage] | 0.055
Bhatt85 2012 Multinational 22450429 CHARISMA | Major bleed (GUSTO criteria) | Ultra metabolizers | Clopidogrel + aspirin | 26/716 | HR=1.54 (95% CI, 0.84 to 2.84) [Cox regression with adjustment for age, sex, inclusion criteria (symptomatic vs. asymptomatic), use of statins, use of calcium channel blockers, and cigarette usage] | 0.055
Bhatt85 2012 Multinational 22450429 CHARISMA | Major bleed (GUSTO criteria) | Ultra metabolizers | Aspirin + placebo | 17/715 | HR=1.54 (95% CI, 0.84 to 2.84) [Cox regression with adjustment for age, sex, inclusion criteria (symptomatic vs. asymptomatic), use of statins, use of calcium channel blockers, and cigarette usage] | 0.055
Bhatt85 2012 Multinational 22450429 CHARISMA | Major bleed (GUSTO criteria) | Unknown metabolizers | Clopidogrel + aspirin | 6/156 | HR=1.40 (95% CI, 0.39 to 4.99) [Cox regression with adjustment for age, sex, inclusion criteria (symptomatic vs. asymptomatic), use of statins, use of calcium channel blockers, and cigarette usage] | 0.055
Bhatt85 2012 Multinational 22450429 CHARISMA | Major bleed (GUSTO criteria) | Unknown metabolizers | Aspirin + placebo | 4/145 | HR=1.40 (95% CI, 0.39 to 4.99) [Cox regression with adjustment for age, sex, inclusion criteria (symptomatic vs. asymptomatic), use of statins, use of calcium channel blockers, and cigarette usage] | 0.055
Bhatt85 2012 Multinational 22450429 CHARISMA | All bleeds (GUSTO criteria) | Poor metabolizers | Clopidogrel + aspirin | 11/52 | HR=1.63 (95% CI, 0.62 to 4.27) [Cox regression with adjustment for age, sex, inclusion criteria (symptomatic vs. asymptomatic), use of statins, use of calcium channel blockers, and cigarette usage] | 0.195
Bhatt85 2012 Multinational 22450429 CHARISMA | All bleeds (GUSTO criteria) | Poor metabolizers | Aspirin + placebo | 7/48 | HR=1.63 (95% CI, 0.62 to 4.27) [Cox regression with adjustment for age, sex, inclusion criteria (symptomatic vs. asymptomatic), use of statins, use of calcium channel blockers, and cigarette usage] | 0.195
Bhatt85 2012 Multinational 22450429 CHARISMA | All bleeds (GUSTO criteria) | Intermediate metabolizers | Clopidogrel + aspirin | 174/458 | HR=1.83 (95% CI, 1.44 to 2.33) [Cox regression with adjustment for age, sex, inclusion criteria (symptomatic vs. asymptomatic), use of statins, use of calcium channel blockers, and cigarette usage] | 0.195
Bhatt85 2012 Multinational 22450429 CHARISMA | All bleeds (GUSTO criteria) | Intermediate metabolizers | Aspirin + placebo | 106/445 | HR=1.83 (95% CI, 1.44 to 2.33) [Cox regression with adjustment for age, sex, inclusion criteria (symptomatic vs. asymptomatic), use of statins, use of calcium channel blockers, and cigarette usage] | 0.195
Bhatt85 2012 Multinational 22450429 CHARISMA | All bleeds (GUSTO criteria) | Extensive metabolizers | Clopidogrel + aspirin | 369/886 | HR=2.21 (95% CI, 1.87 to 2.62) [Cox regression with adjustment for age, sex, inclusion criteria (symptomatic vs. asymptomatic), use of statins, use of calcium channel blockers, and cigarette usage] | 0.195
Bhatt85 2012 Multinational 22450429 CHARISMA | All bleeds (GUSTO criteria) | Extensive metabolizers | Aspirin + placebo | 210/920 | HR=2.21 (95% CI, 1.87 to 2.62) [Cox regression with adjustment for age, sex, inclusion criteria (symptomatic vs. asymptomatic), use of statins, use of calcium channel blockers, and cigarette usage] | 0.195
Bhatt85 2012 Multinational 22450429 CHARISMA | All bleeds (GUSTO criteria) | Ultra metabolizers | Clopidogrel + aspirin | 312/716 | HR=2.45 (95% CI, 2.02 to 2.96) [Cox regression with adjustment for age, sex, inclusion criteria (symptomatic vs. asymptomatic), use of statins, use of calcium channel blockers, and cigarette usage] | 0.195
Bhatt85 2012 Multinational 22450429 CHARISMA | All bleeds (GUSTO criteria) | Ultra metabolizers | | 156/715 | HR=2.45 (95% CI, 2.02 to 2.96) [Cox regression with adjustment for age, sex, inclusion criteria (symptomatic vs. asymptomatic), use of statins, use of calcium channel blockers, and cigarette usage] | 0.195
Bhatt85 2012 Multinational 22450429 CHARISMA | All bleeds (GUSTO criteria) | Unknown metabolizers | Clopidogrel + aspirin | 55/156 | HR=1.65 (95% CI, 1.08 to 2.52) [Cox regression with adjustment for age, sex, inclusion criteria (symptomatic vs. asymptomatic), use of statins, use of calcium channel blockers, and cigarette usage] | 0.195
Bhatt85 2012 Multinational 22450429 CHARISMA | All bleeds (GUSTO criteria) | Unknown metabolizers | Aspirin + placebo | 36/145 | HR=1.65 (95% CI, 1.08 to 2.52) [Cox regression with adjustment for age, sex, inclusion criteria (symptomatic vs. asymptomatic), use of statins, use of calcium channel blockers, and cigarette usage] | 0.195

* The authors reported extensive subgroup and sensitivity analyses across different genotype groupings and after including or excluding subgroups of patients by race or ethnicity. The results relevant to treatment effect heterogeneity from these analyses are presented in the text of this section.

† Patients with genotypes of “unclear” functional significance were excluded.

ACTIVE A Trial = Atrial Fibrillation Clopidogrel Trial with Irbesartan for Prevention of Vascular Events A trial; CABG = coronary artery bypass grafting; GOF = gain-of-function; GUSTO = Global Utilization of Streptokinase and Tissue Plasminogen Activator for Occluded Coronary Arteries; HR = hazard ratio; LOF = loss-of-function; NA = not applicable; NR = not reported; OR = odds ratio; PLATO = PLATelet inhibition and patient Outcomes trial; PPI = proton-pump inhibitors; TIMI = Thrombolysis In Myocardial Infarction; TRITON-TIMI 38 = Trial to Assess Improvement in Therapeutic Outcomes by Optimizing Platelet Inhibition With Prasugrel–Thrombolysis In Myocardial Infarction 38.

Because of the large differences in populations included, treatments compared, and exposure and outcome definitions among studies reporting on treatment-effect modification by CYP2C19 variants, we did not perform a meta-analysis. For purposes of illustration, we used the counts reported in the studies to compare the treatment effect among genotype-defined groups, under a dominant and a recessive model. Figure 40 presents odds ratios for the treatment effect within each genotype subgroup and relative odds ratios comparing the treatment effect across genotype groups. This relative treatment effect is equivalent to a test of genotype × treatment interaction (see Table 41 for detailed results on treatment-effect heterogeneity by genotype status). Regardless of the genetic model, estimates of effect were generally imprecise because of the relatively low event rate in all trials. Estimates under the recessive model were even less precise, owing to the low number of individuals homozygous for loss-of-function alleles in the study populations.

Figure 40 Bleeding events in large randomized trials reporting information on effect modification by CYP2C19 variants

The top set of panels presents forest plots for treatment effects (odds ratios) on bleeding outcomes among carriers of at least one loss-of-function (LOF) allele (top left panel); treatment effects among noncarriers of LOF alleles (top middle panel); and relative effects (relative odds ratios [rOR]) comparing the treatment effect among LOF carriers and LOF noncarriers (top right panel). The bottom set of panels presents forest plots of treatment effects on bleeding outcomes among homozygotes for two LOF alleles (bottom left panel); treatment effects among non-homozygotes of LOF alleles (bottom middle panel); and relative effects comparing the treatment effect among homozygotes and non-homozygotes of LOF alleles (bottom right panel). Two studies did not provide adequate data for the comparisons of homozygotes and non-homozygotes. The CURE, CHARISMA, and ACTIVE A trials compared aspirin plus clopidogrel versus aspirin monotherapy; the TRITON-TIMI 38 trial compared aspirin plus clopidogrel versus aspirin plus prasugrel; the PLATO trial compared aspirin plus clopidogrel versus aspirin plus ticagrelor. Point estimates for treatment effects are shown as black circles (carriers) or white circles (noncarriers); point estimates for relative treatment effects are shown as black squares. For all symbols, size is inversely proportional to the standard error of each estimate. Horizontal extending lines denote 95% confidence intervals for all estimates. Vertical dashed lines denote no effect. Please see Table 41 for definitions of the genotype categories and outcomes reported by each study. References to individual studies are provided in Table 5.

ACTIVE A = Atrial Fibrillation Clopidogrel Trial with Irbesartan for Prevention of Vascular Events A; CHARISMA = Clopidogrel for High Atherothrombotic Risk and Ischemic Stabilization, Management, and Avoidance; CURE = Clopidogrel in Unstable Angina to Prevent Recurrent Events trial; PLATO = PLATelet inhibition and patient Outcomes trial; TRITON-TIMI 38 = Trial to Assess Improvement in Therapeutic Outcomes by Optimizing Platelet Inhibition with Prasugrel–Thrombolysis in Myocardial Infarction; Tx = treatment.

Figure 40 displays forest plots of treatment effects on bleeding outcomes among carriers of at least one loss-of-function (LOF) allele and among noncarriers of LOF alleles and relative effects comparing the treatment effect among carriers and noncarriers. The relative treatment effects comparing the treatment effect across genotype groups showed that treatment effect modification were non–statistically significant in all five studies. Results were similar in three studies that reported results under a recessive model.

#### Studies With Genetic Test–Based Selection of Patients

One study, the ELEVATE-TIMI 56 trial,87 selected patients on the basis of CYP2C19 genotype to compare different clopidogrel doses. As discussed in the corresponding section of Key Question 3, the study genotyped patients on chronic clopidogrel therapy for the presence of CYP2C19 *2 alleles; patients with at least one *2 alleles were randomized to various sequences of clopidogrel at doses of 75, 150, 225, or 300 mg daily (each for approximately 2 weeks). Non-carriers were randomized to clopidogrel 75 or 150 mg daily (each dose for two periods of approximately 2 weeks).

There were no TIMI major or minor bleeding events. Among CYP2C19 *2 noncarriers, no patients taking the 75 mg dose and five patients taking the 150 mg dose had bleeding requiring medical attention. Among carriers, a bleeding event requiring medical attention occurred in one patient in each of the following dosing regimens: 75, 225, and 300 mg. Finally, no adverse events or serious adverse events that were not prespecified end points occurred at a frequency greater than 3 percent per treatment group, and there were no significant differences in hematologic, gastrointestinal, or musculoskeletal disorders in CYP2C19*2 carriers across different clopidogrel doses.

#### Assessment of Risk of Bias of Individual Studies

The ELEVATE-TIMI 56 study was also included in Key Question 3a.87 As such, detailed information on the 17 risk-of-bias items we assessed is not presented here but in the preceding section.

### Phenotypic Testing for Platelet Reactivity

#### Studies of Test-and-Treat Strategies

Seven studies270-276 comparing alternative test-and-treat strategies provided information on harms of test-directed treatment. The study design, patient characteristics, and phenotypic assays used in these studies have been presented in Tables 25–27 under Key Question 3a. Briefly, the studies randomized patients into groups receiving antiplatelet treatment guided by phenotypic testing or into groups receiving standard-dose clopidogrel therapy. Four of the studies used the VASP assay to monitor response and modify treatment accordingly; one study used the VerifyNow P2Y12 assay, and two studies used the Multiplate analyzer. Six of the studies were RCTs and one was a nonrandomized comparative study. No study identified a statistically significant difference between any study arms in the risk of bleeding events (Figure 41). Outcome definitions and frequency of bleeding events are given in Table 42. The studies had short followup durations (1 year in one study; 6 months in another; and 30 days in the remaining five) and few events were observed, particularly severe or major bleeding outcomes. Consequently, data were sparse and CIs around effect estimates were wide, indicating substantial uncertainty.

Table 42 Bleeding events in studies of test-and-treat strategies using phenotypic testing of platelet reactivity

Author Year Country PMID Study Name (if available) | Treatment Group Sample Size | Outcome Definition | Time Point | No. with Outcome (%) | Comparative Metric | 95% CI | p-value [statistical test]
Wang270 2011 China 21538380 | VASP-guided treatment N=150 | TIMI major bleeding: intracranial bleeding, or clinically overt bleeding associated with a decrease in hemoglobin of 50 g/L | 1 yr | 0 (0%) | Not estimable | Not estimable | p>0.99^*^ [unclear]
Wang270 2011 China 21538380 | Control N=156 | TIMI major bleeding: intracranial bleeding, or clinically overt bleeding associated with a decrease in hemoglobin of 50 g/L | 1 yr | 0 (0%) | Not estimable | Not estimable | p>0.99^*^ [unclear]
Wang270 2011 China 21538380
Wang270 2011 China 21538380 | VASP-guided treatment N=150 | TIMI minor bleeding | 1 yr | 19 (12.7%) | OR=0.76 (calculated) | 0.40 to 1.45 (calculated) | p=0.06^†^ [unclear]
Wang270 2011 China 21538380 | Control N=156 | TIMI minor bleeding | 1 yr | 25 (16.6%) | OR=0.76 (calculated) | 0.40 to 1.45 (calculated) | p=0.06^†^ [unclear]
Bonello271 2009 France 19101221 | VASP-guided treatment N=215 | TIMI major bleeding | 30 d | 2 (0.9%) | OR=1.00 (calculated) | 0.14 to 7.13 (calculated) | p>0.99 [Fisher exact test]
Bonello271 2009 France 19101221 | Control N=214 | TIMI major bleeding | 30 d | 2 (0.9%) | OR=1.00 (calculated) | 0.14 to 7.13 (calculated) | p>0.99 [Fisher exact test]
Bonello271 2009 France 19101221
Bonello271 2009 France 19101221 | VASP-guided treatment N=215 | TIMI minor bleeding | 30 d | 6 (2.8%) | OR=1.51 (calculated) | 0.42 to 5.42 (calculated) | p=0.8 [chi-square]
Bonello271 2009 France 19101221 | Control N=214 | TIMI minor bleeding | 30 d | 4 (1.9%) | OR=1.51 (calculated) | 0.42 to 5.42 (calculated) | p=0.8 [chi-square]
Bonello272 2008 France 18387444 | VASP-guided treatment N=78 | TIMI major bleeding: intracranial bleeding, or clinically overt bleeding associated with a decrease in hemoglobin of 5 g/dL | 30 d | 1 (1.3%) | OR=1.08 (calculated) | 0.07 to 17.53 (calculated) | p>0.99 [Fisher exact test; calculated]
Bonello272 2008 France 18387444 | Control N=84 | TIMI major bleeding: intracranial bleeding, or clinically overt bleeding associated with a decrease in hemoglobin of 5 g/dL | 30 d | 1 (1.2%) | OR=1.08 (calculated) | 0.07 to 17.53 (calculated) | p>0.99 [Fisher exact test; calculated]
Bonello272 2008 France 18387444
Bonello272 2008 France 18387444 | VASP-guided treatment N=78 | TIMI minor bleeding | 30 d | 2 (2.6%) | OR=0.71 (calculated) | 0.12 to 4.37 (calculated) | p>0.99 [Fisher exact test; calculated]
Bonello272 2008 France 18387444 | Control N=84 | TIMI minor bleeding | 30 d | 3 (3.6%) | OR=0.71 (calculated) | 0.12 to 4.37 (calculated) | p>0.99 [Fisher exact test; calculated]
Tousek273 2011 Czech Republic 21663983 | VerifyNow-guided treatment N=30 Control N=30 | TIMI major or minor bleeding | 6 mo | 2 (6.7%) 2 (6.7%) | OR=1.00 (calculated) | 0.13 to 7.60 (calculated) | p>0.99 [Fisher exact test; calculated]
Aleil274 2008 France 19463377 VASP-02 | VASP-guided treatment N=95 (93 included in analyses) | Major bleeding=intracranial bleeding or decrease in hemoglobin requiring transfusion | 30 d | 0 (0%) | Not defined | Not defined | NA
Aleil274 2008 France 19463377 VASP-02 | Control N=58 | Major bleeding=intracranial bleeding or decrease in hemoglobin requiring transfusion | 30 d | 0 (0%) | Not defined | Not defined | NA
Aleil274 2008 France 19463377 VASP-02
Aleil274 2008 France 19463377 VASP-02 | VASP-guided treatment N=95 (93 included in analyses) | Minor bleed=increase in skin bleeding, appearance of epistaxis, gum bleeding about which the patient complains | 30 d | 17 (18%) | OR=0.96 (calculated) | 0.41 to 2.22 (calculated) | p=0.92 [chi-square test; calculated]
Aleil274 2008 France 19463377 VASP-02 | Control N=58 | Minor bleed=increase in skin bleeding, appearance of epistaxis, gum bleeding about which the patient complains | 30 d | 11 (19%) | OR=0.96 (calculated) | 0.41 to 2.22 (calculated) | p=0.92 [chi-square test; calculated]
Hazarbasanov275 2012 Bulgaria 22249353 | Multiplate analyzer-guided treatment N=97 | TIMI major bleeding | 30 d (adverse events were monitored during “the intensified therapy” period) | 1 (1%) | OR=2.97 (calculated) | 0.12 to 73.79 (calculated) | p>0.99 (Fisher exact test; calculated)
Hazarbasanov275 2012 Bulgaria 22249353 | Control N=95 | TIMI major bleeding | 30 d (adverse events were monitored during “the intensified therapy” period) | 0 (0%) | OR=2.97 (calculated) | 0.12 to 73.79 (calculated) | p>0.99 (Fisher exact test; calculated)
Tousek273 2011 Czech Republic 21663983 | VerifyNow-guided treatment N=30 | TIMI major or minor bleeding | 6 mo | 2 (6.7%) | OR=1.00 (calculated) | 0.13 to 7.60 (calculated) | p>0.99 [Fisher exact test; calculated]
| Multiplate analyzer-guided treatment N=97 | TIMI minor bleeding | 30 d (adverse events were monitored during “the intensified therapy” period) | 0 (0%) | Not estimable | Not estimable | NA
| Control N=95 | TIMI minor bleeding | 30 d (adverse events were monitored during “the intensified therapy” period) | 0 (0%) | Not estimable | Not estimable | NA
Siller-Matula276 2012 Austria 22656044 MADONNA | Multiplate analyzer-guided treatment N=403 | TIMI major bleeding | 30 d | 4 (1%) | OR=3.95 (calculated) | 0.44 to 35.50 (calculated) | p=0.186 [unclear statistical test] p=0.373 [two-sided Fisher exact test; calculated]
Siller-Matula276 2012 Austria 22656044 MADONNA | Control N=395 | TIMI major bleeding | 30 d | 1 (<1%) | OR=3.95 (calculated) | 0.44 to 35.50 (calculated) | p=0.186 [unclear statistical test] p=0.373 [two-sided Fisher exact test; calculated]

* It is unclear how the reported p-value of 1.0 was calculated. The p-value here is nonestimable by the chi-square test or Fisher exact test.

† Although P = 0.06 was the reported p-value, recalculation using a chi-square test gives a p-value of 0.403 and recalculation using the Fisher exact test gives a p-value of 0.420. It is unclear how the reported p-value was calculated.

CI = confidence interval; d = days; mo = months; NA = not applicable; NR = not reported; OR = odds ratio; PCI = percutaneous coronary intervention; TIMI = Thrombolysis in Myocardial Infarction; VASP = vasodilator-stimulated phosphoprotein; yr = year.

“Calculated” indicates that the result was not reported by the article's authors; rather, we derived the result from reported raw data.

Figure 41 Bleeding events in studies of test-and-treat strategies using phenotypic testing of platelet reactivity

CI = confidence interval; OR = odds ratio. See Table 33 for details on the strategies compared and the definitions of outcomes employed in each study.

Figure 41 displays forest plots for treatment effects on bleeding outcomes among carriers of at least one loss-of-function allele; treatment effects among noncarriers of loss-of-function alleles; and for relative effects comparing the treatment effect among carriers and noncarriers. The relative treatment effect is equivalent to a test of genotype × treatment interaction.

#### Studies of Treatment-Effect Modification by Baseline Platelet Reactivity

Two studies provided information on treatment-effect modification by baseline on-clopidogrel platelet reactivity.242,277 The first study reported that no treatment discontinuations, non–CABG-related major bleeding events (by Thrombolysis in Myocardial Infarction [TIMI] criteria), or severe or life-threatening bleeding events (by GUSTO [Global Utilization of Streptokinase and Tissue Plasminogen Activator for Occluded Coronary Arteries] criteria) were observed during the trial. Additional information on minor bleeding events or deaths (one death, due to cancer) was not stratified by baseline reactivity status.277

The second study did not identify statistically significant effect modification by baseline low platelet reactivity (defined as ≤188 arbitrary units × minute) of the relative effect of abciximab plus heparin versus bivalirudin in patients undergoing PCI on dual antiplatelet therapy (calculated P for interaction = 0.184). However, the relative odds ratio for major bleeding according to TIMI criteria was extreme (OR=13.98) with very wide confidence intervals (95% CI 0.28 to 686.8) suggesting that the number of events (n=6) and followup duration (30 days) was not adequate to reach meaningful conclusions.242

#### Studies With Phenotypic-Test–Based Selection of Patients

Of the 14 studies that reported results from randomized trials with phenotypic testing–based patient selection, 12 reported information on treatment-related harms. 181,203,206,216,242,247,279-281,285,287,290 Detailed information about the study design, patient characteristics, and assays used in these studies is presented under Key Question 3a.

Only 2 of the 14 studies (the GRAVITAS203 and the TRIGGER-PCI284 trial) included more than 100 randomized patients. The large randomized GRAVITAS trial compared high-dose clopidogrel (in 1,109 patients) versus standard-dose clopidogrel (in 1,105 patients); all the patients had high on-clopidogrel platelet reactivity at baseline as measured by the VerifyNow P2Y12 assay. The study found no statistically significant difference between the two treatment groups for any bleeding event (hazard ratio for high-dose vs. standard-dose therapy, 1.19; 95% CI 0.93, 1.53) (P=0.18) after 6 months of followup. The TRIGGER-PCI trial compared prasugrel (in 212 patients) versus standard dose clopidogrel (in 211 patients); all patients had high on-clopidogrel platelet reactivity at baseline as measured by the VerifyNow P2Y12 assay. The primary safety endpoint of the trial (non-CABG TIMI criteria major bleeding) was not statistically significantly different between the two groups at 6 months of followup (OR=3.03; 95% CI, 0.31 to 29.26 [p=0.34, by our calculation]). Of note, the TRIGGER-PCI trial was terminated early for futility, on the basis of “lower than expected incidence of the primary endpoint.”

The remaining 12 studies had smaller sample sizes (ranging from 21 to 159 patients) and generally had shorted followup durations (<1 month in 6 of the 12 studies) and generally reported low rates of events. Results from all studies are summarized in Table 43.

Table 43 Key findings of studies with phenotypic test–based selection of patients reporting information on harms

Author Year Country PMID Study Name (if available) | Treatment Groups (sample size) | Followup Duration | Summary of Findings
Price203 2011 Multinational 21406646 GRAVITAS | High-dose clopidogrel (n=1109): total first day dose 600 mg, followed by a maintenance dose of 150 mg/d for 6 mo Standard-dose clopidogrel (n=1105): loading dose of placebo, followed by a dose of 75 mg/d + a placebo tablet | 6 mo | Randomized comparison^*^: Severe or moderate bleeding events (GUSTO criteria): HR=0.59 (95% CI, 0.31 to 1.11); p=0.10 Any bleeding: HR=1.19 (95% CI, 0.93 to 1.53); p=0.18
Valgimigli206,† 2009 Italy 19528337 3T/2R | IIb/IIIa inhibitor group (n=68, clopidogrel-only nonresponders): tirofiban 50 mL diluted in 200 mL of 0.9% NaCl solution Placebo group (n=79, clopidogrel-only nonresponders): 50 mL of 0.9% NaCl was injected in 200 mL of 0.9% NaCl solution by an unblinded research study nurse (all other personnel were blinded to treatment assignment). | 1 mo | No major bleeding events occurred in the study.
Cuisset279 2008 France 19463379 | IIb/IIIa inhibitor group (n=74): systematic administration of abciximab to all patient Conventional treatment group (n=75): use of IIb/IIIa agonists left at the discretion of physicians | 1 mo | No patients had a major bleeding event (TIMI criteria). No patients required transfusions.
Alexopoulos280 2012 Greece 22789884 | Ticagrelor 90 mg, 2 × daily vs. prasugrel 10 mg/d (crossover RCT) Total N = 44 (43 completed the study) | 1 mo | No patient exhibited a major bleeding event at either treatment group. Two patients during the first period developed allergic reactions under ticagrelor, leading to study drug discontinuation in 1 of them, 4 patients (2 under prasugrel and 2 under ticagrelor) reported minimal bleeding events, 2 patients both under ticagrelor reported dyspepsia, and 4 patients (all under ticagrelor) reported a mild new-onset/worsening dyspnea.
Gremmel281 2012 Austria 21546102 | High-dose group: 100 mg aspirin and 150 mg clopidogrel per day for 3 mo post-PCI (N=21) Standard dose group: aspirin 100 mg/d and clopidogrel 75 mg/d (N=23) | 3 mo | No patient experienced a major bleeding event.
Alexopoulos282 2011 Greece 21985070 | Clopidogrel 150 mg/d or prasugrel 10 mg/d (crossover RCT) Total N = 21 | 1 mo | One patient during the pre-crossover period and another one during the post-crossover period experienced a minor bleeding event, both while receiving prasugrel.
Alexopoulos283 2011 Greece 21982667 | Clopidogrel 150 mg/d or prasugrel 10 mg/d (crossover RCT) Total N = 28 | 1 mo | 2 patients discontinued the study drug during the post-crossover period, due to gastrointestinal and genitourinary bleeding, while receiving clopidogrel and prasugrel respectively.
Ari216 2012 Turkey EFFICIENT 21239075 | High-dose clopidogrel: clopidogrel 150 mg/d for 1 mo + aspirin (100 mg/d) (N=47) Standard-dose clopidogrel: clopidogrel 75 mg/d for 1 mo + aspirin (100 mg/d) (N = 47) | 6 mo | TIMI major bleeding: 1 event in the high-dose group vs. 0 in the standard-dose group; absolute risk difference = 2.1% (95% CI, 5.5 to 11.1); p=0.32 [reported results]; OR=3.07 (95% CI, 0.12 to 77.17); p=0.50 [calculated] TIMI minor bleeding: 3 events in the high-dose group vs. 1 in the standard-dose group; absolute risk difference = 4.3% (95% CI, −2.0 to 15.1); p=0.30 [reported results] ; OR=3.14 (95% CI, 0.31 to 31.30); p=0.33 [calculated]
Trenk284 2012 Multinational (North America and Europe) 22520250 TRIGGER-PCI | Prasugrel + placebo: prasugrel (60 mg) loading dose within 9 h after administration of the non-study-related clopidogrel maintenance dose (75 mg), followed by maintenance treatment of prasugrel 10 mg/d + placebo, starting the day after the loading dose of the study drug (N=212; 136 completed the study) Clopidogrel + placebo: placebo loading dose within 9 h after administration of the non-study-related clopidogrel maintenance dose (75 mg), followed by maintenance treatment of clopidogrel (75 mg) + placebo, starting the day after the loading dose of the study drug (N=211; 137 completed the study) | 6 mo | Non-CABG TIMI major bleeding: 3 events in the prasugrel group vs. 1 events in the clopidogrel group; OR=3.03 (95% CI, 0.31 to 29.26); p=0.34 Non-CABG TIMI fatal bleeding: 0 events in the prasugrel group vs. 0 events in the clopidogrel group; OR and p-values not estimable Non-CABG TIMI life-threatening bleeding: 0 events in the prasugrel group vs. 1 events in the clopidogrel group; OR=0.33 (95% CI, 0.01 to 8.19); p=0.50 Non-CABG TIMI major or minor bleeding: 3 events in the prasugrel group vs. 2 events in the clopidogrel group; OR=1.51 (95% CI, 0.25 to 9.11); p=0.66 Non-CABG TIMI major, minor, or minimal bleeding: 6 events in the prasugrel group vs. 4 events in the clopidogrel group; OR=1.52 (95% CI, 0.42 to 5.45); p=0.53
Aradi181 2012 Hungary 21902692 DOSER | High-dose clopidogrel: clopidogrel maintenance 150 mg/d for 1 mo After 28 days, all patients returned to 75 mg maintenance dose of clopidogrel until 1 year. (N=36) Standard dose clopidogrel: clopidogrel maintenance at a dose of 75 mg/d for 1 mo (N=38) | 1 mo (for adverse events) | During the 4-week period, 1 TIMI major bleeding event occurred in the high-dose clopidogrel group vs. 0 events in the standard-dose group; OR=3.25 (95% CI, 0.13 to 82.50); p=0.47
Tang247 2012 China 22490487 | High dose dual antiplatelet therapy: aspirin (200 mg/d) + clopidogrel (150 mg/d) (N=30) Standard dual antiplatelet treatment: aspirin 100 mg/d + clopidogrel (75 mg/d) (N=30) | 12 mo | No patient had intracranial hemorrhage. The gastrointestinal hemorrhage rate in the standard dose group was 0% vs. 3.3% in the high-dose group.
Alexopoulos285 2011 Greece 21511219 | Prasugrel 10 mg/d or clopidogrel 150 mg/d (crossover RCT) Total N=71 | 2 mo | During the pre-crossover period, 1 patient allocated to clopidogrel had TIMI major bleeding and was excluded from analysis. During the post-crossover period, 1 patient had TIMI major bleeding and 1 experienced a minor bleeding (both allocated to clopidogrel). 3 patients (allocated to prasugrel) experienced minor bleeding events.

* Detailed results on the comparison of patients with high versus low platelet reactivity receiving standard dose clopidogrel (i.e., the nonrandomized comparison) has been summarized in the report's section on Key Question 2b.

† Outcome data were extracted only for patients with poor response to clopidogrel or clopidogrel and aspirin (i.e., we did not extract data on patients who were poor responders to aspirin alone).

ACS = acute coronary syndrome; CABG = coronary artery bypass grafting; CI = confidence interval; CV = cardiovascular; d = day; GUSTO = Global Utilization of Streptokinase and Tissue Plasminogen Activator for Occluded Coronary Arteries; HR = hazard ratio; LTA = light-transmission aggregometry; MI = myocardial infarction; mo = month; OR = odds ratio; PCI = percutaneous coronary intervention; PRI = platelet reactivity index; RCT = randomized controlled trial; TIMI = Thrombolysis In Myocardial Infarction.

#### Combined Testing for CYP2C19 Variants and Phenotypic Testing To Guide Antiplatelet Treatment

Of the four studies287-290 providing information on phenotypic test-based treatment strategies that also provided information on the CYP2C19 genotype of participants, none reported data on treatment related harms stratified by treatment group and genotype status. As such, the interaction of genotype status and treatment could not be assessed.

#### Assessment of Risk of Bias of Individual Studies

All studies addressing Key Question 4 also addressed Key Question 3a. As such, detailed information on the 17 risk-of-bias items we assessed are not presented here, but rather, in the preceding section.

### Harms of Testing Per Se

We found no studies reporting on the harms of the testing process for CYP2C19 genotyping or measuring platelet reactivity in the populations of interest. A review of the extensive literature on potential harms of prognostic or predictive testing in general (potential for discrimination, privacy concerns, or other ethical, legal, or social issues) was considered beyond the scope of this review. Regarding platelet reactivity testing, in many patients (e.g., those undergoing PCI), blood samples can be obtained as part of standard procedures (e.g., after placement of the arterial sheath). In such cases, obtaining samples for analysis would not be expected to cause additional harm.

One study272 comparing VASP-guided therapy with standard clopidogrel dosing in the PCI setting noted that patients in the test-guided arm had a longer time from clopidogrel loading to PCI than patients in the non–test-guided treatment arm (means, 26 ± 3 hours vs. 65 ± 24 hours; p<0.001). The delay was due to the need for repeat testing and treatment modification until a predefined reactivity threshold was reached in the test-guided group. It is unclear whether this delay resulted in harm to patients.