# References

1 Kamath S, Blann AD, Lip GYH. Platelets and atrial fibrillation. European Heart Journal. Dec. 1. 2001;22(24):2233-42. [pmid: 11728143].
2 Writing Group, Roger VrL, Go AS, et al. Executive Summary: Heart Disease and Stroke StatisticsΓÇö2012 Update. Circulation. Jan. 3. 2012;125(1):188-97. [pmid: 22215894].
3 Keenan NL, Shaw KM. Coronary heart disease and stroke deaths - United States, 2006. MMWR Surveill Summ. Jan. 14. Suppl. 2011;60:62-66. [pmid: 21430624].
4 Squizzato A, Keller T, Romualdi E, et al. Clopidogrel plus aspirin versus aspirin alone for preventing cardiovascular disease. Cochrane Database Syst Rev. Jan. 2011;(1):CD005158. [pmid: 21249668].
5 Writing Committee, Levine GN, Bates ER, et al. 2011 ACCF/AHA/SCAI Guideline for Percutaneous Coronary Intervention. Circulation. Dec. 6. 2011;124(23):e574-e651. [pmid: 22064601].
6 Bowry AD, Brookhart MA, Choudhry NK. Meta-analysis of the efficacy and safety of clopidogrel plus aspirin as compared to antiplatelet monotherapy for the prevention of vascular events. Am J Cardiol. Apr. 1. 2008;101(7):960-66. [pmid: 18359315].
7 Sabatine MS, Hamdalla HN, Mehta SR, et al. Efficacy and safety of clopidogrel pretreatment before percutaneous coronary intervention with and without glycoprotein IIb/IIIa inhibitor use. Am Heart J. May. 2008;155(5):910-17. [pmid: 18440341].
8 Sudlow CL, Mason G, Maurice JB, et al. Thienopyridine derivatives versus aspirin for preventing stroke and other serious vascular events in high vascular risk patients. Cochrane Database Syst Rev. Oct. 7. 2009;(4):CD001246. [pmid: 19821273].
9 Collaborative meta-analysis of randomised trials of antiplatelet therapy for prevention of death, myocardial infarction, and stroke in high risk patients. 2002.
10 Effect of Clopidogrel Added to Aspirin in Patients with Atrial Fibrillation. N Engl J Med. May. 14. 2009;360(20):2066-78. PMID:. [doi: 10.1056/NEJMoa0901301]. [pmid: 19336502].
11 Bellemain-Appaix A, Brieger D, Beygui F, et al. New P2Y12 Inhibitors Versus Clopidogrel in Percutaneous Coronary Intervention: A Meta-Analysis. Journal of the American College of Cardiology. Nov. 2. 2010;56(19):1542-51. PMID:. [doi: 10.1016/j.jacc.2010.07.012]. [pmid: 20800407].
12 Wallentin L, Becker RC, Budaj A, et al. Ticagrelor versus clopidogrel in patients with acute coronary syndromes. N Engl J Med. Sep. 10. 2009;361(11):1045-57. [pmid: 19717846].
13 Wiviott SD, Braunwald E, McCabe CH, et al. Prasugrel versus clopidogrel in patients with acute coronary syndromes. N Engl J Med. Nov. 15. 2007;357(20):2001-15. [pmid: 17982182].
14 Navarese EP, Verdoia M, Schaffer A, et al. Ischaemic and bleeding complications with new, compared to standard, ADP-antagonist regimens in acute coronary syndromes: a meta-analysis of randomized trials. QJM. Jul. 1. 2011;104(7):561-69. [pmid: 21572108].
15 Geiger J, Brich J, Honig-Liedl P, et al. Specific impairment of human platelet P2Y(AC) ADP receptor-mediated signaling by the antiplatelet drug clopidogrel. Arterioscler Thromb Vasc Biol. Aug. 1999;19(8):2007-11. [pmid: 10446085].
16 Kazui M, Nishiya Y, Ishizuka T, et al. Identification of the human cytochrome P450 enzymes involved in the two oxidative steps in the bioactivation of clopidogrel to its pharmacologically active metabolite. Drug Metab Dispos. Jan. 2010;38(1):92-99. [pmid: 19812348].
17 Anderson CD, Biffi A, Greenberg SM, et al. Personalized approaches to clopidogrel therapy: are we there yet?. Stroke. Dec. 2010;41(12):2997-3002. [pmid: 21030701].
18 Ma TK, Lam YY, Tan VP, et al. Impact of genetic and acquired alteration in cytochrome P450 system on pharmacologic and clinical response to clopidogrel. Pharmacol Ther. Feb. 2010;125(2):249-59. [pmid: 19919843].
19 Li-Wan-Po A, Girard T, Farndon P, et al. Pharmacogenetics of CYP2C19: functional and clinical implications of a new variant CYP2C19*17. Br J Clin Pharmacol. Mar. 2010;69(3):222-30. [pmid: 20233192].
20 Bauer T, Bouman HJ, van Werkum JW, et al. Impact of CYP2C19 variant genotypes on clinical efficacy of antiplatelet treatment with clopidogrel: systematic review and meta-analysis. BMJ. 2011;343:d4588. [pmid: 21816733].
21 Scholz I, Oberwittler H, Riedel KD, et al. Pharmacokinetics, metabolism and bioavailability of the triazole antifungal agent voriconazole in relation to CYP2C19 genotype. Br J Clin Pharmacol. Dec. 2009;68(6):906-15. [pmid: 20002085].
22 Yoo HD, Cho HY, Lee YB. Population pharmacokinetic analysis of cilostazol in healthy subjects with genetic polymorphisms of CYP3A5, CYP2C19 and ABCB1. Br J Clin Pharmacol. Jan. 2010;69(1):27-37. [pmid: 20078610].
23 Yasui-Furukori N, Takahata T, Nakagami T, et al. Different inhibitory effect of fluvoxamine on omeprazole metabolism between CYP2C19 genotypes. Br J Clin Pharmacol. Apr. 2004;57(4):487-94. [pmid: 15025747].
24 Minelli C, Thompson JR, Abrams KR, et al. Bayesian implementation of a genetic model-free approach to the meta-analysis of genetic association studies. Stat Med. Dec. 30. 2005;24(24):3845-61. [pmid: 16320276].
25 Chang MH, Lindegren ML, Butler MA, et al. Prevalence in the United States of selected candidate gene variants: Third National Health and Nutrition Examination Survey, 1991-1994. Am J Epidemiol. Jan. 1. 2009;169(1):54-66. [pmid: 18936436].
26 Chan MY, Tan K, Tan HC, et al. CYP2C19 and PON1 polymorphisms regulating clopidogrel bioactivation in Chinese, Malay and Indian subjects. Pharmacogenomics. Apr. 2012;13(5):533-42. [pmid: 22462746].
27 Yin SJ, Ni YB, Wang SM, et al. Differences in genotype and allele frequency distributions of polymorphic drug metabolizing enzymes CYP2C19 and CYP2D6 in mainland Chinese Mongolian, Hui and Han populations. J Clin Pharm Ther. Jun. 2012;37(3):364-69. [pmid: 21913948].
28 Veiga MI, Asimus S, Ferreira PE, et al. Pharmacogenomics of CYP2A6, CYP2B6, CYP2C19, CYP2D6, CYP3A4, CYP3A5 and MDR1 in Vietnam. Eur J Clin Pharmacol. Apr. 2009;65(4):355-63. [pmid: 18979093].
29 Shuldiner AR, O'Connell JR, Bliden KP, et al. Association of cytochrome P450 2C19 genotype with the antiplatelet effect and clinical efficacy of clopidogrel therapy. JAMA. Aug. 26. 2009;302(8):849-57. [pmid: 19706858].
30 Harrison P, Frelinger AL III, Furman MI, et al. Measuring antiplatelet drug effects in the laboratory. Thromb Res. 2007;120(3):323-36. [pmid: 17239428].
31 Gurbel PA, Tantry US. Drug insight: Clopidogrel nonresponsiveness. Nat Clin Pract Cardiovasc Med. Jul. 2006;3(7):387-95. [pmid: 16810174].
32 Ben-Dor I, Kleiman NS, Lev E. Assessment, mechanisms, and clinical implication of variability in platelet response to aspirin and clopidogrel therapy. Am J Cardiol. Jul. 15. 2009;104(2):227-33. [pmid: 19576352].
33 Favaloro EJ. Clinical utility of the PFA-100. Semin Thromb Hemost. Nov. 2008;34(8):709-33. [pmid: 19214910].
34 Hayward CP, Harrison P, Cattaneo M, et al. Platelet function analyzer (PFA)-100 closure time in the evaluation of platelet disorders and platelet function. J Thromb Haemost. Feb. 2006;4(2):312-19. [pmid: 16420557].
35 Jilma B. Platelet function analyzer (PFA-100): a tool to quantify congenital or acquired platelet dysfunction. J Lab Clin Med. Sep. 2001;138(3):152-63. [pmid: 11528368].
36 van Werkum JW, Harmsze AM, Elsenberg EH, et al. The use of the VerifyNow system to monitor antiplatelet therapy: a review of the current evidence. Platelets. Nov. 2008;19(7):479-88. [pmid: 18979359].
37 Price MJ. Bedside evaluation of thienopyridine antiplatelet therapy. Circulation. May. 19. 2009;119(19):2625-32. [pmid: 19451364].
38 Bonello L, Tantry US, Marcucci R, et al. Consensus and future directions on the definition of high on-treatment platelet reactivity to adenosine diphosphate. J Am Coll Cardiol. Sep. 14. 2010;56(12):919-33. [pmid: 20828644].
39 Tantry US, Kereiakes DJ, Gurbel PA. Clopidogrel and proton pump inhibitors: influence of pharmacological interactions on clinical outcomes and mechanistic explanations. JACC Cardiovasc Interv. Apr. 2011;4(4):365-80. [pmid: 21511216].
40 Hulot JS, Collet JP, Silvain J, et al. Cardiovascular risk in clopidogrel-treated patients according to cytochrome P450 2C19*2 loss-of-function allele or proton pump inhibitor coadministration: a systematic meta-analysis. J Am Coll Cardiol. Jul. 6. 2010;56(2):134-43. [pmid: 20620727].
41 Holmes MV, Perel P, Shah T, et al. CYP2C19 Genotype, Clopidogrel Metabolism, Platelet Function, and Cardiovascular Events. JAMA: The Journal of the American Medical Association. Dec. 28. 2011;306(24):2704-14.
42 Krishna V, Diamond GA, Kaul S. Do platelet function testing and genotyping improve outcome in patients treated with antithrombotic agents?: the role of platelet reactivity and genotype testing in the prevention of atherothrombotic cardiovascular events remains unproven. Circulation. Mar. 13. 2012;125(10):1288-303. [pmid: 22412090].
43 Gurbel PA, Tantry US. Do platelet function testing and genotyping improve outcome in patients treated with antithrombotic agents?: platelet function testing and genotyping improve outcome in patients treated with antithrombotic agents. Circulation. Mar. 13. 2012;125(10):1276-87. [pmid: 22412089].
44 Scott SA, Sangkuhl K, Gardner EE, et al. Clinical Pharmacogenetics Implementation Consortium guidelines for cytochrome P450-2C19 (CYP2C19) genotype and clopidogrel therapy. Clin Pharmacol Ther. Aug. 2011;90(2):328-32. [pmid: 21716271].
45 Eikelboom JW, Hirsh J, Spencer FA, et al. Antiplatelet drugs: Antithrombotic Therapy and Prevention of Thrombosis, 9th ed: American College of Chest Physicians Evidence-Based Clinical Practice Guidelines. Chest. Feb. 2012;141(2 Suppl):e89S-119S. [pmid: 22315278].
46 Moher D, Liberati A, Tetzlaff J, et al. Preferred Reporting Items for Systematic Reviews and Meta-Analyses: The PRISMA Statement. PLoS Med. Jul. 21. 2009;6(7):e1000097. PMID:. [doi: 10.1371/journal.pmed.1000097]. [pmid: 19621072].
47 Wallace BC, Trikalinos TA, Lau J, et al. Semi-automated screening of biomedical citations for systematic reviews. BMC Bioinformatics. 2010;11:55. [pmid: 20102628].
48 Simon RM, Paik S, Hayes DF. Use of archived specimens in evaluation of prognostic and predictive biomarkers. J Natl Cancer Inst. Nov. 4. 2009;101(21):1446-52. [pmid: 19815849].
49 Dahabreh IJ, Terasawa T, Castaldi PJ, et al. Systematic review: Anti-epidermal growth factor receptor treatment effect modification by KRAS mutations in advanced colorectal cancer. Ann Intern Med. Jan. 4. 2011;154(1):37-49. [pmid: 21200037].
50 Kitsios GD, Kent DM. Personalised medicine: not just in our genes. BMJ. Apr. 3. 2012;344.
51 DerSimonian R, Laird N. Meta-analysis in clinical trials. Controlled Clinical Trials. Sep. 1986;7(3):177-88. PMID:. [doi: 10.1016/0197-2456(86)90046-2]. [pmid: 3802833].
52 Cochran WG. The combination of estimates from different experiments. Biometrics. Mar. 1954;10(1):101-29.
53 Higgins JPT, Thompson SG. Quantifying heterogeneity in a meta-analysis. Statist Med. 2002;21(11):1539-58. PMID:. [doi: 10.1002/sim.1186].
54 Ioannidis JP, Patsopoulos NA, Evangelou E. Uncertainty in heterogeneity estimates in meta-analyses. BMJ. Nov. 2007;1:335.
55 Reitsma JB, Glas AS, Rutjes AW, et al. Bivariate analysis of sensitivity and specificity produces informative summary measures in diagnostic reviews. J Clin Epidemiol. Oct. 2005;58(10):982-90. [pmid: 16168343].
56 Hamza TH, Reitsma JB, Stijnen T. Meta-analysis of diagnostic studies: a comparison of random intercept, normal-normal, and binomial-normal bivariate summary ROC approaches. Med Decis Making. Sep. 2008;28(5):639-49. [pmid: 18753684].
57 Pearce N. What does the odds ratio estimate in a case-control study?. Int J Epidemiol. Dec. 1993;22(6):1189-92. [pmid: 8144304].
58 Knol MJ, Vandenbroucke JP, Scott P, et al. What do case-control studies estimate? Survey of methods and assumptions in published case-control research. Am J Epidemiol. Nov. 1. 2008;168(9):1073-81. [pmid: 18794220].
59 Miettinen OS. Theoretical epidemiology: principles of occurrence research in medicine. Wiley. New York. 1985.
60 Berlin JA, Santanna J, Schmid CH, et al. Individual patient- versus group-level data meta-regressions for the investigation of treatment effect modifiers: ecological bias rears its ugly head. Statist Med. 2002;21(3):371-87. PMID:. [doi: 10.1002/sim.1023].
61 Egger M, Davey SG, Schneider M, et al. Bias in meta-analysis detected by a simple, graphical test. BMJ. Sep. 13. 1997;315(7109):629-34. [pmid: 9310563].
62 Lau J, Ioannidis JP, Terrin N, et al. The case of the misleading funnel plot. BMJ. Sep. 16. 2006;333(7568):597-600. [pmid: 16974018].
63 Terrin N, Schmid CH, Lau J. In an empirical evaluation of the funnel plot, researchers could not visually identify publication bias. J Clin Epidemiol. Sep. 2005;58(9):894-901. [pmid: 16085192].
64 Terrin N, Schmid CH, Lau J, et al. Adjusting for publication bias in the presence of heterogeneity. Statist Med. 2003;22(13):2113-26. PMID:. [doi: 10.1002/sim.1461].
65 Sterne JA, Sutton AJ, Ioannidis JP, et al. Recommendations for examining and interpreting funnel plot asymmetry in meta-analyses of randomised controlled trials. BMJ. 2011;343:d4002. [pmid: 21784880].
66 Ioannidis JPA, Ntzani EE, Trikalinos TA, et al. Replication validity of genetic association studies. Nat Genet. Nov. 2001;29(3):306-09. PMID:. [doi: 10.1038/ng749]. [pmid: 11600885].
67 Trikalinos TA, Ntzani EE, Contopoulos-Ioannidis DG, et al. Establishment of genetic associations for complex diseases is independent of early study findings. Eur J Hum Genet. Jun. 23. 2004;12(9):762-69. [pmid: 15213707].
68 Agency for Healthcare Research and Quality. Methods Reference Guide for Effectiveness and Comparative Effectiveness Reviews. Available at: www.effectivehealthcare.ahrq.gov. AHRQ Publication 10-(11)-EHC063-EF. 2011.
69 Viswanathan M, Ansari MT, Berkman ND, et al. Assessing the Risk of Bias of Individual Studies in Systematic Reviews of Health Care Interventions. Rockville, MD. Agency for Healthcare Research and Quality. 2012.
70 Agency for Healthcare Research and Quality. Methods Guide for Medical Test Reviews. Rockville, MD. AHRQ. 2012.
71 Whiting PF, Rutjes AWS, Westwood ME, et al. QUADAS-2: A Revised Tool for the Quality Assessment of Diagnostic Accuracy Studies. Annals of Internal Medicine. Oct. 18. 2011;155(8):529-36. [pmid: 22007046].
72 Whiting P, Rutjes AW, Reitsma JB, et al. The development of QUADAS: a tool for the quality assessment of studies of diagnostic accuracy included in systematic reviews. BMC Med Res Methodol. Nov. 10. 2003;3:25. [pmid: 14606960].
73 Whiting P, Rutjes AW, Dinnes J, et al. Development and validation of methods for assessing the quality of diagnostic accuracy studies. Health Technol Assess. Jun. 1. 2004;8(25):iii-iii234. [pmid: 15193208].
74 Whiting PF, Weswood ME, Rutjes AWS, et al. Evaluation of QUADAS, a tool for the quality assessment of diagnostic accuracy studies. BMC Med Res Methodol. 2006;6:9. [pmid: 16519814].
75 Higgins JPT, Douglas GA, Peter CG, et al. The Cochrane CollaborationΓÇÖs tool for assessing risk of bias in randomised trials. BMJ. Oct. 2011;18:343.
76 Owens DK, Lohr KN, Atkins D, et al. AHRQ series paper 5: grading the strength of a body of evidence when comparing medical interventions--agency for healthcare research and quality and the effective health-care program. J Clin Epidemiol. May. 2010;63(5):513-23. [pmid: 19595577].
77 Atkins D, Chang SM, Gartlehner G, et al. Assessing applicability when comparing medical interventions: AHRQ and the Effective Health Care Program. J Clin Epidemiol. 2011;64:1198-207. PMID: <[31] UNIQUE ID (DOI)>. [pmid: 21463926].
78 Sibbing D, Stegherr J, Latz W, et al. Cytochrome P450 2C19 loss-of-function polymorphism and stent thrombosis following percutaneous coronary intervention. European Heart Journal. Apr. 2009;30(8):916-22. [pmid: 19193675].
79 Sibbing D, Koch W, Gebhard D, et al. Cytochrome 2C19*17 allelic variant, platelet aggregation, bleeding events, and stent thrombosis in clopidogrel-treated patients with coronary stent placement. Circulation. Feb. 2. 2010;121(4):512-18. [pmid: 20083681].
80 Sibbing D, Koch W, Massberg S, et al. No association of paraoxonase-1 Q192R genotypes with platelet response to clopidogrel and risk of stent thrombosis after coronary stenting. European Heart Journal. Jul. 2011;32(13):1605-13. [pmid: 21527445].
81 Trenk D, Hochholzer W, Fromm MF, et al. Paraoxonase-1 Q192R polymorphism and antiplatelet effects of clopidogrel in patients undergoing elective coronary stent placement. Circulation. Aug. 1. Cardiovascular. 2011;(4):429-36. [pmid: 21685174].
82 Siller-Matula JM, le-Karth G, Lang IM, et al. Phenotyping vs. genotyping for prediction of clopidogrel efficacy and safety: the PEGASUS-PCI study. J Thromb Haemost. Apr. 2012;10(4):529-42. [pmid: 22260716].
83 Namazi S, Kojuri J, Khalili A, et al. The impact of genetic polymorphisms of P2Y12, CYP3A5 and CYP2C19 on clopidogrel response variability in Iranian patients. Biochem Pharmacol. Apr. 1. 2012;83(7):903-08. [pmid: 22265638].
84 Delaney JT, Ramirez AH, Bowton E, et al. Predicting clopidogrel response using DNA samples linked to an electronic health record. Clin Pharmacol Ther. Feb. 2012;91(2):257-63. [pmid: 22190063].
85 Bhatt DL, Pare G, Eikelboom JW, et al. The relationship between CYP2C19 polymorphisms and ischaemic and bleeding outcomes in stable outpatients: the CHARISMA genetics study. Eur Heart J. 2012. Mar. 26.
86 Roberts JD, Wells GA, Le May MR, et al. Point-of-care genetic testing for personalisation of antiplatelet treatment (RAPID GENE): a prospective, randomised, proof-of-concept trial. Lancet. May. 5. 2012;379(9827):1705-11. [pmid: 22464343].
87 Mega JL, Hochholzer W, Frelinger AL III, et al. Dosing clopidogrel based on CYP2C19 genotype and the effect on platelet reactivity in patients with stable cardiovascular disease. JAMA. Nov. 23. 2011;306(20):2221-28. [pmid: 22088980].
88 Campo G, Parrinello G, Ferraresi P, et al. Prospective evaluation of on-clopidogrel platelet reactivity over time in patients treated with percutaneous coronary intervention relationship with gene polymorphisms and clinical outcome. Journal of the American College of Cardiology. Jun. 21. 2011;57(25):2474-83. [pmid: 21679849].
89 Malek LA, Przyluski J, Spiewak M, et al. Cytochrome P450 2C19 polymorphism, suboptimal reperfusion and all-cause mortality in patients with acute myocardial infarction. Cardiology. 2010;117(2):81-87. [pmid: 20924183].
90 Sawada T, Shinke T, Shite J, et al. Impact of cytochrome P450 2C19*2 polymorphism on intra-stent thrombus after drug-eluting stent implantation in Japanese patients receiving clopidogrel. Circulation Journal. Dec. 24. 2010;75(1):99-105. [pmid: 21099121].
91 Tiroch KA, Sibbing D, Koch W, et al. Protective effect of the CYP2C19 *17 polymorphism with increased activation of clopidogrel on cardiovascular events. Am Heart J. Sep. 2010;160(3):506-12. [pmid: 20826260].
92 Chen M, Liu XJ, Yan SD, et al. Association between cytochrome P450 2C19 polymorphism and clinical outcomes in Chinese patients with coronary artery disease. Atherosclerosis. Jan. 2012;220(1):168-71. [pmid: 22071359].
93 Nishio R, Shinke T, Otake H, et al. Effect of Cytochrome P450 2C19 Polymorphism on Target Lesion Outcome After Drug-Eluting Stent Implantation in Japanese Patients Receiving Clopidogrel. Circ J. Sep. 25. 2012;76(10):2348-55. [pmid: 22785462].
94 Collet JP, Hulot JS, Pena A, et al. Cytochrome P450 2C19 polymorphism in young patients treated with clopidogrel after myocardial infarction: a cohort study. Lancet. Jan. 24. 2009;373(9660):309-17. [pmid: 19108880].
95 Giusti B, Gori AM, Marcucci R, et al. Relation of cytochrome P450 2C19 loss-of-function polymorphism to occurrence of drug-eluting coronary stent thrombosis. American Journal of Cardiology. Mar. 15. 2009;103(6):806-11. [pmid: 19268736].
96 Malek LA, Kisiel B, Spiewak M, et al. Coexisting polymorphisms of P2Y12 and CYP2C19 genes as a risk factor for persistent platelet activation with clopidogrel. Circulation Journal. Jul. 2008;72(7):1165-69. [pmid: 18577829].
97 Yamamoto K, Hokimoto S, Chitose T, et al. Impact of CYP2C19 polymorphism on residual platelet reactivity in patients with coronary heart disease during antiplatelet therapy. Journal of Cardiology. Mar. 2011;57(2):194-201. [pmid: 21168310].
98 Luo Y, Zhao YT, Verdo A, et al. Relationship between cytochrome P450 2C19*2 polymorphism and stent thrombosis following percutaneous coronary intervention in Chinese patients receiving clopidogrel. J Int Med Res. 2011;39(5):2012-19. [pmid: 22118006].
99 Mega JL, Close SL, Wiviott SD, et al. Cytochrome p-450 polymorphisms and response to clopidogrel. N Engl J Med. Jan. 22. 2009;360(4):354-62. [pmid: 19106084].
100 Bonello L, Armero S, Ait MO, et al. Clopidogrel loading dose adjustment according to platelet reactivity monitoring in patients carrying the 2C19*2 loss of function polymorphism. Journal of the American College of Cardiology. Nov. 9. 2010;56(20):1630-36. [pmid: 20708365].
101 Bouman HJ, Harmsze AM, van Werkum JW, et al. Variability in on-treatment platelet reactivity explained by CYP2C19*2 genotype is modest in clopidogrel pretreated patients undergoing coronary stenting. Heart. Aug. 2011;97(15):1239-44. [pmid: 21628721].
102 Bouman HJ, Schomig E, van Werkum JW, et al. Paraoxonase-1 is a major determinant of clopidogrel efficacy. [Erratum appears in Nat Med. 2011 Sep;17(9):1153]. Nature Medicine. Jan. 2011;17(1):110-16.
103 Harmsze AM, van Werkum JW, Ten Berg JM, et al. CYP2C19*2 and CYP2C9*3 alleles are associated with stent thrombosis: a case-control study. European Heart Journal. Dec. 2010;31(24):3046-53. [pmid: 20833683].
104 Wallentin L, James S, Storey RF, et al. Effect of CYP2C19 and ABCB1 single nucleotide polymorphisms on outcomes of treatment with ticagrelor versus clopidogrel for acute coronary syndromes: a genetic substudy of the PLATO trial. Lancet. Oct. 16. 2010;376(9749):1320-28. [pmid: 20801498].
105 Hulot JS, Collet JP, Cayla G, et al. CYP2C19 but not PON1 genetic variants influence clopidogrel pharmacokinetics, pharmacodynamics, and clinical efficacy in post-myocardial infarction patients. Circ Cardiovasc Interv. Oct. 1. 2011;4(5):422-28. [pmid: 21972404].
106 Jaitner J, Morath T, Byrne RA, et al. No association of ABCB1 C3435T genotype with clopidogrel response or risk of stent thrombosis in patients undergoing coronary stenting. Circ Cardiovasc Interv. Feb. 1. 2012;5(1):82. [pmid: 22298798].
107 Cayla G, Hulot JS, O'Connor SA, et al. Clinical, angiographic, and genetic factors associated with early coronary stent thrombosis. JAMA. Oct. 26. 2011;306(16):1765-74. [pmid: 22028352].
108 Ono T, Kaikita K, Hokimoto S, et al. Determination of cut-off levels for on-clopidogrel platelet aggregation based on functional CYP2C19 gene variants in patients undergoing elective percutaneous coronary intervention. Thromb Res. Dec. 2011;128(6):e130-e136. [pmid: 21862109].
109 Pare G, Mehta SR, Yusuf S, et al. Effects of CYP2C19 genotype on outcomes of clopidogrel treatment. N Engl J Med. Oct. 28. 2010;363(18):1704-14. [pmid: 20979470].
110 Simon T, Verstuyft C, Mary-Krause M, et al. Genetic determinants of response to clopidogrel and cardiovascular events. N Engl J Med. Jan. 22. 2009;360(4):363-75. [pmid: 19106083].
111 Trenk D, Hochholzer W, Fromm MF, et al. Cytochrome P450 2C19 681G>A polymorphism and high on-clopidogrel platelet reactivity associated with adverse 1-year clinical outcome of elective percutaneous coronary intervention with drug-eluting or bare-metal stents. Journal of the American College of Cardiology. May. 20. 2008;51(20):1925-34. [pmid: 18482659].
112 Rideg O, Komocsi A, Magyarlaki T, et al. Impact of genetic variants on post-clopidogrel platelet reactivity in patients after elective percutaneous coronary intervention. Pharmacogenomics. Sep. 2011;12(9):1269-80. [pmid: 21806387].
113 Harmsze AM, van Werkum JW, Souverein PC, et al. Combined influence of proton-pump inhibitors, calcium-channel blockers and CYP2C19*2 on on-treatment platelet reactivity and on the occurrence of atherothrombotic events after percutaneous coronary intervention. J Thromb Haemost. Oct. 2011;9(10):1892-901. [pmid: 21854540].
114 Jeong YH, Tantry US, Kim IS, et al. Effect of CYP2C19*2 and *3 loss-of-function alleles on platelet reactivity and adverse clinical events in East Asian acute myocardial infarction survivors treated with clopidogrel and aspirin. Circ Cardiovasc Interv. Dec. 1. 2011;4(6):585-94. [pmid: 22045970].
115 Tello-Montoliu A, Jover E, Marin F, et al. Influence of CYP2C19 polymorphisms in platelet reactivity and prognosis in an unselected population of non ST elevation acute coronary syndrome. Rev Esp Cardiol (Engl ). Mar. 2012;65(3):219-26.
116 Teixeira R, Monteiro P, Marques G, et al. CYP2C19*2 and prognosis after an acute coronary syndrome: Insights from a Portuguese center. Rev Port Cardiol. Apr. 2012;31(4):265-73. [pmid: 22377481].
117 Marcucci R, Giusti B, Paniccia R, et al. High on-treatment platelet reactivity by ADP and increased risk of MACE in good clopidogrel metabolizers. Platelets. 2012. Mar. 5.
118 Wallentin L, James S, Storey RF, et al. Effect of CYP2C19 and ABCB1 single nucleotide polymorphisms on outcomes of treatment with ticagrelor versus clopidogrel for acute coronary syndromes: a genetic substudy of the PLATO trial. Lancet. Oct. 16. 2010;376(9749):1320-28. [pmid: 20801498].
119 Harmsze AM, van Werkum JW, Hackeng CM, et al. The influence of CYP2C19*2 and *17 on on-treatment platelet reactivity and bleeding events in patients undergoing elective coronary stenting. Pharmacogenet Genomics. Mar. 2012;22(3):169-75. [pmid: 22228204].
120 Dai ZL, Chen H, Wu XY. Relationship between cytochrome P450 2C19*17 genotype distribution, platelet aggregation and bleeding risk in patients with blood stasis syndrome of coronary artery disease treated with clopidogrel. Zhong Xi Yi Jie He Xue Bao. Jun. 2012;10(6):647-54. [pmid: 22704413].
121 Collet JP, Hulot JS, Pena A, et al. Cytochrome P450 2C19 polymorphism in young patients treated with clopidogrel after myocardial infarction: a cohort study. Lancet. Jan. 24. 2009;373(9660):309-17. [pmid: 19108880].
122 Fernando H, Bassler N, Habersberger J, et al. Randomized double-blind placebo-controlled crossover study to determine the effects of esomeprazole on inhibition of platelet function by clopidogrel. J Thromb Haemost. Aug. 2011;9(8):1582-89. [pmid: 21696537].
123 Maeda A, Ando H, Asai T, et al. Differential impacts of CYP2C19 gene polymorphisms on the antiplatelet effects of clopidogrel and ticlopidine. Clinical Pharmacology & Therapeutics. Feb. 2011;89(2):229-33. [pmid: 21178986].
124 Simon T, Steg PG, Gilard M, et al. Clinical events as a function of proton pump inhibitor use, clopidogrel use, and cytochrome P450 2C19 genotype in a large nationwide cohort of acute myocardial infarction: results from the French Registry of Acute ST-Elevation and Non-ST-Elevation Myocardial Infarction (FAST-MI) registry. Circulation. Feb. 8. 2011;123(5):474-82. [pmid: 21262992].
125 Harmsze A, van Werkum JW, Bouman HJ, et al. Besides CYP2C19*2, the variant allele CYP2C9*3 is associated with higher on-clopidogrel platelet reactivity in patients on dual antiplatelet therapy undergoing elective coronary stent implantation. Pharmacogenetics and Genomics. Jan. 2010;20(1):18-25. [pmid: 19934793].
126 Liu XL, Wang ZJ, Yang Q, et al. Impact of CYP2C19 polymorphism and smoking on response to clopidogrel in patients with stable coronary artery disease. Chinese Medical Journal. Nov. 2010;123(22):3178-83. [pmid: 21163112].
127 Kesteven GL. The coefficient of variation. Nature. Oct. 1946;12(158):520. [pmid: 21065200].
128 Bland JM, Altman DG. Statistical methods for assessing agreement between two methods of clinical measurement. Lancet. Feb. 8. 1986;1(8476):307-10. [pmid: 2868172].
129 Lin LI. A concordance correlation coefficient to evaluate reproducibility. Biometrics. 1989;45(1):255-68. [pmid: 2720055].
130 Landis JR, Koch GG. The measurement of observer agreement for categorical data. Biometrics. 1977;33(1):159-74. [pmid: 843571].
131 Varenhorst C, James S, Erlinge D, et al. Assessment of P2Y12 inhibition with the point-of-care device VerifyNow P2Y12 in patients treated with prasugrel or clopidogrel coadministered with aspirin. Am Heart J. 2009;157:562. PMID: <[31] UNIQUE ID (DOI)>. [pmid: 19249429].
132 Jeong YH, Kim IS, Choi BR, et al. The optimal threshold of high post-treatment platelet reactivity could be defined by a point-of-care VerifyNow P2Y12 assay. European Heart Journal. Sep. 1. 2008;29(17):2186-87. [pmid: 18617479].
133 Michelson AD, Frelinger AL III, Braunwald E, et al. Pharmacodynamic assessment of platelet inhibition by prasugrel vs. clopidogrel in the TRITON-TIMI 38 trial. European Heart Journal. Jul. 2009;30(14):1753-63. [pmid: 19435740].
134 Angiolillo DJ, Bernardo E, Sabate M, et al. Impact of platelet reactivity on cardiovascular outcomes in patients with type 2 diabetes mellitus and coronary artery disease. Journal of the American College of Cardiology. Oct. 16. 2007;50(16):1541-47. [pmid: 17936152].
135 Aradi D, Konyi A, Palinkas L, et al. Thienopyridine therapy influences late outcome after coronary stent implantation. Angiology. Apr. 2008;59(2):172-78. [pmid: 18388039].
136 Bellemain-Appaix A, Montalescot G, Silvain J, et al. Slow response to clopidogrel predicts low response. Journal of the American College of Cardiology. Feb. 23. 2010;55(8):815-22. [pmid: 20170822].
137 Bliden KP, Dichiara J, Tantry US, et al. Increased risk in patients with high platelet aggregation receiving chronic clopidogrel therapy undergoing percutaneous coronary intervention: is the current antiplatelet therapy adequate?. Journal of the American College of Cardiology. Feb. 13. 2007;49(6):657-66. [pmid: 17291930].
138 Blindt R, Stellbrink K, de TA, et al. The significance of vasodilator-stimulated phosphoprotein for risk stratification of stent thrombosis. Thrombosis & Haemostasis. Dec. 2007;98(6):1329-34. [pmid: 18064332].
139 Breet NJ, van Werkum JW, Bouman HJ, et al. Do not adjust the platelet count in light transmittance aggregometry when predicting thrombotic events after percutaneous coronary intervention. Journal of Thrombosis & Haemostasis. Oct. 2010;8(10):2326-28. [pmid: 20695984].
140 Breet NJ, van Werkum JW, Bouman HJ, et al. Comparison of platelet function tests in predicting clinical outcome in patients undergoing coronary stent implantation. [Erratum appears in JAMA. 2010 Apr 7;303(13):1257], [Erratum appears in JAMA. 2011 Jun 1;305(21):2174], [Erratum appears in JAMA. 2011 Jun 1;305(21):2172-3; PMID: 21562204]. JAMA. Feb. 24. 2010;303(8):754-62. [pmid: 20179285].
141 Breet NJ, van Werkum JW, Bouman HJ, et al. High on-treatment platelet reactivity to both aspirin and clopidogrel is associated with the highest risk of adverse events following percutaneous coronary intervention. Heart. Jun. 2011;97(12):983-90. [pmid: 21478385].
142 Buonamici P, Marcucci R, Migliorini A, et al. Impact of platelet reactivity after clopidogrel administration on drug-eluting stent thrombosis. Journal of the American College of Cardiology. Jun. 19. 2007;49(24):2312-17. [pmid: 17572245].
143 Campo G, Valgimigli M, Gemmati D, et al. Poor responsiveness to clopidogrel: drug-specific or class-effect mechanism? Evidence from a clopidogrel-to-ticlopidine crossover study. Journal of the American College of Cardiology. Sep. 18. 2007;50(12):1132-37. [pmid: 17868803].
144 Cuisset T, Frere C, Quilici J, et al. High post-treatment platelet reactivity identified low-responders to dual antiplatelet therapy at increased risk of recurrent cardiovascular events after stenting for acute coronary syndrome. Journal of Thrombosis & Haemostasis. Mar. 2006;4(3):542-49. [pmid: 16371119].
145 Cuisset T, Frere C, Quilici J, et al. Benefit of a 600-mg loading dose of clopidogrel on platelet reactivity and clinical outcomes in patients with non-ST-segment elevation acute coronary syndrome undergoing coronary stenting. J Am Coll Cardiol. Oct. 3. 2006;48(7):1339-45. [pmid: 17010792].
146 Cuisset T, Frere C, Quilici J, et al. High post-treatment platelet reactivity is associated with a high incidence of myonecrosis after stenting for non-ST elevation acute coronary syndromes. Thrombosis & Haemostasis. Feb. 2007;97(2):282-87. [pmid: 17264958].
147 Cuisset T, Frere C, Quilici J, et al. Predictive values of post-treatment adenosine diphosphate-induced aggregation and vasodilator-stimulated phosphoprotein index for stent thrombosis after acute coronary syndrome in clopidogrel-treated patients. American Journal of Cardiology. Oct. 15. 2009;104(8):1078-82. [pmid: 19801028].
148 Cuisset T, Cayla G, Frere C, et al. Predictive value of post-treatment platelet reactivity for occurrence of post-discharge bleeding after non-ST elevation acute coronary syndrome. Shifting from antiplatelet resistance to bleeding risk assessment?. Eurointervention. Aug. 2009;5(3):325-29. [pmid: 19736156].
149 Frere C, Cuisset T, Quilici J, et al. ADP-induced platelet aggregation and platelet reactivity index VASP are good predictive markers for clinical outcomes in non-ST elevation acute coronary syndrome. Thrombosis & Haemostasis. Oct. 2007;98(4):838-43. [pmid: 17938809].
150 Geisler T, Langer H, Wydymus M, et al. Low response to clopidogrel is associated with cardiovascular outcome after coronary stent implantation. European Heart Journal. Oct. 2006;27(20):2420-25. [pmid: 17005534].
151 Geisler T, Grass D, Bigalke B, et al. The Residual Platelet Aggregation after Deployment of Intracoronary Stent (PREDICT) score. Journal of Thrombosis & Haemostasis. Jan. 2008;6(1):54-61. [pmid: 17949474].
152 Geisler T, Mueller K, Aichele S, et al. Impact of inflammatory state and metabolic control on responsiveness to dual antiplatelet therapy in type 2 diabetics after PCI: prognostic relevance of residual platelet aggregability in diabetics undergoing coronary interventions. [Erratum appears in Clin Res Cardiol. 2010 Nov;99(11):769]. Clinical Research in Cardiology. Nov. 2010;99(11):743-52. [pmid: 20526607].
153 Geisler T, Zurn C, Simonenko R, et al. Early but not late stent thrombosis is influenced by residual platelet aggregation in patients undergoing coronary interventions. European Heart Journal. Jan. 2010;31(1):59-66. [pmid: 19812059].
154 Gori AM, Marcucci R, Paniccia R, et al. Thrombotic events in high risk patients are predicted by evaluating different pathways of platelet function. Thrombosis & Haemostasis. Dec. 2008;100(6):1136-45. [pmid: 19132241].
155 Gori AM, Marcucci R, Migliorini A, et al. Incidence and clinical impact of dual nonresponsiveness to aspirin and clopidogrel in patients with drug-eluting stents. Journal of the American College of Cardiology. Aug. 26. 2008;52(9):734-39. [pmid: 18718420].
156 Gurbel PA, Bliden KP, Hiatt BL, et al. Clopidogrel for coronary stenting: response variability, drug resistance, and the effect of pretreatment platelet reactivity. Circulation. Jun. 17. 2003;107(23):2908-13. [pmid: 12796140].
157 Gurbel PA, Bliden KP. Durability of platelet inhibition by clopidogrel. American Journal of Cardiology. May. 1. 2003;91(9):1123-25. [pmid: 12714161].
158 Gurbel PA, Samara WM, Bliden KP. Failure of clopidogrel to reduce platelet reactivity and activation following standard dosing in elective stenting: implications for thrombotic events and restenosis. Platelets. Mar. 2004;15(2):95-99. [pmid: 15154601].
159 Gurbel PA, Bliden KP, Guyer K, et al. Platelet reactivity in patients and recurrent events post-stenting: results of the PREPARE POST-STENTING Study. Journal of the American College of Cardiology. Nov. 15. 2005;46(10):1820-26. [pmid: 16286165].
160 Gurbel PA, Antonino MJ, Bliden KP, et al. Platelet reactivity to adenosine diphosphate and long-term ischemic event occurrence following percutaneous coronary intervention: a potential antiplatelet therapeutic target. Platelets. Dec. 2008;19(8):595-604. [pmid: 19012177].
161 Gurbel PA, Bliden KP, Navickas IA, et al. Adenosine diphosphate-induced platelet-fibrin clot strength: a new thrombelastographic indicator of long-term poststenting ischemic events. Am Heart J. Aug. 2010;160(2):346-54. [pmid: 20691842].
162 Gurbel PA, Bliden KP, Butler K, et al. Response to ticagrelor in clopidogrel nonresponders and responders and effect of switching therapies: the RESPOND study. Circulation. Mar. 16. 2010;121(10):1188-99. [pmid: 20194878].
163 Hochholzer W, Trenk D, Bestehorn HP, et al. Impact of the degree of peri-interventional platelet inhibition after loading with clopidogrel on early clinical outcome of elective coronary stent placement. Journal of the American College of Cardiology. Nov. 7. 2006;48(9):1742-50. [pmid: 17084243].
164 Hoshino K, Horiuchi H, Tada T, et al. Clopidogrel resistance in Japanese patients scheduled for percutaneous coronary intervention. Circulation Journal. Feb. 2009;73(2):336-42. [pmid: 19106460].
165 Htun P, Fateh-Moghadam S, Bischofs C, et al. Low responsiveness to clopidogrel increases risk among CKD patients undergoing coronary intervention. Journal of the American Society of Nephrology. Apr. 2011;22(4):627-33. [pmid: 21273381].
166 L'Allier PL, Ducrocq G, Pranno N, et al. Clopidogrel 600-mg double loading dose achieves stronger platelet inhibition than conventional regimens: results from the PREPAIR randomized study. Journal of the American College of Cardiology. Mar. 18. 2008;51(11):1066-72. [pmid: 18342223].
167 Liu Y, Liu N, Li W, et al. Clopidogrel response variability and its correlation with early recurrent cardiovascular events in chinese patients undergoing percutaneous coronary intervention. Pharmacology. 2011;87(5-6):321-30. [pmid: 21613806].
168 Matetzky S, Shenkman B, Guetta V, et al. Clopidogrel resistance is associated with increased risk of recurrent atherothrombotic events in patients with acute myocardial infarction. [Erratum appears in Circulation. 2011 Oct 25;124(17):e459 Note: Bienart, Roy [corrected to Beinart, Roy]. Circulation. Jun. 29. 2004;109(25):3171-75. [pmid: 15184279].
169 Muller I, Besta F, Schulz C, et al. Prevalence of clopidogrel non-responders among patients with stable angina pectoris scheduled for elective coronary stent placement. Thrombosis & Haemostasis. May. 2003;89(5):783-87. [pmid: 12719773].
170 Muller K, Aichele S, Herkommer M, et al. Impact of inflammatory markers on platelet inhibition and cardiovascular outcome including stent thrombosis in patients with symptomatic coronary artery disease. Atherosclerosis. Nov. 2010;213(1):256-62. [pmid: 20728084].
171 Obradovic SD, Antovic JP, Antonijevic NM, et al. Elevations in soluble CD40 ligand in patients with high platelet aggregability undergoing percutaneous coronary intervention. Blood Coagulation & Fibrinolysis. Jun. 2009;20(4):283-89. [pmid: 19318922].
172 Saw J, Madsen EH, Chan S, et al. The ELAPSE (Evaluation of Long-Term Clopidogrel Antiplatelet and Systemic Anti-Inflammatory Effects) study. J Am Coll Cardiol. Dec. 2. 2008;52(23):1826-33. [pmid: 19038679].
173 Wang L, Wang X, Chen F. Clopidogrel resistance is associated with long-term thrombotic events in patients implanted with drug-eluting stents. Drugs in R & D. 2010;10(4):219-24. [pmid: 21171668].
174 Wang ZJ, Zhou YJ, Liu YY, et al. Impact of clopidogrel resistance on thrombotic events after percutaneous coronary intervention with drug-eluting stent. Thrombosis Research. May. 2009;124(1):46-51. [pmid: 19041120].
175 Yong G, Rankin J, Ferguson L, et al. Randomized trial comparing 600- with 300-mg loading dose of clopidogrel in patients with non-ST elevation acute coronary syndrome undergoing percutaneous coronary intervention: results of the Platelet Responsiveness to Aspirin and Clopidogrel and Troponin Increment after Coronary intervention in Acute coronary Lesions (PRACTICAL) Trial. Am Heart J. Jan. 2009;157(1):60-69. [pmid: 19081397].
176 Gurbel PA, Bliden KP, Antonino MJ, et al. Time dependence of clopidogrel loading effect: platelet activation versus platelet aggregation. Thromb Res. Jan. 2012;129(1):1-2. [pmid: 21862113].
177 Kalantzi KI, Dimitriou AA, Goudevenos JA, et al. The platelet hyporesponsiveness to clopidogrel in acute coronary syndrome patients treated with 75 mg/day clopidogrel may be overcome within 1 month of treatment. Platelets. 2012;23(2):121-31. [pmid: 21806493].
178 Angiolillo DJ, Bernardo E, Zanoni M, et al. Impact of insulin receptor substrate-1 genotypes on platelet reactivity and cardiovascular outcomes in patients with type 2 diabetes mellitus and coronary artery disease. J Am Coll Cardiol. Jun. 28. 2011;58(1):30-39. [pmid: 21700086].
179 Saad AA, Ismail EA, Darwish YW, et al. Platelet function profile post-clopidogrel therapy in patients with type 2 diabetes undergoing coronary stent implantation. Clin Appl Thromb Hemost. Jun. 2012;18(3):249-57. [pmid: 22146578].
180 Gaglia MA, Torguson R, Pakala R, et al. Correlation between light transmission aggregometry, VerifyNow P2Y12, and VASP-P platelet reactivity assays following percutaneous coronary intervention. J Interv Cardiol. Dec. 2011;24(6):529-34. [pmid: 21919956].
181 Aradi D, Rideg O, Vorobcsuk A, et al. Justification of 150 mg clopidogrel in patients with high on-clopidogrel platelet reactivity. Eur J Clin Invest. Apr. 2012;42(4):384-92. [pmid: 21902692].
182 Ge H, Zhou Y, Liu X, et al. Relationship between plasma inflammatory markers and platelet aggregation in patients with clopidogrel resistance after angioplasty. Angiology. Jan. 2012;63(1):62-66. [pmid: 21602258].
183 Kim IS, Jeong YH, Kang MK, et al. Correlation of high post-treatment platelet reactivity assessed by light transmittance aggregometry and the VerifyNow P2Y12 assay. J Thromb Thrombolysis. Nov. 2010;30(4):486-95. [pmid: 20449634].
184 Cuisset T, Frere C, Quilici J, et al. Lack of association between the 807 C/T polymorphism of glycoprotein Ia gene and post-treatment platelet reactivity after aspirin and clopidogrel in patients with acute coronary syndrome. Thrombosis & Haemostasis. Feb. 2007;97(2):212-17. [pmid: 17264949].
185 Linnemann B, Schwonberg J, Toennes SW, et al. Variability of residual platelet function despite clopidogrel treatment in patients with peripheral arterial occlusive disease. Atherosclerosis. Apr. 2010;209(2):504-09. [pmid: 20153859].
186 Reny JL, Berdague P, Poncet A, et al. Antiplatelet drug response status does not predict recurrent ischemic events in stable cardiovascular patients: results of the Antiplatelet Drug Resistances and Ischemic Events study. Circulation. Jun. 26. 2012;125(25):3201-10. [pmid: 22615340].
187 Campo G, Fileti L, de CN, et al. Long-term clinical outcome based on aspirin and clopidogrel responsiveness status after elective percutaneous coronary intervention: a 3T/2R (tailoring treatment with tirofiban in patients showing resistance to aspirin and/or resistance to clopidogrel) trial substudy. Journal of the American College of Cardiology. Oct. 26. 2010;56(18):1447-55. [pmid: 20951320].
188 Cotton JM, Worrall AM, Hobson AR, et al. Individualised assessment of response to clopidogrel in patients presenting with acute coronary syndromes: a role for short thrombelastography?. [Erratum appears in Cardiovasc Ther. 2010 Aug;28(4):254 Note: Rajendra, R [corrected to Raghuraman, R P]. Cardiovascular therapeutics. Jun. 2010;28(3):139-46. [pmid: 20406238].
189 Cuisset T, Hamilos M, Sarma J, et al. Relation of low response to clopidogrel assessed with point-of-care assay to periprocedural myonecrosis in patients undergoing elective coronary stenting for stable angina pectoris. American Journal of Cardiology. Jun. 15. 2008;101(12):1700-03. [pmid: 18549843].
190 de Miguel CA, Cuellas RC, Diego NA, et al. Post-treatment platelet reactivity predicts long-term adverse events better than the response to clopidogrel in patients with non-ST-segment elevation acute coronary syndrome. Revista Espanola de Cardiologia. Feb. 2009;62(2):126-35. [pmid: 19232185].
191 Gladding P, Webster M, Zeng I, et al. The pharmacogenetics and pharmacodynamics of clopidogrel response: an analysis from the PRINC (Plavix Response in Coronary Intervention) trial. Jacc: Cardiovascular Interventions. Dec. 2008;1(6):620-27. [pmid: 19463375].
192 Huczek Z, Filipiak KJ, Kochman J, et al. Medium on-treatment platelet reactivity to ADP is favorable in patients with acute coronary syndromes undergoing coronary stenting. Platelets. 2011;22(7):521-29. [pmid: 21443410].
193 Kim BK, Oh SJ, Yoon SJ, et al. A randomized study assessing the effects of pretreatment with cilostazol on periprocedural myonecrosis after percutaneous coronary intervention. Yonsei Medical Journal. Sep. 2011;52(5):717-26. [pmid: 21786434].
194 Ko YG, Suh JW, Kim BH, et al. Comparison of 2 point-of-care platelet function tests, VerifyNow Assay and Multiple Electrode Platelet Aggregometry, for predicting early clinical outcomes in patients undergoing percutaneous coronary intervention. Am Heart J. Feb. 2011;161(2):383-90. [pmid: 21315223].
195 Lee K, Lee SW, Lee JW, et al. The significance of clopidogrel low-responsiveness on stent thrombosis and cardiac death assessed by the verifynow p(2)y(12) assay in patients with acute coronary syndrome within 6 months after drug-eluting stent implantation. Sunhwangi. Dec. 2009;39(12):512-18.
196 Mangiacapra F, Patti G, Peace A, et al. Comparison of platelet reactivity and periprocedural outcomes in patients with versus without diabetes mellitus and treated with clopidogrel and percutaneous coronary intervention. American Journal of Cardiology. Sep. 1. 2010;106(5):619-23. [pmid: 20723634].
197 Mangiacapra F, Barbato E, Patti G, et al. Point-of-care assessment of platelet reactivity after clopidogrel to predict myonecrosis in patients undergoing percutaneous coronary intervention. Jacc: Cardiovascular Interventions. Mar. 2010;3(3):318-23. [pmid: 20298992].
198 Mangiacapra F, De BB, Muller O, et al. High residual platelet reactivity after clopidogrel: extent of coronary atherosclerosis and periprocedural myocardial infarction in patients with stable angina undergoing percutaneous coronary intervention. Jacc: Cardiovascular Interventions. Jan. 2010;3(1):35-40. [pmid: 20129566].
199 Marcucci R, Gori AM, Paniccia R, et al. Cardiovascular death and nonfatal myocardial infarction in acute coronary syndrome patients receiving coronary stenting are predicted by residual platelet reactivity to ADP detected by a point-of-care assay: a 12-month follow-up. Circulation. Jan. 20. 2009;119(2):237-42. [pmid: 19118249].
200 Patti G, Nusca A, Mangiacapra F, et al. Point-of-care measurement of clopidogrel responsiveness predicts clinical outcome in patients undergoing percutaneous coronary intervention results of the ARMYDA-PRO (Antiplatelet therapy for Reduction of MYocardial Damage during Angioplasty-Platelet Reactivity Predicts Outcome) study. Journal of the American College of Cardiology. Sep. 30. 2008;52(14):1128-33. [pmid: 18804738].
201 Patti G, Pasceri V, Vizzi V, et al. Usefulness of platelet response to clopidogrel by point-of-care testing to predict bleeding outcomes in patients undergoing percutaneous coronary intervention (from the Antiplatelet Therapy for Reduction of Myocardial Damage During Angioplasty-Bleeding Study). American Journal of Cardiology. Apr. 1. 2011;107(7):995-1000. [pmid: 21256470].
202 Price MJ, Endemann S, Gollapudi RR, et al. Prognostic significance of post-clopidogrel platelet reactivity assessed by a point-of-care assay on thrombotic events after drug-eluting stent implantation. European Heart Journal. Apr. 2008;29(8):992-1000. [pmid: 18263931].
203 Price MJ, Berger PB, Teirstein PS, et al. Standard- vs high-dose clopidogrel based on platelet function testing after percutaneous coronary intervention: the GRAVITAS randomized trial. [Erratum appears in JAMA. 2011 Jun 1;305(21);2174 Note: Stillablower, Michael E [corrected to Stillabower, Michael E]. JAMA. Mar. 16. 2011;305(11):1097-105. [pmid: 21406646].
204 Saw J, Densem C, Walsh S, et al. The effects of aspirin and clopidogrel response on myonecrosis after percutaneous coronary intervention: a BRIEF-PCI (Brief Infusion of Intravenous Eptifibatide Following Successful Percutaneous Coronary Intervention) trial substudy. JACC Cardiovasc Interv. Dec. 2008;1(6):654-59. [pmid: 19463380].
205 Suh JW, Lee SP, Park KW, et al. Multicenter randomized trial evaluating the efficacy of cilostazol on ischemic vascular complications after drug-eluting stent implantation for coronary heart disease: results of the CILON-T (influence of CILostazol-based triple antiplatelet therapy ON ischemic complication after drug-eluting stenT implantation) trial. Journal of the American College of Cardiology. Jan. 18. 2011;57(3):280-89. [pmid: 21232664].
206 Valgimigli M, Campo G, de CN, et al. Intensifying platelet inhibition with tirofiban in poor responders to aspirin, clopidogrel, or both agents undergoing elective coronary intervention: results from the double-blind, prospective, randomized Tailoring Treatment with Tirofiban in Patients Showing Resistance to Aspirin and/or Resistance to Clopidogrel study. Circulation. Jun. 30. 2009;119(25):3215-22. [pmid: 19528337].
207 Vavuranakis M, Vrachatis DA, Papaioannou TG, et al. Residual platelet reactivity after clopidogrel loading in patients with ST-elevation myocardial infarction undergoing an unexpectedly delayed primary percutaneous coronary intervention. - Impact on intracoronary thrombus burden and myocardial perfusion-. Circ J. 2011;75(9):2105-12. [pmid: 21712606].
208 Price MJ, Angiolillo DJ, Teirstein PS, et al. Platelet reactivity and cardiovascular outcomes after percutaneous coronary intervention: a time-dependent analysis of the Gauging Responsiveness with a VerifyNow P2Y12 assay: Impact on Thrombosis and Safety (GRAVITAS) trial. Circulation. Sep. 6. 2011;124(10):1132-37. [pmid: 21875913].
209 Mangiacapra F, Patti G, Barbato E, et al. A therapeutic window for platelet reactivity for patients undergoing elective percutaneous coronary intervention: results of the ARMYDA-PROVE (Antiplatelet therapy for Reduction of MYocardial Damage during Angioplasty-Platelet Reactivity for Outcome Validation Effort) study. JACC Cardiovasc Interv. Mar. 2012;5(3):281-89. [pmid: 22440493].
210 Park KW, Jeon KH, Kang SH, et al. Clinical outcomes of high on-treatment platelet reactivity in Koreans receiving elective percutaneous coronary intervention (from results of the CROSS VERIFY study). Am J Cardiol. Dec. 1. 2011;108(11):1556-63. [pmid: 21880289].
211 Park DW, Lee SW, Yun SC, et al. A point-of-care platelet function assay and C-reactive protein for prediction of major cardiovascular events after drug-eluting stent implantation. J Am Coll Cardiol. Dec. 13. 2011;58(25):2630-39. [pmid: 22152948].
212 Jin HY, Yang TH, Kim DI, et al. High post-clopidogrel platelet reactivity assessed by a point-of-care assay predicts long-term clinical outcomes in patients with ST-segment elevation myocardial infarction who underwent primary coronary stenting. Int J Cardiol. 2012. Jun. 9.
213 Yu LH, Kim MH, Zhang HZ, et al. Impact of platelet function test on platelet responsiveness and clinical outcome after coronary stent implantation: platelet responsiveness and clinical outcome. Korean Circ J. Jun. 2012;42(6):382-89. [pmid: 22787468].
214 Saraf S, Christopoulos C, Salha IB, et al. Impaired endogenous thrombolysis in acute coronary syndrome patients predicts cardiovascular death and nonfatal myocardial infarction. J Am Coll Cardiol. May. 11. 2010;55(19):2107-15. [pmid: 20447533].
215 Codner P, Vaduganathan M, Rechavia E, et al. Clopidogrel response up to six months after acute myocardial infarction. Am J Cardiol. Aug. 1. 2012;110(3):321-25. [pmid: 22534051].
216 Ari H, Ozkan H, Karacinar A, et al. The EFFect of hIgh-dose ClopIdogrel treatmENT in patients with clopidogrel resistance (The EFFICIENT Trial). Int J Cardiol. Jun. 14. 2012;157(3):374-80. [pmid: 21239075].
217 Ryu DS, Hong CK, Sim YS, et al. Anti-platelet drug resistance in the prediction of thromboembolic complications after neurointervention. Journal of Korean Neurosurgical Society. Oct. 2010;48(4):319-24. [pmid: 21113358].
218 Kang HS, Kwon BJ, Kim JE, et al. Preinterventional clopidogrel response variability for coil embolization of intracranial aneurysms: clinical implications. AJNR Am J Neuroradiol. Aug. 2010;31(7):1206-10. [pmid: 20223886].
219 Drazin D, Choulakian A, Nuno M, et al. Body weight: a risk factor for subtherapeutic antithrombotic therapy in neurovascular stenting. J Neurointerv Surg. Jun. 2011;3(2):177-81. [pmid: 21990814].
220 Bjelland TW, Hjertner O, Klepstad P, et al. Antiplatelet effect of clopidogrel is reduced in patients treated with therapeutic hypothermia after cardiac arrest. Resuscitation. Dec. 2010;81(12):1627-31. [pmid: 20727659].
221 Bonello L, Paganelli F, rpin-Bornet M, et al. Vasodilator-stimulated phosphoprotein phosphorylation analysis prior to percutaneous coronary intervention for exclusion of postprocedural major adverse cardiovascular events. Journal of Thrombosis & Haemostasis. Aug. 2007;5(8):1630-36. [pmid: 17488353].
222 Djukanovic N, Todorovic Z, Grdinic A, et al. Thienopyridine resistance among patients undergoing intracoronary stent implantation and treated with dual antiplatelet therapy: assessment of some modifying factors. Journal of Pharmacological Sciences. Aug. 2008;107(4):451-55. [pmid: 18719318].
223 El Ghannudi S, Ohlmann P, Meyer N, et al. Impact of P2Y12 inhibition by clopidogrel on cardiovascular mortality in unselected patients treated by percutaneous coronary angioplasty: a prospective registry. Jacc: Cardiovascular Interventions. Jun. 2010;3(6):648-56. [pmid: 20630458].
224 El Ghannudi S, Ohlmann P, Jesel L, et al. Impaired inhibition of P2Y(12) by clopidogrel is a major determinant of cardiac death in diabetes mellitus patients treated by percutaneous coronary intervention. Atherosclerosis. Aug. 2011;217(2):465-72. [pmid: 21524751].
225 Freynhofer MK, Brozovic I, Bruno V, et al. Multiple electrode aggregometry and vasodilator stimulated phosphoprotein-phosphorylation assay in clinical routine for prediction of postprocedural major adverse cardiovascular events. Thrombosis & Haemostasis. Aug. 2011;106(2):230-39. [pmid: 21614416].
226 Kalantzi KI, Dimitriou AA, Milionis HJ, et al. Clopidogrel differentially affects platelet-mediated thrombosis and inflammatory response in patients with acute coronary syndromes. Journal of Thrombosis & Haemostasis. Apr. 2011;9(4):875-78. [pmid: 21255245].
227 Morel O, El GS, Jesel L, et al. Cardiovascular mortality in chronic kidney disease patients undergoing percutaneous coronary intervention is mainly related to impaired P2Y12 inhibition by clopidogrel. Journal of the American College of Cardiology. Jan. 25. 2011;57(4):399-408. [pmid: 21251579].
228 Palmerini T, Barozzi C, Tomasi L, et al. A randomised study comparing the antiplatelet and antiinflammatory effect of clopidogrel 150 mg/day versus 75 mg/day in patients with ST-segment elevation acute myocardial infarction and poor responsiveness to clopidogrel: results from the DOUBLE study. Thrombosis Research. Apr. 2010;125(4):309-14. [pmid: 19604542].
229 Schafer A, Flierl U, Kossler J, et al. Early determination of clopidogrel responsiveness by platelet reactivity indexidentifies patients at risk for cardiovascular events after myocardial infarction. Thrombosis & Haemostasis. Jul. 2011;106(1):141-48. [pmid: 21655677].
230 Siller-Matula JM, Haberl K, Prillinger K, et al. The effect of antiplatelet drugs clopidogrel and aspirin is less immediately after stent implantation. Thromb Res. Apr. 2009;123(6):874-80. [pmid: 19135705].
231 Siller-Matula JM, Christ G, Lang IM, et al. Multiple electrode aggregometry predicts stent thrombosis better than the vasodilator-stimulated phosphoprotein phosphorylation assay. Journal of Thrombosis & Haemostasis. Feb. 2010;8(2):351-59. [pmid: 19943879].
232 Tselepis AD, Tsoumani ME, Kalantzi KI, et al. Influence of high-density lipoprotein and paraoxonase-1 on platelet reactivity in patients with acute coronary syndromes receiving clopidogrel therapy. J Thromb Haemost. Dec. 2011;9(12):2371-78. [pmid: 22008470].
233 Cuisset T, Quilici J, Grosdidier C, et al. Comparison of platelet reactivity and clopidogrel response in patients </= 75 Years Versus > 75 years undergoing percutaneous coronary intervention for non-ST-segment elevation acute coronary syndrome. Am J Cardiol. Nov. 15. 2011;108(10):1411-16. [pmid: 21872198].
234 Eshtehardi P, Windecker S, Cook S, et al. Dual low response to acetylsalicylic acid and clopidogrel is associated with myonecrosis and stent thrombosis after coronary stent implantation. Am Heart J. May. 2010;159(5):891-98. [pmid: 20435201].
235 Ivandic BT, Sausemuth M, Ibrahim H, et al. Dual antiplatelet drug resistance is a risk factor for cardiovascular events after percutaneous coronary intervention. Clinical Chemistry. Jun. 2009;55(6):1171-76. [pmid: 19359538].
236 Schulz S, Sibbing D, Braun S, et al. Platelet response to clopidogrel and restenosis in patients treated predominantly with drug-eluting stents. Am Heart J. Aug. 2010;160(2):355-61. [pmid: 20691843].
237 Sibbing D, Braun S, Morath T, et al. Platelet reactivity after clopidogrel treatment assessed with point-of-care analysis and early drug-eluting stent thrombosis. Journal of the American College of Cardiology. Mar. 10. 2009;53(10):849-56. [pmid: 19264241].
238 Sibbing D, Schulz S, Braun S, et al. Antiplatelet effects of clopidogrel and bleeding in patients undergoing coronary stent placement. Journal of Thrombosis & Haemostasis. Feb. 2010;8(2):250-56. [pmid: 19943882].
239 Sibbing D, Steinhubl SR, Schulz S, et al. Platelet aggregation and its association with stent thrombosis and bleeding in clopidogrel-treated patients: initial evidence of a therapeutic window. Journal of the American College of Cardiology. Jul. 20. 2010;56(4):317-18. [pmid: 20633826].
240 Sibbing D, Morath T, Braun S, et al. Clopidogrel response status assessed with Multiplate point-of-care analysis and the incidence and timing of stent thrombosis over six months following coronary stenting. Thrombosis & Haemostasis. Jan. 2010;103(1):151-59. [pmid: 20062919].
241 Gerotziafas GT, Zarifis J, Bandi A, et al. Description of response to aspirin and clopidogrel in outpatients with coronary artery disease using multiple electrode impedance aggregometry. Clin Appl Thromb Hemost. Jul. 2012;18(4):356-63. [pmid: 22311629].
242 Sibbing D, Bernlochner I, Schulz S, et al. Prognostic value of a high on-clopidogrel treatment platelet reactivity in bivalirudin versus abciximab treated non-ST-segment elevation myocardial infarction patients. ISAR-REACT 4 (Intracoronary Stenting and Antithrombotic Regimen: Rapid Early Action for Coronary Treatment-4) platelet substudy. J Am Coll Cardiol. Jul. 31. 2012;60(5):369-77. [pmid: 22682553].
243 Johnston LR, Larsen PD, La Flamme AC, et al. Suboptimal response to clopidogrel and the effect of prasugrel in acute coronary syndromes. Int J Cardiol. 2012. Mar. 31.
244 Siller-Matula JM, le-Karth G, Christ G, et al. Dual non-responsiveness to antiplatelet treatment is a stronger predictor of cardiac adverse events than isolated non-responsiveness to clopidogrel or aspirin. Int J Cardiol. 2012. Feb. 1.
245 Muller-Schunk S, Linn J, Peters N, et al. Monitoring of clopidogrel-related platelet inhibition: correlation of nonresponse with clinical outcome in supra-aortic stenting. Ajnr: American Journal of Neuroradiology. Apr. 2008;29(4):786-91. [pmid: 18223094].
246 Kwak YL, Kim JC, Choi YS, et al. Clopidogrel responsiveness regardless of the discontinuation date predicts increased blood loss and transfusion requirement after off-pump coronary artery bypass graft surgery. Journal of the American College of Cardiology. Dec. 7. 2010;56(24):1994-2002. [pmid: 21126640].
247 Tang FK, Lin LJ, Hua N, et al. Earlier application of loading doses of aspirin and clopidogrel decreases rate of recurrent cardiovascular ischemic events for patients undergoing percutaneous coronary intervention. Chin Med J (Engl ). Feb. 2012;125(4):631-38. [pmid: 22490487].
248 Malek LA, Spiewak M, Filipiak KJ, et al. Persistent platelet activation is related to very early cardiovascular events in patients with acute coronary syndromes. Kardiologia Polska. Jan. 12. 2007;65(1):40-45. [pmid: 17295159].
249 Foussas SG, Zairis MN, Patsourakos NG, et al. The impact of oral antiplatelet responsiveness on the long-term prognosis after coronary stenting. Am Heart J. Oct. 2007;154(4):676-81. [pmid: 17892990].
250 Smit JJ, van Werkum JW, ten BJ, et al. Prehospital triple antiplatelet therapy in patients with acute ST elevation myocardial infarction leads to better platelet aggregation inhibition and clinical outcome than dual antiplatelet therapy. Heart. Nov. 2010;96(22):1815-20. [pmid: 20889993].
251 Huczek Z, Filipiak KJ, Kochman J, et al. Prognostic significance of platelet function in the early phase of ST-elevation myocardial infarction treated with primary angioplasty. Med Sci Monit. Mar. 2008;14(3):CR144-CR151. [pmid: 18301358].
252 Moerenhout CM, Claeys MJ, Haine S, et al. Clinical relevance of clopidogrel unresponsiveness during elective coronary stenting: experience with the point-of-care platelet function assay-100 C/ADP. Am Heart J. Mar. 2010;159(3):434-38. [pmid: 20211306].
253 Chiu FC, Wang TD, Lee JK, et al. Residual platelet reactivity after aspirin and clopidogrel treatment predicts 2-year major cardiovascular events in patients undergoing percutaneous coronary intervention. Eur J Intern Med. Oct. 2011;22(5):471-77. [pmid: 21925055].
254 Dziewierz A, Dudek D, Heba G, et al. Inter-individual variability in response to clopidogrel in patients with coronary artery disease. Kardiologia Polska. 118 20. 62(2):108-17. [pmid: 15815794].
255 Lindvall G, Sartipy U, Bjessmo S, et al. Aprotinin reduces the antiplatelet effect of clopidogrel. Interactive Cardiovascular & Thoracic Surgery. Aug. 2009;9(2):178-81. [pmid: 19477870].
256 Lakkis NM, George S, Thomas E, et al. Use of ICHOR-platelet works to assess platelet function in patients treated with GP IIb/IIIa inhibitors. Catheter Cardiovasc Interv. Jul. 2001;53(3):346-51. [pmid: 11458412].
257 Mobley JE, Bresee SJ, Wortham DC, et al. Frequency of nonresponse antiplatelet activity of clopidogrel during pretreatment for cardiac catheterization. American Journal of Cardiology. Feb. 15. 2004;93(4):456-58. [pmid: 14969622].
258 Mega JL, Close SL, Wiviott SD, et al. Cytochrome P450 genetic polymorphisms and the response to prasugrel: relationship to pharmacokinetic, pharmacodynamic, and clinical outcomes. Circulation. May. 19. 2009;119(19):2553-60. [pmid: 19414633].
259 Mega JL, Close SL, Wiviott SD, et al. Genetic variants in ABCB1 and CYP2C19 and cardiovascular outcomes after treatment with clopidogrel and prasugrel in the TRITON-TIMI 38 trial: a pharmacogenetic analysis. Lancet. Oct. 16. 2010;376(9749):1312-19. [pmid: 20801494].
260 Kim IS, Jeong YH, Park Y, et al. Platelet inhibition by adjunctive cilostazol versus high maintenance-dose clopidogrel in patients with acute myocardial infarction according to cytochrome P450 2C19 genotype. Jacc: Cardiovascular Interventions. Apr. 2011;4(4):381-91. [pmid: 21511217].
261 Varenhorst C, James S, Erlinge D, et al. Genetic variation of CYP2C19 affects both pharmacokinetic and pharmacodynamic responses to clopidogrel but not prasugrel in aspirin-treated patients with coronary artery disease. Eur Heart J. Jul. 2009;30(14):1744-52. [pmid: 19429918].
262 Tantry US, Bliden KP, Wei C, et al. First analysis of the relation between CYP2C19 genotype and pharmacodynamics in patients treated with ticagrelor versus clopidogrel: the ONSET/OFFSET and RESPOND genotype studies. Circulation. Dec. Cardiovascular. 2010;(6):556-66. [pmid: 21079055].
263 Hwang SJ, Jeong YH, Kim IS, et al. Cytochrome 2C19 polymorphism and response to adjunctive cilostazol versus high maintenance-dose clopidogrel in patients undergoing percutaneous coronary intervention. Circulation: Cardiovascular Interventions. Oct. 2010;3(5):450-59. [pmid: 20823393].
264 Park KW, Park JJ, Lee SP, et al. Cilostazol attenuates on-treatment platelet reactivity in patients with CYP2C19 loss of function alleles receiving dual antiplatelet therapy: a genetic substudy of the CILON-T randomised controlled trial. Heart. Apr. 2011;97(8):641-47. [pmid: 21345843].
265 Collet JP, Hulot JS, Anzaha G, et al. High doses of clopidogrel to overcome genetic resistance: the randomized crossover CLOVIS-2 (Clopidogrel and Response Variability Investigation Study 2). JACC Cardiovasc Interv. Apr. 2011;4(4):392-402. [pmid: 21511218].
266 Taubert D, von Beckerath N, Grimberg G, et al. Impact of P-glycoprotein on clopidogrel absorption. Clin Pharmacol Ther. Nov. 2006;80(5):486-501. [pmid: 17112805].
267 Wallentin L, Varenhorst C, James S, et al. Prasugrel achieves greater and faster P2Y12receptor-mediated platelet inhibition than clopidogrel due to more efficient generation of its active metabolite in aspirin-treated patients with coronary artery disease. European Heart Journal. Jan. 1. 2008;29(1):21-30. [pmid: 18055486].
268 Gurbel PA, Bliden KP, Butler K, et al. Randomized double-blind assessment of the ONSET and OFFSET of the antiplatelet effects of ticagrelor versus clopidogrel in patients with stable coronary artery disease: the ONSET/OFFSET study. Circulation. Dec. 22. 2009;120(25):2577-85. [pmid: 19923168].
269 Gladding P, Webster M, Zeng I, et al. The Antiplatelet Effect of Higher Loading and Maintenance Dose Regimens of Clopidogrel: The PRINC (Plavix Response in Coronary Intervention) Trial. Jacc: Cardiovascular Interventions. Dec. 2008;1(6):612-19. PMID:. [doi: 10.1016/j.jcin.2008.09.005]. [pmid: 19463374].
270 Wang XD, Zhang DF, Zhuang SW, et al. Modifying clopidogrel maintenance doses according to vasodilator-stimulated phosphoprotein phosphorylation index improves clinical outcome in patients with clopidogrel resistance. Clinical Cardiology. May. 2011;34(5):332-38. [pmid: 21538380].
271 Bonello L, Camoin-Jau L, Armero S, et al. Tailored clopidogrel loading dose according to platelet reactivity monitoring to prevent acute and subacute stent thrombosis. American Journal of Cardiology. Jan. 1. 2009;103(1):5-10. [pmid: 19101221].
272 Bonello L, Camoin-Jau L, Arques S, et al. Adjusted clopidogrel loading doses according to vasodilator-stimulated phosphoprotein phosphorylation index decrease rate of major adverse cardiovascular events in patients with clopidogrel resistance: a multicenter randomized prospective study. Journal of the American College of Cardiology. Apr. 8. 2008;51(14):1404-11. [pmid: 18387444].
273 Tousek P, Osmancik P, Paulu P, et al. Clopidogrel up-titration versus standard dose in patients with high residual platelet reactivity after percutaneous coronary intervention: a single-center pilot randomised study. International Journal of Cardiology. Jul. 15. 2011;150(2):231-32. [pmid: 21663983].
274 Aleil B, Jacquemin L, De PF, et al. Clopidogrel 150 mg/day to overcome low responsiveness in patients undergoing elective percutaneous coronary intervention: results from the VASP-02 (Vasodilator-Stimulated Phosphoprotein-02) randomized study. Jacc: Cardiovascular Interventions. Dec. 2008;1(6):631-38. [pmid: 19463377].
275 Hazarbasanov D, Velchev V, Finkov B, et al. Tailoring clopidogrel dose according to multiple electrode aggregometry decreases the rate of ischemic complications after percutaneous coronary intervention. J Thromb Thrombolysis. Jul. 2012;34(1):85-90. PMID:. [doi: 10.1007/s11239-012-0684-z]. [pmid: 22249353].
276 Siller-Matula JM, Francesconi M, Dechant C, et al. Personalized antiplatelet treatment after percutaneous coronary intervention: The MADONNA study. Int J Cardiol. 2012. May. 30. PMID:. [pii: S0167-5273(12)00651-1]. [doi: 10.1016/j.ijcard.2012.05.040].
277 Montalescot G, Sideris G, Cohen R, et al. Prasugrel compared with high-dose clopidogrel in acute coronary syndrome. The randomised, double-blind ACAPULCO study. Thrombosis & Haemostasis. Jan. 2010;103(1):213-23. [pmid: 20062936].
278 Capranzano P, Ferreiro JL, Ueno M, et al. Pharmacodynamic effects of adjunctive cilostazol therapy in patients with coronary artery disease on dual antiplatelet therapy: Impact of high on-treatment platelet reactivity and diabetes mellitus status. Catheter Cardiovasc Interv. 2012. Mar. 19. [doi: 10.1002/ccd.24416].
279 Cuisset T, Frere C, Quilici J, et al. Glycoprotein IIb/IIIa inhibitors improve outcome after coronary stenting in clopidogrel nonresponders: a prospective, randomized study. Jacc: Cardiovascular Interventions. Dec. 2008;1(6):649-53. [pmid: 19463379].
280 Alexopoulos D, Galati A, Xanthopoulou I, et al. Ticagrelor versus prasugrel in acute coronary syndrome patients with high on-clopidogrel platelet reactivity following percutaneous coronary intervention: a pharmacodynamic study. J Am Coll Cardiol. Jul. 17. 2012;60(3):193-99. PMID:. [pii: S0735-1097(12)01508-2]. [doi: 10.1016/j.jacc.2012.03.050]. [pmid: 22789884].
281 Gremmel T, Steiner S, Seidinger D, et al. A high maintenance dose increases the inhibitory response to clopidogrel in patients with high on-treatment residual platelet reactivity. Int J Cardiol. Oct. 4. 2012;160(2):109-13. PMID:. [pii: S0167-5273(11)00348-2]. [doi: 10.1016/j.ijcard.2011.04.001]. [pmid: 21546102].
282 Alexopoulos D, Panagiotou A, Xanthopoulou I, et al. Antiplatelet effects of prasugrel vs. double clopidogrel in patients on hemodialysis and with high on-treatment platelet reactivity. J Thromb Haemost. Dec. 2011;9(12):2379-85. PMID:. [doi: 10.1111/j.1538-7836.2011.04531.x]. [pmid: 21985070].
283 Alexopoulos D, Xanthopoulou I, Davlouros P, et al. Prasugrel overcomes high on-clopidogrel platelet reactivity in chronic coronary artery disease patients more effectively than high dose (150 mg) clopidogrel. Am Heart J. Oct. 2011;162(4):733-39. PMID:. [pii: S0002-8703(11)00570-9]. [doi: 10.1016/j.ahj.2011.07.026]. [pmid: 21982667].
284 Trenk D, Stone GW, Gawaz M, et al. A randomized trial of prasugrel versus clopidogrel in patients with high platelet reactivity on clopidogrel after elective percutaneous coronary intervention with implantation of drug-eluting stents: results of the TRIGGER-PCI (Testing Platelet Reactivity In Patients Undergoing Elective Stent Placement on Clopidogrel to Guide Alternative Therapy With Prasugrel) study. J Am Coll Cardiol. Jun. 12. 2012;59(24):2159-64. PMID:. [pii: S0735-1097(12)00978-3]. [doi: 10.1016/j.jacc.2012.02.026]. [pmid: 22520250].
285 Alexopoulos D, Dimitropoulos G, Davlouros P, et al. Prasugrel overcomes high on-clopidogrel platelet reactivity post-stenting more effectively than high-dose (150-mg) clopidogrel: the importance of CYP2C19*2 genotyping. JACC Cardiovasc Interv. Apr. 2011;4(4):403-10. PMID:. [pii: S1936-8798(11)00134-8]. [doi: 10.1016/j.jcin.2010.12.011]. [pmid: 21511219].
286 Thygesen K, Alpert JS, White HD, et al. Universal Definition of Myocardial Infarction. Circulation. Nov. 27. 2007;116(22):2634-53. [pmid: 17951284].
287 Alexopoulos D, Panagiotou A, Xanthopoulou I, et al. Antiplatelet effects of prasugrel vs. double clopidogrel in patients on hemodialysis and with high on-treatment platelet reactivity. J Thromb Haemost. Dec. 2011;9(12):2379-85. PMID:. [doi: 10.1111/j.1538-7836.2011.04531.x]. [pmid: 21985070].
288 Aleil B, Leon C, Cazenave JP, et al. CYP2C19*2 polymorphism is not the sole determinant of the response to clopidogrel: implications for its monitoring. J Thromb Haemost. Oct. 2009;7(10):1747-49. [pmid: 19624462].
289 Price MJ, Murray SS, Angiolillo DJ, et al. Influence of genetic polymorphisms on the effect of high- and standard-dose clopidogrel after percutaneous coronary intervention: the GIFT (Genotype Information and Functional Testing) study. J Am Coll Cardiol. May. 29. 2012;59(22):1928-37. [pmid: 22624833].
290 Alexopoulos D, Dimitropoulos G, Davlouros P, et al. Prasugrel overcomes high on-clopidogrel platelet reactivity post-stenting more effectively than high-dose (150-mg) clopidogrel: the importance of CYP2C19*2 genotyping. JACC Cardiovasc Interv. Apr. 2011;4(4):403-10. [pmid: 21511219].
291 Holmes DR Jr., Dehmer GJ, Kaul S, et al. ACCF/AHA clopidogrel clinical alert: approaches to the FDA “boxed warning”: a report of the American College of Cardiology Foundation Task Force on clinical expert consensus documents and the American Heart Association endorsed by the Society for Cardiovascular Angiography and Interventions and the Society of Thoracic Surgeons. J Am Coll Cardiol. Jul. 2010;56(4):321-41. [pmid: 20633831].
292 Liu YP, Hao PP, Zhang MX, et al. Association of genetic variants in CYP2C19 and adverse clinical outcomes after treatment with clopidogrel: an updated meta-analysis. Thromb Res. Dec. 2011;128(6):593-94. [pmid: 21794898].
293 Zabalza M, Subirana I, Sala J, et al. Meta-analyses of the association between cytochrome CYP2C19 loss- and gain-of-function polymorphisms and cardiovascular outcomes in patients with coronary artery disease treated with clopidogrel. Heart. Jan. 2012;98(2):100-08. [pmid: 21693476].
294 Mega JL, Simon T, Collet JP, et al. Reduced-function CYP2C19 genotype and risk of adverse clinical outcomes among patients treated with clopidogrel predominantly for PCI: a meta-analysis. JAMA. Oct. 27. 2010;304(16):1821-30. [pmid: 20978260].
295 Jin B, Ni HC, Shen W, et al. Cytochrome P450 2C19 polymorphism is associated with poor clinical outcomes in coronary artery disease patients treated with clopidogrel. Mol Biol Rep. Mar. 2011;38(3):1697-702. [pmid: 20845077].
296 Li Y, Tang HL, Hu YF, et al. The gain-of-function variant allele CYP2C19*17: a double-edged sword between thrombosis and bleeding in clopidogrel-treated patients. J Thromb Haemost. Feb. 2012;10(2):199-206. [pmid: 22123356].
297 Sofi F, Giusti B, Marcucci R, et al. Cytochrome P450 2C19*2 polymorphism and cardiovascular recurrences in patients taking clopidogrel: a meta-analysis. Pharmacogenomics J. Jun. 2011;11(3):199-206. [pmid: 20351750].
298 Yamaguchi Y, Abe T, Sato Y, et al. Effects of VerifyNow P2Y12 test and CYP2C19*2 testing on clinical outcomes of patients with cardiovascular disease: A systematic review and meta-analysis. Platelets. 2012. Jul. 3. PMID:. [doi: 10.3109/09537104.2012.700969].
299 Brar SS, ten Berg J, Marcucci R, et al. Impact of Platelet Reactivity on Clinical Outcomes After Percutaneous Coronary Intervention: A Collaborative Meta-Analysis of Individual Participant Data. Journal of the American College of Cardiology. Nov. 1. 2011;58(19):1945-54. PMID:. [doi: 10.1016/j.jacc.2011.06.059]. [pmid: 22032704].
300 Snoep JD, Hovens MM, Eikenboom JC, et al. Clopidogrel nonresponsiveness in patients undergoing percutaneous coronary intervention with stenting: a systematic review and meta-analysis. Am Heart J. Aug. 2007;154(2):221-31. [pmid: 17643570].
301 Aradi D, Komocsi A, Vorobcsuk A, et al. Prognostic significance of high on-clopidogrel platelet reactivity after percutaneous coronary intervention: systematic review and meta-analysis. Am Heart J. Sep. 2010;160(3):543-51. [pmid: 20826265].
302 Combescure C, Fontana P, Mallouk N, et al. Clinical implications of clopidogrel non-response in cardiovascular patients: a systematic review and meta-analysis. J Thromb Haemost. May. 2010;8(5):923-33. [pmid: 20156305].
303 Sofi F, Marcucci R, Gori AM, et al. Clopidogrel non-responsiveness and risk of cardiovascular morbidity. An updated meta-analysis. Thromb Haemost. Apr. 2010;103(4):841-48. [pmid: 20135063].
304 Burke W. Genetic Testing. N Engl J Med. Dec. 5. 2002;347(23):1867-75. PMID:. [doi: 10.1056/NEJMoa012113]. [pmid: 12466512].
305 Baker SG. The Central Role of Receiver Operating Characteristic (ROC) Curves in Evaluating Tests for the Early Detection of Cancer. Journal of the National Cancer Institute. Apr. 2. 2003;95(7):511-15. [pmid: 12671018].
306 Castaldi PJ, Dahabreh IJ, Ioannidis JPA. An empirical assessment of validation practices for molecular classifiers. Briefings in Bioinformatics. May. 1. 2011;12(3):189-202. [pmid: 21300697].
307 Ransohoff DF. Rules of evidence for cancer molecular-marker discovery and validation. Nat Rev Cancer. Apr. 2004;4(4):309-14. PMID:. [doi: 10.1038/nrc1322]. [pmid: 15057290].
308 Tzoulaki I, Liberopoulos G, Ioannidis JPA. Assessment of Claims of Improved Prediction Beyond the Framingham Risk Score. JAMA: The Journal of the American Medical Association. Dec. 2. 2009;302(21):2345-52.
309 Macaskill P, Walter SD, Irwig L, et al. Assessing the gain in diagnostic performance when combining two diagnostic tests. Statist Med. 2002;21(17):2527-46. PMID:. [doi: 10.1002/sim.1227].
310 Pencina MJ, D'Agostino RB, Steyerberg EW. Extensions of net reclassification improvement calculations to measure usefulness of new biomarkers. Statist Med. 2011;30(1):11-21. PMID:. [doi: 10.1002/sim.4085].
311 Pencina MJ, D' Agostino RB, D' Agostino RB, et al. Evaluating the added predictive ability of a new marker: From area under the ROC curve to reclassification and beyond. Statist Med. 2008;27(2):157-72. PMID:. [doi: 10.1002/sim.2929].
312 Steyerberg EW, Pencina MJ, Lingsma HF, et al. Assessing the incremental value of diagnostic and prognostic markers: a review and illustration. European Journal of Clinical Investigation. 2012;42(2):216-28. PMID:. [doi: 10.1111/j.1365-2362.2011.02562.x]. [pmid: 21726217].
313 Pencina MJ, D'Agostino RB, Vasan RS. Statistical methods for assessment of added usefulness of new biomarkers. Clin Chem Lab Med. Dec. 2010;48(12):1703-11. [pmid: 20716010].
314 Scher HI, Nasso SF, Rubin EH, et al. Adaptive Clinical Trial Designs for Simultaneous Testing of Matched Diagnostics and Therapeutics. Clinical Cancer Research. Nov. 1. 2011;17(21):6634-40. [pmid: 22046024].
315 Simon R. Clinical trial designs for evaluating the medical utility of prognostic and predictive biomarkers in oncology. Per Med. 2010;7(1):33-47. [pmid: 20383292].
316 Cain LE, Robins JM, Lanoy E, et al. When to start treatment? A systematic approach to the comparison of dynamic regimes using observational data. Int J Biostat. 2010;6(2):18.
317 Hernan MA, Lanoy E, Costagliola D, et al. Comparison of Dynamic Treatment Regimes via Inverse Probability Weighting. Basic & Clinical Pharmacology & Toxicology. 2006;98(3):237-42. PMID:. [doi: 10.1111/j.1742-7843.2006.pto_329.x]. [pmid: 16611197].
318 Orellana L, Rotnitzky A, Robins JM. Dynamic regime marginal structural mean models for estimation of optimal dynamic treatment regimes, Part I: main content. Int J Biostat. 2010;6(2):8.