# Methods

This comparative effectiveness review evaluated the analytic validity, prognostic value, and comparative effectiveness of two types of medical tests (genetic testing for CYP2C19 variants and phenotypic testing to measure platelet reactivity) for patients who are candidates for or are already receiving antiplatelet therapy. A primary focus was the evaluation of test-guided therapeutic decisionmaking on patient-relevant clinical outcomes.

We performed a systematic review of the published literature using established methodologies as outlined in the Agency for Healthcare Research and Quality (AHRQ) “Methods Guide for Effectiveness and Comparative Effectiveness Reviews” (hereafter referred to as the Methods Guide; available at www.effectivehealthcare.ahrq.gov/methodsguide.cfm). The main sections in this chapter reflect the elements of the protocol established for the comparative effectiveness review; certain methods map to the Preferred Reporting Items for Systematic Reviews and Meta-Analyses (PRISMA) checklist.46 All methods and analyses were determined a priori. The protocol was developed with input from external clinical and methodological experts and in consultation with officers from AHRQ; it was posted online to solicit additional public comments.

## AHRQ Task Order Officer

The AHRQ Task Order Officer (TOO) assigned to this project was responsible for overseeing all aspects of this report. The TOO facilitated a common understanding among all parties involved in the project, resolved ambiguities, and fielded all queries from the Evidence-based Practice Center (EPC) regarding the scope and processes of the project. The TOO and other staff at AHRQ reviewed the report for consistency, clarity, and to ensure that it conforms to AHRQ standards.

## External Stakeholder Input

An initial set of questions for evidence review were nominated to the Effective Healthcare Program by a Federal agency. During a topic refinement phase, the initial questions that had previously been nominated for this report were refined with input from a panel of Key Informants. The Key Informants included a general internist, a cardiologist, a representative from the FDA, a representative from the Evaluation of Genomic Applications in Practice and Prevention (EGAPP) Working Group, health care payers (one public and one private), and a patient representative. After a public review of the proposed Key Questions, a group of experts was convened to form the Technical Expert Panel (TEP), which served in an advisory capacity to help refine the Key Questions, identify important issues, and define parameters for the review of evidence. TEP members included a representative of the EGAPP Working Group (who also nominated the topic and participated in Topic Refinement), experts in cardiovascular disease (including an interventional cardiologist), experts on the tests of interest, and a methodologist with expertise in health technology assessment. Discussions among the EPC, TOO, Key Informants, and, subsequently, the TEP occurred during a series of teleconferences and via email. In addition, input from the TEP was sought during compilation of the report when questions arose about the scope of the review.

## Key Questions

Four Key Questions were posed. Key Questions 1 and 2 pertains to the analytic validity and prognostic validity of the index tests of interest. Key Question 3 pertains to the comparative effectiveness of alternative test-and-treatment strategies (including a no-testing strategy). Finally, Key Question 4 pertains to the harms of test-directed treatment and testing per se. The complete Key Questions are presented at the end of the Introduction section.

## Analytic Framework

We developed an analytic framework (Figure 1) that maps the Key Questions within the context of populations, interventions, comparators, and outcomes of interest, as well as the chain of logic that evidence must support to link the interventions to health outcomes. Analytic and clinical validity were straightforward to represent in the analytic framework (Key Questions 1a, 1b, 2a, and 2b). Regarding treatment decisionmaking (Key Question 3a), we conceptualized the analytic framework as a decision problem, wherein patients' disease can be managed with one of the following approaches (depicted from top to bottom in the flow diagram):

1. Undergo genetic testing and then base the treatment decision on the test results.
2. Undergo genetic testing and then base the treatment decision on the test results. After receiving therapy for an adequate period of time, undergo phenotypic testing for platelet reactivity and use the results to decide whether the treatment strategy should be modified.
3. Receive standard treatment directly and, after an appropriate amount of time, undergo phenotypic testing for platelet reactivity and use the test results to decide whether the treatment strategy should be modified. Use of phenotypic testing (but not genetic testing) as a monitoring test can be considered a variation of this strategy in which the test is repeatedly performed.
4. Receive antiplatelet therapy without undergoing any testing (the current standard of care).

Figure 1 Analytic framework

Abbreviation: KQ = Key Question.

Figure 1 is an analytic framework that maps the Key Questions within the context of populations, interventions, comparators, and outcomes of interest, as well as the chain of logic that evidence must support to link the interventions to health outcomes. The patient interventions include: (1) genetic testing and treatment; (2) genetic testing and treatment, followed by phenotypic testing for platelet reactivity to determine whether treatment should be modified; (3) standard treatment, followed by phenotypic testing for platelet reactivity to determine if treatment should be modified; and (4) antiplatelet therapy without any testing (current standard of care).

The above strategies were identified as the most prevalent in published studies by preliminary searches conducted in preparation of this review. Additional variations of these strategies were uncovered by the full evidence review.

Modifiers of the effects of testing on outcomes (both in terms of predictive ability and decisionmaking) were reviewed in Key Questions 1c, 2c, and 3b. Tests and test-directed treatments may be associated with harms; this was investigated in Key Question 4.

## Literature Search and Abstract Screening

We conducted literature searches for studies in MEDLINE^®^, the Cochrane Central Trials Registry^®^, and the Cochrane Database of Systematic Reviews (from inception through July 27, 2012) without any language restriction. Our search included terms for the populations, tests, and drugs of interest (see Appendix A for complete search strings, which were extensively validated against previous reviews on the tests of interest). We also performed searches of the Human Genome Epidemiology Network (HuGENet) database and National Institutes of Health Genetic Association Database, using the same cutoff date (July 27, 2012). Finally, we performed a targeted search of the FDA Web site (last search performed on April 25, 2012).

A common set of 200 abstracts was first screened by four investigators and discrepancies were discussed in order to standardize screening practices and ensure understanding of the criteria by all team members. Two hundred additional abstracts were screened by all investigators to ensure that selection criteria were standardized. The remaining citations were split into nonoverlapping sets, each screened by a single reviewer. Abstracts were manually screened, using Abstrackr.47 Reviewers were specifically instructed to be inclusive in order to increase the sensitivity of abstract screening. Abstracts considered not relevant by a reviewer were rereviewed by a second team member. We retrieved the full text of articles for citations considered potentially relevant by at least one investigator.

We asked technical experts to provide additional citations of potentially relevant articles. Additional studies were identified through the perusal of reference lists of eligible studies, published clinical practice guidelines, and relevant narrative and systematic reviews. We also performed a targeted search of the FDA Web site (with the last search performed on April 25, 2012). On the basis of preliminary searches conducted during topic refinement, we provided the Scientific Resource Center (SRC, an entity within the Effective Health Care Program independent of the EPC) with a list of relevant technologies and manufacturers. The SRC solicited information from the manufacturers and organized all obtained material into scientific information packets (SIPs), which were then forwarded to the EPC for review. All articles identified through sources other than electronic database searches were reviewed for eligibility in full text, using the same criteria as for articles identified through our database searches.

Finally, we searched the ClinicalTrials.gov Web site (with the last search performed on May 3, 2012) to identify ongoing comparative trials of test-and-treat strategies for guiding antiplatelet treatment. We did not consider unpublished data other than that included in FDA documents or ClinicalTrials.gov.

## Study Selection and Eligibility Criteria

Full-text articles were reviewed independently by two investigators to determine eligibility. Disagreements regarding inclusion or relevance to a specific question were resolved by consensus including at least one additional senior investigator.

We considered both comparative and noncomparative studies for Key Questions pertaining to prognostic ability but focused on comparative studies of alternative test-and-treat strategies. Below we detail the study selection criteria for each Key Question. The criteria are also summarized in Table 1.

Table 1 Summary of the selection criteria used

Key Question | Population^*^ | Intervention | Comparator | Outcomes | Study Design | Sample Size
KQ1a | Adult patients with vascular disease who were candidates for or were receiving clopidogrel | Genetic testing of CYP2C19 variants | Alternative genotyping assays or repeat testing | Analytic accuracy, analytic precision, test detection limits, dilution linearity, test–retest reliability, interassay agreement; interlaboratory comparison, and proportion of nonevaluable samples for genetic test | Laboratory studies reporting on assay variability, reliability, accuracy, or agreement | ≥50 data points
KQ1b | Same as above | Phenotypic testing of on-clopidogrel platelet reactivity | No testing or other predictive tests | Intermediate outcomes (e.g., platelet reactivity as a biomarker of outcome status) Clinical outcomes: overall or cardiovascular mortality, fatal or nonfatal MI or ischemic stroke, stent thrombosis, bleeding, and health-related and overall quality of life | Prospective or retrospective cohort or case–control studies using genetic test to predict outcomes, comparative studies (of clopidogrel vs. alternative treatment), or clopidogrel-based treatment groups from RCTs | ≥10 patients
KQ1c | Same as above | Genetic testing of CYP2C19 variants | No testing or other predictive tests | Same as for KQ1b | Same as for KQ1b but in addition, formal interaction tests or statistics comparing the test effect among strata of the modifier of interest must have been reported or calculation permitted | ≥10 patients
KQ2a | Same as above | Phenotypic testing of on-clopidogrel platelet reactivity | Alternative phenotypic test assays or repeat testing | Analytic accuracy, analytic precision, test detection limits, dilution linearity, test–retest reliability, interassay agreement; interlaboratory comparison, and proportion of nonevaluable samples for phenotypic test | Laboratory studies reporting on assay variability, reliability, accuracy, or agreement | ≥50 data points
KQ2b | Same as above | Genetic testing of CYP2C19 variants | No testing or other predictive tests | Intermediate outcomes (e.g., platelet reactivity as a biomarker of outcome status) Clinical outcomes: overall or cardiovascular mortality, fatal or nonfatal MI or ischemic stroke, stent thrombosis, bleeding, and health-related and overall quality of life | Prospective or retrospective cohort studies using phenotypic test to predict outcomes, comparative studies (of clopidogrel vs. alternative treatment), or clopidogrel-based treatment groups from RCTs | ≥10 patients
KQ2c | Same as above | Phenotypic testing of on-clopidogrel platelet reactivity | No testing or other predictive tests | Same as for KQ2b | Same as for KQ2b but fin addition, normal interaction tests or statistics comparing the test effect among strata of the modifier of interest must have been reported or calculation permitted | ≥10 patients
KQ3a | Same as above | Management strategies involving CYP2C19 testing, followed by treatment decision on basis of test result^**^ | No-testing strategy or alternative test-and-treat strategy | Intermediate outcomes (e.g., platelet reactivity as a biomarker of outcome status) Impact on therapeutic decisionmaking Clinical outcomes: overall or cardiovascular mortality, fatal or nonfatal MI or ischemic stroke, stent thrombosis, bleeding, and health-related and overall quality of life | Randomized and nonrandomized comparative studies of test-and-treat strategies in unselected populations or “repurposed” RCTs (e.g., clopidogrel-based vs. non–clopidogrel-based management; see text for more information) | ≥10 patients per group
KQ3b | Same as above | Management strategies involving phenotypic testing of on-clopidogrel platelet reactivity, followed by treatment decision on basis of test result^**^ | No-testing strategy or alternative test-and-treat strategy | Same as for KQ 3a | Same as for KQ3a | ≥10 patients per group
KQ4 | Same as above | Same as for KQ3a and 3b | Same as for KQ3a and 3b | Adverse effects of test-directed treatment (e.g., bleeding, gastrointestinal event, liver toxic effect) and of testing (e.g., test-related anxiety, events secondary to venipuncture) | Same as for KQ3a; also noncomparative studies reporting harms of testing | ≥10 patients (per group, for comparative studies)

Abbreviations: KQ = Key Question; MI = myocardial infarction; RCT = randomized controlled trial.

* The population of interest was the same for all the Key Questions and included cardiovascular, cerebrovascular, or peripheral arterial disease (acute coronary syndromes; percutaneous coronary intervention or coronary artery bypass grafting with a contraindication to acetylsalicylic acid; previous ischemic stroke or transient ischemic attack; established peripheral arterial disease; and atrial fibrillation with contraindications to vitamin K antagonist treatment).

** Potential test-and-treat strategies included testing for CYP2C19 genetic variants, testing for platelet reactivity, or both, to guide selection among alternative antiplatelet treatment strategies (including standard clopidogrel dosing, increased clopidogrel dosing, and non–clopidogrel-based antiplatelet therapies such as ticagrelor or prasugrel).

We did not include non–English language studies but we recorded the number of studies that were excluded on the grounds of language for each Key Question. We excluded narrative reviews, editorials, letters to the editor, and other papers not presenting primary research data. We also excluded studies reporting exclusively on healthy individuals. Appendix B lists all the studies excluded after full-text screening and the reason for exclusion.

### Populations and Conditions of Interest

For all Key Questions, the populations of interest consisted of adult patients with cardiovascular, cerebrovascular, or peripheral arterial disease who were candidates for or were receiving clopidogrel. Specifically, we included studies enrolling: (1) patients with acute coronary syndromes, including those who had experienced a myocardial infarction (ST-elevation or non–ST-elevation), or patients who had unstable angina; (2) patients who were undergoing PCI for acute coronary syndromes, those who had undergone PCI with stent implantation (of either bare-metal or drug-eluting stents), or those who had undergone CABG (and had a contraindication to acetylsalicylic acid); (3) patients with a previous ischemic stroke or transient ischemic attack; (4) patients with established peripheral arterial disease; and (5) patients with atrial fibrillation for whom vitamin K antagonist therapy was not suitable. We also reviewed studies evaluating the use of clopidogrel for the prevention of vascular events in high-risk populations (e.g., patients on hemodialysis).

### Interventions

For Key Questions 1 and 2 we reviewed studies of genetic testing (for CYP2C19 variants) or phenotypic testing. Genetic variants of interest were all variants of the CYP2C19 locus, including loss- and gain-of-function alleles. Phenotypic tests of interest were those assessing on-clopidogrel platelet reactivity (the degree to which platelets are able to be activated by an agonist). After consultation with the TEP and the TOO, it was decided that tests of platelet activation (where an agonist is not used) would not be reviewed, because they are not in wide clinical use and are less standardized than tests of reactivity.

For Key Questions 3 (comparative effectiveness of test-and-treat strategies) and 4 (harms) we reviewed studies of management strategies involving genetic testing for CYP2C19 variants or phenotypic testing for platelet reactivity, followed by therapeutic management decisions based on test results. Potential test-and-treat strategies included testing for CYP2C19 genetic variants, testing for platelet reactivity, or both, to guide the choice among alternative antiplatelet treatment strategies (including standard clopidogrel dosing, increased clopidogrel dosing, and use of non–clopidogrel-based antiplatelet therapies such as ticagrelor or prasugrel).

### Comparators

For Key Questions 1 and 2 (prognostic effects), a common implicit comparator is not performing any testing; in studies where information was reported on the prognostic effect of testing without comparisons against alternative tests, we considered the comparison to be testing versus no testing (implicit). However, we included studies comparing the prognostic accuracy of more than one genetic or phenotypic test applied to the same patient population.

For Key Questions 3 (comparative effectiveness of test-and-treat strategies) and 4 (harms), we considered as comparators either a no-testing strategy or alternative test-and-treat strategies.

### Outcomes

For Key Questions 1a and 2a (analytic validity) we considered the following outcomes: analytic accuracy (e.g., analytic sensitivity and specificity), analytic precision, test detection limits, dilution linearity, test–retest reliability (e.g., intra-assay agreement, measurement reproducibility), interassay agreement, interlaboratory comparisons (e.g., interlaboratory agreement, measurement reproducibility), and the proportion of nonevaluable samples.

For Key Questions 1b–c and 2b–c we considered both intermediate outcomes (platelet reactivity, when used as a biomarker of outcome status) and clinical outcomes: overall mortality, myocardial infarction (fatal or nonfatal), ischemic stroke (fatal or nonfatal), cardiovascular mortality, stent thrombosis (for patients with implanted stents), combinations of the above (composite clinical outcomes), bleeding events (categorized by severity and by the organ system affected), and health-related and overall quality of life. Following discussions with Key Informants, it was decided that the review would not cover pharmacokinetic outcomes because they do not directly translate into clinical outcomes and because pharmacokinetic assessments are not routinely performed in patients receiving antiplatelet treatment.

For Key Question 3 we considered intermediate outcomes (platelet reactivity, when used as a biomarker of outcome status, and impact on therapeutic decisionmaking [i.e., change in clinical decisions on the basis of test results) and clinical outcomes (see previous paragraph).

Finally, for Key Question 4, we considered adverse effects of test-directed treatment (including bleeding events and others such as gastrointestinal events and liver toxic effects) and adverse effects of testing per se (such as test-related anxiety and adverse events secondary to venipuncture).

### Study Designs

#### Key Questions 1 and 2

For Key Questions 1a and 2a, we reviewed studies of analytic validity (single laboratory studies or interlaboratory comparisons) reporting on metrics of intra-assay variability, reliability, analytic sensitivity against a reference standard, or agreement between methods.

For Key Questions 1b–c and 2b–c, we included prospective or retrospective cohort studies using the index tests of interest to predict outcomes. For Key Question 1b we also considered case–control studies. We excluded case–control studies from Key Question 2b because platelet reactivity is modified by coronary events, is variable over time, and is affected by treatments that are bound to be systematically different between cases and controls [i.e., platelet reactivity in the cases is modified by post-event exposures (e.g., treatment instituted after an ischemic event) and may be nonrepresentative of reactivity levels preceding the event of interest]. For analyses of prognostic ability, we also included clopidogrel-treated arms of comparative studies (of clopidogrel versus alternative strategies). We included studies assessing a single index test as well as those assessing more than one test (directly comparative studies). For Key Questions pertaining to effect modification (1c, 2c, and 3c) we required that studies reported formal interaction tests or allowed for the calculation of statistics that compare the test effect among strata of the modifier of interest.

#### Key Questions 3 and 4

For Key Questions 3 and 4 we included randomized and nonrandomized comparative studies of test-and-treat strategies in unselected populations. Because such studies are rare we also considered “repurposed” randomized controlled trials.^c,48-50^ These studies are randomized investigations comparing alternative therapeutic interventions (e.g., clopidogrel-based vs. non–clopidogrel-based management). Biological samples are collected from all patients (all comparison groups) and are analyzed for one or more biomarker of interest. Because for each patient there is information on biomarker status, treatment assignment, and outcomes, the studies can provide information on effect modification (i.e., the presence of a differential treatment effect in biomarker-“positive” vs. biomarker-“negative” patients). This effect modification provides information about whether the biomarker can be used to guide therapeutic decisionmaking. In addition, we included studies where patients were selected on the basis of tests of interest (e.g., platelet reactivity above some threshold) and then randomly assigned to one of at least two alternative treatment strategies. For this study design we only considered randomized comparative studies (parallel arm or cross-over) because they can provide information on the unconfounded effect of treatment conditional on the test result. For Key Question 4 we planned to include noncomparative studies reporting on the harms of testing per se, but none of these studies were identified.

c These studies are also referred to as “prospective–retrospective” studies in the oncology literature, which is where the design has been applied mostly (presumably because of the availability of archived tissue samples in randomized trials of cancer therapeutics).48

### Sample Size and Timing

For Key Questions relevant to analytic validity, we used a minimum sample size of 50 patients (or data points, depending on the design and analysis of the primary studies). This minimum sample size is often recommended for statistical comparisons of analytic validity (e.g., test–retest reliability or Bland–Altman test for agreement between continuous measurements). The precision of estimates of analytic validity depends on the specific statistic used; generally, a sample size of 50 excludes studies that are too small to be informative without being otherwise restrictive. For all other Key Questions (1b–c, 2b–c, 3, and 4), we included studies reporting on at least 10 patients (in total or, when there were ≥2 study groups, per group), because smaller studies produce very imprecise estimates.

We included studies of any duration of followup, including those that did not report this information. We considered short-term and long-term outcomes separately (using a cutoff time of 30 days, wherever appropriate). For patients undergoing invasive or interventional procedures (e.g., PCI or CABG), we also considered periprocedural events separately.

### Settings

Studies conducted in all relevant care settings (e.g., primary and secondary care or rural and urban clinics) were included. Study selection was not based on cointerventions.

## Data Extraction

A single investigator extracted data from each study; quantitative results were verified by a second reviewer. Disagreements were resolved by consensus involving a third investigator. Data were extracted into standard forms; separate forms were generated for each Key Question. Extraction forms were piloted on three to five articles for each Key Question and revisions were made as needed. We extracted information on the following items: patient selection criteria, population characteristics, sample size, study design, analytic details, and outcomes.

### Data Synthesis

#### Qualitative Synthesis

We summarized the findings of the report according to the order of the Key Questions. Within each Key Question, results were organized for each appropriate subgroup on the basis of the populations assessed and clinical indications for clopidogrel use (e.g., acute coronary syndromes, stroke, atrial fibrillation not suitable for vitamin K antagonists, etc.), index tests used, and outcomes assessed. Data are presented in evidence tables and are summarized narratively in the full text. We use tables and graphs (histograms, weighted scatterplots, and others) to synthesize information across studies.

Predefined subgroups of interest were those defined by race or ethnicity, sex, specific assay used, and clinical setting of test use (e.g., short-term administration of clopidogrel during treatment of acute cardiac events or PCI vs. chronic clopidogrel use).

#### Quantitative Synthesis

##### Meta-Analysis

We performed meta-analysis when at least three studies were available on sufficiently similar populations, using the same test, and assessing the same outcomes. Sufficient similarity was judged on the basis of the clinical heterogeneity of patient populations, interventions, and testing strategies, as well as the methodological heterogeneity of study designs and outcomes reported. The determination on the appropriateness of meta-analysis was made before any statistical analysis was conducted; we did not base the decision to perform meta-analysis on statistical criteria for heterogeneity. Such criteria are often inadequate (e.g., low power when the number of studies is small) and do not account for the ability to explore and explain heterogeneity by examining study-level characteristics. We provide our rationale for performing (or not performing) meta-analysis on a case-by-case basis in the Results section. Of particular note was our decision not to combine studies of different phenotypic tests for platelet reactivity. This decision was based on the different principles of measurement implemented in different assays and our own findings on interassay agreement (presented under Key Question 2a), which indicated that agreement for identifying lack of response may be limited. Similarly, we decided not to combine randomized treatment trials providing information about effect modification because they had enrolled heterogeneous patient populations and compared different pairs of interventions (i.e., the magnitude and direction of effect modification by the tests of interest was likely to vary among different treatment comparisons).

Meta-analyses of relative risk (RR) estimates from individual studies were performed using random effects inverse-variance models that account for unexplained heterogeneity between studies. Fixed effects models were evaluated in sensitivity analyses. We estimated between-study heterogeneity using the DerSimonian–Laird method.51 Between-study heterogeneity was assessed on the basis of Cochran's chi-square–based Q statistic.52 Heterogeneity was considered statistically significant when the p-value of the Q statistic (P_Q_) was less than 0.1, to account for the low power of the test when the number of studies is relatively low (as was the case in our review). Between-study inconsistency was assessed using the I^2^ index.53I^2^ values higher than 50 percent were considered to indicate moderate inconsistency; values above 75 percent, severe inconsistency. These cutoff values are arbitrary and I^2^ estimates are typically associated with substantial uncertainty.54 In these analyses, for studies where no events were observed in a single arm we used a continuity correction of 0.5. Studies in which no events were observed in both arms (“zero total event” studies) were excluded from meta-analyses.

For meta-analyses of studies of prognostic effects, we also estimated summary prognostic sensitivity and specificity, using bivariate random effects models with the exact binomial likelihood to model within study variability.55,56 Analyses using the exact binomial likelihood do not require continuity corrections when zero events are observed. Although analyses of prognostic sensitivity and specificity can supplement the information from meta-analyses of RRs, we note that they are unadjusted for other patient level covariates and do not account for the time-to-event nature of the outcomes of interest (the necessary information is never reported in individual published studies).

###### Genetic Model for Studies of CYP2C19 Variants

In the case of biallelic loci dominant, recessive, additive, or co-dominant genetic models of inheritance are possible. Inferences under a misspecified model can lead to misleading conclusions regarding the magnitude and direction of genotype-phenotype associations. The “true” genetic model for the effect of CYP2C19 polymorphisms on pharmacodynamic and clinical outcomes is not known. Some evidence suggests that the loss-of-function trait for the CYP2C19 gene has a dominant mode of inheritance, whereas others support an additive or recessive model.21-23 Similar data exist for the gain-of-function (*17) allele. Following previous meta-analyses on the same variants, in our primary analyses we used a dominant model for all minor alleles (i.e., a model that assumes carriers of one and carriers of two minor alleles have the same phenotype).20,41 In addition to having been used by other investigators, the dominant genetic model allows the inclusion of data from the maximum possible number of studies (because data in relevant publications were often inadequate to perform analyses under an additive model). However, to assess the robustness of our findings under different genetic models we repeated meta-analyses using a recessive genetic model (i.e., a model that assumes carriers of one minor allele and non-carriers have the same phenotype) and an additive (per-allele) genetic model (i.e., a model that quantifies the effect of each additional variant allele on the phenotype). Although a model-free approach for meta-analysis of genetic associations is particularly appealing in the presence of uncertainty about the underlying mode of inheritance, available methods are impractical unless the number of studies is fairly large. For this reason they were not implemented for this review.24

###### Measures of Association for Prognostic Studies

Because the majority of studies reporting on clinical outcomes included in this report had longitudinal designs, the most appropriate statistical analyses take into account the time to occurrence of events (e.g., by using survival analysis methods). For this reason, we used hazard or incidence rate ratios in our meta-analyses whenever available or extractable from the reviewed studies. When such statistics were not reported (and could not be calculated), we used risk (proportion) ratios because they approximate the relative incidence rate. For case–control studies we used odds ratios (reported or calculated) because they are valid statistics for these designs and approximate the risk ratio or incidence rate ratio (depending on sampling methods).57-59 For parsimony, we refer to all these statistics as “relative risks” (RRs).

##### Subgroup and Meta-Regression Analysis

To assess the impact of study-level characteristics on estimates of the effect size, we performed univariable (one study-level characteristic used as a predictor at a time) random effects meta-regression.53 We did not perform analyses using averages of patient-level measurements as predictors (e.g., mean age or percent smokers) because these are prone to ecological bias.60 Subgroup and meta-regression analyses were performed for prespecified factors if reported at the group level (i.e., race or ethnicity, sex, specific assay used, and clinical setting of test use) and for quality items included in our quality assessment. We also explored temporal trends in the reported effect sizes using meta-regression with year of publication as the covariate.

##### Small-Study Effects

We used Egger's regression-based test61 to assess the presence of “small-study effects”62—that is, differences between larger (more precise) and smaller (less precise) studies. Although this test is often referred to as a test for “publication bias,”61 theoretical and empirical studies show that the test, and related visualization methods (“funnel plots”), cannot differentiate publication bias from “true” heterogeneity between smaller and larger studies.63,64 Furthermore, selective outcome reporting, other biases, or chance can also lead to significant results. Because of these reasons, we interpreted the results of tests for small-study effects with caution65 and did not display funnel plots.

##### Sensitivity Analyses

When meta-analyses were conducted, we performed the following sensitivity analyses, as appropriate: leave-one-out meta-analysis, analysis under a fixed effects model, and analysis after excluding the first study of a specific association (to assess “first-study effects”66,67).

##### Population Overlap Across Publications

We took particular care to avoid double counting (both in qualitative and quantitative analyses) when published papers reported on potentially (fully or partially) overlapping patient populations. Potential overlap was assessed on the basis of the sampling population of each study, the enrollment period for each publication, the patient selection criteria, and information on overlap provided by the authors in the published papers. We used a conservative approach of considering as potentially overlapping the populations of studies conducted by the same investigators when overlap could not be ruled out on the basis of the above criteria. In the presence of suspected overlap we based our analysis on the study reporting the largest number of outcome events (typically, the study reporting on the longest followup for longitudinal studies). In all cases of suspected overlap we contacted the corresponding authors of each paper using a standardized protocol with a primary contact email and 2 reminders over a period of 6 weeks. Only two authors (corresponding to 6 publications that we considered as overlapping) replied; in all cases they confirmed our suspicions.

##### Software

All analyses were performed using Stata IC, version 12.1 (Stata Corp., College Station, TX). All tests were two-sided (except those for heterogeneity) and statistical significance was defined as a p-value of less than 0.05. We did not perform any adjustments for multiple comparisons.

### Risk of Bias and Completeness of Reporting of Individual Studies

For assessing the risk of bias, we followed recently updated guidance from the Methods Guide.68,69 We used different criteria for assessing the risk of bias (and when appropriate, the completeness of reporting) for each Key Question.

For studies of analytic validity (Key Questions 1a and 2a), we compiled a list of 11 items for assessing quality and completeness of reporting based on a recent AHRQ Methods Report.70 The list of criteria is provided in Appendixes D (for Key Question 1a) and E (for Key Question 2a). Each item was rated as “Yes,” “No,” “Unclear/Not reported,” or “Not applicable.”

For studies of predictive ability (Key Questions 1b–c and 2b–c), we based our assessment on the recently proposed Quality Assessment of Diagnostic Accuracy Studies (QUADAS)–2 instrument,71 a new version of the validated QUADAS list of quality items72-74 for systematic reviews of medical tests. Briefly, the tool assesses four domains for risk of bias: patient selection, index test, reference standard test (outcome), and flow and timing. Each domain is evaluated according to a set of relevant “signaling” questions answered as “Yes,” “No,” or “Unclear/Not reported. The complete tool and the operational definitions we used for each item are presented in Appendix D (for Key Question 1b) and Appendix E (for Key Question 2b). After scoring each item, a summary risk-of-bias assessment is performed for each of the four domains and then an overall determination (across the four domains) is made. We used arbitrary thresholds based on the number of items scored as having been adequately addressed (i.e., indicative of low risk of bias) to classify studies into three categories (A, B, or C) indicating low, moderate, and high risk of bias, respectively. This approach was used as a shorthand description of the available evidence; throughout the report we emphasize the component items that contributed to the summary rate.

Finally, for studies providing information on test-and-treatment strategies (Key Questions 3 and 4) we used a combination of items from the QUADAS-2 tool and the Cochrane risk of bias tool.75 The complete list of items assessed is provided in Appendix F. Each item was labeled as “Yes,” “No,” or “Unclear/Not reported.” Two independent reviewers evaluated the risk of bias for each study and disagreements were resolved by consensus including a third reviewer.

### Grading the Body of Evidence

We graded the strength of the body of evidence for the Key Questions following the Methods Guide and recently updated recommendations for the EPC program.68,76 Briefly, the grading of the strength of evidence was based on four dimensions: risk of bias, consistency, directness, and precision. The risk of bias assessment of individual studies was performed as described in the preceding section.

We assessed consistency of the data as either “no inconsistency” or “inconsistency present” (or “not applicable” if only one study). We did not use rigid counts of studies as standards of evaluation (e.g., four of five studies agree, therefore the data are consistent); instead, we assessed the direction, magnitude, and statistical significance of all studies, and our meta-analysis results (when performed), to reach conclusions. We describe our logic when studies were not unanimous. We assessed the directness of the evidence (“direct” vs. “indirect”) on the basis of the use of surrogate outcomes (e.g., platelet reactivity vs. clinical events as the outcomes of interest) or the need for indirect comparisons (e.g., when tests had not been directly compared in terms of predictive ability or utility for treatment decisionmaking and inference was based on observations across studies). We assessed the precision of the evidence as “precise” or “imprecise” on the basis of the degree of certainty surrounding each effect estimate. A precise estimate is one that allows for a clinically useful conclusion. An imprecise estimate is one for which the CI is wide enough to include clinically distinct conclusions (e.g., situations in which the direction of effect is unknown and CIs are consistent with both clinically important superiority and inferiority; or situations were a statistically significant result is produced but CIs are consistent with a broad range of effect sizes) and that therefore precludes a conclusion. As a component of precision, the sparseness of the evidence was also assessed. We considered evidence to be sparse if it was from only one study with a small sample size. Because this review assessed many outcomes, the evaluation of overall strength of evidence was based on patient-relevant clinical outcomes, which we broadly defined as any outcomes that affect the patient's well-being.

We focused our assessment of the strength of evidence on studies reporting patient-relevant clinical outcomes (for Key Questions 1b–c, 2b–c, 3, and 4); we did not assess the strength of evidence for intermediate outcomes because they were ascertained using diverse methods (platelet reactivity measured with different assays) and their clinical importance is unclear at present. We also did not assess the strength of evidence of studies of analytic validity (Key Questions 1a and 2a) because technical test performance does not directly inform medical decisions (even though it is a prerequisite for the clinical use of tests).

We rated the strength of evidence for each comparison and outcome of interest according to four levels: high, moderate, low, and insufficient. Ratings reflect the investigators' level of confidence that the evidence reflects the true effect for the major comparisons of interest, and are defined as follows:

- High: There is high confidence that the evidence reflects the true effect. Further research is very unlikely to change our confidence in the estimate of effect. No important scientific disagreement exists across studies.
- Moderate: There is moderate confidence that the evidence reflects the true effect. Further research may change our confidence in the estimate of effect and may change the estimate. Little disagreement exists across studies.
- Low: There is low confidence that the evidence reflects the true effect. Further research is likely to change the confidence in the estimate of effect and is likely to change the estimate. Underlying studies may report conflicting results.
- Insufficient: Evidence is either unavailable or does not permit a conclusion. There are sparse or no data. In general, when only one study has been published the evidence is considered insufficient, unless the study was particularly large, robust, and of good quality. We emphasize that when a body of evidence is deemed “insufficient”, the absence of conclusive evidence should not be interpreted as evidence of absence of an association.

These ratings provide a shorthand description of the strength of evidence supporting the major questions we addressed. However, they by necessity may oversimplify the many complex issues involved in the appraisal of a body of evidence. It is important to remember that the individual studies evaluated in formulating the composite rating differed in their design, reporting, and quality. The strengths and weaknesses of the individual reports, as described in detail in the text and tables, should also be taken into consideration.

### Assessing Applicability

We assessed applicability of the study findings on the basis of the individual study eligibility criteria and baseline characteristics of the included populations, following recommendations in the AHRQ Methods Guide and recently updated recommendations for the EPC program.68,76 We did not assess the applicability of studies on the analytic validity of the tests of interest (Key Questions 1a and 2a) because technical test performance does not directly inform medical decisions (it is, however, a prerequisite for the clinical use of tests).77

For studies of predictive ability (Key Questions 1b–c and 2b–c), we judged applicability on the basis of study eligibility criteria (e.g., narrow vs. broad range of demographics [men only vs. men and women]), the use of tests that are not widely available (tests developed “in-house” [“home-brew” assays]), and the assessment of outcomes that required laboratory measurement of platelet reactivity (rather than patient-relevant outcomes). We took a similar approach for studies considered relevant to test-and-treatment strategies (Key Questions 3 and 4). We address applicability along with other key issues relevant to the body of evidence pertaining to each Key Question and also provide comments on specific issues that, according to our best judgment, affected applicability.