# Introduction

Platelets play a role in the development of atherosclerotic vascular diseases such as acute and chronic coronary artery disease, ischemic cerebrovascular disease (i.e., ischemic stroke or transient ischemic attack), and peripheral arterial disease. Specifically, platelet activation and aggregation, and the interaction of platelets with blood cells and the endothelium, contribute to the pathophysiology of these diseases. Furthermore, platelets participate in thrombus formation in the setting of atrial fibrillation.1 Because of the importance of platelets in disease processes that often culminate in major adverse clinical events (e.g., myocardial infarction, ischemic stroke, or cardiovascular death), there is a strong rationale for the development of therapies specifically targeting platelet function for the primary and secondary prevention of cardiovascular disease. Because patient response to antiplatelet treatments is variable, there is also great interest in developing biomarkers to predict treatment response and guide treatment selection.

## Burden of Disease and Clinical Setting

Approximately 82 million Americans currently suffer from some form of cardiovascular disease.2 Coronary heart disease alone is the cause of 1 of every 6 deaths in the United States; and stroke, 1 of every 18 deaths.3 In spite of widespread prevention efforts, it is estimated that every year more than a million Americans have a myocardial infarction and approximately 795,000 Americans experience a first or recurrent stroke.2 There were approximately seven million inpatient cardiovascular operations and procedures in the United States in 2007, of which one million were either percutaneous coronary intervention (PCI) or coronary artery bypass graft (CABG) surgeries.2

Randomized controlled trials have established dual antiplatelet treatment with clopidogrel and aspirin as the current standard of care for medical and interventional management of acute coronary syndromes.4 Dual antiplatelet treatment is also recommended for patients undergoing PCI5 with placement of stents (either bare metal or drug eluting). Randomized controlled trials support the use of clopidogrel in patients who have experienced acute cerebrovascular events (e.g., stroke) and those with peripheral arterial disease.4,6-9 In patients with atrial fibrillation and contraindications to vitamin K antagonists, the ACTIVE-A trial suggested that the combination of clopidogrel and aspirin is more effective than aspirin alone for preventing thromboembolic disease.10

Since the approval of clopidogrel by the Food and Drug Administration (FDA) for routine clinical use, the drug has become one of the most commonly prescribed agents in the United States. However, patient response to clopidogrel-based antiplatelet therapy is variable (both between patients and across multiple measurements within a patient), with some patients showing no or minimal platelet response to clopidogrel administration (often termed clopidogrel “nonresponsiveness” or “resistance”). Alternatives to standard clopidogrel treatment include higher-dose clopidogrel regimens and the use of other antiplatelet agents, such as prasugrel or ticagrelor.11-14 Given the availability of alternative antiplatelet strategies and concern about adverse clinical outcomes in clopidogrel nonresponders, research has focused on methods to identify patients who are unlikely to benefit from clopidogrel-based treatment. The question of identifying the optimal antiplatelet therapy may also carry cost implications because generic clopidogrel products are now available in the United States.^a^

a FDA release, available at: www.fda.gov/NewsEvents/Newsroom/PressAnnouncements/ucm304489.htm; last accessed October 16, 2012.

## Clopidogrel Metabolism

To be biologically active, clopidogrel must be transformed to the active metabolite R-130964 by members of CYP enzyme system, primarily the enzyme CYP2C19. R-130964 acts by binding irreversibly to the P2Y_12_ receptor (the adenosine diphosphate [ADP] receptor) on the surface of platelets and inhibits platelet aggregation for the life cycle of the platelet.15,16 Platelet aggregation in a patient returns to pretreatment levels approximately 5 days after clopidogrel is stopped, owing to the production of new (noninhibited) platelets by the hematopoietic system.17,18

The CYP2C19 gene is highly polymorphic, with more than 35 identified variants. Following the recommendations of the Human Cytochrome P450 Allele Nomenclature Database,^b^ each of these variants is designated by a number (e.g., “*1,” “*2,” and so on). CYP2C19*1 alleles lead to normal enzymatic activity (i.e., a normal metabolizer phenotype). Some alleles, including the relatively common CYP2C19*2, *3, and *4 alleles, are all known to be “loss-of-function” alleles that lead to complete elimination of enzymatic activity (i.e., a poor metabolizer phenotype). The relatively common CYP2C19*17 alleles are known to be “gain-of-function” alleles that lead to increased enzymatic activity (i.e., an enhanced metabolizer phenotype).19

b Available at: www.cypalleles.ki.se; last accessed April 18, 2012.

However, the relationship between genotype and clinical outcomes is not straightforward. The fact that each individual carries two CYP2C19 alleles results in combinations of alleles of varying enzymatic activity. The combined effect of the two alleles on actual enzymatic activity levels depends on the “true” genetic model of CYP2C19 alleles (dominant, recessive, additive, or co-dominant). For example, if the inheritance model of a loss of function allele is dominant, then a patient with only one loss of function allele would have very low levels of enzymatic activity. If, however, the inheritance model is recessive then a patient could have one loss of function allele but still have normal levels of enzymatic activity. Because different combinations of alleles have different metabolic activity—potentially leading to variability in platelet reactivity and clinical outcomes—analyses of the prognostic effect of CYP2C19 genotype need to consider the underlying genetic model. To complicate matters further, the genetic model for different outcomes is not necessarily the same. Unfortunately, the “true” underlying genetic model for CYP2C19 variants is not known with certainty.20-24 This is of particular concern as the allele frequency of CYP2C19 variants is heterogeneous across populations of different ethnicity, resulting in different genotype prevalences. For example, data from the Third National Health and Nutrition Examination Survey (NHANES III) showed statistically significant heterogeneity in the prevalence of the *2 allele among non-Hispanic whites, Mexican-Americans, and non-Hispanic blacks. The latter group had the highest prevalence of the *2 allele (18.3%) and of homozygotes for that allele (*2/*2; 3.8%).25 Studies have shown that the prevalence of the rare allele is even higher in East-Asian populations (with *2 allele frequencies as high as 30-40%); in these populations an increased number of individuals will be susceptible to the effects of reduced clopidogrel metabolism.26-28

Furthermore, the CYP2C19 genotype is only one of many determinants of the effect of clopidogrel on platelet reactivity. For example, a genome-wide association study recently demonstrated that the *2 allele accounts for only 12 percent of the total observed variation in clopidogrel responsiveness in a selected white population.29 Several studies have demonstrated that environmental factors and patient characteristics, such as body mass index, diabetes, and smoking habits, can influence platelet reactivity.

## Predicting Response and Guiding Antiplatelet Treatment

There are currently two main approaches to determine whether a patient will have a poor response to clopidogrel: (1) genetic testing to see whether the patient has a genotype that is associated with reduced ability to metabolize clopidogrel (a poor-metabolizer phenotype), and (2) direct testing of the patient's blood while the patient is taking clopidogrel to see whether the platelets actually have become less prone to aggregate in response to specific agonists (phenotypic testing for platelet reactivity).

### Genetic Tests for CYP2C19 Variants

Genetic testing for one or more genetic variants can be performed with various genotyping methods, such as restriction-fragment-length polymorphism analysis, other polymerase chain reaction (PCR)–based methods, or single nucleotide polymorphism (SNP) microarray methods. Testing for CYP2C19 variants requires a sample of somatic genetic material, usually obtained from a blood sample or from buccal swabs. Because allelic variants at the CYP2C19 locus do not change over a person's lifetime, testing done at any time point is representative of the person's genotype. Several studies have evaluated associations between loss-of-function CYP2C19 alleles and major adverse cardiovascular events as well as intermediate endpoints (e.g., platelet reactivity). Research has also focused on whether CYP2C19 genotypes can be used to predict the phenotype of on-clopidogrel platelet reactivity and whether the association of genotype and phenotype can be modified by alternative treatment strategies (e.g., higher clopidogrel dosing or use other antiplatelet agents).

### Measurement of Platelet Reactivity

Phenotypic testing measures the reactivity of platelets while a patient is taking clopidogrel (on-clopidogrel platelet reactivity). Several assays for measuring platelet reactivity are available. These include rapid (point-of-care) platelet function assays (e.g., VerifyNow, Platelet Function Analyzer [PFA]-100, Plateletworks), measurements of mediators of reactivity (e.g., vasodilator-stimulated phosphoprotein [VASP] phosphorylation using flow cytometry), and functional assays (e.g., turbidimetric, impedance, and conductance aggregometry using appropriate agonists). The technical characteristics and principles of measurement of these tests have been described in recent reviews.30-37 We refer to all these assays as “phenotypic tests,” because they attempt to measure an intermediate clinical phenotype (platelet reactivity).38 A potential advantage of phenotypic tests is that some assays can be easily used during routine care (point-of-care testing). In addition, because platelet reactivity reflects the combined impact of an individual's entire genetic makeup (not limited to CYP2C19) along with environmental exposures on clopidogrel pharmacodynamics, phenotypic testing may better predict clinical outcomes among clopidogrel treated patients. However a number of different assays using diverse measurement techniques are available and the prognostic value and potential clinical utility of platelet reactivity testing are still unclear.

## Modifiers of the Prognostic Ability and Clinical Utility of Tests

Proton-pump inhibitors (PPIs) are often prescribed along with antiplatelet therapy to limit the potential for gastrointestinal bleeding complications. Because CYP2C19 is the key enzyme in the metabolism of several PPIs, it has been hypothesized that coadministration of these drugs could inhibit the activation of clopidogrel.39 A recent systematic review that examined studies investigating the association between PPI use and adverse cardiovascular events among patients receiving clopidogrel concluded that PPI use was associated with an approximately 40 percent increase in the risk of major adverse cardiovascular outcomes and an 18 percent increase in mortality.40 However, no systematic review has assessed the interaction of PPIs with the clopidogrel treatment effect within categories defined by CYP2C19 status or platelet reactivity.

Other potential modifiers of the utility of genetic and phenotypic test results include the specific indication for clopidogrel use (because the prognostic ability of testing may vary among patient populations), race or ethnicity (because of the varying prevalence of CYP2C19 alleles among different groups), comorbid conditions (that may affect the baseline event rate or serve as markers for the coadministration of drugs metabolized by CYP2C19), baseline disease severity, sex, and age.

## Current Uncertainties Regarding Genetic and Phenotypic Testing

There are several areas of uncertainty regarding the use of both genetic tests for CYP2C19 variants and phenotypic tests to assess on-clopidogrel platelet reactivity. First, there is controversy regarding the prognostic ability of these tests for clinical outcomes in patients who are receiving clopidogrel: several studies have reported significant associations between CYP2C19 status or high on-clopidogrel platelet reactivity and clinical outcomes; however concerns have been raised regarding the potential for selective outcome reporting and publication bias to have affected study results.20,41,42,42 The relative prognostic value of genetic and phenotypic testing is also unclear.

Second, there are conflicting views on whether the results of these tests can be used to guide therapeutic decisionmaking for antiplatelet therapy. Although clinicians and patients may find it helpful to know the probability of future outcomes under clopidogrel therapy, medical tests are most valuable when they can be used to guide treatment decisions. Thus, beyond prognostic ability, there is interest in evaluating whether genetic or phenotypic testing can improve patient outcomes by identifying patients who would benefit more (or experience less harm) by using treatment strategies other than standard clopidogrel-based treatment (e.g., using alternative clopidogrel dosing schemes or other antiplatelet agents). The observation that specific CYP2C19 variants or levels of on-treatment platelet reactivity above a threshold predict worse outcomes does not necessarily mean that changing treatment on the basis of these tests will improve outcomes. It is possible that the genotype or phenotype is simply a marker for poor outcome regardless of the treatment strategy used.41 Therefore the evidence of the test's impact on treatment decisions and subsequent patient outcomes must be considered separately from outcome prediction. Some investigators advocate clinical use,43,44 while others suggest that the tests are not ready for clinical application because the evidence on their clinical utility is limited.41,42,45 The best evidence on the use of testing for guiding treatment decisionmaking can be obtained from comparative studies of alternative testing strategies (including no-testing). As discussed above, prognostic value is not enough to establish the utility of testing for guiding treatment choice; it is also important to demonstrate that the prognostic effect is modified by the treatment received. Third, the modifiers of these tests' effects, both in terms of prognostic ability and therapeutic decisionmaking, also have not been fully evaluated.

## Scope of the Review

The purpose of this review was to systematically evaluate the analytic validity, prognostic utility, and comparative effectiveness of two types of biomarker tests (and relevant test-and-treat strategies) for guiding antiplatelet therapy in patient populations who are eligible for clopidogrel treatment. The impact of biomarkers such as genotype or phenotype on patient-relevant outcomes is indirect; any effects of testing are mediated through the impact of test results on clinical thinking and therapeutic decisionmaking. In the case of antiplatelet therapy, the effects of treatment on clinical outcomes are believed to be mediated through platelet reactivity (a surrogate outcome). We aimed to assess the impact of testing on both intermediate and patient-relevant clinical outcomes.

## Key Questions

On the basis of the original topic nomination and an extensive process of topic development and refinement, we formulated the following Key Questions to guide the review. These questions broadly follow the “ACCE framework,” covering [underlined: A]nalytic validity, [underlined: C]linical validity, [underlined: C]linical utility, and test-related harms, as proposed by the Evaluation of Genomic Applications in Practice and Prevention Working Group of the Centers for Disease Control and Prevention.

Key Question 1. In patient populations who are candidates for clopidogrel therapy, does genetic testing for CYP2C19 variants predict intermediate and clinical outcomes following treatment initiation?

a. What is the analytic validity (technical test performance) of the various assays used for CYP2C19 genetic testing?
b. What is the clinical validity (predictive accuracy) of genetic testing for predicting intermediate and clinical outcomes in patients who are receiving clopidogrel therapy?
c. Do the following factors modify the association between genetic test results and clinical outcomes?
  i. Co-medications
  ii. Patient-level factors (e.g., race or ethnicity, age, sex, disease severity, or comorbidities)
  iii. Test-related factors (e.g., between-assay differences)
  iv. System-level factors (e.g., settings where testing is performed)

Key Question 2. In patient populations receiving clopidogrel therapy, does phenotypic testing of platelet reactivity predict intermediate and clinical outcomes?

a. What is the analytic validity (technical test performance) of the various assays used in phenotypic testing of platelet reactivity?
b. What is the clinical validity (predictive accuracy) of phenotypic testing for predicting intermediate and clinical outcomes in patients who are receiving clopidogrel therapy?

Do the following factors modify the association between phenotypic test results and clinical outcomes?

i. Comedications
ii. Patient-level factors (e.g., race or ethnicity, age, sex, disease severity, or comorbidities)
iii. Test-related factors (e.g., between-assay differences)
iv. System-level factors (e.g., settings where testing is performed)

Key Question 3. What is the comparative effectiveness of alternative test-and-treat strategies (including a no-testing strategy) for therapeutic decisionmaking regarding antiplatelet therapy among patients who are candidates for clopidogrel-based treatment?

a. What is the comparative effectiveness of the following testing strategies on therapeutic decisionmaking, platelet reactivity during followup, and clinical outcomes in patients who are candidates for antiplatelet treatment?
  i. Genetic testing for CYP2C19
  ii. Genetic testing for CYP2C19 followed by phenotypic testing for platelet reactivity
  iii. Phenotypic testing for platelet reactivity
  iv. No testing
b. How do modifying factors (e.g., race or ethnicity, age, sex, comorbidities, diet, or the time between conducting the test and obtaining results) affect the association of alternative phenotypic or genetic test-and-treat strategies and patient outcomes? Alternative test-guided treatments can include nonclopidogrel antiplatelet agents or high-dose clopidogrel regimens.

Key Question 4. What are the potential adverse effects or harms from genetic or phenotypic testing per se or from test-directed treatments?