# Technical Expert Panel

In designing the study questions and methodology at the outset of this report, the EPC consulted several technical and content experts. Broad expertise and perspectives were sought. Divergent and conflicted opinions are common and perceived as healthy scientific discourse that results in a thoughtful, relevant systematic review. Therefore, in the end, study questions, design, methodologic approaches, and/or conclusions do not necessarily represent the views of individual technical and content experts.

Technical Experts must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential conflicts of interest identified.

The list of Technical Experts who participated in developing this report follows:

- W. David Dotson, Ph.D.
  Health Scientist, Office of Public Health Genomics
  Centers for Disease Control and Prevention
  Atlanta, GA
- Paul A. Gurbel, M.D., FACC
  Director, Center for Thrombosis Research, Sinai Hospital of Baltimore
  Director, Cardiovascular Research, Life Bridge Health
  Associate Chief for Research, Department of Medicine, Sinai Hospital of Baltimore
  Professor of Medicine, Johns Hopkins University School of Medicine
  Baltimore, MD
- Jessica L. Mega, M.D., M.P.H.
  Assistant Professor of Medicine
  Harvard Medical School
  Brigham and Women's Hospital
  Boston, MA
- Guillaume Paré, M.D., M.Sc., FRCPC
  Assistant Professor, Department of Pathology & Molecular Medicine
  Joint Member, Department of Clinical Epidemiology & Biostatistics
  Director, Genetic and Molecular Epidemiology Laboratory
  McMaster University
  Ontario, Canada
- Alan Shuldiner, M.D.
  Director, Program in Personalized and Genomic Medicine
  Head, Division of Endocrinology, Diabetes and Nutrition
  University of Maryland, School of Medicine
  Baltimore, MD
- David Veenstra, Pharm.D., Ph.D.
  Professor, Pharmaceutical Outcomes Research and Policy Program
  Auxiliary Member, Institute for Public Health Genetics
  University of Washington
  Seattle, WA