# Discussion

Antiplatelet therapy is used for a number of ischemic cardiovascular conditions. Clopidogrel is among the most commonly prescribed antiplatelet drugs. It is used extensively in the interventional management of coronary artery disease and the treatment and secondary prevention of acute coronary syndromes.291 Furthermore, it is used for the management of patients undergoing neurointervention (with stent placement), for the prevention of stroke in patients with atrial fibrillation who are not candidates for vitamin K antagonist therapy, and for the management of selected patients with peripheral arterial disease. Response to clopidogrel therapy—as assessed by ex vivo studies of platelet function—is variable among patients and over time (within a patient). Some patients experience little suppression of platelet reactivity (despite being compliant to treatment) while others experience more profound suppression that may increase their risk of bleeding. Given the availability of several therapeutic options for antiplatelet treatment (e.g., increasing the loading or daily maintenance dose of clopidogrel or using adjunctive or replacement therapies such as prasugrel, ticagrelor, or cilostazol), there is interest in reliably identifying patients who are less likely to respond to standard clopidogrel treatment, as well as those who are most likely to respond to alternative treatments. This report reviewed the evidence of the effectiveness and comparative effectiveness of two types of tests that have been extensively evaluated as biomarkers for outcome prognosis for patients receiving clopidogrel therapy and as biomarkers of treatment response: genetic testing for CYP2C19 variants and phenotypic testing for on-clopidogrel platelet reactivity.

## Key Findings and Assessment of the Strength of Evidence

Table 44 presents a summary of the report's key findings for each Key Question. When appropriate, results are presented separately for each of the populations and outcomes of interest. We did not assess the strength of evidence for evidence on analytic validity (because analytic validity is a prerequisite for the clinical use of the tests and because no framework exists for assessing the strength of evidence for analytic validity studies) or for studies exclusively assessing platelet reactivity as an outcome (because platelet reactivity measurements during followup are not usually performed as part of clinical care and because platelet reactivity is not a patient-relevant outcome). Instead, we focus here on the body of evidence pertaining to predictive effects, treatment decisionmaking, and harms as related to patient-relevant clinical outcomes. Please see the Methods section for a detailed discussion of our approach to rating the strength of evidence.

Table 44 Key findings from this review and assessment of strength of evidence

Key Question | Population | Test/Assay | Outcome | SOE Summary and Comments
1a : What it the analytic validity of tests for genotyping CYP2C19 variants? | NA | Genotyping for any CYP2C19 variant | NA | SOE = NA; - Few studies provided information on analytic validity specifically using samples obtained from patient populations relevant to this review.; - When available, data were limited to test–retest reliability or inter-assay agreement.; - There was limited information comparing the validity of different genetic testing assays.; - However, it is generally accepted that the analytic validity of genotyping assays is robust.
1b : What is the predictive value of genetic testing for CYP2C19 variants? | Ischemic heart disease | Genotyping for LOF CYP2C19 variants | Stent thrombosis | SOE = Moderate; - Meta-analysis of 17 studies found a statistically significant association under a dominant model.; - RR=1.52 (95% CI 1.17 to 1.97); - There was little evidence of heterogeneity (I^2^=0%); but the test for small-study effects was statistically significant.; - Results under additive and recessive models were consistent with a positive association and produced larger effect sizes; however, these analyses were based on a small subset of the available studies.; - There was some concern about selective outcome reporting.; - Studies reported few outcome events and the summary estimate was imprecise.
1b : What is the predictive value of genetic testing for CYP2C19 variants? | Ischemic heart disease | Genotyping for LOF CYP2C19 variants | MACE | SOE = Moderate; - Meta-analysis of 25 studies found a statistically significant association under a dominant model.; - RR=1.20 (95% CI 1.04 to 1.39); - There was some evidence of heterogeneity (I^2^=31%).; - Results under additive and recessive models were consistent with a positive association and produced larger effect sizes; however, these analyses were based on a small subset of the available studies.; - The test for small study effects was statistically significant.
1b : What is the predictive value of genetic testing for CYP2C19 variants? | Ischemic heart disease | Genotyping for LOF CYP2C19 variants | Cardiovascular mortality | SOE = Low; - Meta-analysis of 7 studies found a statistically significant association under a dominant model.; - RR=1.98 (95% CI 1.13 to 3.46); - There was no evidence of heterogeneity (I^2^=0%). The summary estimate was imprecise.; - The test for small study effects was not statistically significant. There was some concern about selective outcome reporting.
1b : What is the predictive value of genetic testing for CYP2C19 variants? | Ischemic heart disease | Genotyping for LOF CYP2C19 variants | All other clinical outcomes | SOE = Insufficient; - Few studies reported information for noncomposite clinical outcomes other than stent thrombosis.; - There was substantial concern about selective outcome reporting.; - Study-specific and meta-analysis estimates (when performed) indicated substantial uncertainty.
1b : What is the predictive value of genetic testing for CYP2C19 variants? | Ischemic heart disease | Genotyping for GOF CYP2C19 variants | MACE | SOE = Low; - Meta-analysis of 7 studies found a statistically significant protective effect (for carriers vs. noncarriers).; - RR=0.82 (95% CI 0.74 to 0.92); - There was substantial concern about selective outcome reporting.
1b : What is the predictive value of genetic testing for CYP2C19 variants? | Ischemic heart disease | Genotyping for GOF CYP2C19 variants | All other clinical outcomes | SOE = Insufficient; - Few studies provided relevant information.; - There was substantial concern about selective outcome reporting.; - Study-specific and meta-analysis estimates (when performed) indicated substantial uncertainty.
1b : What is the predictive value of genetic testing for CYP2C19 variants? | Other patient groups who are candidates for clopidogrel therapy | Genotyping for any CYP2C19 variants | All clinical outcomes | SOE = Insufficient; - Only few (often a single) study was available for patient population other than those with ischemic heart disease;; - Some of the studies did not report information on clinical outcomes.
1c : What factors affect the predictive value of genetic testing for CYP2C19 variants? | All patient populations | Genotyping for any CYP2C19 variants | All clinical outcomes | SOE = Insufficient; - 20 studies provided information on effect modification; a single study reported a statistically significant interaction effect on the prognostic performance of CYP2C19 variants for a clinical outcome.; - No factor was assessed by more than 5 studies, giving rise to concerns about selective outcome reporting.; - In meta-regression analyses (using study-level factors as covariates) we found some evidence of effect modification by ethnicity (East Asians vs. White populations) for MACE and stent thrombosis. However, this result is based on comparisons across studies (which may be confounded by other study characteristics) and was not corroborated by within-study analyses. Confidence intervals for all interaction effects were wide for all genotype–outcome pairs assessed and only few studies in East Asian populations were available.; - Estimates of effect-modification by study-level variables are susceptible to confounding by other study-level characteristics
2a : What is the analytic validity of tests for on-clopidogrel platelet reactivity? | NA | All assays used to measure on-clopidogrel platelet reactivity | NA | SOE = NA; - Few studies reported information on analytic sensitivity and specificity, possibly reflecting the research community's belief that there is no good reference standard assay for platelet reactivity.; - Agreement ranged from poor to moderate and was variable between tests.; - The highest agreement was observed between applications of the same assay with different concentrations of agonists, rather than between different assays.
2b : What is the predictive ability of phenotypic testing for platelet reactivity? | Ischemic heart disease | LTA | All-cause mortality | SOE = Low; - 13 studies using heterogeneous methods to define increased reactivity were available.; - These studies support an association between increased platelet reactivity measured by LTA and mortality.; - There was some concern about selective outcome reporting.
2b : What is the predictive ability of phenotypic testing for platelet reactivity? | Ischemic heart disease | LTA | Cardiovascular mortality | SOE = Low; - 9 studies using heterogeneous methods to define increased reactivity were available.; - Studies provided evidence of an association between increased reactivity and cardiovascular mortality; however, clinical heterogeneity precluded firm conclusions.; - There was some concern about selective outcome reporting.
2b : What is the predictive ability of phenotypic testing for platelet reactivity? | Ischemic heart disease | LTA | Acute coronary syndromes | SOE = Low; - 18 studies using heterogeneous methods to define increased reactivity were available.; - Studies often found statistically significant associations between increased reactivity as measured by LTA and clinical events; however, clinical heterogeneity did not allow for stronger conclusions.; - There was some concern about selective outcome reporting.
2b : What is the predictive ability of phenotypic testing for platelet reactivity? | Ischemic heart disease | LTA | Stent thrombosis | SOE = Low; - 19 studies using heterogeneous methods to define increased reactivity were available.; - Studies often found statistically significant associations between increased reactivity as measured by LTA and clinical events; however, clinical heterogeneity did not allow for stronger conclusions.; - There was some concern about selective outcome reporting.
2b : What is the predictive ability of phenotypic testing for platelet reactivity? | Ischemic heart disease | LTA | Stroke | SOE = Low (for lack of association); - 12 studies using heterogeneous methods to define increased reactivity were available.; - Studies generally did not report statistically significant associations between increased reactivity as measured by LTA and clinical events; however, clinical heterogeneity did not allow for stronger conclusions or quantitative synthesis to increase precision.
2b : What is the predictive ability of phenotypic testing for platelet reactivity? | Ischemic heart disease | LTA | MACE | SOE = Low; - 37 studies using heterogeneous methods to define increased reactivity were available.; - The majority of reviewed studies suggested a statistically significant association between increased platelet reactivity measured by LTA and composite cardiovascular events.; - Definitions of composite outcomes where often heterogeneous.
2b : What is the predictive ability of phenotypic testing for platelet reactivity? | Ischemic heart disease | LTA | All other clinical outcomes | SOE = Insufficient; - Clinical and population heterogeneity or small number of studies limited our ability to draw conclusions.
2b : What is the predictive ability of phenotypic testing for platelet reactivity? | Ischemic heart disease | VerifyNow | All-cause mortality | SOE = Low (for lack of association); - 10 studies were available. Meta-analysis of 4 studies did not find an association between increased reactivity measured by VerifyNow and all-cause mortality.; - RR=1.21 (95% CI 0.83 to 1.76); - The summary estimate was imprecise and 95% CI did not rule out clinically meaningful effects.
2b : What is the predictive ability of phenotypic testing for platelet reactivity? | Ischemic heart disease | VerifyNow | Cardiovascular mortality | SOE = Moderate; - 7 studies were available. Meta-analysis of 4 studies found a statistically significant association with little evidence of heterogeneity.; - RR=2.50 (95% CI 1.28 to 4.87); - The CI of the summary estimate indicated substantial uncertainty.; - There was some concern about selective outcome reporting.
2b : What is the predictive ability of phenotypic testing for platelet reactivity? | Ischemic heart disease | VerifyNow | Acute coronary syndromes | SOE = Low; - 19 studies using heterogeneous methods to define increased reactivity were available.; - Studies generally suggested an association between increased reactivity as measured by VerifyNow and acute coronary syndromes, both periprocedurally and during longer followup.
2b : What is the predictive ability of phenotypic testing for platelet reactivity? | Ischemic heart disease | VerifyNow | Stent thrombosis | SOE = Low (for lack of association); - 15 studies were available. Meta-analysis of 6 studies did not find an association between reactivity measured by VerifyNow and stent thrombosis.; - RR=1.67 (95% CI 0.80 to 3.47); - There was some evidence of heterogeneity (I^2^=37%) and the CI of the summary estimate indicated substantial uncertainty.; - Studies not included in the meta-analysis generally produced non-significant results.; - There was some concern about selective outcome reporting.; - The test for small-study effects was statistically significant.
2b : What is the predictive ability of phenotypic testing for platelet reactivity? | Ischemic heart disease | VerifyNow | MACE | SOE = Moderate; - 24 studies were available. Meta-analysis of 13 studies identified a statistically significant association.; - RR=2.48 (95% CI 1.85 to 3.32); - There was moderate statistical heterogeneity (I^2^=44 percent) and studies used fairly similar definitions of increased reactivity.; - The test for small-study effects was statistically significant.
2b : What is the predictive ability of phenotypic testing for platelet reactivity? | Ischemic heart disease | VerifyNow | Bleeding events (major and all levels of severity combined) | SOE = Low (for lack of association); - 13 studies were available.; - Meta-analysis of 4 studies with data on any bleeding event did not find an association between increased reactivity measured by VerifyNow.; - RR=1.09 (95% CI 0.88 to 1.36). There was little evidence of heterogeneity (I^2^=0 percent).; - Meta-analysis of 4 studies with data on major bleeding events did not find an association between increased reactivity measured by VerifyNow.; - RR=0.85 (95% CI 0.32, 2.25). There was evidence of moderate heterogeneity (I^2^=57 percent).; - For major bleeding events the summary estimate was imprecise and the 95% CI did not rule out clinically meaningful effects.
2b : What is the predictive ability of phenotypic testing for platelet reactivity? | Ischemic heart disease | VerifyNow | All other clinical outcomes | SOE = Insufficient; - Clinical heterogeneity or small number of studies limited our ability to draw conclusions
2b : What is the predictive ability of phenotypic testing for platelet reactivity? | Ischemic heart disease | VASP assay | Cardiovascular mortality | SOE = Insufficient; - 6 studies were available. Meta-analysis of 4 studies did not identify a statistically significant association.; - RR=2.42 (95% CI 0.86 to 6.82); - Although the test for heterogeneity was nonsignificant, point estimates from individual studies ranged from protective effects to strong harmful effects.; - The meta-analytic summary point estimate was far from the null and its CI was wide (imprecise).; - Clinically significant effects could not be ruled out.
2b : What is the predictive ability of phenotypic testing for platelet reactivity? | Ischemic heart disease | VASP assay | Acute coronary syndromes | SOE = Low (for lack of association); - 6 studies were available. Meta-analysis of 3 studies did not identify a statistically significant association.; - RR=1.47 (95% CI 0.77 to 2.79); - The test for heterogeneity was non-significant but point estimates from individual studies were highly variable.; - The meta-analytic summary point estimate was far from the null and its CI was wide (imprecise).; - Clinically significant effects could not be ruled out.
2b : What is the predictive ability of phenotypic testing for platelet reactivity? | Ischemic heart disease | VASP assay | Stent thrombosis | SOE = Low; - 10 studies were available. Meta-analysis of 4 studies identified a statistically significant association.; - RR=3.37 (95% CI 1.59 to 7.11); - There was little evidence of statistical heterogeneity and the 4 studies used fairly similar definitions of increased reactivity.; - The summary estimate was imprecise but the lower bound was consistent with a 59% increase in risk in the high-reactivity group.; - There was some concern about selective outcome reporting.
2b : What is the predictive ability of phenotypic testing for platelet reactivity? | Ischemic heart disease | VASP assay | MACE | SOE = Low; - 8 studies were available. Meta-analysis of 6 studies identified a statistically significant association.; - RR=2.57 (95% CI 1.21 to 5.47); - There was evidence of statistical heterogeneity.; - The summary estimate was imprecise but the lower bound was consistent with a 21% increase in risk in the high-reactivity group.; - There was some concern about selective outcome reporting.
2b : What is the predictive ability of phenotypic testing for platelet reactivity? | Ischemic heart disease | VASP assay | All other clinical outcomes | SOE = Insufficient; - Few studies reported information.; - Clinical heterogeneity or small number of studies limited our ability to draw conclusions.
2b : What is the predictive ability of phenotypic testing for platelet reactivity? | Ischemic heart disease | PFA-100 | MACE | SOE = Low; - 7 of the 9 studies on this assay reporting information on composite clinical outcomes produced statistically significant results indicating an association between increased reactivity and adverse outcomes.; - Heterogeneity in the methods used to define increased reactivity precluded definitive conclusions; however, studies generally indicated an association between increase platelet reactivity as measured by the PFA-100 assay and composite clinical outcomes.
2b : What is the predictive ability of phenotypic testing for platelet reactivity? | Ischemic heart disease | PFA-100 | All other clinical outcomes | SOE = Insufficient; - Few of the available studies reported information on other outcomes.; - There was concern about selective outcome reporting.
2b : What is the predictive ability of phenotypic testing for platelet reactivity? | Ischemic heart disease | All other assays | All clinical outcomes | SOE = Insufficient; - Few studies were available.; - When ≥2 studies were available for the same outcome they used heterogeneous metrics or thresholds to define increased reactivity or used different agonists for ex vivo stimulation of platelets.
2b : What is the predictive ability of phenotypic testing for platelet reactivity? | Other patient groups who are candidates for clopidogrel therapy | All assays used to measure on-clopidogrel platelet reactivity | All clinical outcomes | SOE = Insufficient; - Only 6 studies, using diverse assays to measure reactivity, were available in clinically heterogeneous populations.; - Studies were fairly small.
2c : What factors affect the predictive value of phenotypic testing for platelet reactivity? | All patient populations | All assays used to measure on-clopidogrel platelet reactivity | All clinical outcomes | SOE = Insufficient; - 7 studies provided information on effect modification; no factor was assessed by more than 3 studies.; - Effect modification by study-level factors could not be assessed for most assay–outcome pairs; when such analysis was possible (for VerifyNow MACE), results indicated substantial uncertainty.
3a : What is the comparative effectiveness of alternative test-and-treat strategies | Ischemic heart disease | Genetic testing for CYP2C19 variants or phenotypic testing for platelet reactivity (all assays assessed) | All clinical outcomes | SOE = Insufficient; - 1 RCT of testing vs. no testing was identified; the study had short duration and a small sample size; no events were observed in the two groups during the study period.; - 3 studies provided information on treatment effect modification for clinical outcomes (and reported at least one outcome event); - 1 study randomized patients selected on the basis of genotype status into different clopidogrel doses; no conclusions could be drawn regarding clinical outcomes because of the short duration and small sample size of the study.; - Studies compared different antiplatelet treatments and produced heterogeneous results.; - Study-specific estimates were imprecise.
3a : What is the comparative effectiveness of alternative test-and-treat strategies | Ischemic heart disease | Phenotypic testing for platelet reactivity | All clinical outcomes | SOE = Insufficient; - The 6 RCTs of testing strategies were small, had different designs, and produced extreme results with considerable statistical uncertainty.; - 1 NRCS was judged to be at high-risk of bias on the basis of study design (patients in; - each of the two compared arms were enrolled at different centers).; - 3 studies of effect modification were identified; studies evaluated heterogeneous; - interventions and used different methods to assess reactivity.; - Studies of test-based patient selection assessed different treatments, enrolled; - heterogeneous patient populations, and did not provide robust evidence on clinical; - outcomes.
3a : What is the comparative effectiveness of alternative test-and-treat strategies | Atrial fibrillation | Genetic testing for CYP2C19 variants or phenotypic testing for platelet reactivity (all assays assessed) | All clinical outcomes | SOE = Insufficient; - Only one study providing information on effect modification by CYP2C19 status was identified.; - The study did not find evidence of effect modification by genotype status but there was considerable statistical uncertainty in the study estimates.
3a : What is the comparative effectiveness of alternative test-and-treat strategies | Atrial fibrillation | Phenotypic testing for platelet reactivity | All clinical outcomes | SOE = Insufficient; - No studies were identified.
3a : What is the comparative effectiveness of alternative test-and-treat strategies | Other patient populations | Genetic testing for CYP2C19 variants or phenotypic testing for platelet reactivity (all assays assessed) | All clinical outcomes | SOE = Insufficient; - 1 study provided information on treatment effect modification in a mixed population of; - patients with atherothrombotic disease (cardiovascular, cerebrovascular, or peripheral arterial) along with asymptomatic individuals at risk for atherothrombotic disease; - The study did not provide robust evidence of effect modification.
3a : What is the comparative effectiveness of alternative test-and-treat strategies | Other patient populations | Phenotypic testing for platelet reactivity | All clinical outcomes | SOE = Insufficient; - No studies were identified.
3b : What factors modify the comparative effectiveness of alternative test-and-treat strategies? | All patient populations | Genetic testing for CYP2C19 variants or phenotypic testing for platelet reactivity (all assays assessed) | All clinical outcomes | SOE = Insufficient; - 4 studies provided information on effect modification; each assessed different effect modifiers; no statistically significant interactions were reported.
4 : What are the harms of testing? What are the harms of test-directed treatment? | All patient populations | Genetic testing for CYP2C19 variants | All clinical outcomes | SOE = Insufficient; - 1 RCT of testing vs. no testing was identified; the study had short duration and a small sample size; few events were observed in the two groups during the study period.; - 5 studies assessed treatment effect modification by genotype status (and reported at least one outcome event).; - One study randomized patients selected on the basis of genotype status; it did not provide robust evidence regarding harms due to the relatively small sample size and short followup.; - Studies compared different antiplatelet treatments and had heterogeneous results.; - No studies provided direct information on the harms of testing per se.
4 : What are the harms of testing? What are the harms of test-directed treatment? | All patient populations | Phenotypic testing for platelet reactivity (all assays assessed) | All clinical outcomes | SOE = Insufficient; - The 6 randomized studies of testing strategies were small, had different designs, and produced extreme results with considerable statistical uncertainty (and in some cases; - simply did not report any outcome events).; - 1 NRCS was judged to be at high-risk of bias on the basis of study design (patients in; - each of the two compared arms were enrolled at different centers).; - 2 studies of effect modification were identified; in one study safety outcomes either did not occur (regardless of reactivity status) or results were not stratified by reactivity group; the second study did not identify a significant effect but had short term followup and reported very few outcome events to allow any robust conclusions to be drawn.; - Studies of test-based patient selection assessed different treatments.

CI = confidence interval; GOF = gain-of-function; LOF = loss-of-function; MACE = major adverse cardiovascular events; NA = not applicable; RR = relative risk; SOE = strength of evidence.

### Analytic Validity

Overall, we found limited evidence on the analytic validity of CYP2C19 genotyping assays in the populations of interest. However, the available studies reported almost perfect test–retest reliability and there is general consensus that genotyping methods have adequate analytic performance for clinical application (given the nature of genetic testing, we believe that supportive evidence can be drawn from the application of genetic tests to other patient populations and from the application of genotyping methods to other genes).

In contrast, numerous studies on the analytic validity of assays for measuring platelet reactivity in the populations of interest were available. Platelet reactivity can be affected by environmental exposures (e.g., drugs received by the patient) and patient characteristics (e.g., patients with diabetes have higher reactivity than nondiabetic individuals) and is variable within a person over time. Many of the studies we reviewed performed inappropriate analyses for comparing measurements obtained by reactivity assays, and often did not report information adequate to allow for a complete evaluation of their experimental design and analyses. In the subset of studies using appropriate designs and analyses to assess agreement or analytic performance, tests considered as “analytic gold standards” in some publications were considered as index tests (with measurement error that cannot be ignored) in other publications, indicating the lack of consensus on the optimal method for reactivity measurement. In the studies we reviewed, assays had low to moderate levels of interassay agreement. Agreement was generally higher between applications of the same assay across different concentrations of agonists (e.g., LTA with 5 μM ADP concentration vs. 20 μM) than between different assays. The Working Group on High On-Treatment Platelet Reactivity identified the lack of a universally accepted reference assay as a key reason for the limited implementation of platelet reactivity testing in clinical settings.38

### Predictive Value of Genetic and Phenotypic Testing for Patients on Clopidogrel-Based Antiplatelet Therapy

Studies assessing the predictive value of CYP2C19 variants and platelet reactivity for patients receiving clopidogrel-based antiplatelet therapy represented the majority of the studies included in this report. It is interesting to compare our findings with previous systematic reviews and meta-analyses assessing CYP2C19 polymorphisms (Table 45) and those assessing assays for measuring platelet reactivity (Table 46).

Table 45 Results of systematic reviews assessing the effect of CYP2C19 variants on clinical outcomes among patients receiving clopidogrel treatment

Author Year PMID | No. of Studies | Selection Criteria | Outcome [no. of studies/events]: Effect Size
Holmes41 2011 22203539 | 32 | Articles reporting original data without language restriction | Carriers of at least one CYP2C19 LOF allele vs. noncarriers MACE [24 studies]: RR=1.18 (95% CI, 1.09 to 1.28) MI-fatal and nonfatal [9 studies]: RR=1.37 (95% CI, 1.13 to 1.65) MI-nonfatal [3 studies]: RR=1.48 (95% CI, 1.05 to 2.07) Stent thrombosis [14 studies]: RR=1.75 (95% CI, 1.50 to 2.03) Stroke-fatal and nonfatal [4 studies]: RR=1.98 (95% CI, 0.77 to 5.09) Bleeding-all [3 studies]: RR=0.84 (95% CI, 0.75, 0.94) Bleeding-severe [4 studies]: RR=1.07 (95% CI, 0.92 to 1.25)
Liu292 2011 21794898 | 20 | Articles, conference abstracts and presentation slides; no language restriction | Carriers of at least one CYP2C19 LOF allele vs. noncarriers Stent thrombosis [18 studies]: OR=2.58 (95% CI, 1.77 to 3.77) MACE [18 studies]: OR=1.26 (95% CI, 1.06 to 1.50) Carriers of at least one CYP2C19 GOF allele versus noncarriers MACE [6 studies]: OR=0.82 (95% CI, 0.69 to 0.98)
Bauer20 2011 21816733 | 15 | Observational studies and clinical trials; no language restriction | Carriers of at least one CYP2C19 LOF allele vs. noncarriers MACE [12 studies]: OR=1.11 (95% CI, 0.89 to 1.39) Stent thrombosis [9 studies]: OR=1.77 (95% CI, 1.31 to 2.40) Carriers of at least one CYP2C19 GOF allele vs. noncarriers MACE [5 studies]: OR=0.93 (95% CI, 0.75 to 1.14) Stent thrombosis [3 studies]: OR=0.99 (95% CI, 0.60 to 1.62)
Zabalza293 2012 21693476 | 13 | Case–control or prospective cohort; English language | Carriers of at least one CYP2C19 LOF allele vs. noncarriers MACE [11 studies]: HR=1.23 (95% CI, 0.97 to 1.55) ST [7 studies]: HR=2.24 (95% CI, 1.52 to 3.30) Carriers of at least one CYP2C19 GOF allele vs. noncarriers MACE [4 studies]: HR=0.75 (95% CI, 0.66 to 0.87) Major bleeding [4 studies]: HR=1.26 (95% CI, 1.05 to 1.50)
Hulot40 2010 20620727 | 10 | Original epidemiological studies; no language restriction | MACE [10 studies, 1003 events]: OR=1.29 (95% CI, 1.12 to 1.49) Stent thrombosis [4 studies]: OR=3.45 (95% CI, 2.14 to 5.57) Mortality [5 studies]: OR=1.79 (95% CI, 1.10 to 2.91)
Mega294 2010 20978260 | 9 | Prospective cohort studies or clopidogrel-treated arms from RCTs; summary data for meta-analysis were provided by the primary investigators | Carriers of at least one CYP2C19 LOF allele vs. noncarriers MACE [9 studies]: HR=1.57 (95% CI, 1.13 to 2.16) Stent thrombosis [6 studies]: HR=2.81 (95% CI, 1.81 to 4.37) Cardiovascular death [9 studies]: HR=1.84 (95% CI, 1.03 to 3.28) Nonfatal MI [9 studies]: HR=1.45 (95% CI, 1.09 to 1.92) Nonfatal stroke [9 studies]: HR=1.73 (95% CI, 0.68 to 4.38)
Jin295 2011 20845077 | 8 | Prospective cohort studies; English language only | Carriers of at least one CYP2C19 LOF allele vs. noncarriers Adverse clinical events [8 studies]: OR=1.46 (95% CI, 1.01 to 2.13) Cardiac mortality [5 studies]: OR=2.07 (95% CI, 1.22 to 3.52) MI [5 studies]: OR=1.69 (95% CI, 1.09 to 2.61) ST [5 studies]: OR=3.81 (95% CI, 2.27 to 6.40)
Li296 2012 22123356 | 8 | Randomized or cohort studies; no information on language reported | Carriers of at least one CYP2C19 GOF allele vs. noncarriers MACE [8 studies]: OR=0.86 (95% CI, 0.76 to 0.97) ST [4 studies]: OR=0.92 (95% CI, 0.51 to 1.75) Death [3 studies]: OR=1.23 (95% CI, 0.77, 1.95) Bleeding [4 studies in CAD]: OR=1.25 (195% CI,.07 to 1.47) Bleeding [6 studies, including non-CAP populations]: OR=1.20 (95% CI, 0.88 to 1.66)
Sofi297 2011 20351750 | 7 | Prospective studies; no language restriction | Carriers of at least one CYP2C19 LOF allele vs. noncarriers Cardiovascular events [7 studies]: RR=1.96 (95% CI, 1.14 to 3.37) ST [4 studies]: RR=3.82 (95% CI, 2.23 to 6.54)
Yamaguchi298 2012 22757746 | 7 | Prospective observational studies or RCTs; English language only | Carriers of at least one CYP2C19 *2 allele vs. noncarriers All-cause death [7 studies]: OR 2.00 (95% CI, 1.22 to 3.27) MI [6 studies]: OR=3.07 (95% CI, 2.19 to 4.31) ST [6 studies]: OR=3.26 (95% CI, 1.63 to 6.51) Stroke [3 studies]: OR=1.99 (95% CI, 0.74 to 5.31)

CI = confidence interval; CAD = coronary artery disease; GOF = gain-of-function; HR = hazard ratio; LOF = loss-of-function; MACE = major adverse cardiovascular events; MI = myocardial infarction OR = odds ratio; RCT = randomized controlled trial; RR = relative risk; ST = stent thrombosis.

Effect-size values higher than 1 indicate a detrimental effect (increased frequency of outcomes) among patients carrying the LOF allele. Not all studies reported all outcomes. Reviews are listed by number of included studies contributing to analyses of clinical outcomes, then chronologically. When available, meta-analysis results are from analyses using random effects models. For consistency, data are presented only from dominant genetic models.

Table 46 Results of systematic reviews assessing the predictive ability of phenotypic testing on clinical outcomes among patients receiving clopidogrel treatment

Author Year PMID | No. of Studies | | Selection Criteria | | Outcome [no. of studies/events]: Effect Size (95% CI)
Snoep300 2007 17643570 | 25 | Prospective cohort or case–control studies, and RCTs; no language restriction | | Clopidogrel resistance vs. nonresistance MACE [9 studies] OR=8.0 (95% CI, 3.36 to 19.05) Subacute ST [3 studies] OR=7.02 (95% CI, 0.63 to 79.01) Composite endpoint of clinical ischemic events [4 studies]: OR=12.02 (95% CI, 5.91 to 24.42) Myonecrosis (elevated CK-MB levels) [1 study]: OR=2.20 (95% CI, 0.93 to 5.22)
Aradi301 2010 20826265 | 20 | Observational studies; no language restriction | | High vs. normal on-clopidogrel platelet reactivity Nonfatal MI [11 studies]: OR=3.00 (95% CI, 2.26 to 3.99) ST [11 studies]: OR=4.14 (95% CI, 2.74 to 6.25) Composite ischemic events [17 studies]: OR=4.95 (95% CI, 3.34 to 7.34) CV death [11 studies]: OR=3.35 (95% CI, 2.39 to 4.70)
Combescure302 2010 20156305 | 15 | Prospective cohort or RCTs; no language restriction | | Clopidogrel nonresponder vs. responder Recurrent ischemic events [15 studies]: RR=3.53 (95% CI, 2.39 to 5.20) ADP cutoff >65% for clopidogrel nonresponse Recurrent ischemic events [3 studies]: RR=5.8 (95% CI, 3.2 to 10.3) ADP lower cutoff for clopidogrel nonresponse Recurrent ischemic events [7 studies]: RR=2.9 (95% CI, 2.2 to 3.7)
Sofi303 2010 20135063 | 14 | Prospective cohort studies; no language restriction | | Clopidogrel responder vs. nonresponder MACE [14 studies]: OR=5.67 (95% CI, 2.97 to 10.84)
Yamaguchi298 2012 22757746 | 8 | Prospective observational studies or RCTs; English language only | | High on-treatment platelet reactivity vs. normal on-treatment platelet reactivity MACE [8 studies]: OR=3.03 (95% CI, 2.32 to 3.96) All-cause death [5 studies]: OR=1.11 (95% CI, 0.70 to 1.77) MI [3 studies]: OR=1.37 (95% CI, 0.67 to 2.77) ST [5 studies]: OR=2.65 (95% CI, 1.46 to 4.84)
Brar299 2011 22032704 | 6 | Individual patient data meta-analysis of studies of the VerifyNow P2Y12 assay; no language restriction | | PRU ≥230 vs. <230 Composite primary endpoint [6 studies]: HR=2.10 (95% CI, 1.62 to 2.73) Death [6 studies]: HR=1.66 (95% CI, 1.03 to 2.68) MI [6 studies]: HR=2.04 (95% CI, 1.51 to 2.76) Stent thrombosis [6 studies]: HR=3.11 (95% CI, 1.50 to 6.46)

CI = confidence interval; CK-MB = creatine kinase (MB fraction); HR = hazard ratio; MACE = major adverse cardiovascular events; MI = myocardial infarction; OR = odds ratio; PRU = platelet reactivity unit; RCT = randomized controlled trial; RR = relative risk; ST = stent thrombosis.

Effect size values higher than 1 indicate a detrimental effect (increased frequency of outcomes) among patients with increased on-clopidogrel platelet reactivity. Not all studies reported all outcomes. Reviews are listed by the number of included studies. When available, meta-analysis results are from analyses using random effects models.

#### Genetic Testing for CYP2C19 Variants

In our comparative effectiveness review, we have synthesized more publications than previous reviews, with generally similar findings. We found evidence supporting an association between loss-of-function CYP2C19 alleles and increased risk of stent thrombosis, cardiovascular death, and the composite of adverse cardiovascular outcomes, but not all-cause mortality. Furthermore, we found an association between gain-of-function alleles and reduced risk of MACE (composite). The strength of these findings is limited by concerns about selective reporting bias, because only a subset of the available studies contributed results to the polymorphism–outcome pairs of interest. Furthermore, studies reported on a relatively limited number of events, leading to substantial uncertainty in their effect-size estimates. In addition, data were reported almost exclusively under a dominant genetic model (carriers of at least one allele vs. noncarriers). Analyses under alternative genetic models (recessive and additive) were possible only for a minority of the included studies. Generally, results for the association of loss-of-function alleles with MACE and stent thrombosis under these alternative models were consistent with analyses under a dominant model and had larger effect sizes. The true underlying genetic model remains unknown; the reported data precluded further analyses to address this issue with regards to clinical outcomes. Further, studies did not genotype the same CYP2C19 alleles—for example, loss-of-function alleles other than *2 were not commonly genotyped. However, most loss-of-function variants other than *2 are relatively rare and as such we believe that any effect of exposure misclassification due to incomplete genotyping is likely to be limited. Finally, we found some evidence of statistically significant small-study effects for the two outcomes assessed by most studies (MACE and stent thrombosis). The interpretation of this result is complicated by the fact that statistically significant results of tests for small study effects can be explained by different reasons (selective publication, selective outcome reporting in published papers, real differences between smaller and larger studies, or chance).62 Nonetheless, the presence of small study effects weakens our confidence in the summary estimates and is reflected, among other factors, in the strength of evidence.

Generally, regarding the prognostic effects of CYP2C19 genotype status, existing systematic reviews have reached similar conclusions to ours, both in magnitude and direction. Also consistent with our findings, previous analyses have suggested that selective outcome reporting and publication bias may have affected meta-analytic estimates.20,41

#### Phenotypic Testing for Platelet Reactivity

A large number of studies assessed the prognostic value of various assays for measuring platelet reactivity, mostly in patients with ischemic heart disease. Studies used different assays, definitions, and cutoff values to define increased platelet reactivity. Cutoff values were often identified through analyses of receiver-operating-characteristic curves conducted on the same datasets used to assess the phenotypic test's predictive ability, suggesting that estimates of predictive performance (i.e., estimates of the prediction error) may be overly optimistic. Similar to the situation with genetic testing for CYP2C19 variants, only a subset of the studies evaluating each assay contributed data to each of the outcomes of interest, raising concerns about selective outcome reporting.

Compared to previous systematic reviews, our review includes a much larger number of studies and considers multiple assays assessing on-clopidogrel platelet reactivity using agonists to stimulate platelets ex vivo. In contrast to previous meta-analyses, our review does not combine results across different assays (i.e., across tests using different measurement principles), different agonist concentrations, or different calculation methods or cutoff values for defining high reactivity. We believe that this choice is supported by our review of analytic validity that found low-to-moderate agreement between different assays. We found statistically significant associations between platelet reactivity as measured by various assays (particularly LTA, VerifyNow P2Y12, and the VASP assay) and adverse cardiovascular outcomes. Of note, our analyses include almost double the number of studies included in a recently published meta-analysis of individual data on the VerifyNow assay.299 Despite differences in selection criteria and analysis methods, our findings were similar, identifying a fairly strong association between platelet reactivity measured by this assay and ischemic events.

#### Comparisons Between Alternative Phenotypic Tests and Between Genetic and Phenotypic Testing

We found that directly comparative studies of test performance (defined as studies assessing the prognostic value of two or more tests on the same patient population) were generally rare and almost universally did not perform analyses (or report data) to inform about the relative predictive ability of tests. A qualitative comparison of point estimates and CIs from the available studies suggested that the tests assessed had comparable predictive performance. However, confidence intervals were wide and overlapping, precluding any definitive conclusion. Our findings regarding the comparison of genetic testing for CYP2C19 variants and phenotypic testing for platelet reactivity were similarly inconclusive.

### Use of Testing To Guide Treatment Decisionmaking

To our knowledge, this is the first review to comprehensively evaluate the use of genetic and phenotypic testing for guiding antiplatelet therapy with a focus on patient-relevant benefits and harms. Only a small subset of the reviewed studies directly tested the link between test-based therapy and outcomes. Ideally, directly comparative studies of test-guided treatment versus no testing (or alternative testing strategies) would be used to inform clinical decisions on the benefits and harms of testing. However, because such studies are rarely available, we also considered studies of effect modification based on RCTs of non–test based treatments as well as RCTs of non–test-based therapies using the tests of interest to select “nonresponsive” patients (e.g., patients with high on-clopidogrel reactivity at baseline).

#### Genetic Testing for CYP2C19 Variants

The single directly comparative study of testing versus no-testing for *2 alleles did not provide information regarding clinical outcomes and had short followup. We also reviewed several studies assessing effect modification by CYP2C19 variants; of these, 5 were based on large RCTs comparing antiplatelet treatments within patient groups defined by CYP2C19 genotype. To our knowledge, only one previously published review evaluated such studies of effect modification by CYP2C19 variants and quantitatively synthesized relevant data from large randomized trials. The authors concluded that there is “no clinically significant interaction of CYP2C19 genotype with the association of clopidogrel therapy and cardiovascular events.”41 On the basis of population and treatment heterogeneity, we refrained from quantitatively synthesizing studies of effect modification. Given that the drugs compared have different mechanisms of action, it is plausible that that the true interaction effects (treatment × CYP2C19 genotype) being estimated in the studies may have different magnitudes or directions. However, none of the four studies provided strong evidence that the CYP2C19 genotype modifies the effectiveness of clopidogrel therapy. Despite the studies having included several thousand randomized participants, CIs for relative treatment effects (by genotype status) were fairly wide (with the exception of the CI for the PLATO study) and we could not rule out clinically meaningful differences with regard to relative treatment effectiveness.

Currently, the United States FDA-approved label for clopidogrel^j^ states that poor metabolizers (as identified by CYP2C19 genotype) treated with clopidogrel “exhibit higher cardiovascular event rates following myocardial infarction than do patients with normal CYP2C19 function.” The label also states that CYP2C19 genotyping “can be used as an aid in determining therapeutic strategy”, and that alternative treatment strategies should be considered “in patients identified as CYP2C19 poor metabolizers.” Our review of observational (mostly cohort) studies identified evidence to support the association between loss-of-function CYP2C19 variants and increased rates of some cardiovascular events. At the same time, there was insufficient evidence of antiplatelet treatment effect modification by genotype status. However, the studies investigating treatment effect modification were not specifically designed to assess treatment-genotype interactions, did not have adequate statistical power to detect such effects, and may have been susceptible to selection or survivor bias that could explain the null effects.

j Available at http://products.sanofi.us/PLAVIX/PLAVIX.html; last accessed May 10, 2012.

#### Phenotypic Testing for Platelet Reactivity

Regarding phenotypic testing for platelet reactivity, we identified a small number of comparative studies (6 RCTs and 1 NRCS) evaluating alternative test-and-treatment strategies. The studies were generally small and produced extreme results (with very wide CIs) for all clinical outcomes reported (both benefits and harms). Furthermore, studies had heterogeneous designs (e.g., they differed in the number of measurements performed for monitoring and in the treatment modifications applied for nonresponding patients) and relatively short followup periods (all less than 1 year). In addition, we identified only three studies evaluating different treatments that also provided information on effect modification by baseline platelet reactivity. These studies did not provide compelling evidence of effect modification by baseline platelet reactivity. Finally, although we identified a number of studies selecting patients on the basis of high baseline platelet reactivity and then randomizing them into non–test based comparator groups, these studies are informative about the value of testing to guide treatment selection only if it is assumed that the randomized treatments have the same effect (or at least a relative effect known with certainty) in patients with low baseline platelet reactivity. Overall, we believe there is insufficient evidence to support (or refute) the use of use of phenotypic testing for platelet reactivity to guide antiplatelet treatment selection. Our findings do support current clinical practice guidelines, which in general do not advocate the use of phenotypic testing for platelet reactivity for guiding choice of treatment.

### Modifiers of the Impact of Test Results

We found limited evidence that patient-level characteristics, disease features, cointerventions (including PPIs), or system-level factors impact the predictive effect of genetic or phenotypic tests of interest. No modifier was assessed in more than a few studies for any test–outcome pair of interest to this review. Even when considering information across studies (meta-regression) we did not identify convincing evidence that study-level characteristic modify the prognostic effect of genetic testing (meta-regression analyses were undertaken for CYP2C19 variants only, owing to the small number of available studies for other outcomes). Nonetheless, these analyses provided some indication that the association between loss-of-function alleles with MACE and stent thrombosis is modified by ethnicity, with East Asians experiencing a stronger harmful effect. This is particularly interesting given the reported higher frequency of loss-of-function alleles in East Asian populations. These findings should be investigated further to ensure that this is a true effect and not due to the small number of studies in East Asian populations of confounding by other study-level factors

### Harms of Testing and Test-Directed Treatment

Direct evidence on the harms of test-directed treatment was reported by a limited number of comparative studies. Although the studies did not raise concerns about an increased rate of harms, they were generally small and had followup periods too short to permit conclusions. We found no evidence on harms of testing per se, possibly reflecting the fact that testing procedures, both for genetic and phenotypic testing, are associated with minimal physical harm (e.g., minor complications of phlebotomy to obtain blood samples). Other potential harms of testing—unnecessary exposure to higher-risk treatment or ethical and social issues, such as discrimination on the basis of genetic information and the possibility that the prognostic value of genetic information may be overestimated by patients304—were not considered in the studies we reviewed.

## Applicability

The vast majority of included studies enrolled patients with ischemic heart disease (acute or chronic coronary disease represented almost all available studies for all Key Questions). Other populations who are potential candidates for antiplatelet therapy (e.g., patients with cerebrovascular disease, peripheral arterial disease, or atrial fibrillation) were included in a minority of studies only. This imbalance is not unexpected, given that clopidogrel's primary indications pertain to ischemic heart disease. However, it is probably not prudent to extrapolate findings from studies of ischemic heart disease to other patient populations. Given that a large number of studies included patients undergoing PCI, applicability may also be limited in noninterventional settings.

Particularly for genetic testing for CYP2C19 variants, patient race or ethnicity may be an important effect modifier, because the prevalence of variant alleles is substantially different among racial and ethnic groups (e.g., *2 variants are much more common in East Asian populations than others). We found limited evidence that prognostic effects were different in subgroup and meta-regression analysis by ethnicity (East Asian versus white); more evidence is needed for patient populations underrepresented in this review (e.g., blacks) and to validate our findings.

The majority of studies were conducted in tertiary (usually academic) medical centers. Studies of treatment-effect modification by CYP2C19 genotype were based on large randomized trials, and findings may not be generalizable to everyday care settings. Because patient information on preexisting vascular disease in studies of predictive effects was generally incompletely reported, it is unclear whether patients in the included studies are representative of those seen in clinical practice. Nonetheless, the distribution of risk factors for ischemic vascular disease (male sex, hyperlipidemia, diabetes, hypertension, smoking, etc.) appeared to be representative of contemporary patient populations, and the majority of studies were conducted in recent years.

## Implications for Clinical and Policy Decisionmaking

Despite the large literature on the use of genetic testing of CYP2C19 variants and phenotypic testing of platelet reactivity for predicting outcomes in patients receiving clopidogrel-based therapy, studies provided limited information on the value added by these tests over ascertainment of conventional risk factors in the populations of interest (e.g., clinical or laboratory information or disease-specific predictive scores). Furthermore, there was little comparative evidence that could be used to identify the most informative test or combination of tests for predicting clinical outcomes. This and other limitations of the existing literature may reduce the potential for clinical application of the tests reviewed herein as prognostic markers for patients on clopidogrel-based antiplatelet therapy. The available evidence was even more limited regarding the use of either type of testing to guide the choice of antiplatelet therapy.

Additional research seems warranted for both genetic and phenotypic tests. Genetic testing methods appear to be fairly standardized and reliable so new research can focus on clinical outcomes. In contrast, phenotypic testing with platelet reactivity can be done using a number of different assays and principles of measurement. Identifying the optimal assay, agonist concentration, and reactivity cutoff values for predicting clinical events is a significant challenge for future research. This challenge needs to be addressed in order to prioritize which reactivity assays should be evaluated as methods for guiding treatment choice.

## Limitations of the Evidence

On the basis of the large number of reviewed studies, we believe that the evidence regarding genetic testing for CYP2C19 variants and phenotypic testing for platelet reactivity (for guiding antiplatelet treatment and predicting outcomes in patients who receive it) is limited in the following ways:

- Despite the large number of available studies providing information on analytic validity, most studies used inappropriate statistical methods to assess inter-assay agreement. Few studies accounted for the lack of a perfect reference standard test (no “gold” standard) and the statistical analyses used where often inappropriate for assessing agreement.
- Lack of comparative studies of alternative testing strategies evaluating the relative predictive ability of the tests of interest. No studies reported valid direct comparisons between the tests of interest in terms of prognostic performance; studies either assessed a single test or simply provided information on test performance separately for each test applied to the study population.
- Lack of separation of development (“training”) and assessment (“test”) samples when developing prognostic markers. Many studies of phenotypic tests used receiver-operating-characteristic methods to define an “optimal” cutoff value of reactivity (typically, one that maximized the sum of sensitivity and specificity), without using any methods to limit overfitting.305 In most cases these cutoffs were then applied to the same population sample that was used to derive them, in order to calculate predictive performance. This approach leads to overly optimistic estimates of test performance (i.e., inflated sensitivity and specificity) that are unlikely to generalize to the target population.306
- Selective outcome reporting was a concern for the association between test results and several clinical outcomes. Most studies reported information on composite clinical outcomes but often did not provide results for the component clinical events.
- Uncertainty about the genetic model for CYP2C19 variants. Poor reporting of primary study results precluded the assessment of alternative genetic models (i.e., results were often reported only for collapsed genotype categories).
- Heterogeneity in exposure definitions and uncertainty about the underlying genetic model for CYP2C19 variants. Our ability to synthesize findings across studies was limited by the use of heterogeneous methods to define exposure status. This was particularly true for studies of platelet reactivity assays because of the large variability in measurement methods (existence of multiple assays) and in cutoff values for defining positive results (among studies using the same assay). Heterogeneity of exposure definitions was also present in studies of CYP2C19 variants, because studies genotyped different subsets of known CYP2C19 alleles (e.g., loss-of-function alleles other than *2 were not commonly genotyped). Furthermore, with few exceptions, data were reported in a way that only allowed for analyses under a dominant genetic model (carriers vs. noncarriers), which may not be the true genetic model.
- Paucity of studies evaluating the impact of test-guided treatment selection on the basis of the tests of interest. The literature we reviewed included few studies directly comparing alternative testing strategies or assessing effect modification by test results. Available studies were small, had short followup periods, or did not report information on clinical outcomes. The five large studies reporting information on treatment effect modification by CYP2C19 status based on RCTs of antiplatelet regimens were conducted in heterogeneous populations, compared different treatment regimens, and had several design limitations. No studies used quantitative methods to assess the intermediate outcomes of impact of testing on predictive probabilities or treatment decisions.
- The number of studies providing information on treatment effect modification by CYP2C19 genotype status or baseline on-clopidogrel platelet reactivity was limited. Investigations based on completed randomized trials (repurposed RCTs) were not powered to detect treatment effect modification and were susceptible to selection bias because included patients represented only a minority of the populations included in the parent trials.

## Ongoing Research

A search on May 3, 2012, in the ClinicalTrials.gov registry identified 173 potentially relevant records. After full text review, 28 records of studies that can be expected to provide information relevant to Key Questions 3 and 4 of this report were identified. Appendix G summarizes information from these studies. None of these studies provided results in the ClinicalTrials.gov database at the time of this search.

## Evidence Gaps

Table 47 summarizes the evidence gaps with regards to the five Key Questions of this systematic review.

Table 47 Evidence gaps

Key Question | Category | Evidence Gap
1. Analytic validity and predictive value of genetic testing for CYP2C19 variants | Population | - The analytic validity of alternative assays for measuring platelet reactivity has not been established.; - Studies of the prognostic value of CYP2C19 variants were almost exclusively limited to patients with ischemic heart disease. Additional evidence is needed on the predictive value of tests in other patient populations who are candidates for antiplatelet therapy.
1. Analytic validity and predictive value of genetic testing for CYP2C19 variants | Intervention and exposure definition | - Additional studies comprehensively genotyping CYP2C19 variants (i.e., genotyping all variants prevalent in the population of interest) and reporting on long-term clinical outcomes are needed.; - Combinations of types of tests (e.g., genetic and phenotypic testing) or combinations of genetic tests were rarely assessed.; - Research to identify the most likely genetic model for CYP2C19 variants is needed. Approaches combining clinical data along with pharmacodynamic and pharmacogenetic information would probably be most informative.
1. Analytic validity and predictive value of genetic testing for CYP2C19 variants | Comparator | - No studies reported valid direct comparisons of the prognostic value of different tests (e.g., comparisons between genetic vs. phenotypic testing, or among alternative phenotypic tests) were available.
1. Analytic validity and predictive value of genetic testing for CYP2C19 variants | Outcome | - Many studies assessed platelet reactivity exclusively and clinical outcomes were often reported only as composites. More data on individual clinical outcomes is needed.
2. Analytic validity and predictive value of phenotypic testing for platelet reactivity | Population | - Evidence on the analytic validity and predictive value for populations other than those with ischemic heart disease was limited.
2. Analytic validity and predictive value of phenotypic testing for platelet reactivity | Intervention and exposure definition | - No single assay for measuring platelet reactivity can be considered a “gold standard” test.; - Combinations of tests (e.g., genetic and phenotypic testing) or combinations of genetic tests were rarely assessed.
2. Analytic validity and predictive value of phenotypic testing for platelet reactivity | Comparator | - No studies reporting valid direct comparisons the predictive value of different tests were available.
2. Analytic validity and predictive value of phenotypic testing for platelet reactivity | Outcome | - Studies reporting clinical outcomes often reported only composite outcomes (without providing information on the component outcomes separately).
3. Use of testing to guide treatment choice | General evidence gap | - Directly comparative studies of alternative test strategies using phenotypic tests were few and had short followup durations and heterogeneous designs.; - A single randomized study with short followup compared genetic testing for CYP2C19 variants versus no testing.; - Studies of effect modification were few, pertained to heterogeneous populations, reported information on intermediate outcomes only, or compared different antiplatelet treatments. These studies were based on well-conducted randomized efficacy trials but were not specifically designed to detect effect modification and may have been susceptible to selection (survivor) bias.
4. Harms of testing or test-directed treatment | General evidence gap | - Few studies provided direct comparative information on the impact of alternative test-and-treat strategies on patient safety.; - No studies on the harms of testing per se were identified.; - More evidence is needed regarding monitoring strategies that involve repeat testing that may lead to delays in invasive interventional procedures.

## Future Research

This review has identified substantial gaps in the literature on genetic testing for CYP2C19 variants and phenotypic testing for platelet reactivity, both as biomarkers of future outcomes among patients who are receiving clopidogrel therapy and—more importantly—as tests for guiding treatment selection for patients who are candidates for antiplatelet treatment. We believe that the following evidence gaps may represent fruitful areas for future research (i.e., that they represent areas in need of future research):

- Analytic validity of phenotypic testing: Future studies using rigorous methods to inform the analytic validity of tests for measuring platelet reactivity are needed, particularly with regard to test–retest reliability, interassay agreement, and analytic performance. Ideally studies should evaluate multiple assays applied to the same samples, enroll a large number of patients, and be conducted in a multilaboratory setting. The existing genotypic assays are considered robust; however, studies of CYP2C19 assays should report details of their genotyping quality control methods.307
- Prognostic accuracy, with a focus on comparative prognostic performance: Although we identified several studies reporting on the prognostic value of the tests of interest, studies had several limitations in their design and analysis methods (see the Limitations of the Evidence Base section above). Thus, large-scale prospective studies of the tests of interest are needed to derive reliable estimates of prognostic performance. Because the major source of costs for conducting such studies stems from the need to follow up with large numbers of individuals over time, it may be worthwhile to perform measurements of on-clopidogrel platelet reactivity at baseline using multiple assays as well as obtain genetic material for genotyping CYP2C19 variants or other emerging genetic biomarkers. Such a design would provide information on multiple tests simultaneously; for conducting informative direct comparisons between assays, however, such studies would have to be large. This is because the results of different reactivity assays are correlated (although interassay agreement is not perfect, correlations higher than 0.5 were common in the reviewed studies). Studies of CYP2C19 variants need to assess all polymorphisms with adequate prevalence in the populations of interest; considerations should also be given to genotyping other genes involved in clopidogrel metabolism (e.g., ABCB1 or PON1) and the assessment of gene–gene interactions. Studies will need to predefine cutoff values and genotype groupings and compare the classification performance of individual tests, as well as the reclassification performance of each assay compared to established clinical risk scores or results of other assays.308-313 Complete data for all outcomes assessed should be reported.
- Direct comparisons of methods for test-guided treatment selection: Even if the prognostic value of tests were established, this information is often inadequate as a basis for treatment decisionmaking. Once the prognostic performance of the tests of interest is established, the most promising tests could be prioritized for assessment in directly comparative studies of testing versus no testing. Such studies can provide unconfounded estimates of the relative benefits and harms of the compared strategies. However, randomized comparisons of alternative testing strategies are costly and time consuming. Furthermore, recruitment may be challenging or impossible if one of the treatment groups is standard clopidogrel-based therapy, in view of the current FDA-approved labeling and recent results from studies using pharmacodynamic endpoints. Still, such designs may be appropriate when comparing antiplatelet therapies other than standard clopidogrel dosing (including high-dose clopidogrel treatment). For example, one design that may be particularly appealing for the tests of interest to this review is the use of a test in all patients who are candidates for antiplatelet treatment, followed by randomization of only test-“positive patients to receive one of several different treatments. This design can provide information on the relative harms and benefits of a treatment among patients whose treatment would be expected to change on the basis of test results. A third comparator arm of standard treatment in the test-negative patients can be included as an additional (nonrandomized) “control” group (such an approach was taken by the randomized GRAVITAS trial, and some smaller studies, considered under Key Questions 2 and 3 of this report). A more detailed discussion of efficient biomarker study designs and the conditions under which they can lead to increases in statistical power are out of the scope of this report but have been discussed extensively elsewhere (e.g., Scher et al. 2011,314 Simon 2010^315^). When experimental studies are not considered logistically or ethically feasible, observational data may be useful, especially given that CYP2C19 testing is not universally implemented.
- “Repurposing” completed randomized trials to assess effect modification: An alternative to direct comparative studies of testing strategies is to assess effect modification by genotype status by repurposing already completed randomized trials, in which the drugs of interest were tested against a suitable comparator, by genotyping samples from enrollees. Results of genetic analyses can be associated with the prospectively recorded clinical outcomes.48,49 Although this approach did not provide definitive answers in this review due to limitations of the existing studies, future repurposed trials could yield more informative results if they are properly planned. Such planning must include a strategy for obtaining samples from all participants (or a random sample thereof), acquiring specimens prior to treatment, and using appropriate methods to control for multiple testing. When randomized trials are not available for repurposing, a similar approach can be implemented in the setting of registries linking DNA information to electronic health records. Patients receiving different antiplatelet therapies in whom the choice of treatment has not been based on CYP2C19 status, but for whom material for genotyping is available, are candidates for such research.
- Monitoring of platelet reactivity to guide treatment: Strategies of monitoring platelet reactivity can be conceptualized as “dynamic treatment regimes”316-318 (i.e., rules for sequential decisionmaking based on the evolution of reactivity measurements over time; obviously such methods are not applicable to CYP2C19 testing). Such approaches formalize the process of choosing between competing monitoring strategies, based on expected responses to treatment and related intermediate and long-term outcomes, using appropriate statistical models. Compared to standard research methods (e.g., directly comparing two monitoring strategies in a parallel-group study), dynamic treatment modeling may be better at identifying the optimal monitoring regime while accounting for multiple monitoring visits and the fact that treatment decisions at each visit are determined by the measurements (e.g., platelet reactivity, other laboratory measurements, etc.) obtained in previous visits. Indeed, statistical methods exist that can use observational or randomized study data to determine the factors that should be considered as triggers for intervention, as well as the optimal cutoff values of these factors. These approaches may increase the efficiency of future research because it is impossible to conduct randomized trials comparing all alternative test-and-treat strategies for different assays, thresholds of reactivity, and alternative therapeutic interventions.

## Conclusions

In summary, we found limited evidence on the analytic validity of genetic testing for platelet reactivity. However, using evidence from other populations and genetic variants, we believe that the available assays for CYP2C19 genotyping have adequate technical test performance. In contrast, we found a large body of evidence on the analytic validity of assays for measuring platelet reactivity, suggesting that interassay agreement is only poor to moderate. No phenotypic assays can be considered a “gold standard” test.

We found some evidence supporting a significant association between loss-of-function CYP2C19 variants and increased risk of stent thrombosis, cardiovascular mortality, and MACE. We also found a significant association between gain-of-function alleles and reduced risk of MACE. The interpretation of these associations should be cautious, given the potential for selective reporting and small-study effects to have affected study results. Furthermore, the applicability of findings to patient populations other than those with ischemic coronary artery disease (particularly those undergoing revascularization procedures) was limited. We also found evidence supporting an association between high on-clopidogrel platelet reactivity as measured by various assays (particularly LTA, VerifyNow P2Y12, and the VASP assay) and adverse cardiovascular events. Our confidence in these findings is limited by the relatively small number of studies available for each test–outcome combination, the potential for selective outcome reporting, and the common lack of separation between the populations used to derive test thresholds of optimal predictive value and those used to assess predictive value at these thresholds.

The evidence on the use of testing to guide treatment choice was insufficient. A single randomized trial of CYP2C19 testing versus no-testing provided limited evidence on clinical outcomes. Sub-analyses of five well done randomized controlled trials generally did not find strong evidence of effect modification by CYP2C19 status; however, concern for selection bias and the heterogeneity of patient populations and treatments rendered the evidence inconclusive. Similarly, the short follow-up periods and low numbers of outcome events in trials of platelet reactivity-guided treatment versus standard antiplatelet therapy did not offer a firm base for conclusions. No studies comparing alternative testing strategies were identified.

Additional research is needed to better establish the prognostic value and clinical utility for treatment decisionmaking, both for genetic testing for CYP2C19 variants and phenotypic testing for platelet reactivity, focusing on standardizing testing methods and assessing the relative impact of testing strategies on patient-relevant clinical outcomes in large, well-conducted clinical trials.