# Detailed Assessment of the Strength of Evidence

Appendix Table G1 Assessment of strength of evidence domains