# Appendix Tables for Key Questions 3 and 4

Appendix Table F1 Assessment of risk of bias in comparative studies of test-and-treat strategies using genetic testing for CYP2C19 variants

Appendix Table F2 Assessment of risk of bias in studies of CYP2C19 genetic testing assessing treatment effect modification

Appendix Table F3 Assessment of risk of bias in the study of genetic test–based selection of patients

Appendix Table F4 Baseline and final (longest followup) values of laboratory outcomes (platelet reactivity) in comparative studies assessing test-and-treat strategies using phenotypic testing for platelet reactivity

Appendix Table F5 Assessment of risk of bias for comparative studies assessing test-and-treat strategies using phenotypic testing for platelet reactivity

Appendix Table F6 Assessment of risk of bias for studies assessing effect modification by platelet reactivity status

Appendix Table F7 Assessment of risk of bias for studies of patients selected on the basis of platelet reactivity testing and then randomized into alternative antiplatelet