# Appendix Tables for Key Question 2

Appendix Table E1 Descriptive characteristics of studies reporting analytic validity information

Appendix Table E2 Studies reporting correlation results between alternative platelet reactivity assays

Appendix Table E3 Studies reporting results on the reliability of platelet reactivity assays with unclear study designs

Appendix Table E4 Reporting characteristics and methodological quality of studies of analytic validity

Appendix Table E5 Baseline characteristics of patients with ischemic heart disease in studies assessing the predictive ability of LTA

Appendix Table E6 Baseline characteristics of patients with peripheral arterial disease in studies assessing the predictive ability of LTA

Appendix Table E7 Baseline characteristics of a mixed patient population of patients with ischemic heart, cerebrovascular and peripheral vascular disease in a single study assessing the predictive ability of LTA

Appendix Table E8 Design characteristics of studies assessing the predictive ability of LTA in patients with ischemic heart disease

Appendix Table E9 Design characteristics of studies assessing the predictive ability of LTA in patients with peripheral arterial disease

Appendix Table E10 Design characteristics of a single study assessing the predictive ability of LTA in a mixed patient population with ischemic heart, cerebrovascular and peripheral vascular disease

Appendix Table E11 Phenotypic test details in studies assessing the predictive ability of LTA in patients with ischemic heart disease

Appendix Table E12 Phenotypic test details in a single study assessing the predictive ability of LTA in patients with peripheral arterial disease

Appendix Table E13 Phenotypic test details in studies assessing the predictive ability of LTA in patients with ischemic heart, cerebrovascular and peripheral vascular disease

Appendix Table E14 Results of studies assessing the ability of LTA to predict mortality in patients with ischemic heart disease

Appendix Table E15 Results from studies assessing the ability of LTA to predict myocardial infarction in patients with ischemic heart disease

Appendix Table E16 Results from studies assessing the ability of LTA to predict stent thrombosis in patients with ischemic heart disease

Appendix Table E17 Results from studies assessing the ability of LTA to predict major adverse cardiovascular events in patients with ischemic heart disease

Appendix Table E18 Results from studies assessing the ability of LTA to predict bleeding events in patients with ischemic heart disease

Appendix Table E19 Results from studies assessing the ability of LTA to predict stroke in patients with ischemic heart disease

Appendix Table E20 Results from studies assessing the ability of LTA to predict other clinical events in patients with ischemic heart disease

Appendix Table E21 Results from studies assessing the ability of LTA to predict platelet reactivity during followup (discrete outcome) in patients with ischemic heart disease

Appendix Table E22 Results from the single study assessing the ability of LTA to predict platelet reactivity during followup (discrete outcome) in patients with peripheral artery disease

Appendix Table E23 Results from studies assessing the ability of LTA to predict platelet reactivity during followup (continuous outcome) in patients with ischemic heart disease

Appendix Table E24 Quality assessment of studies assessing the predictive ability of LTA in patients with ischemic heart disease

Appendix Table E25 Quality assessment of the single study assessing the predictive ability of LTA in patients with peripheral arterial disease

Appendix Table E26 Quality assessment of the single study assessing the predictive ability of LTA in a mixed population of patients with ischemic heart disease and peripheral vascular disease

Appendix Table E27 Baseline characteristics of patients with ischemic heart disease in studies assessing the predictive ability of VerifyNow

Appendix Table E28 Baseline characteristics of patients with cerebrovascular disease in studies assessing the predictive ability of VerifyNow

Appendix Table E29 Study design characteristics of studies assessing the predictive ability of VerifyNow in patients with ischemic heart disease

Appendix Table E30 Study design characteristics of studies assessing the predictive ability of VerifyNow in patients with cerebrovascular disease

Appendix Table E31 Phenotypic test details in studies assessing the predictive ability of VerifyNow in patients with ischemic heart disease

Appendix Table E32 Phenotypic test details in studies assessing the predictive ability of VerifyNow in patients with cerebrovascular disease

Appendix Table E33 Results from studies assessing the ability of VerifyNow to predict death in patients with ischemic heart disease

Appendix Table E34 Results from studies assessing the ability of VerifyNow to predict myocardial infarction in patients with ischemic heart disease

Appendix Table E35 Results from studies assessing the ability of VerifyNow to predict stent thrombosis in patients with ischemic heart disease

Appendix Table E36 Results from studies assessing the ability of VerifyNow to predict major adverse cardiovascular events in patients with ischemic heart disease

Appendix Table E37 Results from studies assessing the ability of VerifyNow to predict bleeding events in patients with ischemic heart disease

Appendix Table E38 Results from studies assessing the ability of VerifyNow to predict stroke in patients with ischemic heart disease

Appendix Table E39 Results from studies assessing the ability of VerifyNow to predict other clinical events in patients with ischemic heart disease

Appendix Table E40 Results from studies assessing the ability of VerifyNow to predict other clinical events in patients with cerebrovascular disease

Appendix Table 41 Results from studies assessing the ability of VerifyNow to predict platelet reactivity during followup (discrete outcome) in patients with ischemic heart disease

Appendix Table E42 Results from the single study assessing the ability of VerifyNow to predict platelet reactivity during followup (continuous measurement) in patients with ischemic heart disease

Appendix Table E43 Quality assessment of studies assessing the predictive ability of VerifyNow in patients with ischemic heart disease

Appendix Table E44 Quality assessment of studies assessing the predictive ability of VerifyNow in patients with cerebrovascular disease

Appendix Table E45 Baseline characteristics of patients with ischemic heart disease in studies assessing the predictive ability of VASP

Appendix Table E46 Baseline characteristics of a mixed patient population with ischemic heart, cerebrovascular and peripheral vascular disease in studies assessing the predictive ability of VASP

Appendix Table E47 Study design characteristics of studies assessing the predictive ability of VASP in patients with ischemic heart disease

Appendix Table E48 Study design characteristics of studies assessing the predictive ability of VASP in a mixed patient population with ischemic heart, cerebrovascular and peripheral vascular disease

Appendix Table E49 Phenotypic test details in studies assessing the predictive ability of VASP in patients with ischemic heart disease

Appendix Table E50 Phenotypic test details in a single study assessing the predictive ability of VASP in patients with ischemic heart, cerebrovascular and peripheral vascular disease

Appendix Table E51 Results from studies assessing the ability of VASP to predict death in patients with ischemic heart disease

Appendix Table E52 Results from studies assessing the ability of VASP to predict myocardial infarction in patients with ischemic heart disease

Appendix Table E53 Results from studies assessing the ability of VASP to predict stent thrombosis in patients with ischemic heart disease

Appendix Table E54 Results from studies assessing the ability of VASP to predict major adverse cardiovascular events in patients with ischemic heart disease

Appendix Table E55 Results from studies assessing the ability of VASP to predict major adverse cardiovascular events in patients with ischemic heart, cerebrovascular and peripheral vascular disease

Appendix Table E56 Results from studies assessing the ability of VASP to predict stroke in patients with ischemic heart disease

Appendix Table E57 Results from studies assessing the ability of VASP to predict other clinical events in patients with ischemic heart disease

Appendix Table E58 Results from studies assessing the ability of VASP to predict platelet reactivity during followup (discrete outcome) in patients with ischemic heart disease

Appendix Table E59 Results from studies assessing the ability of VASP to predict platelet reactivity during followup (when used as a continuous measurement) in patients with ischemic heart disease

Appendix Table E60 Quality assessment of studies assessing the predictive ability of VASP in patients with ischemic heart disease

Appendix Table E61 Quality assessment of studies assessing the predictive ability of VASP in a mixed patient population with Ischemic heart, cerebrovascular and peripheral vascular disease

Appendix Table E62 Baseline characteristics of patients with ischemic heart disease in studies assessing the predictive ability of Multiplate Analyzer

Appendix Table E63 Baseline characteristics of patients with cerebrovascular disease in studies assessing the predictive ability of Multiplate Analyzer

Appendix Table E64 Study design characteristics of studies assessing the predictive ability of Multiplate Analyzer in patients with ischemic heart disease

Appendix Table E65 Study design characteristics of studies assessing the predictive ability of Multiplate Analyzer in patients with cerebrovascular disease

Appendix Table E66 Phenotypic test details in studies assessing the predictive ability of Multiplate Analyzer in patients with ischemic heart disease

Appendix Table E67 Phenotypic test details in studies assessing the predictive ability of Multiplate Analyzer in patients with cerebrovascular disease

Appendix Table E68 Results from studies assessing the ability of Multiplate Analyzer to predict death in patients with ischemic heart disease

Appendix Table E69 Results from studies assessing the ability of Multiplate Analyzer to predict myocardial infarction in patients with ischemic heart disease

Appendix Table E70 Results from studies assessing the ability of Multiplate Analyzer to predict stent thrombosis in patients with ischemic heart disease

Appendix Table E71 Results from the studies assessing the ability of Multiplate Analyzer to predict major adverse cardiovascular events in patients with ischemic heart disease

Appendix Table E72 Results from studies assessing the ability of Multiplate Analyzer to predict major adverse cardiovascular events in patients with cerebrovascular disease

Appendix Table E73 Results from studies assessing the ability of Multiplate Analyzer to predict bleeding events in patients with ischemic heart disease

Appendix Table E74 Results from studies assessing the ability of Multiplate Analyzer to predict stroke in patients with ischemic heart disease

Appendix Table E75 Results from studies assessing the ability of Multiplate Analyzer to predict other clinical events in patients with ischemic heart disease

Appendix Table E76 Results from studies assessing the ability of Multiplate Analyzer to predict platelet reactivity during followup (discrete outcome) in patients with ischemic heart disease

Appendix Table E77 Quality assessment of studies assessing the predictive ability of Multiplate Analyzer in patients with ischemic heart disease

Appendix Table E78 Quality assessment of studies assessing the predictive ability of Multiplate Analyzer in patients with cerebrovascular disease

Appendix Table E79 Baseline characteristics of patients with ischemic heart disease in studies assessing the predictive ability of TEG

Appendix Table E80 Design characteristics of studies assessing the predictive ability of TEG in patients with ischemic heart disease

Appendix Table E81 Phenotypic test details in studies assessing the predictive ability of TEG in patients with ischemic heart disease

Appendix Table E82 Results from studies assessing the ability of TEG to predict death in patients with ischemic heart disease

Appendix Table E83 Results from studies assessing the ability of TEG to predict myocardial infarction in patients with ischemic heart disease

Appendix Table E84 Results from studies assessing the ability of TEG to predict stent thrombosis in patients with ischemic heart disease

Appendix Table E85 Results from studies assessing the ability of TEG to predict major adverse cardiovascular events in patients with ischemic heart disease

Appendix Table E86 Results from studies assessing the ability of TEG to predict bleeding events in patients with ischemic heart disease

Appendix Table E87 Results from studies assessing the ability of TEG to predict stroke in patients with ischemic heart disease

Appendix Table E88 Results from studies assessing the ability of TEG to predict other clinical events in patients with ischemic heart disease

Appendix Table E89 Quality assessment of studies assessing the predictive ability of TEG in patients with ischemic heart disease

Appendix Table E90 Baseline characteristics of patients with ischemic heart disease in studies assessing the predictive ability of the PFA-100 System

Appendix Table E91 Baseline characteristics of a mixed patient population with ischemic heart, cerebrovascular and peripheral vascular disease in studies assessing the predictive ability of PFA-100

Appendix Table E92 Study design characteristics of studies assessing the predictive ability of PFA-100 System in patients with ischemic heart disease

Appendix Table E93 Study design characteristics of studies assessing the predictive ability of PFA-100 System in a mixed patient population with ischemic heart, cerebrovascular and peripheral vascular disease

Appendix Table E94 Phenotypic test details in studies assessing the predictive ability of PFA-100 in patients with ischemic heart disease

Appendix Table E95 Phenotypic test details in studies assessing the predictive ability of PFA-100 in patients with ischemic heart, cerebrovascular and peripheral vascular disease

Appendix Table E96 Results from studies assessing the ability of PFA-100 to predict death in patients with ischemic heart disease

Appendix Table E97 Results from studies assessing the ability of PFA-100 to predict myocardial infarction in patients with ischemic heart disease

Appendix Table E98 Results from studies assessing the ability of PFA-100 to predict stent thrombosis in patients with ischemic heart disease

Appendix Table E99 Results from studies assessing the ability of PFA-100 to predict major adverse cardiovascular events in patients with ischemic heart disease

Appendix Table E100 Results from studies assessing the ability of PFA-100 to predict major adverse cardiovascular events in patients with ischemic heart, cerebrovascular and peripheral vascular disease

Appendix Table E101 Results from studies assessing the ability of PFA-100 to predict bleeding events in patients with ischemic heart disease

Appendix Table E102 Results from studies assessing the ability of PFA-100 to predict stroke in patients with ischemic heart disease

Appendix Table E103 Results from studies assessing the ability of PFA-100 to predict other clinical events in patients with ischemic heart disease

Appendix Table E104 Results from studies assessing the ability of PFA-100 to predict platelet reactivity during followup (discrete outcome) in patients with ischemic heart disease

Appendix Table E105 Quality assessment of studies assessing the predictive ability of PFA-100 in patients with ischemic heart disease

Appendix Table E106 Quality assessment of studies assessing the predictive ability of PFA-100 in patients with ischemic heart, cerebrovascular and peripheral vascular disease

Appendix Table E107 Baseline characteristics of patients with ischemic heart disease in studies assessing the predictive ability of miscellaneous platelet function tests

Appendix Table E108 Study design characteristics of studies assessing the predictive ability of miscellaneous platelet function tests in patients with ischemic heart disease

Appendix Table E109 Phenotypic test details in studies assessing the predictive ability of miscellaneous platelet function tests in patients with ischemic heart disease

Appendix Table E110 Results from studies assessing the ability of miscellaneous platelet function tests to predict death in patients with ischemic heart disease

Appendix Table E111 Results from studies assessing the ability of miscellaneous platelet function tests to predict myocardial infarction in patients with ischemic heart disease

Appendix Table E112 Results from studies assessing the ability of miscellaneous platelet function tests to predict stent thrombosis in patients with ischemic heart disease

Appendix Table E113 Results from studies assessing the ability of miscellaneous platelet function tests to predict major adverse cardiovascular events in patients with ischemic heart disease

Appendix Table E114 Results from studies assessing the ability of miscellaneous platelet function tests to predict bleeding events in patients with ischemic heart disease

Appendix Table E115 Results from studies assessing the ability of miscellaneous platelet function tests to predict stroke in patients with ischemic heart disease

Appendix Table E116 Results from studies assessing the ability of miscellaneous platelet function tests to predict other clinical events In patients with ischemic heart disease

Appendix Table E117 Results from studies assessing the ability of miscellaneous platelet function tests to predict platelet reactivity during followup (discrete outcome) in patients with ischemic heart disease

Appendix Table E118 Quality assessment of studies assessing the predictive ability of miscellaneous platelet function tests in patients with ischemic heart disease

## Risk of Bias and Applicability Assessment Key

1. Consecutive or random sample of patients enrolled.
2. Case-control design avoided
3. Study avoided inappropriate exclusions

Risk of bias: could the selection of patients have introduced bias (if ≥2 of the above 3 questions are YES, give LOW here; if ≥2 are NO give HIGH; otherwise, give UNCLEAR)

Applicability: Concerns that the included patients do not match the review question?

4 Index test results interpreted without knowledge of results of reference standard?
5 If a threshold used, was it prespecified?

Risk of bias: Could the conduct or interpretation of the index test have introduced bias? (if both of the above questions are YES, give LOW here; if one or both are NO, give HIGH; otherwise, give UNCLEAR)

Applicability: Concerns that the index test, its conduct, or its interpretation differ from the review question?

6 Reference standard likely to correctly classify the target condition?
7 Reference standard results interpreted without knowledge of index test results?

Risk of bias: Could the reference standard, its conduct, or its interpretation have introduced bias? (If both of the above questions are YES, give LOW here; if one or both are NO, give HIGH; otherwise, give UNCLEAR)

Applicability: Are there concerns that the target condition as defined by the reference standard does not match the review question?

8 Appropriate interval between index test and reference standard?
9 All patients received a reference standard?
10 All patients received the same reference standard?
11 Were all patients included in the analysis?

Risk of bias: Could the patient flow have introduced bias? (If ≥3 of the above 4 questions are YES, give LOW here; if ≥2 are NO give HIGH; otherwise, give UNCLEAR)