# Appendix Tables for Key Question 1

Appendix Table D1 Descriptive characteristics of studies reporting analytic validity information for CYP2C19 assays

Appendix Table D2 Reporting characteristics and methodological quality of studies of analytic validity

Appendix Table D3 Descriptive characteristics of included studies

Appendix Table D4 Study design characteristics

Appendix Table D5 Genotypic test information

Appendix Table D6 Methods for reactivity assessment (used for outcome ascertainment)

Appendix Table D7 Clinical outcome information – mortality

Appendix Table D8 Clinical outcome information – myocardial infarction

Appendix Table D9 Clinical outcome information – stent thrombosis

Appendix Table D10 Clinical outcome information – major adverse cardiovascular events

Appendix Table D11 Clinical outcome information – bleeding

Appendix Table D12 Clinical outcome information – stroke

Appendix Table D13 Clinical outcome information – other clinical events

Appendix Table D14 Platelet reactivity during followup (discrete outcome)

Appendix Table D15 Platelet reactivity during followup (continuous outcome)

Appendix Table D16 Quality assessment