# U.S. Food and Drug Administration Documents Reviewed

The following documents from the U.S. Food and Drug administration were reviewed for this report. They were identified though a search of the database of the 510(k) Database^†^ (1996–current) using the following stem or key words: aggreg*, PFA*, Ultegra*, Impact*, VerifyNow*, platelet*, plateletwork*, CY2C19, *2C19*, CYP2*, VASP*.

† Available at http://www.accessdata.fda.gov/scripts/cdrh/cfdocs/cfPMN/pmn.cfm; last accessed: April 25, 2012.

Appendix Table C1 U.S. Food and Drug Administration documents reviewed: type of testing, test name, and comments

Document | Test name | Comments
Genetic testing
K101683 | INFINITI CYP2C19 Assay | Population not described so document not included; however, indirect data given on limits of detection, sequencing concordance, and interlaboratory reproducibility.
K042259 | Roche AmpliChip CYP450 Test | Gene not of interest (CYPCD6).
K043576 | Amplichip CYP450 Test for CYP2C19 | Population not described so document not included; however, indirect data given on limits of detection, sensitivity and specificity, sequencing concordance, interassay agreement, comparison with a reference standard, cross-contamination, and reproducibility.
K012966 | COBAS TaqMan Analyzer | Population not described so document not included; however, indirect data given on the dynamic range, limits of detection, sensitivity, and specificity.
Phenotypic testing
K992531 | Accumetrics Ultegra System Rapid Platelet Function Assay-TRAP | Population is of interest (patients undergoing PCI [also treated with abciximab]) and reports interassay correlation. However, antiplatelet agents other than abciximab were not reported.
K011337 | Accumetrics Ultegra System Rapid Platelet Function Assay-TRAP | Population is of interest (patients undergoing PCI [also treated with abciximab]) and reports interassay correlation. However, antiplatelet agents other than abciximab were not reported.
K012701 | Accumetrics Ultegra System Rapid Platelet Function Assay-ASA | Test not of interest (measuring response to aspirin)
K013596 | Accumetrics Ultegra System Rapid Platelet Function Assay | Population is of interest (patients undergoing PCI [also treated with abciximab or eptifibatide]) and reports interassay correlation. However, antiplatelet agents other than abciximab or eptifibatide were not reported..
K060489 | Dade PFA-100 Platelet Function Analyzer Dade PFA-100 Reagents | Populations not of interest (data summarized from studies in children and in patients with bleeding disorders)
K970505 | Dade PFA-100 Platelet Function Analyzer Dade PFA Collagen/Epinephrine Test Cartridge Dade PFA Collagen/ADP Test Cartridge Dade PFA Trigger Solution | Collagen/epinephrine test not of interest. For collagen/ADP test, populations not of interest (data summarized from a study of subjects with normal platelet function or paitients with von Willebrand disease, aspirin-induced dysfunction, or Glanzmann's thromasthenia)
K002885 | Dade PFA-100 Platelet Function Analyzer Dade PFA Collagen/Epinephrine Test Cartridge Dade PFA Collagen/ADP Test Cartridge Dade PFA Trigger Solution | Collagen/epinephrine test not of interest. For collagen/ADP test, populations not of interest (data summarized from studies of healthy children, healthy adults, and children with von Willebrand disease))
K042423 | Accumetrics VerifyNow-Aspirin Assay | Test not of interest (measuring response to aspirin)
K051231 | Accumetrics VerifyNow P2Y12 Assay | Population is of interest (patients treated with clopidogrel with a history of vascular disease or risk factors) but n=10 only.
K093626 | INNOVANCE D-Dimer Assay | Population not of interest (patients presenting to emergency department with suspected deep-vein thrombosis)
K990398 | Plateletworks Platelet Aggregation Assay | Population not of interest (includes healthy volunteers)
K012723 | Collagen for Plateletworks | No data available (only approval statement is in database)
K023761 | Plateletworks | No data available (only approval statement is in database)
K061991 | Plateletworks Arachidonic Acid | Test not of interest (measuring response to arachidonic acid)
K032951 | Chrono-log Whole Blood Aggregometer, Model 591A/592A | Population not of interest (“normal, healthy, drug free subjects” or “normal donors and patients known to have von Willebrands Disease”)
K050265 | Model 700 Chrono-log Whole Blood Lumi-Aggregometer | Population not of interest (“normal, healthy, drug free subjects”)
K830749 | Chrono-log Model 560 Whole Blood Lumi-Aggregometer | No data available (no downloadable information in database)
K851025 | AGGRO/LINK Interface | No data available (no downloadable information in database)
K962426 | Chrono-log Whole Blood Aggregometer, Model 591/592 | No data available (only one-page summary is in database)
K954997 | Centocor Aggrestat, Collagen Reagent, Control Reagent | No data available (no downloadable information in database)

ASA=acetylsalicylic acid (aspirin), RPFA=rapid platelet function assay, TRAP=thrombin receptor activating peptide.