# Excluded Studies

Studies are listed in alphabetical order by first author under each main reason for exclusion (bold headings): foreign language (not English), not population of interest (usually healthy volunteers, not patients), test not used for prognosis, prediction, or decisionmaking, insufficient sample size, no primary data, not study design of interest, not test of interest, not treatment of interest, not outcome of interest. PMIDs are given, when available, at the end of each reference.

## Foreign Language

Ainetdinova DK, Udovichenko AE, Sulimov VA. Resistance to antiplatelet drugs in patients with non ST elevation acute coronary syndrome. Kardiologiia. 2008;48(6):35-39. [pmid: 18729834].
Averkov OV, Slavina NN, Gratsianskii NA. Non ST elevation acute coronary syndrome. Some characteristics of coagulation and von Willebrand factor during short term use of ticlopidine or clopidogrel. Kardiologiia. 2003;43(10):50-59. [pmid: 14593356].
Barbou F, Frere C, Hovasse T, et al. Platelet function after a high dose bolus of tirofiban immediately after coronary angioplasty. Arch Mal Coeur Vaiss. Oct. 2006;99(10):894-99. [pmid: 17100140].
Bochenek T, Wilczynski M, Wita K, et al. Evaluation of platelet response to antiplatelet drugs. An important clue for cardiologists and cardiosurgeons. Kardiol Pol. Oct. 2007;65(10):1266-69. [pmid: 17979060].
Bode C. Therapy of acute mayocardial infarction: COMMIT (Clopidogrel and Metoprolol Infarction Trial). Internist (Berl). Jul. 2006;47(7):764-66. [pmid: 16794823].
Buriachkovskaia LI, Uchitel' IA, Sumarokov AV, et al. Difficulties in evaluating the efficacy of antiplatelet therapy in clinical practice. Ter Arkh. 2009;81(5):41-47. [pmid: 19537585].
Cai J, Wu Q, Fan L, et al. Impact of different proton pump inhibitors on the antiplatelet activity of clopidogrel in combination with aspirin for patients undergoing coronary stent implantation. Zhongguo Ying Yong Sheng Li Xue Za Zhi. Aug. 2010;26(3):266-69. [pmid: 21038666].
Chen H, Yan W, Wu XY. Relationships of blood stasis syndrome, CYP2C19 gene polymorphism with clopidogrel resistance and post-PCI prognosis. Zhongguo Zhong Xi Yi Jie He Za Zhi. Dec. 2010;30(12):1245-49. [pmid: 21302482].
Chen ZQ, Hong L, Wang H. Effect of danhong injection on platelet activation and inflammatory factors in patients of acute coronary syndrome after intervention therapy. Zhongguo Zhong Xi Yi Jie He Za Zhi. Aug. 2009;29(8):692-94. [pmid: 19848198].
Cuisset T, Frere C, Quilici J, et al. Beneficial effect of a loading dose of 600 mg of clopidogrel on platelet parameters in patients admitted for acute coronary syndrome. Arch Mal Coeur Vaiss. Oct. 2006;99(10):889-93. [pmid: 17100139].
Dankovtseva EN, Sidorenko BA. The effectiveness of Ticagrelor does not depend on CYP2C19 gene polymorphism and ABCB1: results of a genetic analysis of the study PLATO. Kardiologiia. 2011;51(12):90-92. [pmid: 22304323].
De SS, Lettino M. The TRITON-TIMI 38 trial. G Ital Cardiol (Rome). Mar. 2008;9(3):149-54. [pmid: 18422094].
Eder C, Funke U, Schulze M, et al. Modified platelet aggregation test in patients on ASA and/or clopidogrel. Hamostaseologie. Aug. 2007;27(3):163-76. [pmid: 17694223].
Feher G, Bagoly E, Kover F, et al. The effect of carotid stenting on rheological parameters, free radical production and platelet aggregation. Orv Hetil. Dec. 16. 2007;148(50):2365-70. [pmid: 18055360].
Frolova NS, Shakhnovich RM, Sirotkina OV, et al. Clopidogrel resistance in patients with acute coronary syndrome. Ter Arkh. 2010;82(8):14-20. [pmid: 20873239].
Fukaya S, Iwamoto T, Kin K, et al. Factors influencing platelet function in elderly patients with chronic phase thrombotic diseases. Nihon Ronen Igakkai Zasshi. Aug. 2000;37(8):619-26. [pmid: 11086387].
Galeote G, Lopez PA, Carcamo C, et al. Variable response to the biological inhibition of platelets by abciximab in patients subjected to percutaneous coronary angioplasty. Rev Esp Cardiol. Nov. 2001;54(11):1256-63. [pmid: 11707234].
Galiavich AS, Valeeva DD, Minnetdinov RS, et al. CYP2C19 gene polymorphism in patients with myocardial infarction who use clopidogrel. Kardiologiia. 2012;52(4):20-24. [pmid: 22839512].
Gao L, Wang PP, Liu Q. Removing phlegm and dispelling stasis method combined with Western medicine for treatment of cerebrovascular stenosis. Zhongguo Zhong Xi Yi Jie He Za Zhi. Jan. 2008;28(1):28-31. [pmid: 18418965].
Grajek S. Letter to Kardiologia Polska concerning optimal treatment of myocardial infarction. Kardiol Pol. 2012;70(2):213-14. [pmid: 22427099].
Guan SY, Han YL, Li Y, et al. Effects of intensive antiplatelet therapy for patients with high on-treatment platelet reactivity after coronary stent implantation. Zhonghua Xin Xue Guan Bing Za Zhi. Jan. 2012;40(1):25-29. [pmid: 22490629].
Han YL, Su QF, Li Y, et al. The effects of post coronary stenting triple antiplatelet therapies on platelet functions. Zhonghua Nei Ke Za Zhi. Aug. 2006;45(8):635-38. [pmid: 17074146].
Han YL, Li CY, Li Y, et al. The antiplatelet effect of clopidogrel is not attenuated by statin treatment in patients with acute coronary syndromes undergone coronary stenting. Zhonghua Xin Xue Guan Bing Za Zhi. Sep. 2007;35(9):788-92. [pmid: 18070466].
Haraguchi K, Miyachi S, Izumi T, et al. Resistance to antiplatelet agents assessed by a point-of-care platelet function test and thromboembolic adverse events in neurointervention. No Shinkei Geka. May. 2012;40(5):399-406. [pmid: 22538281].
Izaguirre AR, de la PA, Gonzalez PH, et al. Efficacy of clopidogrel as ADP-dependent platelet aggregation inhibitor. Study on individuals with coronary artery disease. Arch Inst Cardiol Mex. Sep. 2000;70(5):472-80. [pmid: 11534098].
Kawamura H, Kodama H, Takeuchi G, et al. Antiplatelet therapy and platelet function studies in elderly patients with ischemic heart disease--evaluation of whole blood platelet aggregation. Rinsho Ketsueki. Oct. 1986;27(10):1815-22. [pmid: 3820607].
Khaspekova SG, Ziuriaev IT, Iakushkin VV, et al. Platelet aggregation upon acetylsalicylic acid and clopidogrel treatment and glycoprotein IIb/IIIa content in patients with acute coronary syndrome. Kardiologiia. 2011;51(7):4-7. [pmid: 21878077].
Kin K, Iwamoto T, Takasaki M. Evaluation of outcome based on platelet function in elderly patients with various diseases. Nihon Ronen Igakkai Zasshi. Jul. 2002;39(4):419-26. [pmid: 12187807].
Komarov AL, Panchenko EP, Donnikov AE, et al. Factors determining clinical effectiveness of clopidogrel and prognosis of patients with stable ischemic heart disease. Kardiologiia. 2011;51(2):8-18. [pmid: 21627593].
Kum D, Kim M, Paik J, et al. Clinical effects of additional cilostazol administration after drug-eluting stent insertion. Korean Circulation Journal. 2009;39(1):21-25.
Li Z, Liu F, Cui W, et al. Impact of application time of aspirin and clopidogrel on platelet aggregation in patients with acute coronary syndrome. Zhonghua Xin Xue Guan Bing Za Zhi. Apr. 2010;38(4):311-14. [pmid: 20654074].
Liu F, Liu JC, Wang LJ, et al. Effect of different duration of clopidogrel pretreatment on platelet activation in patients undergoing stenting. Zhonghua Wai Ke Za Zhi. Mar. 15. 2009;47(6):411-14. [pmid: 19595223].
Liu QZ, Hong T, Liu ZP, et al. The effect of different loading doses of clopidogrel on platelet aggregation. Zhonghua Nei Ke Za Zhi. Feb. 2007;46(2):107-10. [pmid: 17445432].
Loenko VB, Sorokina EA, Bobrov VS, et al. Assessing clinical efficacy of the generic clopidogrel “Egutromb” in roentgenosurgical practice. Angiol Sosud Khir. 2010;16(4):193-97. [pmid: 21389966].
Lu YL, Chen YD, Lu SZ. Effects of intensive antiplatelet therapy in patients with high platelet aggregability after percutaneous coronary intervention. Zhonghua Xin Xue Guan Bing Za Zhi. Sep. 2007;35(9):793-96. [pmid: 18070468].
Martsevich SI, Tolpygina SN, Lukina I, et al. Comparative evaluation of antiplatelet efectiveness drugs of original and reproduced enteric forms of acetylsalicylic acid (clinical study ICAR)). Kardiologiia. 2012;52(1):74-82. [pmid: 22304357].
Mase K, Yanagihara F, Asada T, et al. Evaluation of platelet aggregation test by grading curve. Rinsho Byori. Aug. 1992;40(8):857-62. [pmid: 1404959].
Meves SH, Overbeck U, Kaiser A, et al. Switching from clopidogrel hydrogen sulfate to clopidogrel besylate. Impaired antiplatelet effect in patients with ischemic stroke. Nervenarzt. Aug. 2010;81(8):992-97. [pmid: 20517690].
Miziuk VM. Effect of ivabradin and clopidogrel on platelet hemostasis indices in patients with acute coronary syndrome without ST-segment elevation and with concurrent cardiac insufficiency. Lik Sprava. Apr. 2008;(3-4):71-75. [pmid: 19145824].
Morel O, Viellard C, Faure A, et al. Platelet responsiveness to clopidogrel in patients with coronary syndrome. Comparison of platelet aggregation induced by ADP and flow cytometric analysis of intraplatelet VASP phosphorylation. Ann Cardiol Angeiol (Paris). Jan. 2007;56(1):21-29. [pmid: 17343035].
Morofuji Y, So G, Hiu T, et al. Preoperative analysis of platelet aggregability in carotid surgery. No Shinkei Geka. May. 2011;39(5):459-63. [pmid: 21512195].
Olszanska-Skorek T, Mazurowa A, Polczynska I, et al. Platelet function in patients with acute myocardial infarct following administration of acetylsalicylic acid and dipyridamole. Pol Arch Med Wewn. Feb. 1979;61(2):135-42. [pmid: 440980].
Ono K, Arimoto H, Shirotani T. Correlation between increased platelet ADP aggregability and silent brain infarcts. Brain Nerve. Feb. 2012;64(2):185-89. [pmid: 22308263].
Ouyang XL, Lin ZL, Wang HB, et al. Slide platelet aggregation test used as a monitor for patient treated with anti-pletelet drugs. Zhongguo Shi Yan Xue Ye Xue Za Zhi. Apr. 2005;13(2):309-12. [pmid: 15854298].
Pakhomov I. Comparison of effects of prasugrel and clopidogrel in patients with acute coronary syndrome, subjected to percutaneous coronary intervention: TRITON-TIMI 38 trial. Kardiologiia. 2010;50(6):63-67. [pmid: 20659030].
Piedade PR, Gagliardi RJ, Damiani IT, et al. Platelet aggregation test: application in the control of antiplatelet aggregation in the secondary prevention of stroke. Arq Neuropsiquiatr. Sep. 2003;61(3B):764-67. [pmid: 14595479].
Poponina TM, Kapilevich NA. Choosing of disaggregants for the treatment of patients with instable angina without lifting the ST segment. Klin Lab Diagn. Oct. 2004;(10):45-46. [pmid: 15584401].
Poponina TM, Kapilevich NA, Kisteneva IV, et al. Dysaggregants effect of platelet aggregation in patients with non-ST segment elevation acute coronary syndrome. Ter Arkh. 2004;76(8):18-22. [pmid: 15471389].
Ren XN, Wang LF, Wang MS, et al. Effect of early high-loading-dose tirofiban on platelet activity in patients with acute ST-segment elevation myocardial infarction undergoing primary percutaneous coronary intervention. Zhonghua Xin Xue Guan Bing Za Zhi. Feb. 2012;40(2):131-35. [pmid: 22490713].
Satoh T, Otsuka K, Sakurai I. Method of quantitative measurement of human platelet aggregation in clinical practice. Nihon Ronen Igakkai Zasshi. Oct. 1998;35(10):748-56. [pmid: 9893479].
Serebruany VL, Malinin AI, Callahan KP, et al. Statins do not affect platelet inhibition with clopidogrel during coronary stenting. Atherosclerosis. Nov. 2001;159(1):239-41. [pmid: 11689228].
Shen J, Zhang RY, Zhang Q. Impact of statins on clopidogrel platelet inhibition in patients with acute coronary syndrome or stable angina. Zhonghua Xin Xue Guan Bing Za Zhi. Sep. 2008;36(9):807-11. [pmid: 19102862].
Shimizu H, Konohana A, Tajima S, et al. Objective judgement on effects of medicine in patients with Raynaud's phenomenon--measurement of cutaneous blood flow using laser Doppler flowmeter and platelet aggregation activity. Nihon Hifuka Gakkai Zasshi. Jan. 1987;97(1):35-38. [pmid: 2952821].
Sirotkina OV, Zabotina AM, Berkovich OA, et al. Genetic variants of platelet ADP receptor P2Y12 associated with changed platelet functional activity and development of cardiovascular diseases. Genetika. Feb. 2009;45(2):247-53. [pmid: 19334620].
Slanar O, Drazd'akova M, Babiarova K, et al. Genotyping of CYP2D6 and CYP2C19. Cas Lek Cesk. 2007;146(9):708-11. [pmid: 17966194].
Slavina NN, Averkov OV, Gratsianskii NA. Indirect comparison of changes of parameters of hemostasis during short-term use of ticlopidine and clopidogrel in patients with non-ST elevation acute coronary syndrome. Kardiologiia. 2005;45(12):11-16. [pmid: 16353041].
Tang XF, He C, Yuan JQ, et al. Impact of cytochrome P450 2C19 polymorphisms on outcome of cardiovascular events in clopidogrel-treated Chinese patients after percutaneous coronary intervention. Zhonghua Xin Xue Guan Bing Za Zhi. Jul. 2011;39(7):617-20. [pmid: 22088240].
Taniguchi N, Yamauchi K, Kondo T, et al. Studies on antiplatelet therapy of low dosage of aspirin from the view point of its effect on platelet aggregation (author's transl). Nihon Ronen Igakkai Zasshi. Nov. 1981;18(6):463-68. [pmid: 7339085].
Telejko B, Zak J, Bachorzewska-Gajewska H, et al. Platelet-monocyte aggregate formation in patients with coronary heart disease and disorders of carbohydrate metabolism. Pol Arch Med Wewn. Sep. 2004;112(3):1067-73. [pmid: 15727088].
Uchiyama S, Yamazaki M, Maruyama S. Antiplatelet effect of clopidogrel. Nihon Rinsho. Feb. 1992;50(2):372-78. [pmid: 1613993].
Voskoboi IV, Rebrov AP, Kirichuk VF, et al. Lectin-induced platelet aggregation inpatients with unstable angina pectoris treated with anti-aggregation agents. Klin Med (Mosk). 2001;79(4):21-25. [pmid: 11496732].
Wang YM, Cao YJ, Liu CF, et al. The changes and effects of antiplatelet agents on platelet-leukocyte aggregation in patients with acute cerebral infarction. Zhonghua Nei Ke Za Zhi. Jul. 2007;46(7):562-65. [pmid: 17959080].
Xie Y, Liu T, Zhou YJ, et al. Effects of upstream tirofiban versus downstream tirofiban on platelet aggregation and clinical outcomes in patients with high-risk acute coronary syndromes undergoing percutaneous coronary interventions. Zhonghua Xin Xue Guan Bing Za Zhi. Jan. 2009;37(1):39-43. [pmid: 19671350].
Yasunaga K. Inhibition of platelet aggregation by platelet inhibitory agents and its relation to their clinical effects. Rinsho Byori. Suppl 40. 1979:181-87. [pmid: 551223].
Zhang Y, Liang J, Zhou YJ, et al. Study on the relationship between aspirin resistance and incidence of myonecrosis after non-emergent percutaneous coronary intervention. Zhonghua Xin Xue Guan Bing Za Zhi. Aug. 2005;33(8):695-99. [pmid: 16188050].
Zimmermann R, Lange D, Zeltsch C, et al. Significance of thrombus structure for the antithrombotic effectiveness of thrombocyte aggregation inhibiting substances and anticoagulants. Verh Dtsch Ges Inn Med. Apr. 17. 1977;83:1173-74. [pmid: 347772].
Zurn CS, Geisler T, Paterok M, et al. Influence of statins on the antiplatelet effect of clopidogrel and on cardiovascular outcome in patients after coronary intervention. Dtsch Med Wochenschr. Apr. 2008;133(16):817-22. [pmid: 18398789].

## Not Population of Interest

Altman R, Scazziota A, DE Lourdes HM, et al. Recombinant factor VIIa reverses the inhibitory effect of aspirin or aspirin plus clopidogrel on in vitro thrombin generation. J Thromb Haemost. Sep. 2006;4(9):2022-27. [pmid: 16961610].
Babcock MJ, Sane AC, Eckman DM, et al. Persistent erythema with niacin is not attributable to aspirin resistance. J Clin Lipidol. Mar. 2011;5(2):114-19. [pmid: 21392725].
Bal Dit SC, Berge N, Boval B, et al. Functional variability of platelet response to clopidogrel correlates with P2Y(12) receptor occupancy. Thromb Haemost. Jan. 2009;101(1):116-22. [pmid: 19132197].
Bal Dit SC, Berge N, Boval B, et al. Differential sensitivity and kinetics of response of different ex vivo tests monitoring functional variability of platelet response to clopidogrel. Thromb Haemost. Sep. 2010;104(3):571-81. [pmid: 20664906].
Bansal V, Fortlage D, Lee J, et al. A new clopidogrel (Plavix) point-of-care assay: rapid determination of antiplatelet activity in trauma patients. J Trauma. Jan. 2011;70(1):65-69. [pmid: 21217483].
Benzon HT, McCarthy RJ, Benzon HA, et al. Determination of residual antiplatelet activity of clopidogrel before neuraxial injections. Br J Anaesth. Dec. 2011;107(6):966-71. [pmid: 21968250].
Brandt JT, Close SL, Iturria SJ, et al. Common polymorphisms of CYP2C19 and CYP2C9 affect the pharmacokinetic and pharmacodynamic response to clopidogrel but not prasugrel. J Thromb Haemost. Dec. 2007;5(12):2429-36. [pmid: 17900275].
Butler K, Teng R. Pharmacokinetics, pharmacodynamics, safety and tolerability of multiple ascending doses of ticagrelor in healthy volunteers. Br J Clin Pharmacol. Jul. 2010;70(1):65-77. [pmid: 20642549].
Cadroy Y, Bossavy JP, Thalamas C, et al. Early potent antithrombotic effect with combined aspirin and a loading dose of clopidogrel on experimental arterial thrombogenesis in humans. Circulation. Jun. 20. 2000;101(24):2823-28. [pmid: 10859288].
Chen BL, Zhang W, Li Q, et al. Inhibition of ADP-induced platelet aggregation by clopidogrel is related to CYP2C19 genetic polymorphisms. Clin Exp Pharmacol Physiol. Aug. 2008;35(8):904-08. [pmid: 18346178].
Chen F, Maridakis V, O'neill EA, et al. A randomized clinical trial comparing point-of-care platelet function assays and bleeding time in healthy subjects treated with aspirin or clopidogrel. Platelets. 2012;23(4):249-58. [pmid: 21919555].
Chen H, Yu G, Sun H, et al. Comparison of Adjunctive Naoxintong versus Clopidogrel in Volunteers with the CYP2C19*2 Gene Mutation Accompanied with Qi Deficiency and Blood Stasis Constitution. Evid Based Complement Alternat Med. 2011;2011:207034. [pmid: 21423686].
Chung I, Choudhury A, Patel J, et al. Soluble, platelet-bound, and total P-selectin as indices of platelet activation in congestive heart failure. Ann Med. 2009;41(1):45-51. [pmid: 18618353].
Depta JP, Fowler J, Novak E, et al. Clinical outcomes using a platelet function-guided approach for secondary prevention in patients with ischemic stroke or transient ischemic attack. Stroke. Sep. 2012;43(9):2376-81. [pmid: 22713488].
Derhaschnig U, Pachinger C, Jilma B. Variable inhibition of high-shear-induced platelet plug formation by eptifibatide and tirofiban under conditions of platelet activation and high von Willebrand release: a randomized, placebo-controlled, clinical trial. Am Heart J. Apr. 2004;147(4):E17. [pmid: 15077100].
Djaffar J, I, Chamseddine N, Keleshian S, et al. Prevalence of CYP2C19 polymorphisms in the Lebanese population. Mol Biol Rep. Nov. 2011;38(8):5449-52. [pmid: 21380557].
Djukanovic N, Todorovic Z, Obradovic S, et al. Abrupt cessation of one-year clopidogrel treatment is not associated with thrombotic events. J Pharmacol Sci. 2011;117(1):12-18. [pmid: 21821970].
Dovlatova NL, Jakubowski JA, Sugidachi A, et al. The reversible P2Y antagonist cangrelor influences the ability of the active metabolites of clopidogrel and prasugrel to produce irreversible inhibition of platelet function. J Thromb Haemost. Jul. 2008;6(7):1153-59. [pmid: 18485086].
Edwards A, Jakubowski JA, Rechner AR, et al. Evaluation of the INNOVANCE PFA P2Y test cartridge: sensitivity to P2Y(12) blockade and influence of anticoagulant. Platelets. 2012;23(2):106-15. [pmid: 21848368].
Ferreiro JL, Ueno M, Capodanno D, et al. Pharmacodynamic effects of concomitant versus staggered clopidogrel and omeprazole intake: results of a prospective randomized crossover study. Circ Cardiovasc Interv. Oct. 2010;3(5):436-41. [pmid: 20858862].
Ferreiro JL, Ueno M, Tomasello SD, et al. Pharmacodynamic evaluation of pantoprazole therapy on clopidogrel effects: results of a prospective, randomized, crossover study. Circ Cardiovasc Interv. Jun. 2011;4(3):273-79. [pmid: 21521834].
Flock A, Zobel A, Bauriedel G, et al. Antiplatelet effects of antidepressant treatment: a randomized comparison between escitalopram and nortriptyline. Thromb Res. Aug. 2010;126(2):e83-e87. [pmid: 20553948].
Fontana P, Nolli S, Reber G, et al. Biological effects of aspirin and clopidogrel in a randomized cross-over study in 96 healthy volunteers. J Thromb Haemost. Apr. 2006;4(4):813-19. [pmid: 16634751].
Frelinger AL III, Li Y, Linden MD, et al. Association of cyclooxygenase-1-dependent and -independent platelet function assays with adverse clinical outcomes in aspirin-treated patients presenting for cardiac catheterization. Circulation. Dec. 22. 2009;120(25):2586-96. [pmid: 19996015].
Frelinger AL III, Barnard MR, Fox ML, et al. The Platelet Activity After Clopidogrel Termination (PACT) study. Circ Cardiovasc Interv. Oct. 2010;3(5):442-49. [pmid: 20736449].
Fuchs I, Frossard M, Spiel A, et al. Platelet function in patients with acute coronary syndrome (ACS) predicts recurrent ACS. J Thromb Haemost. Dec. 2006;4(12):2547-52. [pmid: 17002662].
Furuta T, Iwaki T, Umemura K. Influences of different proton pump inhibitors on the anti-platelet function of clopidogrel in relation to CYP2C19 genotypes. Br J Clin Pharmacol. Sep. 2010;70(3):383-92. [pmid: 20716239].
Geiger J, Teichmann L, Grossmann R, et al. Monitoring of clopidogrel action: comparison of methods. Clin Chem. Jun. 2005;51(6):957-65. [pmid: 15817818].
Gong IY, Crown N, Suen CM, et al. Clarifying the importance of CYP2C19 and PON1 in the mechanism of clopidogrel bioactivation and in vivo antiplatelet response. Eur Heart J. Nov. 2012;33(22):2856-2464a. [pmid: 22374717].
Hjorth ME, Christiansen MK, Schmidt EB, et al. Effect of exercise on platelet activation during aspirin or clopidogrel intake in healthy men. Platelets. May. 2009;20(3):177-82. [pmid: 19437335].
Hobson AR, Qureshi Z, Banks P, et al. Gender and responses to aspirin and clopidogrel: insights using short thrombelastography. Cardiovasc Ther. 2009;27(4):246-52. [pmid: 19903188].
Hobson AR, Qureshi Z, Banks P, et al. The Potential Value of Near Patient Platelet Function Testing in PCI: Randomised Comparison of 600 mg versus 900 mg Clopidogrel Loading Doses. Thrombosis. 2010;2010:908272. [pmid: 22084661].
Homoncik M, Jilma B, Hergovich N, et al. Monitoring of aspirin (ASA) pharmacodynamics with the platelet function analyzer PFA-100. Thromb Haemost. Feb. 2000;83(2):316-21. [pmid: 10739392].
Jakubowski JA, Payne CD, Li YG, et al. The use of the VerifyNow P2Y12 point-of-care device to monitor platelet function across a range of P2Y12 inhibition levels following prasugrel and clopidogrel administration. Thromb Haemost. Feb. 2008;99(2):409-15. [pmid: 18278193].
Jakubowski JA, Payne CD, Li YG, et al. A comparison of the antiplatelet effects of prasugrel and high-dose clopidogrel as assessed by VASP-phosphorylation and light transmission aggregometry. Thromb Haemost. Jan. 2008;99(1):215-22. [pmid: 18217157].
Jakubowski JA, Li YG, Small DS, et al. A comparison of the VerifyNow P2Y12 point-of-care device and light transmission aggregometry to monitor platelet function with prasugrel and clopidogrel: an integrated analysis. J Cardiovasc Pharmacol. Jul. 2010;56(1):29-37. [pmid: 20386460].
Jakubowski JA, Li YG, Small DS, et al. A Comparison of VerifyNow P2Y12 Point-of-Care Device and Light Transmission Aggregometry to Monitor Platelet Function with Prasugrel and Clopidogrel: An Integrated Analysis. J Cardiovasc Pharmacol. 2010. Mar. 24.
Jakubowski JA, Zhou C, Egan B, et al. Modification of the VerifyNow(R) P2Y12 test BASE channel to accommodate high levels of P2Y(12) antagonism. Platelets. 2011;22(8):619-25. [pmid: 21639823].
Johnson GJ, Sharda AV, Rao GH, et al. Measurement of shear-activated platelet aggregate formation in non-anticoagulated blood: utility in detection of clopidogrel-aspirin-induced platelet dysfunction. Clin Appl Thromb Hemost. Mar. 2012;18(2):140-49. [pmid: 22009986].
Kaufman JS, Fiore L, Hasbargen JA, et al. A pharmacodynamic study of clopidogrel in chronic hemodialysis patients. J Thromb Thrombolysis. Oct. 2000;10(2):127-31. [pmid: 11005934].
Keating FK, Whitaker DA, Kabbani SS, et al. Relation of augmented platelet reactivity to the magnitude of distribution of atherosclerosis. Am J Cardiol. Sep. 15. 2004;94(6):725-28. [pmid: 15374774].
Kenngott S, Olze R, Kollmer M, et al. Clopidogrel and proton pump inhibitor (PPI) interaction: separate intake and a non-omeprazole PPI the solution?. Eur J Med Res. May. 18. 2010;15(5):220-24. [pmid: 20562062].
Kim KA, Park PW, Hong SJ, et al. The effect of CYP2C19 polymorphism on the pharmacokinetics and pharmacodynamics of clopidogrel: a possible mechanism for clopidogrel resistance. Clin Pharmacol Ther. Aug. 2008;84(2):236-42. [pmid: 18323861].
Labarthe B, Theroux P, Angioi M, et al. Matching the evaluation of the clinical efficacy of clopidogrel to platelet function tests relevant to the biological properties of the drug. J Am Coll Cardiol. Aug. 16. 2005;46(4):638-45. [pmid: 16098428].
Leadbeater PD, Kirkby NS, Thomas S, et al. Aspirin has little additional anti-platelet effect in healthy volunteers receiving prasugrel. J Thromb Haemost. Oct. 2011;9(10):2050-56. [pmid: 21794076].
Lee CC, McMillin GA, Babic N, et al. Evaluation of a CYP2C19 genotype panel on the GenMark eSensor(R) platform and the comparison to the Autogenomics Infiniti and Luminex CYP2C19 panels. Clin Chim Acta. May. 12. 2011;412(11-12):1133-37. [pmid: 21385571].
Lee W, Suh JW, Yang HM, et al. Celecoxib does not attenuate the antiplatelet effects of aspirin and clopidogrel in healthy volunteers. Korean Circ J. Jul. 2010;40(7):321-27. [pmid: 20664740].
Lee YW, Cho YH, Kim YH, et al. Aspirin non-responsiveness in Korean subjects on dual anti-platelet treatment determined by two different platelet function assays. Ann Clin Lab Sci. 2008;38(2):126-31. [pmid: 18469357].
Li YG, Ni L, Brandt JT, et al. Inhibition of platelet aggregation with prasugrel and clopidogrel: an integrated analysis in 846 subjects. Platelets. Aug. 2009;20(5):316-27. [pmid: 19637095].
Lin PC, Jones SO, McGlasson DL. Effects of glucosamine and Celadrin on platelet function. Clin Lab Sci. 2010;23(1):32-36. [pmid: 20218092].
Litos IK, Emmanouilidou E, Glynou KM, et al. Rapid genotyping of CYP2D6, CYP2C19 and TPMT polymorphisms by primer extension reaction in a dipstick format. Anal Bioanal Chem. Nov. 2007;389(6):1849-57. [pmid: 17909762].
Mach F, Senouf D, Fontana P, et al. Not all statins interfere with clopidogrel during antiplatelet therapy. Eur J Clin Invest. Aug. 2005;35(8):476-81. [pmid: 16101667].
Mahmud E, Cavendish JJ, Tsimikas S, et al. Elevated plasma fibrinogen level predicts suboptimal response to therapy with both single-and double-bolus eptifibatide during percutaneous coronary intervention. J Am Coll Cardiol. Jun. 5. 2007;49(22):2163-71. [pmid: 17543636].
Makkar RR, Eigler NL, Kaul S, et al. Effects of clopidogrel, aspirin and combined therapy in a porcine ex vivo model of high-shear induced stent thrombosis. Eur Heart J. Oct. 1998;19(10):1538-46. [pmid: 9820993].
Marton Z, Horvath B, Alexy T, et al. Follow-up of hemorheological parameters and platelet aggregation in patients with acute coronary syndromes. Clin Hemorheol Microcirc. 2003;29(2):81-94. [pmid: 14610303].
Muller A, Octavio J, Gonzalez MY, et al. Clinical bioequivalence of a dose of clopidogrel Leti Cravid tablets 75 mg versus clopidogrel Sanofi Plavix tablets 75 mg administered on a daily dose for 7 days on healthy volunteers: a clinical trial. Am J Ther. May. 2010;17(3):351-56. [pmid: 20019589].
Neubauer H, Kruger JC, Lask S, et al. Comparing the antiplatelet effect of clopidogrel hydrogensulfate and clopidogrel besylate: a crossover study. Clin Res Cardiol. Sep. 2009;98(9):533-40. [pmid: 19504141].
Ostrowsky J, Foes J, Warchol M, et al. Plateletworks platelet function test compared to the thromboelastograph for prediction of postoperative outcomes. J Extra Corpor Technol. Jun. 2004;36(2):149-52. [pmid: 15334755].
Orford JL, Kinlay S, Adams MR, et al. Clopidogrel inhibits shear-induced platelet function. Platelets. May. 2002;13(3):187-89. [pmid: 12180502].
Pasquali SK, Yow E, Jennings LK, et al. Platelet activity associated with concomitant use of clopidogrel and proton pump inhibitors in children with cardiovascular disease. Congenit Heart Dis. Nov. 2010;5(6):552-55. [pmid: 21106014].
Patti G, Nusca A. Influence of platelet reactivity on outcome of patients with acute myocardial infarction undergoing primary angioplasty. Circ J. 2011;75(9):2050-51. [pmid: 21817805].
Penz SM, Bernlochner I, Toth O, et al. Selective and rapid monitoring of dual platelet inhibition by aspirin and P2Y12 antagonists by using multiple electrode aggregometry. Thromb J. 2010;8:9. [pmid: 20465804].
Pittens CA, Bouman HJ, van Werkum JW, et al. Comparison between hirudin and citrate in monitoring the inhibitory effects of P2Y12 receptor antagonists with different platelet function tests. J Thromb Haemost. Nov. 2009;7(11):1929-32. [pmid: 19691484].
Preisman S, Kogan A, Itzkovsky K, et al. Modified thromboelastography evaluation of platelet dysfunction in patients undergoing coronary artery surgery. Eur J Cardiothorac Surg. Jun. 2010;37(6):1367-74. [pmid: 20181490].
Price MJ, Coleman JL, Steinhubl SR, et al. Onset and offset of platelet inhibition after high-dose clopidogrel loading and standard daily therapy measured by a point-of-care assay in healthy volunteers. Am J Cardiol. Sep. 1. 2006;98(5):681-84. [pmid: 16923461].
Price MJ, Teirstein PS. Dynamics of platelet functional recovery following a clopidogrel loading dose in healthy volunteers. Am J Cardiol. Sep. 15. 2008;102(6):790-95. [pmid: 18774008].
Pulley JM, Denny JC, Peterson JF, et al. Operational implementation of prospective genotyping for personalized medicine: the design of the Vanderbilt PREDICT project. Clin Pharmacol Ther. Jul. 2012;92(1):87-95. [pmid: 22588608].
Przyklenk K, Whittaker P. In vitro platelet responsiveness to adenosine-mediated “preconditioning” is age-dependent. J Thromb Thrombolysis. Feb. 2005;19(1):5-10. [pmid: 15976961].
Reece MJ, Klein AA, Salviz EA, et al. Near-patient platelet function testing in patients undergoing coronary artery surgery: a pilot study. Anaesthesia. Feb. 2011;66(2):97-103. [pmid: 21254984].
Roald HE, Barstad RM, Kierulf P, et al. Clopidogrel--a platelet inhibitor which inhibits thrombogenesis in non-anticoagulated human blood independently of the blood flow conditions. Thromb Haemost. May. 1994;71(5):655-62. [pmid: 8091395].
Saucedo JF, Lui HK, Garza L, et al. Comparative pharmacodynamic evaluation of eptifibatide and abciximab in patients with non-ST-segment elevation acute coronary syndromes: the TAM2 study. J Thromb Thrombolysis. Oct. 2004;18(2):67-74. [pmid: 15789173].
Schneider DJ, Baumann PQ, Whitaker DA, et al. Variation in the ability of glycoprotein IIb-IIIa antagonists to exert and maintain their inhibitory effects on the binding of fibrinogen. J Cardiovasc Pharmacol. Jul. 2005;46(1):41-45. [pmid: 15965353].
Schwarz UR, Geiger J, Walter U, et al. Flow cytometry analysis of intracellular VASP phosphorylation for the assessment of activating and inhibitory signal transduction pathways in human platelets--definition and detection of ticlopidine/clopidogrel effects. Thromb Haemost. Sep. 1999;82(3):1145-52. [pmid: 10494779].
Scott SA, Martis S, Peter I, et al. Identification of CYP2C19*4B: pharmacogenetic implications for drug metabolism including clopidogrel responsiveness. Pharmacogenomics J. Aug. 2012;12(4):297-305. [pmid: 21358751].
Serebruany VL, Malinin AI, Jerome SD, et al. Effects of clopidogrel and aspirin combination versus aspirin alone on platelet aggregation and major receptor expression in patients with heart failure: the Plavix Use for Treatment Of Congestive Heart Failure (PLUTO-CHF) trial. Am Heart J. Oct. 2003;146(4):713-20. [pmid: 14564328].
Sevcikova H, Vojacek J, Bis J, et al. Good short-term but not long-term reproducibility of the antiplatelet efficacy laboratory assessment. Clin Appl Thromb Hemost. Mar. 2012;18(2):174-80. [pmid: 21949037].
Seyfert UT, Haubelt H, Vogt A, et al. Variables influencing Multiplate(TM) whole blood impedance platelet aggregometry and turbidimetric platelet aggregation in healthy individuals. Platelets. May. 2007;18(3):199-206. [pmid: 17497431].
Shaffer KE, Pearman DT, Galen RS, et al. A rapid platelet function assay used to regulate platelet transfusion prophylaxis following cardiopulmonary bypass surgery. J Extra Corpor Technol. Jun. 2004;36(2):145-48. [pmid: 15334754].
Shim CY, Park S, Song JW, et al. Comparison of effects of two different formulations of clopidogrel bisulfate tablets on platelet aggregation and bleeding time in healthy Korean volunteers: A single-dose, randomized, open-label, 1-week, two-period, phase IV crossover study. Clin Ther. Aug. 2010;32(9):1664-73. [pmid: 20974324].
Small DS, Farid NA, Li YG, et al. Effect of ranitidine on the pharmacokinetics and pharmacodynamics of prasugrel and clopidogrel. Curr Med Res Opin. Aug. 2008;24(8):2251-57. [pmid: 18786302].
Small DS, Wrishko RE, Ernest CS, et al. Effect of age on the pharmacokinetics and pharmacodynamics of prasugrel during multiple dosing: an open-label, single-sequence, clinical trial. Drugs Aging. 2009;26(9):781-90. [pmid: 19728751].
Small DS, Payne CD, Kothare P, et al. Pharmacodynamics and pharmacokinetics of single doses of prasugrel 30 mg and clopidogrel 300 mg in healthy Chinese and white volunteers: an open-label trial. Clin Ther. Feb. 2010;32(2):365-79. [pmid: 20206794].
Spiel AO, Frossard M, Mayr FB, et al. Pronounced platelet hyperfunction in patients with cardiac arrest achieving restoration of spontaneous circulation. Crit Care Med. Mar. 2009;37(3):975-79. [pmid: 19237906].
Steinhubl SR, Talley JD, Braden GA, et al. Point-of-care measured platelet inhibition correlates with a reduced risk of an adverse cardiac event after percutaneous coronary intervention: results of the GOLD (AU-Assessing Ultegra) multicenter study. Circulation. May. 29. 2001;103(21):2572-78. [pmid: 11382726].
Strom CM, Goos D, Crossley B, et al. Testing for variants in CYP2C19: Population frequencies and testing experience in a clinical laboratory. Genet Med. 2011. Oct. 7.
Strom CM, Goos D, Crossley B, et al. Testing for variants in CYP2C19: population frequencies and testing experience in a clinical laboratory. Genet Med. Jan. 2012;14(1):95-100. [pmid: 22237437].
Swallow RA, Agarwala RA, Dawkins KD, et al. Thromboelastography: potential bedside tool to assess the effects of antiplatelet therapy?. Platelets. Sep. 2006;17(6):385-92. [pmid: 16973499].
Tang YD, Rinder HM, Katz SD. Effects of recombinant human erythropoietin on antiplatelet action of aspirin and clopidogrel in healthy subjects: results of a double-blind, placebo-controlled randomized trial. Am Heart J. Sep. 2007;154(3):494-97. [pmid: 17719296].
Tazaki J, Jinnai T, Tada T, et al. Prediction of clopidogrel low responders by a rapid CYP2C19 activity test. J Atheroscler Thromb. 2012;19(2):186-93. [pmid: 22166969].
Temesvari M, Paulik J, Kobori L, et al. High-resolution melting curve analysis to establish CYP2C19 *2 single nucleotide polymorphism: Comparison with hydrolysis SNP analysis. Mol Cell Probes. Apr. 2011;25(2-3):130-33. [pmid: 21315147].
Toth O, Calatzis A, Penz S, et al. Multiple electrode aggregometry: a new device to measure platelet aggregation in whole blood. Thromb Haemost. Dec. 2006;96(6):781-88. [pmid: 17139373].
Uotani T, Sugimoto M, Nishino M, et al. Ability of rabeprazole to prevent gastric mucosal damage from clopidogrel and low doses of aspirin depends on CYP2C19 genotype. Clin Gastroenterol Hepatol. Aug. 2012;10(8):879-85. [pmid: 22542748].
van Gestel MA, Heemskerk JW, Slaaf DW, et al. In vivo blockade of platelet ADP receptor P2Y12 reduces embolus and thrombus formation but not thrombus stability. Arterioscler Thromb Vasc Biol. Mar. 1. 2003;23(3):518-23. [pmid: 12615691].
Vilahur G, Choi BG, Zafar MU, et al. Normalization of platelet reactivity in clopidogrel-treated subjects. J Thromb Haemost. Jan. 2007;5(1):82-90. [pmid: 17239165].
Weerakkody GJ, Jakubowski JA, Brandt JT, et al. Greater inhibition of platelet aggregation and reduced response variability with prasugrel versus clopidogrel: an integrated analysis. J Cardiovasc Pharmacol Ther. Sep. 2007;12(3):205-12. [pmid: 17875947].
Weerakkody GJ, Brandt JT, Payne CD, et al. Clopidogrel poor responders: an objective definition based on Bayesian classification. Platelets. Sep. 2007;18(6):428-35. [pmid: 17763152].
Weerakkody GJ, Jakubowski JA, Brandt JT, et al. Comparison of speed of onset of platelet inhibition after loading doses of clopidogrel versus prasugrel in healthy volunteers and correlation with responder status. Am J Cardiol. Jul. 15. 2007;100(2):331-36. [pmid: 17631093].
Wheeler GL, Braden GA, Steinhubl SR, et al. The Ultegra rapid platelet-function assay: comparison to standard platelet function assays in patients undergoing percutaneous coronary intervention with abciximab therapy. Am Heart J. Apr. 2002;143(4):602-11. [pmid: 11923796].
Xie HG. Genetic variations of S-mephenytoin 4'-hydroxylase (CYP2C19) in the Chinese population. Life Sci. Feb. 25. 2000;66(14):L175-L181. [pmid: 10755474].
Yamanouchi J, Hato T, Niiya T, et al. Vasodilator-stimulated phosphoprotein (VASP) phosphorylation assay for platelet response to cilostazol. Platelets. 2011;22(2):135-42. [pmid: 21158496].
Yeung J, Apopa PL, Vesci J, et al. Protein kinase C regulation of 12-lipoxygenase-mediated human platelet activation. Mol Pharmacol. Mar. 2012;81(3):420-30. [pmid: 22155783].
Yousef AM, Arafat T, Bulatova NR, et al. Smoking behaviour modulates pharmacokinetics of orally administered clopidogrel. J Clin Pharm Ther. Aug. 2008;33(4):439-49. [pmid: 18613862].
Yun KH, Rhee SJ, Park HY, et al. Effects of omeprazole on the antiplatelet activity of clopidogrel. Int Heart J. Jan. 2010;51(1):13-16. [pmid: 20145345].
Zhao L, Bath P, Heptinstall S. Effects of combining three different antiplatelet agents on platelets and leukocytes in whole blood in vitro. Br J Pharmacol. Sep. 2001;134(2):353-58. [pmid: 11564653].

## Test Not Used for Prognosis, Prediction, or Decisionmaking

Abuzahra M, Pillai M, Caldera A, et al. Comparison of higher clopidogrel loading and maintenance dose to standard dose on platelet function and outcomes after percutaneous coronary intervention using drug-eluting stents. Am J Cardiol. Aug. 15. 2008;102(4):401-03. [pmid: 18678295].
Addad F, Chakroune T, Asma A, et al. Clopidogrel but not Aspirin prevents acute smoking-induced platelet aggregation in patients with stable coronary artery disease. Thromb Res. Feb. 2009;123(4):640-43. [pmid: 18602138].
Ades PA, Savage PD, Toth MJ, et al. The influence of obesity and consequent insulin resistance on coronary risk factors in medically treated patients with coronary disease. Int J Obes (Lond). Jun. 2008;32(6):967-74. [pmid: 18268512].
Ahn SG, Lee SH, Sung JK, et al. Intra-individual variability of residual platelet reactivity assessed by the VerifyNow-P2Y12 assay in patients with clopidogrel resistance after percutaneous coronary intervention. Platelets. 2011;22(4):305-07. [pmid: 21480769].
Ahn SG, Lee SH, Sung JK, et al. Intra-individual variability of residual platelet reactivity assessed by the VerifyNow-P2Y12 assay in patients with clopidogrel resistance after percutaneous coronary intervention. Platelets. 2011;22(4):305-07. [pmid: 21480769].
Ajzenberg N, Aubry P, Huisse MG, et al. Enhanced shear-induced platelet aggregation in patients who experience subacute stent thrombosis: a case-control study. J Am Coll Cardiol. Jun. 7. 2005;45(11):1753-56. [pmid: 15936600].
Akowuah E, Shrivastava V, Jamnadas B, et al. Comparison of two strategies for the management of antiplatelet therapy during urgent surgery. Ann Thorac Surg. Jul. 2005;80(1):149-52. [pmid: 15975358].
Aleil B, Meyer N, Cazenave JP, et al. High stability of blood samples for flow cytometric analysis of VASP phosphorylation to measure the clopidogrel responsiveness in patients with coronary artery disease. Thromb Haemost. Oct. 2005;94(4):886-87. [pmid: 16270649].
Aleil B, Ravanat C, Cazenave JP, et al. Flow cytometric analysis of intraplatelet VASP phosphorylation for the detection of clopidogrel resistance in patients with ischemic cardiovascular diseases. J Thromb Haemost. Jan. 2005;3(1):85-92. [pmid: 15634270].
Alexopoulos D, Xanthopoulou I, Tsigkas G, et al. Predictors of high on-treatment platelet reactivity early after clopidogrel loading in ST-elevation myocardial infarction. Circ J. 2012;76(9):2183-87. [pmid: 22664584].
Alstrom U, Tyden H, Oldgren J, et al. The platelet inhibiting effect of a clopidogrel bolus dose in patients on long-term acetylsalicylic acid treatment. Thromb Res. 2007;120(3):353-59. [pmid: 17137616].
Althoff TF, Fischer M, Langer E, et al. Sustained enhancement of residual platelet reactivity after coronary stenting in patients with myocardial infarction compared to elective patients. Thromb Res. May. 2010;125(5):e190-e196. [pmid: 20116087].
Altman R, Rivas AJ, Gonzalez CD. Bleeding tendency in dual antiplatelet therapy with aspirin/clopidogrel: rescue of the template bleeding time in a single-center prospective study. Thromb J. 2012;10(1):3. [pmid: 22236361].
Anand SX, Kim MC, Kamran M, et al. Comparison of platelet function and morphology in patients undergoing percutaneous coronary intervention receiving bivalirudin versus unfractionated heparin versus clopidogrel pretreatment and bivalirudin. Am J Cardiol. Aug. 1. 2007;100(3):417-24. [pmid: 17659921].
Ancrenaz V, Desmeules J, James R, et al. The paraoxonase-1 pathway is not a major bioactivation pathway of clopidogrel in vitro. Br J Pharmacol. Aug. 2012;166(8):2362-70. [pmid: 22428615].
Ang L, Palakodeti V, Khalid A, et al. Elevated plasma fibrinogen and diabetes mellitus are associated with lower inhibition of platelet reactivity with clopidogrel. J Am Coll Cardiol. Sep. 23. 2008;52(13):1052-59. [pmid: 18848137].
Angiolillo DJ, Badimon JJ, Saucedo JF, et al. A pharmacodynamic comparison of prasugrel vs. high-dose clopidogrel in patients with type 2 diabetes mellitus and coronary artery disease: results of the Optimizing anti-Platelet Therapy In diabetes MellitUS (OPTIMUS)-3 Trial. Eur Heart J. Apr. 2011;32(7):838-46. [pmid: 21252171].
Angiolillo DJ, Bernardo E, Capodanno D, et al. Impact of chronic kidney disease on platelet function profiles in diabetes mellitus patients with coronary artery disease taking dual antiplatelet therapy. J Am Coll Cardiol. Mar. 16. 2010;55(11):1139-46. [pmid: 20223369].
Angiolillo DJ, Bernardo E, Palazuelos J, et al. Functional impact of high clopidogrel maintenance dosing in patients undergoing elective percutaneous coronary interventions. Results of a randomized study. Thromb Haemost. Jan. 2008;99(1):161-68. [pmid: 18217149].
Angiolillo DJ, Bernardo E, Ramirez C, et al. Insulin therapy is associated with platelet dysfunction in patients with type 2 diabetes mellitus on dual oral antiplatelet treatment. J Am Coll Cardiol. Jul. 18. 2006;48(2):298-304. [pmid: 16843179].
Angiolillo DJ, Capranzano P, Ferreiro JL, et al. Impact of adjunctive cilostazol therapy on platelet function profiles in patients with and without diabetes mellitus on aspirin and clopidogrel therapy. Thromb Haemost. Aug. 2011;106(2):253-62. [pmid: 21614414].
Angiolillo DJ, Capranzano P, Goto S, et al. A randomized study assessing the impact of cilostazol on platelet function profiles in patients with diabetes mellitus and coronary artery disease on dual antiplatelet therapy: results of the OPTIMUS-2 study. Eur Heart J. Sep. 2008;29(18):2202-11. [pmid: 18567918].
Angiolillo DJ, Fernandez-Ortiz A, Bernardo E, et al. 807 C/T Polymorphism of the glycoprotein Ia gene and pharmacogenetic modulation of platelet response to dual antiplatelet treatment. Blood Coagul Fibrinolysis. Jul. 2004;15(5):427-33. [pmid: 15205592].
Angiolillo DJ, Fernandez-Ortiz A, Bernardo E, et al. Clopidogrel withdrawal is associated with proinflammatory and prothrombotic effects in patients with diabetes and coronary artery disease. Diabetes. Mar. 2006;55(3):780-84. [pmid: 16505243].
Angiolillo DJ, Fernandez-Ortiz A, Bernardo E, et al. High clopidogrel loading dose during coronary stenting: effects on drug response and interindividual variability. Eur Heart J. Nov. 2004;25(21):1903-10. [pmid: 15522469].
Angiolillo DJ, Fernandez-Ortiz A, Bernardo E, et al. Identification of low responders to a 300-mg clopidogrel loading dose in patients undergoing coronary stenting. Thromb Res. 2005;115(1-2):101-08. [pmid: 15567460].
Angiolillo DJ, Fernandez-Ortiz A, Bernardo E, et al. Influence of aspirin resistance on platelet function profiles in patients on long-term aspirin and clopidogrel after percutaneous coronary intervention. Am J Cardiol. Jan. 1. 2006;97(1):38-43. [pmid: 16377281].
Angiolillo DJ, Fernandez-Ortiz A, Bernardo E, et al. Is a 300 mg clopidogrel loading dose sufficient to inhibit platelet function early after coronary stenting? A platelet function profile study. J Invasive Cardiol. Jun. 2004;16(6):325-29. [pmid: 15156004].
Angiolillo DJ, Fernandez-Ortiz A, Bernardo E, et al. PlA polymorphism and platelet reactivity following clopidogrel loading dose in patients undergoing coronary stent implantation. Blood Coagul Fibrinolysis. Jan. 2004;15(1):89-93. [pmid: 15166949].
Angiolillo DJ, Fernandez-Ortiz A, Bernardo E, et al. Platelet aggregation according to body mass index in patients undergoing coronary stenting: should clopidogrel loading-dose be weight adjusted?. J Invasive Cardiol. Apr. 2004;16(4):169-74. [pmid: 15152138].
Angiolillo DJ, Fernandez-Ortiz A, Bernardo E, et al. Platelet function profiles in patients with type 2 diabetes and coronary artery disease on combined aspirin and clopidogrel treatment. Diabetes. Aug. 2005;54(8):2430-35. [pmid: 16046311].
Angiolillo DJ, Fernandez-Ortiz A, Bernardo E, et al. Variability in platelet aggregation following sustained aspirin and clopidogrel treatment in patients with coronary heart disease and influence of the 807 C/T polymorphism of the glycoprotein Ia gene. Am J Cardiol. Oct. 15. 2005;96(8):1095-99. [pmid: 16214444].
Angiolillo DJ, Firstenberg MS, Price MJ, et al. Bridging antiplatelet therapy with cangrelor in patients undergoing cardiac surgery: a randomized controlled trial. JAMA. Jan. 18. 2012;307(3):265-74. [pmid: 22253393].
Angiolillo DJ, Saucedo JF, Deraad R, et al. Increased platelet inhibition after switching from maintenance clopidogrel to prasugrel in patients with acute coronary syndromes: results of the SWAP (SWitching Anti Platelet) study. J Am Coll Cardiol. Sep. 21. 2010;56(13):1017-23. [pmid: 20846599].
Angiolillo DJ, Schneider DJ, Bhatt DL, et al. Pharmacodynamic effects of cangrelor and clopidogrel: the platelet function substudy from the cangrelor versus standard therapy to achieve optimal management of platelet inhibition (CHAMPION) trials. J Thromb Thrombolysis. Jul. 2012;34(1):44-55. [pmid: 22569899].
Angiolillo DJ, Shoemaker SB, Desai B, et al. Randomized comparison of a high clopidogrel maintenance dose in patients with diabetes mellitus and coronary artery disease: results of the Optimizing Antiplatelet Therapy in Diabetes Mellitus (OPTIMUS) study. Circulation. Feb. 13. 2007;115(6):708-16. [pmid: 17261652].
Angiolillo DJ, Welsh RC, Trenk D, et al. Pharmacokinetic and pharmacodynamic effects of elinogrel: results of the platelet function substudy from the intravenous and oral administration of elinogrel to evaluate tolerability and efficacy in nonurgent percutaneous coronary intervention patients (INNOVATE-PCI) trial. Circ Cardiovasc Interv. Jun. 2012;5(3):347-56. [pmid: 22619259].
Antman EM, Wiviott SD, Murphy SA, et al. Early and late benefits of prasugrel in patients with acute coronary syndromes undergoing percutaneous coronary intervention: a TRITON-TIMI 38 (TRial to Assess Improvement in Therapeutic Outcomes by Optimizing Platelet InhibitioN with Prasugrel-Thrombolysis In Myocardial Infarction) analysis. J Am Coll Cardiol. May. 27. 2008;51(21):2028-33. [pmid: 18498956].
Aradi D, Vorobcsuk A, Lenkey Z, et al. Low platelet disaggregation predicts poor response to 150 mg clopidogrel in patients with elevated platelet reactivity. Platelets. 2010;21(1):1-10. [pmid: 19929306].
Arai T, Kawamura A, Matsubara Y, et al. Effect of chronic kidney disease on platelet reactivity to dual-antiplatelet therapy in patients treated with drug-eluting stents. Heart Vessels. Sep. 2012;27(5):480-85. [pmid: 21837496].
Arzamendi D, Dandachli F, Theoret JF, et al. An anti-von Willebrand factor aptamer reduces platelet adhesion among patients receiving aspirin and clopidogrel in an ex vivo shear-induced arterial thrombosis. Clin Appl Thromb Hemost. Nov. 2011;17(6):E70-E78. [pmid: 21078615].
Ashraf T, Ahmed M, Talpur MS, et al. Competency profile of locally manufactured clopidogrel Lowplat and foreign manufactured clopidogrel Plavix in patients of suspected ischemic heart disease (CLAP-IHD). J Pak Med Assoc. Oct. 2005;55(10):443-48. [pmid: 16304854].
Attar S, McLaughlin JS, Masaitis C. Clinical application of platelet aggregation. South Med J. Apr. 1973;66(4):481-85. [pmid: 4708247].
Attisani M, Centofanti P, La TM, et al. Safety and effectiveness of low dosing of double antiplatelet therapy during long-term left ventricular support with the INCOR system. J Artif Organs. Dec. 2010;13(4):202-06. [pmid: 21127929].
Awidi A, Saleh A, Dweik M, et al. Measurement of platelet reactivity of patients with cardiovascular disease on-treatment with acetyl salicylic acid: a prospective study. Heart Vessels. Sep. 2011;26(5):516-22. [pmid: 21181173].
Azcona L, Lopez Farre AJ, Jimenez Mateos-Caceres P, et al. Impact of clopidogrel and aspirin treatment on the expression of proteins in platelets from type-2 diabetic patients with stable coronary ischemia. J Pharm Sci. Aug. 2012;101(8):2821-32. [pmid: 22614874].
Bal Dit SC, Crassard I, Simoneau G, et al. Effect of the thromboxane prostaglandin receptor antagonist terutroban on arterial thrombogenesis after repeated administration in patients treated for the prevention of ischemic stroke. Cerebrovasc Dis. 2009;28(5):505-13. [pmid: 19752552].
Barilla F, Pulcinelli FM, Mangieri E, et al. Clopidogrel plus indobufen in acute coronary syndrome patients with hypersensitivity to aspirin undergoing percutaneous coronary intervention. Platelets. 2013;24(3):183-88. [pmid: 22646157].
Batchelor WB, Tolleson TR, Huang Y, et al. Randomized COMparison of platelet inhibition with abciximab, tiRofiban and eptifibatide during percutaneous coronary intervention in acute coronary syndromes: the COMPARE trial. Comparison Of Measurements of Platelet aggregation with Aggrastat, Reopro, and Eptifibatide. Circulation. Sep. 17. 2002;106(12):1470-76. [pmid: 12234950].
Bauriedel G, Skowasch D, Schneider M, et al. Antiplatelet effects of angiotensin-converting enzyme inhibitors compared with aspirin and clopidogrel: a pilot study with whole-blood aggregometry. Am Heart J. Feb. 2003;145(2):343-48. [pmid: 12595854].
Behan MW, Fox SC, Heptinstall S, et al. Inhibitory effects of P2Y12 receptor antagonists on TRAP-induced platelet aggregation, procoagulant activity, microparticle formation and intracellular calcium responses in patients with acute coronary syndromes. Platelets. Mar. 2005;16(2):73-80. [pmid: 15823862].
Beigel R, Hod H, Fefer P, et al. Relation of aspirin failure to clinical outcome and to platelet response to aspirin in patients with acute myocardial infarction. Am J Cardiol. Feb. 1. 2011;107(3):339-42. [pmid: 21256995].
Beres BJ, Toth-Zsamboki E, Vargova K, et al. Analysis of platelet alpha2-adrenergic receptor activity in stable coronary artery disease patients on dual antiplatelet therapy. Thromb Haemost. Nov. 2008;100(5):829-38. [pmid: 18989527].
Bernlochner I, Morath T, Brown PB, et al. A prospective randomized trial comparing the recovery of platelet function after loading dose administration of prasugrel or clopidogrel. Platelets. 2013;24(1):15-25. [pmid: 22372531].
Bernlochner I, Steinhubl S, Braun S, et al. Association between inflammatory biomarkers and platelet aggregation in patients under chronic clopidogrel treatment. Thromb Haemost. Dec. 2010;104(6):1193-200. [pmid: 20838744].
Bigalke B, Geisler T, Stellos K, et al. Platelet collagen receptor glycoprotein VI as a possible novel indicator for the acute coronary syndrome. Am Heart J. Jul. 2008;156(1):193-200. [pmid: 18585516].
Bilsel T, Akbulut T, Yesilcimen K, et al. Single high-dose bolus tirofiban with high-loading-dose clopidogrel in primary coronary angioplasty. Heart Vessels. Mar. 2006;21(2):102-07. [pmid: 16550311].
Bonello L, Berbis J, Laine M, et al. Biological efficacy of a 600 mg loading dose of clopidogrel in ST-elevation myocardial infarction. Thromb Haemost. Jul. 2012;108(1):101-06. [pmid: 22535315].
Bonello L, Paganelli F, gnat-George F, et al. Two strategies of clopidogrel loading dose to decrease the frequency of clopidogrel resistance in patients undergoing percutaneous coronary intervention. Thromb Res. 2008;122(2):285-88. [pmid: 18093637].
Boneu B, Destelle G. Platelet anti-aggregating activity and tolerance of clopidogrel in atherosclerotic patients. Thromb Haemost. Dec. 1996;76(6):939-43. [pmid: 8972014].
Borsiczky B, Sarszegi Z, Konyi A, et al. The effect of clopidogrel besylate and clopidogrel hydrogensulfate on platelet aggregation in patients with coronary artery disease: a retrospective study. Thromb Res. Jun. 2012;129(6):700-03. [pmid: 21924759].
Bouman HJ, van Werkum JW, Hackeng CM, et al. Cangrelor increases the magnitude of platelet inhibition and reduces interindividual variability in clopidogrel-pretreated subjects. Neth Heart J. May. 2009;17(5):195-98. [pmid: 19484155].
Brackbill ML, Kidd RS, Abdoo AD, et al. Frequency of CYP3A4, CYP3A5, CYP2C9, and CYP2C19 variant alleles in patients receiving clopidogrel that experience repeat acute coronary syndrome. Heart Vessels. Mar. 2009;24(2):73-78. [pmid: 19337788].
Braun OO, Amisten S, Wihlborg AK, et al. Residual platelet ADP reactivity after clopidogrel treatment is dependent on activation of both the unblocked P2Y(1) and the P2Y (12) receptor and is correlated with protein expression of P2Y (12). Purinergic Signal. Jun. 2007;3(3):195-201. [pmid: 18404433].
Braun OO, Johnell M, Varenhorst C, et al. Greater reduction of platelet activation markers and platelet-monocyte aggregates by prasugrel compared to clopidogrel in stable coronary artery disease. Thromb Haemost. Oct. 2008;100(4):626-33. [pmid: 18841285].
Breet NJ, van Donkersgoed HE, van Werkum JW, et al. Is platelet inhibition due to thienopyridines increased in elderly patients, in patients with previous stroke and patients with low body weight as a possible explanation of an increased bleeding risk?. Neth Heart J. Jun. 2011;19(6):279-84. [pmid: 21494888].
Brizzio ME, Shaw RE, Bosticco B, et al. Use of an objective tool to assess platelet inhibition prior to off-pump coronary surgery to reduce blood usage. J Invasive Cardiol. Feb. 2012;24(2):49-52. [pmid: 22294531].
Buch AN, Singh S, Roy P, et al. Measuring aspirin resistance, clopidogrel responsiveness, and postprocedural markers of myonecrosis in patients undergoing percutaneous coronary intervention. Am J Cardiol. Jun. 1. 2007;99(11):1518-22. [pmid: 17531573].
Burgstahler C, Geisler T, Lindemann S, et al. Elevated coronary calcium scores are associated with higher residual platelet aggregation after clopidogrel treatment in patients with stable angina pectoris. Int J Cardiol. Jun. 12. 2009;135(1):132-35. [pmid: 18606468].
Campbell CL, Berger PB, Nuttall GA, et al. Can N-acetylcysteine reverse the antiplatelet effects of clopidogrel? An in vivo and vitro study. Am Heart J. Oct. 2005;150(4):796-99. [pmid: 16209984].
Campo G, Ferraresi P, Marchesini J, et al. Relationship between paraoxonase Q192R gene polymorphism and on-clopidogrel platelet reactivity over time in patients treated with percutaneous coronary intervention. J Thromb Haemost. Oct. 2011;9(10):2106-08. [pmid: 21819538].
Campo G, Valgimigli M, Gemmati D, et al. Value of platelet reactivity in predicting response to treatment and clinical outcome in patients undergoing primary coronary intervention: insights into the STRATEGY Study. J Am Coll Cardiol. Dec. 5. 2006;48(11):2178-85. [pmid: 17161242].
Cao YJ, Wang YM, Zhang J, et al. The effects of antiplatelet agents on platelet-leukocyte aggregations in patients with acute cerebral infarction. J Thromb Thrombolysis. Feb. 2009;27(2):233-38. [pmid: 18188511].
Cassar K, Bachoo P, Ford I, et al. Variability in responsiveness to clopidogrel in patients with intermittent claudication. Eur J Vasc Endovasc Surg. Jul. 2006;32(1):71-75. [pmid: 16549375].
Cassar K, Ford I, Greaves M, et al. Randomized clinical trial of the antiplatelet effects of aspirin-clopidogrel combination versus aspirin alone after lower limb angioplasty. Br J Surg. Feb. 2005;92(2):159-65. [pmid: 15609386].
Casterella PJ, Kereiakes DJ, Steinhubl SR, et al. The platelet function dose-response to abciximab during percutaneous coronary revascularization is variable. Catheter Cardiovasc Interv. Dec. 2001;54(4):497-504. [pmid: 11747189].
Cha JK, Jeong MH, Lee KM, et al. Changes in platelet P-selectin and in plasma C-reactive protein in acute atherosclerotic ischemic stroke treated with a loading dose of clopidogrel. J Thromb Thrombolysis. Oct. 2002;14(2):145-50. [pmid: 12714834].
Cho JH, Jeong YH, Ahn YJ, et al. The impact of smoking on post-clopidogrel platelet reactivity in patients with acute myocardial infarction. Korean Circ J. Mar. 2010;40(3):119-24. [pmid: 20339496].
Chyrchel B, Surdacki A, Chyrchel M, et al. Separate dosing of clopidogrel and omeprazole may improve platelet inhibition on dual antiplatelet therapy. Int J Cardiol. May. 19. 2011;149(1):124-25. [pmid: 21345502].
Claeys MJ, Van der Planken MG, Bosmans JM, et al. Does pre-treatment with aspirin and loading dose clopidogrel obviate the need for glycoprotein IIb/IIIa antagonists during elective coronary stenting? A focus on peri-procedural myonecrosis. Eur Heart J. Mar. 2005;26(6):567-75. [pmid: 15618034].
Claeys MJ, Van der Planken MG, Michiels JJ, et al. Comparison of antiplatelet effect of loading dose of clopidogrel versus abciximab during coronary intervention. Blood Coagul Fibrinolysis. Jun. 2002;13(4):283-88. [pmid: 12032392].
Comparative 30-day economic and clinical outcomes of platelet glycoprotein IIb/IIIa inhibitor use during elective percutaneous coronary intervention: Prairie ReoPro versus Integrilin Cost Evaluation (PRICE) Trial. Am Heart J. Mar. 2001;141(3):402-09. [pmid: 11231437].
Craft RM, Chavez JJ, Snider CC, et al. Comparison of modified Thrombelastograph and Plateletworks whole blood assays to optical platelet aggregation for monitoring reversal of clopidogrel inhibition in elective surgery patients. J Lab Clin Med. Jun. 2005;145(6):309-15. [pmid: 15976759].
Cuisset T, Frere C, Moro PJ, et al. Lack of effect of chronic kidney disease on clopidogrel response with high loading and maintenance doses of clopidogrel after Acute Coronary Syndrome. Thromb Res. Nov. 2010;126(5):e400-e402. [pmid: 20828794].
Dalby M, Montalescot G, Bal Dit SC, et al. Eptifibatide provides additional platelet inhibition in non-ST-elevation myocardial infarction patients already treated with aspirin and clopidogrel. Results of the platelet activity extinction in non-Q-wave myocardial infarction with aspirin, clopidogrel, and eptifibatide (PEACE) study. J Am Coll Cardiol. Jan. 21. 2004;43(2):162-68. [pmid: 14736431].
Danzi GB, Capuano C, Sesana M, et al. Variability in extent of platelet function inhibition after administration of optimal dose of glycoprotein IIb/IIIa receptor blockers in patients undergoing a high-risk percutaneous coronary intervention. Am J Cardiol. Feb. 15. 2006;97(4):489-93. [pmid: 16461043].
David JL, Limet R. Antiplatelet activity of clopidogrel in coronary artery bypass graft surgery patients. Thromb Haemost. Nov. 1999;82(5):1417-21. [pmid: 10595630].
Denninger MH, Necciari J, Serre-Lacroix E, et al. Clopidogrel antiplatelet activity is independent of age and presence of atherosclerosis. Semin Thromb Hemost. Suppl 2. 1999;25:41-45. [pmid: 10440422].
Deray G, Bagnis C, Brouard R, et al. Clopidogrel activities in patients with renal function impairment. Clin Drug Investig. 1998;16(4):319-28. [pmid: 18370553].
Desch S, Siegemund A, Scholz U, et al. Platelet inhibition and GP IIb/IIIa receptor occupancy by intracoronary versus intravenous bolus administration of abciximab in patients with ST-elevation myocardial infarction. Clin Res Cardiol. Feb. 2012;101(2):117-24. [pmid: 22015616].
Di SG, Patti G, Pasceri V, et al. Effectiveness of in-laboratory high-dose clopidogrel loading versus routine pre-load in patients undergoing percutaneous coronary intervention: results of the ARMYDA-5 PRELOAD (Antiplatelet therapy for Reduction of MYocardial Damage during Angioplasty) randomized trial. J Am Coll Cardiol. Aug. 10. 2010;56(7):550-57. [pmid: 20688209].
Diego A, de Prado AP, Cuellas C, et al. P2Y12 platelet reactivity after thrombolytic therapy for ST-segment elevation myocardial infarction. Thromb Res. Sep. 2012;130(3):e31-e36. [pmid: 22704077].
Diehl P, Halscheid C, Olivier C, et al. Discontinuation of long term clopidogrel therapy induces platelet rebound hyperaggregability between 2 and 6 weeks post cessation. Clin Res Cardiol. Sep. 2011;100(9):765-71. [pmid: 21479772].
Diehl P, Olivier C, Halscheid C, et al. Clopidogrel affects leukocyte dependent platelet aggregation by P2Y12 expressing leukocytes. Basic Res Cardiol. May. 2010;105(3):379-87. [pmid: 19943165].
Dorr G, Schmidt G, Grafe M, et al. Effects of combined therapy with clopidogrel and acetylsalicylic acid on platelet glycoprotein expression and aggregation. J Cardiovasc Pharmacol. Apr. 2002;39(4):523-32. [pmid: 11904526].
Drosch T, Brodoefel H, Geisler T, et al. Plaque distribution in clopidogrel responders and low responders as determined by multislice computed tomography. Tex Heart Inst J. 2010;37(5):547-52. [pmid: 20978565].
Duerschmied D, Ahrens I, Mauler M, et al. Serotonin antagonism improves platelet inhibition in clopidogrel low-responders after coronary stent placement: an in vitro pilot study. PLoS One. 2012;7(2):e32656. [pmid: 22384279].
Eikelboom JW, Hankey GJ, Thom J, et al. Enhanced antiplatelet effect of clopidogrel in patients whose platelets are least inhibited by aspirin: a randomized crossover trial. J Thromb Haemost. Dec. 2005;3(12):2649-55. [pmid: 16359503].
Elsenberg EH, van Werkum JW, van de Wal RM, et al. The influence of clinical characteristics, laboratory and inflammatory markers on ‘high on-treatment platelet reactivity’ as measured with different platelet function tests. Thromb Haemost. Oct. 2009;102(4):719-27. [pmid: 19806258].
Ernst NM, Suryapranata H, Miedema K, et al. Achieved platelet aggregation inhibition after different antiplatelet regimens during percutaneous coronary intervention for ST-segment elevation myocardial infarction. J Am Coll Cardiol. Sep. 15. 2004;44(6):1187-93. [pmid: 15364318].
Etz C, Welp H, Rothenburger M, et al. Analysis of platelet function during left ventricular support with the Incor and Excor system. Heart Surg Forum. 2004;7(5):E423-E427. [pmid: 15799917].
Fateh-Moghadam S, Htun P, Tomandl B, et al. Hyperresponsiveness of platelets in ischemic stroke. Thromb Haemost. Jun. 2007;97(6):974-78. [pmid: 17549300].
Fatini C, Sticchi E, Bolli P, et al. eNOS gene influences platelet phenotype in acute coronary syndrome patients on dual antiplatelet treatment. Platelets. Dec. 2009;20(8):548-54. [pmid: 19891529].
Fatini C, Sticchi E, Bolli P, et al. Platelet aggregability is modulated by eNOS locus in non-type 2 diabetic patients with acute coronary syndrome. Nutr Metab Cardiovasc Dis. Jan. 2011;21(1):11-17. [pmid: 19819117].
Feher G, Koltai K, Alkonyi B, et al. Clopidogrel resistance: role of body mass and concomitant medications. Int J Cardiol. Aug. 21. 2007;120(2):188-92. [pmid: 17169448].
Ferreiro JL, Ueno M, Desai B, et al. Impact of adjunctive cilostazol therapy versus high maintenance dose of clopidogrel in suboptimal responders with diabetes mellitus. Rev Esp Cardiol (Engl Ed). Jan. 2012;65(1):105-06. [pmid: 21783310].
Flierl U, Fraccarollo D, Lausenmeyer E, et al. Fractalkine activates a signal transduction pathway similar to P2Y12 and is associated with impaired clopidogrel responsiveness. Arterioscler Thromb Vasc Biol. Aug. 2012;32(8):1832-40. [pmid: 22652599].
Fong J, Cheng-Ching E, Hussain MS, et al. Predictors of biochemical aspirin and clopidogrel resistance in patients with ischemic stroke. J Stroke Cerebrovasc Dis. May. 2011;20(3):227-30. [pmid: 20621513].
Fontana P, Berdague P, Castelli C, et al. Clinical predictors of dual aspirin and clopidogrel poor responsiveness in stable cardiovascular patients from the ADRIE study. J Thromb Haemost. Dec. 2010;8(12):2614-23. [pmid: 20860677].
Fontes-Carvalho R, Albuquerque A, Araujo C, et al. Omeprazole, but not pantoprazole, reduces the antiplatelet effect of clopidogrel: a randomized clinical crossover trial in patients after myocardial infarction evaluating the clopidogrel-PPIs drug interaction. Eur J Gastroenterol Hepatol. May. 2011;23(5):396-404. [pmid: 21464720].
Forbes CD, Lowe GD, MacLaren M, et al. Clopidogrel compatibility with concomitant cardiac co-medications: a study of its interactions with a beta-blocker and a calcium uptake antagonist. Semin Thromb Hemost. Suppl 2. 1999;25:55-60. [pmid: 10440425].
Fox SC, May JA, Shah A, et al. Measurement of platelet P-selectin for remote testing of platelet function during treatment with clopidogrel and/or aspirin. Platelets. Jun. 2009;20(4):250-59. [pmid: 19440925].
Frelinger AL III, Michelson AD, Wiviott SD, et al. Intrinsic platelet reactivity before P2Y12 blockade contributes to residual platelet reactivity despite high-level P2Y12 blockade by prasugrel or high-dose clopidogrel. Results from PRINCIPLE-TIMI 44. Thromb Haemost. Aug. 2011;106(2):219-26. [pmid: 21713327].
Freynhofer MK, Bruno V, Willheim M, et al. Vasodilator-stimulated phosphoprotein-phosphorylation assay in patients on clopidogrel: does standardisation matter?. Thromb Haemost. Mar. 2012;107(3):538-44. [pmid: 22274403].
Fu Q, Yokoyama N, Takada K, et al. Comparison of platelet P2Y(12) ADP receptor-mediated pathway inhibition in triple versus dual antiplatelet therapy as assessed by VASP-phosphorylation in Japanese patients undergoing coronary stenting. Int Heart J. 2010;51(5):303-07. [pmid: 20966600].
Fu XH, Hao QQ, Jia XW, et al. Effect of tirofiban plus clopidogrel and aspirin on primary percutaneous coronary intervention via transradial approach in patients with acute myocardial infarction. Chin Med J (Engl ). Mar. 20. 2008;121(6):522-27. [pmid: 18364139].
Fukuoka T, Furuya D, Takeda H, et al. Evaluation of clopidogrel resistance in ischemic stroke patients. Intern Med. 2011;50(1):31-35. [pmid: 21212570].
Fukushima K, Kobayashi Y, Kitahara H, et al. Antiplatelet effect of 50-mg maintenance dose of clopidogrel compared to 200 mg ticlopidine: a preliminary study. Heart Vessels. Jan. 2010;25(1):41-44. [pmid: 20091397].
Fukushima K, Kobayashi Y, Kitahara H, et al. Effect of 150-mg vs 300-mg loading doses of clopidogrel on platelet function in Japanese patients undergoing coronary stent placement. Circ J. Aug. 2008;72(8):1282-84. [pmid: 18654014].
Fukushima K, Kobayashi Y, Kitahara H, et al. Effect of 450-mg loading dose of clopidogrel on platelet function in Japanese patients undergoing coronary stent placement. Heart Vessels. May. 2010;25(3):182-86. [pmid: 20512444].
Furman MI, Kereiakes DJ, Krueger LA, et al. Leukocyte-platelet aggregation, platelet surface P-selectin, and platelet surface glycoprotein IIIa after percutaneous coronary intervention: Effects of dalteparin or unfractionated heparin in combination with abciximab. Am Heart J. Nov. 2001;142(5):790-98. [pmid: 11685164].
Furman MI, Kereiakes DJ, Krueger LA, et al. Quantification of abciximab-induced platelet inhibition is assay dependent: a comparative study in patients undergoing percutaneous coronary intervention. Am Heart J. Feb. 2003;145(2):e6. [pmid: 12595861].
Gaglia MA Jr., Torguson R, Pakala R, et al. Relation of body mass index to on-treatment (clopidogrel + aspirin) platelet reactivity. Am J Cardiol. Sep. 15. 2011;108(6):766-71. [pmid: 21752347].
Gajos G, Rostoff P, Undas A, et al. Effects of polyunsaturated omega-3 fatty acids on responsiveness to dual antiplatelet therapy in patients undergoing percutaneous coronary intervention: the OMEGA-PCI (OMEGA-3 fatty acids after pci to modify responsiveness to dual antiplatelet therapy) study. J Am Coll Cardiol. Apr. 20. 2010;55(16):1671-78. [pmid: 20394870].
Gajos G, Rostoff P, Undas A, et al. Effects of polyunsaturated omega-3 fatty acids on responsiveness to dual antiplatelet therapy in patients undergoing percutaneous coronary intervention: the OMEGA-PCI (OMEGA-3 fatty acids after pci to modify responsiveness to dual antiplatelet therapy) study. J Am Coll Cardiol. Apr. 20. 2010;55(16):1671-78. [pmid: 20394870].
Gao P, Xiong H, Zheng Z, et al. Evaluation of antiplatelet effects of a modified protocol by platelet aggregation in patients undergoing “one-stop” hybrid coronary revascularization. Platelets. 2010;21(3):183-90. [pmid: 20201634].
Garcia-Rinaldi R, Carro-Pagan C, Schaff HV, et al. Initial experience with dual antiplatelet thromboprophylaxis using clopidogrel and aspirin in patients with mechanical aortic prostheses. J Heart Valve Dis. Nov. 2009;18(6):617-25. [pmid: 20099710].
Gawaz M, Seyfarth M, Muller I, et al. Comparison of effects of clopidogrel versus ticlopidine on platelet function in patients undergoing coronary stent placement. Am J Cardiol. Feb. 1. 2001;87(3):332-6. A9. [pmid: 11165971].
Geara AS, Ayoub I, Abi RJ, et al. Does hemodialysis affect clopidogrel resistance as measured by VerifyNow P2Y12 test?. Am J Cardiol. Apr. 1. 2011;107(7):1103-04. [pmid: 21419895].
Geisler T, Anders N, Paterok M, et al. Platelet response to clopidogrel is attenuated in diabetic patients undergoing coronary stent implantation. Diabetes Care. Feb. 2007;30(2):372-74. [pmid: 17259513].
Geisler T, Kapp M, Gohring-Frischholz K, et al. Residual platelet activity is increased in clopidogrel- and ASA-treated patients with coronary stenting for acute coronary syndromes compared with stable coronary artery disease. Heart. Jun. 2008;94(6):743-47. [pmid: 17567647].
Geisler T, Zurn C, Paterok M, et al. Statins do not adversely affect post-interventional residual platelet aggregation and outcomes in patients undergoing coronary stenting treated by dual antiplatelet therapy. Eur Heart J. Jul. 2008;29(13):1635-43. [pmid: 18503057].
Gilard M, Arnaud B, Cornily JC, et al. Influence of omeprazole on the antiplatelet action of clopidogrel associated with aspirin: the randomized, double-blind OCLA (Omeprazole CLopidogrel Aspirin) study. J Am Coll Cardiol. Jan. 22. 2008;51(3):256-60. [pmid: 18206732].
Gilard M, Arnaud B, Le GG, et al. Influence of omeprazol on the antiplatelet action of clopidogrel associated to aspirin. J Thromb Haemost. Nov. 2006;4(11):2508-09. [pmid: 16898956].
Gladding P, Webster M, Zeng I, et al. The antiplatelet effect of higher loading and maintenance dose regimens of clopidogrel: the PRINC (Plavix Response in Coronary Intervention) trial. JACC Cardiovasc Interv. Dec. 2008;1(6):612-19. [pmid: 19463374].
Gorchakova O, von BN, Gawaz M, et al. Antiplatelet effects of a 600 mg loading dose of clopidogrel are not attenuated in patients receiving atorvastatin or simvastatin for at least 4 weeks prior to coronary artery stenting. Eur Heart J. Nov. 2004;25(21):1898-902. [pmid: 15522468].
Gori AM, Cesari F, Marcucci R, et al. The balance between pro- and anti-inflammatory cytokines is associated with platelet aggregability in acute coronary syndrome patients. Atherosclerosis. Jan. 2009;202(1):255-62. [pmid: 18486134].
Graff J, Harder S, Wahl O, et al. Anti-inflammatory effects of clopidogrel intake in renal transplant patients: effects on platelet-leukocyte interactions, platelet CD40 ligand expression, and proinflammatory biomarkers. Clin Pharmacol Ther. Nov. 2005;78(5):468-76. [pmid: 16321613].
Grdinic A, Vojvodic D, Djukanovic N, et al. PCI and clopidogrel: antiplatelet responsiveness and patient characteristics. Acta Cardiol. Jun. 2011;66(3):333-40. [pmid: 21744703].
Gremmel T, Kopp CW, Steiner S, et al. The P-selectin gene Pro715 allele and low levels of soluble P-selectin are associated with reduced P2Y12 adenosine diphosphate receptor reactivity in clopidogrel-treated patients. Atherosclerosis. Jul. 2011;217(1):135-38. [pmid: 21497813].
Gremmel T, Steiner S, Seidinger D, et al. Calcium-channel blockers decrease clopidogrel-mediated platelet inhibition. Heart. Feb. 2010;96(3):186-89. [pmid: 19687016].
Grossmann R, Sokolova O, Schnurr A, et al. Variable extent of clopidogrel responsiveness in patients after coronary stenting. Thromb Haemost. Dec. 2004;92(6):1201-06. [pmid: 15583724].
Guha S, Mookerjee S, Guha P, et al. Antiplatelet drug resistance in patients with recurrent acute coronary syndrome undergoing conservative management. Indian Heart J. Jul. 2009;61(4):348-52. [pmid: 20635737].
Guha S, Sardar P, Guha P, et al. Dual antiplatelet drug resistance in patients with acute coronary syndrome. Indian Heart J. Jan. 2009;61(1):68-73. [pmid: 19729693].
Guha S, Sardar P, Guha P, et al. Dual antiplatelet therapy in ACS: time-dependent variability in platelet aggregation during the first week. Indian Heart J. Mar. 2009;61(2):173-77. [pmid: 20039503].
Gurbel PA, Bliden KP, Etherington A, et al. Assessment of clopidogrel responsiveness: measurements of maximum platelet aggregation, final platelet aggregation and their correlation with vasodilator-stimulated phosphoprotein in resistant patients. Thromb Res. 2007;121(1):107-15. [pmid: 17400283].
Gurbel PA, Bliden KP, Guyer K, et al. Delayed thrombin-induced platelet-fibrin clot generation by clopidogrel: a new dose-related effect demonstrated by thrombelastography in patients undergoing coronary artery stenting. Thromb Res. 2007;119(5):563-70. [pmid: 16806409].
Gurbel PA, Bliden KP, Hayes KM, et al. The relation of dosing to clopidogrel responsiveness and the incidence of high post-treatment platelet aggregation in patients undergoing coronary stenting. J Am Coll Cardiol. May. 3. 2005;45(9):1392-96. [pmid: 15862408].
Gurbel PA, Bliden KP, Hiatt BL. The early antiplatelet effects of clopidogrel loading for coronary stenting and the long-term stability of inhibition. J Thromb Haemost. Jun. 2003;1(6):1319-21. [pmid: 12871340].
Gurbel PA, Bliden KP, Saucedo JF, et al. Bivalirudin and clopidogrel with and without eptifibatide for elective stenting: effects on platelet function, thrombelastographic indexes, and their relation to periprocedural infarction results of the CLEAR PLATELETS-2 (Clopidogrel with Eptifibatide to Arrest the Reactivity of Platelets) study. J Am Coll Cardiol. Feb. 24. 2009;53(8):648-57. [pmid: 19232896].
Gurbel PA, Bliden KP, Tantry US. Effect of clopidogrel with and without eptifibatide on tumor necrosis factor-alpha and C-reactive protein release after elective stenting: results from the CLEAR PLATELETS 1b study. J Am Coll Cardiol. Dec. 5. 2006;48(11):2186-91. [pmid: 17161243].
Gurbel PA, Bliden KP, Zaman KA, et al. Clopidogrel loading with eptifibatide to arrest the reactivity of platelets: results of the Clopidogrel Loading With Eptifibatide to Arrest the Reactivity of Platelets (CLEAR PLATELETS) study. Circulation. Mar. 8. 2005;111(9):1153-59. [pmid: 15738352].
Gurbel PA, Bliden KP. A new method of representing drug-induced platelet inhibition: better description of time course, response variability, non-response, and heightened activity. Platelets. Nov. 2003;14(7-8):481-83. [pmid: 14713517].
Gurbel PA, Bliden KP. Interpretation of platelet inhibition by clopidogrel and the effect of non-responders. J Thromb Haemost. Jun. 2003;1(6):1318-19. [pmid: 12871339].
Gurbel PA, Cummings CC, Bell CR, et al. Onset and extent of platelet inhibition by clopidogrel loading in patients undergoing elective coronary stenting: the Plavix Reduction Of New Thrombus Occurrence (PRONTO) trial. Am Heart J. Feb. 2003;145(2):239-47. [pmid: 12595840].
Gurbel PA, Malinin AI, Callahan KP, et al. Effect of loading with clopidogrel at the time of coronary stenting on platelet aggregation and glycoprotein IIb/IIIa expression and platelet-leukocyte aggregate formation. Am J Cardiol. Aug. 1. 2002;90(3):312-15. [pmid: 12127620].
Guthikonda S, Alviar CL, Vaduganathan M, et al. Role of reticulated platelets and platelet size heterogeneity on platelet activity after dual antiplatelet therapy with aspirin and clopidogrel in patients with stable coronary artery disease. J Am Coll Cardiol. Aug. 26. 2008;52(9):743-49. [pmid: 18718422].
Hafizullah M. Comparison of loading dose of 300mg versus 600mg of clopidogrel on platelet aggregtion in patients with coronary artery disease. Pakistan Heart Journal. 2006;39(3-4).
Harmsze AM, Robijns K, van Werkum JW, et al. The use of amlodipine, but not of P-glycoprotein inhibiting calcium channel blockers is associated with clopidogrel poor-response. Thromb Haemost. May. 2010;103(5):920-25. [pmid: 20352154].
Harmsze AM, van Werkum JW, Moral F, et al. Sulfonylureas and on-clopidogrel platelet reactivity in type 2 diabetes mellitus patients. Platelets. 2011;22(2):98-102. [pmid: 21142408].
Helft G, Osende JI, Worthley SG, et al. Acute antithrombotic effect of a front-loaded regimen of clopidogrel in patients with atherosclerosis on aspirin. Arterioscler Thromb Vasc Biol. Oct. 2000;20(10):2316-21. [pmid: 11031221].
Helgason CM, Grossi E, Pandey D, et al. Platelet aggregation and recruitment with aspirin-clopidogrel therapy. Cerebrovasc Dis. 2008;25(5):392-400. [pmid: 18349532].
Herrmann HC, Swierkosz TA, Kapoor S, et al. Comparison of degree of platelet inhibition by abciximab versus tirofiban in patients with unstable angina pectoris and non-Q-wave myocardial infarction undergoing percutaneous coronary intervention. Am J Cardiol. Jun. 1. 2002;89(11):1293-97. [pmid: 12031731].
Hezard N, Metz D, Garnotel R, et al. Platelet VASP phosphorylation assessment in clopidogrel-treated patients: lack of agreement between Western blot and flow cytometry. Platelets. Dec. 2005;16(8):474-81. [pmid: 16323337].
Hobson AR, Petley GW, Dawkins KD, et al. A novel fifteen minute test for assessment of individual time-dependent clotting responses to aspirin and clopidogrel using modified thrombelastography. Platelets. Nov. 2007;18(7):497-505. [pmid: 17957565].
Hobson AR, Qureshi Z, Banks P, et al. Effects of clopidogrel on “aspirin specific” pathways of platelet inhibition. Platelets. Sep. 2009;20(6):386-90. [pmid: 19811222].
Hobson AR, Qureshi Z, Banks P, et al. The Potential Value of Near Patient Platelet Function Testing in PCI: Randomised Comparison of 600 mg versus 900 mg Clopidogrel Loading Doses. Thrombosis. 2010;2010:908272. [pmid: 22084661].
Hochholzer W, Trenk D, Frundi D, et al. Time dependence of platelet inhibition after a 600-mg loading dose of clopidogrel in a large, unselected cohort of candidates for percutaneous coronary intervention. Circulation. May. 24. 2005;111(20):2560-64. [pmid: 15809367].
Hogberg C, Gidlof O, Deflorian F, et al. Farnesyl pyrophosphate is an endogenous antagonist to ADP-stimulated P2Y(1)(2) receptor-mediated platelet aggregation. Thromb Haemost. Jul. 2012;108(1):119-32. [pmid: 22628078].
Hong SJ, Park JY, Kim KA, et al. Comparison of low vs moderate dose of atorvastatin in clopidogrel resistance after coronary stenting in Korean patients with acute coronary syndrome. Circ J. Jun. 2009;73(6):1111-18. [pmid: 19372620].
Huczek Z, Filipiak KJ, Kochman J, et al. Baseline platelet size is increased in patients with acute coronary syndromes developing early stent thrombosis and predicts future residual platelet reactivity. A case-control study. Thromb Res. May. 2010;125(5):406-12. [pmid: 19786298].
Husted S, Emanuelsson H, Heptinstall S, et al. Pharmacodynamics, pharmacokinetics, and safety of the oral reversible P2Y12 antagonist AZD6140 with aspirin in patients with atherosclerosis: a double-blind comparison to clopidogrel with aspirin. Eur Heart J. May. 2006;27(9):1038-47. [pmid: 16476694].
Husted SE, Storey RF, Bliden K, et al. Pharmacokinetics and pharmacodynamics of ticagrelor in patients with stable coronary artery disease: results from the ONSET-OFFSET and RESPOND studies. Clin Pharmacokinet. Jun. 1. 2012;51(6):397-409. [pmid: 22515556].
Ignjatovic VS, Petrovic N, Miloradovic V, et al. The influence of bisoprolol dose on ADP-induced platelet aggregability in patients on dual antiplatelet therapy. Coron Artery Dis. Dec. 2010;21(8):472-76. [pmid: 20861734].
Inami N, Nomura S, Kajiura T, et al. Significance of alpha(IIb)beta(3) in subacute stent thrombosis after percutaneous coronary intervention. Clin Appl Thromb Hemost. Oct. 2005;11(4):455-59. [pmid: 16244772].
Isordia-Salas I, Olalde-Roman MJ, Santiago-German D, et al. The impact of CYP3A5*1/*3, PIA1/A2 and T744C polymorphisms on clopidogrel and acetylsalicylic acid response variability in Mexican population. Thromb Res. Sep. 2012;130(3):e67-e72. [pmid: 22819265].
Ivandic BT, Giannitsis E, Schlick P, et al. Determination of aspirin responsiveness by use of whole blood platelet aggregometry. Clin Chem. Apr. 2007;53(4):614-19. [pmid: 17332149].
Ivandic BT, Kurz K, Keck F, et al. Tirofiban optimizes platelet inhibition for immediate percutaneous coronary intervention in high-risk acute coronary syndromes. Thromb Haemost. Oct. 2008;100(4):648-54. [pmid: 18841288].
Ivandic BT, Schlick P, Staritz P, et al. Determination of clopidogrel resistance by whole blood platelet aggregometry and inhibitors of the P2Y12 receptor. Clin Chem. Mar. 2006;52(3):383-88. [pmid: 16423907].
Izaguirre-Avila R, De lP-D, Barinagarrementeria-Aldatz F, et al. Effect of clopidogrel on platelet aggregation and plasma concentration of fibrinogen in subjects with cerebral or coronary atherosclerotic disease. Clin Appl Thromb Hemost. Apr. 2002;8(2):169-77. [pmid: 12121059].
Jagroop IA, Matsagas MI, Geroulakos G, et al. The effect of clopidogrel, aspirin and both antiplatelet drugs on platelet function in patients with peripheral arterial disease. Platelets. Mar. 2004;15(2):117-25. [pmid: 15154604].
Jain R, Sood J. Antiplatelet therapy in patients with coronary artery stents for noncardiac surgery: Role of thromboelastography. J Anaesthesiol Clin Pharmacol. Oct. 2011;27(4):537-40. [pmid: 22096292].
Jaremo P, Lindahl TL, Fransson SG, et al. Individual variations of platelet inhibition after loading doses of clopidogrel. J Intern Med. Sep. 2002;252(3):233-38. [pmid: 12270003].
Jeon HW, Cha JK. Factors related to progression of middle cerebral artery stenosis determined using transcranial Doppler ultrasonograhy. J Thromb Thrombolysis. Jun. 2008;25(3):265-69. [pmid: 17541765].
Jeong YH, Bliden KP, Antonino MJ, et al. Usefulness of the VerifyNow P2Y12 assay to evaluate the antiplatelet effects of ticagrelor and clopidogrel therapies. Am Heart J. Jul. 2012;164(1):35-42. [pmid: 22795280].
Jeong YH, Cho JH, Kang MK, et al. Smoking at least 10 cigarettes per day increases platelet inhibition by clopidogrel in patients with ST-segment-elevation myocardial infarction. Thromb Res. Oct. 2010;126(4):e334-e338. [pmid: 20451242].
Jeong YH, Hwang JY, Kim IS, et al. Adding cilostazol to dual antiplatelet therapy achieves greater platelet inhibition than high maintenance dose clopidogrel in patients with acute myocardial infarction: Results of the adjunctive cilostazol versus high maintenance dose clopidogrel in patients with AMI (ACCEL-AMI) study. Circ Cardiovasc Interv. Feb. 1. 2010;3(1):17-26. [pmid: 20118150].
Jeong YH, Koh JS, Kang MK, et al. The impact of generic clopidogrel bisulfate on platelet inhibition in patients with coronary artery stents: results of the ACCEL-GENERIC study. Korean J Intern Med. Jun. 2010;25(2):154-61. [pmid: 20526388].
Jeong YH, Lee SW, Choi BR, et al. Randomized comparison of adjunctive cilostazol versus high maintenance dose clopidogrel in patients with high post-treatment platelet reactivity: results of the ACCEL-RESISTANCE (Adjunctive Cilostazol Versus High Maintenance Dose Clopidogrel in Patients With Clopidogrel Resistance) randomized study. J Am Coll Cardiol. Mar. 31. 2009;53(13):1101-09. [pmid: 19324253].
Jeong YH, Park Y, Bliden KP, et al. High platelet reactivity to multiple agonists during aspirin and clopidogrel treatment is indicative of a global hyperreactive platelet phenotype. Heart. Feb. 2012;98(4):343-44. [pmid: 22076014].
Jeong YH, Park Y, Kim IS, et al. Enhanced platelet inhibition by adjunctive cilostazol to dual antiplatelet therapy after drug-eluting stent implantation for complex lesions. Thromb Haemost. Dec. 2010;104(6):1286-89. [pmid: 20838742].
Jernberg T, Payne CD, Winters KJ, et al. Prasugrel achieves greater inhibition of platelet aggregation and a lower rate of non-responders compared with clopidogrel in aspirin-treated patients with stable coronary artery disease. Eur Heart J. May. 2006;27(10):1166-73. [pmid: 16621870].
Jin EZ, Yu LH, Li XQ. Loading effect of 200 mg cilostazol on platelet inhibition in patients undergoing percutaneous coronary intervention. Int Heart J. 2012;53(1):1-4. [pmid: 22398668].
Judge HM, Patil SB, Buckland RJ, et al. Potentiation of clopidogrel active metabolite formation by rifampicin leads to greater P2Y12 receptor blockade and inhibition of platelet aggregation after clopidogrel. J Thromb Haemost. Aug. 2010;8(8):1820-27. [pmid: 20492465].
Kafian S, Mobarrez F, Kalani M, et al. Comparison of venous and arterial blood sampling for the assessment of platelet aggregation with whole blood impedance aggregometry. Scand J Clin Lab Invest. Dec. 2011;71(8):637-40. [pmid: 21870998].
Kamath S, Blann AD, Chin BS, et al. A prospective randomized trial of aspirin-clopidogrel combination therapy and dose-adjusted warfarin on indices of thrombogenesis and platelet activation in atrial fibrillation. J Am Coll Cardiol. Aug. 7. 2002;40(3):484-90. [pmid: 12142115].
Kar R, Meena A, Yadav BK, et al. Clopidogrel resistance in North Indian patients of coronary artery disease and lack of its association with platelet ADP receptors P2Y1 and P2Y12 gene polymorphisms. Platelets. 2013;24(4):297-302. [pmid: 22721490].
Karlsson F, Modica A, Mooe T. Association of level of kidney function and platelet aggregation in acute myocardial infarction. Am J Kidney Dis. Aug. 2009;54(2):262-69. [pmid: 19560852].
Kastrati A, von BN, Joost A, et al. Loading with 600 mg clopidogrel in patients with coronary artery disease with and without chronic clopidogrel therapy. Circulation. Oct. 5. 2004;110(14):1916-19. [pmid: 15262828].
Khan NA, Peterson JF. A surveillance tool to support quality assurance and research in personalized medicine. AMIA Annu Symp Proc. 2011;2011:701-08. [pmid: 22195126].
Khan SB, Hameedullah, Noor L, et al. Comparison of effect of locally available brands of clopidogrel on platelet aggregation in patients with coronary artery disease. J Ayub Med Coll Abbottabad. Jan. 2010;22(1):115-17. [pmid: 21409920].
Kim GB, Kim JK, Park S, et al. Effect of atorvastatin and clopidogrel co-administration after coronary stenting in korean patients with stable angina. Korean Circ J. Jan. 2011;41(1):28-33. [pmid: 21359066].
Kim H, Lee HK, Han K, et al. Prevalence and risk factors for aspirin and clopidogrel resistance in patients with coronary artery disease or ischemic cerebrovascular disease. Ann Clin Lab Sci. 2009;39(3):289-94. [pmid: 19667414].
Kim JY, Lee K, Shin M, et al. Cilostazol could ameliorate platelet responsiveness to clopidogrel in patients undergoing primary percutaneous coronary intervention. Circ J. Dec. 2007;71(12):1867-72. [pmid: 18037738].
Kimmelstiel C, Badar J, Covic L, et al. Pharmacodynamics and pharmacokinetics of the platelet GPIIb/IIIa inhibitor tirofiban in patients undergoing percutaneous coronary intervention: implications for adjustment of tirofiban and clopidogrel dosage. Thromb Res. 2005;116(1):55-66. [pmid: 15850609].
Kimmelstiel C, Zhang P, Kapur NK, et al. Bivalirudin is a dual inhibitor of thrombin and collagen-dependent platelet activation in patients undergoing percutaneous coronary intervention. Circ Cardiovasc Interv. Apr. 1. 2011;4(2):171-79. [pmid: 21364148].
King A, Bath PM, Markus HS. Clopidogrel versus dipyridamole in addition to aspirin in reducing embolization detected with ambulatory transcranial Doppler: a randomized trial. Stroke. Mar. 2011;42(3):650-55. [pmid: 21257829].
Klinkhardt U, Bauersachs R, Adams J, et al. Clopidogrel but not aspirin reduces P-selectin expression and formation of platelet-leukocyte aggregates in patients with atherosclerotic vascular disease. Clin Pharmacol Ther. Mar. 2003;73(3):232-41. [pmid: 12621388].
Konopka A, Spychalska J, Sitkiewicz D, et al. Expression of platelet surface receptors and early changes in platelet function in patients with STEMI treated with abciximab and clopidogrel versus clopidogrel alone. Am J Cardiovasc Drugs. 2007;7(6):433-39. [pmid: 18076210].
Kottke-Marchant K, Powers JB, Brooks L, et al. The effect of antiplatelet drugs, heparin, and preanalytical variables on platelet function detected by the platelet function analyzer (PFA-100). Clin Appl Thromb Hemost. Apr. 1999;5(2):122-30. [pmid: 10725993].
Kotzailias N, Elwischger K, Sycha T, et al. Clopidogrel-induced platelet inhibition cannot be detected by the platelet function analyzer-100 system in stroke patients. J Stroke Cerebrovasc Dis. Sep. 2007;16(5):199-202. [pmid: 17845916].
Kozinski M, Bielis L, Wisniewska-Szmyt J, et al. Diurnal variation in platelet inhibition by clopidogrel. Platelets. 2011;22(8):579-87. [pmid: 21627410].
Kozinski M, Bielis L, Wisniewska-Szmyt J, et al. Increased morning ADP-dependent platelet aggregation persists despite dual antiplatelet therapy in patients with first ST-segment elevation myocardial infarction: Preliminary report. Cardiol J. 2008;15(6):530-36. [pmid: 19039757].
Krischek B, Brannath W, Klinkhardt U, et al. Role of the retention test Homburg in evaluating platelet hyperactivity and in monitoring therapy with antiplatelet drugs. Semin Thromb Hemost. 2005;31(4):458-63. [pmid: 16149024].
Kuliczkowski W, Greif M, Gasior M, et al. Effects of platelet and inflammatory system activation on outcomes in diabetic patients with ST segment elevation myocardial infarction treated with primary percutaneous coronary intervention. Kardiol Pol. 2011;69(6):531-37. [pmid: 21678284].
Kumar S, Saran RK, Puri A, et al. Profile and prevalence of clopidogrel resistance in patients of acute coronary syndrome. Indian Heart J. Mar. 2007;59(2):152-56. [pmid: 19122249].
Kwan J, Htun WW, Huang Y, et al. Effect of proton pump inhibitors on platelet inhibition activity of clopidogrel in Chinese patients with percutaneous coronary intervention. Vasc Health Risk Manag. 2011;7:399-404. [pmid: 21796254].
Labarthe B, Babin J, Bryckaert M, et al. Effects of P2Y(1) receptor antagonism on the reactivity of platelets from patients with stable coronary artery disease using aspirin and clopidogrel. Br J Pharmacol. May. 2012;166(1):221-31. [pmid: 21950486].
Labarthe B, Theroux P, Angioi M, et al. Matching the evaluation of the clinical efficacy of clopidogrel to platelet function tests relevant to the biological properties of the drug. J Am Coll Cardiol. Aug. 16. 2005;46(4):638-45. [pmid: 16098428].
Lahiri P, Roy S, Sardar P, et al. Platelet responsiveness to yohimbine hydrochloride and MRS2179 in the context of the interaction between collagen and epinephrine in acute coronary syndrome. Blood Cells Mol Dis. Jul. 2009;43(1):105-10. [pmid: 19272818].
Lau WC, Gurbel PA, Watkins PB, et al. Contribution of hepatic cytochrome P450 3A4 metabolic activity to the phenomenon of clopidogrel resistance. Circulation. Jan. 20. 2004;109(2):166-71. [pmid: 14707025].
Lau WC, Waskell LA, Watkins PB, et al. Atorvastatin reduces the ability of clopidogrel to inhibit platelet aggregation: a new drug-drug interaction. Circulation. Jan. 7. 2003;107(1):32-37. [pmid: 12515739].
Lee BK, Lee SW, Park SW, et al. Effects of triple antiplatelet therapy (aspirin, clopidogrel, and cilostazol) on platelet aggregation and P-selectin expression in patients undergoing coronary artery stent implantation. Am J Cardiol. Aug. 15. 2007;100(4):610-14. [pmid: 17697815].
Lee DH, Arat A, Morsi H, et al. Dual antiplatelet therapy monitoring for neurointerventional procedures using a point-of-care platelet function test: a single-center experience. AJNR Am J Neuroradiol. Aug. 2008;29(7):1389-94. [pmid: 18483190].
Lee DH, Kim HS, Kim SM, et al. Change of Platelet Reactivity to Antiplatelet Therapy after Stenting Procedure for Cerebral Artery Stenosis: VerifyNow Antiplatelet Assay before and after Stenting. Neurointervention. Feb. 2012;7(1):23-26. [pmid: 22454781].
Lee J, Hwang Y, Kang W, et al. Population pharmacokinetic/pharmacodynamic modeling of clopidogrel in Korean healthy volunteers and stroke patients. J Clin Pharmacol. Jul. 2012;52(7):985-95. [pmid: 21617016].
Lee JM, Park S, Shin DJ, et al. Relation of genetic polymorphisms in the cytochrome P450 gene with clopidogrel resistance after drug-eluting stent implantation in Koreans. Am J Cardiol. Jul. 1. 2009;104(1):46-51. [pmid: 19576320].
Lee K, Kim JY, Yoo BS, et al. Cilostazol augments the inhibition of platelet aggregation in clopidogrel low-responders. J Thromb Haemost. Nov. 2010;8(11):2577-79. [pmid: 20723027].
Lepantalo A, Virtanen KS, Heikkila J, et al. Limited early antiplatelet effect of 300 mg clopidogrel in patients with aspirin therapy undergoing percutaneous coronary interventions. Eur Heart J. Mar. 2004;25(6):476-83. [pmid: 15039127].
Lev EI, Arikan ME, Vaduganathan M, et al. Effect of caffeine on platelet inhibition by clopidogrel in healthy subjects and patients with coronary artery disease. Am Heart J. Oct. 2007;154(4):694-97. [pmid: 17892993].
Li J, Jian Z, Huang L, et al. Comparison of collagen versus adenosine diphosphate in detecting antiplatelet effect in patients with coronary artery disease. Biomed Pharmacother. Sep. 2009;63(8):608-12. [pmid: 19019624].
Li Y, Tai BC, Sia W, et al. Angiographic and platelet reactivity outcomes with prasugrel 60 mg pretreatment and clopidogrel 600 mg pretreatment in primary percutaneous coronary intervention. J Thromb Thrombolysis. Nov. 2012;34(4):499-505. [pmid: 22855283].
Loreth RM, Klose G. Comparison of Two Different Blood Sample Tubes for Platelet Function Analysis with the Multiplate(R) System. Transfus Med Hemother. 2010;37(5):289-92. [pmid: 21113252].
Luchessi AD, Silbiger VN, Cerda A, et al. Increased clopidogrel response is associated with ABCC3 expression: a pilot study. Clin Chim Acta. Feb. 18. 2012;413(3-4):417-21. [pmid: 22040781].
Madan M, Berkowitz SD, Christie DJ, et al. Determination of platelet aggregation inhibition during percutaneous coronary intervention with the platelet function analyzer PFA-100. Am Heart J. Jul. 2002;144(1):151-58. [pmid: 12094202].
Madan M, Radhakrishnan S, Reis M, et al. Comparison of enoxaparin versus heparin during elective percutaneous coronary intervention performed with either eptifibatide or tirofiban (the ACTION Trial). Am J Cardiol. Jun. 1. 2005;95(11):1295-301. [pmid: 15904632].
Madsen NJ, Holmes CE, Serrano FA, et al. Influence of preparative procedures on assay of platelet function and apparent effects of antiplatelet agents. Am J Cardiol. Aug. 15. 2007;100(4):722-27. [pmid: 17697836].
Mahla E, Suarez TA, Bliden KP, et al. Platelet function measurement-based strategy to reduce bleeding and waiting time in clopidogrel-treated patients undergoing coronary artery bypass graft surgery: the timing based on platelet function strategy to reduce clopidogrel-associated bleeding related to CABG (TARGET-CABG) study. Circ Cardiovasc Interv. Apr. 2012;5(2):261-69. [pmid: 22396581].
Malek LA, Bilinska ZT, Sitkiewicz D, et al. Platelet reactivity on aspirin, clopidogrel and abciximab in patients with acute coronary syndromes and reduced estimated glomerular filtration rate. Thromb Res. Jan. 2010;125(1):67-71. [pmid: 19443019].
Malinin A, Pokov A, Spergling M, et al. Monitoring platelet inhibition after clopidogrel with the VerifyNow-P2Y12(R) rapid analyzer: the VERIfy Thrombosis risk ASsessment (VERITAS) study. Thromb Res. 2007;119(3):277-84. [pmid: 16563469].
Malinin AI, Oshrine BR, Sane DC, et al. Does heart failure etiology, New York Heart Association class, or ejection fraction affect the ability of clopidogrel to inhibit heightened platelet activity?. Blood Coagul Fibrinolysis. Mar. 2007;18(2):91-96. [pmid: 17287623].
Malmstrom RE, Ostergren J, Jorgensen L, et al. Poor performance with a platelet counting technique to monitor clopidogrel inhibitory effects in the point-of-care setting. Thromb Res. May. 2010;125(5):473-74. [pmid: 19896705].
Marcucci R, Cesari F, Cinotti S, et al. ADAMTS-13 activity in the presence of elevated von Willebrand factor levels as a novel mechanism of residual platelet reactivity in high risk coronary patients on antiplatelet treatment. Thromb Res. 2008;123(1):130-36. [pmid: 18603284].
Mardikar HM, Hiremath MS, Moliterno DJ, et al. Optimal platelet inhibition in patients undergoing PCI: data from the Multicenter Registry of High-Risk Percutaneous Coronary Intervention and Adequate Platelet Inhibition (MR PCI) study. Am Heart J. Aug. 2007;154(2):344-45. [pmid: 17643586].
Maruyama H, Takeda H, Dembo T, et al. Clopidogrel resistance and the effect of combination cilostazol in patients with ischemic stroke or carotid artery stenting using the VerifyNow P2Y12 Assay. Intern Med. 2011;50(7):695-98. [pmid: 21467700].
Massberg S, Mueller I, Besta F, et al. Effects of 2 different antiplatelet regimens with abciximab or tirofiban on platelet function in patients undergoing coronary stenting. Am Heart J. Nov. 2003;146(5):E19. [pmid: 14597948].
Matetzky S, Fefer P, Shenkman B, et al. Effectiveness of reloading to overcome clopidogrel nonresponsiveness in patients with acute myocardial infarction. Am J Cardiol. Sep. 1. 2008;102(5):524-29. [pmid: 18721506].
Matetzky S, Fefer P, Shenkman B, et al. Statins have an early antiplatelet effect in patients with acute myocardial infarction. Platelets. 2011;22(2):103-10. [pmid: 21171935].
Matsagas M, Jagroop IA, Geroulakos G, et al. The effect of a loading dose (300 mg) of clopidogrel on platelet function in patients with peripheral arterial disease. Clin Appl Thromb Hemost. Apr. 2003;9(2):115-20. [pmid: 12812379].
Matsuyama N, Takano K, Miura A, et al. The effect of anti-platelet aggregation to prevent pressure ulcer development: a retrospective study of 132 elderly patients. Gerontology. Nov. 2000;46(6):311-17. [pmid: 11044785].
Mendolicchio GL, Zavalloni D, Bacci M, et al. Variable effect of P2Y12 inhibition on platelet thrombus volume in flowing blood. J Thromb Haemost. Feb. 2011;9(2):373-82. [pmid: 21083646].
Meng K, Lu SZ, Zhu HG, et al. Use of tailored loading-dose clopidogrel in patients undergoing selected percutaneous coronary intervention based on adenosine diphosphate-mediated platelet aggregation. Chin Med J (Engl ). Dec. 2010;123(24):3578-82. [pmid: 22166634].
Mengistu AM, Mayer J, Boldt J, et al. Usefulness of monitoring platelet function by multiple electrode aggregometry in primary coronary artery bypass surgery. J Cardiothorac Vasc Anesth. Feb. 2011;25(1):42-47. [pmid: 20427204].
Metzler H, Pruller F, Munch A, et al. Premature preoperative discontinuation of antiplatelet drug therapy in cardiovascular risk patients: a preliminary study on the role of P2Y12 receptor monitoring. Eur J Anaesthesiol. Feb. 2010;27(2):138-45. [pmid: 19593147].
Meuris B, Arnout J, Vlasselaers D, et al. Long-term management of an implantable left ventricular assist device using low molecular weight heparin and antiplatelet therapy: a possible alternative to oral anticoagulants. Artif Organs. May. 2007;31(5):402-05. [pmid: 17470211].
Meves SH, Overbeck U, Endres HG, et al. Dose-dependent effect of early antiplatelet therapy in acute ischaemic stroke. Thromb Haemost. Jan. 2012;107(1):69-79. [pmid: 22159509].
Michelson AD, Linden MD, Furman MI, et al. Evidence that pre-existent variability in platelet response to ADP accounts for ‘clopidogrel resistance’. J Thromb Haemost. Jan. 2007;5(1):75-81. [pmid: 17002661].
Milburn JA, Ford I, Cassar K, et al. Platelet activation, coagulation activation and C-reactive protein in simultaneous samples from the vascular access and peripheral veins of haemodialysis patients. Int J Lab Hematol. Feb. 2012;34(1):52-58. [pmid: 21722325].
Mitsios JV, Papathanasiou AI, Elisaf M, et al. The inhibitory potency of clopidogrel on ADP-induced platelet activation is not attenuated when it is co-administered with atorvastatin (20 mg/day) for 5 weeks in patients with acute coronary syndromes. Platelets. Aug. 2005;16(5):287-92. [pmid: 16011979].
Mitsios JV, Papathanasiou AI, Rodis FI, et al. Atorvastatin does not affect the antiplatelet potency of clopidogrel when it is administered concomitantly for 5 weeks in patients with acute coronary syndromes. Circulation. Mar. 23. 2004;109(11):1335-38. [pmid: 15023882].
Mizia-Stec K, Haberka M, Mizia M, et al. Effects of pantoprazole on dual antiplatelet therapy in stable angina pectoris patients after percutaneous coronary intervention. Pharmacol Rep. 2012;64(2):360-68. [pmid: 22661187].
Moceri P, Doyen D, Cerboni P, et al. Doubling the dose of clopidogrel restores the loss of antiplatelet effect induced by esomeprazole. Thromb Res. Nov. 2011;128(5):458-62. [pmid: 21777954].
Mokhtar OA, Lemesle G, Armero S, et al. Relationship between platelet reactivity inhibition and non-CABG related major bleeding in patients undergoing percutaneous coronary intervention. Thromb Res. Aug. 2010;126(2):e147-e149. [pmid: 20129650].
Morel O, El GS, Hess S, et al. The extent of P2Y12 inhibition by clopidogrel in diabetes mellitus patients with acute coronary syndrome is not related to glycaemic control: roles of white blood cell count and body weight. Thromb Haemost. Aug. 2012;108(2):338-48. [pmid: 22740070].
Morel O, Faure A, Ohlmann P, et al. Impaired platelet responsiveness to clopidogrel identified by flow cytometric vasodilator-stimulated phosphoprotein (VASP) phosphorylation in patients with subacute stent thrombosis. Thromb Haemost. Oct. 2007;98(4):896-99. [pmid: 17938817].
Moshfegh K, Redondo M, Julmy F, et al. Antiplatelet effects of clopidogrel compared with aspirin after myocardial infarction: enhanced inhibitory effects of combination therapy. J Am Coll Cardiol. Sep. 2000;36(3):699-705. [pmid: 10987587].
Motovska Z, Odvodyova D, Fischerova M, et al. Renal function assessed using cystatin C and antiplatelet efficacy of clopidogrel assessed using the vasodilator-stimulated phosphoprotein index in patients having percutaneous coronary intervention. Am J Cardiol. Mar. 1. 2012;109(5):620-23. [pmid: 22154314].
Motovska Z, Widimsky P, Petr R, et al. Factors influencing clopidogrel efficacy in patients with stable coronary artery disease undergoing elective percutaneous coronary intervention: statin's advantage and the smoking “paradox”. J Cardiovasc Pharmacol. May. 2009;53(5):368-72. [pmid: 19247187].
Motovska Z, Widimsky P, Petr R, et al. Optimal pretreatment timing for high load dosing (600 mg) of clopidogrel before planned percutaneous coronary intervention for maximal antiplatelet effectiveness. Int J Cardiol. Oct. 8. 2010;144(2):255-57. [pmid: 19232444].
Mrdovic I, Savic L, Krljanac G, et al. Impact of high post-loading platelet aggregation on 30-day clinical outcomes after primary percutaneous coronary intervention. The antiplatelet regimen tailoring after primary PCI (ART-PCI) trial. Int J Cardiol. 2012. May. 22. [pmid: 22626838].
Mueller T, Dieplinger B, Poelz W, et al. Utility of the PFA-100 instrument and the novel multiplate analyzer for the assessment of aspirin and clopidogrel effects on platelet function in patients with cardiovascular disease. Clin Appl Thromb Hemost. Dec. 2009;15(6):652-59. [pmid: 18805846].
Mueller T, Dieplinger B, Poelz W, et al. Utility of whole blood impedance aggregometry for the assessment of clopidogrel action using the novel Multiplate analyzer--comparison with two flow cytometric methods. Thromb Res. 2007;121(2):249-58. [pmid: 17482663].
Mueller T, Haltmayer M, Poelz W, et al. Monitoring aspirin 100 mg and clopidogrel 75 mg therapy with the PFA-100 device in patients with peripheral arterial disease. Vasc Endovascular Surg. Mar. 2003;37(2):117-23. [pmid: 12669143].
Muller I, Besta F, Schulz C, et al. Effects of statins on platelet inhibition by a high loading dose of clopidogrel. Circulation. Nov. 4. 2003;108(18):2195-97. [pmid: 14568892].
Muller I, Massberg S, Zierhut W, et al. Effects of aspirin and clopidogrel versus oral anticoagulation on platelet function and on coagulation in patients with nonvalvular atrial fibrillation (CLAFIB). Pathophysiol Haemost Thromb. Jan. 2002;32(1):16-24. [pmid: 12214159].
Muller I, Seyfarth M, Rudiger S, et al. Effect of a high loading dose of clopidogrel on platelet function in patients undergoing coronary stent placement. Heart. Jan. 2001;85(1):92-93. [pmid: 11119474].
Muller O, Hamilos M, Bartunek J, et al. Relation of endothelial function to residual platelet reactivity after clopidogrel in patients with stable angina pectoris undergoing percutaneous coronary intervention. Am J Cardiol. Feb. 1. 2010;105(3):333-38. [pmid: 20102944].
Mylotte D, Peace AJ, Tedesco AT, et al. Clopidogrel discontinuation and platelet reactivity following coronary stenting. J Thromb Haemost. Jan. 2011;9(1):24-32. [pmid: 20961396].
Naidech AM, Bassin SL, Bernstein RA, et al. Reduced platelet activity is more common than reported anti-platelet medication use in patients with intracerebral hemorrhage. Neurocrit Care. Dec. 2009;11(3):307-10. [pmid: 19381881].
Naidech AM, Liebling SM, Rosenberg NF, et al. Early platelet transfusion improves platelet activity and may improve outcomes after intracerebral hemorrhage. Neurocrit Care. Feb. 2012;16(1):82-87. [pmid: 21837536].
Neubauer H, Gunesdogan B, Hanefeld C, et al. Lipophilic statins interfere with the inhibitory effects of clopidogrel on platelet function--a flow cytometry study. Eur Heart J. Oct. 2003;24(19):1744-49. [pmid: 14522569].
Neubauer H, Lask S, Engelhardt A, et al. How to optimise clopidogrel therapy? Reducing the low-response incidence by aggregometry-guided therapy modification. Thromb Haemost. Feb. 2008;99(2):357-62. [pmid: 18278186].
Nguyen TA, Lordkipanidze M, Diodati JG, et al. Week-long high-maintenance dose clopidogrel regimen achieves better platelet aggregation inhibition than a standard loading dose before percutaneous coronary intervention: results of a double-blind, randomized clinical trial. J Interv Cardiol. Aug. 2009;22(4):368-77. [pmid: 19689661].
Nielsen AB, Bochsen L, Steinbruchel DA. Hypercoagulability and platelet inhibition after OPCAB. Randomized intervention with clopidogrel. Scand Cardiovasc J. Oct. 2007;41(5):325-30. [pmid: 17852789].
Osmancik P, Jirmar R, Hulikova K, et al. A comparison of the VASP index between patients with hemodynamically complicated and uncomplicated acute myocardial infarction. Catheter Cardiovasc Interv. Feb. 1. 2010;75(2):158-66. [pmid: 19902490].
Osmancik P, Paulu P, Tousek P, et al. High leukocyte count and interleukin-10 predict high on-treatment-platelet-reactivity in patients treated with clopidogrel. J Thromb Thrombolysis. May. 2012;33(4):349-54. [pmid: 22189756].
Osmancik PP, Bednar F, Mocikova H. Glycemia, triglycerides and disease severity are best associated with higher platelet activity in patients with stable coronary artery disease. J Thromb Thrombolysis. Oct. 2007;24(2):105-07. [pmid: 17308964].
Ostad MA, Nick E, Paixao-Gatinho V, et al. Lack of evidence for pleiotropic effects of clopidogrel on endothelial function and inflammation in patients with stable coronary artery disease: results of the double-blind, randomized CASSANDRA study. Clin Res Cardiol. Jan. 2011;100(1):29-36. [pmid: 20644943].
Pandya DJ, Fitzsimmons BF, Wolfe TJ, et al. Measurement of antiplatelet inhibition during neurointerventional procedures: the effect of antithrombotic duration and loading dose. J Neuroimaging. Jan. 2010;20(1):64-69. [pmid: 19018951].
Paniccia R, Antonucci E, Gori AM, et al. Comparison of different methods to evaluate the effect of aspirin on platelet function in high-risk patients with ischemic heart disease receiving dual antiplatelet treatment. Am J Clin Pathol. Jul. 2007;128(1):143-49. [pmid: 17580282].
Papp E, Havasi V, Bene J, et al. Does glycoprotein IIIa gene (Pl(A)) polymorphism influence clopidogrel resistance? : a study in older patients. Drugs Aging. 2007;24(4):345-50. [pmid: 17432927].
Park KJ, Chung HS, Kim SR, et al. Clinical, pharmacokinetic, and pharmacogenetic determinants of clopidogrel resistance in Korean patients with acute coronary syndrome. Korean J Lab Med. Apr. 2011;31(2):91-94. [pmid: 21474982].
Park KW, Kang SH, Kang J, et al. Enhanced clopidogrel response in smokers is reversed after discontinuation as assessed by VerifyNow assay: additional evidence for the concept of ‘smokers’ paradox'. Heart. Jul. 2012;98(13):1000-06. [pmid: 22572048].
Park KW, Park JJ, Jeon KH, et al. Clinical predictors of high posttreatment platelet reactivity to clopidogrel in Koreans. Cardiovasc Ther. Feb. 2012;30(1):5-11. [pmid: 21129165].
Park SH, Kim W, Park CS, et al. A comparison of clopidogrel responsiveness in patients with versus without chronic renal failure. Am J Cardiol. Nov. 1. 2009;104(9):1292-95. [pmid: 19840579].
Parodi G, Marcucci R, Valenti R, et al. High residual platelet reactivity after clopidogrel loading and long-term cardiovascular events among patients with acute coronary syndromes undergoing PCI. JAMA. Sep. 21. 2011;306(11):1215-23. [pmid: 21934054].
Pasqualini L, Pirro M, Lombardini R, et al. A human model of platelet-leucocyte adhesive interactions during controlled ischaemia in patients with peripheral vascular disease. J Clin Pathol. Dec. 2002;55(12):946-50. [pmid: 12461065].
Pattanaik S, Malhotra S, Sharma YP, et al. Effect of cilostazol on platelet aggregation in patients with non-ST elevation acute coronary syndrome. Int J Clin Pharmacol Ther. Feb. 2010;48(2):93-102. [pmid: 20137761].
Patti G, Chello M, Pasceri V, et al. Pretreatment with different loading doses of clopidogrel influences P-selectin levels in patients undergoing percutaneous coronary intervention: results from the ARMYDA-2 (antiplatelet therapy for reduction of myocardial damage during angioplasty) SELECT substudy. J Cardiovasc Med (Hagerstown ). Mar. 2011;12(3):151-56. [pmid: 21085001].
Patti G, Grieco D, Dicuonzo G, et al. High versus standard clopidogrel maintenance dose after percutaneous coronary intervention and effects on platelet inhibition, endothelial function, and inflammation results of the ARMYDA-150 mg (antiplatelet therapy for reduction of myocardial damage during angioplasty) randomized study. J Am Coll Cardiol. Feb. 15. 2011;57(7):771-78. [pmid: 21310311].
Payne DA, Jones CI, Hayes PD, et al. Beneficial effects of clopidogrel combined with aspirin in reducing cerebral emboli in patients undergoing carotid endarterectomy. Circulation. Mar. 30. 2004;109(12):1476-81. [pmid: 15007001].
Payne DA, Jones CI, Hayes PD, et al. Therapeutic benefit of low-dose clopidogrel in patients undergoing carotid surgery is linked to variability in the platelet adenosine diphosphate response and patients' weight. Stroke. Sep. 2007;38(9):2464-69. [pmid: 17656657].
Peace AJ, Tedesco AF, Foley DP, et al. Dual antiplatelet therapy unmasks distinct platelet reactivity in patients with coronary artery disease. J Thromb Haemost. Dec. 2008;6(12):2027-34. [pmid: 18823340].
Perneby C, Wallen NH, Hofman-Bang C, et al. Effect of clopidogrel treatment on stress-induced platelet activation and myocardial ischemia in aspirin-treated patients with stable coronary artery disease. Thromb Haemost. Dec. 2007;98(6):1316-22. [pmid: 18064330].
Petricevic M, Biocina B, Konosic S, et al. Assessment of platelet function by whole blood impedance aggregometry in coronary artery bypass grafting patients on acetylsalicylic acid treatment may prompt a switch to dual antiplatelet therapy. Heart Vessels. Jan. 2013;28(1):57-65. [pmid: 22203409].
Pham JP, Ueno M, Tello-Montoliu A, et al. Impact of gastric acid-suppressing therapies on platelet reactivity in patients with coronary artery disease treated with clopidogrel: results of a pharmacodynamic study. J Am Coll Cardiol. Sep. 20. 2011;58(13):1396-98. [pmid: 21920272].
Piorkowski M, Fischer S, Stellbaum C, et al. Treatment with ezetimibe plus low-dose atorvastatin compared with higher-dose atorvastatin alone: is sufficient cholesterol-lowering enough to inhibit platelets?. J Am Coll Cardiol. Mar. 13. 2007;49(10):1035-42. [pmid: 17349882].
Piorkowski M, Priess J, Weikert U, et al. Abciximab therapy is associated with increased platelet activation and decreased heparin dosage in patients with acute myocardial infarction. Thromb Haemost. Aug. 2005;94(2):422-26. [pmid: 16113834].
Piorkowski M, Weikert U, Schwimmbeck PL, et al. ADP induced platelet degranulation in healthy individuals is reduced by clopidogrel after pretreatment with atorvastatin. Thromb Haemost. Sep. 2004;92(3):614-20. [pmid: 15351859].
Polena S, Gupta MP, Shaikh H, et al. Platelet aggregation inhibition in patients receiving statins either fully or partially metabolized by CYP3A4. Proc West Pharmacol Soc. 2008;51:60-62. [pmid: 19544679].
Pongracz E. Measurement of platelet aggregation during antiplatelet therapy in ischemic stroke. Clin Hemorheol Microcirc. 2004;30(3-4):237-42. [pmid: 15258349].
Poyet R, Cuisset T, Frere C, et al. Comparison of rosuvastatin and atorvastatin on clopidogrel response and lipidic and inflammatory parameters after coronary stenting for acute coronary syndrome: the prospective, randomized OSCAR study (optimal statin therapy with clopidogrel after coronary revascularisation). Thromb Res. Nov. 2010;126(5):e397-e399. [pmid: 20825983].
Prabhakaran S, Wells KR, Lee VH, et al. Prevalence and risk factors for aspirin and clopidogrel resistance in cerebrovascular stenting. AJNR Am J Neuroradiol. Feb. 2008;29(2):281-85. [pmid: 17989373].
Price MJ, Walder JS, Baker BA, et al. Recovery of platelet function after discontinuation of prasugrel or clopidogrel maintenance dosing in aspirin-treated patients with stable coronary disease: the recovery trial. J Am Coll Cardiol. Jun. 19. 2012;59(25):2338-43. [pmid: 22698488].
Quinn MJ, Bhatt DL, Zidar F, et al. Effect of clopidogrel pretreatment on inflammatory marker expression in patients undergoing percutaneous coronary intervention. Am J Cardiol. Mar. 15. 2004;93(6):679-84. [pmid: 15019868].
Qureshi AI, Siddiqui AM, Hanel RA, et al. Safety of high-dose intravenous eptifibatide as an adjunct to internal carotid artery angioplasty and stent placement: a prospective registry. Neurosurgery. Feb. 2004;54(2):307-16. [pmid: 14744276].
Raman S, Jilma B. Time lag in platelet function inhibition by clopidogrel in stroke patients as measured by PFA-100. J Thromb Haemost. Dec. 2004;2(12):2278-79. [pmid: 15613054].
Ravn HB, Hjortdal VE, Stenbog EV, et al. Increased platelet reactivity and significant changes in coagulation markers after cavopulmonary connection. Heart. Jan. 2001;85(1):61-65. [pmid: 11119465].
Ray MJ, Juneja M, Bett N, et al. A comparison of anticoagulation with bivalirudin and provisional GPIIb/IIIa inhibition with unfractionated heparin and mandatory GPIIb/IIIa inhibition during percutaneous coronary intervention in relation to platelet activation and the inhibition of coagulation. EuroIntervention. Aug. 2009;5(3):330-35. [pmid: 19736157].
Ray MJ, Walters DL, Bett N, et al. Point-of-care testing shows clinically relevant variation in the degree of inhibition of platelets by standard-dose abciximab therapy during percutaneous coronary intervention. Catheter Cardiovasc Interv. Jun. 2004;62(2):150-54. [pmid: 15170702].
Ren YH, Yang TS, Wang Y, et al. Evaluation of triple anti-platelet therapy by modified thrombelastography in patients with acute coronary syndrome. Chin Med J (Engl ). May. 5. 2008;121(9):850-52. [pmid: 18701053].
Riondino S, Petrini N, Donato L, et al. Effects of rosuvastatin on platelet inhibition by clopidogrel in cardiovascular patients. J Thromb Thrombolysis. Aug. 2009;28(2):151-55. [pmid: 18636229].
Robier C, Neubauer M, Sternad H, et al. Evaluation of platelet function and pharmacological platelet inhibition in patients with myeloproliferative disorders using multiple electrode aggregometry. Thromb Res. Sep. 2010;126(3):232-37. [pmid: 20630570].
Sagcan A, Nalbantgil S, Omay SB, et al. The effect of type II diabetes mellitus on platelet aggregation in patients who underwent percutaneous transluminal coronary angioplasty. Coron Artery Dis. Feb. 2002;13(1):45-48. [pmid: 11917198].
Sairaku A, Nakano Y, Eno S, et al. Platelet function measured using a whole blood aggregometer can predict bleeding events. J Atheroscler Thromb. 2011;18(1):16-23. [pmid: 21060210].
Samara WM, Bliden KP, Tantry US, et al. The difference between clopidogrel responsiveness and posttreatment platelet reactivity. Thromb Res. 2005;115(1-2):89-94. [pmid: 15567458].
Sambu N, Radhakrishnan A, Dent H, et al. Personalised antiplatelet therapy in stent thrombosis: observations from the Clopidogrel Resistance in Stent Thrombosis (CREST) registry. Heart. May. 2012;98(9):706-11. [pmid: 22523055].
Sarafoff N, Neumann L, Morath T, et al. Lack of impact of calcium-channel blockers on the pharmacodynamic effect and the clinical efficacy of clopidogrel after drug-eluting stenting. Am Heart J. Mar. 2011;161(3):605-10. [pmid: 21392618].
Saucedo JF, Aude W, Pacheco R, et al. Inhibition of platelet aggregation with eptifibatide, bivalirudin, and heparin in patients undergoing percutaneous coronary intervention receiving clopidogrel pretreatment (The PharmacoDynamic Evaluation of Angiomax, Clopidogrel with or without INtegrilin [DEACON] study). Am J Cardiol. Jun. 15. 2005;95(12):1453-56. [pmid: 15950569].
Sbrana S, Della PF, Rizza A, et al. Relationships between optical aggregometry (type born) and flow cytometry in evaluating ADP-induced platelet activation. Cytometry B Clin Cytom. Jan. 2008;74(1):30-39. [pmid: 17630652].
Schafer A, Flierl U, Pfortsch S, et al. The H(2)-receptor antagonist ranitidine interferes with clopidogrel-mediated P2Y(12) inhibition in platelets. Pharmacol Res. Oct. 2010;62(4):352-56. [pmid: 20595015].
Serebruany V, Cherala G, Williams C, et al. Association of platelet responsiveness with clopidogrel metabolism: role of compliance in the assessment of “resistance”. Am Heart J. Dec. 2009;158(6):925-32. [pmid: 19958858].
Serebruany V, Pokov I, Kuliczkowski W, et al. Baseline platelet activity and response after clopidogrel in 257 diabetics among 822 patients with coronary artery disease. Thromb Haemost. Jul. 2008;100(1):76-82. [pmid: 18612541].
Serebruany V, Rao SV, Silva MA, et al. Correlation of inhibition of platelet aggregation after clopidogrel with post discharge bleeding events: assessment by different bleeding classifications. Eur Heart J. Jan. 2010;31(2):227-35. [pmid: 19854728].
Serebruany VL, Kogushi M, stros-Pitei D, et al. The in-vitro effects of E5555, a protease-activated receptor (PAR)-1 antagonist, on platelet biomarkers in healthy volunteers and patients with coronary artery disease. Thromb Haemost. Jul. 2009;102(1):111-19. [pmid: 19572075].
Serebruany VL, Malinin AI, Atar D, et al. Consistent platelet inhibition during long-term maintenance-dose clopidogrel therapy among 359 compliant outpatients with documented vascular disease. Am Heart J. Mar. 2007;153(3):371-77. [pmid: 17307414].
Serebruany VL, Malinin AI, Atar D. Combination antiplatelet therapy with aspirin and clopidogrel: the role of antecedent and concomitant doses of aspirin. An analysis of 711 patients. Cardiology. 2007;107(4):307-12. [pmid: 17264511].
Serebruany VL, Malinin AI, Pokov A, et al. Effects of clopidogrel and aspirin in combination versus aspirin alone on platelet activation and major receptor expression in diabetic patients: the PLavix Use for Treatment Of Diabetes (PLUTO-Diabetes) trial. Am Heart J. Jan. 2008;155(1):93-97. [pmid: 18082496].
Serebruany VL, Malinin AI, Pokov A, et al. Effects of clopidogrel and aspirin in combination versus aspirin alone on platelet activation and major receptor expression in diabetic patients: the PLavix Use for Treatment Of Diabetes (PLUTO-Diabetes) trial. Am Heart J. Jan. 2008;155(1):93-97. [pmid: 18082496].
Serebruany VL, Malinin AI, Ziai W, et al. Effects of clopidogrel and aspirin in combination versus aspirin alone on platelet activation and major receptor expression in patients after recent ischemic stroke: for the Plavix Use for Treatment of Stroke (PLUTO-Stroke) trial. Stroke. Oct. 2005;36(10):2289-92. [pmid: 16151033].
Serebruany VL, Midei MG, Malinin AI, et al. Absence of interaction between atorvastatin or other statins and clopidogrel: results from the interaction study. Arch Intern Med. Oct. 11. 2004;164(18):2051-57. [pmid: 15477442].
Serebruany VL, Steinhubl SR, Berger PB, et al. Variability in platelet responsiveness to clopidogrel among 544 individuals. J Am Coll Cardiol. Jan. 18. 2005;45(2):246-51. [pmid: 15653023].
Serrano Junior CV, Soeiro AM, Araujo LF, et al. Lack of clopidogrel-statin interaction in patients undergoing coronary stent implantation. Arq Bras Cardiol. Sep. 2010;95(3):321-27. [pmid: 20721515].
Seyfarth HJ, Koksch M, Roethig G, et al. Effect of 300- and 450-mg clopidogrel loading doses on membrane and soluble P-selectin in patients undergoing coronary stent implantation. Am Heart J. Jan. 2002;143(1):118-23. [pmid: 11773921].
Shechter M, Shechter A, Hod H, et al. Brachial artery endothelial function predicts platelet function in control subjects and in patients with acute myocardial infarction. Platelets. 2012;23(3):202-10. [pmid: 21824040].
Shim CY, Yoon SJ, Park S, et al. The clopidogrel resistance can be attenuated with triple antiplatelet therapy in patients undergoing drug-eluting stents implantation. Int J Cardiol. May. 29. 2009;134(3):351-55. [pmid: 18579227].
Shim JK, Choi YS, Oh YJ, et al. Effects of preoperative aspirin and clopidogrel therapy on perioperative blood loss and blood transfusion requirements in patients undergoing off-pump coronary artery bypass graft surgery. J Thorac Cardiovasc Surg. Jul. 2007;134(1):59-64. [pmid: 17599487].
Sibbing D, Busch G, Braun S, et al. Impact of bivalirudin or unfractionated heparin on platelet aggregation in patients pretreated with 600 mg clopidogrel undergoing elective percutaneous coronary intervention. Eur Heart J. Jun. 2008;29(12):1504-09. [pmid: 18467322].
Sibbing D, Morath T, Stegherr J, et al. Impact of proton pump inhibitors on the antiplatelet effects of clopidogrel. Thromb Haemost. Apr. 2009;101(4):714-19. [pmid: 19350116].
Sibbing D, Stegherr J, Braun S, et al. A double-blind, randomized study on prevention and existence of a rebound phenomenon of platelets after cessation of clopidogrel treatment. J Am Coll Cardiol. Feb. 9. 2010;55(6):558-65. [pmid: 20152561].
Sibbing D, von BN, Morath T, et al. Oral anticoagulation with coumarin derivatives and antiplatelet effects of clopidogrel. Eur Heart J. May. 2010;31(10):1205-11. [pmid: 20159881].
Sibbing D, von BO, Schomig A, et al. Diabetes mellitus and platelet function after administration of aspirin and a single 600 mg dose of clopidogrel. J Thromb Haemost. Dec. 2006;4(12):2566-68. [pmid: 16938125].
Sibbing D, von BO, Schomig A, et al. Impact of body mass index on platelet aggregation after administration of a high loading dose of 600 mg of clopidogrel before percutaneous coronary intervention. Am J Cardiol. Jul. 15. 2007;100(2):203-05. [pmid: 17631070].
Sibbing D, von BO, Schomig A, et al. Platelet function in clopidogrel-treated patients with acute coronary syndrome. Blood Coagul Fibrinolysis. Jun. 2007;18(4):335-39. [pmid: 17473574].
Siller-Matula JM, Lang I, Christ G, et al. Calcium-channel blockers reduce the antiplatelet effect of clopidogrel. J Am Coll Cardiol. Nov. 4. 2008;52(19):1557-63. [pmid: 19007592].
Siller-Matula JM, Spiel AO, Lang IM, et al. Effects of pantoprazole and esomeprazole on platelet inhibition by clopidogrel. Am Heart J. Jan. 2009;157(1):148-5. [pmid: 19081411].
Skowasch D, Viktor A, Schneider-Schmitt M, et al. Differential antiplatelet effects of angiotensin converting enzyme inhibitors: comparison of ex vivo platelet aggregation in cardiovascular patients with ramipril, captopril and enalapril. Clin Res Cardiol. Apr. 2006;95(4):212-16. [pmid: 16598590].
Slugg PH, Much DR, Smith WB, et al. Cirrhosis does not affect the pharmacokinetics and pharmacodynamics of clopidogrel. J Clin Pharmacol. Apr. 2000;40(4):396-401. [pmid: 10761167].
Smith SM, Judge HM, Peters G, et al. Multiple antiplatelet effects of clopidogrel are not modulated by statin type in patients undergoing percutaneous coronary intervention. Platelets. Dec. 2004;15(8):465-74. [pmid: 15763887].
Smout JD, Mikhailidis DP, Shenton BK, et al. Combination antiplatelet therapy in patients with peripheral vascular bypass grafts. Clin Appl Thromb Hemost. Jan. 2004;10(1):9-18. [pmid: 14979400].
Smout JD, Mikhailidis DP, Shenton BK, et al. Combination antiplatelet therapy in patients with peripheral vascular bypass grafts. Clin Appl Thromb Hemost. Jan. 2004;10(1):9-18. [pmid: 14979400].
Soffer D, Moussa I, Harjai KJ, et al. Impact of angina class on inhibition of platelet aggregation following clopidogrel loading in patients undergoing coronary intervention: do we need more aggressive dosing regimens in unstable angina?. Catheter Cardiovasc Interv. May. 2003;59(1):21-25. [pmid: 12720236].
Solheim S, Pettersen AA, Arnesen H, et al. No difference in the effects of clopidogrel and aspirin on inflammatory markers in patients with coronary heart disease. Thromb Haemost. Nov. 2006;96(5):660-64. [pmid: 17080224].
Solinas E, Gobbi G, Dangas G, et al. Comparison of the effects of pretreatment with tirofiban, clopidogrel or both on the inhibition of platelet aggregation and activation in patients with acute coronary syndromes. J Thromb Thrombolysis. Jan. 2009;27(1):36-43. [pmid: 18049795].
Staritz P, Kurz K, Stoll M, et al. Platelet reactivity and clopidogrel resistance are associated with the H2 haplotype of the P2Y12-ADP receptor gene. Int J Cardiol. Apr. 17. 2009;133(3):341-45. [pmid: 18485500].
Sternberg Z, Ching M, Sawyer RN, et al. Clopidogrel Responsiveness in Stroke Patients on a Chronic Aspirin Regimen. J Stroke Cerebrovasc Dis. 2011. Dec. 28. [pmid: 22209644].
Sternberg Z, Ching M, Sawyer RN, et al. Clopidogrel Responsiveness in Stroke Patients on a Chronic Aspirin Regimen. J Stroke Cerebrovasc Dis. 2011. Dec. 28. [pmid: 22209644].
Storey RF, Angiolillo DJ, Patil SB, et al. Inhibitory effects of ticagrelor compared with clopidogrel on platelet function in patients with acute coronary syndromes: the PLATO (PLATelet inhibition and patient Outcomes) PLATELET substudy. J Am Coll Cardiol. Oct. 26. 2010;56(18):1456-62. [pmid: 20832963].
Storey RF, Bliden KP, Ecob R, et al. Earlier recovery of platelet function after discontinuation of treatment with ticagrelor compared with clopidogrel in patients with high antiplatelet responses. J Thromb Haemost. Sep. 2011;9(9):1730-37. [pmid: 21707911].
Storey RF, Judge HM, Wilcox RG, et al. Inhibition of ADP-induced P-selectin expression and platelet-leukocyte conjugate formation by clopidogrel and the P2Y12 receptor antagonist AR-C69931MX but not aspirin. Thromb Haemost. Sep. 2002;88(3):488-94. [pmid: 12353080].
Storey RF, Wilcox RG, Heptinstall S. Comparison of the pharmacodynamic effects of the platelet ADP receptor antagonists clopidogrel and AR-C69931MX in patients with ischaemic heart disease. Platelets. Nov. 2002;13(7):407-13. [pmid: 12487788].
Suh JW, Seung KB, Gwak CH, et al. Comparison of antiplatelet effect and tolerability of clopidogrel resinate with clopidogrel bisulfate in patients with coronary heart disease (CHD) or CHD-equivalent risks: a phase IV, prospective, double-dummy, parallel-group, 4-week noninferiority trial. Clin Ther. Aug. 2011;33(8):1057-68. [pmid: 21816478].
Suryadevara S, Ueno M, Tello-Montoliu A, et al. Effects of pioglitazone on platelet P2Y12-mediated signalling in clopidogrel-treated patients with type 2 diabetes mellitus. Thromb Haemost. Nov. 2012;108(5):930-36. [pmid: 22782352].
Szapary L, Bagoly E, Kover F, et al. The effect of carotid stenting on rheological parameters, free radical production and platelet aggregation. Clin Hemorheol Microcirc. 2009;43(3):209-17. [pmid: 19847055].
Talarico GP, Brancati M, Burzotta F, et al. Glycoprotein IIB/IIIA inhibitor to reduce postpercutaneous coronary intervention myonecrosis and improve coronary flow in diabetics: the ‘OPTIMIZE-IT’ pilot randomized study. J Cardiovasc Med (Hagerstown ). Mar. 2009;10(3):245-51. [pmid: 19262211].
Talreja D, Lubbe D, Orford JL, et al. Does clopidogrel increase the degree of platelet inhibition when a platelet glycoprotein IIb/IIIa inhibitor has been given? Insights from an optical platelet aggregometry study. J Thromb Thrombolysis. Aug. 2004;18(1):25-30. [pmid: 15744550].
Tang YD, Hasan F, Giordano FJ, et al. Effects of recombinant human erythropoietin on platelet activation in acute myocardial infarction: results of a double-blind, placebo-controlled, randomized trial. Am Heart J. Dec. 2009;158(6):941-47. [pmid: 19958860].
Taubert D, von BN, Grimberg G, et al. Impact of P-glycoprotein on clopidogrel absorption. Clin Pharmacol Ther. Nov. 2006;80(5):486-501. [pmid: 17112805].
Tavassoli N, Voisin S, Carrie D, et al. High maintenance dosage of clopidogrel is associated with a reduced risk of stent thrombosis in clopidogrel-resistant patients. Am J Cardiovasc Drugs. 2010;10(1):29-35. [pmid: 20104932].
Tekten T, Ceyhan C, Ercan E, et al. The effect of atorvastatin on platelet function in patients with coronary artery disease. Acta Cardiol. Jun. 2004;59(3):311-15. [pmid: 15255464].
Tetik S, Ak K, Isbir S, et al. Clopidogrel provides significantly greater inhibition of platelet activity than aspirin when combined with atorvastatin after coronary artery bypass grafting: a prospective randomized study. Clin Appl Thromb Hemost. Apr. 2010;16(2):189-98. [pmid: 19703819].
Trenk D, Hochholzer W, Frundi D, et al. Impact of cytochrome P450 3A4-metabolized statins on the antiplatelet effect of a 600-mg loading dose clopidogrel and on clinical outcome in patients undergoing elective coronary stent placement. Thromb Haemost. Jan. 2008;99(1):174-81. [pmid: 18217151].
Trenk D, Hochholzer W, Muller B, et al. Antiplatelet response to the 150-mg maintenance dose of clopidogrel in patients with insufficient platelet inhibition after clopidogrel loading for elective coronary stent placement. EuroIntervention. Aug. 2008;4(2):214-21. [pmid: 19110786].
Tsoumani ME, Kalantzi KI, Dimitriou AA, et al. Antiplatelet efficacy of long-term treatment with clopidogrel besylate in patients with a history of acute coronary syndrome: comparison with clopidogrel hydrogen sulfate. Angiology. Oct. 2012;63(7):547-51. [pmid: 22144668].
Tsoumani ME, Kalantzi KI, Dimitriou AA, et al. Effect of clopidogrel besylate on platelet reactivity in patients with acute coronary syndromes. Comparison with clopidogrel hydrogen sulfate. Expert Opin Pharmacother. Feb. 2012;13(2):149-58. [pmid: 22188544].
Tsukahara K, Kimura K, Morita S, et al. Impact of concomitant use of proton-pump inhibitors and thienopyridine derivatives on the antiplatelet effects. J Cardiol. May. 2011;57(3):275-82. [pmid: 21371863].
Tunggal P, Ng FH, Lam KF, et al. Effect of esomeprazole versus famotidine on platelet inhibition by clopidogrel: a double-blind, randomized trial. Am Heart J. Nov. 2011;162(5):870-74. [pmid: 22093203].
Ueno M, Ferreiro JL, Desai B, et al. Cigarette smoking is associated with a dose-response effect in clopidogrel-treated patients with diabetes mellitus and coronary artery disease: results of a pharmacodynamic study. JACC Cardiovasc Interv. Mar. 2012;5(3):293-300. [pmid: 22440495].
Ueno M, Ferreiro JL, Tomasello SD, et al. Functional profile of the platelet P2Y(1)(2) receptor signalling pathway in patients with type 2 diabetes mellitus and coronary artery disease. Thromb Haemost. Apr. 2011;105(4):730-32. [pmid: 21225097].
Ueno M, Ferreiro JL, Tomasello SD, et al. Impact of pentoxifylline on platelet function profiles in patients with type 2 diabetes mellitus and coronary artery disease on dual antiplatelet therapy with aspirin and clopidogrel. JACC Cardiovasc Interv. Aug. 2011;4(8):905-12. [pmid: 21851906].
Ural AU, Yilmaz MI, Avcu F, et al. Treatment with cerivastatin in primary mixed hyperlipidemia induces changes in platelet aggregation and coagulation system components. Int J Hematol. Oct. 2002;76(3):279-83. [pmid: 12416740].
Valgimigli M, Tebaldi M, Campo G, et al. Prasugrel versus tirofiban bolus with or without short post-bolus infusion with or without concomitant prasugrel administration in patients with myocardial infarction undergoing coronary stenting: the FABOLUS PRO (Facilitation through Aggrastat By drOpping or shortening Infusion Line in patients with ST-segment elevation myocardial infarction compared to or on top of PRasugrel given at loading dOse) trial. JACC Cardiovasc Interv. Mar. 2012;5(3):268-77. [pmid: 22440491].
van der Meijden PE, Feijge MA, Giesen PL, et al. Platelet P2Y12 receptors enhance signalling towards procoagulant activity and thrombin generation. A study with healthy subjects and patients at thrombotic risk. Thromb Haemost. Jun. 2005;93(6):1128-36. [pmid: 15968399].
Van der Planken MG, Claeys MJ, Vertessen FJ, et al. Comparison of turbidimetric aggregation and in vitro bleeding time (PFA-100) for monitoring the platelet inhibitory profile of antiplatelet agents in patients undergoing stent implantation. Thromb Res. 2003;111(3):159-64. [pmid: 14678814].
van der Stelt CA, van Werkum JW, Seesing TH, et al. To adjust or not to adjust the platelet count in light transmission aggregometry in patients receiving dual aspirin/clopidogrel treatment. Platelets. Nov. 2007;18(7):550-53. [pmid: 17957573].
van Loon JE, de Jaegere PP, Ulrichts H, et al. The in vitro effect of the new antithrombotic drug candidate ALX-0081 on blood samples of patients undergoing percutaneous coronary intervention. Thromb Haemost. Jul. 2011;106(1):165-71. [pmid: 21655675].
van Werkum JW, Gerritsen WB, Kelder JC, et al. Inhibition of platelet function by abciximab or high-dose tirofiban in patients with STEMI undergoing primary PCI: a randomised trial. Neth Heart J. 2007;15(11):375-81. [pmid: 18176639].
van Werkum JW, Topcu Y, Postma S, et al. Effects of diabetes mellitus on platelet reactivity after dual antiplatelet therapy with aspirin and clopidogrel. Thromb Haemost. Mar. 2008;99(3):637-39. [pmid: 18327417].
van Werkum JW, van der Stelt CA, Seesing TH, et al. The flow cytometric VASP assay can be used to determine the effectiveness of clopidogrel in patients treated with abciximab. J Thromb Haemost. Apr. 2007;5(4):881-83. [pmid: 17263784].
Varon D, Lashevski I, Brenner B, et al. Cone and plate(let) analyzer: monitoring glycoprotein IIb/IIIa antagonists and von Willebrand disease replacement therapy by testing platelet deposition under flow conditions. Am Heart J. May. 1998;135(5 Pt 2 Su):S187-S193. [pmid: 9588399].
Vasilieva E, Kasyanova O, Shpektor A. The antiplatelet effect of atorvastatin in patients with acute coronary syndrome depends on the hs-CRP level. Acute Card Care. 2008;10(3):181-84. [pmid: 18608041].
Velik-Salchner C, Maier S, Innerhofer P, et al. An assessment of cardiopulmonary bypass-induced changes in platelet function using whole blood and classical light transmission aggregometry: the results of a pilot study. Anesth Analg. Jun. 2009;108(6):1747-54. [pmid: 19448196].
Vinholt P, Poulsen TS, Korsholm L, et al. The antiplatelet effect of clopidogrel is not attenuated by statin treatment in stable patients with ischemic heart disease. Thromb Haemost. Aug. 2005;94(2):438-43. [pmid: 16113837].
Vogten JM, Gerritsen WB, Ackerstaff RG, et al. Perioperative microemboli and platelet aggregation in patients undergoing carotid endarterectomy. Vascular. May. 2008;16(3):154-60. [pmid: 18674464].
Volpi E, Giusti L, Ciregia F, et al. Platelet proteome and clopidogrel response in patients with stable angina undergoing percutaneous coronary intervention. Clin Biochem. Jul. 2012;45(10-11):758-65. [pmid: 22486984].
von BN, Kastrati A, Wieczorek A, et al. A double-blind, randomized study on platelet aggregation in patients treated with a daily dose of 150 or 75 mg of clopidogrel for 30 days. Eur Heart J. Aug. 2007;28(15):1814-19. [pmid: 17272357].
von BN, Taubert D, Pogatsa-Murray G, et al. Absorption, metabolization, and antiplatelet effects of 300-, 600-, and 900-mg loading doses of clopidogrel: results of the ISAR-CHOICE (Intracoronary Stenting and Antithrombotic Regimen: Choose Between 3 High Oral Doses for Immediate Clopidogrel Effect) Trial. Circulation. Nov. 8. 2005;112(19):2946-50. [pmid: 16260639].
von LF, Riggert J, Paulus W. Towards a rationale of platelet aggregation monitoring in stroke prophylaxis?. J Stroke Cerebrovasc Dis. Mar. 2009;18(2):111-15. [pmid: 19251186].
Wallentin L, Varenhorst C, James S, et al. Prasugrel achieves greater and faster P2Y12receptor-mediated platelet inhibition than clopidogrel due to more efficient generation of its active metabolite in aspirin-treated patients with coronary artery disease. Eur Heart J. Jan. 2008;29(1):21-30. [pmid: 18055486].
Walter T, Szabo S, Kazmaier S, et al. Effect of clopidogrel on adhesion molecules, hemostasis, and fibrinolysis in coronary heart disease. J Cardiovasc Pharmacol. Jun. 2008;51(6):616-20. [pmid: 18574391].
Walters DL, Ray MJ, Wood P, et al. High-dose tirofiban with enoxaparin and inflammatory markers in high-risk percutaneous intervention. Eur J Clin Invest. Feb. 2010;40(2):139-47. [pmid: 20039931].
Wang XD, Zhang DF, Liu XB, et al. Modified clopidogrel loading dose according to platelet reactivity monitoring in patients carrying ABCB1 variant alleles in patients with clopidogrel resistance. Eur J Intern Med. Jan. 2012;23(1):48-53. [pmid: 22153531].
Warnholtz A, Ostad MA, Velich N, et al. A single loading dose of clopidogrel causes dose-dependent improvement of endothelial dysfunction in patients with stable coronary artery disease: results of a double-blind, randomized study. Atherosclerosis. Feb. 2008;196(2):689-95. [pmid: 17214996].
Wenaweser P, Dorffler-Melly J, Imboden K, et al. Stent thrombosis is associated with an impaired response to antiplatelet therapy. J Am Coll Cardiol. Jun. 7. 2005;45(11):1748-52. [pmid: 15936599].
Wenaweser P, Windecker S, Billinger M, et al. Effect of atorvastatin and pravastatin on platelet inhibition by aspirin and clopidogrel treatment in patients with coronary stent thrombosis. Am J Cardiol. Feb. 1. 2007;99(3):353-56. [pmid: 17261397].
Wheeler GL, Braden GA, Bray PF, et al. Reduced inhibition by abciximab in platelets with the PlA2 polymorphism. Am Heart J. Jan. 2002;143(1):76-82. [pmid: 11773915].
Wiviott SD, Trenk D, Frelinger AL, et al. Prasugrel compared with high loading- and maintenance-dose clopidogrel in patients with planned percutaneous coronary intervention: the Prasugrel in Comparison to Clopidogrel for Inhibition of Platelet Activation and Aggregation-Thrombolysis in Myocardial Infarction 44 trial. Circulation. Dec. 18. 2007;116(25):2923-32. [pmid: 18056526].
Woo JS, Kim W, Lee SR, et al. Platelet reactivity in patients with chronic kidney disease receiving adjunctive cilostazol compared with a high-maintenance dose of clopidogrel: results of the effect of platelet inhibition according to clopidogrel dose in patients with chronic kidney disease (PIANO-2 CKD) randomized study. Am Heart J. Dec. 2011;162(6):1018-25. [pmid: 22137075].
Xiao Z, Theroux P. Clopidogrel inhibits platelet-leukocyte interactions and thrombin receptor agonist peptide-induced platelet activation in patients with an acute coronary syndrome. J Am Coll Cardiol. Jun. 2. 2004;43(11):1982-88. [pmid: 15172401].
Yang TH, Kim DI, Kim DK, et al. Detection of clopidogrel hyporesponsiveness using a point-of-care assay and the impact of additional cilostazol administration after coronary stent implantation in diabetic patients. Korean J Intern Med. Jun. 2011;26(2):145-52. [pmid: 21716590].
Yang TH, Kim DI, Kim JY, et al. Comparison of triple anti-platelet therapy (aspirin, clopidogrel, and cilostazol) and double anti-platelet therapy (aspirin and clopidogrel) on platelet aggregation in type 2 diabetic patients undergoing drug-eluting stent implantation. Korean Circ J. Nov. 2009;39(11):462-66. [pmid: 19997541].
Yang YN, Wang XL, Ma YT, et al. Association of interaction between smoking and CYP 2C19*3 polymorphism with coronary artery disease in a Uighur population. Clin Appl Thromb Hemost. Oct. 2010;16(5):579-83. [pmid: 20460345].
Yedidya I, Netzer A, Vaduganathan M, et al. Clopidogrel tapering as a strategy to attenuate platelet rebound phenomenon in patients with bare-metal stents. J Thromb Thrombolysis. Jan. 2012;33(1):16-21. [pmid: 22081256].
Yong AS, Pennings GJ, Chang M, et al. Intracoronary shear-related up-regulation of platelet P-selectin and platelet-monocyte aggregation despite the use of aspirin and clopidogrel. Blood. Jan. 6. 2011;117(1):11-20. [pmid: 20876457].
Zafar MU, Paz-Yepes M, Shimbo D, et al. Anxiety is a better predictor of platelet reactivity in coronary artery disease patients than depression. Eur Heart J. Jul. 2010;31(13):1573-82. [pmid: 20097703].
Zhang R, Ran HH, Zhu HL, et al. Differential effects of esomeprazole on the antiplatelet activity of clopidogrel in healthy individuals and patients after coronary stent implantation. J Int Med Res. Sep. 2010;38(5):1617-25. [pmid: 21309475].
Zhao L, Fletcher S, Weaver C, et al. Effects of aspirin, clopidogrel and dipyridamole administered singly and in combination on platelet and leucocyte function in normal volunteers and patients with prior ischaemic stroke. Thromb Haemost. Mar. 2005;93(3):527-34. [pmid: 15735805].
Ziegler S, Maca T, Alt E, et al. Monitoring of antiplatelet therapy with the PFA-100 in peripheral angioplasty patients. Platelets. Dec. 2002;13(8):493-97. [pmid: 12487783].
Zuern CS, Geisler T, Lutilsky N, et al. Effect of comedication with proton pump inhibitors (PPIs) on post-interventional residual platelet aggregation in patients undergoing coronary stenting treated by dual antiplatelet therapy. Thromb Res. Feb. 2010;125(2):e51-e54. [pmid: 19781742].

## Insufficient Sample Size

Aktas B, Utz A, Hoenig-Liedl P, et al. Dipyridamole enhances NO/cGMP-mediated vasodilator-stimulated phosphoprotein phosphorylation and signaling in human platelets: in vitro and in vivo/ex vivo studies. Stroke. Mar. 2003;34(3):764-69. [pmid: 12624305].
Aleil B, Ravanat C, Cazenave JP, et al. Flow cytometric analysis of intraplatelet VASP phosphorylation for the detection of clopidogrel resistance in patients with ischemic cardiovascular diseases. J Thromb Haemost. Jan. 2005;3(1):85-92. [pmid: 15634270].
Alstrom U, Granath F, Oldgren J, et al. Platelet inhibition assessed with VerifyNow, flow cytometry and PlateletMapping in patients undergoing heart surgery. Thromb Res. Nov. 2009;124(5):572-77. [pmid: 19631364].
Barone-Rochette G, Ormezzano O, Polack B, et al. Resistance to platelet antiaggregants: an important cause of very late thrombosis of drug eluting stents? Observations from five cases. Arch Cardiovasc Dis. Feb. 2008;101(2):100-07. [pmid: 18398394].
Barragan P, Bouvier JL, Roquebert PO, et al. Resistance to thienopyridines: clinical detection of coronary stent thrombosis by monitoring of vasodilator-stimulated phosphoprotein phosphorylation. Catheter Cardiovasc Interv. Jul. 2003;59(3):295-302. [pmid: 12822144].
Bonello L, Palot-Bonello N, Armero S, et al. Impact of loading dose adjustment on platelet reactivity in homozygotes of the 2C19 2* loss of function polymorphism. Int J Cardiol. Nov. 5. 2010;145(1):165-66. [pmid: 19712984].
Bouman HJ, Parlak E, van Werkum JW, et al. Which platelet function test is suitable to monitor clopidogrel responsiveness? A pharmacokinetic analysis on the active metabolite of clopidogrel. J Thromb Haemost. Mar. 2010;8(3):482-88. [pmid: 20040042].
Carville DG, Schleckser PA, Guyer KE, et al. Whole blood platelet function assay on the ICHOR point-of-care hematology analyzer. J Extra Corpor Technol. Dec. 1998;30(4):171-77. [pmid: 10537577].
Fox SC, Behan MW, Heptinstall S. Inhibition of ADP-induced intracellular Ca2+ responses and platelet aggregation by the P2Y12 receptor antagonists AR-C69931MX and clopidogrel is enhanced by prostaglandin E1. Cell Calcium. Jan. 2004;35(1):39-46. [pmid: 14670370].
Freynhofer MK, Bruno V, Brozovic I, et al. Is increased platelet turnover responsible for low responsiveness to different thienopyridienes? A case report of recurrent stent thromboses. Thromb Haemost. Jul. 2011;106(1):182-84. [pmid: 21544319].
Geiger J, Brich J, Honig-Liedl P, et al. Specific impairment of human platelet P2Y(AC) ADP receptor-mediated signaling by the antiplatelet drug clopidogrel. Arterioscler Thromb Vasc Biol. Aug. 1999;19(8):2007-11. [pmid: 10446085].
Gerrits AJ, Koekman CA, van Haeften TW, et al. Platelet tissue factor synthesis in type 2 diabetic patients is resistant to inhibition by insulin. Diabetes. Jun. 2010;59(6):1487-95. [pmid: 20200314].
Grau AJ, Reiners S, Lichy C, et al. Platelet function under aspirin, clopidogrel, and both after ischemic stroke: a case-crossover study. Stroke. Apr. 2003;34(4):849-54. [pmid: 12637702].
Gremmel T, Steiner S, Seidinger D, et al. Adenosine diphosphate-inducible platelet reactivity shows a pronounced age dependency in the initial phase of antiplatelet therapy with clopidogrel. J Thromb Haemost. Jan. 2010;8(1):37-42. [pmid: 19818001].
Kidson-Gerber G, Weaver J, Gemmell R, et al. Serum thromboxane B2 compared to five other platelet function tests for the evaluation of aspirin effect in stable cardiovascular disease. Heart Lung Circ. Apr. 2010;19(4):234-42. [pmid: 20144559].
Kuliczkowski W, Rychlik B, Chizynski K, et al. Comparison of the VASP assay and platelet aggregometry in the evaluation of platelet P2Y12 receptor blockade. Pol Arch Med Wewn. Apr. 2011;121(4):115-21. [pmid: 21532533].
Lakkis NM, George S, Thomas E, et al. Use of ICHOR-platelet works to assess platelet function in patients treated with GP IIb/IIIa inhibitors. Catheter Cardiovasc Interv. Jul. 2001;53(3):346-51. [pmid: 11458412].
Lev EI, Osende JI, Richard MF, et al. Administration of abciximab to patients receiving tirofiban or eptifibatide: effect on platelet function. J Am Coll Cardiol. Mar. 1. 2001;37(3):847-55. [pmid: 11693761].
Lev EI, Alviar CL, Arikan ME, et al. Platelet reactivity in patients with subacute stent thrombosis compared with non-stent-related acute myocardial infarction. Am Heart J. Jan. 2007;153(1):41-46. [pmid: 17174635].
Linnemann B, Schwonberg J, Rechner AR, et al. Assessment of clopidogrel non-response by the PFA-100 system using the new test cartridge INNOVANCE PFA P2Y. Ann Hematol. Jun. 2010;89(6):597-605. [pmid: 20049442].
Morel O, Bernhard N, Desprez D, et al. Residual prothrombotic status in low responder patients to clopidogrel identified by Vasodilator-Stimulated Phosphoprotein Phosphorylation (VASP) analysis?. Thromb Haemost. Feb. 2008;99(2):448-51. [pmid: 18278200].
Morris A, iprandi-Costa B, Brieger D. Platelet function analysis: a comparison of methods. Int J Cardiol. Nov. 5. 2010;145(1):167-68. [pmid: 19897259].
Mukherjee D, Chew DP, Robbins M, et al. Clinical application of procedural platelet monitoring during percutaneous coronary intervention among patients at increased bleeding risk. J Thromb Thrombolysis. Apr. 2001;11(2):151-54. [pmid: 11406730].
Pena A, Collet JP, Hulot JS, et al. Can we override clopidogrel resistance?. Circulation. Jun. 2. 2009;119(21):2854-57. [pmid: 19487603].
Pinto Slottow TL, Bonello L, Gavini R, et al. Prevalence of aspirin and clopidogrel resistance among patients with and without drug-eluting stent thrombosis. Am J Cardiol. Aug. 15. 2009;104(4):525-30. [pmid: 19660606].
Saha S, Berglund M, Sylven C, et al. Clopidogrel inhibits platelet aggregation in patients on aspirin with stable chronic angina pectoris. Int J Cardiol. Jan. 11. 2008;123(2):195-96. [pmid: 17320208].
Schuhmann CG, Sohn HY, Nagel J, et al. Clinical management of clopidogrel inefficiency by point of care platelet function testing and individual adjustment of anti-platelet therapy--initial experiences. Platelets. Nov. 2009;20(7):498-504. [pmid: 19852689].
Serebruany VL, Midei MG, Meilman H, et al. Platelet inhibition with prasugrel (CS-747) compared with clopidogrel in patients undergoing coronary stenting: the subset from the JUMBO study. Postgrad Med J. Jun. 2006;82(968):404-10. [pmid: 16754711].
Siller-Matula JM, Panzer S, Jilma B. Reproducibility and standardized reporting of the vasodilator-stimulated phosphoprotein phosphorylation assay. Platelets. Nov. 2008;19(7):551-54. [pmid: 18979368].
Singla A, Antonino MJ, Bliden KP, et al. The relation between platelet reactivity and glycemic control in diabetic patients with cardiovascular disease on maintenance aspirin and clopidogrel therapy. Am Heart J. Nov. 2009;158(5):784-86. [pmid: 19853698].
Storey RF, Husted S, Harrington RA, et al. Inhibition of platelet aggregation by AZD6140, a reversible oral P2Y12 receptor antagonist, compared with clopidogrel in patients with acute coronary syndromes. J Am Coll Cardiol. Nov. 6. 2007;50(19):1852-56. [pmid: 17980251].
Yokoi H, Kimura T, Isshiki T, et al. Pharmacodynamic assessment of a novel P2Y12 receptor antagonist in Japanese patients with coronary artery disease undergoing elective percutaneous coronary intervention. Thromb Res. May. 2012;129(5):623-28. [pmid: 22178576].

## No Primary Data

Aalbers J. Obesity and platelet reactivity: the relationship remains uncertain. Cardiovasc J Afr. Jul. 2011;22(4):223. [pmid: 21881696].
Akhlaghi A, Shirani S, Ziaie N, et al. Cytochrome P450 2C19 Polymorphism in Iranian Patients with Coronary Artery Disease. ARYA Atheroscler. 2011;7(3):106-10. [pmid: 22577456].
Alexopoulos D. Regarding the “Platelet reactivity in patients with chronic kidney disease receiving adjunctive cilostazol compared with a high-maintenance dose of clopidogrel: Results of the Effect of Platelet Inhibition According to Clopidogrel Dose in Patients with Chronic Kidney Disease (PIANO-2 CKD) randomized study”. Am Heart J. May. 2012;163(5):e31. [pmid: 22607871].
Alexopoulos D, Xanthopoulou I. Clopidogrel dosing based on genotype. JAMA. Mar. 14. 2012;307(10):1024-25. [pmid: 22416093].
Angiolillo DJ, Ueno M. Optimizing platelet inhibition in clopidogrel poor metabolizers: therapeutic options and practical considerations. JACC Cardiovasc Interv. Apr. 2011;4(4):411-14. [pmid: 21511220].
Aradi D, Komocsi A, Vorobcsuk A, et al. Prognostic significance of high on-clopidogrel platelet reactivity after percutaneous coronary intervention: systematic review and meta-analysis. Am Heart J. Sep. 2010;160(3):543-51. [pmid: 20826265].
Becker RC, Gurbel PA. Platelet P2Y12 receptor antagonist pharmacokinetics and pharmacodynamics: A foundation for distinguishing mechanisms of bleeding and anticipated risk for platelet-directed therapies. Thromb Haemost. Mar. 2010;103(3):535-44. [pmid: 20135066].
Beitelshees AL, Horenstein RB, Vesely MR, et al. Pharmacogenetics and clopidogrel response in patients undergoing percutaneous coronary interventions. Clin Pharmacol Ther. Mar. 2011;89(3):455-59. [pmid: 21270785].
Bergmeijer TO, ten Berg JM. Value of CYP2C19 *2 and *17 genotyping in clinical practice. Promising but not ready yet. Rev Esp Cardiol (Engl Ed). Mar. 2012;65(3):205-07. [pmid: 22284726].
Bhattacharyya S, Rakhit R. Cytochrome P450 2C19 polymorphism and clopidogrel after MI. Lancet. Apr. 4. 2009;373(9670):1171-73. [pmid: 19345825].
Biondi-Zoccai G, Lotrionte M, Sheiban I. Overcoming “resistance” to aspirin and clopidogrel with tirofiban: fact or fiction?. Thromb Haemost. Oct. 2008;100(4):521-22. [pmid: 18841270].
Bisdas T, Haverich A, Teebken OE. The unknown effect of clopidogrel resistance in dual antiplatelet therapies after coronary artery bypass grafting. J Am Coll Cardiol. Aug. 30. 2011;58(10):1085-86. [pmid: 21867852].
Blann AD, Draper Z. Platelet activation as a marker of heart attack. Clin Chim Acta. May. 12. 2011;412(11-12):841-42. [pmid: 21338595].
Bonello L, Camoin-Jau L, gnat-George F, et al. A threshold of platelet reactivity for ischaemic events?. Eur Heart J. Sep. 2008;29(17):2185-86. [pmid: 18617480].
Brar SS, ten BJ, Marcucci R, et al. Impact of platelet reactivity on clinical outcomes after percutaneous coronary intervention. A collaborative meta-analysis of individual participant data. J Am Coll Cardiol. Nov. 1. 2011;58(19):1945-54. [pmid: 22032704].
Braunwald E, Angiolillo D, Bates E, et al. Antiplatelet therapy and platelet function testing. Clin Cardiol. Mar. 2008;31(3 Suppl 1):I36. [pmid: 18481821].
Broderick JP. Evidence against rapid reversal of antiplatelet medications in acute intracerebral hemorrhage. Neurology. Apr. 21. 2009;72(16):1376-77. [pmid: 19129503].
Cattaneo M. Tailored treatment with clopidogrel based on the results of platelet function tests should not be implemented, in the absence of clear indications on the methodology to be used. G Ital Cardiol (Rome). Mar. 2011;12(3):172-73. [pmid: 21560472].
Chin CT, Roe MT, Fox KA, et al. Study design and rationale of a comparison of prasugrel and clopidogrel in medically managed patients with unstable angina/non-ST-segment elevation myocardial infarction: the TaRgeted platelet Inhibition to cLarify the Optimal strateGy to medicallY manage Acute Coronary Syndromes (TRILOGY ACS) trial. Am Heart J. Jul. 2010;160(1):16-22. [pmid: 20598967].
Collet JP, Cayla G, Cuisset T, et al. Randomized comparison of platelet function monitoring to adjust antiplatelet therapy versus standard of care: rationale and design of the assessment with a double randomization of (1) a fixed dose versus a monitoring-guided dose of aspirin and clopidogrel after DES implantation, and (2) treatment interruption versus continuation, 1 year after stenting (ARCTIC) study. Am Heart J. Jan. 2011;161(1):5-12. [pmid: 21167334].
Combescure C, Fontana P, Mallouk N, et al. Clinical implications of clopidogrel non-response in cardiovascular patients: a systematic review and meta-analysis. J Thromb Haemost. May. 2010;8(5):923-33. [pmid: 20156305].
Cuisset T, Frere C, Quilici J, et al. Adjusting clopidogrel loading doses according to vasodilator-stimulated phosphoprotein index: on time, too early, or too late?. J Am Coll Cardiol. Aug. 26. 2008;52(9):790-91. [pmid: 18718431].
Cuisset T, Morange PE, Alessi MC. High residual platelet reactivity and thrombotic events. JAMA. Dec. 21. 2011;306(23):2561-62. [pmid: 22187272].
Curzen N, Sambu N. Antiplatelet therapy in percutaneous coronary intervention: is variability of response clinically relevant?. Heart. Sep. 2011;97(17):1433-40. [pmid: 21821634].
Daniel A, Pinter T, Horvath IG, et al. Variability in response to clopidogrel: where is the threshold for ‘low response’?. Eur Heart J. Feb. 2007;28(4):515-16. [pmid: 17289747].
De Miguel CA, Nieto AD, Perez de PA. Letter by De Miguel Castro et al regarding article, “Platelet reactivity and cardiovascular outcomes after percutaneous coronary intervention: a time-dependent analysis of the gauging responsiveness with a VerifyNow P2Y12 assay: impact on Thrombosis and Safety (GRAVITAS) trial”. Circulation. Apr. 10. 2012;125(14):e570-e572. [pmid: 22492956].
Doraiswamy VA. Letter by Doraiswamy regarding article, “Intensifying platelet inhibition with tirofiban in poor responders to aspirin, clopidogrel, or both agents undergoing elective coronary intervention: results from the double-blind, prospective, randomized Tailoring Treatment with Tirofiban in Patients Showing Resistance to Aspirin and/or Resistance to Clopidogrel study”. Circulation. Mar. 9. 2010;121(9):e235. [pmid: 20212290].
Drouet L. Prescription, monitoring of antithrombotic treatment: 1--antiplatelet agents. Rev Prat. Nov. 30. 2007;57(18):2045-50. [pmid: 18326440].
Fattorutto M. Measurement of the effect of ticlopidine with the platelet function analyser (PFA-100) during coronary stent implantation. Am Heart J. Sep. 2003;146(3):E8. [pmid: 12947379].
Fileti L, Campo G, Valgimigli M. Latest clinical data on testing for high on-treatment platelet reactivity. Rev Cardiovasc Med. Suppl 1. 2011;12:S14-S22. [pmid: 22080983].
Fontana P, de MP, Reny JL. Platelet hyperreactivity and dual antiplatelet therapy: can biases be avoided?. J Thromb Haemost. Feb. 2009;7(2):363-64. [pmid: 19036060].
Fosburgh D. Aspirin and clopidogrel resistance. Mayo Clin Proc. Jul. 2006;81(7):989. [pmid: 16835978].
Freedman JE, Hylek EM. Clopidogrel, genetics, and drug responsiveness. N Engl J Med. Jan. 22. 2009;360(4):411-13. [pmid: 19164193].
Frelinger AL III, Michelson AD. Clopidogrel linking evaluation of platelet response variability to mechanism of action. J Am Coll Cardiol. Aug. 16. 2005;46(4):646-47. [pmid: 16098429].
Fuster V, Sweeny JM. Clopidogrel and the reduced-function CYP2C19 genetic variant: a limited piece of the overall therapeutic puzzle. JAMA. Oct. 27. 2010;304(16):1839-40. [pmid: 20978263].
Gaborit B, Cuisset T, Frere C, et al. Glycemic control and clopidogrel response. Am Heart J. Jun. 2010;159(6):e35. [pmid: 20569701].
Gasparovic H, Petricevic M, Biocina B. Reduction of thienopyridine-associated bleeding using multiple electrode whole-blood aggregometry. Ann Thorac Surg. Aug. 2011;92(2):778-79. [pmid: 21801953].
Gawaz M, Geisler T. Coronary artery disease: Platelet activity: an obstacle for successful PCI. Nat Rev Cardiol. Jun. 2009;6(6):391-92. [pmid: 19471282].
Ge J, Zhu J, Hong BK, et al. Prasugrel versus clopidogrel in Asian patients with acute coronary syndromes: design and rationale of a multi-dose, pharmacodynamic, phase 3 clinical trial. Curr Med Res Opin. Sep. 2010;26(9):2077-85. [pmid: 20629598].
Geisler T, Bigalke B, Schwab M. CYP2C19 genotype and outcomes of clopidogrel treatment. N Engl J Med. Feb. 3. 2011;364(5):481. [pmid: 21288102].
Gorelick PB, Hanley DF Jr. Clopidogrel and its use in stroke patients. Stroke. Aug. 1998;29(8):1737. [pmid: 9707220].
Granada JF, Price MJ, French PA, et al. Platelet-mediated thrombosis and drug-eluting stents. Circ Cardiovasc Interv. Dec. 1. 2011;4(6):629-37. [pmid: 22186107].
Grove EL, Hvas AM, Kristensen SD. Platelet function testing in atherothrombotic disease: steps forward in managing resistance to antiplatelet therapy. Kardiol Pol. Apr. 2008;66(4):478-79. [pmid: 19496276].
Gurbel PA, Tantry US, Shuldiner AR. Letter by Gurbel et al regarding article, “Cytochrome 2C19*17 allelic variant, platelet aggregation, bleeding events, and stent thrombosis in clopidogrel-treated patients with coronary stent placement”. Circulation. Oct. 5. 2010;122(14):e478. [pmid: 20921447].
Guzauskas GF, Hughes DA, Bradley SM, et al. A risk-benefit assessment of prasugrel, clopidogrel, and genotype-guided therapy in patients undergoing percutaneous coronary intervention. Clin Pharmacol Ther. May. 2012;91(5):829-37. [pmid: 22453194].
Hall HM, Banerjee S, McGuire DK. Variability of clopidogrel response in patients with type 2 diabetes mellitus. Diab Vasc Dis Res. Oct. 2011;8(4):245-53. [pmid: 21933840].
Hnid K, Chtioui M. Letter by Hnid and Chtioui regarding article, “Clinical events as a function of proton pump inhibitor use, clopidogrel use, and cytochrome P450 2C19 genotype in a large nationwide cohort of acute myocardial infarction: results from the French Registry of Acute ST-Elevation and Non-ST-Elevation Myocardial Infarction (FAST-MI) Registry”. Circulation. Sep. 13. 2011;124(11):e297. [pmid: 21911791].
Horowitz JD, Chirkov YY. Identifying clopidogrel resistance during chronic therapy: the case for a biochemical approach. Thromb Haemost. Oct. 2008;100(4):519-20. [pmid: 18841269].
Hulot JS, Collet JP, Silvain J, et al. Cardiovascular risk in clopidogrel-treated patients according to cytochrome P450 2C19*2 loss-of-function allele or proton pump inhibitor coadministration: a systematic meta-analysis. J Am Coll Cardiol. Jul. 6. 2010;56(2):134-43. [pmid: 20620727].
Hulot JS, Collet JP, Montalescot G. Genetic substudy of the PLATO trial. Lancet. Feb. 19. 2011;377(9766):637. author-8. [pmid: 21334530].
Jagroop IA, Malley M, Mikhailidis DP. Effect of clopidogrel on platelet aggregation and plasma concentration of fibrinogen in subjects with cerebral or coronary atherosclerotic disease. Clin Appl Thromb Hemost. Oct. 2002;8(4):381-82. [pmid: 12516689].
Jeong YH, Bliden KP, Tantry US, et al. The role of platelet function testing and genotyping in the stented patient treated with clopidogrel. J Am Coll Cardiol. Dec. 13. 2011;58(25):2701-02. [pmid: 22152965].
Jeremias A, Gruberg L. Provisional use of glycoprotein IIb/IIIa inhibitors in the era of dual antiplatelet therapy--do “bailouts” pay off?. J Invasive Cardiol. Jun. 2009;21(6):264-65. [pmid: 19494401].
Jilma B. Platelet function analyzer (PFA-100): a tool to quantify congenital or acquired platelet dysfunction. J Lab Clin Med. Sep. 2001;138(3):152-63. [pmid: 11528368].
Jilma B. Synergistic antiplatelet effects of clopidogrel and aspirin detected with the PFA-100 in stroke patients. Stroke. Apr. 2003;34(4):849-54. [pmid: 12680383].
Jin B, Ni HC, Shen W, et al. Cytochrome P450 2C19 polymorphism is associated with poor clinical outcomes in coronary artery disease patients treated with clopidogrel. Mol Biol Rep. Mar. 2011;38(3):1697-702. [pmid: 20845077].
Kalyanasundaram A, Berger PB. Routine platelet testing should not be performed on all patients undergoing percutaneous coronary intervention. Circ Cardiovasc Interv. Jun. 1. 2010;3(3):284-87. [pmid: 20551395].
Kamphuisen PW. Thrombogenicity in patients with percutaneous coronary artery intervention and dual antiplatelet treatment. Eur Heart J. Jul. 2008;29(14):1699-700. [pmid: 18544543].
Kleiman NS. Could clopidogrel's platelet inhibition be enhanced by an increased loading dose and eptifibatide?. Nat Clin Pract Cardiovasc Med. Jul. 2005;2(7):344-45. [pmid: 16265559].
Kuliczkowski W. Pharmacogenetics of antiplatelet therapy- is it time for to evaluate polymorphism?. Kardiol Pol. Aug. 2009;67(8):835-36. [pmid: 19885980].
Lee SP, Suh JW, Park KW, et al. Study design and rationale of ‘Influence of Cilostazol-based triple anti-platelet therapy on ischemic complication after drug-eluting stent implantation (CILON-T)’ study: A multicenter randomized trial evaluating the efficacy of Cilostazol on ischemic vascular complications after drug-eluting stent implantation for coronary heart disease. Trials. 2010;11:87. [pmid: 20735821].
Li Y, Tang HL, Hu YF, et al. The gain-of-function variant allele CYP2C19*17: a double-edged sword between thrombosis and bleeding in clopidogrel-treated patients. J Thromb Haemost. Feb. 2012;10(2):199-206. [pmid: 22123356].
Lin GM, Li YH. Comparison of 600 versus 300-mg clopidogrel loading dose in patients with ST-segment elevation myocardial infarction undergoing primary coronary angioplasty. Am J Cardiol. Feb. 15. 2011;107(4):641. [pmid: 21295179].
Ma YT, Xie X. Impact of genetic polymorphisms on efficacy of antiplatelet therapy. Zhonghua Xin Xue Guan Bing Za Zhi. Jul. 2011;39(7):674-76. [pmid: 22088252].
Mahmud E, Ang L. Platelet function testing in practice: a case study. Rev Cardiovasc Med. Suppl 1. 2011;12:S34-S39. [pmid: 22080985].
Mallouk N, Labruyere C, Reny JL, et al. Prevalence of poor biological response to clopidogrel: a systematic review. Thromb Haemost. Mar. 2012;107(3):494-506. [pmid: 22273694].
Marian AJ. Cytochrome p-450 polymorphisms and response to clopidogrel. Curr Atheroscler Rep. May. 2009;11(3):157-60. [pmid: 19361345].
Masood I. Comparative effect of antiplatelet therapy in retinal vein occlusion evaluated by the particle-counting method using light scattering. Am J Ophthalmol. Jul. 2005;140(1):167. [pmid: 16038677].
McLean DS, Cannon CP. The clinical potential of a point-of-care assay to assess interindividual variability in platelet aggregation among patients taking clopidogrel. Crit Pathw Cardiol. Jun. 2006;5(2):103-13. [pmid: 18340222].
McLean DS, Cannon CP. A point-of-care assay to measure platelet aggregation in patients taking clopidogrel. Future Cardiol. May. 2006;2(3):255-67. [pmid: 19804082].
Mearns BM. Pharmacogenetics: Ticagrelor superior to clopidogrel in individuals predicted to be clopidogrel responders. Nat Rev Cardiol. Jan. 2011;8(1):4. [pmid: 21218558].
Mega JL, Simon T, Collet JP, et al. Reduced-function CYP2C19 genotype and risk of adverse clinical outcomes among patients treated with clopidogrel predominantly for PCI: a meta-analysis. JAMA. Oct. 27. 2010;304(16):1821-30. [pmid: 20978260].
Mega JL, Topol EJ, Sabatine MS. CYP2C19 genotype and cardiovascular events. JAMA. Apr. 11. 2012;307(14):1482-83. [pmid: 22496256].
Miao J, Liu R, Li Z. Cytochrome P-450 polymorphisms and response to clopidogrel. N Engl J Med. May. 21. 2009;360(21):2250-51. [pmid: 19469033].
Miao J, Liu R, Li Z. Cytochrome P450 2C19 polymorphism and clopidogrel after MI. Lancet. Apr. 4. 2009;373(9670):1171-72. [pmid: 19345824].
Michelson AD. Platelet function testing in cardiovascular diseases. Circulation. Nov. 9. 2004;110(19):e489-e493. [pmid: 15533872].
Montalescot G, Bolognese L, Dudek D, et al. A comparison of prasugrel at the time of percutaneous coronary intervention or as pretreatment at the time of diagnosis in patients with non-ST-segment elevation myocardial infarction: design and rationale for the ACCOAST study. Am Heart J. Apr. 2011;161(4):650-56. [pmid: 21473962].
Mustard JF, Kinlough-Rathbone RL, Jenkins CS, et al. Modification of platelet function. Ann N Y Acad Sci. Oct. 27. 1972;201:343-59. [pmid: 4405310].
Nezami N, Nargabad ON, Ghorashi S. Letter by Nezami et al regarding article, “Platelet reactivity and cardiovascular outcomes after percutaneous coronary intervention: a time-dependent analysis of the gauging responsiveness with a VerifyNow P2Y12 assay: impact on thrombosis and safety (GRAVITAS) trial”. Circulation. Apr. 10. 2012;125(14):e569-2. [pmid: 22492955].
Nissen SE. Pharmacogenomics and clopidogrel: irrational exuberance?. JAMA. Dec. 28. 2011;306(24):2727-28. [pmid: 22203545].
O'Connor SK, Ferreri SP, Michaels NM, et al. Exploratory planning and implementation of a pilot pharmacogenetic program in a community pharmacy. Pharmacogenomics. Jun. 2012;13(8):955-62. [pmid: 22676199].
Osnabrugge RL, Kappetein AP, Janssens AC. Carriage of reduced-function CYP2C19 allele among patients treated with clopidogrel. JAMA. Feb. 2. 2011;305(5):467-68. [pmid: 21285422].
Palabrica TM, Burton PB. Letter regarding article by Patti et al, “Randomized trial of high loading dose of clopidogrel for reduction of periprocedural myocardial infarction in patients undergoing coronary intervention: results from the ARMYDA-2 (Antiplatelet therapy for Reduction of MYocardial Damage during Angioplasty) study”. Circulation. Oct. 25. 2005;112(17):e282-e283. [pmid: 16250083].
Pare G, Eikelboom JW, Sibbing D, et al. Testing should not be done in all patients treated with clopidogrel who are undergoing percutaneous coronary intervention. Circ Cardiovasc Interv. Oct. 1. 2011;4(5):514-21. [pmid: 22010190].
Perez de PA, Cuellas C, Diego A, et al. Platelet reactivity and stent thrombosis: still some issues to solve. J Am Coll Cardiol. Aug. 11. 2009;54(7):666-67. [pmid: 19660707].
Peters BJ, Harmsze AM, ten Berg JM, et al. CYP2C19 and ABCB1 genes and individualized treatment with clopidogrel. Pharmacogenomics. Feb. 2011;12(2):141-44. [pmid: 21332306].
Petricevic M, Biocina B. Letter by Petricevic and Biocina regarding article, “Platelet function measurement-based strategy to reduce bleeding and waiting time in clopidogrel-treated patients undergoing coronary artery bypass graft surgery: the Timing Based on Platelet Function Strategy to Reduce Clopidogrel-Associated Bleeding Related to CABG (TARGET-CABG) Study”. Circ Cardiovasc Interv. Jun. 2012;5(3):e47. [pmid: 22715457].
Price MJ, Berger PB, Angiolillo DJ, et al. Evaluation of individualized clopidogrel therapy after drug-eluting stent implantation in patients with high residual platelet reactivity: design and rationale of the GRAVITAS trial. Am Heart J. May. 2009;157(5):818-24. 824. [pmid: 19376306].
Price MJ. The evidence base for platelet function testing in patients undergoing percutaneous coronary intervention. Circ Cardiovasc Interv. Jun. 1. 2010;3(3):277-83. [pmid: 20551394].
Price MJ, Tantry US, Gurbel PA. The influence of CYP2C19 polymorphisms on the pharmacokinetics, pharmacodynamics, and clinical effectiveness of P2Y(12) inhibitors. Rev Cardiovasc Med. 2011;12(1):1-12. [pmid: 21546883].
Price MJ, Barker CM. Functional testing methods for the antiplatelet effect of P2Y12 receptor antagonists. Biomark Med. Feb. 2011;5(1):43-51. [pmid: 21319964].
Rajan L, Moliterno DJ. Options and outcomes with different antiplatelet strategies during primary percutaneous coronary intervention. Eur Heart J. Jul. 2009;30(14):1687-89. [pmid: 19429914].
Ramaraj R. Cytochrome P450 2C19 polymorphism and clopidogrel after MI. Lancet. Apr. 4. 2009;373(9670):1172-73. [pmid: 19345827].
Ramirez AH, Delaney JT, Shuldiner AR. Carrying one or two reduced-function CYP2C19 alleles is associated with an increased risk of major adverse cardiovascular events in people undergoing percutaneous coronary intervention and treated with clopidogrel. Evid Based Med. Aug. 2011;16(4):124-25. [pmid: 21705400].
Rao GH. Need for a point-of-care assay for monitoring antiplatelet and antithrombotic therapies. Stroke. Jun. 2009;40(6):2271-72. [pmid: 19407237].
Rechner AR. Platelet function testing in clinical diagnostics. Hamostaseologie. May. 2. 2011;31(2):79-87. [pmid: 21152677].
Ringelstein. Effect of the combination clopidogrel plus aspirin on silent cerebral microemboli and platelet activation, in patients with nonoperated symptomatic carotid stenosis (CARESS: clopidogrel and aspirin for reduction of emboli in symptomatic carotid stenosis).
Schafer AI. Genetic and acquired determinants of individual variability of response to antiplatelet drugs. Circulation. Aug. 26. 2003;108(8):910-11. [pmid: 12939239].
Scheen AJ, Legrand D. Aspirin and clopidogrel resistance in patients with diabetes mellitus. Eur Heart J. Dec. 2006;27(23):2900-01. [pmid: 17015405].
Schror K, Weber AA, Hohlfeld T. Clopidogrel “resistance”. Thromb Haemost. Aug. 2004;92(2):229-31. [pmid: 15269816].
Schror K, Weber AA, Hohlfeld T. Clopidogrel “resistance” and statin cotreatment - significant for cardiocoronary prevention in real life?. Thromb Haemost. Aug. 2005;94(2):235-37. [pmid: 16113810].
Serebruany VL, Steinhubl SR, Hennekens CH. Are antiplatelet effects of clopidogrel inhibited by atorvastatin? A research question formulated but not yet adequately tested. Circulation. Apr. 1. 2003;107(12):1568-69. [pmid: 12668486].
Serebruany VL. The “clopidogrel resistance” trap. Am J Cardiol. Sep. 15. 2007;100(6):1044-46. [pmid: 17826395].
Serebruany VL, Goto S. The challenge of monitoring platelet response after clopidogrel. Eur Heart J. Dec. 2008;29(23):2833-34. [pmid: 18977768].
Serebruany VL. Current concepts targeting antiplatelet ‘resistance’. Kardiol Pol. Apr. 2008;66(4):477. [pmid: 19496278].
Shantsila E, Lip GY. Beyond glucose levels in diabetic patients with coronary artery disease: platelet activity and non-responsiveness to antiplatelet therapy. Thromb Haemost. Jul. 2008;100(1):7-8. [pmid: 18612528].
Shuldiner AR, Vesely MR, Fisch A. CYP2C19 genotype and cardiovascular events. JAMA. Apr. 11. 2012;307(14):1482-85. [pmid: 22496255].
Siasos G, Tousoulis D, Stefanadis C. CYP2C19 genotype and outcomes of clopidogrel treatment. N Engl J Med. Feb. 3. 2011;364(5):481-82. [pmid: 21288101].
Siasos G, Tousoulis D, Stefanadis C. CYP2C19 genotype and cardiovascular events. JAMA. Apr. 11. 2012;307(14):1483-84. [pmid: 22496257].
Silvain J, Cayla G, Hulot JS, et al. High on-thienopyridine platelet reactivity in elderly coronary patients: the SENIOR-PLATELET study. Eur Heart J. May. 2012;33(10):1241-49. [pmid: 22067090].
Sofi F, Marcucci R, Gori AM, et al. Clopidogrel non-responsiveness and risk of cardiovascular morbidity. An updated meta-analysis. Thromb Haemost. Apr. 2010;103(4):841-48. [pmid: 20135063].
SoRelle R. Clopidogrel resistance marks recurrent risks. Circulation. Jun. 29. 2004;109(25):e9054-e9055. [pmid: 15226243].
Sorich MJ, Vitry A, Ward MB, et al. Prasugrel vs. clopidogrel for cytochrome P450 2C19-genotyped subgroups: integration of the TRITON-TIMI 38 trial data. J Thromb Haemost. Aug. 2010;8(8):1678-84. [pmid: 20492467].
Stegnar M. Platelet function tests and resistance to antiplatelet therapy. Srp Arh Celok Lek. Jan. Suppl 1. 2010;138:59-63. [pmid: 20229685].
Steinhubl SR. Genotyping, clopidogrel metabolism, and the search for the therapeutic window of thienopyridines. Circulation. Feb. 2. 2010;121(4):481-83. [pmid: 20083686].
Steinhubl SR. The illusion of “optimal” platelet inhibition. JACC Cardiovasc Interv. Mar. 2012;5(3):278-80. [pmid: 22440492].
Storey RF. Clopidogrel in acute coronary syndrome: to genotype or not?. Lancet. Jan. 24. 2009;373(9660):276-78. [pmid: 19108882].
Tantry US, Jeong YH, Navarese EP, et al. Platelet function measurement in elective percutaneous coronary intervention patients: exploring the concept of a P2Y(1)(2) inhibitor therapeutic window. JACC Cardiovasc Interv. Mar. 2012;5(3):290-92. [pmid: 22440494].
ten Berg JM, Deneer VH. Antiplatelet therapy: Does CYP2C19 genotype affect clinical outcome?. Nat Rev Cardiol. Apr. 2012;9(4):192-94. [pmid: 22411289].
Tricoci P, Harrington RA, Valgimigli M. Letter regarding article by Patti et al, “Randomized trial of high loading dose of clopidogrel for reduction of periprocedural myocardial infarction in patients undergoing coronary intervention: results from the ARMYDA-2 (Antiplatelet therapy for Reduction of MYocardial Damage during Angioplasty) study”. Circulation. Oct. 25. 2005;112(17):e282. [pmid: 16246954].
Turgeon J, Pharand C, Michaud V. Understanding clopidogrel efficacy in the presence of cytochrome P450 polymorphism. CMAJ. Jun. 6. 2006;174(12):1729. [pmid: 16754901].
van Werkum JW, Heestermans AA, Plokker HW, et al. Clinical, biochemical and genetical resistance to clopidogrel in a patient with recurrent stent thrombosis. Int J Cardiol. Mar. 2. 2007;116(1):136-37. [pmid: 16870279].
van Werkum JW, Harmsze AM, Elsenberg EH, et al. The use of the VerifyNow system to monitor antiplatelet therapy: a review of the current evidence. Platelets. Nov. 2008;19(7):479-88. [pmid: 18979359].
Vassiliou V. Double-dose clopidogrel in patients undergoing PCI for ACS. Lancet. Jan. 22. 2011;377(9762):297. [pmid: 21256377].
Walter T. Influence of a therapy with Clopidogrel on the activation of platelet leukocytes and the endothelium in patients with stable angina pectoris. Zeitschrift Fur Kardiologie. 2002;91(Supplement 1).
Warner TD, Mitchell JA, Kirkby NS. Short thromboelastography and the identification of high platelet reactivity while on and off therapy. Heart. May. 2012;98(9):679-80. [pmid: 22523052].
Wiviott SD, Antman EM, Gibson CM, et al. Evaluation of prasugrel compared with clopidogrel in patients with acute coronary syndromes: design and rationale for the TRial to assess Improvement in Therapeutic Outcomes by optimizing platelet InhibitioN with prasugrel Thrombolysis In Myocardial Infarction 38 (TRITON-TIMI 38). Am Heart J. Oct. 2006;152(4):627-35. [pmid: 16996826].
Wiwanitkit V. CYP2C19 gene variants cut-off levels for on-clopidogrel platelet aggregation. Thromb Res. Feb. 2012;129(2):212. [pmid: 22030270].
Xydakis. The combination of clopidogrel (cl) and acetylsalicylic acid (asa) inhibits more effective the platelet activation in haemodialysis patients with acute coronary syndromes (acs) and high c reactive protein. 41st Congress European Renal Association European Dialysis and Transplantation Association. 2004. <[31] UNIQUE ID (DOI)>.
Yamazaki M, Uchiyama S. Platelet function under aspirin, clopidogrel, and both after ischemic stroke: a case-crossover study. Stroke. Dec. 2003;34(12):e227-e228. [pmid: 14631085].
Yang L, Valdes R Jr., Taubert D, et al. A diagnostic informatics approach for stratifying risk outcome based on combined genotype effects. Ther Drug Monit. Jun. 2012;34(3):283-88. [pmid: 22549497].
Zhao L, Fletcher S, Weaver C, et al. The effects of three anti-platelet drugs (aspirin, clopidogrel, dipyridamole) given singly or together on platelet and leukocyte function in healthy subjects and patients with previous ischemic stroke. Journal of Thrombosis and Haemostasis. 2003;1(Supplement 1).
Zhu B, Effron MB, Kulkarni MP, et al. The onset of inhibition of platelet aggregation with prasugrel compared with clopidogrel loading doses using gatekeeping analysis of integrated clinical pharmacology data. J Cardiovasc Pharmacol. Mar. 2011;57(3):317-24. [pmid: 21266916].

## Not Study Design of Interest

Benzon HT, Fragen R, Benzon HA, et al. Clopidogrel and neuraxial block: the role of the PFA II and P2Y12 assays. Reg Anesth Pain Med. Jan. 2010;35(1):115. [pmid: 20048663].
Bouman HJ, van Werkum JW, Breet NJ, et al. A case-control study on platelet reactivity in patients with coronary stent thrombosis. J Thromb Haemost. May. 2011;9(5):909-16. [pmid: 21382172].
Brar SS, ten BJ, Marcucci R, et al. Impact of platelet reactivity on clinical outcomes after percutaneous coronary intervention. A collaborative meta-analysis of individual participant data. J Am Coll Cardiol. Nov. 1. 2011;58(19):1945-54. [pmid: 22032704].
Briongos FS, Salido-Tahoces L, de Juan-Baguda J, et al. Multiple arterial thrombosis and resistance to conventional antiaggregation. Rev Esp Cardiol. Sep. 2011;64(9):836-37. [pmid: 21497975].
Campo G, Valgimigli M, Carrescia C, et al. Tailored medical and interventional therapy against recurrent stent thrombosis after drug-eluting stenting. Clin Appl Thromb Hemost. Oct. 2010;16(5):591-93. [pmid: 19520678].
Capranzano P, Tamburino C, Capodanno D, et al. Platelet function profiles in the elderly: results of a pharmacodynamic study in patients on clopidogrel therapy and effects of switching to prasugrel 5 mg in patients with high platelet reactivity. Thromb Haemost. Dec. 2011;106(6):1149-57. [pmid: 22011914].
Dick RJ, Dear AE, Byron KA. Clopidogrel Resistance: case reports of CYP2C19 gene variants in suspected coronary stent thrombosis. Heart Lung Circ. Oct. 2011;20(10):657-58. [pmid: 21215696].
Hobson AR, Petley G, Morton G, et al. Point-of-care platelet function assays demonstrate reduced responsiveness to clopidogrel, but not aspirin, in patients with Drug-Eluting Stent Thrombosis whilst on dual antiplatelet therapy. Thromb J. 2008;6:1. [pmid: 18312665].
Jung HJ, Sir JJ. Recurrent myocardial infarction due to one subacute and two very late thrombotic events of drug-eluting stent associated with clopidogrel resistance. J Invasive Cardiol. Feb. 2011;23(2):E15-E18. [pmid: 21297211].
Mazur P, Frolow M, Nizankowski R, et al. Impaired responsiveness to clopidogrel and aspirin in patients with recurrent stent thrombosis following percutaneous intervention for peripheral artery disease. Platelets. 2013;24(2):151-55. [pmid: 22497730].
Notarangelo MF, Marziliano N, Giacalone R, et al. Stent thrombosis and clopidogrel response variability: is the genetic test useful in clinical practice?. G Ital Cardiol (Rome). Oct. 2011;12(10):686-89. [pmid: 21947114].
Nyiro G, Inczedy-Farkas G, Remenyi V, et al. The effect of the CYP 2C19*2 polymorphism on stroke care. Acta Physiol Hung. Mar. 2012;99(1):33-39. [pmid: 22425806].
Park SJ, Oh IY, Kim KH, et al. Minimal withdrawal of dual antiplatelet agents under the guidance of a point-of-care platelet activity assay early after drug-eluting stent implantation for surgical removal of renal cell carcinoma. Int J Cardiol. Jun. 2. 2011;149(2):e85-e87. [pmid: 19477540].
Rajendran S, Parikh D, Shugman I, et al. High on treatment platelet reactivity and stent thrombosis. Heart Lung Circ. Aug. 2011;20(8):525-31. [pmid: 21592858].
Reese ES, Daniel MC, Beitelshees AL, et al. Cost-effectiveness of cytochrome P450 2C19 genotype screening for selection of antiplatelet therapy with clopidogrel or prasugrel. Pharmacotherapy. Apr. 2012;32(4):323-32. [pmid: 22461122].

## Not Test of Interest

Ahn JC, Song WH, Kwon JA, et al. Effects of cilostazol on platelet activation in coronary stenting patients who already treated with aspirin and clopidogrel. Korean J Intern Med. Dec. 2004;19(4):230-36. [pmid: 15683111].
Ahnadi CE, Boughrassa FF, Chapman-Montgomery ES, et al. Comparison of two methods to assess variability of platelet response to anti-platelet therapies in patients with acute coronary syndrome undergoing angioplasty. Thromb Haemost. Dec. 2004;92(6):1207-13. [pmid: 15583725].
Angiolillo DJ, Fernandez-Ortiz A, Bernardo E, et al. Lack of association between the P2Y12 receptor gene polymorphism and platelet response to clopidogrel in patients with coronary artery disease. Thromb Res. 2005;116(6):491-97. [pmid: 16181985].
Angiolillo DJ, Fernandez-Ortiz A, Bernardo E, et al. Contribution of gene sequence variations of the hepatic cytochrome P450 3A4 enzyme to variability in individual responsiveness to clopidogrel. Arterioscler Thromb Vasc Biol. Aug. 2006;26(8):1895-900. [pmid: 16645157].
Assali AR, Salloum J, Sdringola S, et al. Effects of clopidogrel pretreatment before percutaneous coronary intervention in patients treated with glycoprotein IIb/IIIa inhibitors (abciximab or tirofiban). Am J Cardiol. Oct. 15. 2001;88(8):884-6. A6. [pmid: 11676953].
Azar RR, Kassab R, Zoghbi A, et al. Effects of clopidogrel on soluble CD40 ligand and on high-sensitivity C-reactive protein in patients with stable coronary artery disease. Am Heart J. Feb. 2006;151(2):521. [pmid: 16442924].
Bedard E, Rodes-Cabau J, Houde C, et al. Enhanced thrombogenesis but not platelet activation is associated with transcatheter closure of patent foramen ovale in patients with cryptogenic stroke. Stroke. Jan. 2007;38(1):100-04. [pmid: 17122434].
Bhatt DL, Marso SP, Hirsch AT, et al. Amplified benefit of clopidogrel versus aspirin in patients with diabetes mellitus. Am J Cardiol. Sep. 15. 2002;90(6):625-28. [pmid: 12231089].
Bi M, Ma Q, Zhang S, et al. Local mild hypothermia with thrombolysis for acute ischemic stroke within a 6-h window. Clin Neurol Neurosurg. Nov. 2011;113(9):768-73. [pmid: 21893379].
Bouman HJ, van Werkum JW, Rudez G, et al. The relevance of P2Y(12)-receptor gene variation for the outcome of clopidogrel-treated patients undergoing elective coronary stent implantation: a clinical follow-up. Thromb Haemost. Jan. 2012;107(1):189-91. [pmid: 22159428].
Breet NJ, van Werkum JW, Bouman HJ, et al. High on-aspirin platelet reactivity as measured with aggregation-based, cyclooxygenase-1 inhibition sensitive platelet function tests is associated with the occurrence of atherothrombotic events. J Thromb Haemost. Oct. 2010;8(10):2140-48. [pmid: 20723029].
Burdess A, Nimmo AF, Campbell N, et al. Perioperative platelet and monocyte activation in patients with critical limb ischemia. J Vasc Surg. Sep. 2010;52(3):697-703. [pmid: 20816321].
Burdess A, Nimmo AF, Garden OJ, et al. Randomized controlled trial of dual antiplatelet therapy in patients undergoing surgery for critical limb ischemia. Ann Surg. Jul. 2010;252(1):37-42. [pmid: 20562608].
Campo G, Valgimigli M, Frangione A, et al. Evaluation of platelet inhibition by tirofiban in patients stratified according to aspirin and clopidogrel responsiveness: the 3T/2R (Tailoring treatment with tirofiban in patients showing resistance to aspirin and/or resistance to clopidogrel). J Am Coll Cardiol. Jan. 19. 2010;55(3):255-56. [pmid: 20117406].
Cesari F, Marcucci R, Caporale R, et al. Relationship between high platelet turnover and platelet function in high-risk patients with coronary artery disease on dual antiplatelet therapy. Thromb Haemost. May. 2008;99(5):930-35. [pmid: 18449424].
Cesari M, Kritchevsky SB, Nicklas B, et al. Oxidative damage, platelet activation, and inflammation to predict mobility disability and mortality in older persons: results from the health aging and body composition study. J Gerontol A Biol Sci Med Sci. Jun. 2012;67(6):671-76. [pmid: 22389462].
Cha JK, Jo WS, Shin HC, et al. Increased platelet CD63 and P-selectin expression persist in atherosclerotic ischemic stroke. Platelets. Feb. 2004;15(1):3-7. [pmid: 14985170].
Chen WH, Lee PY, Ng W, et al. Aspirin resistance is associated with a high incidence of myonecrosis after non-urgent percutaneous coronary intervention despite clopidogrel pretreatment. J Am Coll Cardiol. Mar. 17. 2004;43(6):1122-26. [pmid: 15028378].
Chen WH, Lee PY, Ng W, et al. Relation of aspirin resistance to coronary flow reserve in patients undergoing elective percutaneous coronary intervention. Am J Cardiol. Sep. 15. 2005;96(6):760-63. [pmid: 16169354].
Ciuffetti G, Lombardini R, Pirro M, et al. Clopidogrel: hemorheological effects in subjects with subclinical atherosclerosis. Clin Hemorheol Microcirc. 2001;25(1):31-39. [pmid: 11790868].
Cooke GE, Liu-Stratton Y, Ferketich AK, et al. Effect of platelet antigen polymorphism on platelet inhibition by aspirin, clopidogrel, or their combination. J Am Coll Cardiol. Feb. 7. 2006;47(3):541-46. [pmid: 16458133].
Cuisset T, Hamilos M, Delrue M, et al. Adrenergic receptor polymorphisms and platelet reactivity after treatment with dual antiplatelet therapy with aspirin and clopidogrel in acute coronary syndrome. Thromb Haemost. Apr. 2010;103(4):774-79. [pmid: 20135061].
Dalen M, van der LJ, Lindvall G, et al. Correlation between point-of-care platelet function testing and bleeding after coronary artery surgery. Scand Cardiovasc J. Feb. 2012;46(1):32-38. [pmid: 21973169].
Dangas G, Mehran R, Guagliumi G, et al. Role of clopidogrel loading dose in patients with ST-segment elevation myocardial infarction undergoing primary angioplasty: results from the HORIZONS-AMI (harmonizing outcomes with revascularization and stents in acute myocardial infarction) trial. J Am Coll Cardiol. Oct. 6. 2009;54(15):1438-46. [pmid: 19796737].
Davlouros PA, Arseniou A, Hahalis G, et al. Timing of clopidogrel loading before percutaneous coronary intervention in clopidogrel-naive patients with stable or unstable angina: a comparison of two strategies. Am Heart J. Oct. 2009;158(4):585-91. [pmid: 19781418].
Deliargyris EN, Upadhya B, Melton LG, et al. Unfractionated heparin reduces the anti-platelet effects of abciximab but not eptifibatide during PCI. Clin Appl Thromb Hemost. Oct. 2006;12(4):458-64. [pmid: 17000891].
Di NM, Bijsterveld NR, Meijers JC, et al. Effects of clopidogrel on the rebound hypercoagulable state after heparin discontinuation in patients with acute coronary syndromes. J Am Coll Cardiol. Oct. 18. 2005;46(8):1582-83. [pmid: 16226189].
Douglas IJ, Evans SJ, Hingorani AD, et al. Clopidogrel and interaction with proton pump inhibitors: comparison between cohort and within person study designs. BMJ. 2012;345:e4388. [pmid: 22782731].
Dropinski J, Musial J, Jakiela B, et al. Anti-thrombotic action of clopidogrel and P1(A1/A2) polymorphism of beta3 integrin in patients with coronary artery disease not being treated with aspirin. Thromb Haemost. Dec. 2005;94(6):1300-05. [pmid: 16411409].
Dropinski J, Jakiela B, Sanak M, et al. The additive antiplatelet action of clopidogrel in patients with coronary artery disease treated with aspirin. Thromb Haemost. Jul. 2007;98(1):201-09. [pmid: 17598014].
Egier DA, Keys JL, Hall SK, et al. Measurement of hemoglobin A1c from filter papers for population-based studies. Clin Chem. Apr. 2011;57(4):577-85. [pmid: 21296974].
Eikelboom JW, Weitz JI, Budaj A, et al. Clopidogrel does not suppress blood markers of coagulation activation in aspirin-treated patients with non-ST-elevation acute coronary syndromes. Eur Heart J. Nov. 2002;23(22):1771-79. [pmid: 12419297].
El-Atat F, Sarkar K, Kodali V, et al. A randomized pilot trial for aggressive therapeutic approaches in aspirin-resistant patients undergoing percutaneous coronary intervention. J Invasive Cardiol. Jan. 2011;23(1):9-13. [pmid: 21183763].
Ercan E, Tengiz I, Duman C, et al. Effect of tirofiban on C-reactive protein in non-ST-elevation myocardial infarction. Am Heart J. Jan. 2004;147(1):E1. [pmid: 14691439].
Eriksson AC, Jonasson L, Lindahl TL, et al. Static platelet adhesion, flow cytometry and serum TXB2 levels for monitoring platelet inhibiting treatment with ASA and clopidogrel in coronary artery disease: a randomised cross-over study. J Transl Med. 2009;7:42. [pmid: 19508722].
Frelinger AL III, Furman MI, Linden MD, et al. Residual arachidonic acid-induced platelet activation via an adenosine diphosphate-dependent but cyclooxygenase-1- and cyclooxygenase-2-independent pathway: a 700-patient study of aspirin resistance. Circulation. Jun. 27. 2006;113(25):2888-96. [pmid: 16785341].
Frossard M, Fuchs I, Leitner JM, et al. Platelet function predicts myocardial damage in patients with acute myocardial infarction. Circulation. Sep. 14. 2004;110(11):1392-97. [pmid: 15313953].
Furman MI, Krueger LA, Linden MD, et al. GPIIb-IIIa antagonists reduce thromboinflammatory processes in patients with acute coronary syndromes undergoing percutaneous coronary intervention. J Thromb Haemost. Feb. 2005;3(2):312-20. [pmid: 15670038].
Furuta T, Iwaki T, Umemura K. [13C]pantoprazole breath test as a predictor of the anti-platelet function of clopidogrel. Eur J Clin Pharmacol. May. 2010;66(5):457-63. [pmid: 20349052].
Gibson CM, Ly HQ, Murphy SA, et al. Usefulness of clopidogrel in abolishing the increased risk of reinfarction associated with higher platelet counts in patients with ST-elevation myocardial infarction (results from CLARITY-TIMI 28). Am J Cardiol. Sep. 15. 2006;98(6):761-63. [pmid: 16950180].
Giusti B, Gori AM, Marcucci R, et al. Role of glycoprotein Ia gene polymorphisms in determining platelet function in myocardial infarction patients undergoing percutaneous coronary intervention on dual antiplatelet treatment. Atherosclerosis. Jan. 2008;196(1):341-48. [pmid: 17157856].
Goncalves SC, Labinaz M, Le MM, et al. Usefulness of mean platelet volume as a biomarker for long-term outcomes after percutaneous coronary intervention. Am J Cardiol. Jan. 15. 2011;107(2):204-09. [pmid: 21129717].
Gremmel T, Steiner S, Seidinger D, et al. Smoking promotes clopidogrel-mediated platelet inhibition in patients receiving dual antiplatelet therapy. Thromb Res. Nov. 2009;124(5):588-91. [pmid: 19631365].
Gremmel T, Steiner S, Seidinger D, et al. Comparison of methods to evaluate aspirin-mediated platelet inhibition after percutaneous intervention with stent implantation. Platelets. 2011;22(3):188-95. [pmid: 21231857].
Gulmez O, Yildirir A, Kaynar G, et al. Effects of persistent platelet reactivity despite aspirin therapy on cardiac troponin I and creatine kinase-MB levels after elective percutaneous coronary interventions. J Thromb Thrombolysis. Jun. 2008;25(3):239-46. [pmid: 17574519].
Hudzik B, Szkodzinski J, Danikiewicz A, et al. Effect of omeprazole on the concentration of interleukin-6 and transforming growth factor-beta1 in patients receiving dual antiplatelet therapy after percutaneous coronary intervention. Eur Cytokine Netw. Dec. 2010;21(4):257-63. [pmid: 21084246].
Husted S, Storey RF, Harrington RA, et al. Changes in inflammatory biomarkers in patients treated with ticagrelor or clopidogrel. Clin Cardiol. Apr. 2010;33(4):206-12. [pmid: 20394040].
Jaster M, Fuster V, Rosenthal P, et al. Catheter based intracoronary brachytherapy leads to increased platelet activation. Heart. Feb. 2004;90(2):160-64. [pmid: 14729786].
Jaumdally RJ, Varma C, Blann AD, et al. Platelet activation in coronary artery disease: intracardiac vs peripheral venous levels and the effects of angioplasty. Chest. Nov. 2007;132(5):1532-39. [pmid: 17908707].
Jin C, Lu L, Zhu ZB, et al. Increased serum vWF and sVCAM-1 levels are associated with late or very late angiographic stent thrombosis after sirolimus-eluting stent implantation. Coron Artery Dis. Aug. 2010;21(5):273-77. [pmid: 20508517].
Jung JH, Min PK, Lee SH, et al. Clopidogrel pretreatment before primary percutaneous coronary stenting in patients with acute ST-segment elevation myocardial infarction: comparison of high loading dose (600 mg) versus low loading dose (300 mg). Coron Artery Dis. Mar. 2009;20(2):150-54. [pmid: 19301464].
Karlsson F, Modica A, Mooe T. Dynamics of platelet activation in diabetic and non-diabetic subjects during the course of an acute myocardial infarction. Thromb Res. 2007;121(2):269-73. [pmid: 17543372].
Kasprzak M, Kozinski M, Bielis L, et al. Pantoprazole may enhance antiplatelet effect of enteric-coated aspirin in patients with acute coronary syndrome. Cardiol J. 2009;16(6):535-44. [pmid: 19950090].
Keating FK, Dauerman HL, Whitaker DA, et al. The effects of bivalirudin compared with those of unfractionated heparin plus eptifibatide on inflammation and thrombin generation and activity during coronary intervention. Coron Artery Dis. Sep. 2005;16(6):401-05. [pmid: 16118546].
Konopka A, Spychalska J, Piotrowski W, et al. Influence of some cardiovascular risk factors on the expression of platelet glycoprotein IIb/IIIa receptors in patients with myocardial infarction treated with antiplatelet drugs under primary percutaneous coronary intervention. Mol Diagn Ther. Dec. 1. 2009;13(6):375-82. [pmid: 19925035].
Konstantinidis K, Gerasimidis T, Verdy E, et al. Inhibition of clot formation process by treatment with the low-molecular-weight heparin nadroparin in patients with carotid artery disease undergoing angioplasty and stenting. A thromboelastography study on whole blood. Thromb Haemost. Jan. 2007;97(1):109-18. [pmid: 17200777].
Kopp CW, Steiner S, Nasel C, et al. Abciximab reduces monocyte tissue factor in carotid angioplasty and stenting. Stroke. Nov. 2003;34(11):2560-67. [pmid: 14563968].
Lau WC, Welch TD, Shields T, et al. The effect of St John's Wort on the pharmacodynamic response of clopidogrel in hyporesponsive volunteers and patients: increased platelet inhibition by enhancement of CYP3A4 metabolic activity. J Cardiovasc Pharmacol. Jan. 2011;57(1):86-93. [pmid: 20980920].
Lev EI, Patel RT, Guthikonda S, et al. Genetic polymorphisms of the platelet receptors P2Y(12), P2Y(1) and GP IIIa and response to aspirin and clopidogrel. Thromb Res. 2007;119(3):355-60. [pmid: 16581111].
Liu F, Li J, Wang DM, et al. Serial changes of circulating platelet activation markers after carotid artery stenting. Angiology. Aug. 2009;60(4):427-30. [pmid: 18796447].
Liu WH, Yang CH, Yeh KH, et al. Circulating levels of soluble P-selectin in patients in the early and recent phases of myocardial infarction. Chang Gung Med J. Sep. 2005;28(9):613-20. [pmid: 16323552].
Madsen EH, Gehr NR, Johannesen NL, et al. Platelet response to aspirin and clopidogrel in patients with peripheral atherosclerosis. Platelets. 2011;22(7):537-46. [pmid: 21591982].
Mahemuti A, Meneveau N, Seronde MF, et al. Early local intracoronary platelet activation after drug-eluting stent placement. Chin Med J (Engl ). Nov. 20. 2007;120(22):1986-91. [pmid: 18067783].
Malmstrom RE, Ostergren J, Jorgensen L, et al. Influence of statin treatment on platelet inhibition by clopidogrel - a randomized comparison of rosuvastatin, atorvastatin and simvastatin co-treatment. J Intern Med. Nov. 2009;266(5):457-66. [pmid: 19549094].
Mannini L, Marcucci R, Paniccia R, et al. Erythrocyte deformability and white blood cell count are associated with aspirin resistance in high-risk vascular patients. Clin Hemorheol Microcirc. 2006;35(1-2):175-81. [pmid: 16899924].
Marcucci R, Paniccia R, Antonucci E, et al. Usefulness of aspirin resistance after percutaneous coronary intervention for acute myocardial infarction in predicting one-year major adverse coronary events. Am J Cardiol. Nov. 1. 2006;98(9):1156-59. [pmid: 17056317].
Mariani M, Mariani G, De SS. Efficacy and safety of prasugrel compared with clopidogrel in patients with acute coronary syndromes: results of TRITON-TIMI 38 trials. Expert Rev Cardiovasc Ther. Jan. 2009;7(1):17-23. [pmid: 19105763].
Marmur JD, Poludasu S, Agarwal A, et al. High-dose tirofiban administered as bolus-only during percutaneous coronary intervention. J Invasive Cardiol. Feb. 2008;20(2):53-58. [pmid: 18252967].
McClung JA, Kruger AL, Ferraris A, et al. Usefulness of clopidogrel to protect against diabetes-induced vascular damage. Am J Cardiol. Apr. 1. 2010;105(7):1014-18. [pmid: 20346323].
Mende A, Obata JE, Sano K, et al. Measurement of the platelet retention rate in a column of collagen-coated beads is useful for the assessment of efficacy of antiplatelet therapy. Thromb Res. Apr. 2009;123(6):856-61. [pmid: 19004478].
Montalescot G, Sideris G, Meuleman C, et al. A randomized comparison of high clopidogrel loading doses in patients with non-ST-segment elevation acute coronary syndromes: the ALBION (Assessment of the Best Loading Dose of Clopidogrel to Blunt Platelet Activation, Inflammation and Ongoing Necrosis) trial. J Am Coll Cardiol. Sep. 5. 2006;48(5):931-38. [pmid: 16949482].
Moriau M, Lavenne-Pardonge E, Crasborn L, et al. The treatment of severe or recurrent deep venous thrombosis. Beneficial effect of the co-administration of antiplatelet agents with or without rheological effects, and anticoagulants. Thromb Res. Jun. 15. 1995;78(6):469-82. [pmid: 15714749].
Motovska Z, Widimsky P, Kvasnicka J, et al. High loading dose of clopidogrel is unable to satisfactorily inhibit platelet reactivity in patients with glycoprotein IIIA gene polymorphism: a genetic substudy of PRAGUE-8 trial. Blood Coagul Fibrinolysis. Jun. 2009;20(4):257-62. [pmid: 19530321].
Naidech AM, Bendok BR, Garg RK, et al. Reduced platelet activity is associated with more intraventricular hemorrhage. Neurosurgery. Oct. 2009;65(4):684-88. [pmid: 19834372].
Norgard NB, Saya S, Hann CL, et al. Clopidogrel attenuates coated-platelet production in patients undergoing elective coronary catheterization. J Cardiovasc Pharmacol. Dec. 2008;52(6):536-39. [pmid: 19034031].
O'Donoghue M, Antman EM, Braunwald E, et al. The efficacy and safety of prasugrel with and without a glycoprotein IIb/IIIa inhibitor in patients with acute coronary syndromes undergoing percutaneous intervention: a TRITON-TIMI 38 (Trial to Assess Improvement in Therapeutic Outcomes by Optimizing Platelet Inhibition With Prasugrel-Thrombolysis In Myocardial Infarction 38) analysis. J Am Coll Cardiol. Aug. 18. 2009;54(8):678-85. [pmid: 19679245].
Obradovic S, Subota V, Baskot B, et al. Changes in platelets and anticoagulant protein activity during adenosine-exercise single-photon emission computed tomography stress test. Srp Arh Celok Lek. Jan. Suppl 1. 2010;138:28-32. [pmid: 20229679].
Pamukcu B, Oflaz H, Oncul A, et al. The role of aspirin resistance on outcome in patients with acute coronary syndrome and the effect of clopidogrel therapy in the prevention of major cardiovascular events. J Thromb Thrombolysis. Oct. 2006;22(2):103-10. [pmid: 17008975].
Pamukcu B, Oflaz H, Onur I, et al. Clinical relevance of aspirin resistance in patients with stable coronary artery disease: a prospective follow-up study (PROSPECTAR). Blood Coagul Fibrinolysis. Mar. 2007;18(2):187-92. [pmid: 17287637].
Paniccia R, Antonucci E, Gori AM, et al. Comparison of different methods to evaluate the effect of aspirin on platelet function in high-risk patients with ischemic heart disease receiving dual antiplatelet treatment. Am J Clin Pathol. Jul. 2007;128(1):143-49. [pmid: 17580282].
Pearson L, Thom J, Adams M, et al. A rapid flow cytometric technique for the detection of platelet-monocyte complexes, activated platelets and platelet-derived microparticles. Int J Lab Hematol. Aug. 2009;31(4):430-39. [pmid: 18384393].
Pride YB, Wiviott SD, Buros JL, et al. Effect of prasugrel versus clopidogrel on outcomes among patients with acute coronary syndrome undergoing percutaneous coronary intervention without stent implantation: a TRial to assess Improvement in Therapeutic Outcomes by optimizing platelet inhibitioN with prasugrel (TRITON)-Thrombolysis in Myocardial Infarction (TIMI) 38 substudy. Am Heart J. Sep. 2009;158(3):e21-e26. [pmid: 19699846].
Rao AK, Vaidyula VR, Bagga S, et al. Effect of antiplatelet agents clopidogrel, aspirin, and cilostazol on circulating tissue factor procoagulant activity in patients with peripheral arterial disease. Thromb Haemost. Dec. 2006;96(6):738-43. [pmid: 17139367].
Reavey-Cantwell JF, Fox WC, Reichwage BD, et al. Factors associated with aspirin resistance in patients premedicated with aspirin and clopidogrel for endovascular neurosurgery. Neurosurgery. May. 2009;64(5):890-95. [pmid: 19287328].
Rudez G, Bouman HJ, van Werkum JW, et al. Common variation in the platelet receptor P2RY12 gene is associated with residual on-clopidogrel platelet reactivity in patients undergoing elective percutaneous coronary interventions. Circ Cardiovasc Genet. Oct. 2009;2(5):515-21. [pmid: 20031628].
Sacristan D, Lopez-Farre AJ, Zamorano-Leon JJ, et al. Effects of coronary prestenting platelet inhibition on coronary poststenting inflammation. J Cardiovasc Pharmacol. Mar. 2008;51(3):286-92. [pmid: 18356694].
Saracini C, Vestrini A, Galora S, et al. Pharmacogenetics of clopidogrel: comparison between a standard and a rapid genetic testing. Genet Test Mol Biomarkers. Jun. 2012;16(6):500-03. [pmid: 22239289].
Saw J, Steinhubl SR, Berger PB, et al. Lack of adverse clopidogrel-atorvastatin clinical interaction from secondary analysis of a randomized, placebo-controlled clopidogrel trial. Circulation. Aug. 26. 2003;108(8):921-24. [pmid: 12925453].
Schneider DJ, Sobel BE. Lack of early augmentation of platelet reactivity after coronary intervention in patients treated with bivalirudin. J Thromb Thrombolysis. Jul. 2009;28(1):6-9. [pmid: 18607689].
Serebruany VL, Glassman AH, Malinin AI, et al. Platelet/endothelial biomarkers in depressed patients treated with the selective serotonin reuptake inhibitor sertraline after acute coronary events: the Sertraline AntiDepressant Heart Attack Randomized Trial (SADHART) Platelet Substudy. Circulation. Aug. 26. 2003;108(8):939-44. [pmid: 12912814].
Shammas NW, Dippel EJ, Lemke JH, et al. Eptifibatide in peripheral vascular interventions: results of the Integrilin Reduces Inflammation in Peripheral Vascular Interventions (INFLAME) trial. J Invasive Cardiol. Jan. 2006;18(1):6-12. [pmid: 16391376].
Sidhu JS, Cowan D, Tooze JA, et al. Peroxisome proliferator-activated receptor-gamma agonist rosiglitazone reduces circulating platelet activity in patients without diabetes mellitus who have coronary artery disease. Am Heart J. Jun. 2004;147(6):e25. [pmid: 15199366].
Smith SM, Judge HM, Peters G, et al. PAR-1 genotype influences platelet aggregation and procoagulant responses in patients with coronary artery disease prior to and during clopidogrel therapy. Platelets. Sep. 2005;16(6):340-45. [pmid: 16194864].
Smith SM, Judge HM, Peters G, et al. Common sequence variations in the P2Y12 and CYP3A5 genes do not explain the variability in the inhibitory effects of clopidogrel therapy. Platelets. Jun. 2006;17(4):250-58. [pmid: 16769602].
Spiewak M, Malek LA, Kostrzewa G, et al. Influence of C3435T multidrug resistance gene-1 (MDR-1) polymorphism on platelet reactivity and prognosis in patients with acute coronary syndromes. Kardiol Pol. Aug. 2009;67(8):827-34. [pmid: 19784880].
Suh JW, Koo BK, Zhang SY, et al. Increased risk of atherothrombotic events associated with cytochrome P450 3A5 polymorphism in patients taking clopidogrel. CMAJ. Jun. 6. 2006;174(12):1715-22. [pmid: 16754899].
Suh JW, Kim SY, Park JS, et al. Comparison of triple antiplatelet therapy including triflusal and conventional dual therapy in patients who underwent drug-eluting stent implantation. Int Heart J. Nov. 2009;50(6):701-09. [pmid: 19952467].
Syros G, Mehran R, Weisz G, et al. Role of PLA2 polymorphism on clinical events after percutaneous coronary intervention. Acute Card Care. 2009;11(2):88-91. [pmid: 19526385].
Szuk T, Nagy B Jr., Bereczky Z, et al. Effects of ad hoc clopidogrel loading versus pre-treatment on P-selectin expression after coronary stent implantation. Platelets. Aug. 2006;17(5):344-46. [pmid: 16928609].
Tsai NW, Chang WN, Shaw CF, et al. Serial change in platelet activation markers with aspirin and clopidogrel after acute ischemic stroke. Clin Neuropharmacol. Jan. 2010;33(1):40-45. [pmid: 19855266].
Undas A, Stepien E, Branicka A, et al. Thrombin formation and platelet activation at the site of vascular injury in patients with coronary artery disease treated with clopidogrel combined with aspirin. Kardiol Pol. Jun. 2009;67(6):591-98. [pmid: 19618315].
van Zyl LT, Lesperance F, Frasure-Smith N, et al. Platelet and endothelial activity in comorbid major depression and coronary artery disease patients treated with citalopram: the Canadian Cardiac Randomized Evaluation of Antidepressant and Psychotherapy Efficacy Trial (CREATE) biomarker sub-study. J Thromb Thrombolysis. Jan. 2009;27(1):48-56. [pmid: 18188512].
Vavuranakis M, Latsios G, Aggelis D, et al. Randomized comparison of the effects of ASA plus clopidogrel versus ASA alone on early platelet activation in acute coronary syndromes with elevated high-sensitivity C-reactive protein and soluble CD40 ligand levels. Clin Ther. Jun. 2006;28(6):860-71. [pmid: 16860169].
von BN, von BO, Koch W, et al. P2Y12 gene H2 haplotype is not associated with increased adenosine diphosphate-induced platelet aggregation after initiation of clopidogrel therapy with a high loading dose. Blood Coagul Fibrinolysis. Apr. 2005;16(3):199-204. [pmid: 15795539].
Waehre T, Damas JK, Pedersen TM, et al. Clopidogrel increases expression of chemokines in peripheral blood mononuclear cells in patients with coronary artery disease: results of a double-blind placebo-controlled study. J Thromb Haemost. Oct. 2006;4(10):2140-47. [pmid: 16856976].
Wallaschofski H, Lohmann T, Hild E, et al. Enhanced platelet activation by prolactin in patients with ischemic stroke. Thromb Haemost. Jul. 2006;96(1):38-44. [pmid: 16807649].
Weber CF, Gorlinger K, Byhahn C, et al. Tranexamic acid partially improves platelet function in patients treated with dual antiplatelet therapy. Eur J Anaesthesiol. Jan. 2011;28(1):57-62. [pmid: 20962655].
Weltermann A, Fritsch P, Kyrle PA, et al. Effects of pretreatment with clopidogrel on platelet and coagulation activation in patients undergoing elective coronary stenting. Thromb Res. 2003;112(1-2):19-24. [pmid: 15013268].
Willerson JT, Cable G, Yeh ET. PROCLAIM: pilot study to examine the effects of clopidogrel on inflammatory markers in patients with metabolic syndrome receiving low-dose aspirin. Tex Heart Inst J. 2009;36(6):530-39. [pmid: 20069077].
Wiviott SD, Braunwald E, Angiolillo DJ, et al. Greater clinical benefit of more intensive oral antiplatelet therapy with prasugrel in patients with diabetes mellitus in the trial to assess improvement in therapeutic outcomes by optimizing platelet inhibition with prasugrel-Thrombolysis in Myocardial Infarction 38. Circulation. Oct. 14. 2008;118(16):1626-36. [pmid: 18757948].
Wong S, Morel-Kopp MC, Chen Q, et al. Overcoming aspirin resistance: increased platelet inhibition with combination aspirin and clopidogrel and high dose aspirin therapy in aspirin resistant patients with peripheral vascular disease. Thromb Haemost. Jun. 2006;95(6):1042-43. [pmid: 16732389].
Yasu T, Ikee R, Miyasaka Y, et al. Efficacy and safety of concomitant use of rabeprazole during dual-antiplatelet therapy with clopidogrel and aspirin after drug-eluting stent implantation: a retrospective cohort study. Yakugaku Zasshi. Dec. 2010;130(12):1743-50. [pmid: 21139402].
Yip HK, Chen SS, Liu JS, et al. Serial changes in platelet activation in patients after ischemic stroke: role of pharmacodynamic modulation. Stroke. Jul. 2004;35(7):1683-87. [pmid: 15155956].
Yip HK, Wu CJ, Hang CL, et al. Serial changes in platelet activation in patients with unstable angina following coronary stenting: evaluation of the effects of clopidogrel loading dose in inhibiting platelet activation. Circ J. Oct. 2005;69(10):1208-11. [pmid: 16195618].
Yip HK, Chang LT, Sun CK, et al. Impact of clopidogrel on suppression of circulating levels of soluble CD40 ligand in patients with unstable angina undergoing coronary stenting. Am J Cardiol. Jan. 15. 2006;97(2):192-94. [pmid: 16442361].
Ziegler S, Schillinger M, Funk M, et al. Association of a functional polymorphism in the clopidogrel target receptor gene, P2Y12, and the risk for ischemic cerebrovascular events in patients with peripheral artery disease. Stroke. Jul. 2005;36(7):1394-99. [pmid: 15933261].

## Not Treatment of Interest

Abumiya T, Houkin K. Association of recurrent cerebral infarction with adenosine diphosphate- and collagen-induced platelet aggregation in patients treated with ticlopidine and/or aspirin. J Stroke Cerebrovasc Dis. Jul. 2011;20(4):319-23. [pmid: 20634093].
al-Mefty O, Marano G, Raiaraman S, et al. Transient ischemic attacks due to increased platelet aggregation and adhesiveness. Ultrastructural and functional correlation. J Neurosurg. Apr. 1979;50(4):449-53. [pmid: 422999].
Antolovic D, Reissfelder C, Rakow A, et al. A randomised controlled trial to evaluate and optimize the use of antiplatelet agents in the perioperative management in patients undergoing general and abdominal surgery--the APAP trial (ISRCTN45810007). BMC Surg. 2011;11:7. [pmid: 21371292].
Aradi D, Kuliczkowski W, Atar D, et al. Inter-patient variability and impact of proton pump inhibitors on platelet reactivity after prasugrel. Thromb Haemost. Feb. 2012;107(2):338-45. [pmid: 22186910].
Arpaia MR, Leonardo G, del GR. Control of platelet antiaggregation therapy using an electronic aggregometer on whole blood. Minerva Cardioangiol. Apr. 1986;34(4):195-98. [pmid: 3725023].
Atalar E, Haznedaroglu I, Aytemir K, et al. Effects of stent coating on platelets and endothelial cells after intracoronary stent implantation. Clin Cardiol. Feb. 2001;24(2):159-64. [pmid: 11214746].
Ault KA, Cannon CP, Mitchell J, et al. Platelet activation in patients after an acute coronary syndrome: results from the TIMI-12 trial. Thrombolysis in Myocardial Infarction. J Am Coll Cardiol. Mar. 1999;33(3):634-39. [pmid: 10080462].
Azar RR, Badaoui G, Sarkis A, et al. Effect of high bolus dose tirofiban on the inflammatory response following percutaneous coronary intervention. Clin Cardiol. Jan. 2010;33(1):E14-E19. [pmid: 19816871].
Banks DC, Mitchell JR. Leucocytes and thrombosis. 3. Effect on white cell behaviour of substances which induce or inhibit platelet aggregation. Thromb Diath Haemorrh. Sep. 15. 1973;30(1):62-71. [pmid: 4788754].
Behr T, Kuch B, Behr W, et al. Optimizing of thienopyridine therapy by multiple electrode platelet aggregometry in clopidogrel low responders undergoing PCI. Clin Res Cardiol. Oct. 2011;100(10):907-14. [pmid: 21533581].
Berent R, Auer J, Franklin B, et al. Platelet response to aspirin 50 and 100 mg in patients with coronary heart disease over a five-year period. Am J Cardiol. Sep. 1. 2011;108(5):644-50. [pmid: 21684508].
Bierend A, Rau T, Maas R, et al. P2Y12 polymorphisms and antiplatelet effects of aspirin in patients with coronary artery disease. Br J Clin Pharmacol. Apr. 2008;65(4):540-47. [pmid: 17995973].
Bizzi B, Leone G, Boni P. Basic considerations on treatment of increased platelet aggregation in diabetic vasculopathic patients. Acta Diabetol Lat. Nov. 1974;11(6):437-45. [pmid: 4469856].
Bologna E. Influence of some drugs on platelet aggregation: a study in hypertensive patients. Acta Univ Carol Med Monogr. 1972;52:87-92. [pmid: 4669830].
Bonello L, Pansieri M, Mancini J, et al. High on-treatment platelet reactivity after prasugrel loading dose and cardiovascular events after percutaneous coronary intervention in acute coronary syndromes. J Am Coll Cardiol. Jul. 26. 2011;58(5):467-73. [pmid: 21777742].
Borgermann J, Kanashnik A, Sossdorf M, et al. Individual variability of response and non-response to acetyl salicylic acid after cardiac surgery. Platelets. 2010;21(8):610-15. [pmid: 20807171].
Bray PF, Mathias RA, Faraday N, et al. Heritability of platelet function in families with premature coronary artery disease. J Thromb Haemost. Aug. 2007;5(8):1617-23. [pmid: 17663734].
Broome A, Davidsson T, Eklof B, et al. Effect of platelet aggregation inhibitors on the rate of thrombectomy following arterial reconstructions with Gore-Tex prostheses: a retrospective study. Vasa. 1982;11(3):210-12. [pmid: 7136240].
Capodanno D, Patel A, Dharmashankar K, et al. Pharmacodynamic effects of different aspirin dosing regimens in type 2 diabetes mellitus patients with coronary artery disease. Circ Cardiovasc Interv. Apr. 1. 2011;4(2):180-87. [pmid: 21386092].
Cattano D, Altamirano AV, Kaynak HE, et al. Perioperative assessment of platelet function by Thromboelastograph Platelet Mapping in cardiovascular patients undergoing non-cardiac surgery. J Thromb Thrombolysis. Jan. 2013;35(1):23-30. [pmid: 22851059].
Chandler AB, Earhart AD, Speich HE, et al. Regulation of CD40L (CD154) and CD62P (p-selectin) surface expression upon GPIIb-IIIa blockade of platelets from stable coronary artery disease patients. Thromb Res. Jan. 2010;125(1):44-52. [pmid: 19487018].
Chen WY, Lee FN, Hsieh BS, et al. Studies on platelet aggregation and antiplatelet therapy in blackfoot disease. Taiwan Yi Xue Hui Za Zhi. Sep. 1981;80(9):873-83. [pmid: 6948081].
Chitkara K, Hogrefe K, Vasa-Nicotera M, et al. Eptifibatide-eluting stent as an antiproliferative and antithrombotic agent: in vitro evaluation. J Invasive Cardiol. Sep. 2006;18(9):417-22. [pmid: 16954580].
Christie DJ, Kottke-Marchant K, Gorman RT. Hypersensitivity of platelets to adenosine diphosphate in patients with stable cardiovascular disease predicts major adverse events despite antiplatelet therapy. Platelets. Mar. 2008;19(2):104-10. [pmid: 17852773].
Coulter SA, Cannon CP, Ault KA, et al. High levels of platelet inhibition with abciximab despite heightened platelet activation and aggregation during thrombolysis for acute myocardial infarction: results from TIMI (thrombolysis in myocardial infarction) 14. Circulation. Jun. 13. 2000;101(23):2690-95. [pmid: 10851205].
Cox D, Smith R, Quinn M, et al. Evidence of platelet activation during treatment with a GPIIb/IIIa antagonist in patients presenting with acute coronary syndromes. J Am Coll Cardiol. Nov. 1. 2000;36(5):1514-19. [pmid: 11079651].
Danta G. Second phase platelet aggregation induced by adenosine diphosphate in patients with cerebral vascular disease and in control subjects. Thromb Diath Haemorrh. Feb. 28. 1970;23(1):159-69. [pmid: 5420427].
Danta G. Platelet aggregation in patients with cerebral vascular disease and in control subjects. Thromb Diath Haemorrh. Jun. 28. 1973;29(3):730-32. [pmid: 4761838].
Danzi GB, Capuano C, Sesana M, et al. Preliminary experience with a high bolus dose of tirofiban during percutaneous coronary intervention. Curr Med Res Opin. 2003;19(1):28-33. [pmid: 12661777].
de GG, Donati MB, Garattini S. Drugs affecting platelet function tests: their effects on haemostasis and surgical bleeding. Thromb Diath Haemorrh. Sep. 30. 1975;34(1):285-303. [pmid: 1081280].
de LM, Boissonnat P, Mamelle N, et al. Platelet aggregation and HDL cholesterol are predictive of acute coronary events in heart transplant recipients. Circulation. Jun. 1994;89(6):2590-94. [pmid: 8205669].
Duzenli MA, Ozdemir K, Aygul N, et al. Comparison of increased aspirin dose versus combined aspirin plus clopidogrel therapy in patients with diabetes mellitus and coronary heart disease and impaired antiplatelet response to low-dose aspirin. Am J Cardiol. Aug. 15. 2008;102(4):396-400. [pmid: 18678294].
Elwood PC, Renaud S, Beswick AD, et al. Platelet aggregation and incident ischaemic heart disease in the Caerphilly cohort. Heart. Dec. 1998;80(6):578-82. [pmid: 10065026].
Elwood PC, Beswick A, Pickering J, et al. Platelet tests in the prediction of myocardial infarction and ischaemic stroke: evidence from the Caerphilly Prospective Study. Br J Haematol. May. 2001;113(2):514-20. [pmid: 11380425].
Eriksson S, Berg LM, Wadelius M, et al. Cytochrome p450 genotyping by multiplexed real-time dna sequencing with pyrosequencing technology. Assay Drug Dev Technol. Nov. 2002;1(1 Pt 1):49-59. [pmid: 15090156].
Eto K, Takeshita S, Ochiai M, et al. Platelet aggregation in acute coronary syndromes: use of a new aggregometer with laser light scattering to assess platelet aggregability. Cardiovasc Res. Oct. 1998;40(1):223-29. [pmid: 9876335].
Fredrickson BJ, Turner NA, Kleiman NS, et al. Effects of abciximab, ticlopidine, and combined Abciximab/Ticlopidine therapy on platelet and leukocyte function in patients undergoing coronary angioplasty. Circulation. Mar. 14. 2000;101(10):1122-29. [pmid: 10715258].
Gawaz M, Neumann FJ, Ott I, et al. Platelet function in acute myocardial infarction treated with direct angioplasty. Circulation. Jan. 15. 1996;93(2):229-37. [pmid: 8548893].
Gawaz M, Ruf A, Neumann FJ, et al. Effect of glycoprotein IIb-IIIa receptor antagonism on platelet membrane glycoproteins after coronary stent placement. Thromb Haemost. Dec. 1998;80(6):994-1001. [pmid: 9869173].
Gazzaniga PP, Ferroni P, Mina C, et al. A multiparametric index of platelet in vitro aggregation in cerebrovascular disease. Ital J Neurol Sci. Dec. 1987;8(6):561-66. [pmid: 3429215].
Gibson CM, de Lemos JA, Murphy SA, et al. Combination therapy with abciximab reduces angiographically evident thrombus in acute myocardial infarction: a TIMI 14 substudy. Circulation. May. 29. 2001;103(21):2550-54. [pmid: 11382722].
Gilchrist IC, O'Shea JC, Kosoglou T, et al. Pharmacodynamics and pharmacokinetics of higher-dose, double-bolus eptifibatide in percutaneous coronary intervention. Circulation. Jul. 24. 2001;104(4):406-11. [pmid: 11468201].
Gorog DA, Kovacs IB. Thrombotic status analyser. Measurement of platelet-rich thrombus formation and lysis in native blood. Thromb Haemost. Mar. 1995;73(3):514-20. [pmid: 7667836].
Gurbel PA, Serebruany VL, Shustov AR, et al. Effects of reteplase and alteplase on platelet aggregation and major receptor expression during the first 24 hours of acute myocardial infarction treatment. GUSTO-III Investigators. Global Use of Strategies to Open Occluded Coronary Arteries. J Am Coll Cardiol. Jun. 1998;31(7):1466-73. [pmid: 9626821].
Gurbel PA, Kereiakes DJ, Atar D, et al. Baseline platelet aggregation and major receptor expression predict subsequent activity following thrombolysis for acute myocardial infarction. Scand Cardiovasc J. 2000;34(1):53-58. [pmid: 10816061].
Haft JI, Gershengorn K, Kranz PD, et al. Protection against epinephrine-induced myocardial necrosis by drugs that inhibit platelet aggregation. Am J Cardiol. Dec. 1972;30(8):838-43. [pmid: 4634281].
Harrington RA, Kleiman NS, Kottke-Marchant K, et al. Immediate and reversible platelet inhibition after intravenous administration of a peptide glycoprotein IIb/IIIa inhibitor during percutaneous coronary intervention. Am J Cardiol. Dec. 15. 1995;76(17):1222-27. [pmid: 7503000].
Heeschen C, Dimmeler S, Hamm CW, et al. Soluble CD40 ligand in acute coronary syndromes. N Engl J Med. Mar. 20. 2003;348(12):1104-11. [pmid: 12646667].
Heeschen C, Dimmeler S, Fichtlscherer S, et al. Prognostic value of placental growth factor in patients with acute chest pain. JAMA. Jan. 28. 2004;291(4):435-41. [pmid: 14747500].
Hezard N, Metz D, Nazeyrollas P, et al. Use of the PFA-100 apparatus to assess platelet function in patients undergoing PTCA during and after infusion of c7E3 Fab in the presence of other antiplatelet agents. Thromb Haemost. Apr. 2000;83(4):540-44. [pmid: 10780313].
Holmes MB, Schneider DJ. Optimizing antiplatelet therapy in patients with acute coronary syndromes: a role for monitoring platelet reactivity. J Invasive Cardiol. Dec. Suppl C. 1999;11:21C-5C. [pmid: 10745432].
Holmes MB, Sobel BE, Cannon CP, et al. Increased platelet reactivity in patients given orbofiban after an acute coronary syndrome: an OPUS-TIMI 16 substudy. Orbofiban in Patients with Unstable coronary syndromes. Thrombolysis In Myocardial Infarction. Am J Cardiol. Feb. 15. 2000;85(4):491-3. A10. [pmid: 10728957].
Hughes A, Daunt S, Vass G, et al. In vivo platelet activation following myocardial infarction and acute coronary ischaemia. Thromb Haemost. Oct. 29. 1982;48(2):133-35. [pmid: 6184842].
Inoue T, Uchida T, Sakuma M, et al. Cilostazol inhibits leukocyte integrin Mac-1, leading to a potential reduction in restenosis after coronary stent implantation. J Am Coll Cardiol. Oct. 6. 2004;44(7):1408-14. [pmid: 15464320].
Inoue T, Hikichi Y, Morooka T, et al. Comparison of changes in circulating platelet-derived microparticles and platelet surface P-selectin expression after coronary stent implantation. Platelets. Sep. 2006;17(6):416-20. [pmid: 16973503].
Ivandic BT, Spanuth E, Haase D, et al. Increased plasma concentrations of soluble CD40 ligand in acute coronary syndrome depend on in vitro platelet activation. Clin Chem. Jul. 2007;53(7):1231-34. [pmid: 17495016].
Iwamoto T, Jingzi J, Sugiyama T, et al. Prognosis of the elderly with asymptomatic atherosclerotic plaques of the carotid arteries. Intern Med. Jul. 2002;41(7):526-31. [pmid: 12132519].
Jeong YH, Park Y, Muse WC, et al. Pharmacodynamic effect of clopidogrel therapy and switching to cilostazol in patients with the CYP2C19 loss-of-function allele (ACCEL-SWITCH) study. J Thromb Haemost. Aug. 2012;10(8):1685-88. [pmid: 22612904].
Kammerer I, Bach J, Saggau W, et al. Functional evaluation of platelet aspirin resistance after on-pump coronary bypass grafting using multiple aggregation tests. Thorac Cardiovasc Surg. Oct. 2011;59(7):425-29. [pmid: 21437867].
Karlberg KE, Chen J, Hagerman I, et al. Streptokinase, but not tissue plasminogen activator, attenuates platelet aggregation in patients with acute myocardial infarction. J Intern Med. Nov. 1993;234(5):513-19. [pmid: 8228797].
Kereiakes DJ, Runyon JP, Kleiman NS, et al. Differential dose-response to oral xemilofiban after antecedent intravenous abciximab. Administration for complex coronary intervention. Circulation. Sep. 1. 1996;94(5):906-10. [pmid: 8790024].
Kereiakes DJ, Kleiman N, Ferguson JJ, et al. Sustained platelet glycoprotein IIb/IIIa blockade with oral xemilofiban in 170 patients after coronary stent deployment. Circulation. Aug. 19. 1997;96(4):1117-21. [pmid: 9286938].
Kereiakes DJ, Broderick TM, Roth EM, et al. Time course, magnitude, and consistency of platelet inhibition by abciximab, tirofiban, or eptifibatide in patients with unstable angina pectoris undergoing percutaneous coronary intervention. Am J Cardiol. Aug. 15. 1999;84(4):391-95. [pmid: 10468074].
Kereiakes DJ, Mueller M, Howard W, et al. Efficacy of abciximab induced platelet blockade using a rapid point of care assay. J Thromb Thrombolysis. Jun. 1999;7(3):265-76. [pmid: 10375388].
Kereiakes DJ, Broderick TM, Roth EM, et al. High platelet count in platelet-rich plasma reduces measured platelet inhibition by abciximab but not tirofiban nor eptifibatide glycoprotein IIb/IIIa receptor antagonists. J Thromb Thrombolysis. Feb. 2000;9(2):149-55. [pmid: 10613996].
Keyl C, Kmitta E, Kueri S, et al. Effects of aspirin and desmopressin on platelet reactivity in patients undergoing cardiac surgery with extracorporeal circulation. Thromb Haemost. Jan. 2011;105(1):113-21. [pmid: 21057697].
Kinoshita Y, Ashida K, Hongo M. Randomised clinical trial: a multicentre, double-blind, placebo-controlled study on the efficacy and safety of rabeprazole 5 mg or 10 mg once daily in patients with non-erosive reflux disease. Aliment Pharmacol Ther. Jan. 2011;33(2):213-24. [pmid: 21083596].
Kitai T, Nishikawa M, Tanigawa T, et al. Inhibition by combined therapy with ticlopidine and aspirin of enhanced platelet aggregation during physical exercise in patients with coronary artery disease. Am Heart J. Aug. 2001;142(2):E1. [pmid: 11479480].
Kralisz P, Dobrzycki S, Nowak K, et al. Platelet inhibition by increased tirofiban dosing during primary coronary angioplasty for ST elevation myocardial infarction. Kardiol Pol. May. 2004;60(5):459-67. [pmid: 15247961].
Lilienberg G, Venge P. Platelet adhesion in patients prone to arterial and venous thrombosis: the impact of gender, smoking and heredity. Scand J Clin Lab Invest. Jul. 1998;58(4):279-86. [pmid: 9741815].
Lynch DR Jr., Khan FH, Vaidya D, et al. Persistent high on-treatment platelet reactivity in acute coronary syndrome. J Thromb Thrombolysis. Apr. 2012;33(3):267-73. [pmid: 22362558].
Madan M, Berkowitz SD, Christie DJ, et al. Rapid assessment of glycoprotein IIb/IIIa blockade with the platelet function analyzer (PFA-100) during percutaneous coronary intervention. Am Heart J. Feb. 2001;141(2):226-33. [pmid: 11174336].
Mascelli MA, Kleiman NS, Marciniak SJ Jr., et al. Therapeutic heparin concentrations augment platelet reactivity: implications for the pharmacologic assessment of the glycoprotein IIb/IIIa antagonist abciximab. Am Heart J. Apr. 2000;139(4):696-703. [pmid: 10740154].
Mascelli MA, Deliargyris EN, Damaraju LV, et al. Antibodies to platelet factor 4/heparin are associated with elevated endothelial cell activation markers in patients with acute coronary ischemic syndromes. J Thromb Thrombolysis. Dec. 2004;18(3):171-75. [pmid: 15815878].
Mendolicchio GL, Zavalloni D, Bacci M, et al. Variable effect of P2Y12 inhibition on platelet thrombus volume in flowing blood. J Thromb Haemost. Feb. 2011;9(2):373-82. [pmid: 21083646].
Milburn JA, Cassar K, Ford I, et al. Prothrombotic changes in platelet, endothelial and coagulation function following hemodialysis. Int J Artif Organs. Mar. 2011;34(3):280-87. [pmid: 21445833].
Mody M, Lazarus AH, Semple JW, et al. Preanalytical requirements for flow cytometric evaluation of platelet activation: choice of anticoagulant. Transfus Med. Jun. 1999;9(2):147-54. [pmid: 10354385].
Mueller HS, Rao PS, Greenberg MA, et al. Systemic and transcardiac platelet activity in acute myocardial infarction in man: resistance to prostacyclin. Circulation. Dec. 1985;72(6):1336-45. [pmid: 2933181].
Muhlhauser I, Schernthaner G, Silberbauer K, et al. Platelet proteins (beta-TG and PF4) in atherosclerosis and related diseases. Artery. 1980;8(1):73-79. [pmid: 6158934].
Nagakawa Y, Orimo H, Harasawa M. The anti-platelet effect of niceritrol in patients with arteriosclerosis and the relationship of the lipid-lowering effect to the anti-platelet effect. Thromb Res. Nov. 15. 1985;40(4):543-53. [pmid: 4082125].
Nenci GG, Agnelli G, Parise P, et al. Sex difference in circulating platelet aggregates and response to antiplatelet treatment. Thromb Haemost. Dec. 27. 1982;48(3):341. [pmid: 7164022].
Neumann FJ, Hochholzer W, Pogatsa-Murray G, et al. Antiplatelet effects of abciximab, tirofiban and eptifibatide in patients undergoing coronary stenting. J Am Coll Cardiol. Apr. 2001;37(5):1323-28. [pmid: 11300442].
Nita I, Papilian M, Theodorini S, et al. Spontaneous thrombocyte aggregation in patients with ischemic cardiopathy. Effect of anti-aggregant treatment on thrombocyte function and other coagulation factors. Med Interne. Apr. 1984;22(2):113-22. [pmid: 6740182].
Ohmori T, Yano Y, Sakata A, et al. Lack of association between serum paraoxonase-1 activity and residual platelet aggregation during dual anti-platelet therapy. Thromb Res. Apr. 2012;129(4):e36-e40. [pmid: 22115701].
Olsson JE. Comparison between induced platelet aggregation and circulating platelet aggregates as platelet function tests in patients with transient ischemic attacks. Acta Neurol Scand. Feb. 1982;65(2):122-32. [pmid: 7072482].
Onoda K, Ohashi K, Hashimoto A, et al. Inhibition of platelet aggregation by combined therapy with aspirin and cilostazol after off-pump coronary artery bypass surgery. Ann Thorac Cardiovasc Surg. Aug. 2008;14(4):230-37. [pmid: 18818572].
Pamukcu B, Oflaz H, Acar RD, et al. The role of exercise on platelet aggregation in patients with stable coronary artery disease: exercise induces aspirin resistant platelet activation. J Thromb Thrombolysis. Aug. 2005;20(1):17-22. [pmid: 16133890].
Peter K, Straub A, Kohler B, et al. Platelet activation as a potential mechanism of GP IIb/IIIa inhibitor-induced thrombocytopenia. Am J Cardiol. Sep. 1. 1999;84(5):519-24. [pmid: 10482148].
Peter K, Kohler B, Straub A, et al. Flow cytometric monitoring of glycoprotein IIb/IIIa blockade and platelet function in patients with acute myocardial infarction receiving reteplase, abciximab, and ticlopidine: continuous platelet inhibition by the combination of abciximab and ticlopidine. Circulation. Sep. 26. 2000;102(13):1490-96. [pmid: 11004138].
Peters AJ, Borries M, Gradaus F, et al. In vitro bleeding test with PFA-100-aspects of controlling individual acetylsalicylic acid induced platelet inhibition in patients with cardiovascular disease. J Thromb Thrombolysis. Dec. 2001;12(3):263-72. [pmid: 11981109].
Pothula S, Sanchala VT, Nagappala B, et al. The effect of preoperative antiplatelet/anticoagulant prophylaxis on postoperative blood loss in cardiac surgery. Anesth Analg. Jan. 2004;98(1):4-10. table. [pmid: 14693573].
Robless PA, Okonko D, Lintott P, et al. Increased platelet aggregation and activation in peripheral arterial disease. Eur J Vasc Endovasc Surg. Jan. 2003;25(1):16-22. [pmid: 12525806].
Saad EM, Kaplan S, el-Massry S, et al. Platelet aggregometry can accurately predict failure of externally supported knitted Dacron femoropopliteal bypass grafts. J Vasc Surg. Oct. 1993;18(4):587-94. [pmid: 8411466].
Saltzman AJ, Mehran R, Hooper WC, et al. The relative effects of abciximab and tirofiban on platelet inhibition and C-reactive protein during coronary intervention. J Invasive Cardiol. Jan. 2010;22(1):2-6. [pmid: 20048389].
Salzman EW, Harris WH, DeSanctis RW. Reduction in venous thromboembolism by agents affecting platelet function. N Engl J Med. Jun. 10. 1971;284(23):1287-92. [pmid: 5576438].
Sambu N, Dent H, Englyst N, et al. Effect of clopidogrel withdrawal on platelet reactivity and vascular inflammatory biomarkers 1 year after drug-eluting stent implantation: results of the prospective, single-centre CESSATION study. Heart. Oct. 2011;97(20):1661-67. [pmid: 21795297].
Schomig A, Kastrati A, Dirschinger J, et al. Coronary stenting plus platelet glycoprotein IIb/IIIa blockade compared with tissue plasminogen activator in acute myocardial infarction. Stent versus Thrombolysis for Occluded Coronary Arteries in Patients with Acute Myocardial Infarction Study Investigators. N Engl J Med. Aug. 10. 2000;343(6):385-91. [pmid: 10933737].
Serebruany V, McKenzie M, Meister A, et al. Whole blood impedance aggregometry for the assessment of platelet function in patients with congestive heart failure (EPCOT Trial). Eur J Heart Fail. Aug. 2002;4(4):461-67. [pmid: 12167384].
Serebruany VL, Lowry DR, Fuzailov SY, et al. Moderate alcohol consumption is associated with decreased platelet activity in patients presenting with acute myocardial infarction. J Thromb Thrombolysis. Apr. 2000;9(3):229-34. [pmid: 10728021].
Serebruany VL, Alford AB, Meister AF, et al. Clinical utility of the platelet function analyzer (PFA-100) for the assessment of the platelet status in patients with congestive heart failure (EPCOT trial). Thromb Res. Mar. 15. 2001;101(6):427-33. [pmid: 11322999].
Serebruany VL, McKenzie ME, Meister AF, et al. Failure of platelet parameters and biomarkers to correlate platelet function to severity and etiology of heart failure in patients enrolled in the EPCOT trial. With special reference to the Hemodyne hemostatic analyzer. Whole Blood Impedance Aggregometry for the Assessment of Platelet Function in Patients with Congestive Heart Failure. Pathophysiol Haemost Thromb. Jan. 2002;32(1):8-15. [pmid: 12214158].
Serebruany VL, Malinin AI, Oshrine BR, et al. Lack of uniform platelet activation in patients after ischemic stroke and choice of antiplatelet therapy. Thromb Res. 2004;113(3-4):197-204. [pmid: 15140583].
Serebruany VL, Malinin AI, Lowry DR, et al. Effects of valsartan and valeryl 4-hydroxy valsartan on human platelets: a possible additional mechanism for clinical benefits. J Cardiovasc Pharmacol. May. 2004;43(5):677-84. [pmid: 15071355].
Serebruany VL, Miller M, Pokov AN, et al. Early impact of prescription Omega-3 fatty acids on platelet biomarkers in patients with coronary artery disease and hypertriglyceridemia. Cardiology. 2011;118(3):187-94. [pmid: 21701167].
Serrano CV Jr., Nicolau JC, Venturinelli M, et al. Role of oral blockade of platelet glycoprotein IIb/IIIa on neutrophil activation in patients with acute coronary syndromes. Cardiovasc Drugs Ther. Mar. 2003;17(2):129-32. [pmid: 12975594].
Sestito A, Sgueglia GA, Spinelli A, et al. Increased platelet reactivity in unstable angina patients is not related to C-reactive protein levels. Platelets. Aug. 2006;17(5):336-39. [pmid: 16928607].
Siriswangvat S, Sansanayudh N, Nathisuwan S, et al. Comparison between the effect of omeprazole and rabeprazole on the antiplatelet action of clopidogrel. Circ J. Oct. 2010;74(10):2187-92. [pmid: 20736505].
Small DS, Farid NA, Li YG, et al. Pharmacokinetics and pharmacodynamics of prasugrel in subjects with moderate liver disease. J Clin Pharm Ther. Oct. 2009;34(5):575-83. [pmid: 19744013].
Smout J, Dyker A, Cleanthis M, et al. Platelet function following acute cerebral ischemia. Angiology. Jun. 2009;60(3):362-69. [pmid: 19398427].
Steinhubl SR, Kottke-Marchant K, Moliterno DJ, et al. Attainment and maintenance of platelet inhibition through standard dosing of abciximab in diabetic and nondiabetic patients undergoing percutaneous coronary intervention. Circulation. Nov. 9. 1999;100(19):1977-82. [pmid: 10556224].
Storey RF, Melissa TS, Lawrance R, et al. Ticagrelor yields consistent dose-dependent inhibition of ADP-induced platelet aggregation in patients with atherosclerotic disease regardless of genotypic variations in P2RY12, P2RY1, and ITGB3. Platelets. Aug. 2009;20(5):341-48. [pmid: 19637098].
Sucker C, Zotz RB, Kurt M, et al. Platelet-function analyzer closure times indicate shear stress-induced hemostatic abnormalities in patients with aortic valve stenosis and correlate with perioperative transfusion requirements. Perfusion. May. 2010;25(3):153-58. [pmid: 20406747].
Sucker C, Litmathe J, Feindt P, et al. Platelet function analyzer (PFA-100) as a useful tool for the prediction of transfusion requirements during aortic valve replacement. Thorac Cardiovasc Surg. Jun. 2011;59(4):233-36. [pmid: 21412708].
Tanaka KA, Szlam F, Kelly AB, et al. Clopidogrel (Plavix) and cardiac surgical patients: implications for platelet function monitoring and postoperative bleeding. Platelets. Aug. 2004;15(5):325-32. [pmid: 15370104].
Tanigawa T, Nishikawa M, Kitai T, et al. Increased platelet aggregability in response to shear stress in acute myocardial infarction and its inhibition by combined therapy with aspirin and cilostazol after coronary intervention. Am J Cardiol. May. 1. 2000;85(9):1054-59. [pmid: 10781751].
Tello-Montoliu A, Tomasello SD, Ferreiro JL, et al. Pharmacodynamic effects of prasugrel dosing regimens in patients on maintenance prasugrel therapy: results of a prospective randomized study. J Am Coll Cardiol. May. 8. 2012;59(19):1681-87. [pmid: 22554598].
Tobin WO, Kinsella JA, Collins DR, et al. Enhanced ex vivo inhibition of platelet function following addition of dipyridamole to aspirin after transient ischaemic attack or ischaemic stroke: first results from the TRinity AntiPlatelet responsiveness (TrAP) study. Br J Haematol. Mar. 2011;152(5):640-47. [pmid: 21223254].
Tsukahara K, Kimura K, Morita S, et al. Impact of high-responsiveness to dual antiplatelet therapy on bleeding complications in patients receiving drug-eluting stents. Circ J. Apr. 2010;74(4):679-85. [pmid: 20173303].
Vaidya D, Yanek LR, Faraday N, et al. Native platelet aggregation and response to aspirin in persons with the metabolic syndrome and its components. Metab Syndr Relat Disord. Aug. 2009;7(4):289-96. [pmid: 19351291].
van den Dungen JJ, Karliczek GF, Brenken U, et al. The effect of prostaglandin E1 in patients undergoing clinical cardiopulmonary bypass. Ann Thorac Surg. Apr. 1983;35(4):406-14. [pmid: 6682305].
Vavalle JP, Stevens SR, Hassinger N, et al. The kinetics of integrilin limited by obesity: a multicenter randomized pharmacokinetic and pharmacodynamic clinical trial. Am Heart J. Dec. 2011;162(6):996-1002. [pmid: 22137072].
Wada R, Rohatagi S, Small D, et al. Correlation of inhibition of platelet aggregation with cardiovascular and bleeding outcomes in acute coronary syndromes. J Clin Pharmacol. Aug. 2010;50(8):904-13. [pmid: 20147617].
Woinke M, Zeiger F, Ruehlmann C, et al. Changes in signal transduction in the platelets of patients with peripheral occlusive arterial disease. Int Angiol. Dec. 2000;19(4):345-50. [pmid: 11305734].
Wykrzykowska JJ, Warnholtz A, de JP, et al. Effect of clopidogrel discontinuation at 1 year after drug eluting stent placement on soluble CD40L, P-selectin and C-reactive protein levels: DECADES (Discontinuation Effect of Clopidogrel After Drug Eluting Stent): a multicenter, open-label study. J Thromb Thrombolysis. Nov. 2009;28(4):410-17. [pmid: 19504052].
Yano Y, Ohmori T, Hoshide S, et al. Determinants of thrombin generation, fibrinolytic activity, and endothelial dysfunction in patients on dual antiplatelet therapy: involvement of factors other than platelet aggregability in Virchow's triad. Eur Heart J. Jul. 2008;29(14):1729-38. [pmid: 18270211].
Zurbano MJ, Anguera I, Heras M, et al. Captopril administration reduces thrombus formation and surface expression of platelet glycoprotein IIb/IIa in early postmyocardial infarction stage. Arterioscler Thromb Vasc Biol. Jul. 1999;19(7):1791-95. [pmid: 10428581].

## Not Outcome of Interest

Alexopoulos D, Plakomyti TE, Xanthopoulou I. Variability and treatment of high on-prasugrel platelet reactivity in patients with initial high on-clopidogrel platelet reactivity. Int J Cardiol. Feb. 9. 2012;154(3):333-34. [pmid: 22075413].
Angiolillo DJ, Capranzano P, Desai B, et al. Impact of P2Y(12) inhibitory effects induced by clopidogrel on platelet procoagulant activity in type 2 diabetes mellitus patients. Thromb Res. Jul. 2009;124(3):318-22. [pmid: 19012950].
Bonello L, Harhouri K, Sabatier F, et al. Level of adenosine diphosphate receptor P2Y12 blockade during percutaneous coronary intervention predicts the extent of endothelial injury, assessed by circulating endothelial cell measurement. J Am Coll Cardiol. Sep. 21. 2010;56(13):1024-31. [pmid: 20846600].
Boulenc X, Djebli N, Shi J, et al. Effects of omeprazole and genetic polymorphism of CYP2C19 on the clopidogrel active metabolite. Drug Metab Dispos. Jan. 2012;40(1):187-97. [pmid: 22004687].
Breet NJ, Sluman MA, van Berkel MA, et al. Effect of gender difference on platelet reactivity. Neth Heart J. Nov. 2011;19(11):451-57. [pmid: 21901505].
Chang MH, Lindegren ML, Butler MA, et al. Prevalence in the United States of selected candidate gene variants: Third National Health and Nutrition Examination Survey, 1991-1994. Am J Epidemiol. Jan. 1. 2009;169(1):54-66. [pmid: 18936436].
Chen L, Bracey AW, Radovancevic R, et al. Clopidogrel and bleeding in patients undergoing elective coronary artery bypass grafting. J Thorac Cardiovasc Surg. Sep. 2004;128(3):425-31. [pmid: 15354103].
Chirumamilla AP, Maehara A, Mintz GS, et al. High platelet reactivity on clopidogrel therapy correlates with increased coronary atherosclerosis and calcification: a volumetric intravascular ultrasound study. JACC Cardiovasc Imaging. May. 2012;5(5):540-49. [pmid: 22595163].
Erlinge D, Varenhorst C, Braun OO, et al. Patients with poor responsiveness to thienopyridine treatment or with diabetes have lower levels of circulating active metabolite, but their platelets respond normally to active metabolite added ex vivo. J Am Coll Cardiol. Dec. 9. 2008;52(24):1968-77. [pmid: 19055987].
Gaglia MA Jr., Torguson R, Pakala R, et al. Relation of body mass index to on-treatment (clopidogrel + aspirin) platelet reactivity. Am J Cardiol. Sep. 15. 2011;108(6):766-71. [pmid: 21752347].
Gremmel T, Kopp CW, Seidinger D, et al. The formation of monocyte-platelet aggregates is independent of on-treatment residual agonists'-inducible platelet reactivity. Atherosclerosis. Dec. 2009;207(2):608-13. [pmid: 19616779].
Gremmel T, Fruhwirth K, Kopp CW, et al. Frequency of heparin/platelet factor 4-dependent platelet antibodies in patients undergoing angioplasty and stenting for cardiovascular disease and their role for on-clopidogrel platelet reactivity. Clin Res Cardiol. Jun. 2012;101(6):445-52. [pmid: 22234620].
Hamilos M, Muller O, Ntalianis A, et al. Relationship between peripheral arterial reactive hyperemia and residual platelet reactivity after 600 mg clopidogrel. J Thromb Thrombolysis. Jul. 2011;32(1):64-71. [pmid: 21290254].
Kim BJ, Lee SW, Park SW, et al. Insufficient platelet inhibition is related to silent embolic cerebral infarctions after coronary angiography. Stroke. Mar. 2012;43(3):727-32. [pmid: 22207508].
Koerner H, Derveaux C, Alexandrou M, et al. Do Clopidogrel Nonresponders Have an Increased Risk of Adverse Events during Supra-Aortal Angioplasty and Stenting?. Stroke Res Treat. 2012;2012:904534. [pmid: 22577603].
Kuliczkowski W, Gasior M, Pres D, et al. Effect of glycemic control on response to antiplatelet therapy in patients with diabetes mellitus and ST-segment elevation myocardial infarction. Am J Cardiol. Aug. 1. 2012;110(3):331-36. [pmid: 22551736].
Lev EI, Patel RT, Maresh KJ, et al. Aspirin and clopidogrel drug response in patients undergoing percutaneous coronary intervention: the role of dual drug resistance. J Am Coll Cardiol. Jan. 3. 2006;47(1):27-33. [pmid: 16386660].
Lev EI, Ramchandani M, Garg R, et al. Response to aspirin and clopidogrel in patients scheduled to undergo cardiovascular surgery. J Thromb Thrombolysis. Aug. 2007;24(1):15-21. [pmid: 17277998].
Malek LA, Grabowski M, Spiewak M, et al. Relation between impaired antiplatelet response to clopidogrel and possible pleiotropic effects. J Thromb Thrombolysis. Dec. 2007;24(3):301-05. [pmid: 17404690].
Mangiacapra F, Peace AJ, Wijns W, et al. Lack of correlation between platelet reactivity and glycaemic control in type 2 diabetes mellitus patients treated with aspirin and clopidogrel. J Thromb Thrombolysis. Jul. 2011;32(1):54-58. [pmid: 21221715].
Meen O, Brosstad F, Bjornsen S, et al. Variability in aggregometry response before and after initiation of clopidogrel therapy. Scand J Clin Lab Invest. 2009;69(6):673-79. [pmid: 19484660].
Minarik M, Kopeckova M, Gassman M, et al. Rapid testing of clopidogrel resistance by genotyping of CYP2C19 and CYP2C9 polymorphisms using denaturing on-chip capillary electrophoresis. Electrophoresis. Apr. 2012;33(8):1306-10. [pmid: 22589111].
Muller O, Hamilos M, Bartunek J, et al. Relation of endothelial function to residual platelet reactivity after clopidogrel in patients with stable angina pectoris undergoing percutaneous coronary intervention. Am J Cardiol. Feb. 1. 2010;105(3):333-38. [pmid: 20102944].
Perez de PA, Fernandez-Vazquez F, Cuellas JC, et al. Association between level of platelet inhibition after early use of abciximab and myocardial reperfusion in ST-elevation acute myocardial Infarction treated by primary percutaneous coronary intervention. Am J Cardiol. Mar. 15. 2006;97(6):798-803. [pmid: 16516579].
Serebruany V, Rao SV, Silva MA, et al. Correlation of inhibition of platelet aggregation after clopidogrel with post discharge bleeding events: assessment by different bleeding classifications. Eur Heart J. Jan. 2010;31(2):227-35. [pmid: 19854728].
Serebruany VL, Malinin AI, Pokov AN, et al. Antiplatelet profiles of the fixed-dose combination of extended-release dipyridamole and low-dose aspirin compared with clopidogrel with or without aspirin in patients with type 2 diabetes and a history of transient ischemic attack: a randomized, single-blind, 30-day trial. Clin Ther. Feb. 2008;30(2):249-59. [pmid: 18343263].
Stellos K, Bigalke B, Stakos D, et al. Platelet-bound P-selectin expression in patients with coronary artery disease: impact on clinical presentation and myocardial necrosis, and effect of diabetes mellitus and anti-platelet medication. J Thromb Haemost. Jan. 2010;8(1):205-07. [pmid: 19874461].
Taomoto K, Ohnishi H, Kuga Y, et al. Platelet function and spontaneous thrombolytic activity of patients with cerebral infarction assessed by the global thrombosis test. Pathophysiol Haemost Thromb. 2010;37(1):43-48. [pmid: 20516672].
Velik-Salchner C, Maier S, Innerhofer P, et al. Point-of-care whole blood impedance aggregometry versus classical light transmission aggregometry for detecting aspirin and clopidogrel: the results of a pilot study. Anesth Analg. Dec. 2008;107(6):1798-806. [pmid: 19020120].
Zalewski J, Durak M, Lech P, et al. Platelet activation and microvascular injury in patients with ST-segment elevation myocardial infarction. Kardiol Pol. 2012;70(7):677-84. [pmid: 22825940].