# Search Strategy

## Search run on June 27, 2012

Ovid MEDLINE(R) 1946 to June Week 2 2012, Ovid MEDLINE(R) In-Process & Other Non-Indexed Citations June 26, 2012, EBM Reviews - Cochrane Database of Systematic Reviews 2005 to June 2012, EBM Reviews - Cochrane Central Register of Controlled Trials June 2012, Ovid MEDLINE(R) Daily Update June 26, 2012, Ovid OLDMEDLINE(R) 1946 to 1965

# | Searches | Results
1 | ((acute and coronary and syndrome$) or ACS or myocardial infarction or ST elevation or non-ST elevation or percutaneous coronary intervention or (percutaneous and coronary and intervention) or PCI or stent$ or implant$ or CABG or (coronary and artery and bypass and graft$) or coronary artery bypass graft$ or stroke or TIA or (transient and isch?emic and attack) or (peripheral and arter$ and disease$) or (atrial and fibrillation) or (coronary and artery and disease) or (unstable and angina) or (angina and (ischemic or pectoris)) or ((cardiac or heart) and catheterization) or respond$ or non-respon$).af. or exp acute coronary syndrome/ or exp myocardial infarction/ or exp peripheral arterial disease/ or exp stent/ or exp atrial fibrillation/ or exp coronary artery bypass graft/ or exp stroke/ or exp transient ischemic attack/ or exp coronary artery disease/ or exp unstable angina/ or exp patient selection/ or exp coronary angiography/ | 1,348,184
2 | (clopidogrel or plavix or prasugrel or effient or ticlopidine or ticlid or aggrenox or dipyridamole or ticagrelor or dipyridamole or persantine or (p2y12 and inhibitor) or antiplatelet$ or anti-platelet$ or “thienopyridine” or platelet inhibition).af. or (90055-48-4 or 55142-85-3 or 150322-43-3or 58-32-2 or 274693-27-5).rn. | 34,489
3 | (cytochrome p450 or pharmacogenetics or cyp450 or cyp-450 or polymorph$ or genetic$ or cyp2c19 or 2c19 or genotype or p-450 or rs4244285 or rs28399504 or rs56337013 or rs12248560 or pharmacogenomics or allele$ or varia$ or ((platelet and activ$) or (platelet and aggregation) or platelet reacti$ or (platelet and function) or “thrombelastography” or “thromboelastography” or TEG or “pfa 100” or “pfa-100” or “pfa100” or ((optical or (light and transmission) or (light and transmittance) or (whole and blood) or impedance) and aggregometry) or (turbidimetric and optical and detection) or aggregometer or vasp or verifynow or p2y12 or ultegra or rpfa or (vasodilator and stimulated and phosphoprotein) or multiplate or “impact-R” or “Impact R”)).af. or (exp cytochrome p450/ or exp Cytochrome P-450 Enzyme System/ OR Cytochrome P-450 CYP2c19/) | 3,960,275
4 | 1 and 2 and 3 | 10,374