# Acronyms

ACTIVE A trial: Atrial Fibrillation Clopidogrel Trial with Irbesartan for Prevention of Vascular Events A trial
ACS: Acute coronary syndromes
ADP: Adenosine diphosphate
AHRQ: Agency for Healthcare Research and Quality
CABG: Coronary artery bypass graft
CHARISMA trial: Clopidogrel for High Atherothrombotic Risk and Ischemic Stabilization, Management and Avoidance trial
CI: Confidence interval
CURE trial: Clopidogrel in Unstable Angina to Prevent Recurrent Events trial
EGAPP: Evaluation of Genomic Applications in Practice and Prevention
EPC: Evidence-based Practice Center
FDA: U.S. Food and Drug Administration
GOF: Gain-of-function
GRAVITAS trial: Gauging Responsiveness with a VerifyNow Assay—Impact on Thrombosis and Safety trial
GUSTO criteria: Global Utilization of Streptokinase and Tissue Plasminogen Activator for Occluded Coronary Arteries criteria
HuGENet: Human Genome Epidemiology Network
ISAR-REACT 4 trial: Intracoronary Stenting and Antithrombotic Regimen: Rapid Early Action for Coronary Treatment 4 trial
LOF: Loss-of-function
LTA: Light-transmission aggregometry
MACE: Major adverse cardiovascular events
OR: Odds ratio
PCI: Percutaneous coronary intervention
PCR: Polymerase chain reaction
PFA: Platelet Function Analyzer
PPI: Proton pump inhibitor
PRI: Platelet reactivity index
PRU: Platelet reactivity units
PLATO trial: PLATelet inhibition and patient Outcomes trial
QUADAS-2: Quality Assessment of Diagnostic Accuracy Studies 2
RCT: Randomized Controlled Trial
RFLP: Restriction fragment length polymorphism
rOR: Relative odds ratio
RR: Relative risk
SIP: Scientific information packets
SRC: Scientific resource center
ST: Stent thrombosis
TEP: Technical Expert Panel
TOO: Task Order Officer
TRIGGER-PCI: Testing Platelet Reactivity In Patients Undergoing Elective Stent Placement on Clopidogrel to Guide Alternative Therapy With Prasugre
TRITON-TIMI 38: Trial to Assess Improvement in Therapeutic Outcomes by trial Optimizing Platelet Inhibition With Prasugrel–Thrombolysis In Myocardial Infarction 38
VASP: Vasodilator-stimulated phosphoprotein