# Acknowledgments

The authors would like to thank C. Michael White, Pharm.D., FCP, FCCP, the Associate Editor for this report, for numerous helpful suggestions.