# References

1 The National Center for Complementary and Alternative Medicine (NCCAM). [Web Page]. http://nccam.nih.gov/. Jan 2012.
2 Barnes PM, Bloom B, Nahin RL. Complementary and alternative medicine use among adults and children: United States, 2007. Natl Health Stat Report. 2008;(12):1-23. [pmid: 19361005].
3 Goyal M, Haythornthwaite J, Levine D, et al. Intensive meditation for refractory pain and symptoms. J Altern Complement Med. 2010;16(6):627-31. [pmid: 20569029].
4 Chiesa A, Malinowski P. Mindfulness-based approaches: are they all the same?. J Clin Psychol. 2011;67(4):404-24. [pmid: 21254062].
5 Ospina MB, Bond TK, Karkhaneh M, Tjosvold L, Vandermeer B, Liang Y, et al. Meditation Practices for Health: State of the Research. Evidence Report/Technology Assessment No. 155. (Prepared by the University of Alberta Evidence-based Practice Center under Contract No. 290-02-0023.) AHRQ Publication No. 07-E010. Rockville, MD. Agency for Healthcare Research and Quality. June. 2007.
6 Travis F, Shear J. Focused attention, open monitoring and automatic self-transcending: Categories to organize meditations from Vedic, Buddhist and Chinese traditions. Conscious Cogn. Dec. 2010;19(4):1110-8. [pmid: 20167507].
7 Bishop SR, Lau M, Shapiro S, et al. Mindfulness: A proposed operational definition. Clin Psychol Sci Prac. 2004;11:230-241.
8 Baer RA, Smith GT, Lykins E, Button D, Krietemeyer J, Sauer S, Williams J. ‥onstruct validity of the five facets mindfulness questionnaire in meditating and nonmeditating samples. Assessment. 2008;15:329-342. [pmid: 18310597].
9 Baer RA, Walsh E, Lykins E. Assessment of mindfulness. Didonna F, editor. Clinical handbook of mindfulness. 2009:153168. New York. Springer.
10 Malinowski P. Mindfulness as psychological dimension: Concepts and applications. Irish Journal of Psychology. 2008;29:155166.
11 Chambers R, G E, A N. Mindful emotion regulation: An integrative review. Clin Psychol Rev. 2009;29(6):560-72. [pmid: 19632752].
12 Rapgay L, Bystrisky A. Classical mindfulness: an introduction to its theory and practice for clinical application. Ann N Y Acad Sci. 2009;1172:148-62. [pmid: 19735247].
13 Walach H. Review of “Effectiveness of Meditation in Healthcare”. www.mum.edu/inmp/walach.html. February 17, 2012.
14 Orme-Johnson DW. Commentary on the AHRQ report on research on meditation practices in health. J Altern Complement Med. 2008;14(10):1215-21. [pmid: 19123876].
15 Bohlmeijer E, Prenger R, Taal E, Cuijpers P. The effects of mindfulness-based stress reduction therapy on mental health of adults with a chronic medical disease: a meta-analysis. J Psychosom Res. 2010;68(6):539-44. [pmid: 20488270].
16 Chiesa A, Serretti A. Mindfulness-based stress reduction for stress management in healthy people: a review and meta-analysis. J Altern Complement Med. 2009;15(5):593-600. [pmid: 19432513].
17 Chiesa A, Calati R, Serretti A. Does mindfulness training improve cognitive abilities? A systematic review of neuropsychological findings. ClinPsychol Rev. 2011;31(3):449-64.
18 Chiesa A, Serretti A. Mindfulness based cognitive therapy for psychiatric disorders: a systematic review and meta-analysis. Psychiatry Res. 2011;187(3):441-53. [pmid: 20846726].
19 Hofmann SG, Sawyer AT, Witt AA, Oh D. The effect of mindfulness-based therapy on anxiety and depression: A meta-analytic review. J Consult Clin Psychol. 2010;78(2):169-83. [pmid: 20350028].
20 Krisanaprakornkit T, Ngamjarus C, Witoonchart C, Piyavhatkul N. Meditation therapies for attention-deficit/hyperactivity disorder (ADHD). Cochrane Database Syst Rev. 2010;(6):CD006507. [pmid: 20556767].
21 Ledesma D, Kumano H. Mindfulness-based stress reduction and cancer: a meta-analysis. Psychooncology. 2009;18(6):571-9. [pmid: 19023879].
22 Matchim Y, Armer JM, Stewart BR. Mindfulness-based stress reduction among breast cancer survivors: a literature review and discussion. Oncol Nurs Forum. 2011;38(2):E61-71. [pmid: 21356643].
23 Piet J, Hougaard E. The effect of mindfulness-based cognitive therapy for prevention of relapse in recurrent major depressive disorder: a systematic review and meta-analysis. Clin Psychol Rev. 2011;31(6):1032-40. [pmid: 21802618].
24 Wanden-Berghe RG, Sanz-Valero J, Wanden-Berghe C. The application of mindfulness to eating disorders treatment: a systematic review. Eat Disord. 2011;19(1):34-48. [pmid: 21181578].
25 Winbush NY, Gross CR, Kreitzer MJ. The effects of mindfulness-based stress reduction on sleep disturbance: a systematic review. Explore (NY). 2007;3(6):585-91. [pmid: 18005910].
26 Zgierska A, Rabago D, Chawla N, Kushner K, Koehler R, Marlatt A. Mindfulness meditation for substance use disorders: a systematic review. Subst Abus. 2009;30(4):266-94. [pmid: 19904664].
27 Bernardy K, Fuber N, Kollner V, Hauser W. Efficacy of cognitive-behavioral therapies in fibromyalgia syndrome—a systematic review and metaanalysis of randomized controlled trials. J Rheumatol. 2010;37(10):1991-2005. [pmid: 20682676].
28 Rainforth MV, Schneider RH, Nidich SI, Gaylord-King C, Salerno JW, Anderson JW. Stress reduction programs in patients with elevated blood pressure: a systematic review and meta-analysis. Curr Hypertens Rep. 2007;9(6):520-8. [pmid: 18350109].
29 Anderson JW, Liu C, Kryscio RJ. Blood pressure response to transcendental meditation: a meta-analysis. Am J Hypertens. 2008;21(3):310-6. [pmid: 18311126].
30 Canter PH, Ernst E. The cumulative effects of Transcendental Meditation on cognitive function—a systematic review of randomised controlled trials. Wien Klin Wochenschr. 2003;115(21-22):758-66. [pmid: 14743579].
31 SO KT, O-J D. Three randomized experiments on the longitudinal effects of the Transcendental Meditation technique on cognition. Intelligence. 2001:419-40.
32 Travis F, G S, Stixrud W. ADHD, Brain Functioning, and Transcendental Meditation Practice. Mind & Brain, The Journal of Psychiatry. 2011:73-81.
33 Chen KW, B C, M E, et al. Meditative therapies for reducing anxiety: a systematic review and meta-analysis of randomized controlled trials. Depress Anxiety. 2012;29(7):545-62. [pmid: 22700446].
34 Chambless DL, Hollon SD. Defining empirically supported therapies. J Consult Clin Psychol. 1998;66(1):7-18. [pmid: 9489259].
35 Hollon SD, Ponniah K. A review of empirically supported psychological therapies for mood disorders in adults. Depress Anxiety. 2010;27(10):891-932. [pmid: 20830696].
36 Moher D, Liberati A, Tetzlaff J, Altman DG, The PRISMA Group. Preferred Reporting Items for Systematic Reviews and Meta-Analyses: The PRISMA Statement. PLoS Med. 6(7):e1000097. [pmid: 19621072].
37 Meditation Programs for Stress and Well-being—Research protocol. [Web Page].
38 Google site. http://translate.google.com.
39 Bhogal SK, Teasell RW, Foley NC, Speechley MR. The PEDro scale provides a more comprehensive measure of methodological quality than the Jadad scale in stroke rehabilitation literature. J Clin Epidemiol. 2005;58(7):668-73. [pmid: 15939217].
40 Chambless DL, Ollendick TH. Empirically supported psychological interventions: controversies and evidence. Annu Rev Psychol. 2001;52:685-716. [pmid: 11148322].
41 Patient Reported Outcomes Measurement Information System (PROMIS^®^). www.nihpromis.org. August 10, 2011. [Web Page].
42 Cohen J. Statistical power analysis for the behavioral sciences. Hillsdale, NJ. L. Erlbaum Associates. 1988.
43 Lyubomirsky S, King L, Diener E. The benefits of frequent positive affect: does happiness lead to success?. Psychol Bull. 2005;131(6):803-55. [pmid: 16351326].
44 Clark LA, Watson D. Tripartite model of anxiety and depression: psychometric evidence and taxonomic implications. J Abnorm Psychol. 1991;100(3):316-36. [pmid: 1918611].
45 Methods Guide for Effectiveness and Comparative Effectiveness Reviews. Rockville, MD. Agency for Healthcare Research and Quality. August. 2007. AHRQ Publication No. 10(11)-EHC063-EF.
46 Higgins JP, Altman DG, Gotzsche PC, et al. The Cochrane Collaboration's tool for assessing risk of bias in randomised trials. BMJ. 2011;343:d5928. [pmid: 22008217].
47 Higgins JPT, Green S, editors. Cochrane handbook for systematic reviews of Interventions Version 5.1.0. London. The Cochrane Collaboration. Updated March 2011. www.cochrane.org/training/cochrane-handbook. February 17, 2012.
48 Owens DK, L K, A D, et al. AHRQ series paper 5: grading the strength of a body of evidence when comparing medical interventions—agency for healthcare research and quality and the effective health-care program. J Clin Epidemiol. 2010;63(5):513-23. [pmid: 19595577].
49 Brewer JA, Sinha R, Chen JA, et al. Mindfulness training and stress reactivity in substance abuse: results from a randomized, controlled stage I pilot study. Subst Abus. 2009;30(4):306-17. [pmid: 19904666].
50 Brewer JA, Mallik S, Babuscio TA, et al. Mindfulness training for smoking cessation: Results from a randomized controlled trial. Drug Alcohol Depend. 2011.
51 Delgado LC, Guerra P, Perakakis P, Vera MN, Reyes del Paso G, Vila J. Treating chronic worry: Psychological and physiological effects of a training programme based on mindfulness. Behav Res Ther. 2010;48(9):873-82. [pmid: 20541180].
52 Garland EL, Gaylord SA, Boettiger CA, Howard MO. Mindfulness training modifies cognitive, affective, and physiological mechanisms implicated in alcohol dependence: results of a randomized controlled pilot trial. J Psychoactive Drugs. 2010;42(2):177-92. [pmid: 20648913].
53 Gaylord SA, Palsson OS, Garland EL, et al. Mindfulness training reduces the severity of irritable bowel syndrome in women: results of a randomized controlled trial. Am J Gastroenterol. 2011;106(9):1678-88. [pmid: 21691341].
54 Gross CR, Kreitzer MJ, Thomas W, et al. Mindfulness-based stress reduction for solid organ transplant recipients: a randomized controlled trial. Altern Ther Health Med. 2010;16(5):30-8. [pmid: 20882729].
55 Gross CR, Kreitzer MJ, Reilly-Spong M, et al. Mindfulness-based stress reduction versus pharmacotherapy for chronic primary insomnia: a randomized controlled clinical trial. Explore (NY). 2011;7(2):76-87. [pmid: 21397868].
56 Hebert JR, Ebbeling CB, Olendzki BC, et al. Change in women's diet and body mass following intensive intervention for early-stage breast cancer. J Am Diet Assoc. 2001;101(4):421-31. [pmid: 11320947].
57 Henderson VP, Clemow L, Massion AO, Hurley TG, Druker S, Hebert JR. The effects of mindfulness-based stress reduction on psychosocial outcomes and quality of life in early-stage breast cancer patients: a randomized trial. Breast Cancer Res Treat. 2011.
58 Koszycki D, Benger M, Shlik J, Bradwejn J. Randomized trial of a meditation-based stress reduction program and cognitive behavior therapy in generalized social anxiety disorder. Behav Res Ther. 2007;45(10):2518-26. [pmid: 17572382].
59 Kuyken W, Byford S, Taylor RS, et al. Mindfulness-based cognitive therapy to prevent relapse in recurrent depression. J Consult Clin Psychol. 2008;76(6):966-78. [pmid: 19045965].
60 Lee SH, Ahn SC, Lee YJ, Choi TK, Yook KH, Suh SY. Effectiveness of a meditation-based stress management program as an adjunct to pharmacotherapy in patients with anxiety disorder. J Psychosom Res. 2007;62(2):189-95. [pmid: 17270577].
61 Malarkey WB, Jarjoura D, Klatt M. Workplace based mindfulness practice and inflammation: A randomized trial. Brain Behav Immun. 2012.
62 Miller CK, Kristeller JL, Headings A, Nagaraja H, Miser WF. Comparative Effectiveness of a Mindful Eating Intervention to a Diabetes Self-Management Intervention among Adults with Type 2 Diabetes: A Pilot Study. J Acad Nutr Diet. 2012;112(11):1835-42. [pmid: 23102183].
63 Moritz S, Quan H, Rickhi B, et al. A home study-based spirituality education program decreases emotional distress and increases quality of life—a randomized, controlled trial. Altern Ther Health Med. 2006;12(6):26-35. [pmid: 17131979].
64 Morone NE, Rollman BL, Moore CG, Li Q, Weiner DK. A mind-body program for older adults with chronic low back pain: results of a pilot study. Pain Med. 2009;10(8):1395-407. [pmid: 20021599].
65 Mularski RA, Munjas BA, Lorenz KA, et al. Randomized controlled trial of mindfulness-based therapy for dyspnea in chronic obstructive lung disease. J Altern Complement Med. 2009;15(10):1083-90. [pmid: 19848546].
66 Oken BS, Fonareva I, Haas M, et al. Pilot controlled trial of mindfulness meditation and education for dementia caregivers. J Altern Complement Med. 2010;16(10):1031-8. [pmid: 20929380].
67 Philippot P, Nef F, Clauw L, Romree M, Segal Z. A Randomized Controlled Trial of Mindfulness-Based Cognitive Therapy for Treating Tinnitus. Clin Psychol Psychother. 2011.
68 Piet J, Hougaard E, Hecksher MS, Rosenberg NK. A randomized pilot study of mindfulness-based cognitive therapy and group cognitive-behavioral therapy for young adults with social phobia. Scand J Psychol. 2010;51(5):403-10.
69 Plews-Ogan M, Owens JE, Goodman M, Wolfe P, Schorling J. A pilot study evaluating mindfulness-based stress reduction and massage for the management of chronic pain. J Gen Intern Med. 2005;20(12):1136-8. [pmid: 16423104].
70 Schmidt S, Grossman P, Schwarzer B, Jena S, Naumann J, Walach H. Treating fibromyalgia with mindfulness-based stress reduction: results from a 3-armed randomized controlled trial. Pain. 2011;152(2):361-9. [pmid: 21146930].
71 Segal ZV, Bieling P, Young T, et al. Antidepressant monotherapy vs sequential pharmacotherapy and mindfulness-based cognitive therapy, or placebo, for relapse prophylaxis in recurrent depression. Arch Gen Psychiatry. 2010;67(12):1256-64. [pmid: 21135325].
72 Whitebird RR, Kreitzer M, Crain AL, Lewis BA, Hanson LR, Enstad CJ. Mindfulness-Based Stress Reduction for Family Caregivers: A Randomized Controlled Trial. Gerontologist. 2012.
73 Wolever RQ, Bobinet KJ, McCabe K, et al. Effective and viable mind-body stress reduction in the workplace: a randomized controlled trial. J Occup Health Psychol. 2012;17(2):246-58. [pmid: 22352291].
74 Wong SY, Chan FW, Wong RL, et al. Comparing the Effectiveness of Mindfulness-based Stress Reduction and Multidisciplinary Intervention Programs for Chronic Pain: A Randomized Comparative Trial. Clin J Pain. 2011;27(8):724-34. [pmid: 21753729].
75 Bormann JE, Gifford AL, Shively M, et al. Effects of spiritual mantram repetition on HIV outcomes: a randomized controlled trial. J Behav Med. 2006;29(4):359-76. [pmid: 16847590].
76 Castillo-Richmond A, Schneider RH, Alexander CN, et al. Effects of stress reduction on carotid atherosclerosis in hypertensive African Americans. Stroke. 2000;31(3):568-73. [pmid: 10700487].
77 Elder C, Aickin M, Bauer V, Cairns J, Vuckovic N. Randomized trial of a whole-system ayurvedic protocol for type 2 diabetes. Altern Ther Health Med. 2006;12(5):24-30. [pmid: 17017752].
78 Jayadevappa R, Johnson JC, Bloom BS, et al. Effectiveness of transcendental meditation on functional capacity and quality of life of African Americans with congestive heart failure: a randomized control study. Ethn Dis. 2007 Summer;17(3):595. Ethnicity & Disease. 2007;17(1):72-7. [pmid: 17274213].
79 Lehrer PM. Progressive relaxation and meditation: A study of psychophysiological and therapeutic differences between two techniques. Behav Res Ther. 1983;21(6):651-62. [pmid: 6362649].
80 Murphy TJ, Pagano RR, Marlatt GA. Lifestyle modification with heavy alcohol drinkers: effects of aerobic exercise and meditation. Addict Behav. 1986;11(2):175-86. [pmid: 3526824].
81 Paul-Labrador M, Polk D, Dwyer JH, et al. Effects of a randomized controlled trial of transcendental meditation on components of the metabolic syndrome in subjects with coronary heart disease. Arch Intern Med. 2006;166(11):1218-24. [pmid: 16772250].
82 Sheppard WD II, Staggers FJ Jr., John L. The effects of a stress management program in a high security government agency. 1997;10(4):341-50.
83 Smith JC. Psychotherapeutic effects of transcendental meditation with controls for expectation of relief and daily sitting. J Consult Clin Psychol. 1976;44(4):630-7. [pmid: 939847].
84 Taub E, Steiner SS, Weingarten E, Walton KG. Effectiveness of broad spectrum approaches to relapse prevention in severe alcoholism: A long-term, randomized, controlled trial of Transcendental Meditation, EMG biofeedback and electronic neurotherapy. Alcoholism Treatment Quarterly. 1994;11(1-2):187-220.
85 Barrett B, Hayney MS, Muller D, et al. Meditation or exercise for preventing acute respiratory infection: a randomized controlled trial. Ann Fam Med. 2012;10(4):337-46. [pmid: 22778122].
86 Chiesa A, Mandelli L, Serretti A. Mindfulness-based cognitive therapy versus psycho-education for patients with major depression who did not achieve remission following antidepressant treatment: a preliminary analysis. J Altern Complement Med. 2012;18(8):756-60. [pmid: 22794787].
87 Jazaieri H, Goldin PR, Werner K, Ziv M, Gross JJ. A Randomized Trial of MBSR Versus Aerobic Exercise for Social Anxiety Disorder. J Clin Psychol. 2012.
88 Pbert L, Madison JM, Druker S, et al. Effect of mindfulness training on asthma quality of life and lung function: A randomised controlled trial. 2012;67(9):769-76.
89 SeyedAlinaghi S, Jam S, Foroughi M, et al. Randomized controlled trial of mindfulness-based stress reduction delivered to human immunodeficiency virus-positive patients in Iran: effects on CD4[sup]+[/sup] T lymphocyte count and medical and psychological symptoms. Psychosom Med. 2012;74(6):620-7. [pmid: 22753635].
90 Schneider RH, Grim CE, Rainforth MV, et al. Stress Reduction in the Secondary Prevention of Cardiovascular Disease: Randomized, Controlled Trial of Transcendental Meditation and Health Education in Blacks. (1941-7705 (Electronic). 1941-7713 (Linking)).
91 Pipe TB, Bortz JJ, Dueck A, Pendergast D, Buchda V, Summers J. Nurse leader mindfulness meditation program for stress management: a randomized controlled trial. J Nurs Adm. 2009;39(3):130-7. [pmid: 19590469].
92 Fournier JC, DeRubeis RJ, Hollon SD, et al. Antidepressant drug effects and depression severity: a patient-level meta-analysis. JAMA. Jan. 6. 2010;303(1):47-53. [pmid: 20051569].
93 Krisanaprakornkit T, Krisanaprakornkit W, Piyavhatkul N, Laopaiboon M. Meditation therapy for anxiety disorders. Cochrane Database Syst Rev. 2006;(1):CD004998. [pmid: 16437509].
94 Veehof MM, Oskam MJ, Schreurs KM, Bohlmeijer ET. Acceptance-based interventions for the treatment of chronic pain: a systematic review and meta-analysis. Pain. 2011;152(3):533-42. [pmid: 21251756].
95 Treadwell JR, Singh S, Talati R, et al. A Framework for “Best Evidence” Approaches in Systematic Reviews. Methods Research Report. (Prepared by the ECRI Institute Evidence-based Practice Center under Contract No. HHSA 290-2007-10063-I). Rockville, MD. Agency for Healthcare Research and Quality. June. 2011. AHRQ Publication No. 11-EHC046-EF.