# Peer Reviewers

Prior to publication of the final evidence report, EPCs sought input from independent Peer Reviewers without financial conflicts of interest. However, the conclusions and synthesis of the scientific literature presented in this report does not necessarily represent the views of individual reviewers.

Peer Reviewers must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential nonfinancial conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential nonfinancial conflicts of interest identified.

The list of Peer Reviewers follows:

- Vernon Barnes, Ph.D.
  Georgia Prevention Center
  Institute of Public and Preventive Health
  Georgia Regents University
  Augusta, GA
- David S. Black, Ph.D., M.P.H.
  Assistant Professor of Preventive Medicine
  Institute for Prevention Research
  Keck School of Medicine
  University of Southern California
  Los Angeles, CA
- Mary Butler, Ph.D., M.B.A.
  Associate Director, Minnesota EPC
  University of Minnesota School of Public Health
  Minneapolis, MN
- Amparo Castillo, M.D., M.S.
  Training Coordinator and Researcher
  Midwest Latino Health Research Training and Policy Center at the Jane Addams College of Social Work and Institute for Health Research and Policy
  University of Illinois at Chicago
  Chicago, IL
- Vinjar Fonnebo, M.D., Ph.D.
  National Research Centre in Complementary and Alternative Medicine (NAFKAM)
  University of Tromso
  Tromso, Norway
- Robert Kane, M.D.
  University of Minnesota School of Public Health
  Minneapolis, MN
- Kathleen Kemper, M.D.
  Ohio State College of Medicine
  Center for Integrative Health and Wellness
  Columbus, OH
- Mary Jo Kreitzer, Ph.D., R.N.
  Center for Spirituality & Healing
  University of Minnesota
  Minneapolis, MN