# Key Informants

In designing the study questions, the EPC consulted several Key Informants who represent the end-users of research. The EPC sought the Key Informant input on the priority areas for research and synthesis. Key Informants are not involved in the analysis of the evidence or the writing of the report. Therefore, in the end, study questions, design, methodological approaches, and/or conclusions do not necessarily represent the views of individual Key Informants.

Key Informants must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their role as end-users, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any conflicts of interest.

The list of Key Informants who participated in developing this report follows:

- Richard J. Davidson, Ph.D.
  University of Wisconsin
  Madison, WI
- John R. Glowa, Ph.D.
  National Center for Complementary and Alternative Medicine
  Bethesda, MD
- Barbara L. Niles, Ph.D.
  National Center for PTSD
  Boston University School of Medicine
  Boston, MA
- Dr. David Orme-Johnson, Ph.D.
  Consultant
  Seagrove Beach, FL
- Robert Schneider, M.D., FACC, FABMR
  Professor and Director
  Institute for Natural Medicine and Prevention
  Dean, Maharishi College of Perfect Health
  Maharishi University of Management
  Maharishi Vedic City, IA