# Addendum

In June 2013, we ran an updated search for the review from our last update in November 2012. We used the same search criteria across the electronic databases, and after removal of duplicate citations we identified 952 new citations. These citations underwent title-abstract review, and 27 trials were pulled for full article review. Of these, six new trials met criteria for inclusion in our review. Further details can be found online at: Goyal M, Singh S. Sibinga EMS, et al. Meditation programs for psychological stress and well-being: a systematic review and meta-analysis. JAMA Intern Med. Epub Jan 6 2014. doi:10.1001/jamainternmed.2013.13018.

Of the six new trials, one was a transcendental meditation trial among patients with HIV, involving nonspecific active controls. Of the remaining five mindfulness trials, two used a nonspecific active control among patients with anxiety or sleep disturbance, and three used a specific active control among patients with anxiety, depression or stress. Three trials contributed to the outcome of anxiety, four trials to the outcome of depression, three trials to the outcome of stress/distress, one trial to the outcome of positive affect, and two trials to the outcome of sleep.

The addition of these trials did not change the overall conclusions or the strength of evidence for any of the outcomes. While the meta-analytic effect sizes for the outcomes where the new trials contributed data changed slightly, the statistical significance did not change and the confidence intervals changed only slightly. Thus only the effect sizes are reported here. For the outcome of anxiety, the effect size changed from 0.40 to 0.38 for mindfulness programs compared with a nonspecific active control, and from 0.06 to 0.07 for mindfulness programs compared with specific active controls. For the outcome of depression, the effect size changed from 0.32 to 0.30 for mindfulness programs compared with nonspecific active controls, from 0.16 to 0.11 for mindfulness programs compared with specific active controls and from 0.24 to 0.27 for Mantra programs compared with nonspecific active controls. For the outcome of negative affect, the effect size changed from 0.34 to 0.33 for mindfulness programs compared with a nonspecific active control. For the outcome of positive affect, the effect size changed from 0.31 to 0.28 for mindfulness programs compared with a nonspecific active control. For the outcome of sleep, the effect size changed from 0.12 to 0.14 for mindfulness programs compared with a nonspecific active control.