# Acknowledgments

The authors gratefully acknowledge the continuing support of our AHRQ Task Order Officer, Shilpa H. Amin. We extend our appreciation to our Key Informants and members of our Technical Expert Panel (listed below), all of whom provided thoughtful advice and input during our research process.

The EPC thanks Swaroop Vedula for conducting meta-analyses and assisting with their interpretation. The EPC also thanks Manisha Reuben, Deepa Pawar, Oluwaseun Shogbesan, and Yohalakshmi Chelladurai for their contributions to this project and Eric Vohr for his editorial contribution.