# Discussion

Forty-one randomized controlled trials (RCTs) reported in this review tested the effects of meditation programs in clinical conditions relative to active controls. Ten programs tested mantra meditation and 31 programs tested mindfulness meditation. Active control groups included both “nonspecific” controls as well as specific controls that offer an opportunity to examine the comparative effectiveness of meditation programs. Our review finds that the mantra meditation programs do not appear to improve any of the psychological stress and well-being outcomes we examined, but the strength of this evidence varies from low to insufficient. We find that the mindfulness meditation programs show small improvements in anxiety, depression, and pain with moderate strength of evidence, and small improvements in stress/distress, negative affect, and the mental-health component of health-related quality of life with low strength of evidence when compared to nonspecific active controls. The remaining outcomes had insufficient evidence to draw any level of conclusion for mindfulness meditation programs. We were unable to draw a high grade for either type of meditation program for any of the psychological stress and well-being outcomes. We also found no evidence for any harms, although few trials reported on this.

It is important to keep in mind the conceptual meanings of our different levels of strength of evidence. “High” strength of evidence indicates high confidence that the evidence reflects the true effect, and further research is very unlikely to change our confidence in the estimate of the effect. “Moderate” strength of evidence indicates moderate confidence that the evidence reflects the true effect, and further research may change our confidence in the estimate of the effect and may change the estimate. “Low” strength of evidence indicates low confidence that the evidence reflects the true effect, and further research is likely to change our confidence in the estimate of the effect and is likely to change the estimate. Finally “insufficient” strength of evidence indicates evidence is either unavailable or inadequate to draw a conclusion.

Before addressing each Key Question (KQ), there are some methodological aspects of this review that deserve comment.

First, our method purposely established a high standard for selecting RCTs by requiring the inclusion of an active control group that was matched for time and attention to the meditation program of interest. We elected to use this approach in order to add to what we have already learned from existing reviews of meditation, and to determine whether any comparative effectiveness conclusions could be drawn from the existing literature. This more rigorous approach supports the conclusion that meditation programs improve psychological stress and well-being in groups with clinical conditions; however, we find no evidence to support the differential effectiveness of meditation in comparison to other treatments for psychological stress and well-being.

Second, our two methods for reporting results—the difference-in-change graphs and the meta-analyses—provide different summaries of the studies included, each of which has strengths and weaknesses. Strengths of the difference-in-change approach include that it controls for baseline difference between groups and yields a change score on the outcome of interest that has the potential for determining clinical meaningfulness. Weaknesses of this approach include the absence of standards for determining clinical meaningfulness for most measures included in the meditation trials. Strengths of the meta-analysis include the empirical approach to summarizing and evaluating the magnitude and quality of the evidence. Weaknesses include the omission of some key papers due to the lack of outcome data available, and lack of adjustment for baseline differences.

And third, we selected an arbitrary cut-off of ±5 percent as the criteria for a difference in change over time indicating improvement of one group over another. This is a small difference for most measures of psychological stress and well-being and may be regarded by some readers as too liberal, especially if the outcome is clinically relevant (e.g., depression in people seeking care for depression). Since the findings reported in these papers generally do not report clinically meaningful outcomes (e.g., reduction in study participants meeting cut-offs for clinical syndromes), we selected a low threshold that could be universally applied to the heterogeneous group of measures included in these studies.

## Key Question 1 What are the efficacy and harms of meditation programs on negative affect (e.g., anxiety, stress) and positive affect (e.g., well-being) among those with a clinical condition (medical or psychiatric)?

We found 32 trials for this KQ, including four evaluating TM, two evaluating other mantra meditation, and 26 evaluating mindfulness meditation. In general, we found no evidence that mantra meditation programs improve psychological stress and well-being. Mindfulness meditation programs improved multiple dimensions of negative affect, including anxiety, depression, and perceived stress/general distress, and the mental-health component of quality of life with a low to moderate strength of evidence when compared to a nonspecific active control. Well-being and positive mood are positive dimensions of mental health. While meditation programs generally seek to improve the positive dimensions of health, the available evidence from a very small number of studies did not show any effects on positive affect or well-being. Both analytic methods, the difference-in-change estimates (which accounted for baseline differences between groups) and the meta-analyses (which only compared end-line differences), generally showed consistent but small effects for anxiety, depression, and stress/distress. However, there are a number of observations that help interpret and give context to our conclusions.

The first observation is that there were very few mantra meditation programs included in our review. This significantly limited our ability to draw inferences about the effects of mantra meditation programs on psychological stress-related outcomes. Of the four TM trials, three were well-designed trials with low risk of bias that studied cardiac patients, while one had a high risk of bias and studied anxiety patients. Among the other mantra trials, both had a medium risk of bias. Based on the available evidence from these trials, we found no evidence that mantra meditation programs have an effect on psychological stress and well-being as compared to a nonspecific active control. These conclusions did not change when we evaluated TM separately from other mantra. Apart from the paucity of trials, another reason for seeing null results may also be due to the type of populations studied (e.g. 3 TM trials enrolled cardiac patients, while only 1 enrolled anxiety patients), and whether these study participants had high levels of a particular negative affect to begin with.

The second observation is that among mindfulness trials, the effects were significant for anxiety and marginally significant for depression at the end of treatment, and these effects continued to be significant at 3–6 months for both anxiety and depression. We did not conduct a meta-analysis of stress/distress at 8 weeks due to a concern for bias, and we did not have enough data to conduct a longer-term meta-analysis for stress/distress. The difference-in-change graphs for the trials comparing mindfulness meditation to nonspecific active controls show a relatively consistent improvement in stress/distress, which is consistent with a prior review by Chiesa et al., comparing MBSR to inactive controls.16

Third, when we combined each outcome that was a sub domain of negative affect (anxiety, depression, and stress/distress), we see a small and consistent signal that any domain of negative affect is improved in mindfulness programs when compared with a nonspecific active control. Since we could only include one outcome from any single trial, we prioritized anxiety over depression and depression over stress/distress for this analysis. When we conducted a sensitivity analysis reversing the prioritization of outcomes, we continued to find the same result.

Fourth, the effect sizes are small. However, they are fairly comparable with what would be expected from the use of an antidepressant in a primary care population. In a study using patient-level meta-analysis, Fournier et al. found that for patients with mild to moderate depressive symptoms, antidepressants had an effect size of 0.11 (−0.18, +0.41), while those with severe depression had an effect size of 0.17 (−0.08, +0.43) compared with placebo.92 Over the course of 2–6 months, we find that mindfulness meditation program effect size estimates range from 0.22–0.40 for anxiety symptoms and 0.23–0.32 for depressive symptoms, and were statistically significant.

The fifth observation is that although there may be differences between trials for which these outcomes are a primary versus secondary focus, we did not find any evidence for this. While we did not conduct separate meta-analyses for primary versus secondary trials due to the small number of each, our analysis of the difference-in-change estimates did not suggest any difference. Some trials, in which an outcome was a primary focus, did not recruit based on high symptom levels of that outcome. Thus, the samples included in these trials more closely resemble a general primary care population, and there may not be room to measure an effect if symptom levels were low to start with (i.e. a “floor” effect).

Sixth, all of the findings favoring an improvement in outcomes among the mindfulness groups as compared to control were found only when the comparisons were made against a nonspecific active control. In each comparison that was made against a known treatment or therapy, mindfulness did not show superiority for any outcome. This was true for all comparisons among any form of meditation for any KQ. Out of 53 comparisons with a specific active control, we found only 2 that showed a statistically significant improvement: MBCT improved quality of life in comparison to antidepressant drug among depressed patientsand mindfulness therapy reduced cigarette consumption in comparison to the Freedom from Smoking program.50 However, we also found five comparisons where the specific active control performed better, with statistically significant results, than the meditation programs. The comparisons with specific therapies led to highly inconsistent results for most outcomes (Figure 4b), and indicated that meditative therapies were no better than the specific therapies they were being compared to. These include such therapies as exercise, yoga, progressive muscle relaxation, cognitive behavioral therapy, and medications.

Seventh, some of our findings are inconsistent with previous reviews. For example, based on three trials we found no evidence that mindfulness-based cognitive therapy (MBCT) improves anxiety.67,68,86 Previous reviews have concluded that MBCT is an effective intervention for anxiety or could provide some improvement in residual anxiety symptoms in some populations.18,19 A strength of our methodology is the comparison of MBCT with nonspecific active controls, which suggests that the conclusions of earlier reviews may be due to nonspecific effects of treatment (e.g. time, attention, expectations for improvement) rather than effects specifically attributable to MBCT.

Finally, by delineating nonspecific and specific active controls, we hoped to derive some information about the comparative effectiveness of meditation programs. The heterogeneity of specific active treatments that these studies investigated makes it impossible to draw conclusions about inferiority or superiority of meditation programs. The studies in depression are notable, though, in examining the effects of MBCT during discontinuation of an antidepressant.59,71 These two trials used a clinically important outcome of relapse rate among a depression population, compared MBCT with tapering of antidepressant medication to maintenance antidepressant medication, and found consistent absolute 8–13 percent reductions in relapse rates.59,71 Both trials were rated as having low risk of bias. These findings warrant further investigation, and are generally consistent with prior reviews.15,18,23

## Key Question 2 What are the efficacy and harms of meditation programs on attention among those with a clinical condition (medical or psychiatric)?

One RCT compared a meditation program to active control on the outcome of attention. There were no statistically significant differences between groups on the attentional network test. There were trends suggesting that the meditation program performed better than the nonspecific active control on this measure, although this did not reach statistical significance.

Of note, three previous reviews assessed the role of meditation programs on attention. A Cochrane review by Krisanaprakornkit et al.,93 on meditation therapies for attention-deficit/hyperactivity disorder that included two mantra meditation trials, could not make any conclusions regarding the effectiveness of meditation programs for attention-deficit/hyperactivity disorder due to high risk of bias and small sample sizes. That review is not directly comparable to the current review, as the trial population is different (the previous review included children with attention-deficit/hyperactivity disorder) and each used different measures of attention. In addition, the previous review included four RCTs, two of which focused on yoga as the primary intervention, which was not included in the current review. Two additional systematic reviews assessed the effect of TM (Canter et al, 2003)30 and mindfulness meditation programs (Chiesa 2010) on cognitive functioning, including the domain of attention. While the review by Canter et al. (2003) did not specify results pertaining to attention, the authors concluded that evidence does not support that TM has “a specific and cumulative effect on cognitive function.” The review by Chiesa included 23 trials but only six RCTs, with the majority of the RCTs (4 of 6) conducted in healthy populations. Of note, the two trials on clinical populations did not include active controls and were, therefore, not included in the present review. The authors preliminarily concluded that mindfulness meditation programs were associated with improvements in attention, although the authors noted that limitations and variability in the trials requires further assessment. In conjunction with the current review, these findings further reiterate the need for more comprehensive trials with a variety of clinical populations (e.g., disorders where attention may be compromised) to provide a clearer understanding of the impact of meditation programs on attention.

## Key Question 3 What are the efficacy and harms of meditation programs on health-related behaviors affected by stress, specifically substance use, sleep, and eating, among those with a clinical condition (medical or psychiatric)?

We included 13 trials for this KQ, four evaluating the effect of meditation on substance use,49,50,80,84 two evaluating eating,56,62 and seven evaluating sleep.54,55,61,66,70,73,85 Overall, there is insufficient evidence to indicate that meditation programs alter health-related behaviors affected by stress.

Among the four trials evaluating substance use, all four were conducted in substance-using populations. Taken together, the trials of mindfulness and mantra meditation failed to provide sufficient evidence of benefit in reducing use of cigarettes or alcohol. Both trials of mindfulness failed to show an effect on reducing calorie consumption on breast cancer patients or diabetics.56,62 Among the seven trials in which sleep was an outcome, only one used an insomnia population,55 but failed to provide evidence of an effect on sleep time or quality. Four other trials, which assessed sleep as a secondary outcome among various clinical populations, had inconsistent results on sleep quality. However, results were significant for one trial in which sleep was a primary outcome.54

Our findings are consistent with past systematic reviews in this area, which have found insufficient evidence for the effects of meditation programs on health-related behaviors affected by stress among controlled studies. Zgierska et al. conducted a systematic review that included trials of a mindfulness-based intervention in patients with substance abuse.26 It found no significant effect. Regarding eating disorders, Wanden (2011) conducted a systematic review that included articles considering mindfulness therapy as a treatment for eating disorders.24 The authors stated that they found evidence of the effectiveness of mindfulness-based interventions for eating disorders. However, this review consisted of largely uncontrolled studies with an N of 1. The literature in this area is still in a preliminary state with regards to quality.

Winbush et al. evaluated seven trials on sleep, four of them uncontrolled, and concluded that the uncontrolled trials found an effect on sleep disturbance while the controlled trials did not find an effect.25 This is also in line with the findings of this review.

## Key Question 4 What are the efficacy and harms of meditation programs on pain and weight among those with a clinical condition (medical or psychiatric)?

We included 14 RCTs for this KQ. We found moderate strength of evidence that mindfulness-based stress reduction (MBSR) reduces pain severity to a small degree when compared with a nonspecific active control. We also found low strength of evidence that when MBSR was compared with various specific active controls including massage, MBSR was not superior in reducing pain severity. One TM trial did not find any improvement in pain severity, but was conducted in 23 patients with congestive heart failure and pain was a secondary outcome.

Among the trials evaluating pain, most evaluated musculoskeletal pain. Based on one study with large significant findings, there is a suggestion that MBSR may be useful for visceral pain. Gaylord et al. evaluated 75 women with irritable bowel syndrome and found a statistically significant 30 percent reduction in abdominal pain severity at 2 months that maintained at six months. Previous systematic reviews by Veehof et al. of trials for pain concluded an effect size of .37 for pain for MBSR and acceptance and commitment therapy, suggesting they were alternatives to cognitive behavior therapy.94 A review by Bernardy et al. combined MBSR with a number of cognitive behavior therapy used on fibromyalgia patients and found that this group of interventions had no significant effects on pain among fibromyalgia patients.27 Both included control and uncontrolled trials.

Two mindfulness trials evaluated weight as an outcome, and it was a primary outcome for both. Three TM trials evaluated weight as a secondary outcome. Due to consistently null results, there was low strength of evidence to suggest that TM or MBSR do not have an effect on weight.

## Harm Outcomes for All Key Questions

Few trials reported on potential harms of meditation programs. Of the nine trials that reported on harms, none reported any harms of the intervention. One trial specified that they looked for toxicities of meditation to hematologic, renal, and liver markers and found none. The remaining eight trials did not specify the type of adverse event they were looking for. Seven reported that they found no significant adverse events, while one did not comment on adverse events. The remaining 32 trials did not report whether they monitored for adverse events.

## Limitations of the Primary Studies

Although we collected information on amount of training provided in the meditation programs, the trials did not provide enough information to make use of that data. The studies generally did not provide enough information to allow us to draw any conclusions about how the effects of the interventions differed among subpopulations, such as racial-ethnic groups, elderly patients, or patients with specific medical or psychiatric conditions. The limited number of trials using various comparators among diverse populations also made using the available information on “dose” of meditation difficult. In addition, we could not rule out selective outcomes reporting and publication bias.

It may be that specific scales may be more relevant for a particular form of meditation. Many of the studies only assessed certain measures and the scales may have been limited in their ability to detect an effect. For example, there was only one measure of attention, and it's possible that this was not a sensitive measure for the populations assessed.

We intended to evaluate the effects of meditation programs on a broad range of medical and psychiatric conditions since psychological stress outcomes are not limited to any particular medical or psychiatric condition. Despite our focus on a subset of meditation programs tested in active controlled RCTs, we were unable to detect a specific effect of meditation on many outcomes, with the majority of our evidence grades being insufficient or low. This was mostly driven by two important evaluation criteria: the risk of bias and the inconsistencies in the body of evidence. The specific reasons for such inconsistencies may have included the differences in the particular clinical conditions, as well as the type of control groups used. When a study compared a meditation program to a specific active control, we could not easily compare these trials with those that used a nonspecific active control. We therefore separated these comparisons to be able to evaluate the effects against a relatively homogenous nonspecific active control group. Comparing trials that used one specific active control to another specific active control led to large inconsistencies that could be explained by differences in the control groups (Figures 26, 28–30, 32, 34–35, 38). The variations in sensitivities of scales that trials used to detect changes from the intervention, and the paucity of trials within each outcome domain, may have also contributed to the inconsistent findings. Another possibility is that there is no real effect of the programs on many of the outcomes that had inconsistent findings. While some of the outcomes were primary outcomes, many were secondary outcomes and the studies may not have been appropriately powered to detect changes in secondary outcomes.

## Limitations of the Review

An important decision in setting up this review was the choice to examine only studies that randomized participants to a meditation program or an active control. We chose not to include observational studies or trials with nonactive controls because previews reviews have already examined these types of studies, this methodology increases risk of bias, and leaves questions regarding the specific effects of meditation on clinical outcomes. Observational studies have a particularly high risk of bias in this area of research because of problems such as self-selection of interventions (people are more likely to enroll in a meditation program if they believe in its benefits or have prior experience with meditation) and the use of largely self-reported outcome measures that can be easily biased by participants' beliefs in the benefits of meditation. In making this decision, we restricted our ability to examine longer-term outcomes, including potential harms of meditation. This is an intriguing issue in the literature, as various experts believe that the benefits of meditation increase with practice and may require years for meaningful, clinically relevant changes to occur. Also, because some meditation programs require behavior change and skill development, it is very likely that participants in observational studies are self-selected for personal characteristics that may not generalize to the larger population. This type of longitudinal observational study could be informative once the specific clinical efficacy of an intervention is established. Since the clinical efficacy of meditation programs remains in question, the validity of longitudinal observational studies remains limited.

We generally rated all self-reported outcomes as being direct except for measures of craving or sub measures of negative or positive affect. Some may consider the measures we rated as direct to be indirect, which would further lower the strength of evidence for such ratings. Our assessment of the risk of bias of these trials needs to be interpreted in the light of unique risk-of-bias issues for non-pharmacologic interventions where blinding of intervention is not possible. Thus, using blinded outcome assessors, even for self-report instruments, is one method that reduces risk of bias.

We did not rate the strength of evidence on publication bias. Our review of clinicaltrials.gov registration database did not provide sufficient information on the scales these trials used to measure outcomes, or on the types of controls they used. This did not allow us to verify whether a potentially applicable outcome could have been included in our review.

Stress outcomes encompass both psychological and biological markers, yet we focused only on the psychological markers. This may disappoint some readers and may have reduced the number of TM trials we included, since many recent trials have been more focused on physiologic markers of stress. However, we included studies with measures of psychological stress and well-being, even as secondary outcomes, and these contribute to the overall strength of our review. An interesting challenge for future work is raised by the findings of one particularly strong TM study. Paul-Labrador and colleagues81 compared TM to a health education control condition in patients with congestive heart failure and found reductions in adjusted systolic blood pressure, heart rate variability, and insulin resistance in the absence of concurrent changes in anxiety, depression, or stress. Given the absence of changes in measures of psychological stress in this study, these authors postulate that meditation may alter the biologic stress response independently of psychological stress responses, a hypothesis that will need to be directly tested in future research.

In addition to limiting our focus to psychological stress and well-being outcomes, we also limited the types of meditation included. We chose not to include other eastern meditative traditions such as qi gong and yoga. These forms typically involve movement and published reports often do not clearly indicate whether the form practiced was purely or mostly meditative. In our initial review of papers for inclusion, we were unable to accurately identify qi gong trials that emphasized movement from those that did not. We also did not include studies in healthy populations.

We selected 5 percent difference in the outcome change scores as being potentially clinically significant and this decision needs to be interpreted in the context of heterogeneous scales reporting on various measures. The literature does not clearly define the appropriate threshold for what is clinically significant on most of these scales. There is variability across measures, and even for those measures that have clinical cut-offs (e.g., many measures of depression), studies rarely reported the change in proportion of study participants meeting these cut-offs following participation in the meditation programs. Some may consider a higher threshold as being clinically relevant. Another limitation is that our method of displaying the relative difference between groups in the change scores from different measurement scales did not take into consideration how the scales varied in the range of scores that were possible. However, we thought this simple method of displaying the data would make it easier for readers to understand the original data. Whenever possible, we also displayed the results using a meta-analysis of standardized mean differences that did account for differences between the measurement scales.

The personal characteristics of individuals (e.g. personality, spirituality, education, etc.) may influence their understanding and skill or abilities in performing meditation. Although trials appeared to recruit individuals with diverse conditions, we are unable to comment on whether individual characteristics of participants influence outcomes. For example, the studies generally did not provide enough information for us to determine whether the effectiveness of mindfulness meditation varied by race, ethnicity, or education.

While this review sought to assess the effectiveness of meditation programs above and beyond the nonspecific effects of time and attention, it did not assess the impact of the preferences of patients. Even though one therapy may not be better than another but is better than doing nothing, many patients may still prefer a particular therapy for personal or philosophical reasons. Further, by reviewing only trials with active controls, we rule out the possibility of an intervention which cultivates high expectations to have a useful effect, particularly when it comes with few to no harms and fits within a person's philosophical mindset.

## Future Directions

Further research in meditation would benefit by addressing several methodological and conceptual issues.

First, all forms of meditation, including both mindfulness and mantra, imply that more time spent meditating will yield larger effects, especially in changing health outcomes including psychological stress and well being. Most forms, but not all, also present meditation as a skill in which skill development occurs over time and is most efficiently achieved by learning from an expert. Thus, more training with an expert and practice in daily life should lead to greater competency in the skill or practice, and greater competency or practice would presumably lead to better outcomes. When compared with other skills that require training, the amount of training in the trials we reviewed was quite small and generally offered over a fairly short period of time. Some of this is due to the challenging logistics of conducting RCTs, and some of this is due to the meditation programs tested (e.g., MBSR is a standardized 8-week program). There was little delineation on exactly what skill novice practitioners are acquiring, or measurement or validation that the skill was being practiced and applied. Given that meditation in its historical forms has been a long-term practice, consideration should be given to placing a greater emphasis on developing the skill. To facilitate this, we need better measurement tools. The currently available mindfulness scales have not been well validated and do not appear to distinguish different forms of meditation.4 Thus, further work on the operationalization and measurement of mindfulness or the particular meditative skill is needed. For those meditation programs that do not believe they are training students in a skill, such as TM and certain mindfulness programs, there is still a need to be able to transparently assess whether a student has attained the mental state or is correctly executing the recommended mental activities (or absence of activities).

Second, trials need to document the amount of training clinicians provide and patients receive, as well as document the amount of home practice patients complete. This gives an indication of how effective the program is at delivering training, how adherent participants were with accepting the intervention, and, in turn, the likelihood these skills will actually be learned and developed by participants. With this type of data, analyses of “dosing” can address the question that remains unclear: how much is enough to accomplish each outcome of interest? As the literature develops and these dosing issues are addressed, RCTs may be indicated to test the effects of dosing on outcome. Amount of training interacts with time to followup and few trials in our review assessed long-term outcomes. One notable exception was the trial by Schneider et al., which followed patients for up to 9 years and assessed effects on mortality.90 Additional high-quality studies with long-term followups are needed to fully examine the effects of “dosing” and the potential impact of meditation on objective indices of health including mortality.

Third, studies should report teacher qualifications in detail. A highly experienced teacher may have a very different effect than an inexperienced teacher, yet the current literature does not provide enough detail to examine this systematically. Given the numerous uncertainties and difficulties around definitions and measurement of skill in meditation programs, quantifying teacher experience and competence adds yet another level of uncertainty. However, the range of experience in meditation and competence as a teacher of this skill or practice likely plays a role in outcomes.

Fourth, the use of nonspecific active control allows one to infer on the effect of meditation when they are matched for time, attention, and expectancy. When using a specific active control, if one finds no statistically significant superiority over the control one is left with the issue of whether the meditation is equivalent to or not inferior to the control, or whether the trial was just underpowered to detect any difference. Conducting comparative effectiveness trials requires prior specification of the hypothesis (superiority, equivalence, non-inferiority), appropriate determination of the margins of clinical significance, and minimum importance difference.95 In the case of equivalence and noninferiority trials, trials also need to have appropriate assay sensitivity. None of the trials showed statistically significant effects against a specific active control, nor did they appear adequately powered to assess noninferiority or equivalence. This leaves a lot of uncertainty in such trial designs.

Fifth, positive outcomes are a key focus of meditative practices. However, positive outcomes were not included as primary or even secondary outcomes for most trials. The few exceptions that we reviewed included measures of positive affect, sense of coherence, and vitality. Future studies should expand upon these domains. There are other domains such as self-efficacy, which we did not review, that may also be important outcomes.

Sixth, we were unable to review biologic markers of stress comprehensively for meditation programs, nor were we able to evaluate the effects of meditation programs that involve more movement such as yoga and qi gong, nor did we review the effects on healthy populations. Numerous trials have been conducted in these areas, and meditation research may benefit from a comprehensive review covering these areas. Such reviews would allow for a cross validation of psychological and biological outcomes.

Future trials should appropriately report key design characteristics to enable the assessment of risk of bias. Future trials should register the trial on a national register, standardize training by using trainers who meet specified criteria, specify primary and secondary outcomes a priori, power the trial based on the primary outcomes, use CONsolidated Standards of Reporting Trials recommendations for reporting results, and operationalize and measure the practice of meditation by study participants. However, an important part of the process of creating standardized meditation programs, when there is uncertainty around the effect or conceptualization of a particular program, is the innovation and testing of small changes to the existing programs in various contexts. We see this in the mindfulness trials and to a smaller degree in the mantra trials. While this adds a layer of complexity in synthesizing the results of these various programs, we do not intend to hinder the innovation of meditation researchers.

## Conclusions

Our review shows that there is moderate strength of evidence that mindfulness meditation programs are beneficial for reducing pain severity, and there is low to moderate strength of evidence that mindfulness meditation programs may lead to improvement in dimensions of negative affect, including anxiety, depression, and perceived stress/general distress. Otherwise, much of the evidence was insufficient to address the comparisons for most of the questions. There were also too few trials of mantra meditation programs to draw meaningful conclusions. There may be many reasons for this lack of evidence.

First, while we sought to review the highest standards of behavioral RCTs, there was wide variation in risk of bias among these. Of 41 RCTs, we only rated 10 as low risk of bias. However, for studies where there is mostly a medium-to-high risk of bias, one might expect to see more positive results. We did not see this.

Second, many if not most studies appeared to be underpowered to find an effect, as we rated most of the studies as imprecise. While this is critical for the individual study, it may not matter as much for a systematic review where we are also concerned with the directionality of effect among numerous studies, irrespective of their statistical significance.

Third, we attempted to analyze the effect meditation programs have on certain domains of mental, emotional, and physical health that are affected by stress. These domains are heterogeneous and studies often report them on different scales, which make it more complicated to analyze. We found modest consistency in improvement on multiple domains of negative affect for mindfulness programs. However, we did not see an effect on positive affect. Due to the limited number of trials we reported, one should view these conclusions cautiously within the context of the particular population studied, type of meditation program used, and type of comparison used.

Fourth, for many outcomes, there was a dearth of adequate studies to draw detailed conclusions. For example, nearly all of the studies assessing pain focused on musculoskeletal pain populations. None assessed neuropathic pain, and only one assessed a visceral pain. We need further studies that better define what outcome is responsive to a particular meditation program.

Fifth, symptom levels may have been low to start with for many trials, not leaving much room to find a difference from an intervention. However, if one purpose of meditation interventions is to improve symptomatology at non-clinical levels, this issue may not be as relevant.

Sixth, the reasons for a lack of a significant reduction of stress-related health behavior outcomes may have to do with the way the research community conceptualizes meditation programs, the difficulties of acquiring such skills or meditative states, and the limited duration of RCTs. Historically, the general public did not conceptualize meditation as a quick fix toward anything. It was a skill or state one learns and practices over time to increase one's awareness; through this awareness one gains insight and understanding into the various subtleties of their existence. Training the mind in awareness, nonjudgementalness, or in the ability to become completely free of thoughts or other activity, are daunting accomplishments. While some meditators may feel that these are easy tasks to do, they likely overestimate their own skills due to a lack of awareness of the different degrees to which these tasks can be done or ability to objectively measure their own progress. Becoming an expert at simple skills such swimming, reading, or writing (which can be objectively measured by others) take a considerable amount of time, so it only follows that meditation would also take a long period of time to master. However many of the studies included in this review were short term (e.g., 2.5 hours a week for 8 weeks) and the participants likely did not achieve a level of expertise needed to improve outcomes that depend on a mastery of our mental and emotional processes. Trials of short duration and training may be insufficient to develop the meditative skills or states necessary to affect stress related outcomes in substantial ways.