# Evidence Tables

Evidence Table E1 Study characteristics for included studies

Evidence Table E2 Participant characteristics for included studies

Evidence Table E3 Scales for anxiety (KQ1)

Evidence Table E4 Scales for depression (KQ1)

Evidence Table E5 Scales for stress (KQ1)

Evidence Table E6 Scales for attention (KQ2)

Evidence Table E7 Scales for substance abuse (KQ3)

Evidence Table E8 Scales for well-being (KQ1)

Evidence Table E9 Scales for pain (KQ4)

Evidence Table E10 KQ1 outcomes—difference in differences—MBSR for anxiety

Evidence Table E11 KQ1 outcomes—difference in differences—other mindfulness for anxiety

Evidence Table E12 KQ1 outcomes—difference in differences—TM anxiety

Evidence Table E13 KQ1 outcomes—difference in differences—thought emotion suppression for anxiety

Evidence Table E14 KQ1 outcomes—difference in differences—social anxiety

Evidence Table E15 KQ1 outcomes—difference in differences—MBSR for depression

Evidence Table E16 KQ1 outcomes—difference in differences—other meditation for depression

Evidence Table E17 KQ1 outcomes—difference in differences—other meditation for depression

Evidence Table E18 KQ1 outcomes—difference in differences—mantra for depression

Evidence Table E19 KQ1 outcomes—difference in differences—stress

Evidence Table E20 KQ1 outcomes—difference in differences—distress

Evidence Table E21 KQ1 outcomes—difference in differences—QOL/mental health

Evidence Table E22 KQ1 outcomes—difference in differences—well being

Evidence Table E23 KQ1 outcomes—difference in differences—positive mood

Evidence Table E24 KQ3 outcomes—difference in differences—substance use

Evidence Table E25 KQ3 outcomes—difference in differences—eating

Evidence Table E26 KQ3 outcomes—difference in differences—sleeping

Evidence Table E27 KQ4 outcomes—difference in differences—pain severity

Evidence Table E28 KQ4 outcomes—difference in differences—pain interference

Evidence Table E29 KQ4 outcomes—difference in differences—weight

Evidence Table E30 Sponsors and AEs for included studies

Evidence Table E31 Meditation intervention descriptions