# Excluded Studies

Appendix D lists studies that were excluded from this review, categorized by reason for exclusion and alphabetized.

## No Original Data

Biofeedback and meditation have little effect on high blood pressure. AHRQ Research Activities. 1993;(171):4-5.
Yoga may help improve women's sexual function. Harv Womens Health Watch. 2010;17(8):7.
Carefully performed yoga may help with chronic back pain. Mayo Clin Health Lett. 2010;28(5):4.
Daily 12-minute meditation can improve cognition, memory, & attention. Journal of Gerontological Nursing. 2010;36(6):5. [pmid: 20954599].
Retraction. Preliminary study of the effects of Tai Chi and Qigong medical exercise on indicators of metabolic syndrome and glycaemic control in adults with raised blood glucose levels. Br J Sports Med. 2010;44(8):608. [pmid: 20547669].
Ades PA, Wu G. Benefits of tai chi in chronic heart failure: body or mind?. Am J Med. 2004;117(8):611-2. [pmid: 15465511].
Aickin M. Does T'ai Chi Chuan improve health-related quality of life in elderly patients?. [1]. 2007;13(10):1053.
Anon. Influence of mindfulness meditation on assisted reproduction treatment programmes. Human Reproduction (Oxford, England). suppl 1. 2003;18:207-8.
Anon. Meditation-based treatment for binge-eating disorder. Http://Www.Clinicaltrials.Gov. 2003.
Anon. Meditation or education for Alzheimer caregivers or meditation for Alzheimer caregivers. Http://Www.Clinicaltrials.Gov. 2007.
Anon. Mindfulness meditation as a rehabilitation strategy for persons with schizophrenia. Http://Wwwclinicaltrialsgov. 2009.
Arana D. The practice of mindfulness meditation to alleviate the symptoms of chronic shyness and social anxiety. Dissertation Abstracts International. 2006;67(5-B):2822.
Arcari P. Efficacy of a workplace smoking cessation program: mindfulness meditation vs cognitive-behavioral interventions. Boston College. 1996.
Aron A, Aron EN. The transcendental meditation program's effect on addictive behavior. Addict Behav. 1980;5(1):3-12. [pmid: 6994433].
Asare F, Simren M. Mindfulness-based stress reduction in patients with irritable bowel syndrome. Aliment Pharmacol Ther. 2011;34(5):578-9. author reply 579-80. [pmid: 21806641].
Asberg M, Skold C, Wahlberg K, Nygren A. Mindfulness meditation--an old fashion method for stress relief. Lakartidningen. 2006;103(42):3174-7. [pmid: 17111986].
Barnes VA. Reduced cardiovascular and all-cause mortality in older African Americans practicing the Transcendental Meditation. [dissertation]. Dissertation Abstracts International. 1997;57(8-B).
Barrows K. The application of mindfulness to HIV. Focus. 2006;21(8):1-5. [pmid: 17096484].
Battle CL, Uebelacker LA, Howard M, Castaneda M. Prenatal yoga and depression during pregnancy. Birth. 2010;37(4):353-4. [pmid: 21083731].
Bauer-Wu S. Mindfulness meditation. Oncology (Williston Park). 2010;24(10 Suppl):36-40. [pmid: 21275324].
Benson H, Malvea BP, Graham JR. Physiologic correlates of meditation and their clinical effects in headache: an ongoing investigation. Headache. 1973;13(1):23-4. [pmid: 4696143].
Bijlani RL. Influence of yoga on brain and behaviour: facts and speculations. Indian J Physiol Pharmacol. 2004;48(1):1-5. [pmid: 15270365].
Blomberg M. Training for improved body awareness and relaxation for stress management. Lakartidningen. 2004;101(15-16):1398-400. [pmid: 15146668].
Boudette R. Integrating mindfulness into the therapy hour. Eat Disord. 2011;19(1):108-15. [pmid: 21181583].
Bower JE. Management of cancer-related fatigue. Clin Adv Hematol Oncol. 2006;4(11):828-9. [pmid: 17143252].
Bowman K. Commentary on “Loving-kindness meditation for chronic low back pain”. J Holist Nurs. 2005;23(3):305-9. [pmid: 16049119].
Brown KD, Koziol JA, Lotz M. A yoga-based exercise program to reduce the risk of falls in seniors: a pilot and feasibility study. J Altern Complement Med. 2008;14(5):454-7. [pmid: 18564950].
Buhle J, Wager TD. Does meditation training lead to enduring changes in the anticipation and experience of pain?. Pain. 2010;150(3):382-3. [pmid: 20546996].
Butler LD, Spiegel D. Meditation and hypnosis for chronic depressed mood. Controlled-Trials.Com. 2006.
Campbell C. Re: The effectiveness of yoga for the improvement of well-being and resilience to stress in the workplace. Scand J Work Environ Health. 2011;37(1):80. [pmid: 20499040].
Campbell RJ, Brantley J. Being mindful of change: a technique to reduce stress amid change. J AHIMA. 2011;82(8):36-9. [pmid: 21877646].
Canter P, Jayadevappa R. Is transcendental meditation effective in congestive heart failure?. Focus on Alternative & Complementary Therapies. 2007;12(3):199-201.
Carlisle TW. Effects of the transcendental meditation program on Psychological, health, social, and behavioral indicators of stress reduction and Human Resource development in the indian workplace. Dissertation Abstracts International. 2005;65(12-A):4629.
Cashman K, Halpern M. Transcendental meditation and individual development. NLN Publ. 1977;(16-1674):70-6. [pmid: 329224].
Chalmers R. Transcendental meditation does not predispose to epilepsy. Med Hypotheses. 2005;65(3):624-5. [pmid: 15913905].
Chang J, Chiung W. Effect of meditation on music performance anxiety. Dissertation Abstracts International. 2001;62(5-A):1765.
Chen HL, Liu K, You QS. Attention should be paid to preventing knee injury in tai chi exercise. Inj Prev. 2011;17(4):286-7. [pmid: 21788230].
Cheng TO. Tai Chi for chronic heart failure. Int J Cardiol. 2006;110(1):96. [pmid: 16723290].
Cheng TO. Tai Chi: the Chinese ancient wisdom of an ideal exercise for cardiac patients. Int J Cardiol. 2007;117(3):293-5. [pmid: 16904211].
Chiesa A, Brambilla P, Serretti A. Neuro-imaging of mindfulness meditations: implications for clinical practice. Epidemiol Psychiatr Sci. 2011;20(2):205-10. [pmid: 21714367].
Danusantoso H, Heijnen L. Tai Chi Chuan for people with haemophilia. Haemophilia. 2001;7(4):437-9. [pmid: 11442652].
Delmonte MM. Physiological concomitants of meditation practice. Int J Psychosom. 1984;31(4):23-36. [pmid: 6397456].
Dillbeck MC. The application of the transcendental meditation program to corrections. International Journal of Comparative and Applied Criminal Justice. 1987;1(11):111-32.
Dosh SA. The treatment of adults with essential hypertension. J. Fam. Pract. 2002;51(1):74-80. [pmid: 11927069].
Eliopoulos C. Integrative care--health benefits of Tai Chi. Director. 2001;9(4):138-9. [pmid: 15307370].
Eliopoulos C. Integrative care--take a deep breath and stretch … benefits of yoga in LTC. Director. 2004;12(2):114-5. [pmid: 15106372].
Epstein-Lubow GP, Miller IW, McBee L. Mindfulness training for caregivers. Psychiatr Serv. 2006;57(3):421. [pmid: 16525012].
Evans AT, Hadler NM. Yoga improved function and reduced symptoms of chronic low-back pain more than a self-care book. ACP J Club. 2006;145(1):16. [pmid: 16813364].
Evans S, Cousins L, Tsao JC, Sternlieb B, Zeltzer LK. Protocol for a randomized controlled study of Iyengar yoga for youth with irritable bowel syndrome. Trials. 2011;12:15. [pmid: 21244698].
Evans S, Cousins L, Tsao JC, Subramanian S, Sternlieb B, Zeltzer LK. A randomized controlled trial examining Iyengar yoga for young adults with rheumatoid arthritis: a study protocol. Trials. 2011;12:19. [pmid: 21255431].
Fehr TG. Transcendental meditation may prevent partial epilepsy. Med Hypotheses. 2006;67(6):1462-3. [pmid: 16890382].
Freret N, Ricci L, Murphy S. Recruiting and screening older, transitional to frail adults in congregate living facilities. Appl Nurs Res. 2003;16(2):118-25. [pmid: 12764723].
Garcia-Trujillo Mr, De Rivera Jlg. Physiological Changes Induced By Meditation And Deep Relaxation. Cambios Fisiologicos Durante Los Ejercicios De Meditacion Y Relajacion Profunda. 1992;13(6-7):57-63.
Garland SN, Carlson LE, Antle MC, Samuels C, Campbell T. I-CAN SLEEP: rationale and design of a non-inferiority RCT of Mindfulness-based Stress Reduction and Cognitive Behavioral Therapy for the treatment of Insomnia in CANcer survivors. Contemp Clin Trials. 2011;32(5):747-54. [pmid: 21658476].
Gokal R, Shillito L, Maharaj SR. Positive impact of yoga and pranayam on obesity, hypertension, blood sugar, and cholesterol: a pilot assessment. J Altern Complement Med. 2007;13(10):1056-7. [pmid: 18166115].
Gorczynski P, Faulkner G. Exercise therapy for schizophrenia (Brief record). Schizophrenia Bulletin. 2010;36(4):665-6. [pmid: 20484521].
Grandinetti NS, Schneider R, Chang H, Ricketts L, Toomey M. The transcendental meditation program and cardiovascular disease in native Hawaiins. Journal of Psychosomatic Research. 2003;55:144.
Grant JA, Rainville P. Hypnosis and meditation: similar experiential changes and shared brain mechanisms. Med Hypotheses. 2005;65(3):625-6. [pmid: 15982830].
Graves N, Krepcho M, Mayo HG, Hill J. Clinical inquiries. Does yoga speed healing for patients with low back pain?. J Fam Pract. 2004;53(8):661-2. [pmid: 15298844].
Greenfield RH. Blowing off steam: Mindfulness and COPD. 2010;13(3):34-6.
Greenfield RH. “Qigong show”-MQ for cancer patients. 2010;13(1):11-2.
Hankey A, McCrum S. Qigong: life energy and a new science of life. J Altern Complement Med. 2006;12(9):841-2. [pmid: 17109573].
Heidenreich T, Tuin I, Pflug B, Michal M, Michalak J. Mindfulness-based cognitive therapy for persistent insomnia: A pilot study. [2]. 2006;75(3):188-9.
Immink M. A yoga and meditation program to improve physical function, mood and quality of life in individuals with chronic stroke hemiparesis. Australian New Zealand Clinical Trials Registry (ANZCTR). Http://Www.Anzctr.Org.Au/. 2009.
Jackson C. Pilates and yoga: holistic practices that are perfect together. Holist Nurs Pract. 2011;25(5):225-30. [pmid: 21832925].
Jaseja H. A brief study of a possible relation of epilepsy association with meditation. Med Hypotheses. 2006;66(5):1036-7. [pmid: 16442747].
Jaseja H. Meditation and epilepsy: the ongoing debate. Med Hypotheses. 2007;68(4):916-7. [pmid: 17045412].
Kamiya K. Keratectasia, Rubbing, Yoga, Weightlifting Intraocular Pressure. Cornea. 2010.
Kemp CA. Qigong as a therapeutic intervention with older adults (Provisional abstract). Journal of Holistic Nursing. 2004;22(4):351-73. [pmid: 15486154].
Kepner J. Yoga research and Richard Freeman. Altern Ther Health Med. 2004;10(4):14. [pmid: 15285269].
Khianman B, Pattanittum P, Thinkhamrop J, Lumbiganon P. Relaxation therapy for preventing and treating preterm labour. 2008;(4).
Krishnamurthy M, Telles S. Effects of Yoga and an Ayurveda preparation on gait, balance and mobility in older persons. Med Sci Monit. 2007;13(12):LE19-20. [pmid: 18049442].
Kugler JE. Meditation and the electroencephalogram. Electroencephalogr Clin Neurophysiol Suppl. 1982;(35):391-8. [pmid: 6749481].
Liem T. Osteopathy and Hatha Yoga. Osteopathie und (Hatha-)Yoga. 2009;10(1):21-7.
Lin MR, Hwang HF, Wang YW, Chang SH, Wolf SL. Community-based tai chi and its effect on injurious falls, balance, gait, and fear of falling in older people. Phys Ther. 2006;86(9):1189-201. [pmid: 16959668].
Maki PM. New data on mindfulness-based stress reduction for hot flashes: how do alternative therapies compare with selective serotonin reuptake inhibitors?. Menopause. 2011;18(6):596-8. [pmid: 21701435].
Manikonda P, Stoerk S, Toegel S, et al. Influence of non-pharmacological treatment (contemplative meditation and breathing technique) on stress induced hypertension - A randomized controlled study. American Journal of Hypertension. 2005;18(5):89A-90A.
Manocha R. Sahaja yoga in asthma. [2]. 2003;58(9):825-6.
Mansky P, Sannes T, Wallerstedt D, et al. Tai chi chuan: mind-body practice or exercise intervention? Studying the benefit for cancer survivors (Structured abstract). Integrative Cancer Therapies. 2006;5(3):192-201. [pmid: 16880423].
Manyam BV. Diabetes mellitus, Ayurveda, and yoga. J Altern Complement Med. 2004;10(2):223-5. [pmid: 15165400].
Marc I. Integrative approach for tinnitus: Potential for qigong. Focus on Alternative and Complementary Therapies. 2011;(16 1):58.
Mariano C. A 16-week tai chi programme prevented falls in healthy older adults. Evid Based Nurs. 2008;11(2):60. [pmid: 18364430].
Marks I, Dar R. Fear reduction by psychotherapies. Recent findings, future directions. 2000;176(JUN.):507-11.
Martiny PJ. Research on the physiological effects of transcendential meditation: studies show wholesome and good effects in meditators. Forskningen af de fysiologiske virkninger af Transcendental Meditation: forskningen viser sund og god virkning hos de mediterende. 1978;78(17):4-7. 28.
Mathuna D. Tai chi for fall prevention among the elderly. Alternative Therapies in Women's Health. 2005;7(5):33-6.
Matsuda S, Martin D, Yu T. Ancient exercise for modern rehab. Rehab Manag. 2005;18(2):24-7. [pmid: 15786666].
McCown D. Cognitive and perceptual benefits of meditation. 2004;2(4):148-51.
Meares A. A form of intensive meditation associated with the regression of cancer. Am J Clin Hypn. 1982-1983;25(2-3):114-21. [pmid: 6764710].
Miller JB. Yoga, visualisation and affirmation in YogaBirth. Pract Midwife. 2010;13(5):14-5. [pmid: 20481076].
Morse DR, Martin JS, Furst ML, Dubin LL. A physiological and subjective evaluation of neutral and emotionally-charged words for meditation. Part III. J Am Soc Psychosom Dent Med. 1979;26(3):106-12. [pmid: 391786].
Morse DR, Martin JS, Furst ML, Dubin LL. A physiological and subjective evaluation of neutral and emotionally-charged words for meditation. Part II. J Am Soc Psychosom Dent Med. 1979;26(2):56-62. [pmid: 389906].
Murphy L, Riley D, Rodgers J, Plank S, Lehman S, Duryea B. Effects of Tai Chi on balance, mobility, and strength among older persons participating in an osteoporosis prevention and education program. Explore (NY). 2005;1(3):192-3. [pmid: 16781529].
Mustian KM, Katula JA, Roscoe J, Morrow G. The influence of Tai Chi (TC) and support therapy (ST) on fatigue and quality of life (QOL) in women with breast cancer (BC). [abstract]. Annual Meeting Proceedings of the American Society of Clinical Oncology. 2004;760.
NCT00558402. 2007. Meditation or Education for Alzheimer Caregivers Or Meditation for Alzheimer Caregivers: Stress & Physiology. Http://Www.Clinicaltrials.Gov 2007.
Nespor K. The combination of psychiatric treatment and yoga. Int J Psychosom. 1985;32(2):24-7. [pmid: 3894269].
Nichol G, Ding L, Mathias S, Lovell-Smith D, Low W. Transcendental meditation. N Z Med J. 1983;96(742):814. [pmid: 6353299].
Nolfe G. EEG and meditation. Clin Neurophysiol. 2011.
Oh B, Butow P, Mullan B, Clarke SJ, Beale P, Rosenthal D. Randomized clinical trial: The Impact of Medical Qigong (traditional Chinese medicine) on fatique, quality of life, side effects, mood status and inlfammation of cancer patients. [abstarct no. 9565]. Journal of Clinical Oncology: ASCO Annual Meeting Proceedings. 2008;26(15S part I):518.
Orme-Johnson DW. Transcendental meditation does not predispose to epilepsy. Med Hypotheses. 2005;65(1):201-2. [pmid: 15893150].
Osteras N, Fongen C. Tai Chi reduces pain and improves physical function for people with knee OA. J Physiother. 2010;56(1):57. [pmid: 20500138].
Parati G, Steptoe A. Stress reduction and blood pressure control in hypertension: a role for transcendental meditation?. J Hypertens. 2004;22(11):2057-60. [pmid: 15480086].
Pierce S, Rakel D. Is therapeutic yoga helpful for chronic low back pain?. Evidence-Based Practice. 2010;13(8):4.
Porter N. Yoga & Tai Chi: stress management and low impact fitness from the East. Pa Health You. 2002;105(2):6-8. [pmid: 16350773].
Rakel D, Fortney L, Sierpina VS, Kreitzer MJ. Mindfulness in medicine. Explore (NY). 2011;7(2):124-6. [pmid: 21397875].
Rasmussen LB. Transcendental meditation and mild hypertension. Transcendental meditasjon og mild hypertensjon. 1998;118(5):775.
Rediger JD, Summers L. Mindfulness training and meditation for mental health. Adv Mind Body Med. 2007;22(1):16-26. [pmid: 20671339].
Riley D. Hatha yoga and the treatment of illness. Altern Ther Health Med. 2004;10(2):20-1. [pmid: 15055088].
Robertshawe P. Effects of yoga on maternal comfort, labour pain and birth outcomes. Journal of the Australian Traditional-Medicine Society. 2009;15(2):81.
Rogers C, Keller C, Larkey LK. Perceived benefits of meditative movement in older adults (Structured abstract). Geriatric Nursing. 2010;31(1):37-51. [pmid: 20159352].
Rosdahl DRL. The effect of mindfulness meditation on tension headaches and secretory immunoglobulin A in saliva [dissertation]. 2003.
Rosdahl D. The effect of mindfulness meditation on tension headaches and secretory immunoglobulin A in saliva. University of Arizona. 2003.
Roth B. Mindfulness-based stress reduction at the Yale School of Nursing. 2001;74(4):249-58.
Roy DJ. The thistle is a flower? A meditation on seeing the unseen. J Palliat Care. 2011;27(2):67-8. [pmid: 21805940].
Rubenfire M. [Commentary on] Effects of tai chi mind-body movement therapy on functional status and exercise capacity in patients with chronic heart failure: a randomized controlled trial. ACC Current Journal Review. 2005;14(2):35.
Sagula DA. Varying treatment duration in a mindfulness meditation stress reduction program for chronic pain patients [dissertation]. 1999.
Salomons TV, Kucyi A. Does Meditation Reduce Pain through a Unique Neural Mechanism?. J Neurosci. 2011;31(36):12705-7. [pmid: 21900549].
Sarukkai S. Inside/outside: Merleau-ponty/yoga. 2002;52(4):459-78.
Schmidt S. Mindfulness meditation for the treatment of chronic low back pain in older adults: A randomized controlled pilot study - Commentary. Achtsamkeit hilft bei chronischen schmerzen: Kommentar. Forsch. Komplementarmed. 2008;15(2):106-8.
Schneider R, Alexander C, Myers H, et al. Lifestyle modification in the prevention of left ventricular hypertrophy: A randomized controlled trial of stress reduction and health education in hypertensive African Americans. Journal of Hypertension. 2006;24(Suppl. 6):90.
Schneider RH, Alexander CN, Staggers F, et al. Long-term effects of stress reduction on mortality in persons > or = 55 years of age with systemic hypertension. Am J Cardiol. 2005;95(9):1060-4. [pmid: 15842971].
Schneider RH, Cavanaugh KL, Kasture HS, Rothenberg S. Health promotion with a traditional system of natural health care: Maharishi Ayur-Veda. Journal of Social Behavior & Personality. 1990;5(3):1-27.
Sengoku M, Murata H, Kawahara T, Nakagome K. Does daily Naikan therapy maintain the efficacy of intensive Naikan therapy against depression?. Erratum. Psychiatry and Clinical Neurosciences. 2010;64(2).
Shannahoff-Khalsa D. Kundalini yoga meditation techniques for psychiatric disorders. 157th Annual Meeting of the American Psychiatric Association. 2004 May 1-6. New York, NY. 2004.
Steptoe A. New approaches to the management of essential hypertension with psychological techniques. 1978;22(4):339-54.
Stevinson C. Preliminary results suggest that yoga can alleviate depression. Focus on Alternative & Complementary Therapies. 2001;6(1):27-8.
Stevinson C. Inconclusive trial on yoga for anxiety among breast cancer patients: Commentary. Focus Altern. Complement. Ther. 2009;14(2):123-4.
Straus S. A 16-week tai chi programme prevented falls in healthy older adults. Evid Based Med. 2008;13(2):54. [pmid: 18375707].
Tavee J, Stone L. Healing the mind: meditation and multiple sclerosis. Neurology. 2010;75(13):1130-1. [pmid: 20876465].
Teasdale JD. Emotional processing, three modes of mind and the prevention of relapse in depression. Behav Res Ther. Suppl 1. 1999;37:S53-77. [pmid: 10402696].
Teerlink JR. Mind or body: evaluating mind-body therapy efficacy in heart failure trials. Arch Intern Med. 2011;171(8):758-9. [pmid: 21518943].
Telles S, Naveen KV. Changes in middle latency auditory evoked potentials during meditation. Psychol Rep. 2004;94(2):398-400. [pmid: 15154162].
Telles S, Naveen KV. Effect of yoga on somatic indicators of distress in professional computer users. Med Sci Monit. 2006;12(10):LE21-2. [pmid: 17006412].
Telles S, Singh N. High frequency yoga breathing increases energy -expenditure from carbohydrates. Comment to: Assessment of sleep patterns, energy expenditure and circadian rhythms of skin temperature in patients with acute coronary syndrome Hadil Al Otair, Mustafa Al-shamiri, Mohammed Bahobail, Munir M. Sharif, Ahmed S. BaHammam Med Sci Monit, 2011; 17(7): CR397-403. Med Sci Monit. 2011;17(9):LE7-8. [pmid: 21873954].
Theadom A, Cropley M, Hankins M, Smith HE. Mind and body therapy for fibromyalgia. 2009;(4).
Tsai P, Chang JY, Chowdhury N, Beck C, Roberson PK, Rosengren K. Enrolling older adults with cognitive impairment in research: lessons from a study of Tai Chi for osteoarthritis knee pain. Research in Gerontological Nursing. 2009;2(4):228-34. [pmid: 20077977].
Van Eijk-Hustings Y, Boonen A, Landew R. A randomized trial of tai chi for fibromyalgia. [7]. 2010;363(23):2266.
Vanfraechem-Raway R. Fatigue. Relaxation therapy. Arch Belg. 1985;43(11-12):511-7. [pmid: 3914865].
von Durckheim K. The use of meditative practices in psychotherapy. Praxis Der Psychotherapie. 1973;18(2):63-74.
Wang C, Xu D, Qian Y. Medical and health care Qigong (Qu Bing Yang Sheng Gong). J Tradit Chin Med. 1991;11(4):296-301. contd. [pmid: 1795547].
Wang YT. Effects of long term Tai Chi practice and jogging exercise on muscle strength and endurance in older people: Commentary. Br. J. Sports Med. 2006;40(1):54.
Wayne PM, Krebs DE, Wolf SL, et al. Can Tai Chi improve vestibulopathic postural control? (Structured abstract). Archives of Physical Medicine and Rehabilitation. 2004;85(1):142-52. [pmid: 14970982].
Wayne P, McGibbon C, Scarborough D, et al. Tai chi improves dynamic postural stability in patients with vestibular disease: results of a randomized trial. Journal of Alternative & Complementary Medicine. 2006;12(2):214.
Whitebird RR, Kreitzer MJ, O'Connor PJ. Mindfulness-Based Stress Reduction and Diabetes. Diabetes Spectr. 2009;22(4):226-30. [pmid: 20657669].
Williams A, Selwyn P, McCorkle R, Molde S, Liberti L, Katz D. Application of community-based participatory research methods to a study of complementary medicine interventions at end of life. Complementary Health Practice Review. 2005;10(2):91-104.
Wolf DB. Effects of the hare krsna maha mantra on stress, depression, and the three gunas. (spirituality, yoga). [dissertation]. Dissertation Abstracts International. 2000;60(7-B).
Yalta K, Sivri N, Yetkin E. Sahaja yoga: A unique adjunctive approach for the management of cardiac arrhythmias?. Int J Cardiol. 2011;152(1):99-100. [pmid: 21807424].
Yount G, Solfvin J, Moore D, et al. In vitro test of external Qigong. BMC Complement Altern Med. 2004;4:5. [pmid: 15102336].
Zeeuwe PEM, Verhagen AP, Bierma-Zeinstra SMA, Van Rossum E, Faber MJ, Koes BW. The effect of Tai Chi Chuan in reducing falls among elderly people: Design of a randomized clinical trial in the Netherlands [ISRCTN98840266]. 2006;6.
Zhang F, Wu Y. A randomized trial of tai chi for fibromyalgia. [6]. 2010;363(23):2265-6.
Zhou M, Zhou D, He L. A randomized trial of tai chi for fibromyalgia. [5]. 2010;363(23):2265.
Zwick D. Integrating Iyengar yoga into rehab for spinal cord injury. Nursing. Suppl P T. 2006;36:18-22. [pmid: 17038855].

## Meeting Abstracts

Biofeedback and meditation have little effect on high blood pressure. AHRQ Research Activities. 1993;(171):4-5.
Abstracts: archives journals. JAMA: Journal of the American Medical Association. 2006;296(6):633-5.
Anderson VL. The effects of meditation on teacher perceived occupational stress and trait anxiety. Dissertation Abstracts International. 1996;57(3-A):934.
Anon. The effects of meditation on selected measures of human potential. Dissertation Abstracts International. 1982;42(11-A):4717.
Anthony W Jr. An evaluation of meditation as a stress reduction technique for persons with spinal cord injury. Dissertation Abstracts International. 1986;46(11):3251.
Arana D. The practice of mindfulness meditation to alleviate the symptoms of chronic shyness and social anxiety. Dissertation Abstracts International. 2006;67(5-B):2822.
Brach AW. Clinical applications of meditation: A treatment outcome evaluation study of an intervention for binge eating among the obese that combines formal meditation and contingent formal and informal meditation. Dissertation Abstracts International. 1992;52(7-B):3898.
Britton Willoughby B. Meditation and depression. Dissertation Abstracts International. 2007;68(5-B):3387.
Carlisle TW. Effects of the transcendental meditation program on Psychological, health, social, and behavioral indicators of stress reduction and Human Resource development in the indian workplace. Dissertation Abstracts International. 2005;65(12-A):4629.
Chang J, Chiung W. Effect of meditation on music performance anxiety. Dissertation Abstracts International. 2001;62(5-A):1765.
Chhabra AK. The effect of self-aware meditation on stress in Indian immigrants living in the United States. Dissertation Abstracts International: Section B: The Sciences and Engineering. 2011;71(10-B):6435.
Clark P, Cortese-Jimenez G, Cohen E. Using Reiki, Yoga, meditation or patient education to address physical and psychological symptoms related to chemotherapy-induced peripheral neuropathy: A pilot study. [conference abstract]. Psycho-Oncology. Abstracts From the 8th Annual Conference of the American Psychosocial Oncology Society Anaheim. CA United States. Feb 17-19 2011. 2011.
Cole B, Broer K, Hopkins C, et al. A randomized controlled trial of spiritually-focused meditation in patients newly diagnosed with acute leukemia. [Abstract No. 1519]. Blood. 2010;116(21).
Collins LA. Stress management and yoga. Dissertation Abstracts International. 1984;45(1-A):0116.
Comer James F. Meditation and progressive relaxation in the treatment of test anxiety. Dissertation Abstracts International. 1978;38(12-B):6142-3.
DeBlassie PA. Christian meditation: A clinical investigation. Dissertation Abstracts International. 1981;42(3-B):1167.
Diner MD. The differential effects of meditation and systematic desensitization on specific and general anxiety. Dissertation Abstracts International. 1978;39(4-B):1950.
Donesky-Cuenco D, Carrieri-Kohlman V, Park SK, Jacobs B. Safety and feasibility of yoga in patients with COPD. [Abstract]. Proceedings of the American Thoracic Society. 2006;A221.
Dua JK. Effect of meditation and progressive relaxation training on reported relaxation and on blood pressure. [abstract]. Aust Psychol. 1984;19(1):71.
Dudani U, Gupta HL, Singh SH, Selvamurthy W, Surange SG. Effect of Sahaja yoga on the frequency of seizures in epileptics. 18th International Epilepsy Congress. 1989. 161.
Frisvold MH. The “midlife study”: Mindfulness as an intervention to change health behaviors in midlife women. University of Minnesota. 2009.
Gilmore JV. Relative effectiveness of meditation and autogenic training for the self-regulation of anxiety. Dissertation Abstracts International. 1985;45(8-B):2686.
Humphrey CW. A stress management intervention with forgiveness as the goal (Meditation, mind-body medicine). Dissertation Abstracts International : Section B: the Sciences and Engineering. 1999;60(4-B):1855.
Immink M. A pilot study on yoga and meditation as an adjunct to fitness rehabilitation programs for stroke patients with chronic hemiparesis. Australian New Zealand Clinical Trials Registry (ANZCTR). Http://Www.Anzctr.Org.Au/. 2009.
Jones Roger C. A comparison of aerobic exercise, anaerobic exercise and meditation on multidimensional stress measures. Dissertation Abstracts International. 1981;42(6-B):2504-5.
Katiyar SK, Singh L, Bihari S. Role of yogic exercises in rehabilitation of patients with chronic obstructive pulmonary disease. [Abstract]. Indian Journal of Allergy Asthma and Immunology. 2005;19(2):123.
Klein PT, Adams W. Cardiopulmonary physiotherapeutic applications of taiji (Structured abstract). Cardiopulmonary Physical Therapy. 2004;15(4):5-11.
Kondwani KA, Kelley ME, Meng YX, Quyyumi AA, Gibbons GH, Vaccarino V. Effects of a meditation intervention on endothelial function in African americans with metabolic syndrome: A randomized trial. [conference abstract]. Psychosomatic Medicine. Abstracts From the 69th Annual Meeting of the American Psychosomatic Society San Antonio. TX United States. Mar 9-12, 2011. 2011;73(3).
Krueger RC. The comparative effects of Zen focusing and muscle relaxation training on selected experiential variables. Dissertation Abstracts International. 1980;41(4-A):1405.
Kulshreshtha A, Norton C, Veledar E, Eubanks G, Sheps D. Mindfulness based meditation results in improved subjective emotional assessment among patients with coronary artery disease: Results from the mindfulness based stress reduction study. [conference abstract]. Psychosomatic Medicine. Abstracts From the 69th Annual Meeting of the American Psychosomatic Society San Antonio. TX United States. Mar 9-12, 2011. 2011;73(3).
Lavretsky H, Irwin M. Meditation improves depressive symptoms, coping, cognition, and inflammation in family dementia caregivers in a randomized 8-week pilot study. [conference abstract]. American Journal of Geriatric Psychiatry. Abstracts of the American Association for Geriatric Psychiatry, AAGP Annual Meeting. 2011 Mar 18-21. San Antonio, TX United States. 2011.
Malphurs JE, Asebey-Birkholm MA, Petisco I, David D. A Randomized Clinical Trial of Meditation for Veterans with Post-Traumatic Stress Disorder. Military Health Research Forum. Kansas City, MO. August 31- September 3, 2009. [Conference Abstracts]. 2009.
Manikonda P, Stoerk S, Toegel S, et al. Influence of non-pharmacological treatment (contemplative meditation and breathing technique) on stress induced hypertension - A randomized controlled study. American Journal of Hypertension. 2005;18(5):89A-90A.
Marcel A, de Dios Herman D, Hagerty C, Anderson BJ, Britton W, Stein M. Motivational enhancment and mindfulness meditation for young adult female marijuana users. Proceedings of the 73rd Annual Scientific Meeting of the College on Problems of Drug Dependence. 2011 June 18-23. Hollywood, Florida. 2011;203. Abstract no: 811.
Miro DJ. A comparative evaluation of relaxation training strategies utilizing EMG biofeedback. Dissertation Abstracts International. 1981;42(3-B):1183-4.
Oh B, Butow P, Mullan B, Clarke SJ, Beale P, Rosenthal D. Randomized clinical trial: The Impact of Medical Qigong (traditional Chinese medicine) on fatique, quality of life, side effects, mood status and inlfammation of cancer patients. [abstarct no. 9565]. Journal of Clinical Oncology: ASCO Annual Meeting Proceedings. 2008;26(15S part I):518.
Price A, Meah M, O'Shaughnessy T. A pilot study to compare qiqong exercises with conventional exercises in pulmonary rehabilitation. [Abstract]. Thorax. 2006;61(Suppl 2):ii67. [P032].
Rosdahl DRL. The effect of mindfulness meditation on tension headaches and secretory immunoglobulin A in saliva [dissertation]. 2003.
Sagula DA. Varying treatment duration in a mindfulness meditation stress reduction program for chronic pain patients [dissertation]. 1999.
Schneider R, Alexander C, Myers H, et al. Lifestyle modification in the prevention of left ventricular hypertrophy: A randomized controlled trial of stress reduction and health education in hypertensive African Americans. Journal of Hypertension. 2006;24(Suppl. 6):90.
Smith JC. Meditation as psychotherapy. Dissertation Abstracts International. 1975;36(6-B):3073.
Straus S. A 16-week tai chi programme prevented falls in healthy older adults. Evid Based Med. 2008;13(2):54. [pmid: 18375707].
Toomey M. The effects of the transcendental meditation program on carotid atherosclerosis and cardiovascular disease risk factors in Native Hawaiians. Dissertation Abstracts International: Section B: The Sciences and Engineering. 2007;68(6):4169.
Weiner Donald E. The effects of mantra meditation and progressive relaxation on self-actualization, state and trait anxiety, and frontalis muscle tension. Dissertation Abstracts International. 1977;37(8-B):4174.
Wilson HB. The specific effects model: Relaxation and meditation effects on cognitive and somatic anxiety. Dissertation Abstracts International. 2001;61(9-b):5013.
Wolf DB. Effects of the hare krsna maha mantra on stress, depression, and the three gunas. (spirituality, yoga). [dissertation]. Dissertation Abstracts International. 2000;60(7-B).
Wood DT. The effects of progressive relaxation, heart rate feedback, and content-specific meditation on anxiety and performance in a class situation. Dissertation Abstracts International. 1978;39(6-A):3458.
Young EC, Brown ND, Brammar C, Owen E, Lowe J, Johnson C, et al. Effect of mindfulness meditation as a psychological intervention for chronic cough. [Abstract]. American Thoracic Society International Conference. May 15-20, 2009. San Diego. 2009;A5760. [Poster #F8].

## Other Meditation

Alberts HJ, Thewissen R. The Effect of a Brief Mindfulness Intervention on Memory for Positively and Negatively Valenced Stimuli. Mindfulness (N Y). 2011;2(2):73-7. [pmid: 21660085].
Dahl JC, Lundgren TL, Yardi N. Evaluation of short term ACT psychotherapy and yoga in a RCT trial for refractory seizures in India. Epilepsia. Suppl 6. 2005;46:196.
Deberry S, Davis S, Reinhard KE. A comparison of meditation - Relaxtion and cognitive/behavioral techniques for reducing anxiety and depression in geriatric population. 1989;22(2):231-47.
DeBerry S. The effects of meditation-relaxation on anxiety and depression in a geriatric population. Psychotherapy: Theory, Research & Practice. 1982;19(4):512-21.
Fledderus M, Bohlmeijer ET, Smit F, Westerhof GJ. Mental health promotion as a new goal in public mental health care: a randomized controlled trial of an intervention enhancing psychological flexibility. Am J Public Health. 2010;100(12):2372. [pmid: 20966360].
Gaudiano BA, Herbert JD. Acute treatment of inpatients with psychotic symptoms using Acceptance and Commitment Therapy: pilot results. Behav Res Ther. 2006;44(3):415-37. [pmid: 15893293].
Khumar SS, Kaur P, Kaur S. Effectiveness of Shavasana on depression among university students. Indian Journal of Clinical Psychology. 1993;20(2):82-7.
Lillis J, Hayes SC, Bunting K, Masuda A. Teaching acceptance and mindfulness to improve the lives of the obese: a preliminary test of a theoretical model. Ann Behav Med. 2009;37(1):58-69. [pmid: 19252962].
Lundgren T, Dahl J, Yardi N, Melin L. Acceptance and Commitment Therapy and yoga for drug-refractory epilepsy: a randomized controlled trial. Epilepsy Behav. 2008;13(1):102-8. [pmid: 18343200].
Margolin A, Schuman-Olivier Z, Beitel M, Arnold RM, Fulwiler CE, Avants SK. A preliminary study of spiritual self-schema (3-S) therapy for reducing impulsivity in HIV positive drug users. 2007;63(10):979-99.
McMillan TM, Robertson IH, Brock D, Chorlton L. Brief mindfulness training for attentional problems after traumatic brain injury: A randomised control treatment trial. Neuropsychological Rehabilitation. 2002;12(2):117-25.
Sengoku M, Murata H, Kawahara T, Imamura K, Nakagome K. Does daily Naikan therapy maintain the efficacy of intensive Naikan therapy against depression?. Psychiatry and Clinical Neurosciences. 2010;64(1):44-51. [pmid: 20416025].
Smith WP, Compton WC, West WB. Meditation as an adjunct to a happiness enhancement program. J Clin Psychol. 1995;51(2):269-73. [pmid: 7797651].
Targ EF, Levine EG. The efficacy of a mind-body-spirit group for women with breast cancer: a randomized controlled trial. Gen Hosp Psychiatry. 2002;24(4):238-48. [pmid: 12100834].

## Other Population

Carei TR, Fyfe-Johnson AL, Breuner CC, Brown MA. Randomized controlled clinical trial of yoga in the treatment of eating disorders. J Adolesc Health. 2010;46(4):346-51. [pmid: 20307823].
Franco Justo C, de la Fuente Arias M, Salvador Granados M. Impact of a training program in full consciousness (mindfulness) in the measure of growth and personal self-realization. Psicothema. 2011;23(1):58-65. [pmid: 21266143].
Kratter J. The use of meditation in the treatment of attention deficit disorder with hyperactivity [dissertation]. 1983.
Madanmohan, Udupa K, Bhavanani AB, Vijayalakshmi P, Surendiran A. Effect of slow and fast pranayams on reaction time and cardiorespiratory variables. Indian J Physiol Pharmacol. 2005;49(3):313-8. [pmid: 16440849].
Moretti-Altuna G. The effects of meditation versus medication in the treatment of Attention Deficit Disorder with Hyperactivity [dissertation]. 1987.
Verma IC, Jayashankarappa BS, Palani M. Effect of transcendental meditation on the performance of some cognitive psychological tests. Indian J Med Res. 1982;76(Suppl):136-43. [pmid: 6764454].

## No Control Group

Agarwal BL, Kharbanda A. Effect of transcendental meditation on mild and moderate hypertension. J Assoc Physicians India. 1981;29(8):591-6. [pmid: 7040331].
Allison J. Respiratory changes during transcendental meditation. Lancet. 1970;1(7651):833-4. [pmid: 4191449].
An H, Kulkarni R, Nagarathna R, Nagendra H. Measures of heart rate variability in women following a meditation technique. Int J Yoga. 2010;3(1):6-9. [pmid: 20948895].
Andrade C, Andrade AC. Meditation versus medication. Indian J Psychiatry. 1991;33(1):39-43. [pmid: 21897460].
Astin J. Effects of transcendental meditation on patients with cardiac syndrome X. Focus on Alternative & Complementary Therapies. 2000;5(3):216-7.
Beauregard M, Courtemanche J, Paquette V. Brain activity in near-death experiencers during a meditative state. Resuscitation. 2009;80(9):1006-10. [pmid: 19573975].
Benson H, Lehmann JW, Malhotra MS, Goldman RF, Hopkins J, Epstein MD. Body temperature changes during the practice of g Tum-mo yoga. Nature. 1982;295(5846):234-6. [pmid: 7035966].
Benson H, Malvea BP, Graham JR. Physiologic correlates of meditation and their clinical effects in headache: an ongoing investigation. Headache. 1973;13(1):23-4. [pmid: 4696143].
Bera TK, Gore MM, Oak JP. Recovery from stress in two different postures and in Shavasana--a yogic relaxation posture. Indian J Physiol Pharmacol. 1998;42(4):473-8. [pmid: 10874346].
Carlson LE, Garland SN. Impact of mindfulness-based stress reduction (MBSR) on sleep, mood, stress and fatigue symptoms in cancer outpatients. Int J Behav Med. 2005;12(4):278-85. [pmid: 16262547].
Chalmers R. Transcendental meditation does not predispose to epilepsy. Med Hypotheses. 2005;65(3):624-5. [pmid: 15913905].
Chambers SK, Foley E, Galt E, Ferguson M, Clutton S. Mindfulness groups for men with advanced prostate cancer: a pilot study to assess feasibility and effectiveness and the role of peer support. Support Care Cancer. 2011.
Chang J, Midlarsky E, Lin P. Effects of meditation on music performance anxiety. Medical Problems of Performing Artists. 2003;18(3):126-30.
Chen K, He B, Rihacek G, Sigal LH. A pilot trial of external Qigong therapy for arthritis. J Clin Rheumatol. 2003;9(5):332-5. [pmid: 17041488].
Chen KM, Hsu YC, Chen WT, Tseng HF. Well-being of institutionalized elders after Yang-style Tai Chi practice. J Clin Nurs. 2007;16(5):845-52. [pmid: 17459141].
Chen KW, Marbach JJ. External qigong therapy for chronic orofacial pain. [2]. 2002;8(5):532-4.
Cohen-Katz J, Wiley S, Capuano T, Baker DM, Deitrick L, Shapiro S. The effects of mindfulness-based stress reduction on nurse stress and burnout: a qualitative and quantitative study, part III. Holist Nurs Pract. 2005;19(2):78-86. [pmid: 15871591].
Duncan L, Weissenburger D. Effects of a Brief Meditation Program on Well-being and Loneliness. TCA Journal. 2003;31(1):4-14.
Dunn BR, Hartigan JA, Mikulas WL. Concentration and mindfulness meditations: unique forms of consciousness?. Appl Psychophysiol Biofeedback. 1999;24(3):147-65. [pmid: 10652635].
Galantino ML, Desai K, Greene L, Demichele A, Stricker CT, Mao JJ. Impact of Yoga on Functional Outcomes in Breast Cancer Survivors With Aromatase Inhibitor-Associated Arthralgias. Integr Cancer Ther. 2011.
Ghista DN, Nandagopal D, Ramamurthi B, Das A, Mukherju A, Krinivasan TM. Physiological characterisation of the ‘meditative state’ during intutional practice (the Ananda Marga system of meditation) and its therapeutic value. Med Biol Eng. 1976;14(2):209-13. [pmid: 781406].
Gonzalez A, Solomon SE, Zvolensky MJ, Miller CT. The interaction of mindful-based attention and awareness and disengagement coping with HIV/AIDS-related stigma in regard to concurrent anxiety and depressive symptoms among adults with HIV/AIDS. J Health Psychol. 2009;14(3):403-13. [pmid: 19293302].
Greendale GA, McDivit A, Carpenter A, Seeger L, Huang MH. Yoga for women with hyperkyphosis: results of a pilot study. Am J Public Health. 2002;92(10):1611-4. [pmid: 12356608].
Gururaja D, Harano K, Toyotake I, Kobayashi H. Effect of yoga on mental health: Comparative study between young and senior subjects in Japan. Int J Yoga. 2011;4(1):7-12. [pmid: 21654969].
Haas M. Economic analysis of tai chi as a means of preventing falls and falls related injuries among older adults (Structured abstract). 2006:1-14.
Heidenreich T, Tuin I, Pflug B, Michal M, Michalak J. Mindfulness-based cognitive therapy for persistent insomnia: a pilot study. Psychother Psychosom. 2006;75(3):188-9. [pmid: 16636636].
Hyeong-Dong Kim, Tae-You Kim, Hyun Dong J, Seon-Tae Son. The Effects of Tai Chi Based Exercise on Dynamic Postural Control of Parkinson's Disease Patients while Initiating Gait. Journal of Physical Therapy Science. 2011;23(2):265-9.
Johnson DP, Penn DL, Fredrickson BL, et al. A pilot study of loving-kindness meditation for the negative symptoms of schizophrenia. Schizophr Res. 2011;129(2-3):137-40. [pmid: 21385664].
Joseph S, Sridharan K, Patil SK, et al. Study of some physiological and biochemical parameters in subjects undergoing yogic training. Indian J Med Res. 1981;74:120-4. [pmid: 7309176].
Kaul P, Passafiume J, Sargent CR, O'Hara BF. Meditation acutely improves psychomotor vigilance, and may decrease sleep need. Behav Brain Funct. 2010;6:47. [pmid: 20670413].
Kinoshita K. A study on response of EEG during Zen meditation--alpha-blocking to name calling (author's transl). Seishin Shinkeigaku Zasshi. 1975;77(9):623-58. [pmid: 1243181].
Kjaer TW, Bertelsen C, Piccini P, Brooks D, Alving J, Lou HC. Increased dopamine tone during meditation-induced change of consciousness. Brain Res Cogn Brain Res. 2002;13(2):255-9. [pmid: 11958969].
Lee KYT, Jones AYM, Hui-Chan CWY, Tsang WWN. Kinematics and energy expenditure of sitting T'ai Chi. 2011;17(8):665-8.
Lee MS, Kang CW, Ryu H, Moon SR. Endocrine and immune effects of Qi-training. International Journal of Neuroscience. 2004;114(4):529-37. [pmid: 15195356].
Li J, Sharma K, Finkelstein J. Feasibility of computer-assisted Tai Chi education. AMIA Annu Symp Proc. 2005;1027.
Madhavi S, Raju PS, Reddy MV, et al. Effect of yogic exercises on lean body mass. J Assoc Physicians India. 1985;33(7):465-6. [pmid: 4055664].
Maras ML, Rinke WJ, Stephens CR, Boehm TM. Effect of meditation on insulin dependent diabetes mellitus. Diabetes Educ. 1984;10(1):22-5. [pmid: 6370638].
McIver S, O'Halloran P, McGartland M. The impact of Hatha yoga on smoking behavior. Altern Ther Health Med. 2004;10(2):22-3. [pmid: 15055089].
McManus F, Muse K, Surawy C. Mindfulness-based cognitive therapy (MBCT) for severe health anxiety. Healthcare Counselling & Psychotherapy Journal. 2011;11(1):19-23.
Morse DR. An exploratory study of the use of meditation alone and in combination with hypnosis in clinical dentistry. J Am Soc Psychosom Dent Med. 1977;24(4):113-20. [pmid: 338563].
Morse DR, Cohen L, Furst ML, Martin JS. A physiological evaluation of the yoga concept of respiratory control of autonomic nervous system activity. Int J Psychosom. 1984;31(1):3-19. [pmid: 6590525].
Morse DR, Schacterle GR, Esposito JV, et al. Stress, meditation and saliva: a study of separate salivary gland secretions in endodontic patients. J Oral Med. 1983;38(4):150-60. [pmid: 6366165].
Morse DR, Schacterle GR, Furst ML, et al. The effect of stress and meditation on salivary protein and bacteria: a review and pilot study. J Human Stress. 1982;8(4):31-9.
Moustgaard A, Bedard M, Felteau M. Mindfulness-based cognitive therapy (MBCT) for individuals who had a stroke: results from a pilot study. Journal of Cognitive Rehabilitation. 2007;25(4):4-10.
Murphy L, Riley D, Rodgers J, Plank S, Lehman S, Duryea B. Effects of Tai Chi on balance, mobility, and strength among older persons participating in an osteoporosis prevention and education program. Explore (NY). 2005;1(3):192-3. [pmid: 16781529].
Mustata S, Cooper L, Langrick N, Simon N, Jassal SV, Oreopoulos DG. The effect of a Tai Chi exercise program on quality of life in patients on peritoneal dialysis: a pilot study. Perit Dial Int. 2005;25(3):291-4. [pmid: 15981780].
Narahari SR, Aggithaya MG, Prasanna KS, Bose KS. An integrative treatment for lower limb lymphedema (elephantiasis). J Altern Complement Med. 2010;16(2):145-9. [pmid: 20180687].
Orme-Johnson DW. Transcendental meditation does not predispose to epilepsy. Med Hypotheses. 2005;65(1):201-2. [pmid: 15893150].
Patra S, Telles S. Positive impact of cyclic meditation on subsequent sleep. Med Sci Monit. 2009;15(7):CR375-81. [pmid: 19564829].
Patra S, Telles S. Heart rate variability during sleep following the practice of cyclic meditation and supine rest. Appl Psychophysiol Biofeedback. 2010;35(2):135-40. [pmid: 19838801].
Robins JL, McCain NL, Gray DP, Elswick RK Jr, Walter JM, McDade E. Research on psychoneuroimmunology: tai chi as a stress management approach for individuals with HIV disease. Appl Nurs Res. 2006;19(1):2-9. [pmid: 16455435].
Sakata T, Li Q, Tanaka M, Tajima F. Positive effects of a qigong and aerobic exercise program on physical health in elderly Japanese women: an exploratory study. Environ Health Prev Med. 2008;13(3):162-8. [pmid: 19568901].
Satyanarayanamurthi GV, Sastry PB. A preliminary scientific investigation into some of the unusual physiological manifestations acquired as a result of yogic practices in India. Wien Z Nervenheilkd Grenzgeb. 1958;15(1-4):239-49. [pmid: 13604305].
Schneider B, Ercoli L, Siddarth P, Lavretsky H. Vascular Burden and Cognitive Functioning in Depressed Older Adults. Am J Geriatr Psychiatry. 2011.
Shah AH, Joshi SV, Mehrotra PP, Potdar N, Dhar HL. Effect of Saral meditation on intelligence, performance and cardiopulmonary functions. Indian J Med Sci. 2001;55(11):604-8. [pmid: 12508633].
Singh NN, Lancioni GE, Winton AS, Singh AN, Adkins AD, Singh J. Clinical and benefit-cost outcomes of teaching a mindfulness-based procedure to adult offenders with intellectual disabilities (Provisional abstract). Behavior Modification. 2008;32(5):622-37. [pmid: 18362201].
Spanos NP, Rivers SM, Gottlieb J. Hypnotic responsivity, meditation, and laterality of eye movements. J Abnorm Psychol. 1978;87(5):566-9. [pmid: 359619].
Subramanya P, Telles S. Effect of two yoga-based relaxation techniques on memory scores and state anxiety. Biopsychosoc Med. 2009;3:8. [pmid: 19674483].
Taggart HM. Effects of Tai Chi exercise on balance, functional mobility, and fear of falling among older women. Appl Nurs Res. 2002;15(4):235-42. [pmid: 12444582].
Telles S, Naveen KV. Changes in middle latency auditory evoked potentials during meditation. Psychol Rep. 2004;94(2):398-400. [pmid: 15154162].
Uhlig T, Larsson C, Hjorth AG, Odegard S, Kvien TK. No improvement in a pilot study of tai chi exercise in rheumatoid arthritis. Ann Rheum Dis. 2005;64(3):507-9. [pmid: 15708910].
Weissbecker I, Salmon P, Studts JL, Floyd AR, Dedert EA, Sephton SE. Mindfulness-based stress reduction and sense of coherence among women with fibromyalgia. Journal of Clinical Psychology in Medical Settings. 2002;9(4):297-307.
Wenger Ma, Bagchi Bk, Anand Bk. Experiments in India on “voluntary” control of the heart and pulse. Circulation. 1961;24:1319-25. [pmid: 14006121].
Yeh SH, Chuang H, Lin LW, Hsiao CY, Wang PW, Yang KD. Tai chi chuan exercise decreases A1C levels along with increase of regulatory T-cells and decrease of cytotoxic T-cell population in type 2 diabetic patients. Diabetes Care. 2007;30(3):716-8. [pmid: 17327347].
Oktedalen O, Solberg EE, Haugen AH, Opstad PK. The influence of physical and mental training on plasma beta-endorphin level and pain perception after intensive physical exercise. Stress and Health: Journal of the International Society for the Investigation of Stress. 2001;17(2):121-7.
Zeidan F, Martucci KT, Kraft RA, Gordon NS, McHaffie JG, Coghill RC. Brain mechanisms supporting the modulation of pain by mindfulness meditation. J Neurosci. 2011;31(14):5540-8. [pmid: 21471390].

## Not Randomized

Acharya B, Upadhyay A, Upadhyay RT, Kumar A. Effect of Pranayama (voluntary regulated breathing) and Yogasana (yoga postures) on lipid profile in normal healthy junior footballers. Int J Yoga. 2010;3(2):70. [pmid: 21170233].
Aftanas LI, Golocheikine SA. Human anterior and frontal midline theta and lower alpha reflect emotionally positive state and internalized attention: high-resolution EEG investigation of meditation. Neurosci Lett. 2001;310(1):57-60. [pmid: 11524157].
Aftanas LI, Golosheikin SA. Changes in cortical activity during altered state of consciousness: study of meditation by high resolution EEG. Fiziol Cheloveka. 2003;29(2):18-27. [pmid: 12751217].
Agarwal BL, Kharbanda A. Effect of transcendental meditation on mild and moderate hypertension. J Assoc Physicians India. 1981;29(8):591-6. [pmid: 7040331].
Agte V, Tarwadi K. Sudarshan Kriya yoga for treating type 2 diabetes: a preliminary study. Alternative & Complementary Therapies. 2004;10(4):220-2.
Alexander CN, Swanson GC, Rainforth MV, Carlisle TW. Effects of the transcendental meditation program on stress reduction, health, and employee development: A prospective study in two occupational settings. Anxiety, Stress & Coping: An International Journal. 1993;6(3):245-62.
Allison J. Respiratory changes during transcendental meditation. Lancet. 1970;1(7651):833-4. [pmid: 4191449].
An H, Kulkarni R, Nagarathna R, Nagendra H. Measures of heart rate variability in women following a meditation technique. Int J Yoga. 2010;3(1):6-9. [pmid: 20948895].
Andrade C, Andrade AC. Meditation versus medication. Indian J Psychiatry. 1991;33(1):39-43. [pmid: 21897460].
Anon. Transcendental Meditation in the treatment of post-Vietnam adjustment. Journal of Counseling & Development. 1985;64(3):212-5.
Astin J. Effects of transcendental meditation on patients with cardiac syndrome X. Focus on Alternative & Complementary Therapies. 2000;5(3):216-7.
Badawi K, Wallace RK, Orme-Johnson D, Rouzere AM. Electrophysiologic characteristics of respiratory suspension periods occurring during the practice of the Transcendental Meditation Program. Psychosom Med. 1984;46(3):267-76. [pmid: 6377350].
Baijal S, Srinivasan N. Theta activity and meditative states: spectral changes during concentrative meditation. Cogn Process. 2010;11(1):31-8. [pmid: 19626355].
Banquet JP. Spectral analysis of the EEG in meditation. Electroencephalogr Clin Neurophysiol. 1973;35(2):143-51. [pmid: 4124606].
Barmark SM, Gaunitz SC. Transcendental meditation and heterohypnosis as altered states of consciousness. Int J Clin Exp Hypn. 1979;27(3):227-39. [pmid: 396256].
Battle CL, Uebelacker LA, Howard M, Castaneda M. Prenatal yoga and depression during pregnancy. Birth. 2010;37(4):353-4. [pmid: 21083731].
Bay R, Bay F. Combined Therapy Using Acupressure Therapy, Hypnotherapy, and Transcendental Meditation versus Placebo in Type 2 Diabetes. J Acupunct Meridian Stud. 2011;4(3):183-6. [pmid: 21981869].
Beauregard M, Courtemanche J, Paquette V. Brain activity in near-death experiencers during a meditative state. Resuscitation. 2009;80(9):1006-10. [pmid: 19573975].
Bedard M, Felteau M, Gibbons C, et al. A mindfulness-based intervention to improve quality of life among individuals who sustained traumatic brain injuries: one-year follow-up. Journal of Cognitive Rehabilitation. 2005;23(1):8-13.
Benson H, Lehmann JW, Malhotra MS, Goldman RF, Hopkins J, Epstein MD. Body temperature changes during the practice of g Tum-mo yoga. Nature. 1982;295(5846):234-6. [pmid: 7035966].
Benson H, Malvea BP, Graham JR. Physiologic correlates of meditation and their clinical effects in headache: an ongoing investigation. Headache. 1973;13(1):23-4. [pmid: 4696143].
Benson H, Rosner BA, Marzetta BR, Klemchuk HP. Decreased blood pressure in borderline hypertensive subjects who practiced meditation. J Chronic Dis. 1974;27(3):163-9. [pmid: 4830843].
Bera TK, Gore MM, Oak JP. Recovery from stress in two different postures and in Shavasana--a yogic relaxation posture. Indian J Physiol Pharmacol. 1998;42(4):473-8. [pmid: 10874346].
Berkovich-Ohana A, Glicksohn J, Goldstein A. Mindfulness-induced changes in gamma band activity - Implications for the default mode network, self-reference and attention. Clin Neurophysiol. 2011.
Bernardi L, Passino C, Spadacini G, et al. Reduced hypoxic ventilatory response with preserved blood oxygenation in yoga trainees and Himalayan Buddhist monks at altitude: evidence of a different adaptive strategy?. Eur J Appl Physiol. 2007;99(5):511-8. [pmid: 17206440].
Bharshankar JR, Bharshankar RN, Deshpande VN, Kaore SB, Gosavi GB. Effect of yoga on cardiovascular system in subjects above 40 years. Indian J Physiol Pharmacol. 2003;47(2):202-6. [pmid: 15255625].
Bhatia M, Kumar A, Kumar N, Pandey RM, Kochupillai V. Electrophysiologic evaluation of Sudarshan Kriya: an EEG, BAER, P300 study. Indian J Physiol Pharmacol. 2003;47(2):157-63. [pmid: 15255618].
Bhatnagar OP, Anantharaman V. The effect of yoga training on neuromuscular excitability and muscular relaxation. Neurol India. 1977;25(4):230-2. [pmid: 614510].
Bhattacharya S, Pandey US, Verma NS. Improvement in oxidative status with yogic breathing in young healthy males. Indian J Physiol Pharmacol. 2002;46(3):349-54. [pmid: 12613400].
Borker AS, Pednekar JR. Effect of pranayam on visual and auditory reaction time. [2]. 2003;47(2):229-30.
Bosch PR, Traustadottir T, Howard P, Matt KS. Functional and physiological effects of yoga in women with rheumatoid arthritis: a pilot study. Altern Ther Health Med. 2009;15(4):24-31. [pmid: 19623830].
Bowen S, Witkiewitz K, Dillworth TM, et al. Mindfulness meditation and substance use in an incarcerated population. Psychol Addict Behav. 2006;20(3):343-7. [pmid: 16938074].
Bowen S, Witkiewitz K, Dillworth TM, Marlatt GA. The role of thought suppression in the relationship between mindfulness meditation and alcohol use. Addictive Behaviors. 2007;32(10):2324-8. [pmid: 17300875].
Brooks JS, Scarano T. Transcendental Meditation in the treatment of post-Vietnam adjustment. Journal of Counseling & Development. 1985;64(3):212-5.
Brown KD, Koziol JA, Lotz M. A yoga-based exercise program to reduce the risk of falls in seniors: a pilot and feasibility study. J Altern Complement Med. 2008;14(5):454-7. [pmid: 18564950].
Brown LL, Robinson SE. The relationship between meditation and/or exercise and three measures of self-actualization. Journal of Mental Health Counseling. 1993;15(1):85-93.
Caldwell K, Harrison M, Adams M, Triplett NT. Effect of Pilates and taiji quan training on self-efficacy, sleep quality, mood, and physical performance of college students. J Bodyw Mov Ther. 2009;13(2):155-63. [pmid: 19329051].
Campbell JF, Stenstrom RJ, Bertrand D. Systematic changes in perceptual reactance induced by physical fitness training. Percept Mot Skills. 1985;61(1):279-84. [pmid: 3900922].
Carlson CR, Bacaseta PE, Simanton DA. A controlled evaluation of devotional meditation and progressive relaxation. Journal of Psychology and Theology. 1988;16(4):362-8.
Carter OL, Presti DE, Callistemon C, Ungerer Y, Liu GB, Pettigrew JD. Meditation alters perceptual rivalry in Tibetan Buddhist monks. Curr Biol. 2005;15(11):R412-3. [pmid: 15936259].
Cazard P. Interhemispheric synchronism of parieto-occipital alpha rhythm. Attention and conscious experience. Synchronie interhemispherique des rythmes alpha parito-occipitaux. Attention et experience consciente. 1974;74(1):7-22.
Chang RY, Koo M, Kan CB, et al. Effects of Tai Chi rehabilitation on heart rate responses in patients with coronary artery disease. Am J Chin Med. 2010;38(3):461-72. [pmid: 20503465].
Chatzisarantis NL, Hagger MS. Mindfulness and the intention-behavior relationship within the theory of planned behavior. Pers Soc Psychol Bull. 2007;33(5):663-76. [pmid: 17440208].
Chaudhary AK, Bhatnagar HN, Bhatnagar LK, Chaudhary K. Comparative study of the effect of drugs and relaxation exercise (yoga shavasan) in hypertension. J Assoc Physicians India. 1988;36(12):721-3. [pmid: 3069839].
Chaya MS, Nagendra HR. Long-term effect of yogic practices on diurnal metabolic rates of healthy subjects. Int J Yoga. 2008;1(1):27-32. [pmid: 21829281].
Chen K, He B, Rihacek G, Sigal LH. A pilot trial of external Qigong therapy for arthritis pain. [2]. 2003;9(5):332-5.
Chen KM, Hsu YC, Chen WT, Tseng HF. Well-being of institutionalized elders after Yang-style Tai Chi practice. J Clin Nurs. 2007;16(5):845-52. [pmid: 17459141].
Chen KW, Marbach JJ. External qigong therapy for chronic orofacial pain. [2]. 2002;8(5):532-4.
Chen WW, Sun WY. Tai Chi Chuan, an alternative form of exercise for health promotion and disease prevention for older adults in the community. International Quarterly of Community Health Education. 1997;16(4):333-9. [pmid: 20841054].
Chen YS, Crowley Z, Zhou S, Cartwright C. Effects of 12-week Tai Chi training on soleus H-reflex and muscle strength in older adults: a pilot study. Eur J Appl Physiol. 2011.
Chen YS, Zhou S, Cartwright C. Effect of 12 weeks of Tai Chi training on soleus Hoffmann reflex and control of static posture in older adults. Arch Phys Med Rehabil. 2011;92(6):886-91. [pmid: 21621664].
Cheung SY, Tsai E, Fung L, Ng J. Physical benefits of Tai Chi Chuan for individuals with lower-limb disabilities. Occup Ther Int. 2007;14(1):1-10. [pmid: 17623375].
Choi KE, Rampp T, Saha FJ, Dobos GJ, Musial F. Pain modulation by meditation and electroacupuncture in experimental submaximum effort tourniquet technique (SETT). Explore (NY). 2011;7(4):239-45. [pmid: 21724157].
Coelho CM, Lessa TT, Coelho LAMC, da Silva Scari R, Junior JMN, de Carvalho RM. Ventilatory function in female practitionersof Hatha Yoga. Funcao ventilatoria em mulheres praticantes de Hatha Ioga. 2011;13(4):279-84.
Colby F. An analogue study of the initial carryover effects of meditation, hypnosis, and relaxation using native college students. Biofeedback Self Regul. 1991;16(2):157-65. [pmid: 1854860].
Cooper MJ, Aygen MM. A relaxation technique in the management of hypercholesterolemia. J Human Stress. 1979;5(4):24-7.
Coubard OA, Duretz S, Lefebvre V, Lapalus P, Ferrufino L. Practice of contemporary dance improves cognitive flexibility in aging. Front Aging Neurosci. 2011;3:13. [pmid: 21960971].
Cowger EL, Torrance EP. Further examination of the quality of changes in creative functioning resulting from meditation (Zazen) training. Creative Child & Adult Quarterly. 1982;7(4):211-7.
Danhauer S, Rutherford C, McQuellon R, et al. Restorative yoga as a supportive intervention for women with ovarian or breast cancer. American Psychosocial Oncology Society (APOS) Third Annual Conference. Amelia Island, Florida. 16th-19th February 2006. Psycho-Oncology. 2006;15(1):S72-3.
Dash M, Telles S. Improvement in hand grip strength in normal volunteers and rheumatoid arthritis patients following yoga training. Indian J Physiol Pharmacol. 2001;45(3):355-60. [pmid: 11881576].
De La Arias JF, Justo CF, Manas I. Results of a program on mindfulness on the emotional situation of university students. Efectos de un programa de entrenamiento en conciencia plena (mindfulness) en el estado emocional de estudiantes universitarios. 2010;(19):31-52.
Deberry S, Davis S, Reinhard KE. A comparison of meditation - Relaxtion and cognitive/behavioral techniques for reducing anxiety and depression in geriatric population. 1989;22(2):231-47.
Delgado LC, Guerra P, Perakakis P, Viedma MI, Robles H, Vila J. Human values education and mindfulness meditation as a tool for emotional regulation and stress prevention for teachers: An efficiency study. Eficacia de un programa de entrenamiento en conciencia plena (mindfulness) y valores humanos como herramienta de regulacion emocional y prevencion del estres para profesores. 2010;18(3):511-33.
Delmonte MM. Response to meditation in terms of physiological, behavioral and self-report measures. Int J Psychosom. 1984;31(2):3-17. [pmid: 6392131].
Delmonte MM. Effects of expectancy on physiological responsivity in novice meditators. Biol Psychol. 1985;21(2):107-21. [pmid: 3907725].
Delmonte MM. Expectancy and response to meditation. Int J Psychosom. 1986;33(2):28-34. [pmid: 3528015].
Dhikav V, Karmarkar G, Gupta M, Anand KS. Yoga in premature ejaculation: a comparative trial with fluoxetine. J Sex Med. 2007;4(6):1726-32. [pmid: 17888067].
Dunn BR, Hartigan JA, Mikulas WL. Concentration and mindfulness meditations: unique forms of consciousness?. Appl Psychophysiol Biofeedback. 1999;24(3):147-65. [pmid: 10652635].
Eisendrath SJ, Delucchi K, Bitner R, Fenimore P, Smit M, McLane M. Mindfulness-based cognitive therapy for treatment-resistant depression: a pilot study. Psychother Psychosom. 2008;77(5):319-20. [pmid: 18600038].
Elson BD, Hauri P, Cunis D. Physiological changes in yoga meditation. Psychophysiology. 1977;14(1):52-7. [pmid: 319471].
Emavardhana T, Tori CD. Changes in self-concept, ego defense mechanisms, and religiosity following seven-day Vipassana meditation retreats. Journal for the Scientific Study of Religion. 1997;36(2):194-206.
Fan JT, Chen KM. Using silver yoga exercises to promote physical and mental health of elders with dementia in long-term care facilities. 2011:1-9.
Ferguson JK, Willemsen EW, Castaneto MV. Centering prayer as a healing response to everyday stress: A psychological and spiritual process. Pastoral Psychology. 2010;59(3):305-29.
Fishman L. Yoga for osteoporosis: a pilot study. Topics in Geriatric Rehabilitation. 2009;25(3):244-50.
Fjellman-Wiklund A, Stenlund T, Steinholtz K, Ahlgren C. Take charge: Patients' experiences during participation in a rehabilitation programme for burnout. J Rehabil Med. 2010;42(5):475-81. [pmid: 20544160].
Franco C, Sola Mad M, Justo E. Reduccion del malestar psicolgico y de la sobrecarga en familiares cuidadores de enfermos de Alzheimer mediante la aplicacion de un programa de entrenamiento en mindfulness (conciencia plena). Revista Espanola De Geriatria y Gerontologia. 2010;45(5):252-8. [pmid: 20541288].
Frumkin LR, Pagano RR. The effect of transcendental meditation on iconic memory. Biofeedback Self Regul. 1979;4(4):313-22. [pmid: 393303].
Galantino ML, Desai K, Greene L, Demichele A, Stricker CT, Mao JJ. Impact of Yoga on Functional Outcomes in Breast Cancer Survivors With Aromatase Inhibitor-Associated Arthralgias. Integr Cancer Ther. 2011.
Gallois P. Neurophysiologic and respiratory changes during the practice of relaxation technics. Encephale. 1984;10(3):139-44. [pmid: 6389092].
Gallois P, Forzy G, Dhont JL. Hormonal changes during relaxation. Encephale. 1984;10(2):79-82. [pmid: 6381032].
Gardner-Nix J, Backman S, Barbati J, Grummitt J. Evaluating distance education of a mindfulness-based meditation programme for chronic pain management. J Telemed Telecare. 2008;14(2):88-92. [pmid: 18348755].
Ghista DN, Nandagopal D, Ramamurthi B, Das A, Mukherju A, Krinivasan TM. Physiological characterisation of the ‘meditative state’ during intutional practice (the Ananda Marga system of meditation) and its therapeutic value. Med Biol Eng. 1976;14(2):209-13. [pmid: 781406].
Gode JD, Singh RH, Settiwar RM, Gode KD, Udupa KN. Increased urinary excretion of testosterone following a course of yoga in normal young volunteers. Indian J Med Sci. 1974;28(4-5):212-5. [pmid: 4435928].
Gokal R, Shillito L, Maharaj SR. Positive impact of yoga and pranayam on obesity, hypertension, blood sugar, and cholesterol: a pilot assessment. J Altern Complement Med. 2007;13(10):1056-7. [pmid: 18166115].
Gokhan N, Meehan EF, Peters K. The value of mindfulness-based methods in teaching at a clinical field placement. Psychol Rep. 2010;106(2):455-66. [pmid: 20524546].
Goldenberg DL, Kaplan KH, Nadeau MG, Brodeur C, Smith S, Schmid CH. A controlled study of a stress-reduction, cognitive-behavioral treatment program in fibromyalgia. 1994;2(2):53-66.
Goncalves LC, Vale RGDS, Barata NJF, Varejao RV, Dantas EHM. Flexibility, functional autonomy and quality of life (QoL) in elderly yoga practitioners. 2011;53(2):158-62.
Gonzalez A, Solomon SE, Zvolensky MJ, Miller CT. The interaction of mindful-based attention and awareness and disengagement coping with HIV/AIDS-related stigma in regard to concurrent anxiety and depressive symptoms among adults with HIV/AIDS. J Health Psychol. 2009;14(3):403-13. [pmid: 19293302].
Gopal KS, Anantharaman V, Balachander S, Nishith SD. The cardiorespiratory adjustments in ‘Pranayama’, with and without ‘Bandhas’, in ‘Vajrasana’. Indian J Med Sci. 1973;27(9):686-92. [pmid: 4775468].
Gopal KS, Anantharamn V, Nishith SD, Bhatnagar OP. The effect of yogasanas on muscular tone and cardio-respiratory adjustments. Indian J Med Sci. 1974;28(10):438-43. [pmid: 4466776].
Gopal KS, Bhatnagar OP, Subramanian N, Nishith SD. Effect of yogasanas and pranayamas on blood pressure, pulse rate and some respiratory functions. Indian J Physiol Pharmacol. 1973;17(3):273-6. [pmid: 4788511].
Greendale GA, McDivit A, Carpenter A, Seeger L, Huang MH. Yoga for women with hyperkyphosis: results of a pilot study. Am J Public Health. 2002;92(10):1611-4. [pmid: 12356608].
Greene YN, Hiebert B. A comparison of mindfulness meditation and cognitive self-observation. Canadian Journal of Counselling. 1988;22(1):25-34.
Grepmair L, Mitterlehner F, Rother W, Nickel M. Promotion of mindfulness in psychotherapists in training and treatment results of their patients. J Psychosom Res. 2006;60(6):649-50. [pmid: 16731244].
Grover P, Varma VK, Verma SK, Pershad D. Factors influencing treatment acceptance in neurotic patients referred for yoga therapy-;an exploratory study. Indian J Psychiatry. 1989;31(3):250-7. [pmid: 21927394].
Gururaja D, Harano K, Toyotake I, Kobayashi H. Effect of yoga on mental health: Comparative study between young and senior subjects in Japan. Int J Yoga. 2011;4(1):7-12. [pmid: 21654969].
Holzel BK, Carmody J, Vangel M, et al. Mindfulness practice leads to increases in regional brain gray matter density. Psychiatry Research: Neuroimaging. 2011;191(1):36-43.
Haas M. Economic analysis of tai chi as a means of preventing falls and falls related injuries among older adults (Structured abstract). 2006:1-14.
Hart CE, Tracy BL. Yoga as steadiness training: effects on motor variability in young adults. J Strength Cond Res. 2008;22(5):1659-69. [pmid: 18714217].
Harvey JR. The effect of yogic breathing exercises on mood. J Am Soc Psychosom Dent Med. 1983;30(2):39-48. [pmid: 6350245].
Hawkins MA, Alexander CN, Travis FT, et al. Consciousness-Based rehabilitation of inmates in the Netherlands Antilles: Psychosocial and cognitive changes. Journal of Offender Rehabilitation. 2003;36(1-4):205-28.
He Q, Zhang JZ, Li JZ. The effects of long-term Qi Gong exercise on brain function as manifested by computer analysis. J Tradit Chin Med. 1988;8(3):177-82. [pmid: 3216659].
Hegde SV, Adhikari P, Kotian S, Pinto VJ, D'Souza S, D'Souza V. Effect of 3-Month Yoga on Oxidative Stress in Type 2 Diabetes With or Without Complications: A controlled clinical trial. Diabetes Care. 2011;34(10):2208-10. [pmid: 21836105].
Heide FJ. Psychophysiological responsiveness to auditory stimulation during transcendental meditation. Psychophysiology. 1986;23(1):71-5. [pmid: 3511490].
Heidenreich T, Tuin I, Pflug B, Michal M, Michalak J. Mindfulness-based cognitive therapy for persistent insomnia: A pilot study. [2]. 2006;75(3):188-9.
Heppner WL, Kernis MH, Lakey CE, et al. Mindfulness as a means of reducing aggressive behavior: dispositional and situational evidence. Aggress Behav. 2008;34(5):486-96. [pmid: 18464229].
Hill JM, Vernig PM, Lee JK, Brown C, Orsillo SM. The development of a brief acceptance and mindfulness-based program aimed at reducing sexual revictimization among college women with a history of childhood sexual abuse. J Clin Psychol. 2011;67(9):969-80. [pmid: 21544818].
Hjelle LA. Transcendental meditation and psychological health. Percept Mot Skills. 1974;39(1 Pt 2):623-8. [pmid: 4424110].
Hui PN, Wan M, Chan WK, Yung PM. An evaluation of two behavioral rehabilitation programs, qigong versus progressive relaxation, in improving the quality of life in cardiac patients. J Altern Complement Med. 2006;12(4):373-8. [pmid: 16722787].
Jacobs B, Nagel L. The Impact of a Brief Mindfulness-Based Stress Reduction Program on Perceived Quality of Life. 2003;2(2):155-68.
Jevning R, Wilson AF, VanderLaan EF. Plasma prolactin and growth hormone during meditation. Psychosom Med. 1978;40(4):329-33. [pmid: 356081].
Johnson DP, Penn DL, Fredrickson BL, et al. A pilot study of loving-kindness meditation for the negative symptoms of schizophrenia. Schizophr Res. 2011;129(2-3):137-40. [pmid: 21385664].
Jung YH, Kang DH, Byun MS, et al. Influence of brain-derived neurotrophic factor and catechol O-methyl transferase polymorphisms on effects of meditation on plasma catecholamines and stress. Stress. 2011.
Jung YH, Kang DH, Jang JH, et al. The effects of mind-body training on stress reduction, positive affect, and plasma catecholamines. Neurosci Lett. 2010;479(2):138-42. [pmid: 20546836].
Kang HY, Yoo YS. Effects of a bereavement intervention program in middle-aged widows in Korea. Arch Psychiatr Nurs. 2007;21(3):132-40. [pmid: 17556106].
Karambelkar PV, Bhole MV, Gharote ML. Effect of Yogic asanas on uropepsin excretion. Indian J Med Res. 1969;57(5):944-7. [pmid: 5195646].
Kasamatsu A, Hirai T. An electroencephalographic study on the zen meditation (Zazen). Folia Psychiatr Neurol Jpn. 1966;20(4):315-36. [pmid: 6013341].
Kaul P, Passafiume J, Sargent CR, O'Hara BF. Meditation acutely improves psychomotor vigilance, and may decrease sleep need. Behav Brain Funct. 2010;6:47. [pmid: 20670413].
Khalsa SB, Cope S. Effects of a yoga lifestyle intervention on performance-related characteristics of musicians: a preliminary study. Med Sci Monit. 2006;12(8):CR325-31. [pmid: 16865063].
Khalsa SB, Shorter SM, Cope S, Wyshak G, Sklar E. Yoga ameliorates performance anxiety and mood disturbance in young professional musicians. Appl Psychophysiol Biofeedback. 2009;34(4):279-89. [pmid: 19657730].
Kim SJ, Lee CS. The Effects of Meditation on Stress and Self Efficacy of College Students. Chonnam Medical Journal. 2000;36(4):403-14.
Kim TS, Park JS, Kim MA. The relation of meditation to power and well-being. Nurs Sci Q. 2008;21(1):49-58. [pmid: 18096986].
Kingston T, Dooley B, Bates A, Lawlor E, Malone K. Mindfulness-based cognitive therapy for residual depressive symptoms. Psychol Psychother. 2007;80(Pt 2):193-203. [pmid: 17535594].
Kirk U, Downar J, Montague PR. Interoception drives increased rational decision-making in meditators playing the ultimatum game. Front Neurosci. 2011;5:49. [pmid: 21559066].
Kirsteins AE, Dietz F, Hwang SM. Evaluating the safety and potential use of a weight-bearing exercise, Tai-Chi Chuan, for rheumatoid arthritis patients. Am J Phys Med Rehabil. 1991;70(3):136-41. [pmid: 2039615].
Kjaer TW, Bertelsen C, Piccini P, Brooks D, Alving J, Lou HC. Increased dopamine tone during meditation-induced change of consciousness. Brain Res Cogn Brain Res. 2002;13(2):255-9. [pmid: 11958969].
Kjellgren A, Bood SA, Axelsson K, Norlander T, Saatcioglu F. Wellness through a comprehensive yogic breathing program - a controlled pilot trial. BMC Complement Altern Med. 2007;7:43. [pmid: 18093307].
Kligler B, Homel P, Harrison LB, et al. Impact of the Urban Zen Initiative on patients' experience of admission to an inpatient oncology floor: a mixed-methods analysis. J Altern Complement Med. 2011;17(8):729-34. [pmid: 21745096].
Kline KS, Docherty EM, Farley FH. Transcendental Meditation, self/actualization, and global personality. Journal of General Psychology. 1982;106(1):3-8.
Kochupillai V, Kumar P, Singh D, et al. Effect of rhythmic breathing (Sudarshan Kriya and Pranayam) on immune functions and tobacco addiction. Ann N Y Acad Sci. 2005;1056:242-52. [pmid: 16387692].
Kolsawalla MB. An experimental investigation into the effectiveness of some yogic variables as a mechanism of change in the value-attitude system. Journal of Indian Psychology. 1978;1(1):59-68.
Kozasa EH, Santos RF, Rueda AD, Benedito-Silva AA, De Ornellas FL, Leite JR. Evaluation of Siddha Samadhi Yoga for anxiety and depression symptoms: a preliminary study. Psychol Rep. 2008;103(1):271-4. [pmid: 18982958].
Kozasa EH, Sato JR, Lacerda SS, et al. Meditation training increases brain efficiency in an attention task. Neuroimage. 2011.
Kuan SC, Chen KM, Wang C. Effects of Qigong in Promoting Health of the Wheelchair-Bound Older Adults in Long-Term Care Facilities. Biol Res Nurs. 2011.
Kuang AK, Wang CX, Zhao GS, et al. Long-term observation on qigong in prevention of stroke--follow-up of 244 hypertensive patients for 18-22 years. J Tradit Chin Med. 1986;6(4):235-8. [pmid: 3600015].
Kulkarni R, Nagarathna R, Nagendra HR, An H. Measures of heart rate variability in women following a meditation technique. International Journal of Yoga. 2010;3(1):6-9. [pmid: 20948895].
Kyizom T, Singh S, Singh KP, Tandon OP, Kumar R. Effect of pranayama & yoga-asana on cognitive brain functions in type 2 diabetes-P3 event related evoked potential (ERP). Indian J Med Res. 2010;131:636-40. [pmid: 20516534].
Labelle LE, Campbell TS, Carlson LE. Mindfulness-based stress reduction in oncology: Evaluating mindfulness and rumination as mediators of change in depressive symptoms. Mindfulness. 2010;1(1):28-40.
Lakey CE, Berry DR, Sellers EW. Manipulating attention via mindfulness induction improves P300-based brain-computer interface performance. J Neural Eng. 2011;8(2):025019. [pmid: 21436516].
Lan C, Lai JS, Chen SY, Wong MK. 12-month Tai Chi training in the elderly: its effect on health fitness. Med Sci Sports Exerc. 1998;30(3):345-51. [pmid: 9526879].
Langer AI, Cangas AJ, Gallego J. Mindfulness-based intervention on distressing hallucination-like experiences in a nonclinical sample. Behav. Change. 2010;27(3):176-83.
Lavallee CF, Hunter MD, Persinger MA. Intracerebral source generators characterizing concentrative meditation. Cogn Process. 2011;12(2):141-50. [pmid: 21350845].
Lee EN, Kim YH, Chung WT, Lee MS. Tai chi for disease activity and flexibility in patients with ankylosing spondylitis--a controlled clinical trial. Evid Based Complement Alternat Med. 2008;5(4):457-62. [pmid: 18955296].
Lee KYT, Jones AYM, Hui-Chan CWY, Tsang WWN. Kinematics and energy expenditure of sitting T'ai Chi. 2011;17(8):665-8.
Lee LY, Lee DT, Woo J. Effect of Tai Chi on state self-esteem and health-related quality of life in older Chinese residential care home residents. J Clin Nurs. 2007 Sep;16(9):1592. Journal of Clinical Nursing. 2007;16(8):1580-2. [pmid: 17655547].
Lee LY, Lee DT, Woo J. Tai Chi and health-related quality of life in nursing home residents. J Nurs Scholarsh. 2009;41(1):35-43. [pmid: 19335676].
Lee MS, Lim HJ, Lee MS. Impact of qigong exercise on self-efficacy and other cognitive perceptual variables in patients with essential hypertension. J Altern Complement Med. 2004;10(4):675-80. [pmid: 15353025].
Lee MS, Rim YH, Kang CW. Effects of external Qi-therapy on emotions, electroencephalograms, and plasma cortisol. 2004;114(11):1493-502.
Lee MS, Kang CW, Ryu H, Moon SR. Endocrine and immune effects of Qi-training. International Journal of Neuroscience. 2004;114(4):529-37. [pmid: 15195356].
Lee TI, Chen HH, Yeh ML. Effects of chan-chuang qigong on improving symptom and psychological distress in chemotherapy patients. Am J Chin Med. 2006;34(1):37-46. [pmid: 16437737].
Lehrer PM, Schoicket S, Carrington P, Woolfolk RL. Psychophysiological and cognitive responses to stressful stimuli in subjects practicing progressive relaxation and clinically standardized meditation. Behaviour Research and Therapy. 1980;18(4):293-303. [pmid: 7002148].
Lesh TV. Zen meditation and the development of empathy in counselors. Journal of Humanistic Psychology. 1970;10(1):39-74.
Li M, Chen K, Mo Z. Use of qigong therapy in the detoxification of heroin addicts. Altern Ther Health Med. 2002;8(1):50-4. 56. 9. [pmid: 11795622].
Li Y, Devault CN, Van Oteghen S. Effects of extended Tai Chi intervention on balance and selected motor functions of the elderly. Am J Chin Med. 2007;35(3):383-91. [pmid: 17597497].
Lin MR, Hwang HF, Wang YW, Chang SH, Wolf SL. Community-based tai chi and its effect on injurious falls, balance, gait, and fear of falling in older people. Phys Ther. 2006;86(9):1189-201. [pmid: 16959668].
Little SA, Kligler B, Homel P, Belisle SS, Merrell W. Multimodal mind/body group therapy for chronic depression: a pilot study. Explore (NY). 2009;5(6):330-7. [pmid: 19913759].
Liu CY, Wei CC, Lo PC. Variation Analysis of Sphygmogram to Assess Cardiovascular System under Meditation. Evid Based Complement Alternat Med. 2009;6(1):107-12. [pmid: 18955219].
Logghe IH, Verhagen AP, Rademaker AC, et al. Explaining the ineffectiveness of a Tai Chi fall prevention training for community-living older people: a process evaluation alongside a randomized clinical trial (RCT). Arch Gerontol Geriatr. 2011;52(3):357-62. [pmid: 20965096].
Lu WA, Kuo CD. Comparison of the effects of Tai Chi Chuan and Wai Tan Kung exercises on autonomic nervous system modulation and on hemodynamics in elder adults. Am J Chin Med. 2006;34(6):959-68. [pmid: 17163585].
Madanmohan, Bhavanani AB, Prakash ES, Kamath MG, Amudhan J. Effect of six weeks of shavasan training on spectral measures of short-term heart rate variability in young healthy volunteers. Indian J Physiol Pharmacol. 2004;48(3):370-3. [pmid: 15648413].
Madanmohan, Mahadevan SK, Balakrishnan S, Gopalakrishnan M, Prakash ES. Effect of six weeks yoga training on weight loss following step test, respiratory pressures, handgrip strength and handgrip endurance in young healthy subjects. Indian J Physiol Pharmacol. 2008;52(2):164-70. [pmid: 19130860].
Madanmohan, Udupa K, Bhavanani AB, Vijayalakshmi P, Surendiran A. Effect of slow and fast pranayams on reaction time and cardiorespiratory variables. Indian J Physiol Pharmacol. 2005;49(3):313-8. [pmid: 16440849].
Mahapure HH, Shete SU, Bera TK. Effect of yogic exercise on super oxide dismutase levels in diabetics. Int J Yoga. 2008;1(1):21-6. [pmid: 21829280].
Malhotra V, Singh S, Tandon OP, Madhu SV, Prasad A, Sharma SB. Effect of Yoga asanas on nerve conduction in type 2 diabetes. Indian J Physiol Pharmacol. 2002;46(3):298-306. [pmid: 12613392].
Maloney R, Altmaier E. An initial evaluation of a mindful parenting program. J Clin Psychol. 2007;63(12):1231-8. [pmid: 17972292].
Manjunath NK, Telles S. Factors influencing changes in tweezer dexterity scores following yoga training. Indian J Physiol Pharmacol. 1999;43(2):225-9. [pmid: 10365316].
Maras ML, Rinke WJ, Stephens CR, Boehm TM. Effect of meditation on insulin dependent diabetes mellitus. Diabetes Educ. 1984;10(1):22-5. [pmid: 6370638].
Marc I, Langguth B, Biesinger E. Integrative approach for tinnitus: potential for qigong. Focus on Alternative & Complementary Therapies. 2011;16(1):58-9.
Marcus MT, Schmitz J, Moeller G, et al. Mindfulness-based stress reduction in therapeutic community treatment: a stage 1 trial. Am J Drug Alcohol Abuse. 2009;35(2):103-8. [pmid: 19322731].
Marcus M, Fine M, Kouzekanani K. Mindfulness-based meditation in a therapeutic community. Journal of Substance Use. 2001;5(4):305-11.
Margolin A, Schuman-Olivier Z, Beitel M, Arnold RM, Fulwiler CE, Avants SK. A preliminary study of spiritual self-schema (3-S+) therapy for reducing impulsivity in HIV positive drug users. 2007;63(10):979-99.
Maupin Ew. Individual Differences In Response To A Zen Meditation Exercise. J Consult Psychol. 1965;29:139-45. [pmid: 14282421].
McIver S, O'Halloran P, McGartland M. The impact of Hatha yoga on smoking behavior. Altern Ther Health Med. 2004;10(2):22-3. [pmid: 15055089].
Meares A. A form of intensive meditation associated with the regression of cancer. Am J Clin Hypn. 1982-1983;25(2-3):114-21. [pmid: 6764710].
Mills PJ, Schneider RH, Hill D, Walton KG, Wallace RK. Beta-adrenergic receptor sensitivity in subjects practicing transcendental meditation. J Psychosom Res. 1990;34(1):29-33. [pmid: 2156071].
Mirabel-Sarron C, Dorocant ES, Sala L, Bachelart M, Guelfi JD, Rouillon F. Mindfulness based cognitive therapy (MBCT): A pilot study in bipolar patients. Mindfulness based cognitive therapy (MBCT) dans la prevention des rechutes thymiques chez le patient bipolaire I : une etude pilote. Ann. Med.-Psychol. 2009;167(9):686-92.
Mohan A, Sharma R, Bijlani RL. Effect of meditation on stress-induced changes in cognitive functions. J Altern Complement Med. 2011;17(3):207-12. [pmid: 21417807].
Monk-Turner E, Turner C. Does yoga shape body, mind and spiritual health and happiness: Differences between yoga practitioners and college students. Int J Yoga. 2010;3(2):48-54. [pmid: 21170230].
Monk-Turner E. The benefits of meditation: Experimental findings. The Social Science Journal. 2003;40(3):465-70.
Morse DR. An exploratory study of the use of meditation alone and in combination with hypnosis in clinical dentistry. J Am Soc Psychosom Dent Med. 1977;24(4):113-20. [pmid: 338563].
Morse DR, Cohen L, Furst ML, Martin JS. A physiological evaluation of the yoga concept of respiratory control of autonomic nervous system activity. Int J Psychosom. 1984;31(1):3-19. [pmid: 6590525].
Morse DR, Furst ML. Meditation: an in depth study. J Am Soc Psychosom Dent Med. 1982;29(5):1-96. [pmid: 6757206].
Morse DR, Martin JS, Furst ML, Dubin LL. A physiological and subjective evaluation of neutral and emotionally-charged words for meditation. Part III. J Am Soc Psychosom Dent Med. 1979;26(3):106-12. [pmid: 391786].
Morse DR, Martin JS, Furst ML, Dubin LL. A physiological and subjective evaluation of neutral and emotionally-charged words for meditation. Part I. J Am Soc Psychosom Dent Med. 1979;26(1):31-8. [pmid: 387680].
Morse DR, Schacterle GR, Esposito JV, et al. Stress, meditation and saliva: a study of separate salivary gland secretions in endodontic patients. J Oral Med. 1983;38(4):150-60. [pmid: 6366165].
Morse DR, Schacterle GR, Furst ML, et al. The effect of stress and meditation on salivary protein and bacteria: a review and pilot study. J Human Stress. 1982;8(4):31-9.
Motivala SJ, Sollers J, Thayer J, Irwin MR. Tai Chi Chih acutely decreases sympathetic nervous system activity in older adults. J Gerontol A Biol Sci Med Sci. 2006;61(11):1177-80. [pmid: 17167159].
Mourya M, Mahajan AS, Singh NP, Jain AK. Effect of slow- and fast-breathing exercises on autonomic functions in patients with essential hypertension. J Altern Complement Med. 2009;15(7):711-7. [pmid: 19534616].
Moustgaard A, Bedard M, Felteau M. Mindfulness-based cognitive therapy (MBCT) for individuals who had a stroke: results from a pilot study. Journal of Cognitive Rehabilitation. 2007;25(4):4-10.
Myint K, Choy KL, Su TT, Lam SK. The effect of short-term practice of mindfulness meditation in alleviating stress in university students. 2011;22(2):165-71.
Nagarathna R, Nagendra HR. Yoga for bronchial asthma: a controlled study. Br Med J (Clin Res Ed). 1985;291(6502):1077-9.
Narahari SR, Aggithaya MG, Prasanna KS, Bose KS. An integrative treatment for lower limb lymphedema (elephantiasis). J Altern Complement Med. 2010;16(2):145-9. [pmid: 20180687].
Narendran S, Nagarathna R, Narendran V, Gunasheela S, Nagendra HR. Efficacy of yoga on pregnancy outcome. J Altern Complement Med. 2005;11(2):237-44. [pmid: 15865489].
Naruka JS, Mathur R, Mathur A. Effect of pranayama practices on fasting blood glucose and serum cholesterol. Indian J Med Sci. 1986;40(6):149-52. [pmid: 3770842].
Neumark-Sztainer D, Eisenberg ME, Wall M, Loth KA. Yoga and Pilates: associations with body image and disordered-eating behaviors in a population-based sample of young adults. Int J Eat Disord. 2011;44(3):276-80. [pmid: 20862694].
Newberg AB, Wintering N, Waldman MR, Amen D, Khalsa DS, Alavi A. Cerebral blood flow differences between long-term meditators and non-meditators. Conscious Cogn. 2010;19(4):899-905. [pmid: 20570534].
Nidich S, Seeman W, Dreskin T. Influence of transcendental meditation: A replication. Journal of Counseling Psychology. 1973;20(6):565-6.
Nomura T, Nagano K, Takato J, Ueki S, Matsuzaki Y, Yasumura S. The development of a Tai Chi exercise regimen for the prevention of conditions requiring long-term care in Japan. Arch Gerontol Geriatr. 2011;52(3):e198-203. [pmid: 21145120].
Norton GR, Rhodes L, Hauch J, Kaprowy EA. Characteristics of subjects experiencing relaxation and relaxation-induced anxiety. J Behav Ther Exp Psychiatry. 1985;16(3):211-6. [pmid: 3905864].
Nowakowska C, Fellmann B, Pasek T, Hauser J, Sluzewska A. Evaluation of the effect of relaxation and concentration exercises based on yoga on patients with psychogenic mental disorders. Psychiatr Pol. 1982;16(5-6):365-70. [pmid: 6764258].
Orme-Johnson D, Dillbeck MC, Wallace RK, Landrith GS 3rd. Intersubject EEG coherence: is consciousness a field?. Int J Neurosci. 1982;16(3-4):203-9. [pmid: 6763008].
Orme-Johnson DW. Autonomic stability and Transcendental Meditation. Psychosom Med. 1973;35(4):341-9. [pmid: 4719021].
Orme-Johnson DW, Schneider RH, Son YD, Nidich S, Cho ZH. Neuroimaging of meditation's effect on brain reactivity to pain. Neuroreport. 2006;17(12):1359-63. [pmid: 16951585].
Orzech KM, Shapiro SL, Brown KW, McKay M. Intensive mindfulness training-related changes in cognitive and emotional experience. The Journal of Positive Psychology. 2009;4(3):212-22.
Ospina-Kammerer V, Figley CR. An evaluation of the Respiratory One Method (ROM) in reducing emotional exhaustion among family physician residents. International Journal of Emergency Mental Health. 2003;5(1):29-32. [pmid: 12722487].
Overbeck KD. Effects of the transcendental meditation technic on the psychological and psychosomatic state. Psychother Psychosom Med Psychol. 1982;32(6):188-92. [pmid: 6758016].
Palta A. Sahajayoga and quality of life: An empirical study. Journal of Indian Psychology. 2009;27(1-2):21-34.
Pandey S, Mahato NK, Navale R. Role of self-induced sound therapy: Bhramari Pranayama in tinnitus. Audiological Medicine. 2010;8(3):137-41.
Pattanashetty R, Sathiamma S, Talakkad S, Nityananda P, Trichur R, Kutty BM. Practitioners of vipassana meditation exhibit enhanced slow wave sleep and REM sleep states across different age groups. Sleep and Biological Rhythms. 2010;8(1):34-41.
Paty J, Brenot P, Tignol J, Bourgeois M. Evoked cerebral activity (contingent negative variation and evoked potentials) and modified states of consciousness (sleeplike relaxation, transcendential meditation). Ann Med Psychol (Paris). 1978;136(1):143-69. [pmid: 354456].
Peng CK, Mietus JE, Liu Y, et al. Exaggerated heart rate oscillations during two meditation techniques. Int J Cardiol. 1999;70(2):101-7. [pmid: 10454297].
Poulin P, Mackenzie C, Soloway G, Karayolas E. Mindfulness training as an evidenced-based approach to reducing stress and promoting well-being among human services professionals. International Journal of Health Promotion & Education. 2008;46(2):72-80.
Radin DI, Vieten C, Michel L, Delorme A. Electrocortical activity prior to unpredictable stimuli in meditators and nonmeditators. Explore (NY). 2011;7(5):286-99. [pmid: 21907152].
Rakoviç D, Tomaíeviç M, Jovanov E, et al. Electroencephalographic (EEG) correlates of some activities which may alter consciousness: The transcendental meditation technique, musicogenic states, microwave resonance relaxation, healer/healee interaction, and alertness/drowsiness. 1999;23(3):399-412.
Ramachandran AK, Rosengren KS, Yang Y, Hsiao-Wecksler ET. Effect of Tai Chi on gait and obstacle crossing behaviors in middle-aged adults. Gait Posture. 2007;26(2):248-55. [pmid: 17035021].
Ramos NS, Hernandez SM, Bianca MaJ. Efecto de un programa integrado de mindfulness e inteligencia emocional sobre las estrategias cognitivas de regulacion emocional. Ansiedad y Estres. 2009;15(2-3):207-16.
Randolph PD, Caldera YM, Tacone AM, Greak BL. The long-term combined effects of medical treatment and a mindfulness-based behavioral program for the multidisciplinary management of chronic pain in west Texas. 1999;9(2):103-12.
Robertshawe P. Glutathione and total antioxidant status improved with yoga. Journal of the Australian Traditional-Medicine Society. 2008;14(1):29.
Robertson DW. The short and long range effects of the Transcendental Meditation technique on fractionated reaction time. J Sports Med Phys Fitness. 1983;23(1):113-20. [pmid: 6348419].
Roth B, Robbins D. Mindfulness-based stress reduction and health-related quality of life: findings from a bilingual inner-city patient population. Psychosom Med. 2004;66(1):113-23. [pmid: 14747645].
Rubik B. Neurofeedback-enhanced gamma brainwaves from the prefrontal cortical region of meditators and non-meditators and associated subjective experiences. J Altern Complement Med. 2011;17(2):109-15. [pmid: 21303197].
Rungreangkulkij S, Wongtakee W, Thongyot S. Buddhist group therapy for diabetes patients with depressive symptoms. Arch Psychiatr Nurs. 2011;25(3):195-205. [pmid: 21621733].
Sahay BK, Sadasivudu B, Yogi R, et al. Biochemical parameters in normal volunteers before and after yogic practices. Indian J Med Res. 1982;76(Suppl):144-8. [pmid: 7185755].
Sahdra BK, MacLean KA, Ferrer E, et al. Enhanced response inhibition during intensive meditation training predicts improvements in self-reported adaptive socioemotional functioning. Emotion. 2011;11(2):299-312. [pmid: 21500899].
Saito Y, Sasaki Y. The effect of transcendental meditation training on psychophysiological reactivity to stressful situations. Japanese Journal of Hypnosis. 1993;38(1):20-6.
Sakata T, Li Q, Tanaka M, Tajima F. Positive effects of a qigong and aerobic exercise program on physical health in elderly Japanese women: an exploratory study. Environ Health Prev Med. 2008;13(3):162-8. [pmid: 19568901].
Sampalli T, Berlasso E, Fox R, Petter M. A controlled study of the effect of a mindfulness-based stress reduction technique in women with multiple chemical sensitivity, chronic fatigue syndrome, and fibromyalgia. J Multidiscip Healthc. 2009;2:53-9. [pmid: 21197347].
Sarang SP, Telles S. Immediate effect of two yoga-based relaxation techniques on performance in a letter-cancellation task. Percept Mot Skills. 2007;105(2):379-85. [pmid: 18065059].
Sathyaprabha TN, Satishchandra P, Netravati K, et al. Effect of yoga on autonomic dysfunction associated with refractory epilepsy. Epilepsia. Suppl 6. 2005;46:353.
Schejbal P, Kroner B, Niesel W. An attempt to determine the effects of autogenic training and transcendental meditation on the variables of a personality inventory (author's transl). Psychother Med Psychol (Stuttg). 1978;28(5):158-64. [pmid: 360268].
Seeman W, Nidich S, Banta T. Influence of transcendental meditation on a measure of self-actualization. Journal of Counseling Psychology. 1972;19(3):184-7.
Seiler G, Seiler V. The effects of transcendental meditation on periodontal tissue. J Am Soc Psychosom Dent Med. 1979;26(1):8-12. [pmid: 387681].
Sengoku M, Murata H, Kawahara T, Imamura K, Nakagome K. Does daily Naikan therapy maintain the efficacy of intensive Naikan therapy against depression?. Psychiatry and Clinical Neurosciences. 2010;64(1):44-51. [pmid: 20416025].
Sengoku M, Murata H, Kawahara T, Nakagome K. Does daily Naikan therapy maintain the efficacy of intensive Naikan therapy against depression?. Erratum. Psychiatry and Clinical Neurosciences. 2010;64(2).
Shah AH, Joshi SV, Mehrotra PP, Potdar N, Dhar HL. Effect of Saral meditation on intelligence, performance and cardiopulmonary functions. Indian J Med Sci. 2001;55(11):604-8. [pmid: 12508633].
Shapiro SL, Figueredo AJ, Caspi O, et al. Going Quasi: The Premature Disclosure Effect in a Randomized Clinical Trial. 2002;25(6):605-21.
Singh NN, Lancioni GE, Winton AS, Singh AN, Adkins AD, Singh J. Clinical and benefit-cost outcomes of teaching a mindfulness-based procedure to adult offenders with intellectual disabilities (Provisional abstract). Behavior Modification. 2008;32(5):622-37. [pmid: 18362201].
Sinha S, Singh SN, Monga YP, Ray US. Improvement of glutathione and total antioxidant status with yoga. J Altern Complement Med. 2007;13(10):1085-90. [pmid: 18166119].
Skoglund L, Jansson E. Qigong reduces stress in computer operators. Complement Ther Clin Pract. 2007;13(2):78-84. [pmid: 17400142].
Slagter HA, Lutz A, Greischar LL, et al. Mental training affects distribution of limited brain resources. PLoS Biol. 2007;5(6):e138. [pmid: 17488185].
Son'kin VD, Zaitseva VV, Ivanov SA. The effect of a complex of meditation exercises on the psychophysiological state of young men. Fiziol Cheloveka. 2006;32(5):128-31. [pmid: 17100350].
Soriano En, Franco C, Justo E. Reducing psychological distress in immigrants living in Spain through the practice of flow meditation. European Journal of Education and Psychology. 2009;2(3):223-33.
Spanos NP, Rivers SM, Gottlieb J. Hypnotic responsivity, meditation, and laterality of eye movements. J Abnorm Psychol. 1978;87(5):566-9. [pmid: 359619].
Spanos NP, Steggles S, Radtke-Bodorik HL, Rivers SM. Nonanalytic attending, hypnotic susceptibility, and psychological well-being in trained meditators and nonmeditators. J Abnorm Psychol. 1979;88(1):85-7. [pmid: 370175].
Spicuzza L, Gabutti A, Porta C, Montano N, Bernardi L. Yoga and chemoreflex response to hypoxia and hypercapnia. Lancet. 2000;356(92-40):1495-6. [pmid: 11081541].
Srivastava M, Talukdar U, Lahan V. Application of meditation training in managing the symptoms of adjustment disorder with mixed anxiety and depression.
Stek RJ, Bass BA. Personal adjustment and perceived locus of control among students interested in meditation. Psychol Rep. 1973;32(3):1019-22. [pmid: 4704748].
Steptoe A. New approaches to the management of essential hypertension with psychological techniques. 1978;22(4):339-54.
Subrahmanyam S, Satyanarayana M, Rajeswari KR. Alcoholism: newer methods of management. Indian J Physiol Pharmacol. 1986;30(1):43-54. [pmid: 3818032].
Subramanya P, Telles S. Changes in midlatency auditory evoked potentials following two yoga-based relaxation techniques. Clin EEG Neurosci. 2009;40(3):190-5. [pmid: 19715182].
Sudheesh NN, Joseph KP. Investigation into the effects of music and meditation on galvanic skin response. 2000;21(3):158-63.
Sulekha S, Thennarasu K, Vedamurthachar A, Raju TR, Kutty BM. Evaluation of sleep architecture in practitioners of Sudarshan Kriya yoga and Vipassana meditation. Sleep and Biological Rhythms. 2006;4(3):207-14.
Sundar S, Agrawal SK, Singh VP, Bhattacharya SK, Udupa KN, Vaish SK. Role of yoga in management of essential hypertension. Acta Cardiol. 1984;39(3):203-8. [pmid: 6331698].
Surwillo WW, Hobson DP. Brain electrical activity during prayer. Psychol Rep. 1978;43(1):135-43. [pmid: 360259].
Taggart HM. Effects of Tai Chi exercise on balance, functional mobility, and fear of falling among older women. Appl Nurs Res. 2002;15(4):235-42. [pmid: 12444582].
Tebecis AK. A controlled study of the EEG during transcendental meditation: comparison with hypnosis. Folia Psychiatr Neurol Jpn. 1975;29(4):305-13. [pmid: 783025].
Telles S, Gaur V, Balkrishna A. Effect of a yoga practice session and a yoga theory session on state anxiety. Percept Mot Skills. 2009;109(3):924-30. [pmid: 20178291].
Telles S, Joshi M, Dash M, Raghuraj P, Naveen KV, Nagendra HR. An evaluation of the ability to voluntarily reduce the heart rate after a month of yoga practice. Integr Physiol Behav Sci. 2004;39(2):119-25. [pmid: 15759599].
Telles S, Maharana K, Balrana B, Balkrishna A. Effects of high-frequency yoga breathing called kapalabhati compared with breath awareness on the degree of optical illusion perceived. Percept Mot Skills. 2011;112(3):981-90. [pmid: 21853784].
Telles S, Raghuraj P, Arankalle D, Naveen KV. Immediate effect of high-frequency yoga breathing on attention. Indian J Med Sci. 2008;62(1):20-2. [pmid: 18239268].
Thomas D, Abbas KA. Comparison of transcendental meditation and progressive relaxation in reducing anxiety. Br Med J. 1978;2(6154):1749. [pmid: 367516].
Throll DA. Transcendental meditation and progressive relaxation: Their psychological effects. Journal of Clinical Psychology. 1981;37(4):776-81.
Throll DA. Transcendental meditation and progressive relaxation: their physiological effects. J Clin Psychol. 1982;38(3):522-30. [pmid: 7050179].
Tloczynski J, Tantriella M. A comparison of the effects of Zen breath meditation or relaxation on college adjustment. Psychologia: An International Journal of Psychology in the Orient. 1998;41(1):32-43.
Travis F, Arenander A. Cross-sectional and longitudinal study of effects of transcendental meditation practice on interhemispheric frontal asymmetry and frontal coherence. Int J Neurosci. 2006;116(12):1519-38. [pmid: 17145686].
Travis F, Olson T, Egenes T, Gupta HK. Physiological patterns during practice of the Transcendental Meditation technique compared with patterns while reading Sanskrit and a modern language. Int J Neurosci. 2001;109(1-2):71-80. [pmid: 11699342].
Travis F, Tecce J, Arenander A, Wallace RK. Patterns of EEG coherence, power, and contingent negative variation characterize the integration of transcendental and waking states. Biol Psychol. 2002;61(3):293-319. [pmid: 12406612].
Travis F, Tecce JJ, Guttman J. Cortical plasticity, contingent negative variation, and transcendent experiences during practice of the Transcendental Meditation technique. Biol Psychol. 2000;55(1):41-55. [pmid: 11099807].
Travis FT, Orme-Johnson DW. Field model of consciousness: EEG coherence changes as indicators of field effects. Int J Neurosci. 1989;49(3-4):203-11. [pmid: 2700478].
Travis FT, Orme-Johnson DW. EEG coherence and power during Yogic Flying. Int J Neurosci. 1990;54(1-2):1-12. [pmid: 2265953].
Turnbull MJ, Norris H. Effects of Transcendental Meditation on self-identity indices and personality. British Journal of Psychology. 1982;73(1):57-68.
Udupa KN, Singh RH, Dwivedi KN, Pandey HP, Rai V. Comparative biochemical studies on meditation. Indian J Med Res. 1975;63(12):1676-9. [pmid: 5370].
van den Hout MA, Engelhard IM, Beetsma D, et al. EMDR and mindfulness. Eye movements and attentional breathing tax working memory and reduce vividness and emotionality of aversive ideation. J Behav Ther Exp Psychiatry. 2011;42(4):423-31. [pmid: 21570931].
van den Hurk PA, Wingens T, Giommi F, Barendregt HP, Speckens AE, van Schie HT. On the Relationship Between the Practice of Mindfulness Meditation and Personality-an Exploratory Analysis of the Mediating Role of Mindfulness Skills. Mindfulness (N Y). 2011;2(3):194-200. [pmid: 21909341].
van Vugt MK, Jha AP. Investigating the impact of mindfulness meditation training on working memory: a mathematical modeling approach. Cogn Affect Behav Neurosci. 2011;11(3):344-53. [pmid: 21732031].
Verma IC, Jayashankarappa BS, Palani M. Effect of transcendental meditation on the performance of some cognitive psychological tests. Indian J Med Res. 1982;76(Suppl):136-43. [pmid: 6764454].
Walach H, Nord E, Zier C, Dietz-Waschkowski B, Kersig S, Schpbach H. Mindfulness-based stress reduction as a method for personnel development: A pilot evaluation. International Journal of Stress Management. 2007;14(2):188-98.
Walia IJ, Mehra P, Grover P, Verma SK, Sanjeev. Health status of nurses and Yoga. II. Subjects with and without-health problems. Nurs J India. 1989;80(10):256-8. 278. [pmid: 2631037].
Wallace RK, Mills PJ, Orme-Johnson DW, Dillbeck MC, Jacobe E. Modification of the paired H reflex through the transcendental meditation and TM-Sidhi program. Exp Neurol. 1983;79(1):77-86. [pmid: 6337056].
Walrath LC, Hamilton DW. Autonomic correlates of meditation and hypnosis. Am J Clin Hypn. 1975;17(3):190-7. [pmid: 1146710].
Wandhofer A, Kobal G, Plattig KH. Decrease of latency of auditory evoked potentials in humans practicing transcendental meditation (author's transl. EEG EMG Z Elektroenzephalogr Elektromyogr Verwandte Geb. 1976;7(2):99-103. [pmid: 829055].
Wang YT. Effects of long term Tai Chi practice and jogging exercise on muscle strength and endurance in older people: Commentary. Br. J. Sports Med. 2006;40(1):54.
Watkins E, Teasdale JD. Adaptive and maladaptive self-focus in depression. J Affect Disord. 2004;82(1):1-8. [pmid: 15465571].
Weissbecker I, Salmon P, Studts JL, Floyd AR, Dedert EA, Sephton SE. Mindfulness-based stress reduction and sense of coherence among women with fibromyalgia. Journal of Clinical Psychology in Medical Settings. 2002;9(4):297-307.
Wenger Ma, Bagchi Bk, Anand Bk. Experiments in India on “voluntary” control of the heart and pulse. Circulation. 1961;24:1319-25. [pmid: 14006121].
Wenk-Sormaz H. Meditation can reduce habitual responding. Adv Mind Body Med. 2005;21(3-4):33-49. [pmid: 20671347].
West MA. Physiological effects of meditation: a longitudinal study. Br J Soc Clin Psychol. 1979;18(2):219-26. [pmid: 378312].
Williams LR, Lodge B, Reddish PS. Effects of transcendental meditation on rotary pursuit skill. Res Q. 1977;48(1):196-201. [pmid: 323947].
Wilson AF, Jevning R, Guich S. Marked reduction of forearm carbon dioxide production during states of decreased metabolism. Physiol Behav. 1987;41(4):347-52. [pmid: 3124144].
Wood CJ. Evaluation of meditation and relaxation on physiological response during the performance of fine motor and gross motor tasks. Percept Mot Skills. 1986;62(1):91-8. [pmid: 3515311].
Woolfolk RL, Lehrer PM, McCann BS, Rooney AJ. Effects of progressive relaxation and meditation on cognitive and somatic manifestations of daily stress. Behav Res Ther. 1982;20(5):461-7. [pmid: 6758758].
Woolfolk RL, Carr-Kaffashan L, McNulty TF, Lehrer PM. Meditation training as a treatment for insomnia. Behavior Therapy. 1976;7(3):359-65.
Xu D, Hong Y, Li J, Chan K. Effect of tai chi exercise on proprioception of ankle and knee joints in old people. Br J Sports Med. 2004;38(1):50-4. [pmid: 14751946].
Yan JH. Tai chi practice reduces movement force variability for seniors. J Gerontol A Biol Sci Med Sci. 1999;54(12):M629-34. [pmid: 10647969].
Yan X, Shen H, Jiang H, et al. External Qi of Yan Xin Qigong induces G2/M arrest and apoptosis of androgen-independent prostate cancer cells by inhibiting Akt and NF-kappa B pathways. Mol Cell Biochem. 2008;310(1-2):227-34. [pmid: 18080802].
Yeh ML, Lee TI, Chen HH, Chao TY. The influences of Chan-Chuang qi-gong therapy on complete blood cell counts in breast cancer patients treated with chemotherapy. Cancer Nurs. 2006;29(2):149-55. [pmid: 16565626].
Yip VYB, Sit JWH, Wong DYS. A quasi-experimental study on improving arthritis self-management for residents of an aged people's home in Hong Kong. 2004;9(2):235-46.
Yong WK, Lee SH, Tae KC, et al. Effectiveness of mindfulness-based cognitive therapy as an adjuvant to pharmacotherapy in patients with panic disorder or generalized anxiety disorder. 2009;26(7):601-6.
Zamarra JW, Schneider RH, Besseghini I, Robinson DK, Salerno JW. Usefulness of the transcendental meditation program in the treatment of patients with coronary artery disease. Am J Cardiol. 1996;77(10):867-70. [pmid: 8623742].
Zeidan F, Martucci KT, Kraft RA, Gordon NS, McHaffie JG, Coghill RC. Brain mechanisms supporting the modulation of pain by mindfulness meditation. J Neurosci. 2011;31(14):5540-8. [pmid: 21471390].
Zettergren KK, Lubeski JM, Viverito JM. Effects of a yoga program on postural control, mobility, and gait speed in community-living older adults: a pilot study. J Geriatr Phys Ther. 2011;34(2):88-94. [pmid: 21937898].

## Not Relevant to Key Questions

Aherne C, Moran AP, Lonsdale C. The effect of mindfulness training on athletes' flow: An initial investigation. The Sport Psychologist. 2011;25(2):177-89.
Alberts HJ, Mulkens S, Smeets M, Thewissen R. Coping with food cravings. Investigating the potential of a mindfulness-based intervention. Appetite. 2010;55(1):160-3. [pmid: 20493913].
Alexander CN, Schneider RH, Staggers F, et al. Trial of stress reduction for hypertension in older African Americans. II. Sex and risk subgroup analysis. Hypertension. 1996;28(2):228-37. [pmid: 8707387].
Alpher VS, Blanton RL. Motivational processes and behavioral inhibition in breath holding. J Psychol. 1991;125(1):71-81. [pmid: 2033561].
Anon. Self-desensitization and meditation in the reduction of public speaking anxiety. Journal of Consulting and Clinical Psychology. 1979;47(3):536-41. [pmid: 43339].
Arch JJ, Craske MG. Mechanisms of mindfulness: emotion regulation following a focused breathing induction. Behav Res Ther. 2006;44(12):1849-58. [pmid: 16460668].
Bagga OP, Gandhi A. A comparative study of the effect of Transcendental Meditation (T.M.) and Shavasana practice on cardiovascular system. Indian Heart J. 1983;35(1):39-45. [pmid: 6343229].
Bahrke MS, Morgan WP. Anxiety reduction following exercise and meditation. Cognitive Therapy and Research. 1978;2(4):323-33.
Banquet JP, Bourzeix JC, Lesevre N. Evoked potentials and vigilance states induced during the course of choice reaction time tests. Rev Electroencephalogr Neurophysiol Clin. 1979;9(3):221-7. [pmid: 392646].
Barovick H. What's so funny? Laughter-yoga fans hail the health benefits of giggling for no reason. Time. 2010;176(11):54. [pmid: 20873409].
Bera TK, Gore MM, Oak JP. Recovery from stress in two different postures and in Shavasana--a yogic relaxation posture. Indian J Physiol Pharmacol. 1998;42(4):473-8. [pmid: 10874346].
Berghmans C, Tarquinio C, Kretsch M. Impact of the therapeutic approach of mindfulness-based stress reduction (MBSR) on psychic health (stress, anxiety, depression) in students: A controlled and randomized pilot study. Impact de l'approche therapeutique de pleine conscience mindfulness-based stress reduction (MBSR) sur la sant psychique (stress, anxiety, depression) chez des etudiants : une etude pilote controle et randomise. 2010;20(1):11-5.
Blanchard EB, Appelbaum KA, Radnitz CL, et al. A controlled evaluation of thermal biofeedback and thermal biofeedback combined with cognitive therapy in the treatment of vascular headache. J Consult Clin Psychol. 1990;58(2):216-24. [pmid: 2186067].
Bormann JE, Carrico AW. Increases in positive reappraisal coping during a group-based mantram intervention mediate sustained reductions in anger in HIV-positive persons. Int J Behav Med. 2009;16(1):74-80. [pmid: 19127438].
Boudette R. Integrating mindfulness into the therapy hour. Eat Disord. 2011;19(1):108-15. [pmid: 21181583].
Bradley BW, McCanne TR. Autonomic responses to stress: the effects of progressive relaxation, the relaxation response, and expectancy of relief. Biofeedback Self Regul. 1981;6(2):235-51. [pmid: 7020779].
Brandon Jeffrey E, Poppen Roger. A Comparison of Behaviorial, Meditation, and Placebo Control Relaxation Training Procedures. Health-Education. 1985;16(5):42-6. 33. [pmid: 3939950].
Broota A, Dhir R. Efficacy of two relaxation techniques in depression. Journal of Personality and Clinical Studies. 1990;6(1):83-90.
Broota A, Sanghvi C. Efficacy of two relaxation techniques in examination anxiety. Journal of Personality and Clinical Studies. 1994;10(1-2):29-35.
Bruning NS, Frew DR. Effects of exercise, relaxation, and management skills training on physiological stress indicators: A field experiment. Journal of Applied Psychology. 1987;72(4):515-21. [pmid: 3316168].
Campbell JF, Stenstrom RJ, Bertrand D. Systematic changes in perceptual reactance induced by physical fitness training. Percept Mot Skills. 1985;61(1):279-84. [pmid: 3900922].
Cardozo B, Thakar AB, Skandhan KP. A clinical study on psyco-somatic management of shukraavrlta vata (premature ejaculation) with rasayana yoga and shirodhara. AYU. 2006;27(4):94-8.
Carlson CR, Bacaseta PE, Simanton DA. A controlled evaluation of devotional meditation and progressive relaxation. Journal of Psychology and Theology. 1988;16(4):362-8.
Carmody J, Olendzki B, Reed G, Andersen V, Rosenzweig P. A dietary intervention for recurrent prostate cancer after definitive primary treatment: results of a randomized pilot trial. Urology. 2008;72(6):1324-8. [pmid: 18400281].
Carson JW, Carson KM, Gil KM, Baucom DH. Self-expansion as a mediator of relationship improvements in a mindfulness intervention. J Marital Fam Ther. 2007;33(4):517-28. [pmid: 17935533].
Carson JW. Mindfulness meditation-based treatment for relationship enhancement. [dissertation]. Dissertation Abstracts International. 2003;63(8-B).
Carter OL, Presti DE, Callistemon C, Ungerer Y, Liu GB, Pettigrew JD. Meditation alters perceptual rivalry in Tibetan Buddhist monks. Curr Biol. 2005;15(11):R412-3. [pmid: 15936259].
Cazard P. Interhemispheric synchronism of parieto-occipital alpha rhythm. Attention and conscious experience. Synchronie interhemispherique des rythmes alpha parieto-occipitaux. Attention et experience consciente. 1974;74(1):7-22.
Chan AS, Han YM, Cheung MC. Electroencephalographic (EEG) measurements of mindfulness-based Triarchic body-pathway relaxation technique: a pilot study. Appl Psychophysiol Biofeedback. 2008;33(1):39-47. [pmid: 18214668].
Chatzisarantis NL, Hagger MS. Mindfulness and the intention-behavior relationship within the theory of planned behavior. Pers Soc Psychol Bull. 2007;33(5):663-76. [pmid: 17440208].
Cheema BS, Marshall PW, Chang D, Colagiuri B, Machliss B. Effect of an office worksite-based yoga program on heart rate variability: a randomized controlled trial. BMC Public Health. 2011;11:578. [pmid: 21771340].
Chen K, He B, Rihacek G, Sigal LH. A pilot trial of external Qigong therapy for arthritis pain. [2]. 2003;9(5):332-5.
Chen K, He B, Rihacek G, Sigal LH. A pilot trial of external Qigong therapy for arthritis. J Clin Rheumatol. 2003;9(5):332-5. [pmid: 17041488].
Chen KW, Marbach JJ. External qigong therapy for chronic orofacial pain. [2]. 2002;8(5):532-4.
Chu L. The benefits of meditation vis-a-vis emotional intelligence, perceived stress and negative mental health. Stress & Health: Journal of the International Society for the Investigation of Stress. 2010;26(2):169-80.
Clark MM, Abrams DB, Niaura RS, Eaton CA, Rossi JS. Self-efficacy in weight management. 1991;59(5):739-44.
Coatsworth JD, Duncan LG, Greenberg MT, Nix RL. Changing parent's mindfulness, child management skills and relationship quality with their youth: Results from a randomized pilot intervention trial. 2010;19(2):203-17.
Colby F. An analogue study of the initial carryover effects of meditation, hypnosis, and relaxation using native college students. Biofeedback Self Regul. 1991;16(2):157-65. [pmid: 1854860].
Cooper S, Oborne J, Newton S, et al. Do breathing exercises (buteyko and pranayama) help to control asthma: a randomised controlled trial. [abstract]. European Respiratory Society Annual Congress 2002. 2002. abstract P1929.
Cooper S, Oborne J, Newton S, et al. Effect of two breathing exercises (Buteyko and pranayama) in asthma: a randomised controlled trial. Thorax. 2003;58(8):674-9. [pmid: 12885982].
Cooper SE, Oborne J, Newton S, et al. The effect of two breathing exercises (Buteyko and Pranayama) on the ability to reduce inhaled corticosteroids in asthma: a randomised controlled trial. [abstract]. American Thoracic Society 99th International Conference. 2003. B023 Poster 924.
Cowger EL, Torrance EP. Further examination of the quality of changes in creative functioning resulting from meditation (Zazen) training. Creative Child & Adult Quarterly. 1982;7(4):211-7.
Crane C, Winder R, Hargus E, Amarasinghe M, Barnhofer T. Effects of Mindfulness-Based Cognitive Therapy on Specificity of Life Goals. 2011:1-8.
Credidio SG. Comparative effectiveness of patterned biofeedback vs meditation training on EMG and skin temperature changes. Behav Res Ther. 1982;20(3):233-41. [pmid: 7046724].
Curiati JA, Bocchi E, Freire JO, et al. Meditation reduces sympathetic activation and improves the quality of life in elderly patients with optimally treated heart failure: a prospective randomized study. J Altern Complement Med. 2005;11(3):465-72. [pmid: 15992231].
Cuthbert B, Kristeller J, Simons R, Hodes R, Lang PJ. Strategies of arousal control: biofeedback, meditation, and motivation. J Exp Psychol Gen. 1981;110(4):518-46. [pmid: 6459406].
da Silva GD, Lorenzi-Filho G, Lage LV. Effects of yoga and the addition of Tui Na in patients with fibromyalgia. J Altern Complement Med. 2007;13(10):1107-13. [pmid: 18166122].
Danusantoso H, Heijnen L. Tai Chi Chuan for people with haemophilia. [1]. [d]. 2001;7(4):437-9.
Dave HR, Srikrishna Ch, Vyas SN, Dave AR. A comparative study on the role of medhya rasayana yoga and dashamula kwathadhara in the management of vatika shirahshula (tension headache). AYU. 2006;27(2):36-40.
de la Fuente Arias M, Granados MS, Justo CF. Efectos de un programa de entrenamiento en conciencia plena (mindfulness) en la autoestima y la inteligencia emocional percibidas. Behavioral Psychology/Psicologia Conductual: Revista Internacional Clinica y De La Salud. 2010;18(2):297-315.
de la Fuente Arias M, Justo CF, Granados MS. Effects of a meditation program (mindfulness) on the measure of alexithymia and social skills. Efectos de un programa de meditacion (mindfulness) en la medida de la alexitimia y las habilidades sociales. 2010;22(3):369-75.
de Santana JS, de Almeida APG, Brandúo PMC. The effect of Ai Chi method in fybromialgic patients. Os efeitos do mtodo Ai Chi em pacientes portadoras da syndrome fibromiílgica. 2010;15(SUPPL. 1):1433-8.
Deberry S, Davis S, Reinhard KE. A comparison of meditation-relaxation and cognitive/behavioral techniques for reducing anxiety and depression in a geriatric population. J Geriatr Psychiatry. 1989;22(2):231-47. [pmid: 2701175].
Delinsky SS, Wilson GT. Mirror exposure for the treatment of body image disturbance. Int J Eat Disord. 2006;39(2):108-16. [pmid: 16231342].
Delmonte MM. Effects of expectancy on physiological responsivity in novice meditators. Biol Psychol. 1985;21(2):107-21. [pmid: 3907725].
Delmonte MM. Response to meditation in terms of physiological, behavioral and self-report measures. Int J Psychosom. 1984;31(2):3-17. [pmid: 6392131].
Dillbeck MC, Bronson EC. Short-term longitudinal effects of the transcendental meditation technique on EEG power and coherence. Int J Neurosci. 1981;14(3-4):147-51. [pmid: 7030999].
Dillbeck MC. The effect of the Transcendental Meditation technique on anxiety level. J Clin Psychol. 1977;33(4):1076-8. [pmid: 336648].
Ditto B, Eclache M, Goldman N. Short-Term Autonomic and Cardiovascular Effects of Mindfulness Body Scan Meditation. Annals of Behavioral Medicine. 2006;32(3):227-34. [pmid: 17107296].
Domino G. Transcendental meditation and creativity: an empirical investigation. J Appl Psychol. 1977;62(3):358-62. [pmid: 324968].
Dosh SA. The treatment of adults with essential hypertension. J. Fam. Pract. 2002;51(1):74-80. [pmid: 11927069].
Downey N. Mindfulness training: The effect of process and outcome instructions on the experience of control and the level of mindfulness among older women. Educational Gerontology. 1991;17(2):97-109.
Dunn BR, Hartigan JA, Mikulas WL. Concentration and mindfulness meditations: unique forms of consciousness?. Appl Psychophysiol Biofeedback. 1999;24(3):147-65. [pmid: 10652635].
Duraiswamy G, Thirthalli J, Nagendra HR, Gangadhar BN. Yoga therapy as an add-on treatment in the management of patients with schizophrenia--a randomized controlled trial. Acta Psychiatr Scand. 2007;116(3):226-32. [pmid: 17655565].
Eifert GH, Heffner M. The effects of acceptance versus control contexts on avoidance of panic-related symptoms. J Behav Ther Exp Psychiatry. 2003;34(3-4):293-312. [pmid: 14972675].
Elson BD, Hauri P, Cunis D. Physiological changes in yoga meditation. Psychophysiology. 1977;14(1):52-7. [pmid: 319471].
Erisman SM, Roemer L. A preliminary investigation of the effects of experimentally induced mindfulness on emotional responding to film clips. Emotion. 2010;10(1):72-82. [pmid: 20141304].
Fan Y, Tang YY, Ma Y, Posner MI. Mucosal immunity modulated by integrative meditation in a dose-dependent fashion. J Altern Complement Med. 2010;16(2):151-5. [pmid: 20105036].
Fang W, Weidong W, Rongrui Z, et al. Clinical observation on physiological and psychological effects of Eight-Section Brocade on type 2 diabetic patients. 2008;28(2):101-5.
Fee RA, Girdano DA. The relative effectiveness of three techniques to induce the trophotropic response. Biofeedback Self Regul. 1978;3(2):145-57. [pmid: 356900].
Feldman G, Greeson J, Senville J. Differential effects of mindful breathing, progressive muscle relaxation, and loving-kindness meditation on decentering and negative reactions to repetitive thoughts. Behav Res Ther. 2010;48(10):1002-11. [pmid: 20633873].
Fiebert MS, Mead TM. Meditation and academic performance. Perceptual and Motor Skills. 1981;53(2):447-50.
Fling S, Thomas A, Gallaher M. Participant characteristics and the effects of two types of meditation vs. quiet sitting. Journal of Clinical Psychology. 1981;37(4):784-90.
Fragoso CM, Grinberg-Zylberbaum J, Perez MAG, Ortiz CA, Loyo JR. Efectos de la meditacion sobre la actividad electrica cerebral. Revista Mexicana De Psicologia. 1999;16(1):101-15.
Franco C, Manas I, Cangas AJ, Moreno E, Gallego J. Reducing teachers' psychological distress through a mindfulness training program. Span J Psychol. 2010;13(2):655-66. [pmid: 20977015].
Franco C, Sola Mdel M, Justo E. Reducing psychological discomfort and overload in Alzheimer's family caregivers through a mindfulness meditation program. Rev Esp Geriatr Gerontol. 2010;45(5):252-8. [pmid: 20541288].
Franco Justo C, de la Fuente Arias M, Salvador Granados M. Impact of a training program in full consciousness (mindfulness) in the measure of growth and personal self-realization. Psicothema. 2011;23(1):58-65. [pmid: 21266143].
Franco Justo C. Reducing stress levels and anxiety in primary-care physicians through training and practice of a mindfulness meditation technique. Reduccion de los niveles de estres y ansiedad en medicos de Atencion Primaria mediante la aplicacion de un programa de entrenamiento en conciencia plena (mindfulness). 2010;42(11):564-70.
Freret N, Ricci L, Murphy S. Recruiting and screening older, transitional to frail adults in congregate living facilities. Appl Nurs Res. 2003;16(2):118-25. [pmid: 12764723].
Fukushima M, Kataoka T, Hamada C, Matsumoto M. Evidence of Qi-gong energy and its biological effect on the enhancement of the phagocytic activity of human polymorphonuclear leukocytes. Am J Chin Med. 2001;29(1):1-16. [pmid: 11321466].
Gallois Ph, Forzy G, Dhont JL. Changements hormonaux durant la relaxation. L'Encéphale: Revue de psychiatrie clinique biologique et thérapeutique. 1984;10(2):79-82.
Gaston L, Crombez JC, Joly J, Hodgins S. Efficacy of imagery and meditation techniques in treating psoriasis. Imagination, Cognition and Personality. 1988;8(1):25-38.
Gaylord SA, Whitehead WE, Coble RS, et al. Mindfulness for irritable bowel syndrome: protocol development for a controlled clinical trial. BMC Complement Altern Med. 2009;9:24. [pmid: 19638214].
Geisler M. Transcendental meditation as a therapeutic tool for drug users. Zeitschrift Fr Klinische Psychologie. 1978;7(4):235-55.
Gilbert GS, Parker JC, Claiborn CD. Differential mood changes in alcoholics as a function of anxiety management strategies. J Clin Psychol. 1978;34(1):229-32. [pmid: 346607].
Gokhan N, Meehan EF, Peters K. The value of mindfulness-based methods in teaching at a clinical field placement. Psychol Rep. 2010;106(2):455-66. [pmid: 20524546].
Goldman BL, Domitor PJ, Murray EJ. Effects of Zen meditation on anxiety reduction and perceptual functioning. J Consult Clin Psychol. 1979;47(3):551-6. [pmid: 393735].
Grant AM, Langer EJ, Falk E, Capodilupo C. Mindful creativity: Drawing to draw distinctions. Creativity Research Journal. 2004;16(2-3):261-5.
Grepmair L, Mitterlehner F, Rother W, Nickel M. Promotion of mindfulness in psychotherapists in training and treatment results of their patients. J Psychosom Res. 2006;60(6):649-50. [pmid: 16731244].
Griffiths TJ, Steel DH, Vaccaro P, Karpman MB. The effects of relaxation techniques on anxiety and underwater performance. International Journal of Sport Psychology. 1981;12(3):176-82.
Gross CR, Kreitzer MJ, Reilly-Spong M, Winbush NY, Schomaker EK, Thomas W. Mindfulness meditation training to reduce symptom distress in transplant patients: rationale, design, and experience with a recycled waitlist. Clin Trials. 2009;6(1):76-89. [pmid: 19254938].
Hakim R, Segal J, Newton R, DuCette J. A fall risk reduction intervention for community-dwelling older adults. Journal of Geriatric Physical Therapy. 2001;24(3):21-2.
Hall EG, Hardy CJ. Ready, aim, fire□Ç^a^relaxation strategies for enhancing pistol marksmanship. Perceptual and Motor Skills. 1991;72(3, Pt 1):775-86.
Hall PD. The effect of meditation on the academic performance of African American college students. Journal of Black Studies. 1999;29(3):408-15.
Hart DE, Means JR. Effects of meditation vs professional reading on students' perceptions of paraprofessional counselors' effectiveness. Psychol Rep. 1982;51(2):479-82. [pmid: 6758012].
Hart J, Kanner H, Gilboa-Mayo R, Haroeh-Peer O, Rozenthul-Sorokin N, Eldar R. Tai Chi Chuan practice in community-dwelling persons after stroke. Int J Rehabil Res. 2004;27(4):303-4. [pmid: 15572994].
Harvey JR. The effect of yogic breathing exercises on mood. J Am Soc Psychosom Dent Med. 1983;30(2):39-48. [pmid: 6350245].
Heppner WL, Kernis MH, Lakey CE, et al. Mindfulness as a means of reducing aggressive behavior: dispositional and situational evidence. Aggress Behav. 2008;34(5):486-96. [pmid: 18464229].
Hillemeier MM, Downs DS, Feinberg ME, et al. Improving women's preconceptional health: findings from a randomized trial of the Strong Healthy Women intervention in the Central Pennsylvania women's health study. Womens Health Issues. 2008;18(6 Suppl):S87-96. [pmid: 19059553].
Holt WR, Caruso JL, Riley JB. Transcendental meditation vs pseudo-meditation on visual choice reaction time. Perceptual and Motor Skills. 1978;46(3, Pt 1).
Hong PY, Lishner DA, Han KH, Huss EA. The positive impact of mindful eating on expectations of food liking. Mindfulness. 2011;2(2):103-13.
Hooper N, Villatte M, Neofotistou E, McHugh L. The effects of mindfulness versus thought suppression on implicit and explicit measures of experiential avoidance. International Journal of Behavioral Consultation and Therapy. 2010;6(3):233-44.
Innes KE, Selfe TK, Alexander GK, Taylor AG. A new educational film control for use in studies of active mind-body therapies: acceptability and feasibility. J Altern Complement Med. 2011;17(5):453-8. [pmid: 21554109].
Jain S, Jain M, Sharma CS. Effect of yoga and relaxation techniques on cardiovascular system. Indian J Physiol Pharmacol. 2010;54(2):183-5. [pmid: 21090538].
Jain S, Shapiro SL, Swanick S, et al. A randomized controlled trial of mindfulness meditation versus relaxation training: effects on distress, positive states of mind, rumination, and distraction. Ann Behav Med. 2007;33(1):11-21. [pmid: 17291166].
Jang HS, Lee MS, Kim MJ, Chong ES. Effects of Qi-therapy on premenstrual syndrome. 2004;114(8):909-21.
Jang HS, Lee MS. Effects of qi therapy (external qigong ) on premenstrual syndrome: a randomized placebo-controlled study. J Altern Complement Med. 2004;10(3):456-62. [pmid: 15253849].
Janowiak JJ, Hackman R. Meditation and college students' self-actualization and rated stress. Psychol Rep. 1994;75(2):1007-10. [pmid: 7862775].
Jensen CG, Vangkilde S, Frokjaer V, Hasselbalch SG. Mindfulness training affects attention-or is it attentional effort?. J Exp Psychol Gen. 2011.
Kabat-Zinn J, Wheeler E, Light T, et al. Part II: Influence of a mindfulness meditation-based stress reduction intervention on rates of skin clearing in patients with moderate to severe psoriasis undergoing phototherapy (UVB) and photochemo-therapy (PUVA). [References]. Constructivism in the Human Sciences. 2003;8(2):85-106.
Katiyar SK, Bihari S. Role of pranayama in rehabilitation of copd patients - a randomized controlled study. Indian Journal of Allergy Asthma Immunology. 2006;20(2):98-104.
Kaviani A, Hatami N, ShafiAbadi A. The impact of mindfulness-based cognitive therapy on the quality of life in non-clinically depressed people. Advances in Cognitive Science. 2008;10(4).
Keller S, Seraganian P. Physical fitness level and autonomic reactivity to psychosocial stress. J Psychosom Res. 1984;28(4):279-87. [pmid: 6481662].
Kember P. The Transcendental Meditation technique and postgraduate academic performance. British Journal of Educational Psychology. 1985;55(2):164-6.
Kepner J. Yoga research and Richard Freeman. Altern Ther Health Med. 2004;10(4):14. [pmid: 15285269].
Kerr D, Gillam E, Ryder J, Trowbridge S, Cavan D, Thomas P. An Eastern art form for a Western disease: randomised controlled trial of yoga in patients with poorly controlled insulin-treated diabetes. Practical Diabetes International. 2002;19(6):164-6.
Khasky AD, Smith JC. Stress, relaxation states, and creativity. Percept Mot Skills. 1999;88(2):409-16. [pmid: 10483629].
Kiken LG, Shook NJ. Looking up: Mindfulness increases positive judgments and reduces negativity bias. Social Psychological and Personality Science. 2011;2(4):425-31.
Kingston J, Chadwick P, Meron D, Skinner TC. A pilot randomized control trial investigating the effect of mindfulness practice on pain tolerance, psychological well-being, and physiological activity. J Psychosom Res. 2007;62(3):297-300. [pmid: 17324679].
Kinoshita K. A study on response of EEG during Zen meditation--alpha-blocking to name calling (author's transl). Seishin Shinkeigaku Zasshi. 1975;77(9):623-58. [pmid: 1243181].
Kirsch I, Henry D. Self-desensitization and meditation in the reduction of public speaking anxiety. J Consult Clin Psychol. 1979;47(3):536-41. [pmid: 43339].
Knox SS. Effect of passive concentration as instructional set for training enhancement of EEG alpha. Percept Mot Skills. 1980;51(3 Pt 1):767-75. [pmid: 7010297].
Koole SL, Govorun O, Cheng CM, Gallucci M. Pulling yourself together: Meditation promotes congruence between implicit and explicit self-esteem. Journal of Experimental Social Psychology. 2009;45(6):1220-6.
Kova-ìi-ì T, Kova-ìi-ì M. Impact of relaxation training according to Yoga in Daily Life-« system on perceived stress after breast cancer surgery. 2011;10(1):16-26.
Kuang AK, Jiang MD, Wang CX, Zhao GS, Xu DH. Research on the mechanism of “Qigong (breathing exercise)”. A preliminary study on its effect in balancing “Yin” and “Yang”, regulating circulation and promoting flow in the meridian system. J Tradit Chin Med. 1981;1(1):7-10. [pmid: 6926699].
Kubose SK. An experimental investigation of psychological aspects of meditation. Psychologia: An International Journal of Psychology in the Orient. 1976;19(1):1-10.
Kuehner C, Huffziger S, Liebsch K. Rumination, distraction and mindful self-focus: effects on mood, dysfunctional attitudes and cortisol stress response. Psychol Med. 2009;39(2):219-28. [pmid: 18485265].
Kugler JE. Meditation and the electroencephalogram. Electroencephalogr Clin Neurophysiol Suppl. 1982;(35):391-8. [pmid: 6749481].
Kumari S, Nath NCB, Nagendra HR. Enhancing emotional competence among managers through SMET. Psychological Studies. 2007;52(2):171-3.
Lee EN. The effects of tai chi exercise program on blood pressure, total cholesterol and cortisol level in patients with essential hypertension. Taehan Kanho Hakhoe Chi. 2004;34(5):829-37. [pmid: 15502448].
Lee KY, Jeong OY. The effect of Tai Chi movement in patients with rheumatoid arthritis. Taehan Kanho Hakhoe Chi. 2006;36(2):278-85. [pmid: 16691045].
Lee MS, Jeong SM, Jang HS, Ryu H, Moon SR. Effects of in vitro and in vivo Qi-therapy on neutrophil superoxide generation in healthy male subjects. 2003;31(4):623-8.
Lee MS, Kim MK, Lee YH. Effects of Qi-therapy (external Qigong) on cardiac autonomic tone: a randomized placebo controlled study. Int J Neurosci. 2005;115(9):1345-50. [pmid: 16048810].
Lee MS, Rim YH, Jeong DM, Kim MK, Joo MC, Shin SH. Nonlinear analysis of heart rate variability during Qi therapy (external Qigong). Am J Chin Med. 2005;33(4):579-88. [pmid: 16173532].
Lee MS, Rim YH, Kang CW. Effects of external Qi-therapy on emotions, electroencephalograms, and plasma cortisol. 2004;114(11):1493-502.
Lehrer PM, Schoicket S, Carrington P, Woolfolk RL. Psychophysiological and cognitive responses to stressful stimuli in subjects practicing progressive relaxation and clinically standardized meditation. Behav Res Ther. 1980;18(4):293-303. [pmid: 7002148].
Leung RW, Alison JA, McKeough ZJ, Peters MJ. A study design to investigate the effect of short-form Sun-style Tai Chi in improving functional exercise capacity, physical performance, balance and health related quality of life in people with Chronic Obstructive Pulmonary Disease (COPD). Contemp Clin Trials. 2011;32(2):267-72. [pmid: 21078418].
Li J, Sharma K, Finkelstein J. Feasibility of computer-assisted Tai Chi education. AMIA Annu Symp Proc. 2005;1027.
Liu X, Miller YD, Burton NW, Brown WJ. Changes in mechanical loading lead to tendonspecific alterations in MMP and TIMP expression: Influence of stress deprivation and intermittent cyclic hydrostatic compression on rat supraspinatus and Achilles tendons. 2010;44(10):704-9.
Liu YS. Analysis of the curative effect of electroacupuncture plus qigong on ulcerative colonitis. J Acu Tuina Sci. 2003;1(2):23.
Liu YS. Analysis on the therapeutic effect of ulcerative colitis treated with electroacupuncture plus qigong. World Journal of Acupuncture-Moxibustion. World J Acup-Moxi: Shi Jie Zhen Jiu Za Zhi. 1998;8(1):3-8.
Liubimov NN. Changes in the electroencephalogram and evoked potentials while using a special form of psychological training (meditation). Fiziol Cheloveka. 1999;25(2):56-66. [pmid: 10500354].
Lu CF, Liao JC, Liu CY, Liu HY, Chang YH. Meditation therapy in the treatment of anxiety disorders. Taiwanese Journal of Psychiatry. 1998;12(4):343-51.
MacLean CR, Walton KG, Wenneberg SR, et al. Effects of the Transcendental Meditation program on adaptive mechanisms: changes in hormone levels and responses to stress after 4 months of practice. Psychoneuroendocrinology. 1997;22(4):277-95. [pmid: 9226731].
Mamatha SD, Gorkal AR. Comparative study of breath holding time in pranayama practitioners, suryanamaskara practitioners and in non-yogic individuals (Biomedicine). 2010;30(3):403.
Maupin EW. Individual Differences In Response To A Zen Meditation Exercise. J Consult Psychol. 1965;29:139-45. [pmid: 14282421].
Maybery DJ, Graham D. The influence of physical and mental training on plasma beta-endorphin level and pain perception after intensive physical exercise. 2001;17(2):121-7.
McGibbon CA, Krebs DE, Wolf SL, Wayne PM, Scarborough DM, Parker SW. Tai Chi and vestibular rehabilitation effects on gaze and whole-body stability. J Vestib Res. 2004;14(6):467-78. [pmid: 15735329].
Mehling WE. Breath therapy for chronic low back pain. 2006;10(2):96-8.
Monk-Turner E, Turner C. Does yoga shape body, mind and spiritual health and happiness: Differences between yoga practitioners and college students. Int J Yoga. 2010;3(2):48-54. [pmid: 21170230].
Morrell EM, Hollandsworth JG Jr. Norepinephrine alterations under stress conditions following the regular practice of meditation. Psychosom Med. 1986;48(3-4):270-7. [pmid: 3517923].
Morse DR, Furst ML. Meditation: an in depth study. J Am Soc Psychosom Dent Med. 1982;29(5):1-96. [pmid: 6757206].
Morse DR, Martin JS, Furst ML, Dubin LL. A physiological and subjective evaluation of neutral and emotionally-charged words for meditation. Part I. J Am Soc Psychosom Dent Med. 1979;26(1):31-8. [pmid: 387680].
Nakamura Y, Lipschitz DL, Landward R, Kuhn R, West G. Two sessions of sleep-focused mind-body bridging improve self-reported symptoms of sleep and PTSD in veterans: A pilot randomized controlled trial. J Psychosom Res. 2011;70(4):335-45. [pmid: 21414453].
Narahari SR, Aggithaya MG, Prasanna KS, Bose KS. An integrative treatment for lower limb lymphedema (elephantiasis). J Altern Complement Med. 2010;16(2):145-9. [pmid: 20180687].
Neumark-Sztainer D, Eisenberg ME, Wall M, Loth KA. Yoga and Pilates: associations with body image and disordered-eating behaviors in a population-based sample of young adults. Int J Eat Disord. 2011;44(3):276-80. [pmid: 20862694].
Oman D, Shapiro SL, Thoresen CE, Flinders T, Driskill JD, Plante TG. Learning from spiritual models and meditation: A randomized evaluation of a college course. Pastoral Psychology. 2007;55(4):473-93.
Oman D, Shapiro SL, Thoresen CE, Plante TG, Flinders T. Meditation lowers stress and supports forgiveness among college students: a randomized controlled trial. J Am Coll Health. 2008;56(5):569-78. [pmid: 18400671].
Ortner CNM, Kilner SJ, Zelazo PD. Mindfulness meditation and reduced emotional interference on a cognitive task. Motivation and Emotion. 2007;31(4):271-83.
Pace TW, Negi LT, Adame DD, et al. Effect of compassion meditation on neuroendocrine, innate immune and behavioral responses to psychosocial stress. Psychoneuroendocrinology. 2009;34(1):87-98. [pmid: 18835662].
Pandey S, Mahato NK, Navale R. Role of self-induced sound therapy: Bhramari Pranayama in tinnitus. Audiological Medicine. 2010;8(3):137-41.
Paty J, Brenot P, Tignol J, Bourgeois M. Evoked cerebral activity (contingent negative variation and evoked potentials) and modified states of consciousness (sleeplike relaxation, transcendential meditation). Ann Med Psychol (Paris). 1978;136(1):143-69. [pmid: 354456].
Paty J, Brenot Ph, Tignol J, Bourgeois M. Cerebral activity (contingent negative variation and evoked potentials) evoked during modified states of consciousness (deep relaxation, transcendental meditation). Annales Medico-Psychologiques. 1978;136(1):143-69. [pmid: 354456].
Puente AE. Psychophysiological investigations on transcendental meditation. Biofeedback Self Regul. 1981;6(3):327-42. [pmid: 7034788].
Puryear HB, Cayce CT, Thurston MA. Anxiety reduction associated with meditation: home study. Percept Mot Skills. 1976;42(43):527-31. [pmid: 790294].
Rakhshaee Z. Effect of three yoga poses (cobra, cat and fish poses) in women with primary dysmenorrhea: a randomized clinical trial. J Pediatr Adolesc Gynecol. 2011;24(4):192-6. [pmid: 21514190].
Rakoviç D, Tomaseviç M, Jovanov E, et al. Electroencephalographic (EEG) correlates of some activities which may alter consciousness: The transcendental meditation technique, musicogenic states, microwave resonance relaxation, healer/healee interaction, and alertness/drowsiness. 1999;23(3):399-412.
Rani NJ. Impact of yoga training on triguna and self-ideal disparity. Psychological Studies. 2007;52(2):174-7.
Rao AV, Krishna DR, Ramanakar TV, Prabhakar MC. Jala Neti' a yoga technique for nasal comfort and hygiene in leprosy patients. Lepr India. 1982;54(4):691-4. [pmid: 7183836].
Rausch SM, Gramling SE, Auerbach SM. Effects of a single session of large-group meditation and progressive muscle relaxation training on stress reduction, reactivity, and recovery. International Journal of Stress Management. 2006;13(3):273-90.
Ray US, Hegde KS, Selvamurthy W. Improvement in muscular efficiency as related to a standard task after yogic exercises in middle aged men. Indian J Med Res. 1986;83:343-8. [pmid: 3733196].
Rejeski WJ, Mihalko SL, Ambrosius WT, Bearon LB, McClelland JW. Weight loss and self-regulatory eating efficacy in older adults: The cooperative lifestyle intervention program. 2011;66 B(3):279-86.
Rogojanski J, Vettese LC, Antony MM. Coping with cigarette cravings: Comparison of suppression versus mindfulness-based strategies. Mindfulness. 2011;2(1):14-26.
Roldan E, Los J, Dostalek C, Bohdanecky Z. Frequency characteristics, distribution and dominance of the EEG during rest and a yogic breathing exercise □□□□□□□□□□□. Activitas Nervosa Superior. 1983;25(3).
Roy DJ. The thistle is a flower? A meditation on seeing the unseen. J Palliat Care. 2011;27(2):67-8. [pmid: 21805940].
Sabel BA. Transcendental Meditation and concentration ability. Perceptual and Motor Skills. 1980;50(3, Pt 1):799-802.
Sadeghi S, Sohrabi F, Delavar A, Borjaali A, Ghassemi GR. Combined effect of anti depressant and mindfulness based group cognitive therapy (MBCT) on psychological well being of divorced women. 2010;28(112).
Sarang SP, Telles S. Immediate effect of two yoga-based relaxation techniques on performance in a letter-cancellation task. Percept Mot Skills. 2007;105(2):379-85. [pmid: 18065059].
Saxena T, Saxena M. The effect of various breathing exercises (pranayama) in patients with bronchial asthma of mild to moderate severity. Int J Yoga. 2009;2(1):22-5. [pmid: 21234211].
Schejbal P, Krner B, Niesel W. An attempt to determine the effects of autogenic training and Transcendental Meditation on the variables of a personality inventory. Psychotherapie Und Medizinische Psychologie. 1978;28(5):158-64. [pmid: 360268].
Schneider B, Ercoli L, Siddarth P, Lavretsky H. Vascular Burden and Cognitive Functioning in Depressed Older Adults. Am J Geriatr Psychiatry. 2011.
Schneider RH, Alexander CN, Staggers F, et al. A randomized controlled trial of stress reduction in African Americans treated for hypertension for over one year. Am J Hypertens. 2005;18(1):88-98. [pmid: 15691622].
Schneider RH, Alexander CN, Staggers F, et al. Long-term effects of stress reduction on mortality in persons > or = 55 years of age with systemic hypertension. 2005;95(9):1060-4.
Schneider RH, Staggers F, Alexander CN, et al. A randomized controlled trial of stress reduction for hypertension in older African Americans. 1995;26(5):820-7.
Schoicket SL, Bertelson AD, Lacks P. Is sleep hygiene a sufficient treatment for sleep-maintenance insomnia?. Behavior Therapy. 1988;19(2):183-90.
Selfridge N. Meditation for fibromyalgia: Yea or nay?. 2011;14(3):34-6.
Severtsen B, Bruya MA. Effects of meditation and aerobic exercise on EEG patterns. J Neurosci Nurs. 1986;18(4):206-10. [pmid: 2943837].
Shapiro SL, Figueredo AJ, Caspi O, et al. Going Quasi: The Premature Disclosure Effect in a Randomized Clinical Trial. 2002;25(6):605-21.
Shapiro SL, Oman D, Thoresen CE, Plante TG, Flinders T. Cultivating mindfulness: effects on well-being. J Clin Psychol. 2008;64(7):840-62. [pmid: 18484600].
Sharma VK, Das S, Mondal S, Goswami U. Comparative effect of Sahaj Yoga on EEG in patients of major depression and healthy subjects. 2007;27(3):95-9.
Sharma VK, Das S, Mondal S, Goswami U. Effect of Sahaj yoga on autonomic functions in healthy subjects and patients of major depression. 2008;28(2):139-41.
Shin TB, Jin SR. The qualitative study of “mindfulness group” toward the self-care and counseling practice of counselor interns. Bulletin of Educational Psychology. 2010;42(1):163-84.
Sime W. A comparison of exercise and meditation in reducing physiological responses to stress. Medicine in Sports and Science. 1977;9:55.
Smith WP, Compton WC, West WB. Meditation as an adjunct to a happiness enhancement program. J Clin Psychol. 1995;51(2):269-73. [pmid: 7797651].
Solberg EE, Ingjer F, Holen A, Sundgot-Borgen J, Nilsson S, Holme I. Stress reactivity to and recovery from a standardised exercise bout: a study of 31 runners practising relaxation techniques. Br J Sports Med. 2000;34(4):268-72. [pmid: 10953899].
Spanos NP, Stam HJ, Rivers SM, Radtke HL. Meditation, expectation and performance on indices of nonanalytic attending. Int J Clin Exp Hypn. 1980;28(3):244-51. [pmid: 6993377].
Spence GB, Cavanagh MJ, Grant AM. The integration of mindfulness training and health coaching: An exploratory study. Coaching: An International Journal of Theory, Research and Practice. 2008;1(2):145-63.
Sridevi K, Sitamma M, Krishna Rao PV. Perceptual organisation and yoga training. Journal of Indian Psychology. 1995;13(2):21-7.
Steinhauser KE, Alexander SC, Byock IR, George LK, Tulsky JA. Seriously ill patients' discussions of preparation and life completion: an intervention to assist with transition at the end of life. Palliat Support Care. 2009;7(4):393-404. [pmid: 19939302].
Stek RJ, Bass BA. Personal adjustment and perceived locus of control among students interested in meditation. Psychol Rep. 1973;32(3):1019-22. [pmid: 4704748].
Steptoe A. New approaches to the management of essential hypertension with psychological techniques. 1978;22(4):339-54.
Stormer-Labonte M, Machemer P, Hardinghaus W. A Meditative Stress-Management-Programm For Psychosomatic Patients. Ein Meditatives Stressbewaltigungsprogramm Bei Psychosomatischen Patienten. 1992;42(12):436-44.
Strijk JE, Proper KI, van der Beek AJ, van Mechelen W. A process evaluation of a worksite vitality intervention among ageing hospital workers. Int J Behav Nutr Phys Act. 2011;8:58. [pmid: 21663610].
Subramanya P, Telles S. Changes in midlatency auditory evoked potentials following two yoga-based relaxation techniques. Clin EEG Neurosci. 2009;40(3):190-5. [pmid: 19715182].
Sudheesh NN, Joseph KP. Investigation into the effects of music and meditation on galvanic skin response. 2000;21(3):158-63.
Surwillo WW, Hobson DP. Brain electrical activity during prayer. Psychol Rep. 1978;43(1):135-43. [pmid: 360259].
Surwit RS, Shapiro D, Good MI. Comparison of cardiovascular biofeedback, neuromuscular biofeedback, and meditation in the treatment of borderline essential hypertension. J Consult Clin Psychol. 1978;46(2):252-63. [pmid: 348731].
Tang YY, Ma Y, Wang J, et al. Short-term meditation training improves attention and self-regulation. Proc Natl Acad Sci U S A. 2007;104(43):17152-6. [pmid: 17940025].
Targ EF, Levine EG. The efficacy of a mind-body-spirit group for women with breast cancer: a randomized controlled trial. Gen Hosp Psychiatry. 2002;24(4):238-48. [pmid: 12100834].
Taylor DN. Effects of a behavioral stress-management program on anxiety, mood, self-esteem, and T-cell count in HIV positive men. Psychol Rep. 1995;76(2):451-7. [pmid: 7667456].
Telles S, Balkrishna A, Maharana K. Effect of yoga and ayurveda on duchenne muscular dystrophy. Indian J Palliat Care. 2011;17(2):169-70. [pmid: 21976863].
Telles S, Maharana K, Balrana B, Balkrishna A. Effects of high-frequency yoga breathing called kapalabhati compared with breath awareness on the degree of optical illusion perceived. Percept Mot Skills. 2011;112(3):981-90. [pmid: 21853784].
Thiede W. Occultism in children and adolescents. Search movements by youth for an orienting world view and possible transcendence--theological observations and reflections. Kinderkrankenschwester. 2005;24(12):510-3. [pmid: 16425894].
Thomas M, Sadlier M, Smith A. A multiconvergent approach to the rehabilitation of patients with chronic fatigue syndrome: a comparative study. Physiotherapy. 2008;94(1):35-42.
Tloczynski J, Malinowski A, Lamorte R. Rediscovering and reapplying contingent informal meditation. Psychologia: An International Journal of Psychology in the Orient. 1997;40(1):14-21.
Tloczynski J. A preliminary study of opening-up meditation college adjustment, and self-actualization. Psychol Rep. 1994;75(1 Pt 2):449-50. [pmid: 7809316].
Travis F, Olson T, Egenes T, Gupta HK. Physiological patterns during practice of the Transcendental Meditation technique compared with patterns while reading Sanskrit and a modern language. Int J Neurosci. 2001;109(1-2):71-80. [pmid: 11699342].
Travis F. Comparison of coherence, amplitude, and eLORETA patterns during Transcendental Meditation and TM-Sidhi practice. Int J Psychophysiol. 2011.
Travis FT, Orme-Johnson DW. EEG coherence and power during Yogic Flying. Int J Neurosci. 1990;54(1-2):1-12. [pmid: 2265953].
Tsang WW, Hui-Chan CW. Effect of 4- and 8-wk intensive Tai Chi Training on balance control in the elderly. Med Sci Sports Exerc. 2004;36(4):648-57. [pmid: 15064593].
Ussher M, Cropley M, Playle S, Mohidin R, West R. Effect of isometric exercise and body scanning on cigarette cravings and withdrawal symptoms. 2009;104(7):1251-7.
Vahia VN, Shetty HK, Motiwala S, Thakkar G, Fernandes L, Sharma JC. Efficacy of meditation in generalized anxiety disorder. Indian J Psychiatry. 1993;35(2):87-91. [pmid: 21743608].
van den Hout MA, Engelhard IM, Beetsma D, et al. EMDR and mindfulness. Eye movements and attentional breathing tax working memory and reduce vividness and emotionality of aversive ideation. J Behav Ther Exp Psychiatry. 2011;42(4):423-31. [pmid: 21570931].
Vandana B, Vaidyanathan K, Saraswathy LA, Sundaram KR, Kumar H. Impact of integrated amrita meditation technique on adrenaline and cortisol levels in healthy volunteers. Evid Based Complement Alternat Med. 2011;2011:379645. [pmid: 21318156].
von Trott P, Wiedemann AM, Ludtke R, Reishauer A, Willich SN, Witt CM. Qigong and exercise therapy for elderly patients with chronic neck pain (QIBANE): a randomized controlled study. J Pain. 2009;10(5):501-8. [pmid: 19231298].
Wachholtz AB, Pargament KI. Migraines and meditation: does spirituality matter?. J Behav Med. 2008;31(4):351-66. [pmid: 18551362].
Wang F, Wang W, Zhang R, et al. Clinical observation on physiological and psychological effects of Eight-Section Brocade on type 2 diabetic patients. J Tradit Chin Med. 2008;28(2):101-5. [pmid: 18652115].
Warber SL, Ingerman S, Moura VL, et al. Healing the heart: a randomized pilot study of a spiritual retreat for depression in acute coronary syndrome patients. Explore (NY). 2011;7(4):222-33. [pmid: 21724155].
Watkins E, Teasdale JD. Adaptive and maladaptive self-focus in depression. J Affect Disord. 2004;82(1):1-8. [pmid: 15465571].
Wenk-Sormaz H. Meditation can reduce habitual responding. Altern Ther Health Med. 2005;11(2):42-58. [pmid: 15819448].
Williams JMG, Russell IT, Crane C, et al. Staying well after depression: Trial design and protocol. BMC Psychiatry. 2010;10.
Wilson AF, Honsberger R, Chiu JT, Novey HS. Transcendental meditation and asthma. Respiration. 1975;32(1):74-80. [pmid: 1118672].
Winzelberg AJ, Luskin FM. The effect of a meditation training in stress levels in secondary school teachers. Stress Medicine. 1999;15(2):69-77.
Wirth DP, Cram JR. Multisite surface electromyography and complementary healing intervention: a comparative analysis. J Altern Complement Med. 1997;3(4):355-64. [pmid: 9449057].
Wolfson L, Whipple R, Derby C, et al. Balance and strength training in older adults: intervention gains and Tai Chi maintenance. J Am Geriatr Soc. 1996;44(5):498-506. [pmid: 8617896].
Wood C. Mood change and perceptions of vitality: a comparison of the effects of relaxation, visualization and yoga. J R Soc Med. 1993;86(5):254-8. [pmid: 8505745].
Xu WS. Meditating on the management of sepsis at early stage of burns. Zhonghua Shao Shang Za Zhi. 2005;21(2):81-2. [pmid: 15938945].
Xu YH, Wang JH, Li HF, Zhu XH, Wang G. Efficacy of integrative respiratory rehabilitation training in exercise ability and quality of life of patients with chronic obstructive pulmonary disease in stable phase: a randomized controlled trial. Zhong Xi Yi Jie He Xue Bao. 2010;8(5):432-7. [pmid: 20456841].
Yan X, Shen H, Jiang H, et al. External Qi of Yan Xin Qigong differentially regulates the Akt and extracellular signal-regulated kinase pathways and is cytotoxic to cancer cells but not to normal cells. Int J Biochem Cell Biol. 2006;38(12):2102-13. [pmid: 16893670].
Yan X, Shen H, Jiang H, et al. External Qi of Yan Xin Qigong Induces apoptosis and inhibits migration and invasion of estrogen-independent breast cancer cells through suppression of Akt/NF-kB signaling. Cell Physiol Biochem. 2010;25(2-3):263-70. [pmid: 20110687].
Yan X, Shen H, Jiang H, et al. External Qi of Yan Xin Qigong induces G2/M arrest and apoptosis of androgen-independent prostate cancer cells by inhibiting Akt and NF-kappa B pathways. Mol Cell Biochem. 2008;310(1-2):227-34. [pmid: 18080802].
Young EC, Brammer C, Owen E, et al. The effect of mindfulness meditation on cough reflex sensitivity. Thorax. 2009;64(11):993-8. [pmid: 19679578].
Yount G, Solfvin J, Moore D, et al. In vitro test of external Qigong. BMC Complement Altern Med. 2004;4:5. [pmid: 15102336].
Zaichkowsky LD, Kamen R. Biofeedback and meditation: effects on muscle tension and locus of control. Percept Mot Skills. 1978;46(3 Pt 1):955-8. [pmid: 353698].
Zautra AJ, Fasman R, Davis MC, Craig AD. The effects of slow breathing on affective responses to pain stimuli: an experimental study. Pain. 2010;149(1):12-8. [pmid: 20079569].
Zeidan F, Johnson SK, Diamond BJ, David Z, Goolkasian P. Mindfulness meditation improves cognition: evidence of brief mental training. Conscious Cogn. 2010;19(2):597-605. [pmid: 20363650].
Zeidan F, Johnson SK, Gordon NS, Goolkasian P. Effects of brief and sham mindfulness meditation on mood and cardiovascular variables. J Altern Complement Med. 2010;16(8):867-73. [pmid: 20666590].
Zeier H. Relaxation by biofeedback controlled respiratory meditation and autogenic training. Z Exp Angew Psychol. 1985;32(4):682-95. [pmid: 3904237].
Zhuo D, Dighe J, Basmajian JV. EMG biofeedback and Chinese ‘Chi Kung’: relaxation effects in patients with low back pain. Physiother. Can. 1983;35(1):13-7.
Zuroff DC, Schwarz JC. Effects of transcendental meditation and muscle relaxation on trait anxiety, maladjustment, locus of control, and drug use. J Consult Clin Psychol. 1978;46(2):264-71. [pmid: 348732].
Zuroff DC, Schwarz JC. Transcendental meditation versus muscle relaxation: A two-year follow-up of a controlled experiment. The American Journal of Psychiatry. 1980;137(10):1229-31. [pmid: 6998304].

## Movement-Based Meditation

Adjunctive T'ai Chi Chih with escitalopram for geriatric depression. Brown University Psychopharmacology Update. 2011;22(5):3-4.
Adler P. The effects of Tai Chi on pain and function in older adults with osteoarthritis. Case Western Reserve University. 2007.
Agte V, Tarwadi K. Sudarshan Kriya yoga for treating type 2 diabetes: a preliminary study. Alternative & Complementary Therapies. 2004;10(4):220-2.
Ahmadi A, Nikbakh M, Arastoo A, Habibi AH. The Effects of a yoga intervention on balance, speed and endurance of walking, fatigue and quality of life in people with multiple sclerosis. 2010;23(1):71-8.
Alp A, Cansever S, Gorgec N, Yurtkuran M, Topsac T. Effects of Tai Chi exercise on functional and life quality assessments in senile osteoporosis. 2009;29(3):687-95.
Amita S, Prabhakar S, Manoj I, Harminder S, Pavan T. Effect of yoga-nidra on blood glucose level in diabetic patients. Indian J Physiol Pharmacol. 2009;53(1):97-101. [pmid: 19810584].
Annapoorna K, Latha KS, Bhat SM, Bhandary PV. Effectiveness of the practice of yoga therapy in anxiety disorders: A randomized controlled trial. Asian J. Psychiatry. 2011;4:S45.
Anon. The effect of ‘QiGong’ training on the rheoencephalogram. Chinese Journal of Sports Medicine. 1993;12(1):55-6.
Armstrong W, Smedley J. Effects of a home-based yoga exercise program on flexibility in older women. Clinical Kinesiology: Journal of the American Kinesiotherapy Association. 2003;57(1):1-6.
Aslan U, Livanelioglu A. The effects of Hatha yoga on flexibility. [Turkish]. Fizyoterapi Rehabilitasyon. 2001;12(1):25-30.
Attanayake AMP, Somarathna KIWK, Vyas GH, Dash SC. Clinical evaluation of selected yogic procedures in individuals with low back pain. AYU. 2010;31(2):245-50. [pmid: 22131719].
Audette JF, Jin YS, Newcomer R, Stein L, Duncan G, Frontera WR. Tai Chi versus brisk walking in elderly women. Age Ageing. 2006;35(4):388-93. [pmid: 16624847].
Baker MA. The effects of Hatha Yoga and self-recording on trait anxiety and locus of control. Dissertation Abstracts International. 1980;41(2-B):680.
Balk JL. Does yoga untie the pretzel of anxiety and depression?. 2009;12(9):100-2.
Balzano J, Burke J, Hoy T, Roberts E, Hakim R. A comparative study of balance measures among elderly persons participating in Tai Chi or structured exercise programs. Journal of Geriatric Physical Therapy. 2002;25(3):44.
Barovick H. What's so funny? Laughter-yoga fans hail the health benefits of giggling for no reason. Time. 2010;176(11):54. [pmid: 20873409].
Barrow DE, Bedford A, Ives G, O'Toole L, Channer KS. An evaluation of the effects of Tai Chi Chuan and Chi Kung training in patients with symptomatic heart failure: a randomised controlled pilot study. Postgrad Med J. 2007;83(985):717-21. [pmid: 17989272].
Belaia NA, Zhuravleva AI, Andreeva VM. Effect of certain asanas used in the system of yoga on the central nervous and cardiovascular systems. Vliiani nekotorykh asan, primeniaemykh po sisteme ¦Éogov, na tsentral'nuiu nervnuiu i serdechno-cosudistuiu sistemy. 1976;0(3):13-8.
Bezerra L, Bottaro M, Reis VM, et al. Effects of yoga on bone metabolism in postmenopausal women. 2010;13(4):58-65.
Bhat R, Ganaraja B, Bhagylakshmi K. Yoga and exercise show beneficial effects on heart rate variability and blood pressure in geriatric hypertensivepatients. J. Gen. Intern. Med. 2010;25:S434.
Bhatnagar OP, Anantharaman V. The effect of yoga training on neuromuscular excitability and muscular relaxation. Neurol India. 1977;25(4):230-2. [pmid: 614510].
Bhatti TI, Gillin JC, Atkinson JH, et al. T'ai chi chih as a treatment for chronic low back pain: a randomized, controlled study (abstract). Alternative Therapies in Health and Medicine. 1998;4(2):90-1.
Bijlani RL. Influence of yoga on brain and behaviour: facts and speculations. Indian J Physiol Pharmacol. 2004;48(1):1-5. [pmid: 15270365].
Blom KC, Baker B, Irvine J, et al. The harmony study: Hypertension analysis of stress reduction using mindfulness meditation and yoga. J. Clin. Hypertens. 2011;13(4):A141.
Blumenthal JA, Emery CF, Madden DJ, et al. Effects of exercise training on bone density in older men and women. J Am Geriatr Soc. 1991;39(11):1065-70. [pmid: 1753043].
Bobby. Effect of Qigong on physical and psychosocial status of Chinese COPD patients: a randomized controlled trial. Hong Kong Polytechnic University (Hong Kong). 2010.
Bosch P. Stress responsiveness and adaptations of the neuroendocrine system in women with rheumatoid arthritis. Arizona State University. 2003.
Boylan M. External Qigong therapy and fibromyalgia -- a pilot study. Journal of the Australian Traditional-Medicine Society. 2007;13(2):105.
Brady Michele Ruggiero. The effects of Hatha yoga and weight training on trait and state anxiety. Dissertation Abstracts International. 2007;67(8-B):4699.
Broota A, Varma R, Singh A. Role of relaxation in hypertension. Journal of the Indian Academy of Applied Psychology. 1995;21(1):29-36.
Bulavin VV, Kliuzhev VM, Kliachkin LM, Lakshmankumar Zuikhin ND, Vlasova TN. Elements of yoga therapy in the combined rehabilitation of myocardial infarct patients in the functional recovery period. Vopr Kurortol Fizioter Lech Fiz Kult. 1993;(4):7-9. [pmid: 8236936].
Cespedes EM, Riveron G, Alonso CA, Gordon L. Evolucion metabolica de pacientes diabeticos tipo 2 sometidos a un tratamiento combinado de dieta y ejercicios yoga. 2002;21(2):98-101.
Caldwell K, Harrison M, Adams M, Triplett NT. Effect of Pilates and taiji quan training on self-efficacy, sleep quality, mood, and physical performance of college students. J Bodyw Mov Ther. 2009;13(2):155-63. [pmid: 19329051].
Canter P, Brazier A. Inconclusive study of yoga and meditation in HIV/AIDS. Focus on Alternative & Complementary Therapies. 2006;11(3):227-8.
Canter P, Gangadhar B. Possible antidepressant effects of yogic breathing during early stage alcohol detoxification. Focus on Alternative & Complementary Therapies. 2006;11(4):318-9.
Cardozo B, Thakar AB, Skandhan KP. A clinical study on psyco-somatic management of shukraavrlta vata (premature ejaculation) with rasayana yoga and shirodhara. AYU. 2006;27(4):94-8.
Carei TR, Fyfe-Johnson AL, Breuner CC, Brown MA. Randomized controlled clinical trial of yoga in the treatment of eating disorders. J Adolesc Health. 2010;46(4):346-51. [pmid: 20307823].
Carei Tiffany Rain. Randomized controlled clinical trial of yoga in the treatment of eating disorders. Dissertation Abstracts International. 2008;68(8-B):5560.
Carrieri-Kohlmann V, Stulbarg S. Yoga for treating shortness of breath in chronic obstructive pulmonary disease (COPD). ClinicalTrials.Gov. 2003.
Carter JJ. Evaluation of a multi-component yoga intervention as adjunct to psychiatric treatment for Vietnam veterans with posttraumatic stress disorder (PTSD): A randomized controlled trial (RCT). Controlled-Trials.Com. 2006.
Chandwani KD, Thornton B, Perkins GH, et al. Yoga improves quality of life and benefit finding in women undergoing radiotherapy for breast cancer. J Soc Integr Oncol. 2010;8(2):43-55. [pmid: 20388445].
Chaudhary AK, Bhatnagar HN, Bhatnagar LK, Chaudhary K. Comparative study of the effect of drugs and relaxation exercise (yoga shavasan) in hypertension. J Assoc Physicians India. 1988;36(12):721-3. [pmid: 3069839].
Cheema BS, Marshall PW, Chang D, Colagiuri B, Machliss B. Effect of an office worksite-based yoga program on heart rate variability: a randomized controlled trial. BMC Public Health. 2011;11:578. [pmid: 21771340].
Chen HH, Yeh ML, Lee FY. The effects of Baduanjin qigong in the prevention of bone loss for middle-aged women. Am J Chin Med. 2006;34(5):741-7. [pmid: 17080541].
Chen KM, Fan JT, Wang HH, Wu SJ, Li CH, Lin HS. Silver yoga exercises improved physical fitness of transitional frail elders. Nurs Res. 2010;59(5):364-70. [pmid: 20808194].
Chen LX. Curative effect of yoga exercise prescription in treating menstrual disorders. 2005;9(4):164-5.
Chen WW, Sun WY. Tai chi chuan, an alternative form of exercise for health promotion and disease prevention for older adults in the community. Int Q Community Health Educ. 1996;16(4):333-9. [pmid: 20841054].
Chen ZX, Lin BL, Chen JY, et al. Effect of Qigong exercise on the contentration of plasma fibronectin. Journal of Guangzhou University of Traditional Chinese Medicine. Guang Zhou Zhong Yi Xue Yuan Xue Bao. 1989;6(1):46. 48.
Chi I, Jordan-Marsh M, Guo M, Xie B, Zhang M. Tai Chi for depression. 2008;(2).
Cho HS. The Effects of Yoga Exercise on Stress and Health status in Clinical Nurses. Korean J Rehabil Nurs. 2004;7(1):15-23.
Cho KL. Effect of Tai Chi on depressive symptoms amongst Chinese older patients with major depression: the role of social support. Med Sport Sci. 2008;52:146-54. [pmid: 18487894].
Christou EA, Yang Y, Rosengren KS. Taiji training improves knee extensor strength and force control in older adults. J Gerontol A Biol Sci Med Sci. 2003;58(8):763-6. [pmid: 12902537].
Chyu MC, James CR, Sawyer SF, et al. Effects of tai chi exercise on posturography, gait, physical function and quality of life in postmenopausal women with osteopaenia: a randomized clinical study. Clin Rehabil. 2010;24(12):1080-90. [pmid: 20702512].
Clark P, Cortese-Jimenez G, Cohen E. Using Reiki, Yoga, meditation or patient education to address physical and psychological symptoms related to chemotherapy-induced peripheral neuropathy: A pilot study. [conference abstract]. Psycho-Oncology. Abstracts From the 8th Annual Conference of the American Psychosocial Oncology Society Anaheim. CA United States. Feb 17-19 2011. 2011.
Coelho CM, Lessa TT, Coelho LAMC, da Silva Scari R, Junior JMN, de Carvalho RM. Ventilatory function in female practitionersof Hatha Yoga. Funcao ventilatoria em mulheres praticantes de Hatha Ioga. 2011;13(4):279-84.
Cohen L. Randomized Controlled Trial of Yoga Among a Multiethnic Sample of Breast Cancer Patients: Effects on Quality of Life. 2008;19(2):129.
Cohen L, Chandwani K, Thornton B, Perkins G, et al. Randomized trial of yoga in women with breast cancer undergoing radiation treatment. Journal of Clinical Oncology. 2006;24(18 Suppl):469s.
Collins LA. Stress management and yoga. Dissertation Abstracts International. 1984;45(1-A):0116.
Cowen V, Adams T. Physical and perceptual benefits of yoga asana practice: results of a pilot study. Journal of Bodywork & Movement Therapies. 2005;9(3):211-9.
Cromwell S. Benefits of Tai Chi for sedentary Mexican-American women. Communicating Nursing Research. 2005;38:259.
Culos-Reed SN, Carlson LE, Daroux LM, Hately-Aldous S. A pilot study of yoga for breast cancer survivors: physical and psychological benefits. Psychooncology. 2006;15(10):891-7. [pmid: 16374892].
Cusumano JA. The short-term psychophysiological effects of Hatha Yoga and progressive relaxation on female Japanese students. Dissertation Abstracts International. 1991;51(10):3333.
Cusumano JA, Robinson SE. The short-term psychophysiological effects of hatha yoga and progressive relaxation on female Japanese students. Applied Psychology: An International Review. 1993;42(1):77-90.
Dahl JC, Lundgren TL, Yardi N. Evaluation of short term ACT psychotherapy and yoga in a RCT trial for refractory seizures in India. Epilepsia. Suppl 6. 2005;46:196.
Danhauer S, Rutherford C, McQuellon R, et al. Restorative yoga as a supportive intervention for women with ovarian or breast cancer. American Psychosocial Oncology Society (APOS) Third Annual Conference. Amelia Island, Florida. 16th-19th February 2006. Psycho-Oncology. 2006;15(1):S72-3.
Dave HR, Srikrishna Ch, Vyas SN, Dave AR. A comparative study on the role of medhya rasayana yoga and dashamula kwathadhara in the management of vatika shirahshula (tension headache). AYU. 2006;27(2):36-40.
de Godoy DV, Bringhenti RL, Severa A, de Gasperi R, Poli LV. Yoga versus aerobic activity: effects on spirometry results and maximal inspiratory pressure. J Bras Pneumol. 2006;32(2):130-5. [pmid: 17273582].
Dechamps A, Onifade C, Decamps A, Bourdel-Marchasson I. Health-related quality of life in frail institutionalized elderly: effects of a cognition-action intervention and Tai Chi. Journal of Aging & Physical Activity. 2009;17(2):236-48. [pmid: 19451671].
Dechamps A, Quintard B, Lafont L. Effects of a short-term tai-chi-chuan mind-body approach on self-efficacy, anxiety and mood among sedentary lifestyle students. [French]. [References]. European Review of Applied Psychology/Revue Europeenne De Psychologie Appliquee. 2008;58(2):125-32.
Deuskar M, Poonawala N, Bhatewara SA. Effect of Yoga Nidra and Applied Relaxation Technique on Steadiness and Performance of Archers. Psychological Studies. 2006;51(1):64-8.
Djelic M, Nesic D, Ilic V, et al. Positive impact of yoga exercise program for female seniors on risk profiles of cardiovascular diseases. Eur. J. Cardiovasc. Prev. Rehabil. 2011;18(1):S31.
Donesky-Cuenco D, Carrieri-Kohlman V, Park SK, Jacobs B. Safety and feasibility of yoga in patients with COPD. [Abstract]. Proceedings of the American Thoracic Society. 2006;A221.
Du ZY, Zhang JZ, Li XG, Di XM. Cardiovascular effect of different ‘QiGong’. Chinese Journal of Sports Medicine. 1992;11(1):32-5.
Dudani U, Gupta HL, Singh SH, Selvamurthy W, Surange SG. Effect of Sahaja yoga on the frequency of seizures in epileptics. 18th International Epilepsy Congress. 1989. 161.
Dvivedi J, Dvivedi S, Mahajan KK, Mittal S, Singhal A. Effect of ‘61-points relaxation technique’ on stress parameters in premenstrual syndrome. Indian J Physiol Pharmacol. 2008;52(1):69-76. [pmid: 18831354].
Engelman SR, Clance PR, Imes S. Self and body-cathexis change in therapy and yoga groups. J Am Soc Psychosom Dent Med. 1982;29(3):77-88. [pmid: 6958667].
Evans AT, Hadler NM. Yoga improved function and reduced symptoms of chronic low-back pain more than a self-care book. ACP J Club. 2006;145(1):16. [pmid: 16813364].
Faber MJ, Bosscher RJ, Chin A, Paw MJ, van Wieringen PC. Effects of exercise programs on falls and mobility in frail and pre-frail older adults: A multicenter randomized controlled trial. Arch Phys Med Rehabil. 2006;87(7):885-96. [pmid: 16813773].
Field T, Diego M, Hernandez-Reif M, Medina L, Delgado J, Hernandez A. Yoga and massage therapy reduce prenatal depression and prematurity.
Flegal KE, Kishiyama S, Zajdel D, Haas M, Oken BS. Adherence to yoga and exercise interventions in a 6-month clinical trial. BMC Complement Altern Med. 2007;7:37. [pmid: 17996075].
Fluge T, Richter J, Fabel H, Zysno E, Weller E, Wagner TO. Long-term effects of breathing exercises and yoga in patients with bronchial asthma. Pneumologie. 1994;48(7):484-90. [pmid: 7937658].
Friedman S. A qigong approach to treating breast cancer. California Journal of Oriental Medicine (CJOM). 2007;18(1):18-9.
Frye B, Scheinthal S, Kemarskaya T, Pruchno R. Tai chi and low impact exercise: effects on the physical functioning and psychological well-being of older people. Journal of Applied Gerontology. 2007;26(5):433-53.
Furian TC, Wagner D, Ritthaler F. Effect of tai chi training equipment on physical performance, ventilatory parameters and balance. Deutsche Zeitschrift Fur Sportmedizin. 1999;50(S1):64.
Galani K, Vyas SN, Dave AR. A clinical study on role of of “Saptasamo yoga and darvyadi yamak malahara” In the management of ekakushtha (psoriasis). AYU. 2009;30(4):415-20.
Galantino M, Capito L, Kane R, Ottey N, Switzer S, Packel L. The effects of Tai Chi and walking on fatigue and body mass index in women living with breast cancer: a pilot study. Rehabilitation Oncology. 2003;21(1):17-22.
Galantino M. Blending traditional and alternative strategies for rehabilitation: measuring functional outcomes and quality of life issues in an AIDS population. Temple University. 1997.
Garfinkel MS, Schumacher HR Jr, Husain A, Levy M, Reshetar RA. Evaluation of a yoga based regimen for treatment of osteoarthritis of the hands. J Rheumatol. 1994;21(12):2341-3. [pmid: 7699639].
Gatts S. Neural mechanisms underlying balance control in Tai Chi. Med Sport Sci. 2008;52:87-103. [pmid: 18487889].
Gatts SK, Woollacott MH. How Tai Chi improves balance: biomechanics of recovery to a walking slip in impaired seniors. Gait Posture. 2007;25(2):205-14. [pmid: 16672187].
Gatts S. Neural and biomechanical mechanisms underlying balance improvement with short term Tai Chi training in balance impaired older adults. University of Oregon. 2005.
Gemmell C, Leathem JM. A study investigating the effects of Tai Chi Chuan: individuals with traumatic brain injury compared to controls. Brain Inj. 2006;20(2):151-6. [pmid: 16421063].
Gharote ML, Ganguly SK. Effects of a nine-week yogic training programme on some aspects of physical fitness of physically conditioned young males. Indian J Med Sci. 1979;33(10):258-63. [pmid: 521103].
Gode JD, Singh RH, Settiwar RM, Gode KD, Udupa KN. Increased urinary excretion of testosterone following a course of yoga in normal young volunteers. Indian J Med Sci. 1974;28(4-5):212-5. [pmid: 4435928].
Gokal R, Shillito L, Maharaj SR. Positive impact of yoga and pranayam on obesity, hypertension, blood sugar, and cholesterol: A pilot assessment. [3]. 2007;13(10):1056-7.
Goncalves LC, Vale RGDS, Barata NJF, Varejao RV, Dantas EHM. Flexibility, functional autonomy and quality of life (QoL) in elderly yoga practitioners. 2011;53(2):158-62.
Gopal A, Mondal S, Gandhi A, Arora S, Bhattacharjee J. Effect of integrated yoga practices on immune responses in examination stress - A preliminary study. Int J Yoga. 2011;4(1):26-32. [pmid: 21654972].
Gopal KS, Anantharaman V, Balachander S, Nishith SD. The cardiorespiratory adjustments in ‘Pranayama’, with and without ‘Bandhas’, in ‘Vajrasana’. Indian J Med Sci. 1973;27(9):686-92. [pmid: 4775468].
Gopal KS, Anantharamn V, Nishith SD, Bhatnagar OP. The effect of yogasanas on muscular tone and cardio-respiratory adjustments. Indian J Med Sci. 1974;28(10):438-43. [pmid: 4466776].
Gopal KS, Bhatnagar OP, Subramanian N, Nishith SD. Effect of yogasanas and pranayamas on blood pressure, pulse rate and some respiratory functions. Indian J Physiol Pharmacol. 1973;17(3):273-6. [pmid: 4788511].
Gopinath KS, Rao R, Raghuram N, et al. Evaluation of yoga therapy as a psychotherapeutic intervention in breast cancer patients on conventional combined modality of treatment. Proceedings of American Society of Clinical Oncology. 2003;22:26.
Gordon L, Morrison EY, McGrowder D, et al. Effect of yoga and traditional physical exercise on hormones and percentage insulin binding receptor in patients with type 2 diabetes. 2008;4(1):35-42.
Gordon L, Morrison EY, McGrowder DA, et al. Changes in clinical and metabolic parameters after exercise therapy in patents with type 2 diabetes. 2008;4(4):427-37.
Gordon LA, Morrison EY, McGrowder DA, et al. Effect of exercise therapy on lipid profile and oxidative stress indicators in patients with type 2 diabetes. 2008;8.
Grover P, Varma VK, Verma SK, Pershad D. Factors influencing treatment acceptance in neurotic patients referred for yoga therapy-;an exploratory study. Indian J Psychiatry. 1989;31(3):250-7. [pmid: 21927394].
Gundling K. A randomised trial of medical Qigong for cancer patients. Focus on Alternative and Complementary Therapies. 2010;15(4):299-300.
Haber D. Yoga as a preventive health care program for white and black elders: an exploratory study. Int J Aging Hum Dev. 1983;17(3):169-76. [pmid: 6671816].
Hackney ME, Earhart GM. Tai Chi improves balance and mobility in people with Parkinson disease. Gait Posture. 2008;28(3):456-60. [pmid: 18378456].
Hakim R, Segal J, Newton R, DuCette J. A fall risk reduction intervention for community-dwelling older adults. Journal of Geriatric Physical Therapy. 2001;24(3):21-2.
Halpern J, Cohen M, Kennedy G. Yoga for improving sleep and life quality in the elderly population. Sleep Biol. Rhythms. 2010;8:A41.
Halpern J, Cohen M, Kennedy G. Yoga for improving sleep and life quality in the elderly population. [Abstract]. Sleep and Biological Rhythms. 2010;8(Suppl 1):A41. [P037].
Hart J, Kanner H, Gilboa-Mayo R, Haroeh-Peer O, Rozenthul-Sorokin N, Eldar R. Tai Chi Chuan practice in community-dwelling persons after stroke. Int J Rehabil Res. 2004;27(4):303-4. [pmid: 15572994].
Hartfiel N, Havenhand J, Khalsa SB, Clarke G, Krayer A. The effectiveness of yoga for the improvement of well-being and resilience to stress in the workplace. Scand J Work Environ Health. 2011;37(1):70-6. [pmid: 20369218].
Haslock I, Monro R, Nagarathna R, Nagendra HR, Raghuram NV. Measuring the effects of yoga in rheumatoid arthritis. [3]. BR. J. Rheumatol. 1994;33(8):787-8. [pmid: 8055212].
He Q, Zhang JZ, Li JZ. The effects of long-term Qi Gong exercise on brain function as manifested by computer analysis. J Tradit Chin Med. 1988;8(3):177-82. [pmid: 3216659].
Hipp A, Heitkamp HC, Rocker K, Schuller H, Dickhuth HH. Effects of yoga on lipid metabolism in patients with coronary artery disease. International Journal of Sports Medicine. 1998;19:S.
Hiraoka A, Kobayashi H, Shimono F, Ohsuga M. Effects of Kai-Gou (air-ball handling), a Qi-Gong strategy, on the biofeedback training for enhancement of the electroencephalographic activity. Japanese Journal of Biofeedback Research. 1997;24:74-8.
Hu X. Effects of Tai Chi on functional fitness and subjective health status in older Japanese returnees from China: A randomized controlled trial. 2007;56(4):409-17.
Huang HC, Liu CY, Huang YT, Kernohan WG. Health education and Tai Chi reduce falls - a one-year follow-up RCT. [abstract]. Irish Journal of Medical Science. 2009;178(Suppl 8):S289.
Huang T, Yang L, Liu C. Reducing the fear of falling among community□ÇÉdwelling elderly adults through cognitive□ÇÉbehavioural strategies and intense Tai Chi exercise: A randomized controlled trial. Journal of Advanced Nursing. 2011;67(5):961-71. [pmid: 21214623].
Hui G, Kaijun N, Yano H, et al. The effect of a new exercise program including Tai Chi Chuan and Kung Fu gymnastics elements for the physical fitness of older subjects who have lower physical fitness - Compared to a well-accepted exercise program. 2007;56(2):241-56.
Hung H, Chen K. Effects of the simplified Tai-Chi exercise program in promoting the health of the urban elderly. [Chinese]. Journal of Evidence-Based Nursing. 2007;3(3):225-35.
Hyeong-Dong Kim, Tae-You Kim, Hyun Dong J, Seon-Tae Son. The Effects of Tai Chi Based Exercise on Dynamic Postural Control of Parkinson's Disease Patients while Initiating Gait. Journal of Physical Therapy Science. 2011;23(2):265-9.
Immink M. A pilot study on yoga and meditation as an adjunct to fitness rehabilitation programs for stroke patients with chronic hemiparesis. Australian New Zealand Clinical Trials Registry (ANZCTR). Http://Www.Anzctr.Org.Au/. 2009.
Immink M. A yoga and meditation program to improve physical function, mood and quality of life in individuals with chronic stroke hemiparesis. Australian New Zealand Clinical Trials Registry (ANZCTR). Http://Www.Anzctr.Org.Au/. 2009.
Innes KE, Selfe TK, Alexander GK, Taylor AG. A new educational film control for use in studies of active mind-body therapies: acceptability and feasibility. J Altern Complement Med. 2011;17(5):453-8. [pmid: 21554109].
Innes KE, Selfe TK, Vishnu A. Association of fructosamine to indices of dyslipidemia in older adults with type 2 diabetes. Diabetes Metab. Syndr. Clin. Res. Rev. 2010.
Irwin MR, Olmstead R. Mitigating Cellular Inflammation in Older Adults: A Randomized Controlled Trial of Tai Chi Chih. Am J Geriatr Psychiatry. 2011.
Jaffe R. Tai Chi retards bone loss and improves muscle strenght. Phys. Sportsmed. 2003;31(4):16-7.
Janelsins MC, Davis PG, Wideman L, et al. Effects of Tai Chi Chuan on insulin and cytokine levels in a randomized controlled pilot study on breast cancer survivors. Clin Breast Cancer. 2011;11(3):161-70. [pmid: 21665136].
Jang HS, Lee MS. Effects of qi therapy (external qigong ) on premenstrual syndrome: a randomized placebo-controlled study. J Altern Complement Med. 2004;10(3):456-62. [pmid: 15253849].
Jatuporn S, Sangwatanaroj S, Saengsiri AO, et al. Short-term effects of an intensive lifestyle modification program on lipid peroxidation and antioxidant systems in patients with coronary artery disease. Clin Hemorheol Microcirc. 2003;29(3-4):429-36. [pmid: 14724371].
Jhansi Rani N. Impact of yoga training on cognitive style and body awareness. Journal of Indian Psychology. 2008;26(1-2):69-78.
Johansson M, Hassmen P, Jouper J. Acute effects of qigong exercise on mood and anxiety. International Journal of Stress Management. 2008;15(2):199-207.
Joseph S, Sridharan K, Patil SK, et al. Study of some physiological and biochemical parameters in subjects undergoing yogic training. Indian J Med Res. 1981;74:120-4. [pmid: 7309176].
Karambelkar PV, Bhole MV, Gharote ML. Effect of Yogic asanas on uropepsin excretion. Indian J Med Res. 1969;57(5):944-7. [pmid: 5195646].
Katiyar SK, Bihari S. Role of pranayama in rehabilitation of copd patients - a randomized controlled study. Indian Journal of Allergy Asthma Immunology. 2006;20(2):98-104.
Kepner J. Yoga research and Richard Freeman. Altern Ther Health Med. 2004;10(4):14. [pmid: 15285269].
Kerr D, Gillam E, Ryder J, Trowbridge S, Cavan D, Thomas P. An Eastern art form for a Western disease: randomised controlled trial of yoga in patients with poorly controlled insulin-treated diabetes. Practical Diabetes International. 2002;19(6):164-6.
Khalsa SB. Evaluation of a yoga breathing meditation as a treatment for chronic insomnia. Biological Psychology. 2006;72(3):232.
Khalsa SB, Cope S. Effects of a yoga lifestyle intervention on performance-related characteristics of musicians: a preliminary study. Med Sci Monit. 2006;12(8):CR325-31. [pmid: 16865063].
Khalsa SB, Shorter SM, Cope S, Wyshak G, Sklar E. Yoga ameliorates performance anxiety and mood disturbance in young professional musicians. Appl Psychophysiol Biofeedback. 2009;34(4):279-89. [pmid: 19657730].
Khare KC, Sanghvi VC, Bhatnagar AD, Khare R. Effect of Yoga in treatment of bronchial asthma. Indian Practitioner. 1991;44(1):23-7.
Khemka SS, Rao NH, Nagarathna R. Immediate effects of two relaxation techniques on healthy volunteers. Indian J Physiol Pharmacol. 2009;53(1):67-72. [pmid: 19810579].
Khumar SS, Kaur P, Kaur S. Effectiveness of Shavasana on depression among university students. Indian Journal of Clinical Psychology. 1993;20(2):82-7.
Kim H. Effects of Tai Chi exercise on the center of pressure trace during obstacle crossing in older adults who are at a risk of falling. Journal of Physical Therapy Science. 2009;21(1):49-54.
Kim H, Han J, Cho Y. The effectiveness of community-based Tai Chi training on balance control during stair descent by older adults. Journal of Physical Therapy Science. 2009;21(4):317-23.
Kimbrough S, Balkin R, Rancich A. The effect of inverted yoga positions on short-term memory. Athletic Insight: The Online Journal of Sport Psychology. 2007;9(2).
Kin SK, Kurosawa K. Effect of Tai Chi on improving physical performance and preventing falling in community-dwelling old women. 2006;21(3):275-9.
Kinney A, Campo R, O'Connor K, et al. Feasibility and acceptability of a randomized trial of tai chi chih in senior female cancer survivors. Psycho-Oncology. 2011;20:235-6.
Klein PT, Adams W. Cardiopulmonary physiotherapeutic applications of taiji (Structured abstract). Cardiopulmonary Physical Therapy. 2004;15(4):5-11.
Kligler B, Homel P, Blank AE, Kenney J, Levenson H, Merrell W. Randomized trial of the effect of an integrative medicine approach to the management of asthma in adults on disease-related quality of life and pulmonary function. Altern Ther Health Med. 2011;17(1):10-5. [pmid: 21614939].
Kolsawalla MB. An experimental investigation into the effectiveness of some yogic variables as a mechanism of change in the value-attitude system. Journal of Indian Psychology. 1978;1(1):59-68.
Kova-ìi-ì T, Kova-ìi-ì M. Impact of relaxation training according to Yoga in Daily Life-« system on perceived stress after breast cancer surgery. 2011;10(1):16-26.
Kovacic T, Kovacic M. Impact of relaxation training according to Yoga In Daily Life(R) system on perceived stress after breast cancer surgery. Integr Cancer Ther. 2011;10(1):16-26. [pmid: 21147813].
Kroner-Herwig B, Hebing G, Van Rijn-Kalkmann U, Frenzel A. The management of chronic tinnitus: Comparison of a cognitive-behavioural group training with yoga. Journal of Psychosomatic Research. 1995;39(2):153-65. [pmid: 7595873].
Krishnamurthy M, Telles S. Effects of Yoga and an Ayurveda preparation on gait, balance and mobility in older persons. Med Sci Monit. 2007;13(12):LE19-20. [pmid: 18049442].
Kuang A, Wang C, Xu D, Qian Y. Research on “anti-aging” effect of qigong. J Tradit Chin Med. 1991;11(2):153-8. [pmid: 1861523].
Kuang AK. Treatment of hypertensive patients with Chi-kung and regular antihypertensive therapy--a comparative study of 4-year treatment results of 135 cases (author's transl). Zhonghua Nei Ke Za Zhi. 1979;18(3):187-91. [pmid: 400334].
Kuang AK, Chen JL, Lu YR. Changes of the sex hormones in female type II diabetics, coronary heart disease, essential hypertension and its relations with kidney deficiency, cardiovascular complications and efficacy of traditional Chinese medicine or qigong treatment. Zhong Xi Yi Jie He Za Zhi. 1989;9(6):331-4. 323. [pmid: 2776274].
Kuang AK, Jiang MD, Wang CX, Zhao GS, Xu DH. Research on the mechanism of “Qigong (breathing exercise)”. A preliminary study on its effect in balancing “Yin” and “Yang”, regulating circulation and promoting flow in the meridian system. J Tradit Chin Med. 1981;1(1):7-10. [pmid: 6926699].
Kuang AK, Wang CX, Zhao GS, et al. Long-term observation on qigong in prevention of stroke--follow-up of 244 hypertensive patients for 18-22 years. J Tradit Chin Med. 1986;6(4):235-8. [pmid: 3600015].
Kuang AX, Wang CX, Xu DH, Qian YC, Huang ML. Study of the anti-aging effect of Qigong. Zhong Xi Yi Jie He Za Zhi = Chinese Journal of Modern Developments in Traditional Medicine / Zhongguo Zhong Xi Yi Jie He Yan Jiu Hui (Chou), Zhong Yi Yan Jiu Yuan, Zhu Ban. 1987;7(8):455-8.
Kuang Anbi, Wang Chongxing, Xu Dinghai, Qian Yuecheng, Huang Meiling. The washback study of Qigong in anti-aging. Zhong Xi Yi Jie He Za Zhi = Chinese Journal of Modern Developments in Traditional Medicine / Zhongguo Zhong Xi Yi Jie He Yan Jiu Hui (Chou), Zhong Yi Yan Jiu Yuan, Zhu Ban. 1987;7(8):455-8.
Kulmatycki L, Burzäski Z. Yoga nidra and Benson's meditative relaxation and anxiety level, anger and depression emotions. Relaksacja joga nidry i medytacji Bensona a poziom leku oraz emocje gniewu i depresji. 2007;21(3):23-8.
Kulpati DD, Kamath RK, Chauhan MR. The influence of physical conditioning by yogasanas and breathing exercises in patients of chronic obstructive lung disease. J Assoc Physicians India. 1982;30(12):865-8. [pmid: 7184909].
Kumari S, Nath NCB, Nagendra HR. Enhancing emotional competence among managers through SMET. Psychological Studies. 2007;52(2):171-3.
Kutner NG, Barnhart H, Wolf SL, McNeely E, Xu T. Self-report benefits of Tai Chi practice by older adults. J Gerontol B Psychol Sci Soc Sci. 1997;52(5):P242-6. [pmid: 9310093].
Kyizom T, Singh S, Singh KP, Tandon OP, Kumar R. Effect of pranayama & yoga-asana on cognitive brain functions in type 2 diabetes-P3 event related evoked potential (ERP). Indian J Med Res. 2010;131:636-40. [pmid: 20516534].
LaDue L. A quantitative study comparing tai chi and traditional balance exercises on emotional well-being, balance control and mobility efficacy in older adults. Walden University. 2009.
Lakshmikanthan C, Alagesan R, Thanikachalam S, et al. Long term effects of yoga on hypertension and/or coronary artery disease. J Assoc Physicians India. 1979;27(12):1055-8. [pmid: 398852].
Lam LC, Chau RC, Wong BM, et al. Interim follow-up of a randomized controlled trial comparing Chinese style mind body (Tai Chi) and stretching exercises on cognitive function in subjects at risk of progressive cognitive decline. Int J Geriatr Psychiatry. 2011;26(7):733-40. [pmid: 21495078].
Latha, Kaliappan KV. Yoga, pranayama, thermal biofeedback techniques in the management of stress and high blood pressure. Journal of Indian Psychology. 1991;9(1-2):36-46.
Latha Dr, Kaliappan KV. Efficacy of yoga therapy in the management of headaches. Journal of Indian Psychology. 1992;10(1-2):41-7.
Latha M, Kaliappan KV. The efficacy of yoga therapy in the treatment of migraine and tension headaches. Journal of the Indian Academy of Applied Psychology. 1987;13(2):95-100.
Lavretsky H, Irwin M. Complementary use of tai chi improves resilience, quality of life, and cognitive function in depressed older adults. 163rd Annual Meeting of the American Psychiatric Association. 2010 May 22-26. New Orleans, LA. 2010:NR3-70.
Lavretsky H, Irwin M. Complementary use of Tai Chi improves resilience, quality of life, and cognitive function in depressed older adults. Biol. Psychiatry. 2010;67(9):58S-9S.
Lee KO, Kim KR, Ahn SH. Effects of a Qigong prenatal education program on anxiety, depression and physical symptoms in pregnant women. Korean Journal of Women Health Nursing. 2006;12(3):240-8.
Lee KY, Jeong OY. The effect of Tai Chi movement in patients with rheumatoid arthritis. Taehan Kanho Hakhoe Chi. 2006;36(2):278-85. [pmid: 16691045].
Lee KYT, Jones AYM, Hui-Chan CWY, Tsang WWN. Kinematics and energy expenditure of sitting T'ai Chi. 2011;17(8):665-8.
Lee LKY, Tim HM, Lee DTF, Woo J. Tai chi and health-related quality of life among Chinese nursing home residents. [abstract]. Quality of Life Research : an International Journal of Quality of Life Aspects of Treatment, Care and Rehabilitation. 2005;14(9):2049.
Lee LY, Lee DT, Woo J. Effect of Tai Chi on state self-esteem and health-related quality of life in older Chinese residential care home residents. J Clin Nurs. 2007 Sep;16(9):1592. Journal of Clinical Nursing. 2007;16(8):1580-2. [pmid: 17655547].
Lee LY, Lee DT, Woo J. Tai Chi and health-related quality of life in nursing home residents. J Nurs Scholarsh. 2009;41(1):35-43. [pmid: 19335676].
Lee MS, Kang CW, Lim HJ, Lee MS. Effects of Qi-training on anxiety and plasma concentrations of cortisol, ACTH, and aldosterone: A randomized placebo-controlled pilot study. 2004;20(5):243-8.
Lee MS, Lee MS, Kim HJ, Moon SR. Qigong reduced blood pressure and catecholamine levels of patients with essential hypertension. Int J Neurosci. 2003;113(12):1691-701. [pmid: 14602541].
Lee MS, Lim HJ, Lee MS. Impact of qigong exercise on self-efficacy and other cognitive perceptual variables in patients with essential hypertension. J Altern Complement Med. 2004;10(4):675-80. [pmid: 15353025].
Lee MS, Rim YH, Jeong DM, Kim MK, Joo MC, Shin SH. Nonlinear analysis of heart rate variability during Qi therapy (external Qigong). Am J Chin Med. 2005;33(4):579-88. [pmid: 16173532].
Lee M, Koo M. Is tai chi exercise programme beneficial for patients with coronary artery disease?. Focus on Alternative & Complementary Therapies. 2011;16(1):60-1.
Leininger P. Physical and psychological effects of yoga exercise on healthy community-dwelling older adult women. Temple University. 2006.
Leung RW, Alison JA, McKeough ZJ, Peters MJ. A study design to investigate the effect of short-form Sun-style Tai Chi in improving functional exercise capacity, physical performance, balance and health related quality of life in people with Chronic Obstructive Pulmonary Disease (COPD). Contemp Clin Trials. 2011;32(2):267-72. [pmid: 21078418].
Li F, Duncan TE, Duncan SC, McAuley E, Chaumeton NR, Harmer P. Enhancing the psychological well-being of elderly individuals through Tai Chi exercise: A latent growth curve analysis. [References]. Structural Equation Modeling. 2001;8(1):53-83.
Li F, Harmer P, Chaumeton N, Duncan T, Duncan S. Tai Chi as a means to enhance self-esteem: a randomized controlled trial. Journal of Applied Gerontology. 2002;21(1):70-89.
Li F, Harmer P, Fisher KJ, et al. Tai Chi and fall reductions in older adults: a randomized controlled trial. J Gerontol A Biol Sci Med Sci. 2005;60(2):187-94. [pmid: 15814861].
Li JP. Effect of ‘QiGong’ on plasma norepinephrine and serotonin in patients with essential hypertension. Chinese Journal of Sports Medicine. 1993;12(3):152-6.
Li JX, Xu DQ, Hong Y. Effects of 16-week Tai Chi intervention on postural stability and proprioception of knee and ankle in older people. Age Ageing. 2008;37(5):575-8. [pmid: 18541612].
Li M, Chen K, Mo Z. Use of qigong therapy in the detoxification of heroin addicts. Altern Ther Health Med. 2002;8(1):50-4. 56. 9. [pmid: 11795622].
Li W, Pi DR, Xing ZH, et al. The clinical observation on the effect of Qigong in treating patients with hypertension caused by liver-yang hyperactivity and Yang hyperactivity-Yin deficiency. Zhong Xi Yi Jie He Za Zhi = Chinese Journal of Modern Developments in Traditional Medicine/Zhongguo Zhong Xi Yi Jie He Yan Jiu Hui (Chou), Zhong Yi Yan Jiu Yuan, Zhu Ban. 1989;9(1):34-5.
Li W, Xin Z, Pi D. Effect of qigong on sympathetico-adrenomedullary function in patients with liver yang exuberance hypertension. Zhong Xi Yi Jie He Za Zhi. 1990;10(5):283-5. 261. [pmid: 2168814].
Li W, Xing Z, Pi D, Li X. Influence of qi-gong on plasma TXB2 and 6-keto-PGF1 alpha in two TCM types of essential hypertension. Hunan Yi Ke Da Xue Xue Bao. 1997;22(6):497-9. [pmid: 10072988].
Li W, Xing Z, Pi D, Wu Y. The efficacy of Qigong training in patients with various TCM types of hypertension. 1996;21(2):123-6.
Liem T. Osteopathy and Hatha Yoga. Osteopathie und (Hatha-)Yoga. 2009;10(1):21-7.
Lin YG. Effects of the skin potential activity and respiratory movement in the practice of Qi-Gong in different postures. Zhong Xi Yi Jie He Za Zhi. 1983;3(5):304-6. [pmid: 6227417].
Linder K, Svardsudd K. Qigong has a relieving effect on stress. Lakartidningen. 2006;103(24-25):1942-5. [pmid: 16838579].
Liu C, Yang KY, Chen WC, Shiang TY, Chuang LR. Effects of Tai Chi Chuan combined with vibration training on the reflex activity of peripheral neuron. 2011;26(4):329-34.
Liu J, Li B, Shnider R. Effects of Tai Chi Training on Improving Physical Function in Patients With Coronary Heart Diseases. 2010;8(2):78-84.
Liu X, Miller YD, Burton NW, Brown WJ. Changes in mechanical loading lead to tendonspecific alterations in MMP and TIMP expression: Influence of stress deprivation and intermittent cyclic hydrostatic compression on rat supraspinatus and Achilles tendons. 2010;44(10):704-9.
Liu XD. Effect of 8-week Tai Chi Chuan on immune function of older people. 2006;10(27):10-2.
Liu YS. Analysis on the therapeutic effect of ulcerative colitis treated with electroacupuncture plus qigong. World Journal of Acupuncture-Moxibustion. World J Acup-Moxi: Shi Jie Zhen Jiu Za Zhi. 1998;8(1):3-8.
Liu YS. Analysis of the curative effect of electroacupuncture plus qigong on ulcerative colonitis. J Acu Tuina Sci. 2003;1(2):23.
Lo RSK, Hui EST, Cheng JOY, Cheng HKT. Benefits of Tai Chi in palliative care for advanced cancer patients. [3]. 2008;22(1):93-4.
Logghe IH, Verhagen AP, Rademaker AC, et al. Explaining the ineffectiveness of a Tai Chi fall prevention training for community-living older people: a process evaluation alongside a randomized clinical trial (RCT). Arch Gerontol Geriatr. 2011;52(3):357-62. [pmid: 20965096].
Lu C, Wang B. A study on effects of aerobics combined with yoga exercise on physical training. 2007;22(10):885-7.
Lu WA, Kuo CD. Comparison of the effects of Tai Chi Chuan and Wai Tan Kung exercises on autonomic nervous system modulation and on hemodynamics in elder adults. Am J Chin Med. 2006;34(6):959-68. [pmid: 17163585].
Lu X, Wang B, Lee Y, Hui-Chan CWY. The effect of sitting Tai Chi on eye-hand coordination in frail older adults|. 2009;24(3):236-9.
Lu ZC. Comparative study on the therapeutic effects of a breathing exercise (qigong), jogging and drug therapy on essential hypertension. Zhong Xi Yi Jie He Za Zhi. 1987;7(8):462-4. 452. [pmid: 3436010].
Lundgren T, Dahl J, Yardi N, Melin L. Acceptance and Commitment Therapy and yoga for drug-refractory epilepsy: a randomized controlled trial. Epilepsy Behav. 2008;13(1):102-8. [pmid: 18343200].
Lv ZC, Yu HP, Liu JW, Mo GM, Zhang YW. Controlled study of qigong, jogging and drug therapy on essential hypertension. Zhong Xi Yi Jie He Za Zhi = Chinese Journal of Modern Developments in Traditional Medicine / Zhongguo Zhong Xi Yi Jie He Yan Jiu Hui (Chou), Zhong Yi Yan Jiu Yuan, Zhu Ban. 1987;7(8):462-4.
Lv Zengchun, Yu Huapei, Liu Jingwen, Mo Guomeng, Zhang Yuwen. The comparative analysis of Qigong, jogging and medical therapy. Zhong Xi Yi Jie He Za Zhi = Chinese Journal of Modern Developments in Traditional Medicine / Zhongguo Zhong Xi Yi Jie He Yan Jiu Hui (Chou), Zhong Yi Yan Jiu Yuan, Zhu Ban. 1987;7(8):462-4.
Macfarlane D, Chou K, Cheng W. Effects of Tai Chi on the physical and psychological well-being of Chinese older women. Journal of Exercise Science & Fitness. 2005;3(2):87-94.
Madhavi S, Raju PS, Reddy MV, et al. Effect of yogic exercises on lean body mass. J Assoc Physicians India. 1985;33(7):465-6. [pmid: 4055664].
Malathi A, Damodaran A, Shah N, Krishnamurthy G, Namjoshi P, Ghodke S. Psychophysiological changes at the time of examination in medical students before and after the practice of yoga and relaxation. Indian J Psychiatry. 1998;40(1):35-40. [pmid: 21494440].
Manjunath NK, Telles S. Influence of yoga & ayurveda on self-rated sleep in a geriatric population. Indian Journal of Medical Research. 2005;121:683-90. [pmid: 15937373].
Manjunath NK, Telles S. Effects of Yoga and an Ayurveda preparation on gait, balance and mobility in older persons. 2007;13(12):LE19-LE20.
Manjunath NK, Telles S. Pulmonary functions following yoga in a community dwelling geriatric population in India. Journal of Indian Psychology. 2006;24(1-2):44-51.
Manocha R. Sahaja yoga in asthma. [2]. 2003;58(9):825-6.
Mao HN, Sha P. Effect of Tai Chi exercise on blood pressure, plasma nitrogen monoxidum and endothelin in hypertensive patients. 2006;10(48):65-7.
Marc I. Integrative approach for tinnitus: Potential for qigong. Focus on Alternative and Complementary Therapies. 2011;16(1):58.
Marc I, Langguth B, Biesinger E. Integrative approach for tinnitus: potential for qigong. Focus on Alternative & Complementary Therapies. 2011;16(1):58-9.
Mathuna D. Tai chi for fall prevention among the elderly. Alternative Therapies in Women's Health. 2005;7(5):33-6.
McGibbon CA, Krebs DE, Parker SW, Scarborough DM, Wayne PM, Wolf SL. Tai Chi and vestibular rehabilitation improve vestibulopathic gait via different neuromuscular mechanisms: preliminary report. BMC Neurol. 2005;5(1):3. [pmid: 15717934].
McGibbon CA, Krebs DE, Wolf SL, Wayne PM, Scarborough DM, Parker SW. Tai Chi and vestibular rehabilitation effects on gaze and whole-body stability. J Vestib Res. 2004;14(6):467-78. [pmid: 15735329].
McIver S. Yoga may help manage binge eating disorder. Focus on Alternative and Complementary Therapies. 2010;15(1):43-4.
Mihay L, Iltzsche E, Tribby A, et al. Balance and perceived confidence with performance of instrumental activities of daily living: a pilot study of Tai Chi inspired exercise with elderly retirement-community dwellers. Physical & Occupational Therapy in Geriatrics. 2003;21(3):75-86.
Mihay L, Boggs K, Breck A, Dokken E, NaThalang G. The effect of Tai Chi inspired exercise compared to strength training: a pilot study. Physical & Occupational Therapy in Geriatrics. 2006;24(3):13-26.
Miles Wr. Oxygen Consumption During Three Yoga-Type Breathing Patterns. J Appl Physiol. 1964;19:75-82. [pmid: 14104293].
Mitchell KS, Mazzeo SE, Rausch SM, Cooke KL. Innovative interventions for disordered eating: evaluating dissonance-based and yoga interventions. Int J Eat Disord. 2007;40(2):120-8. [pmid: 17089413].
Mo FF, Yan RF. A study of QiGong on aged microcirculation disability. Chinese Journal of Geriatrics. 1990;9(2):108.
Moadel AB, Shah C, Patel S, et al. Randomized controlled trial of yoga for symptom management during breast cancer treatment. [abstract]. Proceedings of the American Society of Clinical Oncology. 2003;726.
Moegling K. How Tai Chi Chuan influences health: some observations and results. [German]. Krankengymnastik. 1997;49(6):950-8.
Mollo K, Schaaf R, Benevides T. The use of kripalu yoga to decrease sensory overresponsivity: a pilot study. Sensory Integration Special Interest Section Quarterly. 2008;31(3):1-4.
Monro R, Power J, Coumar A, Nagarathna R, Dandona P. Yoga therapy for NIDDM: A controlled trial. 1992;6(2):66-8.
Morris DM. An evaluation of yoga for the reduction of fall risk factors in older adults. 2008.
Motajova J, Vicenik K. Effect of hatha yoga on heart activity in exercising women. ACT. NERV. SUPER. 1980;22(2):125-6.
Mourya M, Mahajan AS, Singh NP, Jain AK. Effect of slow- and fast-breathing exercises on autonomic functions in patients with essential hypertension. J Altern Complement Med. 2009;15(7):711-7. [pmid: 19534616].
Muralidhara DV, Ranganathan KV. Effect of yoga practice on Cardiac Recovery Index. Indian J Physiol Pharmacol. 1982;26(4):279-83. [pmid: 7152636].
Mustian KM, Katula JA, Roscoe J, Morrow G. The influence of Tai Chi (TC) and support therapy (ST) on fatigue and quality of life (QOL) in women with breast cancer (BC). [abstract]. Annual Meeting Proceedings of the American Society of Clinical Oncology. 2004;760.
Mustian KM, Katula JA, Zhao H. A pilot study to assess the influence of tai chi chuan on functional capacity among breast cancer survivors. J Support Oncol. 2006;4(3):139-45. [pmid: 16553140].
Mustian KM, Palesh OG, Flecksteiner SA. Tai Chi Chuan for breast cancer survivors. Med Sport Sci. 2008;52:209-17. [pmid: 18487900].
Naruka JS, Mathur R, Mathur A. Effect of pranayama practices on fasting blood glucose and serum cholesterol. Indian J Med Sci. 1986;40(6):149-52. [pmid: 3770842].
Nau JY. Heart and tai chi; Viagra and mountaineering. Rev Med Suisse. 2011;7(294):1058-9. [pmid: 21695810].
Naveen KV, Telles S. Yoga and psychosis: Risks and therapeutic potential. Journal of Indian Psychology. 2003;21(1):34-7.
Nespor K. The combination of psychiatric treatment and yoga. Int J Psychosom. 1985;32(2):24-7. [pmid: 3894269].
Ng BHP. Effect of Qigong on physical and psychosocial status of Chinese COPD patients: a randomized controlled trial. [Dissertation]. Hong Kong Polytechnic University (Hong Kong). 2010:135.
Niranjan M, Bhagyalakshmi K, Ganaraja B, Adhikari P, Bhat R. Effects of yoga and supervised integrated exercise on heart rate variability and blood pressure in hypertensive patients. 2009;4(3):139-43.
Nnodim JO, Strasburg D, Nabozny M, et al. Dynamic balance and stepping versus tai chi training to improve balance and stepping in at-risk older adults. J Am Geriatr Soc. 2006;54(12):1825-31. [pmid: 17198486].
Nowakowska C, Fellmann B, Pasek T, Hauser J, Sluzewska A. Evaluation of the effect of relaxation and concentration exercises based on yoga on patients with psychogenic mental disorders. Psychiatr Pol. 1982;16(5-6):365-70. [pmid: 6764258].
O'Grady M, Wolf SL, Barnhart HX, Kutner N, McNeely E. Tai Chi effect on falls in frail older adults. [abstract]. Archives of Physical Medicine and Rehabilitation. 1997;78:1028.
Oh B, Butow P, Mullan B, Clarke SJ, Beale P, Rosenthal D. Randomized clinical trial: The Impact of Medical Qigong (traditional Chinese medicine) on fatique, quality of life, side effects, mood status and inlfammation of cancer patients. [abstarct no. 9565]. Journal of Clinical Oncology: ASCO Annual Meeting Proceedings. 2008;26(15S part I):518.
Oh B, Butow PN, Mullan BA, et al. Effect of medical Qigong on cognitive function, quality of life, and a biomarker of inflammation in cancer patients: a randomized controlled trial. 2011:1-8.
Okoli U, Dehaney M, Hillman A, Robinson M. Can we get away with anything less? Evaluating health promotion interventions: A Tai Chi exercise programme for older people. 2002;4(1):10-3.
Orr R, Tsang T, Lam P, Comino E, Singh MF. Mobility impairment in type 2 diabetes: association with muscle power and effect of Tai Chi intervention. Diabetes Care. 2006;29(9):2120-2. [pmid: 16936164].
Osteras N, Fongen C. Tai Chi reduces pain and improves physical function for people with knee OA. J Physiother. 2010;56(1):57. [pmid: 20500138].
Pages Bolibar E, Climent Barbera J, Iborra Urios J, Rodriguez-Pinero Duran M, Pena Arrebola A. Tai Chi, falls and osteoporosis. [Spanish]. Rehabilitacion. 2005;39(5):230-45.
Pal A, Srivastava N, Tiwari S, et al. Effect of yogic practices on lipid profile and body fat composition in patients of coronary artery disease. Complement Ther Med. 2011;19(3):122-7. [pmid: 21641516].
Palta A. Sahajayoga and quality of life: An empirical study. Journal of Indian Psychology. 2009;27(1-2):21-34.
Panjwani U, Gupta HL, Singh SH, Selvamurthy W, Rai UC. Effect of Sahaja yoga practice on stress management in patients of epilepsy. Indian J Physiol Pharmacol. 1995;39(2):111-6. [pmid: 7649596].
Panjwani U, Selvamurthy W, Singh SH, Gupta HL, Thakur L, Rai UC. Effect of Sahaja yoga practice on seizure control & EEG changes in patients of epilepsy. Indian J Med Res. 1996;103:165-72. [pmid: 9062044].
Patel C. Yoga and biofeedback in the management of ‘stress’ in hypertensive patients. Clin Sci Mol Med Suppl. 1975;2:171s-4s. [pmid: 1077768].
Paterna AA. The effectiveness of a recreational modality (Tai Chi Chuan) in enhancing health status in an older adult population. 2003;124.
Patra S, Telles S. Positive impact of cyclic meditation on subsequent sleep. Med Sci Monit. 2009;15(7):CR375-81. [pmid: 19564829].
Peng Y, He S, Zhang X, Liu G, Xie J. Effects of hypoxia and qigong on urine malondialdehyde, superoxide dismutase and circulating endothelial cell in humans during simulated weightlessness. Space Med Med Eng (Beijing). 1998;11(2):136-8. [pmid: 11543231].
Pereira MM, de Oliveira RJ, Silva MAF, Souza LHR, Vianna LG. Effects of Tai Chi Chuan on knee extensor muscle strength and balance in elderly women. 2008;12(2):121-6.
Phoosuwan M, Kritpet T, Yuktanandana P. The effects of weight bearing yoga training on the bone resorption markers of the postmenopausal women. J Med Assoc Thai. Suppl5. 2009;92:S102-8. [pmid: 19891384].
Pierce S, Rakel D. Is therapeutic yoga helpful for chronic low back pain?. Evidence-Based Practice. 2010;13(8):4.
Posadzki P. Tai chi/qigong improves selected indicators of metabolic syndrome, QoL, depression and perceived stress. Focus Altern. Complement. Ther. 2011;16(2):161-2.
Price A, Meah M, O'Shaughnessy T. A pilot study to compare qiqong exercises with conventional exercises in pulmonary rehabilitation. [Abstract]. Thorax. 2006;61(Suppl 2):ii67. [P032].
Pullen PR, Nagamia SH, Mehta PK, et al. Effects of yoga on inflammation and exercise capacity in patients with chronic heart failure. J Card Fail. 2008;14(5):407-13. [pmid: 18514933].
Pullen PR. The benefits of yoga therapy for heart failure patients. Georgia State University. 2009.
Raghavendra RM, Ajaikumar BS, Patil S, et al. Effects of pretreatment,pharmacologic factors, and yoga intervention on CINV outcomes in breast cancer. [abstract no. 9599]. Journal of Clinical Oncology: ASCO Annual Meeting Proceedings. 2008;26:526.
Raghuraj P, Telles S. Improvement in spatial and temporal measures of visual perception following yoga training. Journal of Indian Psychology. 2002;20(1):23-31.
Rahnama N, Namazizadeh M, Etemadifar M, Bambaeichi E, Arbabzadeh S, Sadeghipour HR. Effects of yoga on depression in women with multiple sclerosis. 2011;29(136).
Raina N, Chakraborty PK, Basit MA, Samarth SN, Singh H. Evaluation of yoga therapy in alcohol dependence syndrome. Indian Journal of Psychiatry. 2001;43(2).
Raju PS, Madhavi S, Prasad KV, et al. Comparison of effects of yoga & physical exercise in athletes. Indian J Med Res. 1994;100:81-6. [pmid: 7927562].
Rakhshaee Z. Effect of Three Yoga Poses (Cobra, Cat and Fish Poses) in Women with Primary Dysmenorrhea: A Randomized Clinical Trial.
Rakhshani A, Maharana S, Raghuram N, Nagendra HR, Venkatram P. Effects of integrated yoga on quality of life and interpersonal relationship of pregnant women. Qual Life Res. 2010;19(10):1447-55. [pmid: 20632115].
Rani K, Tiwari S, Singh U, Agrawal G, Ghildiyal A, Srivastava N. Impact of Yoga Nidra on psychological general wellbeing in patients with menstrual irregularities: A randomized controlled trial. Int J Yoga. 2011;4(1):20-5. [pmid: 21654971].
Rani NJ. Impact of yoga training on triguna and self-ideal disparity. Psychological Studies. 2007;52(2):174-7.
Rani NJ, Rao PVK. Body awareness and yoga training. Perceptual and Motor Skills. 1994;79(3, Pt 1):1103-6.
Ranjbar F, Hemmati L, Rezaei S. The effects of yoga in women with generalized anxiety disorder. [conference abstract]. European Psychiatry. Abstracts of the 19th European Congress of Psychiatry, EPA 2011. Vienna Austria. Conference Start: 20110312 Conference End: 20110315. 2011.
Rao AV, Krishna DR, Ramanakar TV, Prabhakar MC. Jala Neti' a yoga technique for nasal comfort and hygiene in leprosy patients. Lepr India. 1982;54(4):691-4. [pmid: 7183836].
Rao RM, Nagendra HR, Raghuram N, et al. Influence of yoga on postoperative outcomes and wound healing in early operable breast cancer patients undergoing surgery. Int J Yoga. 2008;1(1):33-41. [pmid: 21829282].
Rao RM, Telles S, Nagendra HR, et al. Effects of yoga on natural killer cell counts in early breast cancer patients undergoing conventional treatment. 2008;14(2):LE3-LE4.
Ray US, Hegde KS, Selvamurthy W. Improvement in muscular efficiency as related to a standard task after yogic exercises in middle aged men. Indian J Med Res. 1986;83:343-8. [pmid: 3733196].
Ray US, Mukhopadhyaya S, Purkayastha SS, et al. Effect of yogic exercises on physical and mental health of young fellowship course trainees. Indian J Physiol Pharmacol. 2001;45(1):37-53. [pmid: 11211570].
Razumov AN, Namsaraeva GT, Frolkov VK. Some physiological aspects of the mechanism of action of traditional health-improving methods (Cigun, Indian, and Tibetan Yoga). Vopr Kurortol Fizioter Lech Fiz Kult. 2008;(4):55-9. [pmid: 18819375].
Rendant D, Pach D, Ludtke R, Reisshauer A, Willich S, Witt CM. Qigong versus exercise versus no therapy for patients with chronic neck pain - a randomized controlled trial. Spine. 2010;36(6):419-27. [pmid: 21178832].
Ritter C, Aldridge D. Qigong Yangsheng as a therapeutic approach for the treatment of essential hypertension in comparison with a western muscle relaxation therapy: A randomised, controlled pilot study. Qigong Yangsheng in der anwendung bei essentieller hypertonie im vergleich mit einer westlichen muskelentspannungstherapie: Eine randomisierte, kontrollierte pilotstudie. 2001;16(2):48-63.
Ritter C, Aldridge D. Qigong Yangsheng as a therapeutic approach for the treatment of essential hypertension in comparison with a western muscle relaxation therapy: A randomised, controlled pilot study. Chinesische Medizin. 2001;16(2):48-63.
Robertshawe P. A comparative trial of yoga and relaxation to reduce stress and anxiety. Journal of the Australian Traditional-Medicine Society. 2007;13(4):225.
Robertshawe P. Glutathione and total antioxidant status improved with yoga. Journal of the Australian Traditional-Medicine Society. 2008;14(1):29.
Robertshawe P. Effects of yoga on maternal comfort, labour pain and birth outcomes. Journal of the Australian Traditional-Medicine Society. 2009;15(2):81.
Rogers CE, Keller C, Larkey LK, Ainsworth BE. A Randomized Controlled Trial to Determine the Efficacy of Sign Chi Do Exercise on Adaptation to Aging. Res Gerontol Nurs. 2011:1-13.
Rohini V, Pandey RS, Janakiramaiah N, Gangadhar BN, Vedamurthachar A. A comparative study of full and partial Sudarshan Kriya Yoga (SKY) in major depressive disorder. NIMHANS Journal. 2000;18(1-2):53-7.
Rubenfire M. [Commentary on] Effects of tai chi mind-body movement therapy on functional status and exercise capacity in patients with chronic heart failure: a randomized controlled trial. ACC Current Journal Review. 2005;14(2):35.
Ryu H, Jun CD, Lee BS, Choi BM, Kim HM, Chung HT. Effect of qigong training on proportions of T lymphocyte subsets in human peripheral blood. Am J Chin Med. 1995;23(1):27-36. [pmid: 7598089].
Ryu H, Mo HY, Mo GD, et al. Delayed cutaneous hypersensitivity reactions in Qigong (chun do sun bup) trainees by multitest cell mediated immunity. Am J Chin Med. 1995;23(2):139-44. [pmid: 7572774].
Sahasi G, Mohan D, Kacker C. Effectiveness of yogic techniques in the management of anxiety. Journal of Personality and Clinical Studies. 1989;5(1):51-5.
Sahay BK, Sadasivudu B, Yogi R, et al. Biochemical parameters in normal volunteers before and after yogic practices. Indian J Med Res. 1982;76(Suppl):144-8. [pmid: 7185755].
Sanglier I, Sarazin M, Zinetti J. Tai Chi, body and cognitive rehabilitation of Alzheimer's and related diseases. Soins. 2004;(685):42-3. [pmid: 15208956].
Santana JS, Almeida AP, Brandao PM. The effect of Ai Chi method in fibromyalgic patients. Cien Saude Colet. Suppl 1. 2010;15:1433-8. [pmid: 20640304].
Sareen S, Kumari V, Gajebasia KS, Gajebasia NK. Yoga: a tool for improving the quality of life in chronic pancreatitis. World J Gastroenterol. 2007;13(3):391-7. [pmid: 17230607].
Sathyaprabha TN, Satishchandra P, Pradhan C, et al. Modulation of cardiac autonomic balance with adjuvant yoga therapy in patients with refractory epilepsy. Epilepsy Behav. 2008;12(2):245-52. [pmid: 18024208].
Sattin RW, Easley KA, Wolf SL, Chen Y, Kutner MH. Reduction in fear of falling through intense tai chi exercise training in older, transitionally frail adults. J Am Geriatr Soc. 2005;53(7):1168-78. [pmid: 16108935].
Satyanarayanamurthi Gv, Sastry Pb. A preliminary scientific investigation into some of the unusual physiological manifestations acquired as a result of yogic practices in India. Wien Z Nervenheilkd Grenzgeb. 1958;15(1-4):239-49. [pmid: 13604305].
Schell EJ, Allolio B, Schonecke OW. Physiological and psychological effects of Hatha-yoga exercise in health women. 1994;41(1-4):46-52.
Selfridge N. From padasana to pain relief: Iyengar yoga for chronic low back pain. 2010;13(1):9-11.
Selvamurthy W, Sridharan K, Ray US, et al. A new physiological approach to control essential hypertension. Indian J Physiol Pharmacol. 1998;42(2):205-13. [pmid: 10225047].
Shaffer HJ, LaSalvia TA, Stein JP. Comparing Hatha yoga with dynamic group psychotherapy for enhancing methadone maintenance treatment: a randomized clinical trial. Altern Ther Health Med. 1997;3(4):57-66. [pmid: 9210777].
Shannahoff-Khalsa D. Kundalini yoga meditation for the treatment of OCD. 156th Annual Meeting of the American Psychiatric Association. May 17-22. San Francisco CA. 2003.
Shannahoff-Khalsa D. Kundalini yoga meditation techniques for psychiatric disorders. 157th Annual Meeting of the American Psychiatric Association. 2004 May 1-6. New York, NY. 2004.
Sharma I, Azmi SA, Settiwar RM. Evaluation of the effect of pranayama in anxiety state. Alternative Medicine. 1991;3(4):227-35.
Sharma VK, Das S, Mondal S, Goswami U. Comparative effect of Sahaj Yoga on EEG in patients of major depression and healthy subjects. 2007;27(3):95-9.
Sharma VK, Das S, Mondal S, Goswampi U, Gandhi A. Effect of Sahaj Yoga on depressive disorders. Indian J Physiol Pharmacol. 2005;49(4):462-8. [pmid: 16579401].
Shen CL, Chyu MC, Yeh JK, et al. Effect of green tea and Tai Chi on bone health in postmenopausal osteopenic women: a 6-month randomized placebo-controlled trial. 2011:1-12.
Sherman KJ, Cherkin DC, Erro J, Miglioretti DL, Deyo RA. Comparing yoga, exercise, and a self-care book for chronic low back pain: a randomized, controlled trial. Ann Intern Med. 2005;143(12):849-56. [pmid: 16365466].
Sherman K. Does tai chi chuan improve balance in less robust elderly?. Focus on Alternative & Complementary Therapies. 2006;11(1):54-5.
Spicuzza L, Gabutti A, Porta C, Montano N, Bernardi L. Yoga and chemoreflex response to hypoxia and hypercapnia. Lancet 2000 Nov 4;356(9241):1612. Lancet. 2000;356(9240):1495-6. [pmid: 11081541].
Sridevi K, Krishna Rao PV. Yoga practice and menstrual distress. Journal of the Indian Academy of Applied Psychology. 1996;22(1-2):47-54.
Sridevi K, Sitamma M, Krishna Rao PV. Perceptual organisation and yoga training. Journal of Indian Psychology. 1995;13(2):21-7.
Stenlund T, Ahlgren C, Lindahl B, et al. Cognitively oriented behavioral rehabilitation in combination with Qigong for patients on long-term sick leave because of burnout: REST□ÇöA randomized clinical trial. International Journal of Behavioral Medicine. 2009;16(3):294-303. [pmid: 19148765].
Stevinson C. Preliminary results suggest that yoga can alleviate depression. Focus on Alternative & Complementary Therapies. 2001;6(1):27-8.
Stevinson C. Inconclusive trial on yoga for anxiety among breast cancer patients: Commentary. Focus Altern. Complement. Ther. 2009;14(2):123-4.
Straus S. A 16-week tai chi programme prevented falls in healthy older adults. Evid Based Med. 2008;13(2):54. [pmid: 18375707].
Streeter CC, Whitfield TH, Owen L, et al. Effects of yoga versus walking on mood, anxiety, and brain GABA levels: a randomized controlled MRS study. J Altern Complement Med. 2010;16(11):1145-52. [pmid: 20722471].
Streeter CC, Whitfield TH, Rein T, Ciraulo DA, Renshaw PF, Jensen E. Correlations between mood and brain gaba levels after yoga and walking. 163rd Annual Meeting of the American Psychiatric Association. 2010 May 22-26. New Orleans, LA. 2010.
Suksom D, Siripatt A, Lapo P, Patumraj S. Effects of two modes of exercise on physical fitness and endothelial function in the elderly: exercise with a flexible stick versus Tai Chi. J Med Assoc Thai. 2011;94(1):123-32. [pmid: 21425738].
Sun GC, Lovejoy J, Bradley R, Putiri A, Gillham S. Qigong therapy vs progressive resistance exercise in patients with type 2 diabetes: A pilot study. FASEB J. 2009;23(S1).
Sun WY, Dosch M, Gilmore GD, Pemberton W, Scarseth T. Effects of a Tai Chi Chuan program on Hmong American older adults. Educational Gerontology. 1996;22(2):161-7.
Sundar S, Agrawal SK, Singh VP, Bhattacharya SK, Udupa KN, Vaish SK. Role of yoga in management of essential hypertension. Acta Cardiol. 1984;39(3):203-8. [pmid: 6331698].
Szabo A, Mesko A, Caputo A, Gill T. Examination of exercise-induced feeling states in four modes of exercise. International Journal of Sport Psychology. 1998;29(4):376-90.
Taboonpong S, Puthsri N, Kong-In W, Saejew A. The effects of Tai Chi on sleep quality, well-being and physical performances among older adults. Thai Journal of Nursing Research. 2008;12(1):1-13.
Taylor-Piliae RE, Newell KA, Cherin R, Lee MJ, King AC, Haskell WL. Effects of Tai Chi and Western exercise on physical and cognitive functioning in healthy community-dwelling older adults. J Aging Phys Act. 2010;18(3):261-79. [pmid: 20651414].
Telles S, Balkrishna A. Yoga and diet change influence renal functions in the obese. Med Sci Monit. 2010;16(10):LE15. [pmid: 20885359].
Telles S, Balkrishna A, Maharana K. Effect of yoga and ayurveda on duchenne muscular dystrophy. Indian J Palliat Care. 2011;17(2):169-70. [pmid: 21976863].
Telles S, Hanumanthaiah BH, Nagarathna R, Nagendra HR. Plasticity of motor control systems demonstrated by yoga training. Indian J Physiol Pharmacol. 1994;38(2):143-4. [pmid: 8063362].
Telles S, Joshi M, Dash M, Raghuraj P, Naveen KV, Nagendra HR. An evaluation of the ability to voluntarily reduce the heart rate after a month of yoga practice. Integr Physiol Behav Sci. 2004;39(2):119-25. [pmid: 15759599].
Telles S, Maharana K, Balrana B, Balkrishna A. Effects of high-frequency yoga breathing called kapalabhati compared with breath awareness on the degree of optical illusion perceived. Percept Mot Skills. 2011;112(3):981-90. [pmid: 21853784].
Telles S, Nagarathna R, Vani PR, Nagendra HR. A combination of focusing and defocusing through yoga reduces optical illusion more than focusing alone. Indian J Physiol Pharmacol. 1997;41(2):179-82. [pmid: 9142567].
Telles S, Praghuraj P, Ghosh A, Nagendra HR. Effect of a one-month yoga training program on performance in a mirror-tracing task. Indian J Physiol Pharmacol. 2006;50(2):187-90. [pmid: 17051740].
Telles S, Singh N. High frequency yoga breathing increases energy -expenditure from carbohydrates. Comment to: Assessment of sleep patterns, energy expenditure and circadian rhythms of skin temperature in patients with acute coronary syndrome Hadil Al Otair, Mustafa Al-shamiri, Mohammed Bahobail, Munir M. Sharif, Ahmed S. BaHammam Med Sci Monit, 2011; 17(7): CR397-403. Med Sci Monit. 2011;17(9):LE7-8. [pmid: 21873954].
Telles S, Nagarathna R, Nagendra HR. Improvement in visual perception following yoga training. Journal of Indian Psychology. 1995;13(1):30-2.
Thomas GN, Hong AW, Tomlinson B, et al. Effects of Tai Chi and resistance training on cardiovascular risk factors in elderly Chinese subjects: a 12-month longitudinal, randomized, controlled intervention study. Clin Endocrinol (Oxf). 2005;63(6):663-9. [pmid: 16343101].
Thomas M, Sadlier M, Smith A. A multiconvergent approach to the rehabilitation of patients with chronic fatigue syndrome: a comparative study. Physiotherapy. 2008;94(1):35-42.
Toise S, Sears SF, Schoenfeld MH, et al. The efficacy of adapted yoga in managing anxiety and depression in implantable cardioverter defibrillator (ICD) patients. [conference abstract]. Heart Rhythm. Abstracts From the 32nd Annual Scientific Sessions of the Heart Rhythm Society, Heart Rhythm San Francisco. CA United States. May 4-7 2011. 2011.
Tsai P. RIG sponsored biobehavioral symposium: use of Tai Chi to reduce cognitive deficits in elders -- a pilot study. Southern Online Journal of Nursing Research. 2008;8(2):2p.
Tsang T, Orr R, Lam P, Comino E, Singh MF. Effects of Tai Chi on glucose homeostasis and insulin sensitivity in older adults with type 2 diabetes: a randomised double-blind sham-exercise-controlled trial. Age Ageing. 2008;37(1):64-71. [pmid: 17965035].
Tsang WW, Hui-Chan CW. Effect of 4- and 8-wk intensive Tai Chi Training on balance control in the elderly. Med Sci Sports Exerc. 2004;36(4):648-57. [pmid: 15064593].
Udani JK, Ofman JJ. Tai Chi for the prevention of falls in the elderly. 1998;1(4):167-9.
Udupa KN, Singh RH, Settiwar RM. A comparative study on the effect of some individual yogic practices in normal persons. Indian J Med Res. 1975;63(8):1066-71. [pmid: 1213802].
Udupa KN, Singh RH, Settiwar RM. Studies on the effect of some yogic breathing exercises (Pranayams) in normal persons. Indian J Med Res. 1975;63(8):1062-5. [pmid: 1213801].
Vadiraja HS, Raghavendra RM. Effects of a yoga program on cortisol rhythm and mood states in early breast cancer patients undergoing adjuvant radiotherapy: A randomized controlled trial. (Integrative Cancer Therapies (2009) 8, 1, (37-46) DOI: 10.1177/1534735409331456). 2009;8(2):195.
van Montfrans GA, Karemaker JM, Wieling W, Dunning AJ. Relaxation therapy and continuous ambulatory blood pressure in mild hypertension: a controlled study. BMJ. 1990;300(6736):1368-72. [pmid: 2196946].
Van Puymbroeck M, Payne LL, Hsieh PC. A phase I feasibility study of yoga on the physical health and coping of informal caregivers. Evid Based Complement Alternat Med. 2007;4(4):519-29. [pmid: 18227920].
Vancampfort D, De Hert M, Knapen J, et al. State anxiety, psychological stress and positive well-being responses to yoga and aerobic exercise in people with schizophrenia: a pilot study. Disabil Rehabil. 2011;33(8):684-9. [pmid: 20718623].
Vedamurthachar A, Janakiramaiah N, Hegde JM, et al. Antidepressant efficacy and hormonal effects of Sudarshana Kriya Yoga (SKY) in alcohol dependent individuals. J Affect Disord. 2006;94(1-3):249-53. [pmid: 16740317].
Vedanthan PK. Clinical study of yoga techniques in university students with asthma: A controlled study. 1998;19(1):3-9.
Verma KK, Varstala V, Kytokorpi L, Telama R. The effects of a three-week hatha yoga programme on the reduction of anxiety level and neck and shoulder pain. Liikunnan Ja Kansanterveyden Julkaisuja. 1990;(67):229.
Vijayalakshmi S, Satyanarayana M, Krishna Rao PV, Prakash V. Combined effect of yoga and psychotherapy on management of asthma: A preliminary study. Journal of Indian Psychology. 1988;7(2):32-9.
Visceglia E, Lewis S. Yoga therapy as an adjunctive treatment for schizophrenia: a randomized, controlled pilot study. J Altern Complement Med. 2011;17(7):601-7. [pmid: 21711202].
von Trott P, Wiedemann AM, Ludtke R, Reishauer A, Willich SN, Witt CM. Qigong and exercise therapy for elderly patients with chronic neck pain (QIBANE): a randomized controlled study. J Pain. 2009;10(5):501-8. [pmid: 19231298].
Voukelatos A, Cumming RG, Lord SR, Rissel C. A randomized, controlled trial of tai chi for the prevention of falls: the Central Sydney tai chi trial. J Am Geriatr Soc. 2007;55(8):1185-91. [pmid: 17661956].
Wallsten S, Bintrim K, Denman D, Parrish J, Hughes G. The effect of Tai Chi Chuan on confidence and lower extremity strength and balance in residents living independently at a continuing care retirement community. Journal of Applied Gerontology. 2006;25(1):82-95.
Wang C. Tai Chi improves pain and functional status in adults with rheumatoid arthritis: results of a pilot single-blinded randomized controlled trial. Med Sport Sci. 2008;52:218-29. [pmid: 18487901].
Wang C, Xu D, Qian Y. Medical and health care Qigong (Qu Bing Yang Sheng Gong). J Tradit Chin Med. 1991;11(4):296-301. contd. [pmid: 1795547].
Wang CX, Xu DH. Influence of qigong therapy upon serum HDL-C in hypertensive patients. Zhong Xi Yi Jie He Za Zhi. 1989;9(9):543-4. 516. [pmid: 2688940].
Wang CX, Xu DH. The beneficial effect of qigong on the ventricular function and microcirculation in deficiency of heart-energy hypertensive patients. Zhong Xi Yi Jie He Za Zhi. 1991;11(11):659-60. 644. [pmid: 1813167].
Wang CX, Xu DH, Qian YS, Zhao GS, Kuang AK. The influence of qigong therapy upon serum HDL-C of hypertensive patients. Zhong Xi Yi Jie He Za Zhi = Chinese Journal of Modern Developments in Traditional Medicine / Zhongguo Zhong Xi Yi Jie He Yan Jiu Hui (Chou), Zhong Yi Yan Jiu Yuan, Zhu Ban. 1989;9(9):543-4.
Wang CX, You CY. The efficacy of qigong (breathing exercise) and antihypertensive drug therapy in 426 hypertensive patients and changes in plasma dopamine-beta-hydroxylase activity. Zhong Xi Yi Jie He Za Zhi. 218. 1982;2(4):195-9. [pmid: 6222834].
Wang CX. XDQYSW. Observation on the effect of QiGong on Serum Apolipoprotein in patients with Hypertension. Shanghai Journal of Traditional Chinese Medicine (Shang Hai Zhong Yi Yao Za Zhi). 1993;39(5):22-3.
Wang MY, An LG. Effects of 12 weeks' tai chi chuan practice on the immune function of female college students who lack physical exercise. 2011;28(1):45-9.
Wang W, Sawada M, Noriyama Y, Arita K, Ota T, Kishimoto T. Effects of Qigong in Tai Chi in the elderly using General Health Questionnaire (GHQ). 2009;60(5-6):159-65.
Wayne P, McGibbon C, Scarborough D, et al. Tai chi improves dynamic postural stability in patients with vestibular disease: results of a randomized trial. Journal of Alternative & Complementary Medicine. 2006;12(2):214.
Wiholm C, Arnetz B. Stress management and musculoskeletal disorders in knowledge workers: The possible mediating effects of stress hormones. 2006;8(1):5-14.
Williams KA, Petronis J, Smith D, et al. Effect of Iyengar yoga therapy for chronic low back pain. Pain. 2005;115(1-2):107-17. [pmid: 15836974].
Wolf SL, Barnhart HX, Ellison GL, Coogler CE. The effect of Tai Chi Quan and computerized balance training on postural stability in older subjects. Atlanta FICSIT Group. Frailty and Injuries: Cooperative Studies on Intervention Techniques. Phys Ther. 1997;77(4):371-81. discussion 382-4. [pmid: 9105340].
Wolf SL, Barnhart HX, Kutner NG, McNeely E, Coogler C, Xu T. Reducing frailty and falls in older persons: An investigation of Tai Chi and computerized balance training. 1996;44(5):489-97.
Wolf SL, O'Grady M, Easley KA, Guo Y, Kressig RW, Kutner M. The influence of intense Tai Chi training on physical performance and hemodynamic outcomes in transitionally frail, older adults. J Gerontol A Biol Sci Med Sci. 2006;61(2):184-9. [pmid: 16510864].
Wolf SL, Sattin RW, Kutner M, O'Grady M, Greenspan AI, Gregor RJ. Intense tai chi exercise training and fall occurrences in older, transitionally frail adults: a randomized, controlled trial. J Am Geriatr Soc. 2003;51(12):1693-701. [pmid: 14687346].
Wolfgang WJ, Mayer-Berger J, Kettner C, et al. Randomized controlled trial of long-term use of yoga and progressive relaxation in cardiovascular rehabilitation. European Journal of Cardiovascular Prevention and Rehabilitation. 2010;17:S58.
Wood C. Mood change and perceptions of vitality: a comparison of the effects of relaxation, visualization and yoga. J R Soc Med. 1993;86(5):254-8. [pmid: 8505745].
Wu G, Keyes L, Callas P, Ren X, Bookchin B. Comparison of telecommunication, community, and home-based Tai Chi exercise programs on compliance and effectiveness in elders at risk for falls. Arch Phys Med Rehabil. 2010;91(6):849-56. [pmid: 20510973].
Xie J, Lin YH, Guo CR, Chen F. Study on influences of yoga on quailty of life of schizophrenic inpatients. Nanfang Journal of Nursing. 2006;13(1):9-10.
Xiong HF, Long YD, Xu SM, Liu PF, Xiong Zh, Wang KY. A study on the mechanism of QiGong(breathing exercise) in the treatment of coronary heart disease. Chinese Journal of Sports Medicine. 1983;2(3):29-34.
Xu H, Lawson D, Kras A. A study on Tai Ji exercise and traditional Chinese medical modalities in relation to bone structure, bone function and menopausal symptoms. J. Chin. Med. 2004;(74):10-4.
Xu H, Lawson D, Kras A. A study on Tai Ji exercise and traditional Chinese medical modalities in relation to bone structure, bone function and menopausal symptoms. Journal of Chinese Medicine. 2004;(74):3-7.
Yang Y, Verkuilen J, Rosengren KS, et al. Effects of a traditional Taiji/Qigong curriculum on older adults' immune response to influenza vaccine. Med Sport Sci. 2008;52:64-76. [pmid: 18487887].
Yao Q, Yujun T, Cunzhe Q. Effect of short wave infrared qigong information therapy on chronic active hepatitis. Chinese Journal of Infectious Diseases. 1986;4(Suppl 2):64-7.
Yeh GY, Mietus JE, Peng CK, et al. Enhancement of sleep stability with Tai Chi exercise in chronic heart failure: preliminary findings using an ECG-based spectrogram method. Sleep Med. 2008;9(5):527-36. [pmid: 17689142].
Yeh GY, Wayne PM, Phillips RS. T'ai Chi exercise in patients with chronic heart failure. Med Sport Sci. 2008;52:195-208. [pmid: 18487899].
Yeh GY, Wood MJ, Lorell BH, Jha AK. Benefits of Tai Chi for elderly patients with congestive heart failure. J. Clin. Outcomes Manage. 2004;11(11):690-1.
Yeh GY, Wood MJ, Lorell BH, et al. Heart failure patients improve quality of life and exercise capacity with tai chi. 2005;10(1):50-1.
Yogendra J, Yogendra HJ, Ambardekar S, et al. Beneficial effects of yoga lifestyle on reversibility of ischaemic heart disease: caring heart project of International Board of Yoga. J Assoc Physicians India. 2004;52:283-9. [pmid: 15636328].
Youshan W, Wei L, Deren P, Zhihua X, Jinhui X. Laboratory study of Qigong therapy for patients with essential hypertension. 1993;18(3):269-71.
Yurtkuran M, Alp A, Yurtkuran M, Dilek K. A modified yoga-based exercise program in hemodialysis patients: a randomized controlled study. Complement Ther Med. 2007;15(3):164-71. [pmid: 17709061].
Zeeuwe PEM, Verhagen AP, Bierma-Zeinstra SMA, Van Rossum E, Faber MJ, Koes BW. The effect of Tai Chi Chuan in reducing falls among elderly people: Design of a randomized clinical trial in the Netherlands [ISRCTN98840266]. 2006;6.
Zhang BL, Song KZ, Zhang JX, Xie JS, Wang CM. Counteracting effect of hypoxia and Qigong on cardiac rhythm during orthostatic test post simulated weightlessness. Space Med Med Eng (Beijing). 1999;12(1):59-61. [pmid: 11765777].
Zhang LT, Shen FD, Ji ZH, Luo XL, Qi FJ, Fan JY, et al. Clinical study on Yigan qigong in the treatment of chronic hepatitis B. Chinese Journal of Integrated Traditional & Western Medicine on Liver Diseases. 1993;3(1):7-9.
Zhao J, Zhang L, Tian Y. Effect of 6 months of Tai Chi Chuan and calcium supplementation on bone health in females aged 50-59 years. Journal of Exercise Science & Fitness. 2007;5(2):88-94.
Zhou MR, Lian MR. Observation of qi-gong treatment in 60 cases of pregnancy-induced hypertension. Zhong Xi Yi Jie He Za Zhi. 1989;9(1):16-8. 4. 5. [pmid: 2776267].
Zhuo D, Dighe J, Basmajian JV. EMG biofeedback and Chinese ‘Chi Kung’: relaxation effects in patients with low back pain. Physiother. Can. 1983;35(1):13-7.
Zhuo D, Dighe J, Basmajian J. EMG biofeedback and Chinese “Chi Kung”: relaxation effects in patients with low back pain. Physiotherapy Canada. 1983;35(1):13-8.

## Other

Abstracts: archives journals. JAMA: Journal of the American Medical Association. 2006;296(6):633-5.
Retraction. Preliminary study of the effects of Tai Chi and Qigong medical exercise on indicators of metabolic syndrome and glycaemic control in adults with raised blood glucose levels. Br J Sports Med. 2010;44(8):608. [pmid: 20547669].
Abrams AI, Siegel LM. The Transcendental Meditation program and rehabilitation at Folsom State Prison: A cross-validation study. Criminal Justice and Behavior. 1978;5(1):3-20.
Agte V, Tarwadi K. Sudarshan Kriya yoga for treating type 2 diabetes: a preliminary study. Alternative & Complementary Therapies. 2004;10(4):220-2.
Alberts HJ, Thewissen R. The Effect of a Brief Mindfulness Intervention on Memory for Positively and Negatively Valenced Stimuli. Mindfulness (N Y). 2011;2(2):73-7. [pmid: 21660085].
Alexander CN, Swanson GC, Rainforth MV, Carlisle TW. Effects of the transcendental meditation program on stress reduction, health, and employee development: A prospective study in two occupational settings. Anxiety, Stress & Coping: An International Journal. 1993;6(3):245-62.
Anderson VL. The effects of meditation on teacher perceived occupational stress and trait anxiety. Dissertation Abstracts International. 1996;57(3-A):934.
Anderson VL, Levinson EM, Barker W, Kiewra KR. The Effects of Meditation on Teacher Perceived Occupational Stress, State and Trait Anxiety, and Burnout 1. 1999;14(1):3-25.
Andrew J, Winzelberg Ma, Frederic M, Luskin MS. The effect of a meditation training in stress levels in secondary school teachers. 1999;15(2):69-77.
Anon. The effects of meditation on selected measures of human potential. Dissertation Abstracts International. 1982;42(11-A):4717.
Anon. Meditation-based treatment for binge-eating disorder. Http://Www.Clinicaltrials.Gov. 2003.
Anon. Meditation or education for Alzheimer caregivers or meditation for Alzheimer caregivers. Http://Www.Clinicaltrials.Gov. 2007.
Anon. Mindfulness meditation as a rehabilitation strategy for persons with schizophrenia. Http://Wwwclinicaltrialsgov. 2009.
Anthony W Jr. An evaluation of meditation as a stress reduction technique for persons with spinal cord injury. Dissertation Abstracts International. 1986;46(11):3251.
Arcari P. Efficacy of a workplace smoking cessation program: mindfulness meditation vs cognitive-behavioral interventions. Boston College. 1996.
Arch JJ, Craske MG. Mechanisms of mindfulness: emotion regulation following a focused breathing induction. Behav Res Ther. 2006;44(12):1849-58. [pmid: 16460668].
Berghmans C, Tarquinio C, Kretsch M. Impact of the therapeutic approach of mindfulness-based stress reduction (MBSR) on psychic health (stress, anxiety, depression) in students: A controlled and randomized pilot study. Impact de l'approche therapeutique de pleine conscience mindfulness-based stress reduction (MBSR) sur la sant psychique (stress, anxiety, depression) chez des etudiants : une etude pilote controle et randomise. 2010;20(1):11-5.
Blom KC, Baker B, Irvine J, et al. The harmony study: Hypertension analysis of stress reduction using mindfulness meditation and yoga. J. Clin. Hypertens. 2011;13(4):A141.
Brach AW. Clinical applications of meditation: A treatment outcome evaluation study of an intervention for binge eating among the obese that combines formal meditation and contingent formal and informal meditation. Dissertation Abstracts International. 1992;52(7-B):3898.
Britton Willoughby B. Meditation and depression. Dissertation Abstracts International. 2007;68(5-B):3387.
Broota A, Dhir R. Efficacy of two relaxation techniques in depression. Journal of Personality and Clinical Studies. 1990;6(1):83-90.
Broota A, Sanghvi C. Efficacy of two relaxation techniques in examination anxiety. Journal of Personality and Clinical Studies. 1994;10(1-2):29-35.
Brown LL, Robinson SE. The relationship between meditation and/or exercise and three measures of self-actualization. Journal of Mental Health Counseling. 1993;15(1):85-93.
Butler LD, Spiegel D. Meditation and hypnosis for chronic depressed mood. Controlled-Trials.Com. 2006.
Calderon R Jr. Effects of nonpharmacological approaches on cholesterol levels in mild hypertensive African Americans: A pilot study of the Transcendental Meditation program and a health education program. 2000.
Canter P, Gangadhar B. Possible antidepressant effects of yogic breathing during early stage alcohol detoxification. Focus on Alternative & Complementary Therapies. 2006;11(4):318-9.
Carlson CR, Bacaseta PE, Simanton DA. A controlled evaluation of devotional meditation and progressive relaxation. Journal of Psychology and Theology. 1988;16(4):362-8.
Carmody J, Olendzki B, Reed G, Andersen V, Rosenzweig P. A dietary intervention for recurrent prostate cancer after definitive primary treatment: results of a randomized pilot trial. Urology. 2008;72(6):1324-8. [pmid: 18400281].
Chan AS, Han YM, Cheung MC. Electroencephalographic (EEG) measurements of mindfulness-based Triarchic body-pathway relaxation technique: a pilot study. Appl Psychophysiol Biofeedback. 2008;33(1):39-47. [pmid: 18214668].
Chang J, Midlarsky E, Lin P. Effects of meditation on music performance anxiety. Medical Problems of Performing Artists. 2003;18(3):126-30.
Chhabra AK. The effect of self-aware meditation on stress in Indian immigrants living in the United States. Dissertation Abstracts International: Section B: The Sciences and Engineering. 2011;71(10-B):6435.
Chu L. The benefits of meditation vis-a-vis emotional intelligence, perceived stress and negative mental health. Stress & Health: Journal of the International Society for the Investigation of Stress. 2010;26(2):169-80.
Cohen-Katz J, Wiley S, Capuano T, Baker DM, Deitrick L, Shapiro S. The effects of mindfulness-based stress reduction on nurse stress and burnout: a qualitative and quantitative study, part III. Holist Nurs Pract. 2005;19(2):78-86. [pmid: 15871591].
Colby F. An analogue study of the initial carryover effects of meditation, hypnosis, and relaxation using naive college students. Biofeedback & Self Regulation. 1991;16(2):157-65. [pmid: 1854860].
Comer James F. Meditation and progressive relaxation in the treatment of test anxiety. Dissertation Abstracts International. 1978;38(12-B):6142-3.
Cooper S, Oborne J, Newton S, et al. Do breathing exercises (buteyko and pranayama) help to control asthma: a randomised controlled trial. [abstract]. European Respiratory Society Annual Congress 2002. 2002. abstract P1929.
Cooper SE, Oborne J, Newton S, et al. The effect of two breathing exercises (Buteyko and Pranayama) on the ability to reduce inhaled corticosteroids in asthma: a randomised controlled trial. [abstract]. American Thoracic Society 99th International Conference. 2003. B023 Poster 924.
Cropley M, Ussher M, Charitou E. Acute effects of a guided relaxation routine (body scan) on tobacco withdrawal symptoms and cravings in abstinent smokers. 2007;102(6):989-93.
Curiati JA, Bocchi E, Freire JO, et al. Meditation reduces sympathetic activation and improves the quality of life in elderly patients with optimally treated heart failure: a prospective randomized study. J Altern Complement Med. 2005;11(3):465-72. [pmid: 15992231].
da Silva GD, Lorenzi-Filho G, Lage LV. Effects of yoga and the addition of Tui Na in patients with fibromyalgia. J Altern Complement Med. 2007;13(10):1107-13. [pmid: 18166122].
De Jong-Meyer R, Parthe T, Projektgruppe. The influence of mindfulness exercises and decentring on rumination and specificity of autobiographical memory. Einfluss von achtsamkeitsbung und dezentrierung auf rumination und spezifitñt autobiographischererinnerungen. 2009;38(4):240-9.
De La Arias JF, Justo CF, Manas I. Results of a program on mindfulness on the emotional situation of university students. Efectos de un programa de entrenamiento en conciencia plena (mindfulness)en el estado emocional de estudiantes universitarios. 2010;(19):31-52.
de la Fuente Arias M, Justo CF, Granados MS. Effects of a meditation program (mindfulness) on the measure of alexithymia and social skills. Efectos de un programa de meditacion (mindfulness) en la medida de la alexitimia y las habilidades sociales. 2010;22(3):369-75.
de la Fuente M, Franco C, Salvador M. Reduction of blood pressure in a group of hypertensive teachers through a program of mindfulness meditation. Reduccion de la presion arterial en un grupo de docentes hipertensos mediante un programa de entrenamiento en conciencia plena (mindfulness). 2010;18(3):533-52.
Deberry S. The Effects Of Meditation-Relaxation On Anxiety And Depression In A Geriatric Population. Psychotherapy. 1982;19(4):512-21.
Deberry S, Davis S, Reinhard KE. A comparison of meditation-relaxation and cognitive/behavioral techniques for reducing anxiety and depression in a geriatric population. J Geriatr Psychiatry. 1989;22(2):231-47. [pmid: 2701175].
DeBlassie PA. Christian meditation: A clinical investigation. Dissertation Abstracts International. 1981;42(3-B):1167.
Delgado LC, Guerra P, Perakakis P, Viedma MI, Robles H, Vila J. Human values education and mindfulness meditation as a tool for emotional regulation and stress prevention for teachers: An efficiency study. Eficacia de un programa de entrenamiento en conciencia plena (mindfulness) y valores humanos como herramienta de regulacion emocional y prevencion del estres para profesores. 2010;18(3):511-33.
Delgado LC, Guerra P, Perakakis P, Viedma MaI, Robles H, Vila J. Eficacia de un programa de entrenamiento en conciencia plena (mindfulness) y valores humanos como herramienta de regulacion emocional y prevencion del estres para profesores. Behavioral Psychology/Psicologia Conductual: Revista Internacional Clinica y De La Salud. 2010;18(3):511-32.
Diner MD. The differential effects of meditation and systematic desensitization on specific and general anxiety. Dissertation Abstracts International. 1978;39(4-B):1950.
Downey N. Mindfulness training: The effect of process and outcome instructions on the experience of control and the level of mindfulness among older women. Educational Gerontology. 1991;17(2):97-109.
Duncan L, Weissenburger D. Effects of a Brief Meditation Program on Well-being and Loneliness. TCA Journal. 2003;31(1):4-14.
Duraiswamy G, Thirthalli J, Nagendra HR, Gangadhar BN. Yoga therapy as an add-on treatment in the management of patients with schizophrenia--a randomized controlled trial. Acta Psychiatr Scand. 2007;116(3):226-32. [pmid: 17655565].
Ellett L, Freeman D, Garety PA. The psychological effect of an urban environment on individuals with persecutory delusions: the Camberwell walk study. Schizophr Res. 2008;99(1-3):77-84. [pmid: 18061407].
English EH, Baker TB. Relaxation training and cardiovascular response to experimental stressors. Health Psychology. 1983;2(3):239-59.
Erisman SM, Roemer L. A preliminary investigation of the effects of experimentally induced mindfulness on emotional responding to film clips. Emotion. 2010;10(1):72-82. [pmid: 20141304].
Evans S, Cousins L, Tsao JC, Sternlieb B, Zeltzer LK. Protocol for a randomized controlled study of Iyengar yoga for youth with irritable bowel syndrome. Trials. 2011;12:15. [pmid: 21244698].
Evans S, Cousins L, Tsao JC, Subramanian S, Sternlieb B, Zeltzer LK. A randomized controlled trial examining Iyengar yoga for young adults with rheumatoid arthritis: a study protocol. Trials. 2011;12:19. [pmid: 21255431].
Faber MJ, Bosscher RJ, Chin A, Paw MJ, van Wieringen PC. Effects of exercise programs on falls and mobility in frail and pre-frail older adults: A multicenter randomized controlled trial. Arch Phys Med Rehabil. 2006;87(7):885-96. [pmid: 16813773].
Fang W, Weidong W, Rongrui Z, et al. Clinical observation on physiological and psychological effects of Eight-Section Brocade on type 2 diabetic patients. 2008;28(2):101-5.
Fjellman-Wiklund A, Stenlund T, Steinholtz K, Ahlgren C. Take charge: Patients' experiences during participation in a rehabilitation programme for burnout. J Rehabil Med. 2010;42(5):475-81. [pmid: 20544160].
Franco C, Sola MadM, Justo E. Reduccion del malestar psicoligico y de la sobrecarga en familiares cuidadores de enfermos de Alzheimer mediante la aplicacion de un programa de entrenamiento en mindfulness (conciencia plena). Revista Espanola De Geriatria y Gerontologia. 2010;45(5):252-8. [pmid: 20541288].
Franco Justo C. Reducing stress levels and anxiety in primary-care physicians through training and practice of a mindfulness meditation technique. Reduccion de los niveles de estres y ansiedad en medicos de Atencion Primaria mediante la aplicacion de un programa de entrenamiento en conciencia plena (mindfulness). 2010;42(11):564-70.
Franco Justo C. Reduccion de la percepcion del estres en estudiantes de magisterio mediante la praíctica de la meditacion fluir. Apuntes De Psicologia. 2009;27(1):99-109.
Frisvold MH. The “midlife study”: Mindfulness as an intervention to change health behaviors in midlife women. University of Minnesota. 2009.
Fukushima M, Kataoka T, Hamada C, Matsumoto M. Evidence of Qi-gong energy and its biological effect on the enhancement of the phagocytic activity of human polymorphonuclear leukocytes. Am J Chin Med. 2001;29(1):1-16. [pmid: 11321466].
Galani K, Vyas SN, Dave AR. A clinical study on role of of “Saptasamo yoga and darvyadi yamak malahara” In the management of ekakushtha (psoriasis). AYU. 2009;30(4):415-20.
Garcia-Trujillo MR, De Rivera JLG. Physiological changes induced by meditation and deep relaxation. Cambios Fisiologicos Durante Los Ejercicios De Meditacion Y Relajacion Profunda. 1992;13(6-7):57-63.
Geisler M. Transcendental meditation as a therapeutic tool for drug users. Zeitschrift Fr Klinische Psychologie. 1978;7(4):235-55.
Gilmore JV. Relative effectiveness of meditation and autogenic training for the self-regulation of anxiety. Dissertation Abstracts International. 1985;45(8-B):2686.
Gordon L, Morrison EY, McGrowder DA, et al. Changes in clinical and metabolic parameters after exercise therapy in patents with type 2 diabetes. 2008;4(4):427-37.
Gordon LA, Morrison EY, McGrowder DA, et al. Effect of exercise therapy on lipid profile and oxidative stress indicators in patients with type 2 diabetes. 2008;8.
Greene YN, Hiebert B. A comparison of mindfulness meditation and cognitive self-observation. Canadian Journal of Counselling. 1988;22(1):25-34.
Griffiths TJ, Steel DH, Vaccaro P, Karpman MB. The effects of relaxation techniques on anxiety and underwater performance. International Journal of Sport Psychology. 1981;12(3):176-82.
Gross CR, Kreitzer MJ, Reilly-Spong M, Winbush NY, Schomaker EK, Thomas W. Mindfulness meditation training to reduce symptom distress in transplant patients: rationale, design, and experience with a recycled waitlist. Clin Trials. 2009;6(1):76-89. [pmid: 19254938].
Gururaja D, Harano K, Toyotake I, Kobayashi H. Effect of yoga on mental health: Comparative study between young and senior subjects in Japan. Int J Yoga. 2011;4(1):7-12. [pmid: 21654969].
Heeren A, Philippot P. Changes in ruminative thinking mediate the clinical benefits of mindfulness: Preliminary findings. Mindfulness. 2011;2(1):8-13.
Heffner KL, Talbot NL, Krasner MS, Moynihan JA. Pain in older men is associated with interleukin (IL)-6 change across time following a mindfulness-based stress reduction intervention. Brain Behav. Immun. 2011;25:S205.
Hillemeier MM, Downs DS, Feinberg ME, et al. Improving women's preconceptional health: findings from a randomized trial of the Strong Healthy Women intervention in the Central Pennsylvania women's health study. Womens Health Issues. 2008;18(6 Suppl):S87-96. [pmid: 19059553].
Hong PY, Lishner DA, Han KH, Huss EA. The positive impact of mindful eating on expectations of food liking. Mindfulness. 2011;2(2):103-13.
Hui PN, Wan M, Chan WK, Yung PM. An evaluation of two behavioral rehabilitation programs, qigong versus progressive relaxation, in improving the quality of life in cardiac patients. J Altern Complement Med. 2006;12(4):373-8. [pmid: 16722787].
Humphrey CW. A stress management intervention with forgiveness as the goal (Meditation, mind-body medicine). Dissertation Abstracts International : Section B: the Sciences and Engineering. 1999;60(4-B):1855.
Innes KE, Selfe TK, Alexander GK, Taylor AG. A new educational film control for use in studies of active mind-body therapies: acceptability and feasibility. J Altern Complement Med. 2011;17(5):453-8. [pmid: 21554109].
Innes KE, Selfe TK, Vishnu A. Association of fructosamine to indices of dyslipidemia in older adults with type 2 diabetes. Diabetes Metab. Syndr. Clin. Res. Rev. 2010.
Jones Roger C. A comparison of aerobic exercise, anaerobic exercise and meditation on multidimensional stress measures. Dissertation Abstracts International. 1981;42(6-B):2504-5.
Kabat-Zinn J, Wheeler E, Light T, et al. Part II: Influence of a mindfulness meditation-based stress reduction intervention on rates of skin clearing in patients with moderate to severe psoriasis undergoing phototherapy (UVB) and photochemo-therapy (PUVA). [References]. Constructivism in the Human Sciences. 2003;8(2):85-106.
Kaviani A, Hatami N, ShafiAbadi A. The impact of mindfulness-based cognitive therapy on the quality of life in non-clinically depressed people. Advances in Cognitive Science. 2008;10(4).
Kember P. The Transcendental Meditation technique and postgraduate academic performance. British Journal of Educational Psychology. 1985;55(2):164-6.
Khasky AD, Smith JC. Stress, relaxation states, and creativity. Percept Mot Skills. 1999;88(2):409-16. [pmid: 10483629].
Khianman B, Pattanittum P, Thinkhamrop J, Lumbiganon P. Relaxation therapy for preventing and treating preterm labour. 2008;(4).
Khumar SS, Kaur P, Kaur S. Effectiveness of Shavasana on depression among university students. Indian Journal of Clinical Psychology. 1993;20(2):82-7.
Kiken LG, Shook NJ. Looking up: Mindfulness increases positive judgments and reduces negativity bias. Social Psychological and Personality Science. 2011;2(4):425-31.
Kim TS, Park JS, Kim MA. The relation of meditation to power and well-being. Nurs Sci Q. 2008;21(1):49-58. [pmid: 18096986].
Kligler B, Homel P, Blank AE, Kenney J, Levenson H, Merrell W. Randomized trial of the effect of an integrative medicine approach to the management of asthma in adults on disease-related quality of life and pulmonary function. Altern Ther Health Med. 2011;17(1):10-5. [pmid: 21614939].
Kolsawalla MB. An experimental investigation into the effectiveness of some yogic variables as a mechanism of change in the value-attitude system. Journal of Indian Psychology. 1978;1(1):59-68.
Koole SL, Govorun O, Cheng CM, Gallucci M. Pulling yourself together: Meditation promotes congruence between implicit and explicit self-esteem. Journal of Experimental Social Psychology. 2009;45(6):1220-6.
Kova-ìi-ì T, Kova-ìi-ì M. Impact of relaxation training according to Yoga in Daily Life-« system on perceived stress after breast cancer surgery. 2011;10(1):16-26.
Kozasa EH, Santos RF, Rueda AD, Benedito-Silva AA, De Ornellas FL, Leite JR. Evaluation of Siddha Samadhi Yoga for anxiety and depression symptoms: a preliminary study. Psychol Rep. 2008;103(1):271-4. [pmid: 18982958].
Krueger RC. The comparative effects of Zen focusing and muscle relaxation training on selected experiential variables. Dissertation Abstracts International. 1980;41(4-A):1405.
Kubose SK. An experimental investigation of psychological aspects of meditation. Psychologia: An International Journal of Psychology in the Orient. 1976;19(1):1-10.
Kulkarni R, Nagarathna R, Nagendra HR, An H. Measures of heart rate variability in women following a meditation technique. International Journal of Yoga. 2010;3(1):6-9. [pmid: 20948895].
Kulmatycki L, Burzyäski Z. Yoga nidra and Benson's meditative relaxation and anxiety level, anger and depression emotions. Relaksacja joga nidry i medytacji Bensona a poziom leku oraz emocje gniewu i depresji. 2007;21(3):23-8.
Kyizom T, Singh S, Singh KP, Tandon OP, Kumar R. Effect of pranayama & yoga-asana on cognitive brain functions in type 2 diabetes-P3 event related evoked potential (ERP). Indian J Med Res. 2010;131:636-40. [pmid: 20516534].
Labelle LE, Campbell TS, Carlson LE. Mindfulness-based stress reduction in oncology: Evaluating mindfulness and rumination as mediators of change in depressive symptoms. Mindfulness. 2010;1(1):28-40.
Laitinen J. Meditation--relaxation. Mietiskely - rentoutuminen. 1975;91(19):1136-41.
Lee EN, Kim YH, Chung WT, Lee MS. Tai chi for disease activity and flexibility in patients with ankylosing spondylitis--a controlled clinical trial. Evid Based Complement Alternat Med. 2008;5(4):457-62. [pmid: 18955296].
Lee JH, Kim YM, Choi YM, Lee GC. The effect of meditation on problem solving ability and self-perception. Journal of the Korean Neuropsychiatric Association. 1997;36(4):723-31.
Lee LY, Lee DT, Woo J. Effect of Tai Chi on state self-esteem and health-related quality of life in older Chinese residential care home residents. J Clin Nurs. 2007;16(8):1580-2. [pmid: 17655547].
Lee MS, Kang CW, Lim HJ, Lee MS. Effects of Qi-training on anxiety and plasma concentrations of cortisol, ACTH, and aldosterone: A randomized placebo-controlled pilot study. 2004;20(5):243-8.
Lee W, Bang H. The effects of mindfulness-based group intervention on the mental health of middle-aged Korean women in community. Stress & Health: Journal of the International Society for the Investigation of Stress. 2010;26(4):341-8.
Leung RW, Alison JA, McKeough ZJ, Peters MJ. A study design to investigate the effect of short-form Sun-style Tai Chi in improving functional exercise capacity, physical performance, balance and health related quality of life in people with Chronic Obstructive Pulmonary Disease (COPD). Contemp Clin Trials. 2011;32(2):267-72. [pmid: 21078418].
Li M, Chen K, Mo Z. Use of qigong therapy in the detoxification of heroin addicts. Altern Ther Health Med. 2002;8(1):50-4. 56. 9. [pmid: 11795622].
Lin MR, Hwang HF, Wang YW, Chang SH, Wolf SL. Community-based tai chi and its effect on injurious falls, balance, gait, and fear of falling in older people. Phys Ther. 2006;86(9):1189-201. [pmid: 16959668].
Lu CF, Liao JC, Liu CY, Liu HY, Chang YH. Meditation therapy in the treatment of anxiety disorders. Taiwanese Journal of Psychiatry. 1998;12(4):343-51.
Luethcke CA, McDaniel L, Becker CB. A comparison of mindfulness, nonjudgmental, and cognitive dissonance-based approaches to mirror exposure. Body Image. 2011;8(3):251-8. [pmid: 21561817].
Maloney R, Altmaier E. An initial evaluation of a mindful parenting program. J Clin Psychol. 2007;63(12):1231-8. [pmid: 17972292].
Marfurt S. Reducing stress in women recovering from substance abuse. Texas Woman's University. 2006.
Mariano C. A 16-week tai chi programme prevented falls in healthy older adults. Evid Based Nurs. 2008;11(2):60. [pmid: 18364430].
Maybery DJ, Graham D. The influence of physical and mental training on plasma beta-endorphin level and pain perception after intensive physical exercise. 2001;17(2):121-7.
McMillan TM, Robertson IH, Brock D, Chorlton L. Brief mindfulness training for attentional problems after traumatic brain injury: A randomised control treatment trial. Neuropsychological Rehabilitation. 2002;12(2):117-25.
Mirabel-Sarron C, Dorocant ES, Sala L, Bachelart M, Guelfi JD, Rouillon F. Mindfulness based cognitive therapy (MBCT): A pilot study in bipolar patients. Mindfulness based cognitive therapy (MBCT) dans la prevention des rechutes thymiques chez le patient bipolaire I : une etude pilote. Ann. Med.-Psychol. 2009;167(9):686-92.
Miro DJ. A comparative evaluation of relaxation training strategies utilizing EMG biofeedback. Dissertation Abstracts International. 1981;42(3-B):1183-4.
Mohan A, Sharma R, Bijlani RL. Effect of meditation on stress-induced changes in cognitive functions. J Altern Complement Med. 2011;17(3):207-12. [pmid: 21417807].
Monk-Turner E. The benefits of meditation: Experimental findings. The Social Science Journal. 2003;40(3):465-70.
Moretti-Altuna G. The effects of meditation versus medication in the treatment of Attention Deficit Disorder with Hyperactivity [dissertation]. 1987.
Moynihan JA, Klorman R, Chapman BP, et al. Mindfulness to improve elders' immune and health status. Brain Behav. Immun. 2010;24:S13.
Mustata S, Cooper L, Langrick N, Simon N, Jassal SV, Oreopoulos DG. The effect of a Tai Chi exercise program on quality of life in patients on peritoneal dialysis: a pilot study. Perit Dial Int. 2005;25(3):291-4. [pmid: 15981780].
Nakamura Y, Lipschitz DL, Landward R, Kuhn R, West G. Two sessions of sleep-focused mind-body bridging improve self-reported symptoms of sleep and PTSD in veterans: A pilot randomized controlled trial. J Psychosom Res. 2011;70(4):335-45. [pmid: 21414453].
Nakamura Y, Lipschitz DL, Landward R, Kuhn R, West G. Two sessions of sleep-focused mind-body bridging improve self-reported symptoms of sleep and PTSD in veterans: A pilot randomized controlled trial. Journal of Psychosomatic Research. 2011;70(4):335-45. [pmid: 21414453].
NCT00558402. 2007. Meditation or Education for Alzheimer Caregivers Or Meditation for Alzheimer Caregivers: Stress & Physiology. Http://Www.Clinicaltrials.Gov. 2007.
Paty J, Brenot P, Tignol J, Bourgeois M. Evoked cerebral activity (contingent negative variation and evoked potentials) and modified states of consciousness (sleeplike relaxation, transcendential meditation). Ann Med Psychol (Paris). 1978;136(1):143-69. [pmid: 354456].
Rakhshaee Z. Effect of three yoga poses (cobra, cat and fish poses) in women with primary dysmenorrhea: a randomized clinical trial. J Pediatr Adolesc Gynecol. 2011;24(4):192-6. [pmid: 21514190].
Ramos NS, Hernandez SM, Blanca MJ. Effects of an integrated programme of mindfulness and emotional intelligence on cognitive strategies of emotional regulation. Efecto de un programa integrado de mindfulness e inteligencia emocional sobre las estrategias cognitivas de regulacion emocional. 2009;15(2-3):207-16.
Rasmussen LB. Transcendental meditation and mild hypertension. Transcendental meditasjon og mild hypertensjon. 1998;118(5):775.
Rediger JD, Summers L. Mindfulness training and meditation for mental health. Adv Mind Body Med. 2007;22(1):16-26. [pmid: 20671339].
Robins JL, McCain NL, Gray DP, Elswick RK Jr, Walter JM, McDade E. Research on psychoneuroimmunology: tai chi as a stress management approach for individuals with HIV disease. Appl Nurs Res. 2006;19(1):2-9. [pmid: 16455435].
Rogers CE, Keller C, Larkey LK, Ainsworth BE. A Randomized Controlled Trial to Determine the Efficacy of Sign Chi Do Exercise on Adaptation to Aging. Res Gerontol Nurs. 2011:1-13.
Rohini V, Pandey RS, Janakiramaiah N, Gangadhar BN, Vedamurthachar A. A comparative study of full and partial Sudarshan Kriya Yoga (SKY) in major depressive disorder. NIMHANS Journal. 2000;18(1-2):53-7.
Rosdahl D. The effect of mindfulness meditation on tension headaches and secretory immunoglobulin A in saliva. University of Arizona. 2003.
Sawada Y, Steptoe A. The effects of brief meditation training on cardiovascular stress responses. Journal of Psychophysiology. 1988;2(4):249-57.
Schneider RH, Alexander CN, Staggers F, et al. Long-term effects of stress reduction on mortality in persons > or = 55 years of age with systemic hypertension. 2005;95(9):1060-4.
Semple RJ. Does mindfulness meditation enhance attention? A randomized controlled trial. Mindfulness. 2010;1(2):121-30.
Shahar B, Britton WB, Sbarra DA, Figueredo AJ, Bootzin RR. Mechanisms of change in mindfulness-based cognitive therapy for depression: Preliminary evidence from a randomized controlled trial. International Journal of Cognitive Therapy. 2010;3(4):402-18.
Shapiro SL, Astin JA, Bishop SR, Cordova M. Mindfulness-Based Stress Reduction for Health Care Professionals: Results From a Randomized Trial. International Journal of Stress Management. 2005;12(2):164-76.
Sharma I, Azmi SA, Settiwar RM. Evaluation of the effect of pranayama in anxiety state. Alternative Medicine. 1991;3(4):227-35.
Shin TB, Jin SR. The qualitative study of “mindfulness group” toward the self-care and counseling practice of counselor interns. Bulletin of Educational Psychology. 2010;42(1):163-84.
Smith JC. Meditation as psychotherapy. Dissertation Abstracts International. 1975;36(6-B):3073.
Smith WP, Compton WC, West WB. Meditation as an adjunct to a happiness enhancement program. J Clin Psychol. 1995;51(2):269-73. [pmid: 7797651].
Spadaro K. Weight loss: exploring self-regulation through Mindfulness Meditation. University of Pittsburgh. 2008.
Sridevi K, Krishna Rao PV. Yoga practice and menstrual distress. Journal of the Indian Academy of Applied Psychology. 1996;22(1-2):47-54.
Stormer-Labonte M, Machemer P, Hardinghaus W. Ein meditatives Streewaltigungsprogramm bei psychosomatischen Patienten. Psychotherapie Psychosomatik Medizinische Psychologie. 1992;42(12):436-43.
Stevinson C. Preliminary results suggest that yoga can alleviate depression. Focus on Alternative & Complementary Therapies. 2001;6(1):27-8.
Strijk JE, Proper KI, van der Beek AJ, van Mechelen W. A process evaluation of a worksite vitality intervention among ageing hospital workers. Int J Behav Nutr Phys Act. 2011;8:58. [pmid: 21663610].
Szabo A, Mesko A, Caputo A, Gill T. Examination of exercise-induced feeling states in four modes of exercise. International Journal of Sport Psychology. 1998;29(4):376-90.
Tanay G, Lotan G, Bernstein A. Salutary Proximal Processes and Distal Mood and Anxiety Vulnerability Outcomes of Mindfulness Training: A Pilot Preventive Intervention.
Targ EF, Levine EG. The efficacy of a mind-body-spirit group for women with breast cancer: a randomized controlled trial. Gen Hosp Psychiatry. 2002;24(4):238-48. [pmid: 12100834].
Taylor DN. Effects of a behavioral stress-management program on anxiety, mood, self-esteem, and T-cell count in HIV positive men. Psychol Rep. 1995;76(2):451-7. [pmid: 7667456].
Telles S, Naveen KV. Effect of yoga on somatic indicators of distress in professional computer users. Med Sci Monit. 2006;12(10):LE21-2. [pmid: 17006412].
Tloczynski J, Malinowski A, Lamorte R. Rediscovering and reapplying contingent informal meditation. Psychologia: An International Journal of Psychology in the Orient. 1997;40(1):14-21.
Tloczynski J, Tantriella M. A comparison of the effects of Zen breath meditation or relaxation on college adjustment. Psychologia: An International Journal of Psychology in the Orient. 1998;41(1):32-43.
Travis F, Olson T, Egenes T, Gupta HK. Physiological patterns during practice of the Transcendental Meditation technique compared with patterns while reading Sanskrit and a modern language. Int J Neurosci. 2001;109(1-2):71-80. [pmid: 11699342].
van den Hout MA, Engelhard IM, Beetsma D, et al. EMDR and mindfulness. Eye movements and attentional breathing tax working memory and reduce vividness and emotionality of aversive ideation. J Behav Ther Exp Psychiatry. 2011;42(4):423-31. [pmid: 21570931].
Vanfraechem-Raway R. Fatigue. Relaxation therapy. Arch Belg. 1985;43(11-12):511-7. [pmid: 3914865].
Vedamurthachar A, Janakiramaiah N, Hegde JM, et al. Antidepressant efficacy and hormonal effects of Sudarshana Kriya Yoga (SKY) in alcohol dependent individuals. J Affect Disord. 2006;94(1-3):249-53. [pmid: 16740317].
Wang F, Wang W, Zhang R, et al. Clinical observation on physiological and psychological effects of Eight-Section Brocade on type 2 diabetic patients. J Tradit Chin Med. 2008;28(2):101-5. [pmid: 18652115].
Warber SL, Ingerman S, Moura VL, et al. Healing the heart: a randomized pilot study of a spiritual retreat for depression in acute coronary syndrome patients. Explore (NY). 2011;7(4):222-33. [pmid: 21724155].
Weiner Donald E. The effects of mantra meditation and progressive relaxation on self-actualization, state and trait anxiety, and frontalis muscle tension. Dissertation Abstracts International. 1977;37(8-B):4174.
Wenger Ma, Bagchi Bk, Anand Bk. Experiments In India On “Voluntary” Control Of The Heart And Pulse. Circulation. 1961;24:1319-25. [pmid: 14006121].
Williams JMG, Alatiq Y, Crane C, et al. Mindfulness-based Cognitive Therapy (MBCT) in bipolar disorder: Preliminary evaluation of immediate effects on between-episode functioning. 2008;107(1-3):275-9.
Wolfson L, Whipple R, Derby C, et al. Balance and strength training in older adults: intervention gains and Tai Chi maintenance. J Am Geriatr Soc. 1996;44(5):498-506. [pmid: 8617896].
Wood DT. The effects of progressive relaxation, heart rate feedback, and content-specific meditation on anxiety and performance in a class situation. Dissertation Abstracts International. 1978;39(6-A):3458.
Yan X, Shen H, Jiang H, et al. External Qi of Yan Xin Qigong Induces apoptosis and inhibits migration and invasion of estrogen-independent breast cancer cells through suppression of Akt/NF-kB signaling. Cell Physiol Biochem. 2010;25(2-3):263-70. [pmid: 20110687].
Yan X, Shen H, Jiang H, et al. External Qi of Yan Xin Qigong differentially regulates the Akt and extracellular signal-regulated kinase pathways and is cytotoxic to cancer cells but not to normal cells. Int J Biochem Cell Biol. 2006;38(12):2102-13. [pmid: 16893670].
Yan X, Shen H, Jiang H, et al. External Qi of Yan Xin Qigong induces G2/M arrest and apoptosis of androgen-independent prostate cancer cells by inhibiting Akt and NF-kappa B pathways. Mol Cell Biochem. 2008;310(1-2):227-34. [pmid: 18080802].
Oktedalen O, Solberg EE, Haugen AH, Opstad PK. The influence of physical and mental training on plasma beta-endorphin level and pain perception after intensive physical exercise. Stress and Health: Journal of the International Society for the Investigation of Stress. 2001;17(2):121-7.
Zautra AJ, Fasman R, Davis MC, Craig AD. The effects of slow breathing on affective responses to pain stimuli: an experimental study. Pain. 2010;149(1):12-8. [pmid: 20079569].
Zika B. The effects of hypnosis and meditation on a measure of self-actualization. Australian Journal of Clinical & Experimental Hypnosis. 1987;15(1):21-8.