# Screening Forms

Title—Abstract Review Selected—No

Appendix C has several screening forms. The forms cover abstract review, article review, study characteristics, participant characteristics, intervention characteristics, outcomes measures for KQs 1 to 4, and risk of bias.

Article Review Selected—Yes

Appendix C has several screening forms. The forms cover abstract review, article review, study characteristics, participant characteristics, intervention characteristics, outcomes measures for KQs 1 to 4, and risk of bias.

Article Review Selected—No

Appendix C has several screening forms. The forms cover abstract review, article review, study characteristics, participant characteristics, intervention characteristics, outcomes measures for KQs 1 to 4, and risk of bias.

Study Characteristics Selected—Yes

Appendix C has several screening forms. The forms cover abstract review, article review, study characteristics, participant characteristics, intervention characteristics, outcomes measures for KQs 1 to 4, and risk of bias.

Study Characteristics Selected—No

Appendix C has several screening forms. The forms cover abstract review, article review, study characteristics, participant characteristics, intervention characteristics, outcomes measures for KQs 1 to 4, and risk of bias.

Participant Characteristics Selected—Reported

Appendix C has several screening forms. The forms cover abstract review, article review, study characteristics, participant characteristics, intervention characteristics, outcomes measures for KQs 1 to 4, and risk of bias.

Intervention Characteristics Arm A

Appendix C has several screening forms. The forms cover abstract review, article review, study characteristics, participant characteristics, intervention characteristics, outcomes measures for KQs 1 to 4, and risk of bias.

Intervention Arm B (same for Arm C)

Appendix C has several screening forms. The forms cover abstract review, article review, study characteristics, participant characteristics, intervention characteristics, outcomes measures for KQs 1 to 4, and risk of bias.

Intervention Arm D (Usual Care)

Appendix C has several screening forms. The forms cover abstract review, article review, study characteristics, participant characteristics, intervention characteristics, outcomes measures for KQs 1 to 4, and risk of bias.

Outcomes for KQ 1 Anxiety Scales

Appendix C has several screening forms. The forms cover abstract review, article review, study characteristics, participant characteristics, intervention characteristics, outcomes measures for KQs 1 to 4, and risk of bias.

Outcomes for KQ1 Depression Scales

Appendix C has several screening forms. The forms cover abstract review, article review, study characteristics, participant characteristics, intervention characteristics, outcomes measures for KQs 1 to 4, and risk of bias.

Outcomes for KQ1 Scales for Stress

Appendix C has several screening forms. The forms cover abstract review, article review, study characteristics, participant characteristics, intervention characteristics, outcomes measures for KQs 1 to 4, and risk of bias.

Outcomes for KQ1 Scales for General Distress

Appendix C has several screening forms. The forms cover abstract review, article review, study characteristics, participant characteristics, intervention characteristics, outcomes measures for KQs 1 to 4, and risk of bias.

Outcomes for KQ1 Scales for Subjective Well-Being

Appendix C has several screening forms. The forms cover abstract review, article review, study characteristics, participant characteristics, intervention characteristics, outcomes measures for KQs 1 to 4, and risk of bias.

Outcomes for KQ 1—Harms

Appendix C has several screening forms. The forms cover abstract review, article review, study characteristics, participant characteristics, intervention characteristics, outcomes measures for KQs 1 to 4, and risk of bias.

Outcomes for KQ 2

Appendix C has several screening forms. The forms cover abstract review, article review, study characteristics, participant characteristics, intervention characteristics, outcomes measures for KQs 1 to 4, and risk of bias.

Outcomes for KQ 3 Scales for Substance Use

Appendix C has several screening forms. The forms cover abstract review, article review, study characteristics, participant characteristics, intervention characteristics, outcomes measures for KQs 1 to 4, and risk of bias.

Outcomes for KQ 3 Scales for Sleep

Appendix C has several screening forms. The forms cover abstract review, article review, study characteristics, participant characteristics, intervention characteristics, outcomes measures for KQs 1 to 4, and risk of bias.

Outcomes for KQ 3 Scales for Eating

Appendix C has several screening forms. The forms cover abstract review, article review, study characteristics, participant characteristics, intervention characteristics, outcomes measures for KQs 1 to 4, and risk of bias.

Outcomes for KQ 3—Harms

Appendix C has several screening forms. The forms cover abstract review, article review, study characteristics, participant characteristics, intervention characteristics, outcomes measures for KQs 1 to 4, and risk of bias.

Outcomes for KQ 4 Scales for Pain

Appendix C has several screening forms. The forms cover abstract review, article review, study characteristics, participant characteristics, intervention characteristics, outcomes measures for KQs 1 to 4, and risk of bias.

Outcomes for KQ 4 Scales for Weight

Appendix C has several screening forms. The forms cover abstract review, article review, study characteristics, participant characteristics, intervention characteristics, outcomes measures for KQs 1 to 4, and risk of bias.

Outcomes for KQ 4—Harms

Appendix C has several screening forms. The forms cover abstract review, article review, study characteristics, participant characteristics, intervention characteristics, outcomes measures for KQs 1 to 4, and risk of bias.

Risk of Bias

Appendix C has several screening forms. The forms cover abstract review, article review, study characteristics, participant characteristics, intervention characteristics, outcomes measures for KQs 1 to 4, and risk of bias.