# Detailed Search Strategies

## PubMed

meditation[mh] OR meditat*[tiab] OR mindful*[tiab] OR transcendental Meditation[mh] OR “transcendental Meditation”[tiab] OR “mindfulness-based cognitive therapy”[tiab] OR “MBCT”[tiab] OR “mindfulness-based stress reduction”[tiab] OR “MBSR”[tiab] OR Vipassana[tiab] OR zen[tiab] OR Qi-gong[tiab] OR Qigong[tiab] OR Chi kung[tiab] OR Tai Chi[tiab] OR TaiChi[tiab] OR tai ji[mh] OR Yoga[mh]OR yoga[tiab] OR Yogic[tiab]OR dhyana[tiab] OR asana[tiab] OR pranayama[tiab] OR sudarshan[tiab]

## CINAHL

TI meditat* OR SU meditation OR TI mindful* OR SU mindfulness OR TI “transcendental Meditation” OR SU transcendental Meditation OR TI “mindfulness-based cognitive therapy” OR TI “MBCT” OR TI “mindfulness-based stress reduction” OR TI “MBSR” OR TI Vipassana OR TI zen OR TI Qigong OR TI Qi gong OR SU Qigong OR TI Chi kung OR TI Tai Chi OR TI TaiChi OR SU Tai Chi OR TI Yoga OR SU yoga OR TI dhyana OR TI asana OR TI pranayama OR TI sudarshan

## PsycINFO

TI meditat* OR SU meditation OR TI mindful* OR SU mindfulness OR TI “transcendental Meditation” OR SU transcendental Meditation OR TI “mindfulness-based cognitive therapy” OR TI “MBCT” OR TI “mindfulness-based stress reduction” OR TI “MBSR” OR TI Vipassana OR TI zen OR TI Qigong OR TI Qi gong OR SU Qigong OR TI Chi kung OR TI Tai Chi OR TI TaiChi OR SU Tai Chi OR TI Yoga OR SU yoga OR TI dhyana OR TI asana OR TI pranayama OR TI sudarshan

## PsycARTICLES

TI meditat* OR SU meditation OR TI mindful* OR SU mindfulness OR TI “transcendental Meditation” OR SU transcendental Meditation OR TI “mindfulness-based cognitive therapy” OR TI “MBCT” OR TI “mindfulness-based stress reduction” OR TI “MBSR” OR TI Vipassana OR TI zen OR TI Qigong OR TI Qi gong OR SU Qigong OR TI Chi kung OR TI Tai Chi OR TI TaiChi OR SU Tai Chi OR TI Yoga OR SU yoga OR TI dhyana OR TI asana OR TI pranayama OR TI sudarshan

## Scopus

(KEY(meditation) OR TITLE(meditation) OR KEY(mindfulness) OR TITLE(mindfulness) OR TITLE(“transcendental Meditation”) OR TITLE(“mindfulness-based cognitive therapy”) OR TITLE(“MBCT”) OR TITLE(“mindfulness-based stress reduction”) OR TITLE(“MBSR”) OR KEY(yoga) OR TITLE(yoga) OR TITLE-ABS-KEY(vipassana) OR TITLE-ABS-KEY(tai chi) OR TITLE-ABS-KEY(qigong) OR TITLE-ABS-KEY(chi kung) OR TITLE-ABS-KEY(dhyana) OR TITLE-ABS-KEY(asana) OR TITLE-ABS-KEY(pranayama) OR TITLE-ABS-KEY(sudarshan))

## Cochrane

ID | Search
#1 | (meditation):ti,ab,kw (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=1)
#2 | MeSH descriptor Meditation, this term only (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=2)
#3 | (meditation):ti or (meditation):kw (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=3)
#4 | (#2 OR #3) (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=4)
#5 | MeSH descriptor Tai Ji explode tree 1 (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=5)
#6 | MeSH descriptor Yoga explode tree 1 (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=6)
#7 | (#4 OR #5 OR #6) (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=7)
#8 | (Vipassana):ti or (Vipassana):kw or (zen):ti or (zen):kw or (Qigong):ti (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=8)
#9 | (#7 OR #8) (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=9)
#10 | “Tai Chi”:ti or “Tai Chi”:kw or (yoga):ti or (yoga):kw or (dhyana):kw (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=10)
#11 | (#9 OR #10) (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=11)
#12 | (Qigong):kw or (asana):ti or (asana):kw or (pranayama):ti or (pranayama):kw (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=12)
#13 | (#11 OR #12) (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=13)

## Embase

‘meditation’/exp/mj OR meditat*:ab,ti OR mindful*:ab,ti OR transcendental AND meditation:ab,ti OR ‘transcendental meditation’:ab,ti OR ‘mindfulness-based cognitive therapy’:ab,ti OR ‘mbct’:ab,ti OR ‘mindfulness-based stress reduction’:ab,ti OR ‘mbsr’:ab,ti OR vipassana:ab,ti OR zen:ab,ti OR ‘qi gong’:ab,ti OR qigong:ab,ti OR chi AND kung:ab,ti OR tai AND chi:ab,ti OR taichi:ab,ti OR tai AND ji:ab,ti OR yoga:ab,ti OR yogic:ab,ti OR dhyana:ab,ti OR asana:ab,ti OR pranayama:ab,ti OR sudarshan:ab,ti AND [humans]/lim

## AMED

Meditation (TI) OR Meditation (Sh) OR Mindfulness (TI) OR Mindfulness (Sh) OR Transcendental Meditation (TI) OR Transcendental Meditation (Sh) OR Mindfulness-based cognitive therapy (TI) OR Mindfulness-based cognitive therapy (Sh) OR MBCT (TI) OR MBCT (Sh) OR Mindfulness-Based Stress Reduction(TI) OR Mindfulness-Based Stress Reduction (Sh) OR MBSR (TI) OR MBSR (Sh) OR Vipassana (TI) OR Vipassana (Sh) OR Zen (TI) OR Zen (Sh) OR Qi-gong(TI) OR Qi-gong (Sh) OR Qigong(TI) OR Qigong (Sh) OR Chi kung (TI) OR Chi kung (Sh) OR Tai Chi(TI) OR Tai Chi(Sh) OR TaiChi(TI) OR TaiChi (Sh ) OR Tai ji(TI) OR Tai ji(Sh) OR Yoga (TI) OR Yoga(Sh) OR Yogic(TI) OR Yogic(Sh) OR Dhyana(TI) OR Dhyana(Sh) OR Asana(TI) OR Asana(Sh) OR Pranayama(TI) OR Pranayama(Sh) OR Surdarshan(TI) OR Surdarshan(Sh)