# Abbreviations and Glossary of Terms

Table A1 Abbreviations and acronyms

Abbreviation/Acronym | Explanation
AC | Active Control
ASG | Alcohol dependence Support Group
BAI | Beck Anxiety Index
BDI | Beck Depression Inventory
BSI | Brief Symptom Inventory
CBGT | Cognitive Behavioral Group Therapy
CESD | Center for Epidemiologic Studies Depression Scale
CHF | Congestive heart failure
COPD | Chronic obstructive pulmonary disease
CSM | Clinically Standardized Meditation
FFS | Freedom From Smoking Treatment
HE | Health Education
IBS | irritable bowel syndrome
IPAT | Institute for Personality and Ability Testing
Kcal/d | Kilocalorie per day
LSQ | Life Stress lns Q
M-ADM | Maintenance Antidepressant Mono-Therapy
MBBT | Mindfulness-based Breathing Therapy
MBCT | Mindfulness-based Cognitive Therapy
MBRP | Mindfulness-based Relapse Prevention
MBSR | Mindfulness Based Stress Reduction
MG | Mindfulness Group/Mindfulness Treatment Group
MORE | Mindfulness-oriented Recovery Enhancement
MP | Meditation Program
MPI | Multidisciplinary Pain Intervention
MT | Mindfulness Training
NE | Nutrition Education
NEP | Nutrition Education Program
NP | Not Provided
NRS | Numeric Rating Scale
OM | Other Mantra (any mantra program other than TM)
P+CL | Placebo Plus Clinical Management
PANAS | Positive and Negative Affect Scale/Schedule
PANAS-N | Positive and Negative Affect Scale—Negative mood
PCT | Pharmacotherapy
POMS | Profile of Mood States
PMR | Progressive muscular relaxation
PPS | Pain Perception (Sensory)
PSQL | Pittsburgh Sleep Quality Index
PSS | Perceived Stress Scale
RG | Relaxation Treatment Group
RL | Progressive Muscle Relaxation Group
SCID | Structured Clinical Interview
SCL | Symptom Checklist
SCL90 | Symptom Checklist 90
SCL90-GSI | Symptom Checklist 90 Global Severity Index
SF12:MC | Short Form-12: Mental Component Score of Health-related Quality of Life
SF36 | Short Form-36
SF36:MC | Short Form 36: Mental Component Score of Health-related Quality of Life
SG | Support Group
SIAS | Social Interaction Scale
SP | Spiritual Meditation Group
SRDS | Self-rating Depression Scale
STAI | State Trait Anxiety Index
TM | Transcendental Meditation
VR36 | Veterans RAND 36 Item Health Survey
WHOQL | World Health Organization Quality of Life Assessment

Appendix Table A2 Glossary

Term | Definition
Affect | A clinical term that refers to emotion or mood. It can be positive, such as the feeling of well-being, or negative, such as anxiousness, depression, or stress. Studies usually measure affect through self-reported questionnaires designed to gauge how much someone experiences a particular affect.
Attrition | A reduction in sample size due to withdrawal of study participants
Difference in change | An analytic strategy that factors in baseline measurements of both the treatment group and control group in examining the effect of a treatment.
Intent-to-treat (ITT) | An analytic strategy that includes all patients based on their original assignment in a randomized controlled trial. This allows for more accurate assessment of the effectiveness of an intervention as everyone who is initially randomized is included in the analysis, regardless of their completion of the trial.
Mantra meditation | Any mantra meditation program, including transcendental meditation (TM), Clinically standardized meditation, or other mantra-based program
Meta-analysis | A statistical method of combining results from a group of research findings in order to determine patterns and an overall effect size (i.e., strength of a relationship).
Mindfulness meditation | Any mindfulness meditation program, including mindfulness-based stress reduction (MBSR), mindfulness-based cognitive therapy (MBCT), or other variation
Modified mindfulness program | Any mindfulness program that has used a variation of MBSR or other Buddhist-based mindfulness technique
Nonspecific active control | A nonspecific active control only matches time and attention, and is not a known therapy
Other Mantra | Any mantra program other than transcendental meditation (TM)
Percent difference in change | Percent change that the difference in change (see above) represents from baseline.
Randomization | A process whereby participants in a research study are assigned to a treatment(s) or control group(s) by chance (i.e., there is an equal possibility that they will be assigned to either group(s)). This allows for equal allocation of factors that may impact study results (e.g., age, gender, race, etc.) in each group.
Scale | An instrument to measure something. Examples include the Perceived Stress Scale or the SF 36 Mental Health subscale.
Specific active control | A specific active control compares the intervention to another known therapy, such as progressive muscle relaxation.
Standardized mean difference | A statistic in meta-analysis when studies that assess an outcome using a variety of measures are made standard on a scale for a more direct comparison.