# Results

## Introduction

In what follows, we begin by describing the results of our literature searches. We then provide a brief description of the included studies. The remainder of the chapter is organized by Key Question (KQ). Under each of the six KQs, we begin by listing the key points of the findings, followed by a brief description of included studies and a detailed synthesis of the evidence. The detailed syntheses are organized first by risk stratification strategy or treatment comparison and then by outcome. We conducted quantitative syntheses where possible, as described in the Methods chapter.

A list of abbreviations and acronyms used in this chapter is provided at the end of the report.

## Results of Literature Searches

Figure 2 depicts the flow of articles through the literature search and screening process. Searches of PubMed^®^, Embase^®^, and CDSR yielded 7,417 unique citations. Manual searching of gray literature databases, bibliographies of key articles, and information received through requests for scientific information packets identified 208 additional citations, for a total of 7,625 citations. After applying inclusion/exclusion criteria at the title-and-abstract level, 704 full-text articles were retrieved and screened. Of these, 582 were excluded at the full-text screening stage, leaving 122 articles for data abstraction. These 122 articles described 92 unique studies. The relationship of studies to the review questions is as follows: 37 studies relevant to KQ 1, 17 studies relevant to KQ 2, 43 studies relevant to KQ 3, 13 studies relevant to KQ 4, 0 studies relevant to KQ 5, and 0 studies relevant to KQ 6 (some studies were relevant to more than one KQ).

Figure 2 Literature flow diagram

^a^ Some studies were relevant to more than one KQ.

Abbreviation: KQ=Key Question

Figure 2. Literature flow diagram. This figure depicts the flow of articles through the literature search and screening process. Searches of PubMed, Embase, and the Cochrane Database of Systematic Reviews yielded 7,417 unique citations. Manual searching identified 208 additional citations, for a total of 7,625 citations. After applying inclusion/exclusion criteria at the title-and-abstract level, 704 full-text articles were retrieved and screened. Of these, 582 were excluded at the full-text screening stage, leaving 122 articles (representing 92 unique studies) for data abstraction. Many included articles/studies were relevant to more than one KQ. Totals included for each KQ were: 37 studies for KQ 1; 17 studies for KQ 2; 43 studies for KQ 3, 13 studies for KQ 4; 0 studies for KQ 5; and 0 studies for KQ 6.

Appendix C provides a detailed listing of included articles. Appendix D provides a complete list of articles excluded at the full-text screening stage, with reasons for exclusion. Appendix E provides a “study key” table listing the primary and companion publications for the 92 included studies.

## Description of Included Studies

Overall, we included 92 studies represented by 122 publications: 37 studies were relevant to KQ 1, 17 studies to KQ 2, 43 studies to KQ 3, 13 studies to KQ 4, 0 studies to KQ 5, and 0 studies to KQ 6. Studies were conducted wholly or partly in continental Europe (49%), the United States or Canada (33%), Asia (22%), the UK (13%), South or Central America (5%), Australia or New Zealand (5%), Africa (3%), and unspecified or other locations (4%). Further details on the studies included for each KQ are provided in the relevant results sections, below, and in Appendix F.

We searched the ClinicalTrials.gov registry of clinical studies to identify completed but unpublished studies as a mechanism for ascertaining publication bias. We acknowledge that this is not an exhaustive strategy, as several other registries also exist with differing geographical focus and varying degrees of overlap in their trial listings; however, in the opinion of the investigators, the widely used, U.S.-based ClinicalTrials.gov registry provided the most relevant information to the populations and interventions of interest in this review. Our search yielded 186 trial records. A single reviewer identified 59 of these records as potentially relevant to this review. Of those 59 records, 32 had expected completion dates of 1 year or more prior to our search. From that group of 32 trials, we identified publications for 18. The remaining 14 trial records for which we did not identify publications were all considered potentially relevant to KQ 3. However these 14 unpublished studies provided data on only 8,879 patients, while the 43 published studies included for KQ 3 in this review involved more than 433,500 patients. Therefore we do not believe there is significant publication bias in the evidence base that would impact our overall conclusions for any of the key questions.

## Key Question 1 Predicting Thromboembolic Risk

KQ 1: In patients with nonvalvular atrial fibrillation, what are the comparative diagnostic accuracy and impact on clinical decisionmaking (diagnostic thinking, therapeutic efficacy, and patient outcome efficacy) of available clinical and imaging tools for predicting thromboembolic risk?

### Key Points

- Comparison of risk scores between study populations was complicated by multiple factors. Included studies used heterogeneous populations; some participants were on and some were off antiplatelets and anticoagulants at baseline. Also, few studies used clinical validation in their report of stroke rates, instead relying on administrative data, chart review, or other measures that did not use consistent definitions and were not similar across studies, complicating synthesis of their findings. Furthermore, although event rates were consistently reported, c-statistics and measures of calibration, strength of association, and diagnostic accuracy were inconsistently reported. No studies performed net reclassification improvement (NRI) in their selected population. As a result, our ability to draw firm conclusions was limited.
- Based on a meta-analysis of 8 studies (5 good quality, 3 fair quality; 379,755 patients), there is low strength of evidence that the continuous CHADS_2_ score provides modest stroke risk discrimination (c-statistic of 0.71; 95% CI 0.66 to 0.75).
- Based on a meta-analysis of 5 studies (4 good quality, 1 fair quality; 371,911 patients), there is low strength of evidence that the continuous CHA_2_DS_2_-VASc score provides modest stroke risk discrimination (c-statistic of 0.70; 95% CI 0.66 to 0.75).
- Based on a meta-analysis of 5 studies (4 good quality, 1 fair quality; 259,253 patients), there is moderate strength of evidence that the categorical Framingham score provides limited stroke risk discrimination (c-statistic of 0.63; 95% CI 0.62 to 0.65).
- Given the imprecision and inconsistency across studies of c-statistics for the categorical CHADS_2_ and CHA_2_DS_2_-VASc scores, there is insufficient evidence of their ability to discriminate stroke risk.
- There is insufficient evidence for the relationship between LA thrombus on echocardiography and subsequent stroke based on 5 studies (3 good quality, 2 fair quality; 1,228 patients) that reported discrepant results.
- Of the tools reviewed, the CHADS_2_ and CHA_2_DS_2_-VASc continuous risk scores appear to be similar and have the most discrimination of stroke events when compared with the CHADS_2_ categorical score, the CHA_2_DS_2_-VASc categorical score, and the Framingham categorical score. This finding was, however, statistically significant only for the comparison with the Framingham categorical score. Other comparisons were not possible given limited data.

### Description of Included Studies

An expert panel recently recommended that for all patients with AF, stroke risk should be assessed using an established risk scoring tool.101 Per the expert panel, if a patient’s stroke risk is high enough to require anticoagulation, providers should use a bleeding risk scoring tool to estimate the net clinical benefit of anticoagulation: “For the majority of patients, the net benefit of stroke prophylaxis supersedes the ‘net harm’ of serious bleeding events, even among older patients.”101 Therefore, assessment of stroke and bleeding risk is not an opportunity to look for reasons not to anticoagulate, but rather an opportunity to assure that all patients with sufficient stroke risk are treated appropriately while addressing correctable risk factors for bleeding. In order to inform clinical decisionmaking regarding the net clinical benefit of anticoagulation, we have focused this review on studies evaluating the risk scores most typically utilized for prospective estimation of stroke risk in clinical settings.

Overall, 37 studies described in 38 publications from 2001 to 2012 investigated our included tools for determining stroke risk in patients with nonvalvular AF and met the other inclusion criteria for KQ 1 (Appendix Table F-1).13,15,27,102–136 Two articles reporting analyses based on the ATRIA study cohort118,121 are counted here as one study grouping due to overlapping patient populations; they address different research questions and are represented in separate rows of Appendix Table F-2 and in separate sections under “Detailed Synthesis,” below. The included articles explored tools in studies of diverse quality, design, geographical location, and study characteristics. Fourteen included studies were of good quality,13,15,27,104,106,109,117–122,124,129,130 21 of fair quality,103,105,107,108,110–116,123,126–128,131–136 and 2 of poor quality.102,125 Five studies enrolled patients from an inpatient setting;102,115,117,133,136 the majority (23) were from outpatient settings,13,15,27,104–107,109,110,113,116,118–129,131 and 3 studies enrolled patients from both types of settings.108,114,130 In 6 studies, the location of enrollment was not reported.103,111,112,132,134,135 The studies covered broad geographical locations with 16 studies conducted in Europe,102–104,109,110,114,120,125,126,128–130,132,134–136 8 in the United States,13,107,108,111,112,118,121–123 3 in the UK,105,115,116 7 in Asia,106,113,117,124,127,131,133 and 2 in multiple nations;15,27 1 study did not report geography of enrollment.119 Fourteen studies were conducted at multiple sites,13,15,27,102,103,116,118–121,126,129,130,132,136 and 18 studies were conducted at a single center.106–115,117,123,124,127,128,131,133,135 In 5 studies, this information was unclear or not reported.104,105,122,125,134 Four studies were supported solely by industry. 27,115,116,119 Two studies received solely government support,13,135 and in one study funding was partially composed of government support.117 Seven studies received funding from multiple sources including government, industry, nongovernment and nonindustry.15,118,121,122,128,130,131,133 Three studies had no funding support,103,104,132 while in 17 studies funding was unclear or not reported.102,105–107,109,111,113,114,120,123–127,129,134,136

Studies examined patients enrolled or with encounters between the years of 1948^122^ and 2008.^108^ The number of patients included in studies ranged from fewer than 100^124^ to 170,291^130^ with overlap in patient populations between some studies; altogether, the included studies analyzed data from almost 500,000 unique patients. The mean age of study participants ranged from 53–81 years. None of the studies presented data on ethnicity of subjects. Study gender distributions ranged from 44 percent male128 to 84 percent male123 in the included studies. Study followup duration ranged from 1–12 years. Sixteen studies provided specific information on event definition 15,27,103,107,109,111,114,118–122,128,131,134,135 and of these, 4 described a clinical adjudication process to validate these events,27,118,119,121,122 while the other studies either relied on billing or other administrative data source or did not report how events were classified.

Sixteen studies used prospective cohorts to identify patients,103,106,107,109–111,113,114,120,122–124,128,130,133,135 while 19 studies utilized retrospective cohorts,13,15,102,104,105,108,112,115–118,121,125–127,129,131,132,134,136 and 2 studies were RCTs.27,119 Two studies were derivation studies for risk scores for CHADS_2_ and CHA_2_DS_2_-VASc, respectively,13,15 the remaining studies were validation studies (excluding the imaging studies that have minimal overlap in criteria examined).

Many studies examined multiple risk stratification scores concurrently. The tool most commonly examined for risk stratification was the CHADS_2_ score (27 studies13,15,27,102–107,109,110,112–116,118,119,126–132,135) Ten studies examined CHA_2_DS_2_-VASc;15,102,104,105,109,119,129,130,135 the Framingham risk score was evaluated in six studies.15,105,118,119,122,130 Six studies examined the use of echocardiography for evaluation of left atrial characteristics and stroke risk,111,117,120,123,124,133 and one study used magnetic resonance imaging (MRI) to examine this relationship.108 Finally, four studies described the predictive role of INR values for stroke risk.118,120,128,131

### Detailed Synthesis

#### CHADS_2_ Risk Tool

Twenty-seven studies directly compared CHADS_2_ risk score and its predictive ability for thromboembolic events (stroke or peripheral arterial, but excluding venous thrombus or pulmonary embolism; Table 4).13,15,27,102–107,109,110,112–116,118,119,126–132,135,136 Twenty-three of the studies included patients on oral anticoagulant therapy.27,102,103,105–107,109,110,112–116,118,119,126–128,131,132,134–136 One study examined CHADS_2_ risk and stroke outcomes among patients undergoing coronary revascularization with PCI126 one study in patients after surgical Maze procedure,107 one in elderly patients (mean age 74 years),109 two in Japanese patients,113,127 and one in Mediterranean patients.128

Table 4 Thromboembolic events by CHADS_2_ score and concomitant stroke prevention therapy (antiplatelet and/or anticoagulant) use

Study | No. of Patients | Results (Thromboembolic Event Rates) | Followup Period | Risk of Bias
Patients [underlined: on] therapy
Naganuma, 2012^131^ | 845 | CHADS_2_=0: 0.9 CHADS_2_=1: 2.5^*^ CHADS_2_=2: 2.9^*^ CHADS_2_ ≥3: 4.8^*^ ^*^Per patient-year | Median 27 months | Low
Olesen, 2012^132^ | 87,202 | [underlined: 1-year] CHADS_2_=0: 1.59^*^ [underlined: 12-year] CHADS_2_=0: 1.28^*^ ^*^Per 100 patient-years | Maximum 12 years | Low
Olesen, 2012^129^ | 47,576 | CHADS_2_=0: 1.59^*^, 1.28^**^ CHADS_2_=1: 4.92^*^, 3.61^**^ ^*^Per 100 patient-years, 1 year followup ^**^Per 100 patient-years, 12 years followup | 12 years | Low
Potpara, 2012^135^ | 345 | CHADS_2_=0: 1.8%^*^ ^*^Per 100 patient-years | Mean 12.1 years; 4,166.5 patient-years | Unclear
Poli, 2011^103^ | 3,302 | CHADS_2_=0–1: 0.1^*^ CHADS_2_=1–2: 0.7^*^ CHADS_2_=3–6: 1.2^*^ ^*^Per 100 patient-years | 10,019 patient-years, median (IQR)=2.3 (0.8–4.4) | Low
Poli, 2011^109^ | 662 | [underlined: Classic:] CHADS_2_=0: 0% CHADS_2_=1–2: 3.9% CHADS_2_=3–6: 6.2% [underlined: Revised:] CHADS_2_=0: 0% CHADS_2_=1: 4.4% CHADS_2_=2–6: 5.2% | Mean 3.6 years | Low
Ruiz-Nodar, 2011^126^ | 604 | CHADS_2_ ≤1: 5.4% CHADS_2_ >1: 4.8% | Mean 642.2 days | Low
Van Staa, 2011^105^ | 79,844 | CHADS_2_=Low: 1.0^*^ CHADS_2_=Moderate: 3.7^*^ CHADS_2_=High: 8.3^*^ ^*^number of cases per 100 patient-years | Mean 4 years | High
Ad, 2010^107^ | 385 | Of the patients that experienced stroke/TIA, the median CHADS2 score was 0.5 | Mean 32.77 months | Low
Komatsu, 2010^127^ | 344 | CHADS_2_=0: 0% CHADS_2_=1: 0% CHADS_2_=2: 1.4% CHADS_2_=3: 4.4% CHADS_2_=4: 13.5% | Mean 60 months | Low
Lip, 2010^15^ | 1,084 | CHADS_2_=0: 1.4% CHADS_2_=1–2: 2.4% CHADS_2_=3–6: 3.2% | 1 year | Low
Sadanaga, 2010^106^ | 245 | CHADS_2_=0: 0% CHADS_2_=1: 0.6% CHADS_2_=2: 0.8% CHADS_2_=3: 3.6% CHADS_2_=4: 5.9% CHADS_2_=5–6: 8.3% | Average 756 days | Low
Connolly, 2009^27^ | 18,113 | [underlined: Total Population] CHADS_2_=0–1: 0.93^*^ CHADS_2_=2: 1.22^*^ CHADS_2_=3–6: 2.44^*^ ^*^% per year [underlined: Dabigatran 110 mg] CHADS_2_=0–1: 1.06^*^ CHADS_2_=2: 1.43^*^ CHADS_2_=3–6: 2.12^*^ [underlined: Dabigatran 150 mg] CHADS_2_=0–1: 0.65^*^ CHADS_2_=2: 0.84^*^ CHADS_2_=3–6: 1.88^*^ [underlined: Warfarin] CHADS_2_=0–1: 1.05^*^ CHADS_2_=2: 1.38^*^ CHADS_2_=3–6: 2.68^*^ ^*^% per year | 2 years | Low
Crandall, 2009^112^ | 343 | CHADS_2_=0: NR^*^ CHADS_2_=1: 1.29^*^ CHADS_2_=2: 1.54^*^ CHADS_2_=3: 2.07^*^ CHADS_2_=4: 2.41^*^ CHADS_2_=5: 2.68^*^ CHADS_2_=6: NR^*^ ^*^Reported as major cardiac events (stroke, MI, death) | Mean 8.9 years | High
Masaki, 2009^113^ | 293 | [underlined: Not on Warfarin] CHADS_2_=0: 0% CHADS_2_=1–2: 7.7% CHADS_2_=3–4: 21.7% CHADS_2_=5–6: 100% [underlined: On Warfarin] CHADS_2_=0: 3.1% CHADS_2_=1–2: 4.7% CHADS_2_=3–4: 16.7% CHADS_2_=5–6: 0% | 703 days | Low
Morgan, 2009^115^ | 5,513 | CHADS<2: On warfarin: 46.08^*^ Not on warfarin: 44.5^*^ CHADS≥2: On warfarin: 116.5^*^ Not warfarin: 113.9^*^ ^*^Stroke rate per 1,000 patient-years NR by risk score | 1,025 days | High
Poli, 2009^114^ | 662 | CHADS_2_=0–1: 0^*^ CHADS_2_=1–2: 0.7^*^ CHADS_2_=3–6: 3.0^*^ ^*^Per 100 patient-years | Mean 3.1 years, 2,365 patient-years | Low
Fang, 2008^118^ | 10,932 | CHADS 0: 18.8%^*^ CHADS 1–2: 61.2%^*^ CHADS 3–6: 20.1%^*^ ^*^Risk of thromboembolism NR by risk score | Median 6 years | Low
Rietbrock, 2008^116^ | 51,807 | [underlined: Control:]^*^ CHADS_2_=0: 0.34% CHADS_2_=1: 1.09% CHADS_2_=2: 1.62% CHADS_2_=3: 3.70% CHADS_2_=4: 6.22% CHADS_2_=5: 7.52% CHADS_2_=6: 9.51% [underlined: AF:]^*^ CHADS_2_=0: 0.83% CHADS_2_=1: 1.54% CHADS_2_=2: 2.35% CHADS_2_=3: 4.29% CHADS_2_=4: 9.06% CHADS_2_=5: 11.02% CHADS_2_=6: 13.40% ^*^Number of cases per 100 person-years | Control: 2.74 years (median) AF: 2.46 years (median) | Low
Ruiz Ortiz, 2008^128^ | 1,137 | CHADS_2_=0: 2.88^*^ CHADS_2_=1: 5.8^*^ CHADS_2_=2: 5.16^*^ CHADS_2_=3: 14.78^*^ CHADS_2_≥4: 22.02^*^ ^*^Per 100 patient-years | 21 months (484 patient-years) | Low
Baruch, 2007^119^ | 7,329 | CHADS_2_=0–1: 0%^*^ CHADS_2_=1–2: 1.0%^*^ CHADS_2_=3–6: 2.3%^*^ ^*^Per patient-year | 11,245 patient-years Mean 1.5 years per patient | Low
Patients [underlined: off] therapy
Friberg, 2012 130 | 182,678 | [underlined: Unadjusted:] CHADS_2_=0: 0.9^*^ CHADS_2_=1: 4.3^*^ CHADS_2_=2: 6.1^*^ CHADS_2_=3: 9.9^*^ CHADS_2_=4: 14.9^*^ CHADS_2_=5: 16.7^*^ CHADS_2_=6: 17.2^*^ [underlined: Adjusted for aspirin:] CHADS_2_=0: 0.9^*^ CHADS_2_=1: 4.9^*^ CHADS_2_=2: 6.8^*^ CHADS_2_=3: 11.1^*^ CHADS_2_=4: 16.8^*^ CHADS_2_=5: 18.9^*^ CHADS_2_=6: 19.4^*^ ^*^Per 100 patient-years | 1.5 years | Low
Olesen, 2011^104^ | 73,538 | CHADS_2_=0: 1.24%^*^ CHADS_2_=1: 3.56%^*^ CHADS_2_=2: 5.4%^*^ CHADS_2_=3: 9.89%^*^ CHADS_2_=4: 13.7%^*^ CHADS_2_=5: 12.57%^*^ CHADS_2_=6: 17.17%^*^ ^*^Event rate for hospital admission and death due to thromboembolism per 100 person-years | 10 years | Low
Gage, 2001^13^ | 1,733 | [underlined: Unadjusted:] CHADS_2_=0: 1.2^*^ CHADS_2_=1: 2.8^*^ CHADS_2_=2: 3.6^*^ CHADS_2_=3: 6.4^*^ CHADS_2_=4: 8.0^*^ CHADS_2_=5: 7.7^*^ CHADS_2_=6: 44^*^ [underlined: Adjusted:] CHADS_2_=0: 1.9^*^ CHADS_2_=1: 2.8^*^ CHADS_2_=2: 4.0^*^ CHADS_2_=3: 5.9^*^ CHADS_2_=4: 8.5^*^ CHADS_2_=5: 12.5^*^ CHADS_2_=6: 18.5^*^ ^*^Per 100 patient-years | 1733 patients were followed up for a mean (median) of 1.2 (1.0) years | Low
Patients on [underlined: and] off therapy
Olesen, 2012^136^ | 6,438 | Age <65 (CHADS_2_=0): 0.23^*^ Age 65–74 (CHADS_2_=0): 2.05^*^ Age ≥75 (CHADS_2_=0): 3.99^*^ ^*^Per 100 person-years | Maximum 11 years. | High
Olesen, 2011^102^ | 132,372 | [underlined: No treatment:]^*^ CHADS_2_=0: 1.6% CHADS_2_=1: 4.0% CHADS_2_=2–6: 8.4% [underlined: Treatment (antiplatelet or anticoagulation):]^*^ CHADS_2_=0: 1.4% CHADS_2_=1: 2.8% CHADS_2_=2–6: 6.0% ^*^percentage of thromboembolic events per patient year | Maximum 12 years | High
Ruiz Ortiz, 2010^110^ | 796 | [underlined: On OAC:]^*^ CHADS_2_=0: 1.0 CHADS_2_=1: 0.6 CHADS_2_=2: 0.5 CHADS_2_=3: 2.4 CHADS_2_≥ 4: 2.9 [underlined: No OAC:]^*^ CHADS_2_=0: 4.1 CHADS_2_=1: 7.1 CHADS_2_=2: 5.1 CHADS_2_=3: 12.5 CHADS_2_≥4: 20.0 ^*^events per 100 patient-years | Mean 2.4 years | Low

Abbreviations: AF=atrial fibrillation; CHADS_2_=Congestive heart failure, Hypertension, Age ≥75, Diabetes mellitus, prior Stroke/transient ischemic attack (2 points); MI=myocardial infarction; No.=number; NR=not reported; OAC=oral anticoagulation

The use of CHADS_2_ to predict stroke risk varied among the studies. Four studies reported CHADS_2_ score and stroke outcomes by individual CHADS_2_ score.13,104,106,116 Nine studies investigated the classical CHADS_2_ risk as categorical variables: low (CHADS_2_=0), moderate (CHADS_2_=1–2), and high (CHADS_2_=3–6).15,27,103,105,109,114,118,119,131 Three studies examined the revised CHADS_2_ score classification as continuous variables,102,109,130 and five studies did not report results by categorical or continuous CHADS_2_ score.107,115,118,132,135 The remaining studies used varying categorical classifications.

#### CHA_2_DS_2_-VASc Risk Tool

Ten studies directly examined CHA_2_DS_2_-VASc risk score and its predictive ability for thromboembolic events (Table 5).15,102,104,105,109,129,130,132,134,135 One study examined the predictive value in elderly patients (mean age 74 years).109 Five studies had identical categorical classification of stroke risk by CHA_2_DS_2_-VASc score: low (score=0), moderate (score=1), and high (score=2–9).15,102,104,105,109 Five studies reported stroke outcomes by individual CHA_2_DS_2_-VASc score,15,104,132,134,135 while one reported stroke outcomes by CHA_2_DS_2_-VASc score from 0 to 4 points.129 Six studies examined stroke risk among patients not treated with oral anticoagulant therapy.15,102,104,129,130,132

Table 5 Thromboembolic events by CHA_2_DS_2_-VASc score and concomitant stroke prevention therapy (antiplatelet and/or anticoagulant) use

Study | No. of Patients | Results (Thromboembolic Event Rates) | Followup Period | Risk of Bias
Patients [underlined: on] therapy
Olesen, 2012^132^ | 87,202 | [underlined: 1 year:] CHA_2_DS_2_-VASc=0: 1.59^*^ [underlined: 12 years:] CHA_2_DS_2_-VASc=0: 1.28^*^ ^*^Per 100 person-years | Maximum 12 years | Low
Olesen, 2012^129^ | 47,576 | CHA_2_DS_2_-VASc=0: 0.76^*^ CHA_2_DS_2_-VASc=1: 1.44^*^ CHA_2_DS_2_-VASc=2: 2.89^*^ CHA_2_DS_2_-VASc=3: 4.22^*^ CHA_2_DS_2_-VASc=4: 4.93^*^ ^*^Rate per 100 person-years | 12 years | Low
Potpara, 2012^135^ | 345 | CHA_2_DS_2_-VASc=0: 0^*^ ^*^Per 100 patient-years | Mean 12.1 years; 4,166.5 patient-years | Unclear
Ruiz-Nodar, 2012^134^ | 590 | [underlined: Continuous:] CHA_2_DS_2_-VASc=2: 3%^*^ CHA_2_DS_2_-VASc=3: 11%^*^ CHA_2_DS_2_-VASc=4: 16%^*^ CHA_2_DS_2_-VASc=5: 20%^*^ CHA_2_DS_2_-VASc=6: 22%^*^ CHA_2_DS_2_-VASc=7: 15%^*^ CHA_2_DS_2_-VASc=8: 40%^*^ CHA_2_DS_2_-VASc=9: 50%^*^ ^*^Percent of major adverse cardiovascular events | 1 year | Low
Poli, 2011^109^ | 662 | CHA_2_DS_2_-VASc=0: 0^*^ CHA_2_DS_2_-VASc=1: 2.8^*^ CHA_2_DS_2_-VASc ≥2: 5.0^*^ ^*^Percent of patients with event during study | Mean 3.6 years | Low
Van Staa, 2011^105^ | 79,844 | CHA_2_DS_2_-VASc=0: 0.5^*^ CHA_2_DS_2_-VASc=1: 1.1^*^ CHA_2_DS_2_-VASc ≥2: 4.6^*^ ^*^Number of cases per 100 person-years | Mean 4 years | High
Lip, 2010^15^ | 1,084 | [underlined: Categorical:] CHA_2_DS_2_-VASc=0: 0.0%^*^ CHA_2_DS_2_-VASc=1: 0.6%^*^ CHA_2_DS_2_-VASc ≥2: 3.0%^*^ [underlined: Continuous:] CHA_2_DS_2_-VASc=0: 0.0%^*^ CHA_2_DS_2_-VASc=1: 0.6%^*^ CHA_2_DS_2_-VASc=2: 1.6%^*^ CHA_2_DS_2_-VASc=3: 3.9%^*^ CHA_2_DS_2_-VASc=4: 1.9%^*^ CHA_2_DS_2_-VASc=5: 3.2%^*^ CHA_2_DS_2_-VASc=6: 3.6%^*^ CHA_2_DS_2_-VASc=7: 8.0%^*^ CHA_2_DS_2_-VASc=8: 11.1%^*^ CHA_2_DS_2_-VASc=9: 100.0%^*^ ^*^Percentage of patients with event during study | 1 year | Low
Patients [underlined: off] therapy
Friberg, 2012^130^ | 182,678 | [underlined: Unadjusted:] CHA_2_DS_2_-VASc=0: 0.3^*^ CHA_2_DS_2_-VASc=1: 0.9^*^ CHA_2_DS_2_-VASc=2: 2.9^*^ CHA_2_DS_2_-VASc=3: 4.6^*^ CHA_2_DS_2_-VASc=4: 6.7^*^ CHA_2_DS_2_-VASc=5: 10.0^*^ CHA_2_DS_2_-VASc=6: 13.6^*^ CHA_2_DS_2_-VASc=7: 15.7^*^ CHA_2_DS_2_-VASc=8: 15.2^*^ CHA_2_DS_2_-VASc=9: 17.4^*^ [underlined: Adjusted for aspirin:] CHA_2_DS_2_-VASc=0: 0.3^*^ CHA_2_DS_2_-VASc=1: 1.0^*^ CHA_2_DS_2_-VASc=2: 3.3^*^ CHA_2_DS_2_-VASc=3: 5.3^*^ CHA_2_DS_2_-VASc=4: 7.8^*^ CHA_2_DS_2_-VASc=5: 11.7^*^ CHA_2_DS_2_-VASc=6: 15.9^*^ CHA_2_DS_2_-VASc=7: 18.4^*^ CHA_2_DS_2_-VASc=8: 17.9^*^ CHA_2_DS_2_-VASc=9: 20.3^*^ ^*^Per 100 patient-years | 1.5 years | Low
Olesen, 2011^104^ | 73,538 | [underlined: Categorical:]^*^ CHA_2_DS_2_-VASc=0: 0.66 CHA_2_DS_2_-VASc=1: 1.45 CHA_2_DS_2_-VASc ≥2: 5.72 [underlined: Continuous:]^*^ CHA_2_DS_2_-VASc=0: 0.66 CHA_2_DS_2_-VASc=1: 1.45 CHA_2_DS_2_-VASc=2: 2.92 CHA_2_DS_2_-VASc=3: 4.28 CHA_2_DS_2_-VASc=4: 6.46 CHA_2_DS_2_-VASc=5: 9.97 CHA_2_DS_2_-VASc=6: 12.52 CHA_2_DS_2_-VASc=7: 13.96 CHA_2_DS_2_-VASc=8: 14.10 CHA_2_DS_2_-VASc=9: 15.89 ^*^Rate for hospital admission and death due to thromboembolism per 100 person-years | 10 years | Low
Patients on [underlined: and] off therapy
Olesen, 2011^102^ | 132,372 | [underlined: VKA:]^*^ CHA_2_DS_2_-VASc=0: 0.7% CHA_2_DS_2_-VASc=1: 1.1% CHA_2_DS_2_-VASc [underlined: >] ≥2: 3.1% [underlined: ASA:]^*^ CHA_2_DS_2_-VASc=0: 1.1% CHA_2_DS_2_-VASc=1: 1.8% CHA_2_DS_2_-VASc ≥2: 6.3% [underlined: No antithrombotic:]^*^ CHA_2_DS_2_-VASc=0: 0.9% CHA_2_DS_2_-VASc=1: 1.7% CHA_2_DS_2_-VASc ≥2: 6.3% ^*^Percentage per patient-year | 12 years | High

Abbreviation: ASA=aspirin; CHA_2_DS_2_-VASc=Congestive heart failure/left ventricular ejection fraction ≤ 40%, Hypertension, Age ≥75 (2 points), Diabetes mellitus, prior Stroke/transient ischemic attack/thromboembolism (2 points), Vascular disease, Age 65–74, Sex category female; VKA=vitamin K antagonist

#### Framingham Risk Tool

Six studies reported the association of Framingham risk and stroke events among patients with AF (Table 6).15,105,118,119,122,130 All studies reported the individual risk factors associated with Framingham risk. Three studies reported stroke outcomes in patients without oral anticoagulant therapy,15,122,130 and one study where all patients were on oral anticoagulant therapy.119

Table 6 Thromboembolic events by Framingham risk score and concomitant stroke prevention therapy (antiplatelet and/or anticoagulant) use

Study | No. of Patients | Results (Thromboembolic Rates) | Followup Period | Risk of Bias
Patients [underlined: on] therapy
Van Staa, 2011^105^ | 79,844 | Low: 1.8^*^ Moderate: 4.3^*^ High: 9.5^*^ ^*^Per 100 patient-years | 4 years | High
Fang, 2008^118^ | 10,932 | Low: 0.81% (95% CI 0.66% to 0.99%)^*^ Moderate: NR High: 3.9% (95% CI 3.4% to 4.5%)^*^ ^*^Annual thromboembolism rate | Median 6.0 years | Low
Baruch, 2007^119^ | 7,329 | Low: 0.7%^*^ Moderate: 1.4%^*^ High: 2.7%^*^ ^*^Per patient-year | Mean 1.5 years | Low
Patients on [underlined: and] off therapy
Friberg, 2012^130^ | 182,678 | Low: 1.8^*^ Moderate: 5.9^*^ High: 11.8^*^ ^*^Event rate per 100 years at risk | 1.5 years | Low
Lip, 2010^15^ | 1,084 | [underlined: Not on Anticoagulation at baseline:]^*^ Low: 1.2% Moderate: 3.2% High: 4.6% [underlined: Not on Anticoagulation at baseline and 1 year:]^*^ Low: 1.0% Moderate: 1.2% High: 3.5% ^*^Incidence of thromboembolic events | 1 year | Low
Use of therapy uncertain (no VKA, but antiplatelet use NR)
Wang, 2003^122^ | 705 | NR by category | 4.3 years | Low

Abbreviations: No.=number; NR=not reported; VKA=vitamin K antagonist

#### Imaging Risk Tool

Seven studies examined specific anatomical findings on imaging studies and the association with stroke risk in patients with AF (Table 7).108,111,117,120,123,124,133 One study used MRI and magnetic resonance angiography (MRA) quantification of left atrial appendage (LAA) dimensions.108 Four studies utilized transesophageal echocardiography to examine imaging parameters or findings associated with stroke risk in patients with AF,111,117,123,124 and two used both transesophageal echocardiography and transthoracic echocardiography.120,133

Table 7 Thromboembolic events by echocardiographic criteria and concomitant stroke prevention therapy (antiplatelet and/or anticoagulant) use

Study | No. of Patients | Features Examined | Results | Risk of Bias
Patients on [underlined: and] off therapy
Tamura, 2012^133^ | 179 | LAA wall velocity | Relative risk 3.86 of recurrent stroke in patients with low TTE-LAWV (<8.7 cm/sec) compared to high TTE-LAWV | Low
Beinart, 2011^108^ | 144 | LAA volume LAA depth LAA neck (short and long axes) Number of LAA lobes | LAA neck dimension (short x long axis): OR 3.59 per cm2 (95% CI 1.93–6.69, p<0.001) | Low
Nair, 2009^111^ | 226 | Presence or absence of LA thrombus on TEE | No difference in stroke rates in patients with LA thrombus vs. those without LA thrombus (7% vs. 4%, p=NS) | Low
Okuyama, 2008^117^ | 192 | LAA spontaneous contrast LAA thrombus LAA peak flow velocity (cm/s) LAA peak flow velocity ≤20cm/s LAA area LAA wall velocity LAA intensity variation LAA intensity variation ≤9.2 dB | Decreased LAA intensity variation (HR 5.24; 95% CI 1.81 to 16.4) | Low
Stollberger, 2004^120^ | 409 | [underlined: TTE:] LV fractional shortening Reduced LV systolic function LA diameter Valvular abnormalities [underlined: TEE:] LAA thrombus Spontaneous echo contrast LAA size LAA length LAA width LAA area, mean | None significant in multivariate analysis | Low
Stoddard, 2003^123^ | 272 | LA diameter LVEF LVEF<40% LA SEC Aortic plaque ≥5 mm Mobile PFO ≥grade 2 MV/AV strands Atrial septal aneurysm Mitral stenosis | LA thrombus (OR 7.7, 95% CI 2.7 to 21.6) | Low
Miyazaki, 2001^124^ | 89 | LA dimension LV end-diastolic dimension LV fractional shortening Moderate to severe MR LAA velocity (cm/s) LAA size LA SEC LAA thrombus present | LAA thrombus (chi-square 5.5, p=0.019) LAA dysfunction (chi-square 4.0, p=0.045) | Low

Abbreviations: AV=aortic valve; CI=confidence interval; HR=hazard ratio; LA=left atrial; LAA=left atrial appendage; LV=left ventricular; LVEF=left ventricular ejection fraction; MR=mitral regurgitation; MV=mitral valve; NS=not statistically significant; OR=odds ratio; PFO=patent foramen ovale; SEC=spontaneous echocardiographic contrast; TEE=transesophageal echocardiography; TTE=transthoracic echocardiography; TTE-LAWV=transthoracic echocardiographic LAA wall velocity

In the study examining MRI/MRA characteristics, 144 patients with nonvalvular AF not on warfarin underwent MRI/MRA prior to catheter ablation for AF.108 LAA volume, LAA depth, short and long axes of LAA neck, and numbers of lobes and their association with stroke risk were examined. In univariate analysis, LAA volume, LAA depth, and short and long axes of LAA neck were significantly associated with stroke risk. In multivariate analysis, the only MRI/MRA characteristic significant in the stroke prediction model was product of the short and long axes of the LAA neck (odds ratio [OR] 3.59; 95% CI 1.93 to 6.69; p<0.001).

#### International Normalized Ratio (INR) Tool

Four studies evaluated the predictor role of INR and its association with stroke risk in patients with AF.115,121,125,131 One study considered the INR value on hospital admission,121 one considered the time in therapeutic range (TTR) of INR,115 and one study considered both TTR and the standard deviation of transformed INR.125 In one study of 6,108 patients, investigators examined the rate of stroke events on patients treated with warfarin after a mean followup of 1,025.1 days.115 The study reported that only patients with CHADS_2_ ≥2 and a TTR for warfarin (INR 2.0–3.0) of 71–100 percent during the study had a signification reduction in stroke risk (HR 0.20; 95% CI 0.05 to 0.82; p=0.025). A second study of 13,559 patients on warfarin showed that an INR of <2.0 compared with an INR ≥2.0 independently increased the odds of a severe stroke in a multivariate model (OR 1.9; 95% CI 1.1 to 3.4).121 The third study examined 19,180 patients on warfarin to determine if INR variability (standard deviation of transformed INR [SDT_INR_]) has better predictive value for stroke events than TTR.125 The HR for stroke events was higher for the SDT_INR_ than for the TTR (1.30; 95% CI 1.22 to 1.39 vs. 1.06; 95% CI 1.00 to 1.13). The final study examined the thromboembolism rate in elderly Japanese patients (≥70 years old) with AF across INR values.131 The thromboembolism rates (per patient-year) for patients with INR ≤1.49, 1.50–1.99, 2.00–2.49, 2.50–2.99, and ≥3.00 were 12.6, 2.7, 2.8, 0.9, and 2.9 percent, respectively.

#### Summary—Comparison of Stroke Risk Scores and Meta-Analysis Results

Comparison of risk scores between study populations was complicated by some studies assessing risk of events with patients on therapy, others with patients no on any therapy, and finally others with patients who could be on or off antiplatelet or anticoagulation therapies. Second, the vast majority of studies did not clinical validate thromboembolic events, instead relying on administrative claims data, chart review, or other electronic methods for capturing data retrospectively. Identification of these events and comparison across studies was further complicated by the lack of standard definitions for defining thromboembolic events, which could have affected the estimates of the performance of these risk scores. Finally, not all studies reported c-statistics to help with determining the discrimination of the risk prediction tools in the selected population making cross study comparisons difficult.

A total of 10 studies directly investigated at least 2 risk scores of interest in the same population. Three studies used the same population to examine the performance of the CHADS_2_, Framingham, and CHA_2_DS_2_-VASc scores.105,119,130 These studies showed similar performance of all three scores in the same population, with similar c-statistics ranging from 0.56–0.67. Three studies used the same population to assess the risk discrimination of CHADS_2_ and CHA_2_DS_2_-VASc,104,109,129 with c-statistics ranging from 0.60–0.89 overall, but with similar performance of the two scores in the same population. Three studies used the same population of patients to examine the CHADS_2_ and Framingham risk scores, with similar performance of the two risk scores in the same populations.15,118,122 Only one study compared CHADS2-VASc and Framingham risk scores in the same population with a c-statistic of 0.67 for the former (continuous variables) versus 0.64 for the latter.130 These findings suggest that all three of these risk scores perform similarly when used in the same populations.

Table 8 provides a summary of available c-statistics for discrimination accuracy of the risk scores of interest. This table demonstrates both a range of scoring systems evaluated (continuous vs. categorical) as well as a range of c-statistics across studies, with the CHADS_2_ score c-statistic estimates ranging from 0.52–0.82, the Framingham scores ranging from 0.62–0.69, and the CHA_2_DS_2_-VASc ranging from 0.52–0.89.

Table 8 C-statistics from studies comparing stroke risk scores of interest

Study | CHADS_2_ | Framingham | CHA_2_DS_2_-VASc
Friberg, 2012^130^ | [underlined: Continuous:] 0.66 (95% CI 0.65 to 0.66) [underlined: Categorical (Revised):] 0.61 (95% CI 0.61 to 0.62) [underlined: Categorical (Classic):] 0.64 (95% CI 0.64 to 0.65) | [underlined: Continuous:] 0.67 (95% CI 0.66 to 0.67) [underlined: Categorical:] 0.64 (95% CI 0.64 to 0.65) | [underlined: Continuous:] 0.67 (95% CI 0.67 to 0.68) [underlined: Categorical:] 0.56 (95% CI 0.56 to 0.57)
Olesen, 2012^129^ | [underlined: Categorical:] 0.63 (95% CI 0.62 to 0.65) | - | [underlined: Continuous:] 0.66 (95% CI 0.65 to 0.68)
Potpara, 2012^135^ | [underlined: Categorical:] [underlined: 0.58] (95% CI 0.38 to 0.79) | - | Categorical: 0.72 (95% CI 0.61 to 0.84)
Olesen, 2011^104^ | Covariates analyzed as categorical variables: [underlined: Continuous:] 0.78 (95% CI 0.76 to 0.80) [underlined: Categorical:] 0.81 (95% CI 0.80 to 0.83) Covariates analyzed as continuous variables: [underlined: Continuous:] 0.80 (95% CI 0.79 to 0.82) [underlined: Categorical:] 0.81 (95% CI 0.80 to 0.83) | - | Covariates analyzed as categorical variables: Continuous: 0.78 (95% CI 0.76 to 0.79) [underlined: Categorical:] 0.89 (95% CI 0.88 to 0.90) Covariates analyzed as continuous variables: [underlined: Continuous:] 0.79 (95% CI 0.78 to 0.81) [underlined: Categorical:] 0.89 (95% CI 0.88 to 0.90)
Poli, 2011^109^ | [underlined: Continuous (Revised):] 0.72 (95% CI 0.64 to 0.80) [underlined: Categorical (Classic):] 0.68 (95% CI 0.61 to 0.76) [underlined: Categorical (Revised):] 0.60 (95% CI 0.51 to 0.67) | - | [underlined: Continuous:] 0.72 (95% CI 0.65 to 0.80) [underlined: Categorical:] 0.52 (95% CI 0.44 to 0.61)
Van Staa, 2011^105^ | [underlined: Continuous:] 0.66 (95% CI 0.64 to 0.68) [underlined: Categorical:] 0.65 (95% CI 0.63 to 0.67) | [underlined: Continuous:] 0.65 (95% CI 0.63 to 0.68) [underlined: Categorical:] 0.62 (95% CI 0.60 to 0.64) | [underlined: Continuous:] 0.67 (95% CI 0.65 to 0.69) [underlined: Categorical:] 0.60 (95% CI 0.59 to 0.61)
Lip, 2010^15^ | [underlined: Continuous:] 0.60 (95% CI 0.49 to 0.72) [underlined: Categorical (Classic):] 0.56 (95% CI 0.44 to 0.66) [underlined: Categorical (Revised):] 0.59 (95% CI 0.48 to 0.70) | [underlined: Continuous:] 0.69 (95% CI 0.60 to 0.78) [underlined: Categorical:] 0.64 (95% CI 0.53 to 0.74) | -
Ruiz Ortiz, 2010^110^ | [underlined: Continuous:] 0.63 (95% CI 0.55 to 0.72) | - | -
Poli, 2009^114^ | [underlined: Categorical:] All patients: 0.68 On therapy: 0.52 | - | -
Fang, 2008^118^ | [underlined: Continuous:] All patients: 0.60 [underlined: Categorical:] All patients: 0.58 Off therapy: 0.67 | [underlined: Continuous:] All patients: 0.64 [underlined: Categorical:] All patients: 0.62 Off therapy: 0.69 | -
Rietbrock, 2008^116^ | [underlined: Continuous (Classic):] 0.68 (95% CI 0.68 to 0.69) [underlined: Continuous (Revised):] 0.72 (95% CI 0.72 to 0.73) | - | -
Baruch, 2007^119^ | [underlined: Categorical (Classic):] 0.64 (95% CI 0.61 to 0.67) [underlined: Categorical (Revised):] 0.64 (95% CI 0.61 to 0.67) | [underlined: Categorical:] 0.62 (95% CI 0.59 to 0.66) | [underlined: Categorical:] 0.65 (95% CI 0.61 to 0.68)
Wang, 2003^122^ | [underlined: Categorical:] 0.62 | [underlined: Categorical:] 0.66 (SD 0.03) | -
Gage, 2001^13^ | [underlined: Continuous:] 0.82 (95% CI 0.80 to 0.84) | - | -

Abbreviations: CHADS_2_=Congestive heart failure, Hypertension, Age ≥75, Diabetes mellitus, prior Stroke/transient ischemic attack (2 points); CHA_2_DS_2_-VASc=Congestive heart failure/left ventricular ejection fraction ≤ 40%, Hypertension, Age ≥75 (2 points), Diabetes mellitus, prior Stroke/transient ischemic attack/thromboembolism (2 points), Vascular disease, Age 65–74, Sex category female; CI=confidence interval; SD=standard deviation

Sufficient data existed to permit meta-analysis of studies evaluating c-statistics for the CHADS_2_ score using a continuous score (Figure 3) and categorical score (Figure 4), the Framingham categorical score (Figure 5), and the CHA_2_DS_2_-VASc continuous score (Figure 6) and categorical score (Figure 7). Meta-analysis could not be completed for other risk scores of interest.

Figure 3 Summary estimate of c-statistics for discrimination ability of CHADS_2_ continuous stroke risk score

Abbreviations: CHADS_2_=Congestive heart failure, Hypertension, Age ≥75, Diabetes mellitus, prior Stroke/transient ischemic attack (2 points); CI=confidence interval

Figure 3. Summary estimate of c-statistics for discrimination ability of CHADS2 continuous stroke risk score. This figure displays a forest plot of 8 studies that looked at the discrimination ability of CHADS2 continuous stroke risk score. The summary c-statistic value was 0.71 (95% CI, 0.66 to 0.75).

Figure 4 Summary estimate of c-statistics for discrimination ability of CHADS_2_ categorical stroke risk score

Abbreviations: CHADS_2_=Congestive heart failure, Hypertension, Age ≥75, Diabetes mellitus, prior Stroke/transient ischemic attack (2 points); CI=confidence interval

Figure 4. Summary estimate of c-statistics for discrimination ability of CHADS2 categorical stroke risk score. This figure displays a forest plot of 8 studies that looked at the discrimination ability of CHADS2 categorical stroke risk score. The summary c-statistic value was 0.66 (95% CI, 0.61 to 0.71).

Figure 5 Summary estimate of c-statistics for discrimination ability of Framingham categorical stroke risk score

Abbreviation: CI=confidence interval

Figure 5. Summary estimate of c-statistics for discrimination ability of Framingham categorical stroke risk score. This figure displays a forest plot of 5 studies that looked at the discrimination ability of Framingham categorical stroke risk score. The summary c-statistic value was 0.63 (95% CI, 0.62 to 0.65).

Figure 6 Summary estimate of c-statistics for discrimination ability of CHA_2_DS_2_-VASc continuous stroke risk score

Abbreviations: CHA_2_DS_2_-VASc=Congestive heart failure/left ventricular ejection fraction ≤40%, Hypertension, Age ≥75 (2 points), Diabetes mellitus, prior Stroke/transient ischemic attack/thromboembolism (2 points), Vascular disease, Age 65–74, Sex category female; CI=confidence interval

Figure 6. Summary estimate of c-statistics for discrimination ability of CHA2DS2-VASc continuous stroke risk score. This figure displays a forest plot of 5 studies that looked at the discrimination ability of CHA2DS2-VASc continuous stroke risk score. The summary c-statistic value was 0.70 (95% CI, 0.66 to 0.75).

Figure 7 Summary estimate of c-statistics for discrimination ability of CHA_2_DS_2_-VASc categorical stroke risk score

Abbreviations: CHA_2_DS_2_-VASc=Congestive heart failure/left ventricular ejection fraction ≤ 40%, Hypertension, Age ≥75 (2 points), Diabetes mellitus, prior Stroke/transient ischemic attack/thromboembolism (2 points), Vascular disease, Age 65–74, Sex category female; CI=confidence interval

Figure 7. Summary estimate of c-statistics for discrimination ability of CHA2DS2-VASc categorical stroke risk score. This figure displays a forest plot of 6 studies that looked at the discrimination ability of CHA2DS2-VASc categorical stroke risk score. The summary c-statistic value was 0.66 (95% CI, 0.54 to 0.78).

These analyses demonstrated that the CHADS_2_ continuous score and the CHA_2_DS_2_-VASc continuous score have comparable discrimination abilities for stroke risk (0.71 [95% CI 0.66 to 0.75], Q=471.8 [p<0.001], I^2^=98.5; and 0.70 [95% CI 0.66 to 0.75], Q=205.4 [p<0.001], I^2^=98.1, respectively; both modest risk prediction with low strength of evidence) and greater discrimination ability than other scores. These scores are not, however, statistically significantly different from either the CHADS_2_ categorical score (0.66 [95% CI 0.61 to 0.71], Q=445.9 [p<0.001], I^2^=98.4) or the CHA_2_DS_2_-VASc categorical score (0.66 [95% CI 0.54 to 0.78], Q=2333.9 [p<0.001], I^2^=99.8). They do appear to be better predictors of risk than the Framingham categorical score (0.63 [95% CI 0.62 to 0.65], Q=6.6 [p=0.65], I^2^=39.8) given our included studies. Although the 10 studies in Table 8 provide direct comparison evidence, our meta-analysis allows us to combine findings across studies and to synthesize seemingly inconsistent findings between scores. Note that only the Framingham categorical score has limited heterogeneity, while all other scores have substantial heterogeneity, reducing the strength of evidence. Given the imprecision and inconsistency of the c-statistics in the categorical CHADS_2_ and the CHA_2_DS_2_-VASc scores, there was insufficient strength of evidence for their discrimination abilities.

#### Strength of Evidence

Table 9 summarizes the strength of evidence for the thromboembolic risk discrimination abilities of the included tools. This summary table represents only those studies that evaluated the risk discrimination abilities of the tools using a c-statistic.

Table 9 Strength of evidence domains for discrimination of thromboembolic risk

Outcome | Number of Studies (Subjects) | Domains Pertaining to SOE | | | | SOE and Magnitude of Effect (95% CI)
Outcome | Number of Studies (Subjects) | Risk of Bias | Consistency | Directness | Precision | SOE and Magnitude of Effect (95% CI)
CHADS_2_ (Categorical) | 8 (380,669) | Observational/Moderate | Inconsistent | Direct | Imprecise | SOE=Insufficient
CHADS_2_ (Continuous) | 8 (379,755) | Observational/Moderate | Inconsistent | Direct | Precise | SOE=Low Modest risk discrimination ability (c-statistic=0.71; 95% CI 0.66 to 0.75)
CHA_2_DS_2_-VASc (Categorical) | 6 (332,009) | Observational/Moderate | Inconsistent | Direct | Imprecise | SOE=Insufficient
CHA_2_DS_2_-VASc (Continuous) | 5 (371,911) | Observational/Moderate | Inconsistent | Direct | Precise | SOE=Low Modest risk discrimination ability (c-statistic=0.70; 95% CI 0.66 to 0.75)
Framingham (Categorical) | 5 (259,253) | Observational/Moderate | Consistent | Direct | Precise | SOE=Moderate Limited risk discrimination ability (c-statistic=0.63; 95% CI 0.62 to 0.65)
Framingham (Continuous) | 4 (262,151) | Observational/Moderate | Consistent | Direct | Imprecise | SOE=Low Limited risk discrimination ability (c-statistic ranges between 0.64 and 0.69 across studies)
Imaging | 0 | NA | NA | NA | NA | SOE=Insufficient
INR | 0 | NA | NA | NA | NA | SOE=Insufficient

Abbreviations: CHADS_2_=Congestive heart failure, Hypertension, Age ≥75, Diabetes mellitus, prior Stroke/transient ischemic attack (2 points); CHA_2_DS_2_-VASc=Congestive heart failure/left ventricular ejection fraction ≤ 40%, Hypertension, Age ≥75 (2 points), Diabetes mellitus, prior Stroke/transient ischemic attack/thromboembolism (2 points), Vascular disease, Age 65–74, Sex category female; CI=confidence interval; INR=international normalized ratio; NA=not applicable; SOE=strength of evidence

## Key Question 2 Predicting Bleeding Events

KQ 2: In patients with nonvalvular AF, what are the comparative diagnostic accuracy and impact on clinical decisionmaking (diagnostic thinking, therapeutic efficacy, and patient outcome efficacy) of clinical tools and associated risk factors for predicting bleeding events?

### Key Points

- Comparison of risk scores between study populations was complicated by multiple factors. First, included studies used different approaches to calculating bleeding risk scores of interest due to unavailable data, such as genetic factors in HEMORR_2_HAGES or data on INR lability for HAS-BLED. Second, some studies were unable to validate clinical bleeding events, which could have affected their estimates of the performance of these risk scores. Third, although studies consistently reported event rates and c-statistics, measures of calibration, strength of association, and diagnostic accuracy were inconsistently reported.
- Among AF patients on warfarin, 9 studies (6 good quality, 2 fair quality, 1 poor quality; 319,183 patients) compared different risk scores (Bleeding Risk Index [BRI], HEMORR_2_HAGES, HAS-BLED, and ATRIA) in predicting major bleeding events. These studies differed markedly in population, major bleeding rates, and statistics reported for evaluating risk prediction scores for major bleeding events. Limited evidence favors HAS-BLED based on two studies demonstrating that it has significantly higher discrimination (by c-statistic) for major bleeding events than other scores among patients on warfarin, but the majority of studies showed no statistically significant differences in discrimination, reducing the strength of evidence. One study showed that HAS-BLED had a significantly higher net reclassification improvement (NRI) than ATRIA for patients on warfarin, while another showed that HAS-BLED had a significantly higher NRI than three other scores in a mixed group of patients on and off warfarin (low strength of evidence).
- Among AF patients on warfarin, 1 study (good quality; 48,599 patients) compared HEMORR_2_HAGES and HAS-BLED in predicting intracranial hemorrhage (ICH). This study showed no statistically significant difference in discrimination between the two scores (low strength of evidence).
- Among AF patients on aspirin alone, 3 studies (2 good quality, 1 fair quality; 177,538 patients) comparing different combinations of bleeding risk scores (BRI, HEMORR_2_HAGES, and HAS-BLED) in predicting major bleeding events showed no statistically significant differences in discrimination (low strength of evidence).
- Among AF patients not on antithrombotic therapy, 6 studies (4 good quality, 2 fair quality; 310,607 patients) comparing different combinations of bleeding risk scores (BRI, HEMORR_2_HAGES, HAS-BLED, and ATRIA) in predicting major bleeding events showed no statistically significant differences in discrimination (low strength of evidence).

### Description of Included Studies

An expert panel recently recommended that, following stroke risk assessment, bleeding risk for all patients with AF be assessed using an available scoring tool.101 The factors comprising the bleeding risk scores of interest (Table 10), as well as other risk factors not included in these scores (e.g., small vessel disease, cerebral amyloid angiopathy, and particular ApoE genotypes), are all individually associated with bleeding risk in patients with AF based on available data. In order to inform clinical decisionmaking regarding the net clinical benefit of anticoagulation, we have focused this review on studies evaluating the risk scores most typically utilized for prospective estimation of bleeding risk in clinical settings. Multiple studies evaluated CHADS_2_ and CHA_2_DS_2_-VASc, which are risk scores validated for thromboembolic risk prediction, as predictors of bleeding events; however, because these scores are not used clinically for estimation of bleeding risk, we did not include them in our analysis.

Table 10 Description and interpretation of included bleeding risk scores

Bleeding Risk Score | Reference | Risk Factors Included | Interpretation
ATRIA | Fang, 2011^137^ | Anemia, renal disease (CrCl <30) (3 points each); age ≥75 (2 points); any prior bleeding, hypertension (1 point each) | Low (0–3), moderate (4), high (5–10)
BRI | Beyth, 1998^148^ | Age ≥65, GI bleed in past 2 weeks, previous stroke, comorbidities (recent MI, hematocrit <30%, diabetes, creatinine >1.5), with 1 point for presence of each condition and 0 if absent | low (0), moderate (1–2), high (3–4)
HAS-BLED | Pisters, 2010^16^ | Hypertension, abnormal renal (CrCl <50) or liver function (1 point each); stroke, bleeding history or predisposition, labile INR (TTR <60%), age >65, drugs of interest/alcohol (1 point each) | Low (0), moderate (1–2), high (≥3)
HEMORR_2_HAGES | Gage, 2006^140^ | Liver/renal disease, ethanol abuse, malignancy, age >75, low platelet count or function, re-bleeding risk, uncontrolled hypertension, anemia, genetic factors (CYP2C9), risk of fall or stroke (1 point for each risk factor present with 2 points for previous bleed) | low (0–1), moderate (2–3), high (≥4)

Abbreviations: ATRIA=Anticoagulation and Risk Factors in Atrial Fibrillation; BRI=Bleeding Risk Index; CrCl=creatinine clearance; GI=gastrointestinal; HAS-BLED=Hypertension, Abnormal renal/liver function, Stroke, Bleeding history or predisposition, Labile international normalized ratio, Elderly (> 65 years), Drugs/alcohol concomitantly; HEMORR_2_HAGES=Hepatic or renal disease, Ethanol abuse, Malignancy, Older (age >75 years), Reduced platelet count or function, Re-bleeding risk (2 points), Hypertension (uncontrolled), Anemia, Genetic factors, Excessive fall risk, Stroke; INR=international normalized ratio; MI=myocardial infarction; TTR=time in therapeutic range

Seventeen studies described in 18 papers met our inclusion criteria (Appendix Table F-2).16,102,103,121,125,130,131,134,137–146 Two articles reporting analyses based on the ATRIA study cohort121,137 are counted here as one study grouping due to overlapping patient populations; they address different research questions and are represented in separate rows of Appendix Table F-2 and in separate sections under “Detailed Synthesis,” below. Apart from a shared focus on outpatient settings, the included studies varied in geographical location, study design, quality, and patient characteristics. Five studies analyzed prospective data (including data from RCTs),16,103,130,138,143 while 12 analyzed retrospective data (including registries).102,121,125,131,134,137,139–142,144–146 Ten studies were conducted in Europe,16,102,103,125,130,134,142,144–146 four in the United States,121,137,139–141 and one in Asia;131 one study was multinational,143 and another did not report geographical location.138 Eleven studies were multicenter,16,102,103,121,130,137–140,142,143,146 four were single-site,131,141,144,145 and study site data were not reported for two studies.125,134 Eleven studies were conducted primarily in the outpatient setting,16,121,125,130,131,137–141,144,145 three did not report setting, and103,134,143 three were conducted in the inpatient setting.102,142,146 Of the 17 studies, 6 did not report funding source;102,125,134,142,145,146 3 used exclusively industry funding;16,138,143 2 used exclusively government funding;139,144 2 were unfunded;103,141 1 used funding exclusively from nongovernment, nonindustry sources;131 and 3 used funding from multiple sources.121,130,137,140 Eight studies were of good methodological quality,16,121,130,137–139,141–143 6 were of fair quality,103,131,134,140,144,146 and 3 were of poor quality.102,125,145

Studies enrolled patients between 1995 and 2010. The number of patients included in studies ranged from fewer than 600^134^ to 170,291,^130^ with overlap in patient populations between some studies; altogether, the included studies analyzed data from approximately 250,000 unique patients. The mean age of study participants ranged from 65–80 years. The proportion of male patients ranged from approximately 40–60 percent. None of the studies presented data on ethnicity of subjects, and only one presented data on race (81% white).141 Study followup duration ranged from 1–12 years. Each of the study populations included patients with paroxysmal, persistent, and permanent AF.

Regarding the outcomes assessed, 17 studies reported evaluated bleeding risk prediction scores with respect to major bleeding.16,102,103,125,130,131,134,137–146 Two studies evaluated bleeding risk prediction scores with respect to intracranial hemorrhage (ICH) as a separate outcome (ICH was also included in definitions of major bleeding),121,130 and one study reported these outcomes with respect to minor bleeding.141 Clinical tools of interest included risk scores and INR indices (INR, time in therapeutic range [TTR], and standard deviation of transformed INR [SDT_INR_]; Table 10).

Included studies most often presented data for the categorical versions of bleeding risk scores (i.e., risk score categorized as “low,” “medium,” or “high”), though some also presented data for continuous versions of the scores. When available, we present data for both categorical and continuous scores. Included studies consistently presented results using bleeding event rates (either bleeding events per 100 patient-years or percent of individuals experiencing a bleeding event within the followup period) and reported model discrimination using c-statistics. Measures of calibration, strength of association, and measures of diagnostic accuracy were inconsistently reported. The c-statistic, or area under the receiver operating characteristic curve, may not be optimal in assessing models that predict future risk or stratify individuals into risk categories,147 but it is a commonly reported statistic for characterizing a predictive model’s discrimination. Because studies included in this section generally used the c-statistic to characterize risk scores, we have used it as a basis for comparing these scores within a given study population, while also keeping in mind its limitations. We do not directly compare data from different studies, as this would not be appropriate given inter-study differences in patient population, followup times, and definitions of outcomes. A few studies presented other means for comparing bleeding risk scores, such as net reclassification improvement (NRI), and we provide this information when available.

### Detailed Synthesis

#### Major Bleeding

##### Overview

A total of 16 studies evaluated various risk scores for estimating major bleeding risk in patients with AF, including patients on warfarin, aspirin, and no antithrombotic therapy.16,102,103,130,131,134,137–146 In general, major bleeding constituted clinically significant bleeding episodes; however, differences existed in the definitions of major bleeding used in different studies. Large database and registry studies used standard sets of International Classification of Diseases, 9^th^ Revision (ICD-9) codes, while other studies cited the 2005 International Society on Thrombosis and Haemostasis (ISTH) criteria for major bleeding.149 This heterogeneity in the definitions of major bleeding used by the included studies is a limiting factor in comparing data across study populations for this KQ.

Studies most commonly evaluated tools among AF patients on warfarin, though some also provided data on other populations. Different studies compared scores for predicting major bleeding and utilized different statistics to describe their findings; studies most commonly presented major bleeding event rates and c-statistics. Results are presented below by risk score. The final subsection below presents a table summarizing available c-statistics for the risk scores among patients on different antithrombotic therapies. Due to the limited number of studies available, the variability in the application the scores, the differences in the definitions of bleeding outcomes, and the heterogeneity in the populations studied quantitative meta-analysis was not possible for the studied risk scores.

##### Bleeding Risk Index (BRI)

The Bleeding Risk Index (BRI), also known as the Outpatient Bleeding Risk Index, was evaluated in seven included studies among patients with AF with and without anticoagulation.103,137–141,146 Five of these studies compared BRI with other risk scores of interest, while two did not provide comparisons with other risk scores of interest. Multiple studies presented major bleeding event rate data for BRI stratified by risk level among patients on warfarin (Table 11). Although different study populations had variable incidence of bleeding events, bleeding event rate generally increased with increased BRI in all studies for patients taking warfarin.

Table 11 Summary of results for studies evaluating BRI among patients on warfarin

Study | Non Warfarin | Followup | Bleeding Event Rates | C-statistic^a^ | Risk of Bias
Lip, 2012^146^ | 3,607 | NR | NR | Categorical: 0.56 (95% CI 0.53 to 0.59) Continuous: 0.60 (95% CI 0.56 to 0.63) | Unclear
Fang, 2011^137^ | 3,063 | Median 3.5 years | Low=0.39 events/100 patient-years Moderate=1.31 High=3.96 | Categorical: 0.59 (95% CI 0.58 to 0.61) Continuous: 0.68 (95% CI 0.65 to 0.70) | Low
Lip, 2011^138^ | 3,665 | Mean 499 days | Low=2.1% with bleeding event Moderate=3.9% High=4.0% | 0.56 (95% CI 0.51 to 0.60) | Low
Poli, 2011^103^ | 3,302 | Median 2.3 years | Low=0.95 events/100 patient-years Moderate=1.26 (BRI=1), 1.22 (BRI=2) High=1.74 | NR | Low
Gage, 2006^140^ | 1,604 | Mean 0.82 years | Low=1.1 events/100 patient-years Moderate=4.9 High=8.8 | 0.65 (SE 0.03) | Low
Shireman, 2006^139^ | 26,345 | 90 days | Low=0% with bleeding event Moderate=1% High=2.5% | 0.61 | Low
Aspinall, 2005^141^ | 543 with AF | Mean 1.02 years | Low=0% with bleeding event Moderate=2.3% High=11.1% | NR | Low

a C-statistics given are for categorical risk scores unless otherwise noted.

Abbreviations: AF=atrial fibrillation; BRI=Bleeding Risk Index; CI=confidence interval; N=number of participants; NR=not reported; SE=standard error

Among patients on warfarin, c-statistics for the categorical BRI ranged from 0.56–0.65, demonstrating moderate strength of evidence for limited risk discrimination ability (Table 11).137–140,146 Three studies presented c-statistics for the categorical BRI in other populations; for patients on aspirin alone, one study reported a c-statistic of 0.69,^140^ while for patients not on antithrombotic therapy, c-statistics ranged from 0.50–0.65.^138,140,146^

##### HEMORR_2_HAGES

HEMORR_2_HAGES was evaluated in eight included studies among patients with AF with and without anticoagulation.16,130,137,138,140,142,143,146 Each of these eight studies compared HEMORR_2_HAGES with at least one other risk score of interest. Of note, one issue with the included studies is that different studies used different approaches to calculating patients’ HEMORR_2_HAGES score. Due to unavailability of information on genetic factors, multiple database studies left out the “genetic factors” component of the score130,137,140,143,146 and so were, in effect, evaluating a modified HEMORR_2_HAGES. Not all studies described in detail whether certain factors were omitted from their HEMORR_2_HAGES calculation. Inter-study differences in approach to calculating HEMORR_2_HAGES limited our ability to compare data across populations.

Multiple studies presented major bleeding event rate data for HEMORR_2_HAGES among patients on warfarin, either continuous or stratified by risk level (Table 12). Although different study populations had variable incidence of bleeding events, bleeding event rate generally increased with increased HEMORR_2_HAGES in all studies for patients taking warfarin.

Table 12 Summary of results for studies evaluating HEMORR_2_HAGES among patients on warfarin

Study | N on Warfarin | Followup | Bleeding Event Rates | C-statistic^a^ | Risk of Bias
Apostolakis, 2012^143^ | 4,576 | Mean 429 days | Low=1.4% with bleeding event Moderate=2.5% High=7.7% 0=1.0% with bleeding event 1=1.8% 2=2.1% 3=4.7% ≥4=7.6% | 0.60 (95% CI 0.51 to 0.69) | Low
Friberg, 2012^130^ | 48,599 | Mean 1.4 years | 0=0.6% with bleeding event/yr 1=1.7% 2=2.2% 3=3.0% 4=4.4% 5=6.0% 6=7.1% 7=9.6% 8=19.3% 9=0.0% | 0.63 (95% CI 0.61 to 0.64) | Low
Lip, 2012^146^ | 3,607 | NR | NR | Categorical: 0.53 (95% CI 0.50 to 0.57) Continuous: 0.59 (95% CI 0.56 to 0.62) | Unclear
Fang, 2011^137^ | 3,063 | Median 3.5 years | Low=0.72 events/100 patient-years Moderate=2.49 High=3.96 | Categorical: 0.67 (95% CI 0.65 to 0.70) Continuous: 0.71 (95% CI 0.69 to 0.73) | Low
Lip, 2011^138^ | 3,665 | Mean 499 days | Low=3.0% with bleeding event Moderate=6.1% High=2.0% (based on only 2.7% of population) | 0.61 (95% CI 0.56 to 0.65) | Low
Olesen, 2011^142^ | 44,771 | Mean 10 years | Low=3.06 events/100 patient-years Moderate=6.33 High=12.16 | Categorical: 0.78 (95% CI 0.75 to 0.82) Continuous: 0.77 (95% CI 0.73 to 0.81) | High
Pisters, 2010^16^ | 1,706 | Mean 1 year | NR | 0.64 (95% CI 0.53 to 0.75) | Low
Gage, 2006^140,b^ | 1,604 | Mean 0.82 years | 0=1.9 events/100 patient-years 1=2.5 2=5.3 3=8.4 4=10.4 ≥5=12.3 | 0.67 (SE 0.04) | Low

a C-statistics given are for categorical risk scores unless otherwise noted.

b Derivation study.

Abbreviations: CI=confidence interval; HEMORR_2_HAGES=Hepatic or renal disease, Ethanol abuse, Malignancy, Older (age >75 years), Reduced platelet count or function, Re-bleeding risk (2 points), Hypertension (uncontrolled), Anemia, Genetic factors, Excessive fall risk, Stroke; N=number of participants; SE=standard error

Among patients on warfarin, c-statistics for the categorical HEMORR_2_HAGES ranged from 0.53–0.78, demonstrating moderate strength of evidence for limited risk discrimination ability (Table 12).16,130,137,138,140,142,143,146 Six studies presented c-statistics for HEMORR_2_HAGES in other populations; for patients on aspirin alone, c-statistics ranged from 0.60–0.83,^16,130,140^ while for patients not on antithrombotic therapy, c-statistics ranged from 0.50–0.81.^16,130,138,140,142,146^

##### HAS-BLED

HAS-BLED was evaluated in 10 included studies among patients with AF with and without anticoagulation.16,130,131,134,138,142–146 Seven of these studies compared HAS-BLED with at least one other risk score of interest. Of note, some studies excluded patients with labile INR and so quantified “labile INR”’ as 0 for all patients;130,144,145 these studies were, in effect, evaluating a modified HAS-BLED. One study also excluded the “drugs” component of the HAS-BLED score.130 Not all studies described in detail how they calculated the HAS-BLED score within their population. Inter-study differences in approach to calculating HAS-BLED limited our ability to compare data across populations.

Multiple studies presented major bleeding event rate data for HAS-BLED among patients on warfarin, either continuous or stratified by risk level (Table 13). Although different study populations had variable incidence of bleeding events, bleeding event rate generally increased with increased HAS-BLED in all studies for patients taking warfarin.

Table 13 Summary of results for studies evaluating HAS-BLED among patients on warfarin

Study | Non Warfarin | Followup | Bleeding Event Rates | C-statistic^a^ | Risk of Bias
Apostolakis, 2012^143^ | 4,576 | Mean 429 days | Low (<3)=1.3% with bleeding event High (≥3)=3.1% 0=1.1% with bleeding event 1=0.6% 2=1.8% 3=2.9% 4=3.4% ≥5=7.7% | 0.65 (95% CI 0.56 to 0.73) | Low
Friberg, 2012^130^ | 48,599 | Mean 1.4 years | 0=0.0% with bleeding event/year 1=0.7% 2=1.9% 3=2.4% 4=3.4% 5=5.7% 6=15.5% 7=0% | 0.61 (95% CI 0.59 to 0.62) | Low
Gallego, 2012^144^ | 965 | Median 861 days | 0=0.0% with bleeding event/year 1=1.2% 2=2.2% 3=5.9% 4=7.0% ≥5=19.4% | 0.70 (95% CI 0.64 to 0.76) | Unclear
Lip, 2012^146^ | 3,607 | NR | NR for patients on warfarin | Categorical: 0.58 (95% CI 0.55 to 0.61) Continuous: 0.61 (95% CI 0.58 to 0.65) | Unclear
Naganuma, 2012^131^ | 845 | Median 27 months | Low (<3)=2.0% with bleeding event High (≥3)=5.6% | NR | Low
Roldan, 2012^145^ | 937 | Median 952 days | 0=0.0% with bleeding event/year 1=0.8% 2=1.9% 3=5.7% 4=5.6% ≥5=16.48% | Categorical: 0.68 (95% CI 0.65 to 0.71) Continuous: 0.71 (95% CI 0.68 to 0.74) | Unclear
Lip, 2011^138^ | 3,665 | Mean 499 days | Low=0.9% with bleeding event Moderate=3.7% High=6.7% 0=0.9% with bleeding event 1=3.4% 2=4.1% 3=5.8% 4=8.9% 5=9.1% 6=0% | 0.66 (95% CI 0.61 to 0.70) | Low
Olesen, 2011^142^ | 44,771 | Mean 10 years | Low=2.66 events/100 patient-years Moderate=5.54 High=8.11 | Categorical: 0.80 (95% CI 0.76 to 0.83) Continuous: 0.80 (95% CI 0.76 to 0.83) | High
Pisters, 2010^16,b^ | 1,722 | Mean 1 year | 0=1.13 events/100 patient-years (includes patients off warfarin) 1=1.02 2=1.88 3=3.74 4=8.70 5=12.50 6=0.0 7–9=no patients | 0.69 (95% CI 0.59 to 0.80) | Low

a C-statistics given are for categorical risk scores unless otherwise noted.

b Derivation study.

Abbreviations: CI=confidence interval; HAS-BLED=Hypertension, Abnormal renal/liver function, Stroke, Bleeding history or predisposition, Labile international normalized ratio, Elderly (> 65 years), Drugs/alcohol concomitantly; N=number of participants; NR=not reported

Among patients on warfarin, c-statistics for the categorical HAS-BLED ranged from 0.58–0.80, demonstrating moderate strength of evidence for modest risk discrimination ability (Table 13).16,130,138,142–146 Five studies presented c-statistics for HAS-BLED in other populations; for patients on aspirin alone, c-statistics ranged from 0.59–0.91,^16,130^ while for patients not on antithrombotic therapy, c-statistics ranged from 0.60–0.81.^16,130,138,142,146^

Of note, one study provided event data for HAS-BLED ≤2 and ≥3 using a complicated matrix in which results were stratified by CHADS_2_, CHA_2_DS_2_-VASc, and treatment status.102 Because the primary goal of this analysis was to evaluate the net clinical benefit of antithrombotic treatment versus no treatment in different subgroups, these data are not presented here. Another study presented data for HAS-BLED and major bleeding event risk among patients status post coronary artery stents and showed no significant association between major bleeding event rate and HAS-BLED score ≤2 versus ≥3. Because this was a specialized population, these data are not included in Table 13.

##### ATRIA

ATRIA was evaluated in four included studies among patients with AF with and without anticoagulation.137,143,145,146 All of these studies compared ATRIA with other risk scores of interest. Multiple studies presented major bleeding event rate data for ATRIA stratified by risk level among patients on warfarin (Table 14). Although different study populations had variable incidence of bleeding events, bleeding event rate generally increased with increased ATRIA in all studies for patients taking warfarin.

Table 14 Summary of results for studies evaluating ATRIA among patients on warfarin

Study | N on Warfarin | Followup | Bleeding Event Rates | C-statistic^a^ | Risk of Bias
Apostolakis, 2012^143^ | 4,576 | Mean 429 days | Low=1.5% with bleeding event Moderate=2.9% High=3.9% 0=1.2% with bleeding event 1=1.2% 2=1.9% 3=2.2% 4=2.9% 5=3.6% 6=4.0% ≥7=0.0% | 0.61 (95% CI 0.51 to 0.70) | Low
Lip, 2012^146^ | 3,607 | NR | NR | Categorical: 0.55 (95% CI 0.52 to 0.59) Continuous: 0.60 (95% CI 0.56 to 0.63) | Unclear
Roldan, 2012^145^ | 937 | Median 952 days | 0=1.1% with bleeding event/year 1=2.0% 2=2.4% 3=1.9% 4=9.1% ≥5=6.5% | Categorical: 0.59 (95% CI 0.55 to 0.62) Continuous: 0.68 (95% CI 0.65 to 0.71) | Unclear
Fang, 2011^137,b^ | 3,063 | Median 3.5 years | Low=0.83 events/100 patient-years Moderate=2.41 High=5.32 0=0.48 events/100 patient-years 1=0.58 2=0.78 3=1.27 4=2.41 5=4.18 6=5.11 7=3.56 8=23.11 9=10.13 10=16.34 | Categorical: 0.69 (95% CI 0.66 to 0.71) Continuous: 0.74 (95% CI 0.72 to 0.76) | Low

a C-statistics given are for categorical risk scores unless otherwise noted.

b Derivation study; bleeding event rate data presented is for validation cohort, c-statistic data provided for combined cohort only.

Abbreviations: CI=confidence interval; ATRIA=Anticoagulation and Risk Factors in Atrial Fibrillation; N=number of participants; NR=not reported

Among patients on warfarin, c-statistics for the categorical ATRIA ranged from 0.55–0.69, but given the inconsistency and imprecision of the findings, there was insufficient evidence to determine the risk discrimination abilities (Table 14).137,143,145,146 One study presented c-statistics for ATRIA among patients not on antithrombotic therapy: 0.59 (continuous) and 0.47 (categorical).146

##### INR

One included study evaluated the use of two INR-related statistics, TTR (% time in therapeutic INR range of 2.0–3.0) and SDT_INR_ (standard deviation of transformed INR values), in terms of impact on diagnostic thinking with respect to estimating the likelihood of major bleeding in patients with AF on warfarin.125 This study presented hazard ratios (HRs) associated with a 1 standard deviation (SD) change in each risk variable. The HR for the SDT_INR_ variable was 1.27 (95% CI 1.20 to 1.35), and the HR for TTR was 1.07 (95% CI 1.01 to 1.14).

Another included study evaluated the relationship between patient-years within an INR range and incidence of major bleeding events among patients with AF on warfarin.131 This study indicated that major bleeding incidence increased with increasing INR, but the study was not designed to evaluate the predictive accuracy of this risk factor. Major bleeding event rates per patient-year were 1.7 for INR <1.49, 1.8 for INR 1.50–1.99, 1.5 for INR 2.00–2.49, 3.4 for INR 2.50–2.99, and 20.0 for INR >3.00.

##### Comparison of Bleeding Risk Scores and Meta-Analysis Results for Major Bleeding

Comparison of risk scores between study populations was complicated by some studies’ use of administrative data sources, for 2 main reasons. First, many of the included studies used different approaches to calculating the risk scores of interest due to unavailable data (e.g., genetic factors in HEMORR_2_HAGES or data on INR lability for HAS-BLED). Second, some studies were unable to validate clinical bleeding events, which could have affected their estimates of the performance of these risk scores. For these reasons, we did not attempt meta-analysis for bleeding risk score data.

Included studies consistently used c-statistics to characterize these risk prediction scores, so we have used it as the basis for comparing these scores within study populations, while also keeping in mind its limitations as a measure of discrimination only. Table 15 provides a summary of available c-statistics for the risk scores of interest among AF patients on warfarin. Tables 16 and 17 provide the same for patients on aspirin alone and on no antithrombotic therapy, respectively. Fewer studies presented other means for comparing risk scores, such as NRI, but available data on NRI with different risk scores are presented in Table 18.

Table 15 C-statistics from studies comparing scores of interest for discrimination of major bleeding risk among patients on warfarin^a^

Study | BRI | HEMORR_2_HAGES | HAS-BLED | ATRIA
Apostolakis, 2012^143,d^ | - | 0.60 (95% CI 0.51 to 0.69) | 0.65 (95% CI 0.56 to 0.73) | 0.61 (95% CI 0.51 to 0.70)
Friberg, 2012^130,d^ | - | 0.63 (95% CI 0.61 to 0.64) | 0.61 (95% CI 0.59 to 0.62) | -
Lip, 2012^146,g^ | Categorical: 0.56 (95% CI 0.53 to 0.59) Continuous: 0.60 (95% CI 0.56 to 0.63) | Categorical: 0.53 (95% CI 0.50 to 0.57) Continuous: 0.59 (95% CI 0.56 to 0.62) | Categorical: 0.58 (95% CI 0.55 to 0.61) Continuous: 0.61 (95% CI 0.58 to 0.65) | Categorical: 0.55 (95% CI 0.52 to 0.59) Continuous: 0.60 (95% CI 0.56 to 0.63)
Roldan, 2012^145,h^ | - | - | Categorical: 0.68 (95% CI 0.65 to 0.71) Continuous: 0.71 (95% CI 0.68 to 0.74) | Categorical: 0.59 (95% CI 0.55 to 0.62) Continuous: 0.68 (95% CI 0.65 to 0.71)
Fang, 2011^137,d,f^ | Categorical: 0.59 (95% CI 0.58 to 0.61) Continuous: 0.68 (95% CI 0.65 to 0.70) | Categorical: 0.67 (95% CI 0.65 to 0.70) Continuous: 0.71 (95% CI 0.69 to 0.73) | - | Categorical: 0.69 (95% CI 0.66 to 0.71) Continuous: 0.74 (95% CI 0.72 to 0.76)
Lip, 2011^138,d^ | 0.56 (95% CI 0.51 to 0.60) | 0.61 (95% CI 0.56 to 0.65) | 0.66 (95% CI 0.61 to 0.70) | -
Olesen, 2011^142,d^ | - | Categorical: 0.78 (95% CI 0.75 to 0.82) Continuous: 0.77 (95% CI 0.73 to 0.81) | Categorical: 0.80 (95% CI 0.76 to 0.83) Continuous: 0.80 (95% CI 0.76 to 0.83) | -
Pisters, 2010^16,d,e^ | - | 0.64 (95% CI 0.53 to 0.75) | 0.69 (95% CI 0.59 to 0.80) | -
Gage, 2006^140,b,c^ | 0.65 (SE 0.03) | 0.67 (SE 0.04) | - | -

a C-statistics given are for categorical risk scores unless otherwise noted.

b Derivation study for HEMORR_2_HAGES.

c P-value for 2-way between-score comparison not provided.

d P-value for between-score comparison not provided.

e Derivation study for HAS-BLED.

f Derivation study for ATRIA.

g P-values for all between-score comparisons >0.05 (not specified as <0.05 in source article).

h P=0.035 for comparison of between-score categorical c-statistics and p=0.356 for comparison of between-score continuous c-statistics.

Abbreviations: ATRIA=Anticoagulation and Risk Factors in Atrial Fibrillation; BRI=Bleeding Risk Index; CI=confidence interval; HAS-BLED=Hypertension, Abnormal renal/liver function, Stroke, Bleeding history or predisposition, Labile international normalized ratio, Elderly (> 65 years), Drugs/alcohol concomitantly; HEMORR_2_HAGES=Hepatic or renal disease, Ethanol abuse, Malignancy, Older (age >75 years), Reduced platelet count or function, Re-bleeding risk (2 points), Hypertension (uncontrolled), Anemia, Genetic factors, Excessive fall risk, Stroke; SE=standard error

Table 16 C-statistics from studies comparing scores of interest for discrimination of major bleeding risk among patients on aspirin alone^a^

Study | BRI | HEMORR_2_HAGES | HAS-BLED
Friberg, 2012^130,e^ | - | 0.60 (95% CI 0.59 to 0.61) | 0.59 (95% CI 0.58 to 0.60)
Pisters, 2010^16,d,e^ | - | 0.83 (95% CI 0.68 to 0.98) | 0.91 (95% CI 0.83 to 1.00)
Gage, 2006^140,b,c^ | 0.69 (SE 0.05) | 0.72 (SE 0.05)^b^ | -

a C-statistics given are for categorical risk scores unless otherwise noted.

b Derivation study for HEMORR_2_HAGES.

c P-value for 2-way between-score comparison not provided.

d Derivation study for HAS-BLED.

e P-value for between-score comparison not provided.

Abbreviations: BRI=Bleeding Risk Index; CI=confidence interval; HAS-BLED=Hypertension, Abnormal renal/liver function, Stroke, Bleeding history or predisposition, Labile international normalized ratio, Elderly (> 65 years), Drugs/alcohol concomitantly; HEMORR_2_HAGES=Hepatic or renal disease, Ethanol abuse, Malignancy, Older (age >75 years), Reduced platelet count or function, Re-bleeding risk (2 points), Hypertension (uncontrolled), Anemia, Genetic factors, Excessive fall risk, Stroke; SE=standard error

Table 17 C-statistics from studies comparing scores of interest for discrimination of major bleeding risk among patients off antithrombotic therapy^a^

Study | BRI | HEMORR_2_HAGES | HAS-BLED | ATRIA
Friberg, 2012^130,e^ | - | 0.69 (95% CI 0.67 to 0.70) | 0.66 (95% CI 0.65 to 0.68) | -
Lip, 2012^146,f^ | Categorical: 0.58 (95% CI 0.54 to 0.62) Continuous: 0.60 (95% CI 0.56 to 0.64) | Categorical: 0.55 (95% CI 0.50 to 0.59) Continuous: 0.59 (95% CI 0.54 to 0.63) | Categorical: 0.60 (95% CI 0.54 to 0.64) Continuous: 0.60 (95% CI 0.56 to 0.64) | Categorical: 0.47 (95% CI 0.42 to 0.51) Continuous: 0.59 (95% CI 0.55 to 0.64)
Lip, 2011^138,d^ | 0.50 (95% CI 0.44 to 0.57) | 0.62 (95% CI 0.52 to 0.72) | 0.66 (95% CI 0.55 to 0.74) | -
Olesen, 2011^142,d^ | - | Categorical: 0.77 (95% CI 0.74 to 0.80) Continuous: 0.79 (95% CI 0.73 to 0.79) | Categorical: 0.82 (95% CI 0.79 to 0.84) Continuous: 0.81 (95% CI 0.78 to 0.83) | -
Pisters, 2010^16,d,e^ | - | 0.81 (95% CI 0.00 to 1.00) | 0.85 (95% CI 0.00 to 1.00) | -
Gage, 2006^140,b,c^ | 0.65 (SE 0.03) | 0.66 (SE 0.04) | - | -

a C-statistics given are for categorical risk scores unless otherwise noted.

b Derivation study for HEMORR_2_HAGES.

c P-value for 2-way between-score comparison not provided.

d P-value for between-score comparison not provided.

e Derivation study for HAS-BLED.

f P-values for all between-score comparisons >0.05 (not specified as <0.05 in source article).

Abbreviations: ATRIA=Anticoagulation and Risk Factors in Atrial Fibrillation; BRI=Bleeding Risk Index; CI=confidence interval; HAS-BLED=Hypertension, Abnormal renal/liver function, Stroke, Bleeding history or predisposition, Labile international normalized ratio, Elderly (> 65 years), Drugs/alcohol concomitantly; HEMORR_2_HAGES=Hepatic or renal disease, Ethanol abuse, Malignancy, Older (age >75 years), Reduced platelet count or function, Re-bleeding risk (2 points), Hypertension (uncontrolled), Anemia, Genetic factors, Excessive fall risk, Stroke; SE=standard error

Table 18 Net reclassification improvement from studies comparing scores of interest for predicting major bleeding risk among patients on warfarin (except as indicated)

Study | Referent | Comparison 1 | Comparison 2 | Comparison 3
Apostolakis, 2012^143^ | HAS-BLED | +6.8% compared with HEMORR_2_HAGES (p=0.42) | +9.0% compared with ATRIA (p=0.33) | -
| ATRIA | −2.2% compared with HEMORR_2_HAGES (p=0.82)
Lip, 2012^146,a^ | HAS-BLED | +11.2% compared with HEMORR_2_HAGES (p<0.0001) | +9.1% compared with BRI (p<0.0001) | +6.6% compared with ATRIA (p=0.0007)
Roldan, 2012^145^ | HAS-BLED | +13.6% compared with ATRIA (continuous) (p=0.04) +19.6% compared with ATRIA (categorical) (p=0.02) | - | -
Fang, 2011^137,b^ | ATRIA | +50.5% compared with BRI (p=NR) | +28.9% compared with HEMORR_2_HAGES (p=NR) | -

a Population used to calculate NRI included both patients on warfarin and patients not taking warfarin.

b Derivation study for ATRIA.

Abbreviations: ATRIA=Anticoagulation and Risk Factors in Atrial Fibrillation; BRI=Bleeding Risk Index; CI=confidence interval; HAS-BLED=Hypertension, Abnormal renal/liver function, Stroke, Bleeding history or predisposition, Labile international normalized ratio, Elderly (> 65 years), Drugs/alcohol concomitantly; HEMORR_2_HAGES=Hepatic or renal disease, Ethanol abuse, Malignancy, Older (age >75 years), Reduced platelet count or function, Re-bleeding risk (2 points), Hypertension (uncontrolled), Anemia, Genetic factors, Excessive fall risk, Stroke; NR=not reported; SE=standard error

Among patients on warfarin, the four risk scores—BRI, HEMORR_2_HAGES, HAS-BLED, and ATRIA—were evaluated in studies where direct comparison with one or more of the other three scores was possible (Table 15). Of note, as with bleeding event rate estimates, c-statistics for each score varied considerably by population, making comparisons across studies difficult. Within-study c-statistics for patients on warfarin differed significantly between scores (as indicated by a p-value <0.05 or non-overlapping 95% CIs) in only two cases; in one study HAS-BLED had a statistically significantly higher c-statistic than BRI,138 while in another the categorical HAS-BLED had a statistically significantly higher c-statistic than the categorical ATRIA (Table 15).145 Neither of these two studies was the derivation study for any bleeding risk score. Among patients on aspirin alone or no antithrombotic therapy, no study appeared to show any significant between-score differences in c-statistics (Tables 16 and 17).

Four studies provided data on NRI as a means for comparing bleeding risk scores (Table 18). Within studies, NRI for patients differed significantly between risk scores in only two cases. In one study,145 HAS-BLED had a statistically significant positive NRI compared with ATRIA among patients on warfarin. In another study,146 HAS-BLED had a statistically significant positive NRI in separate, two-way comparisons with BRI, HEMORR_2_HAGES, and ATRIA; however, it should be noted that the reported NRI values were for a mixed population of patients on or off warfarin, and not reported separately for patients on warfarin alone.

Although some studies seem to suggest that HAS-BLED predicts major bleeding more effectively than other scores among AF patients on warfarin, the majority of included studies do not show statistically significant differences between risk scores in discrimination or NRI. Further studies comparing all available risk scores for predicting major bleeding should use consistent and appropriate statistical evaluations (hazard ratios, likelihood ratios, c-statistics, NRI, etc.) in independent cohorts to better establish whether any score is superior in any population (e.g., AF patients on warfarin, AF patients on newer antithrombotic agents, and AF patients off of anticoagulation therapy).

Sufficient data on homogenous populations/scores/outcomes did not exist to permit quantitative meta-analysis of available risk scores of interest.

Although the 95% confidence intervals on the c-statistics overlap between scores, many of the point estimates when given direct comparison of scores are better for HAS-BLED than for the other scores. In addition the net reclassification improvement data is promising for the HAS-BLED score. These led us to suggest a potential benefit of the HAS-BLED score albeit it with low strength of evidence/limited confidence.

#### Intracranial Hemorrhage

##### Overview

Most available studies for KQ 2 included ICH within the outcome “major bleeding,” but two studies presented this outcome separately. One of these studies evaluated both HAS-BLED and HEMORR_2_HAGES,130 and the other evaluated INR.121

##### HEMORR_2_HAGES

HEMORR_2_HAGES was evaluated in one included study of patients with AF with and without anticoagulation.130 This study compared HEMORR_2_HAGES with one other risk score of interest, HAS-BLED. Of note, due to unavailability of information on genetic factors, this study left out the “genetic factors” component of the score and so was, in effect, evaluating a modified HEMORR_2_HAGES.

This study presented ICH event rate data for the continuous HEMORR_2_HAGES score among 48,599 patients on warfarin. ICH bleeding rate for a HEMORR_2_HAGES score of 0 was 0.2 bleeding events per year: score 1=0.5, score 2=0.7, score 3=0.9, score 4=1.4, score 5=1.8, score 6=1.4, score 7=1.1, score 8=0, and score 9=0. Among patients on warfarin, the ICH c-statistic for HEMORR_2_HAGES in this study was 0.62 (95% CI 0.60 to 0.64). This study also presented c-statistics for HEMORR_2_HAGES in other populations; for patients on aspirin alone, the c-statistic was 0.58 (95% CI 0.55 to 0.60), while for patients not on antithrombotic therapy the c-statistic was 0.66 (95% CI 0.63 to 0.69).

##### HAS-BLED

HAS-BLED was evaluated in one included study of patients with AF with and without anticoagulation.130 This study compared HAS-BLED with one other risk score of interest, HEMORR_2_HAGES. Of note, this study excluded patients with labile INR, so quantified “labile INR” as 0 for all patients; the study also excluded the “drugs” component of the HAS-BLED score. Because of these changes, the study was, in effect, evaluating a modified HAS-BLED.

This study presented ICH event rate data for the continuous HAS-BLED score among 48,599 patients on warfarin. ICH bleeding rate for a HAS-BLED score of 0 was 0 bleeding events per year: score 1=0.2, score 2=0.6, score 3=0.7, score 4=1.2, score 5=1.6, score 6=0, and score 7=0. Among patients on warfarin, the ICH c-statistic for HAS-BLED in this study was 0.60 (95% CI 0.58 to 0.62). This study also presented c-statistics for HAS-BLED in other populations; for patients on aspirin alone, the c-statistic was 0.58 (95% CI 0.56 to 0.61), while for patients not on antithrombotic therapy, the c-statistic was 0.64 (95% CI 0.61 to 0.67).

##### INR

A single study conducted among patients with AF presenting with stroke evaluated the incidence of ICH by INR at the time of stroke.121 This study suggested that at supratherapeutic INR ranges, ICH incidence was higher, but the study was not designed to truly evaluate the predictive accuracy of this risk factor. ICH rates per 100 patient-years were 0.5 for INR <1.5, 0.3 for INR 1.5–1.9, 0.3 for INR 2.0–2.5, 0.5 for INR 2.6–3.0, 0.6 for INR 3.1–3.5, 0.4 for INR 3.6–3.9, 2.7 for INR 4.0–4.5, and 9.4 for INR >4.5.

##### Comparison of Bleeding Risk Scores and Meta-Analysis Results for Intracranial Hemorrhage

The single included study comparing HAS-BLED and HEMORR_2_HAGES did not show a statistically significant difference between the risk scores in discrimination for ICH in any patient population. No NRI data was available for comparing risk scores in predicting ICH. Further studies comparing all available risk scores for predicting ICH should use appropriate statistical evaluations (hazard ratios, likelihood ratios, c-statistics, NRI, etc.) in independent cohorts to better establish whether any score is superior in any population (e.g., AF patients on warfarin, AF patients on newer antithrombotic agents, and AF patients off of anticoagulation therapy). Better understanding ICH risk prediction will be particularly important, because this represents the most devastating variety of major bleeding event that patients on anticoagulation suffer.101

#### Minor Bleeding

##### Overview

A single study evaluated the impact of the BRI on estimating the risk of minor bleeding (not requiring transfusion, no major associated morbidity) in patients with AF on warfarin.141

##### BRI

A single study provided event rate data for incidence of minor bleeding by BRI risk category among patients on warfarin.141 In this study, 8.3 percent of the low-risk group, 4.4 percent moderate-risk group, and 6.9 percent of the high-risk group experienced minor bleeding per patient-year. The BRI was not felt to be predictive of minor bleeding in this analysis.

#### Strength of Evidence

Table 19 summarizes the strength of evidence for the bleeding risk discrimination abilities of the included tools. This summary table represents only those studies that evaluated the risk discrimination abilities of the tools using a c-statistic.

Table 19 Strength of evidence domains for discrimination of bleeding risk^a^

Outcome | Number of Studies (Subjects) | Domains Pertaining to Strength of Evidence (SOE) | | | | SOE and Magnitude of Effect (95% CI)
Outcome | Number of Studies (Subjects) | Risk of Bias | Consistency | Directness | Precision | SOE and Magnitude of Effect (95% CI)
Summary c-Statistic (Patients on Warfarin)
BRI | 5 (47,684) | Observational/Moderate | Consistent | Direct | Precise | SOE=Moderate Limited risk discrimination ability (c-statistic ranging from 0.56 to 0.65)
HEMORR_2_HAGES | 8 (318,246) | Observational/Moderate | Consistent | Direct | Imprecise | SOE=Moderate Limited risk discrimination ability (c-statistic ranging from 0.53 to 0.78)
HAS-BLED | 8 (313,294) | Observational/Moderate | Consistent | Direct | Imprecise | SOE=Moderate Modest risk discrimination ability (c-statistic ranging from 0.58 to 0.80)
ATRIA | 4 (15,732) | Observational/Moderate | Inconsistent | Direct | Imprecise | SOE=Insufficient
Comparative Risk Discrimination Abilities
Major bleeding events among patients with AF on warfarin | 9 (319,183) | Observational/Moderate | Consistent | Direct | Imprecise | SOE=Low Favors HAS-BLED
Intracranial hemorrhage among patients with AF on warfarin | 1 (48,599) | Observational/Moderate | NA | Direct | Precise | SOE=Low No difference
Major bleeding events among patients with AF on aspirin alone | 3 (177,538) | Observational/Moderate | Inconsistent | Direct | Imprecise | SOE=Low No difference
Major bleeding events among patients with AF not on antithrombotic therapy | 6 (310,607) | Observational/Moderate | Consistent | Direct | Imprecise | SOE=Low No difference

a C-statistics given are for categorical risk scores unless otherwise noted.

Abbreviations: AF=atrial fibrillation; ATRIA=Anticoagulation and Risk Factors in Atrial Fibrillation; BRI=Bleeding Risk Index; CI=confidence interval; HAS-BLED=Hypertension, Abnormal renal/liver function, Stroke, Bleeding history or predisposition, Labile international normalized ratio, Elderly (> 65 years), Drugs/alcohol concomitantly; HEMORR_2_HAGES=Hepatic or renal disease, Ethanol abuse, Malignancy, Older (age >75 years), Reduced platelet count or function, Re-bleeding risk (2 points), Hypertension (uncontrolled), Anemia, Genetic factors, Excessive fall risk, Stroke; KQ=Key Question; NA=not applicable; SOE=strength of evidence

## Key Question 3 Interventions for Preventing Thromboembolic Events

KQ 3. What are the comparative safety and effectiveness of specific anticoagulation therapies, antiplatelet therapies, and procedural interventions for preventing thromboembolic events:

- In patients with nonvalvular AF?
- In specific subpopulations of patients with nonvalvular AF?

### Key Points

- Based on 4 retrospective studies (1 good quality, 2 fair quality, and 1 poor quality) involving 170,642 patients, warfarin reduces the risk of non-fatal and fatal ischemic stroke compared with aspirin (moderate strength of evidence); on the other hand, based on 3 studies (1 good quality, 1 fair quality, and 1 poor quality) involving 99,876 patients, warfarin is associated with increased annual rates of severe bleeding complications compared with aspirin (moderate strength of evidence).
- In patients not eligible for warfarin, the combination of aspirin+clopidogrel is more effective than aspirin alone for preventing any stroke. This conclusion is based on 1 large good quality trial involving 7,554 patients that showed lower rates of stroke for combination therapy, but the strength of evidence was rated as only moderate because a much smaller study (593 patients) did not find any difference. In the large RCT, the combination of aspirin+clopidogrel was associated with higher rates of major bleeding than aspirin alone (high strength of evidence).
- Based on 1 large retrospective, good quality study involving 54,636 patients, warfarin reduces the risk of non-fatal and fatal ischemic stroke compared with clopidogrel monotherapy, with no differences in major bleeding (moderate strength of evidence).
- Based on 1 large, good-quality RCT of 6,706 patients, warfarin is superior to aspirin plus clopidogrel for the prevention of stroke or systemic embolism and reduction in minor bleeding, although this did not result in a difference in all-cause mortality (high strength of evidence for all 3 outcomes). There was moderate strength of evidence that warfarin increases hemorrhagic stroke risk, and that there is no difference between therapies for MI or death from vascular causes. A retrospective, good-quality study of 53,778 patients confirmed the stroke outcome findings.
- Adding clopidogrel to warfarin shows a trend toward a benefit on stroke prevention (low strength of evidence) and is associated with increased risk of non-fatal and fatal bleeding compared with warfarin alone (moderate strength of evidence). These findings are based on 1 good-quality retrospective study involving 52,349 patients
- Triple therapy with warfarin+aspirin+clopidogrel substantially increases the risk of non-fatal and fatal bleeding (moderate strength of evidence) and also shows a trend toward increased ischemic stroke (low strength of evidence) compared with warfarin alone. These findings are based on 1 good-quality retrospective study involving 52,180 patients
- A Factor IIa inhibitor (dabigatran) at a 150 mg dose is superior to warfarin in reducing the incidence of the composite outcome of stroke (including hemorrhagic) or systemic embolism, with no significant difference in the occurrence of major bleeding (high strength of evidence for both outcomes) or all-cause mortality (moderate strength of evidence). However, dabigatran increases MI risk (moderate strength of evidence). These findings are based on 1 large good-quality RCT involving 12,098 patients from the larger RE-LY trial of 18,113 patients.
- A Factor IIa inhibitor (dabigatran) at a 110 mg dose is noninferior to warfarin for the composite outcome of stroke or systemic embolism and is associated with a reduction in major bleeding when compared with warfarin (high strength of evidence for both outcomes), but there is no difference in all-cause mortality (moderate strength of evidence). Dabigatran increases MI risk, although this finding did not reach statistical significance (low strength of evidence). The rates of ICH are significantly lower with both dabigatran doses (150 mg and 110 mg) compared with warfarin (high strength of evidence). These findings are based on 1 large good-quality RCT involving 12,037 patients from the larger RE-LY trial of 18,113 patients. Of note, the 150 mg dabigatran dose is FDA approved and marketed in the United States; the 110 mg dose is not.
- The Xa inhibitor apixaban is superior to aspirin in reducing the incidence of stroke or systemic embolism, with similar major bleeding risk, in patients who are not suitable for oral anticoagulation (high strength of evidence for both outcomes). These findings are based on 1 good-quality RCT involving 5,599 patients.
- The Xa inhibitor apixaban is superior in reducing the incidence (separately) of (1) stroke or systemic embolism (high strength of evidence), (2) major bleeding (high strength of evidence), and (3) all-cause mortality (moderate strength of evidence) when compared with warfarin. These findings are based on similar findings from 1 good-quality RCT involving 18,201 patients and one small, fair-quality RCT involving 222 Japanese patients.
- The Xa inhibitor rivaroxaban is noninferior to warfarin in preventing stroke or systemic embolism (moderate strength of evidence), with similar rates of major bleeding (moderate strength of evidence) and all-cause mortality (high strength of evidence). These findings are based on 1 large, good-quality RCT involving 14,264 patients and a second good-quality RCT involving 1,280 Japanese patients.
- Percutaneous left atrial appendage (LAA) closure shows trends toward a benefit over warfarin for all strokes and all-cause mortality (low strength of evidence for both outcomes). Although LAA with percutaneous closure results in less frequent major bleeding than warfarin (low strength of evidence), it is also associated with a higher rate of adverse safety events (moderate strength of evidence). These findings are based on 1 good-quality RCT involving 707 patients. LAA occluding devices are currently investigational, pending approval by the FDA.
- Based on a two substudies of the ROCKET-AF and ARISTOTLE trials for rivaroxaban and apixaban respectively, patients with renal impairment benefitted equally for stroke prevention from the new anticoagulant agents compared with warfarin. Results were also similar in a substudy of the AVERROES (Apixaban Versus Acetylsalicylic acid [ASA] to Prevent Strokes in Atrial Fibrillation Patients Who Have Failed or Are Unsuitable for Vitamin K Antagonist Treatment) trial comparing apixaban with aspirin and demonstrating equal benefit in stroke prevention for patients with renal impairment (low strength of evidence).
- Patients with different INR control and with prior stroke seem to benefit equally for stroke prevention from the new anticoagulant agents when compared with warfarin or aspirin (low strength of evidence). This finding is based on four studies of patients at centers with different INR control, and seven studies of patients with prior stroke.

### Description of Included Studies

We identified 43 relevant studies (Appendix Table F-3). The majority (28) were multicenter,14,27,28,102,121,150–172 14 were single-center,110,173–185 and in 1 the study site was unclear.186 A total of 22 RCTs,27,28,150–152,154–156,158–161,163,166–168,171,172,176,177,180,181 12 retrospective studies,102,121,153,162,165,170,174,175,182–184,186 8 prospective cohorts,14,110,157,164,173,178,179,185 and 1 case-control study169 were included in our analyses. Eight studies enrolled only inpatients,102,155,157,160,161,165,168,181 17 included only outpatients,27,28,110,121,152–154,156,167,169,171,175–177,180,185,186 5 included both inpatients and outpatients,164,166,170,178,179,182 and 12 studies included patients from unclear settings.14,150,151,158,159,162,163,172–174,183,184 The number of patients included in studies ranged from 30^180^ to 132,372,^102^ with a total of 447,175 patients.

In regards to funding, 19 studies were sponsored by industry,27,28,150–156,158–160,163,166,169,171,172,175,180 3 by government,121,167,186 3 received funding from nongovernment, nonindustry sources,161,165,168 5 received funding from multiple sources including government, industry, nongovernment and nonindustry,162,164,170,174,182 and 13 had either no sponsorship or this information was unclear.14,102,110,157,173,176–179,181,183–185 Sixteen studies enrolled consecutive patients,28,110,152,155,160,164,168,173,178–185 and one used a convenience sample.27 The remaining studies either did not report the enrollment approach, or the approach used was unclear.14,102,121,150,151,153,154,156–159,161–163,165–167,169–172,174–177,186

The mean age of included patients varied from 62.6^181^ to 77.2^165^ years. Only three studies reported the overall mean CHADS_2_ score, which varied from 2.1^156^ to 3.5.^28^ Three studies included only patients with persistent AF,154,162,181 while three studies included only patients with permanent AF.110,157,176 In two studies, only patients with prior stroke were enrolled.121,168 Among the studies in which comorbidities were reported these varied widely, 6.6–40 percent of the population had diabetes mellitus, 15.4–90.5 percent had systemic hypertension, 14–62.5 percent had congestive heart failure, 9–67.4 percent had coronary artery disease, and 6.2–17 percent had a history of prior MI.

Among the multicenter studies, three were performed exclusively in the UK,161,162,169 six in Europe,102,153,157,164,166,168 five in Asia,14,151,167,171,172 four in the United States,121,158,165,170 two in both the United States and Europe,155,160 and the remaining in multiple continents.27,28,150,152,154,156,159,163 Among the single-center studies, one was conducted in the United States,175 one in the UK176 three in Asia,173,174,184 and seven in Europe.110,177–183,185

Twenty-one studies were considered of good quality,27,28,121,150,152–156,158–161,163,164,168,170–172,176,179 15 of fair quality,110,151,165,166,169,173,174,177,178,180,181,183–186 and 7 were of poor quality.14,102,157,162,167,175,182

Figure 8 represents the treatment comparisons evaluated for this KQ.

Figure 8 Overview of treatment comparisons evaluated for KQ 3

Abbreviations: ASA=aspirin; KQ=Key Question; LAA=left atrial appendage. Numbers refer to numbers of comparisons.

Figure 8. Overview of treatment comparisons evaluated for KQ 3. This figure shows the number of comparisons between treatments evaluated in KQ 3. Most comparisons were only explored in a limited number of studies, although many of these were good-quality RCTs involving over 5,000 patients. Seven studies compared Xa inhibitor versus warfarin. Four studies compared aspirin (ASA) versus warfarin. Two studies compared clopidogrel + ASA versus warfarin. Two studies compared clopidogrel + ASA versus ASA alone. There was one study for each of the following comparisons: ASA versus Xa inhibitor; Factor IIa inhibitor versus warfarin; Factor IIa inhibitor ± ASA versus warfarin; clopidogrel + warfarin + ASA versus warfarin; clopidogrel versus warfarin; warfarin + ASA versus warfarin; clopidogrel + warfarin versus warfarin; and percutaneous LAA closure versus warfarin.

As Figure 8 shows, most comparisons were explored in only a limited number of studies, although many of these were good-quality RCTs involving over 5,000 patients. The comparisons of Xa inhibitor versus warfarin and aspirin versus warfarin were the only comparisons for which we identified more than two studies.

We also describe results from 17 substudies187–203 of the 43 included studies in the relevant subsections under “Detailed Synthesis,” below; see Appendix E for details of the relationship between primary publications and substudy reports.

### Relationship to Previous Systematic Reviews

Our systematic review builds on two prior meta-analyses by Hart and colleagues.19,20. Their 1999 meta-analysis included the classic clinical trials of AFASAK I and II (Copenhagen Atrial Fibrillation, Aspirin, and Anticoagulation Study, I and II), SPAF I, II (Stroke Prevention in Atrial Fibrillation, I and II), EAFT (European Atrial Fibrillation Trial), ESPS II (European Stroke Prevention Study II), and LASAF (Low-Dose Aspirin, Stroke, and Atrial Fibrillation Pilot Study), demonstrating the superiority of warfarin (relative risk reduction of 36%) over aspirin.20 This meta-analysis included 16 RCTs with a total of 9,874 patients. Adjusted-dose warfarin was reported to reduce the risk of stroke by 62 percent (95% CI 48% to 72%) compared with aspirin, with a reduced stroke risk of 22 percent (95% CI 2% to 38%). Absolute risk reduction was 2.7 percent per year (primary prevention) and 8.4 percent per year (secondary prevention) for adjusted-dose warfarin, and 1.5 percent and 2.5 percent per year, respectively, for aspirin.

From 1999–2007, there were 13 additional RCTs that included 18,140 additional patients with nonvalvular AF. Hart and colleagues reviewed these additional trials in 2007 using long-term (≥12 weeks) use of antithrombotic agents in patients with nonvalvular AF and addressing five outcomes: all stroke (ischemic and hemorrhagic), ischemic stroke, intracranial hemorrhage, all-cause mortality, and major extracranial hemorrhage.19 Included in the 2007 meta-analysis were the SPORTIF II, III, V (Stroke Prevention using an ORal Thrombin Inhibitor in atrial Fibrillation, II, III, and IV) and ACTIVE-W (Atrial Fibrillation Clopidogrel Trial with Irbesartan for Prevention of Vascular Events-W) trials, focusing on comparisons of adjusted-dose warfarin with a combination of clopidogrel plus aspirin and warfarin therapy compared with all antiplatelet therapies. The superiority of adjusted-dose warfarin was clearly established by consistent results from eight of the RCTs included in the 2007 meta-analysis. All stroke was reduced by 38 percent (95% CI 18% to 51%) in the 3,647 patients included in those 8 trials. These earlier trials included participants typically younger (mean of 70 years of age) than those seen in current clinical practice (typically late 70s and early 80s), leaving a gap in the evidence on the safety and efficacy of adjusted-dose warfarin in the very elderly.

Stroke risk was confirmed to be reduced by approximately 60 percent when using adjusted-dose warfarin, and risk of death reduced by 25 percent when compared with no antithrombotic therapy in patients with nonvalvular AF.19,20 When compared with antiplatelet agents, adjusted-dose warfarin reduced stroke by approximately 40 percent. The best estimate of stroke reduction by antiplatelet drugs was reported to be approximately 20 percent. No major benefit of adding clopidogrel to aspirin in patients with nonvalvular AF was found.19 Whether specific antiplatelet agents and their combinations are more or less efficacious in patients with nonvalvular AF was not clear. No evidence favored one dosage of aspirin over another.

Recommendations suggest that choice of antithrombotic agents should be based on each patient’s individual stroke and bleeding risks, including factors such as access to anticoagulation monitoring and patient preferences. Low-risk patients did not benefit substantially from warfarin, and the risk stratification scores were noted to reliably identify these patients. Recommendations of adjusted-dose warfarin for high-risk patients with nonvalvular AF were validated, with antiplatelet medications for low-risk patients or for those with contraindications to warfarin.

We now update the findings above with literature through 2012. In this updated review, we are now able to evaluate studies that stratify patients previously classified as low-risk by CHADS_2_ criteria into further subgroups to tailor anticoagulation recommendations based on more specific criteria. Also, we evaluate newer antithrombotic agents for use in stroke prevention in patients with nonvalvular AF.

### Detailed Synthesis

Nineteen studies looked explicitly at the comparative safety and effectiveness of specific anticoagulation therapies, antiplatelet therapies, and procedural interventions for preventing thromboembolic events in patients with nonvalvular AF. Below we describe each of these studies categorized by the treatment comparisons represented. An additional 24 unique studies (and 15 substudies of included RCTs) focused on specific subgroups of interest. These studies are not combined with the more general AF population studies, but instead are discussed separately at the end of this section categorized by specific subgroup.

As described above, for most comparisons we identified only one or two studies per comparison of interest. The data for these comparisons therefore were deemed inappropriate for meta-analysis. Although we identified four studies for the Xa inhibitors versus warfarin comparison, the specific Xa inhibitors and the trials differed substantially, and a quantitative synthesis of these data was also considered inappropriate. We therefore describe results for outcomes of interest qualitatively below.

#### Aspirin Versus Warfarin

We identified one good-quality retrospective study involving 98,460 patients153 and one poor-quality retrospective study involving 601 patients162 that compared aspirin with warfarin. Two additional retrospective studies169,184 evaluated aspirin and warfarin compared with no therapy (we concentrate on the aspirin vs. warfarin findings here). The latter included a population-based cohort analysis of 70,766 patients with a first-ever diagnosis of chronic AF conducted within the United Kingdom to estimate the risk of ischemic stroke and intracranial hemorrhage associated with the use of warfarin and aspirin,169 and a fair-quality observational study that compared the efficacy of warfarin, antiplatelet therapy, and no therapy in 815 Taiwanese patients with nonvalvular AF.184 A fifth retrospective study186 also evaluated aspirin versus warfarin, but study investigators were not able to distinguish patients who were on a combination of warfarin+aspirin and counted these patients as warfarin only. This final study was therefore excluded from our analysis and not synthesized with the other four.

##### Ischemic Stroke

In one study,153 treatment with aspirin was associated with increased risk of non-fatal and fatal ischemic stroke when compared with warfarin (HR 1.83; 95% CI 1.73 to 1.94). Similarly, in the second study,162 there were increased rates of stroke among patients receiving aspirin compared with warfarin (3.57% per patient-year in the aspirin group vs. 1.64% per patient-year in the warfarin group). The third study169 showed that warfarin use was associated with a three percent decreased risk of ischemic stroke compared with no use of any antithrombotic therapy. On the other hand, treatment with aspirin was not associated with a decreased risk of ischemic stroke. Finally, the study by Yang and colleagues184 demonstrated that rates of non-ischemic stroke did not differ between treatment with warfarin, aspirin, and no therapy (2.9% with warfarin vs. 3.7% with aspirin vs. 5.8% with no therapy; p=0.395). There was moderate strength of evidence that warfarin therapy reduced stroke as compared with aspirin.

##### Bleeding

In one study,153 the risk of non-fatal and fatal bleeding was lower in the aspirin group (HR 0.93; 95% CI 0.88 to 0.98). Similarly, in the second study,162 annual rates of severe bleeding complications were higher in the warfarin group (1.90% per patient-year in the aspirin group vs. 2.6% per patient-year in the warfarin group). Overall bleeding rates were also higher in the warfarin group (4.7% per patient-year in the aspirin group vs. 9.0% per patient-year in the warfarin group). A third study184 reported similar rates of any bleeding with warfarin (0.4% major bleeding), aspirin (0.2% major bleeding), and no therapy (0.7% major bleeding; p=0.196). There was moderate strength of evidence that warfarin increased rates of bleeding compared with aspirin.

##### All-Cause Mortality

One study162 reported rates of all-cause mortality and found that they were lower among patients receiving warfarin (7.3% per patient-year in the warfarin group vs. 13.3% per patient-year in the aspirin group). There was insufficient evidence to determine the impact of warfarin and aspirin on all-cause mortality.

##### Strength of Evidence

Table 20 summarizes the strength of evidence for outcomes of interest for this comparison.

Table 20 Strength of evidence domains for preventing thromboembolic events—aspirin vs. warfarin

Outcome | Number of Studies (Subjects) | Domains Pertaining to SOE | | | | SOE and Magnitude of Effect (95% CI)
Outcome | Number of Studies (Subjects) | Risk of Bias | Consistency | Directness | Precision | SOE and Magnitude of Effect (95% CI)
Ischemic stroke | 4 (170,642) | Observational/Moderate | Consistent | Direct | Precise | SOE=Moderate 4 retrospective studies showing consistent reduction in stroke with warfarin
Bleeding | 3 (99,876) | Observational/Moderate | Consistent | Direct | Precise | SOE=Moderate Warfarin associated with increased rates of bleeding
All-cause mortality | 1 (601) | Observational/High | NA | Direct | Imprecise | SOE=Insufficient

Abbreviations: ASA=aspirin; CI=confidence interval; NA=not applicable; SOE=strength of evidence

#### Warfarin+Aspirin Versus Warfarin Alone

One good-quality retrospective cohort study compared warfarin+aspirin (18,345 patients) with warfarin monotherapy (50,919 patients).153 This study demonstrated increased risks of both stroke and bleeding in the combination arm compared with warfarin monotherapy.

##### Ischemic Stroke

In this study, the combination of warfarin+aspirin was associated with statistically significant increased risk of non-fatal and fatal ischemic stroke when compared with warfarin monotherapy (HR 1.27; 95% CI 1.14 to 1.40) (moderate strength of evidence).

##### Bleeding

In this study, the risk of non-fatal and fatal bleeding was almost twice as high among patients on combined warfarin+aspirin therapy as among patients receiving warfarin monotherapy (HR 1.83; 95% CI 1.72 to 1.96) (moderate strength of evidence).

##### Strength of Evidence

Table 21 summarizes the strength of evidence for outcomes of interest for this comparison.

Table 21 Strength of evidence domains for preventing thromboembolic events—warfarin+aspirin vs. warfarin alone

Outcome | Number of Studies (Subjects) | Domains Pertaining to SOE | | | | SOE and Magnitude of Effect (95% CI)
Outcome | Number of Studies (Subjects) | Risk of Bias | Consistency | Directness | Precision | SOE and Magnitude of Effect (95% CI)
Ischemic stroke | 1 (69,264) | Observational/Moderate | NA | Direct | Precise | SOE=Moderate Increased with warfarin+ASA (HR 1.27 (95% CI 1.14 to 1.40)
Bleeding | 1 (69,264) | Observational/Moderate | NA | Direct | Precise | SOE=Moderate Increased with warfarin+ASA (HR 1.83 (95% CI 1.72 to 1.96)

Abbreviations: ASA=aspirin; CI=confidence interval; HR=hazard ratio; NA=not applicable; SOE=strength of evidence

#### Clopidogrel+Aspirin Versus Aspirin Alone

Two good-quality RCTs involving 8,147 patients analyzed the combination of clopidogrel+aspirin compared with aspirin alone in patients with AF.156,158 Both reported intention-to-treat (ITT) analyses. Given the size and quality of the larger RCT of 7,554 patients,156 the findings of the smaller study involving 593 patients158 are presented here, but our findings and strength of evidence rating are based mainly on the larger RCT.

##### Any Stroke

The findings of these two studies differed in terms of the impact of treatment on all strokes. The larger study showed lower rates of stroke in the group treated with clopidogrel+aspirin (2.4% per year vs. 3.3% per year for clopidogrel+aspirin and aspirin alone, respectively; HR 0.72; 95% CI 0.62 to 0.83; p<0.001).156 Rates of any stroke did not, however, differ between groups in the smaller study (2.2% per year vs. 2.1% per year for clopidogrel+aspirin and aspirin alone, respectively; HR 1.03; 95% CI 0.49 to 2.13; p=0.94).158 Based on the large study, but reflecting the inconsistent findings, there was moderate strength of evidence that combined treatment lowered the risk of any stroke.

##### Ischemic Stroke

Rates of ischemic stroke were higher in the aspirin group in the larger study (1.9% per year for clopidogrel+aspirin vs. 2.8% per year for aspirin alone; HR 0.68; 95% CI 0.57 to 0.80),156 and similar across groups in the smaller study (2.0% per year for clopidogrel+aspirin vs. 2.1% per year for aspirin alone; HR 0.96; 95% CI 0.46 to 2.01; p=0.91).158 Based on the large study, but reflecting the inconsistent findings, there was low strength of evidence that combined therapy lowered the risk of ischemic stroke.

##### Hemorrhagic Stroke

Rates of hemorrhagic stroke were similar between the groups in both studies (moderate strength of evidence).

##### Systemic Embolism

Only the larger study involving 7,554 patients reported the rates of systemic embolism, which were similar between the groups (0.4% per year for clopidogrel+aspirin vs. 0.4% per year for aspirin alone; HR 0.96; 95% CI 0.66 to 1.40; p=0.84)156 (moderate strength of evidence).

##### Major Bleeding

The combination of clopidogrel+aspirin was associated with higher rates of major bleeding when compared with aspirin alone in the larger study involving 7,554 patients (2.0% per year for clopidogrel+aspirin vs. 1.3% per year for aspirin alone; HR 1.57; 95% CI 1.29 to 1.92; p<0.001)156 (high strength of evidence). The smaller study did not report rates of major bleeding.158

##### Minor Bleeding

Rates of minor bleeding were higher in the clopidogrel+aspirin group compared with aspirin alone in the larger study involving 7,554 patients (3.5% per year for clopidogrel+aspirin vs. 1.4% per year for aspirin alone; HR 2.42; 95% CI 2.03 to 2.89; p<0.001)156 (high strength of evidence). The other smaller study did not report this outcome.

##### Intracranial Bleeding

Rates of intracranial bleeding were higher in the clopidogrel+aspirin group in the larger study involving 7,554 patients (0.4% per year for clopidogrel+aspirin vs. 0.2% per year for aspirin alone; HR 1.87; 95% CI 1.19 to 2.94; p=0.006),156 and similar between therapies in one small study involving 593 patients (3 patients in the clopidogrel+aspirin group vs. 1 patient in the aspirin alone group; p=0.62).158 Based on the larger study, but reflecting the inconsistent and imprecise findings, there was low strength of evidence that combined therapy increased intracranial bleeding.

##### Extracranial Bleeding

Rates of extracranial bleeding were higher with clopidogrel+aspirin than with aspirin alone in both studies. In the larger study involving 7,554 patients, rates were 1.6% per year for clopidogrel+aspirin vs. 1.1% per year for aspirin alone (HR 1.51; 95% CI 1.21 to 1.88; p<0.001).156 The small study involving 593 patients found 2% extracranial bleeding in the clopidogrel+aspirin group vs. 1% in the aspirin alone group (p=0.51),158 Given the consistent findings, there was high strength of evidence that combined therapy increased extracranial bleeding.

##### All-Cause Mortality

All-cause mortality did not differ between the groups in either study (in the larger study, 6.4% per year for clopidogrel+aspirin vs. 6.6% per year for aspirin alone; HR 0.98; 95% CI 0.89 to 1.08; p=0.69;^156^ in the smaller study, 29 patients in the clopidogrel+aspirin vs. 25 patients in aspirin alone group; HR 1.12; 95% CI 0.65 to 1.90; p=0.69^158^) (moderate strength of evidence).

##### Death From Vascular Causes

Death from vascular causes also did not differ between the groups in the larger study (4.7% per year for clopidogrel+aspirin vs. 4.7% per year for aspirin alone; HR 1.00; 95% CI 0.89 to 1.12; p=0.97;^156^ however, in the smaller study there was a trend toward a benefit of aspirin alone (21 patients in the clopidogrel+aspirin vs. 12 patients in aspirin alone group; HR 1.68; 95% CI 0.83 to 3.42; p=0.15^158^), reducing the strength of evidence (low strength of evidence).

##### Myocardial Infarction

Myocardial infarction did not differ between treatment groups in the larger study (0.7% per year for clopidogrel+aspirin vs. 0.9% per year for aspirin alone; HR 0.78; 95% CI 0.59 to 1.03; p=0.08);156 however, in the smaller study there was a trend toward a benefit of aspirin alone (9 patients in the clopidogrel+aspirin group vs. 6 patients in the aspirin alone group; HR 1.43; 95% CI 0.51 to 4.01; p=0.50^158^), reducing the strength of evidence (low strength of evidence).

##### Hospitalization

Only the smaller study involving 593 patients reported rates of rehospitalization, which were similar between the two groups (41 patients in the clopidogrel+aspirin group vs. 43 patients in the aspirin alone group; HR 0.89; 95% CI 0.58 to 1.37; p=0.60).158 Given the small size of the study and the imprecision of the findings, there was insufficient strength of evidence to determine the impact of combined therapy on hospitalization.

##### Strength of Evidence

Table 22 summarizes the strength of evidence for outcomes of interest for this comparison.

Table 22 Strength of evidence domains for preventing thromboembolic events—clopidogrel+aspirin vs. aspirin alone

Outcome | Number of Studies (Subjects) | Domains Pertaining to SOE | | | | SOE and Magnitude of Effect (95% CI)
Outcome | Number of Studies (Subjects) | Risk of Bias | Consistency | Directness | Precision | SOE and Magnitude of Effect (95% CI)
Any stroke | 2 (8,147) | RCT/Low | Inconsistent | Direct | Precise | SOE=Moderate Lower rates with combined therapy (HR 0.72; 95% CI 0.62 to 0.83)
Ischemic stroke | 2 (8,147) | RCT/Low | Inconsistent | Direct | Imprecise | SOE=Low Lower rates with combined therapy (HR 0.68; 95% CI 0.57 to 0.80)
Hemorrhagic stroke | 2 (8,147) | RCT/Low | Consistent | Direct | Imprecise | SOE=Moderate Similar between therapies in both studies
Systemic embolism | 1 (7,554) | RCT/Low | NA | Direct | Imprecise | SOE=Moderate Similar between therapies (HR 0.96; 95% CI 0.66 to 1.40)
Major bleeding | 1 (7,554) | RCT/Low | NA | Direct | Precise | SOE=High Clopidogrel+ASA associated with higher rates (HR 1.57; 95% CI 1.29 to 1.92)
Minor bleeding | 1 (7,554) | RCT/Low | NA | Direct | Precise | SOE=High Clopidogrel+ASA associated with higher rates (HR 2.42; 95% CI 2.03 to 2.89)
Intracranial bleeding | 2 (8,147) | RCT/Low | Inconsistent | Direct | Imprecise | SOE=Low Higher rate with clopidogrel+ASA (HR 1.87; 95% CI 1.19 to 2.94)
Extracranial bleeding | 2 (8,147) | RCT/Low | Inconsistent | Direct | Imprecise | SOE=High Higher rate with clopidogrel+ASA (HR 1.51; 95% CI 1.21 to 1.88)
All-cause mortality | 2 (8,147) | RCT/Low | Consistent | Direct | Imprecise | SOE=Moderate No difference (HR 0.98 [95% CI 0.89 to 1.08] in one study; HR 1.12 [95% CI 0.65 to 1.90] in other study)
Death from vascular causes | 2 (8,147) | RCT/Low | Inconsistent | Direct | Imprecise | SOE=Low No difference based on large RCT (HR 1.00; 95% CI 0.89 to 1.12), although a smaller study showed a trend toward a benefit of ASA alone (HR 1.68; 95% CI 0.83 to 3.42)
Myocardial infarction | 2 (8,147) | RCT/Low | Inconsistent | Direct | Imprecise | SOE=Low No difference based on large RCT (HR 0.78; 95% CI 0.59 to 1.03), although a smaller study showed a trend toward a benefit of ASA alone (HR 1.43; 95% CI 0.51 to 4.01)
Hospitalization | 1 (593) | RCT/Low | NA | Direct | Imprecise | SOE=Insufficient

Abbreviations: ASA=aspirin; CI=confidence interval; HR=hazard ratio; NA=not applicable; RCT=randomized controlled trial; SOE=strength of evidence

#### Clopidogrel Versus Warfarin

One good-quality retrospective cohort study compared clopidogrel (3,717 patients) with warfarin (50,919 patients).153

##### Ischemic Stroke

This study demonstrated that treatment with clopidogrel was associated with increased risk of non-fatal and fatal ischemic stroke when compared with warfarin (HR 1.86; 95% CI 1.52 to 2.27) (moderate strength of evidence).

##### Bleeding

This study found that the risk of non-fatal and fatal bleeding was similar between groups (HR 1.06; 95% CI 0.87 to 1.29) (moderate strength of evidence).

##### Strength of Evidence

Table 23 summarizes the strength of evidence for outcomes of interest for this comparison.

Table 23 Strength of evidence domains for preventing thromboembolic events—clopidogrel vs. warfarin

Outcome | Number of Studies (Subjects) | Domains Pertaining to SOE | | | | SOE and Magnitude of Effect (95% CI)
Outcome | Number of Studies (Subjects) | Risk of Bias | Consistency | Directness | Precision | SOE and Magnitude of Effect (95% CI)
Ischemic stroke | 1 (54,636) | Observational/Moderate | NA | Direct | Precise | SOE=Moderate Increased risk with clopidogrel (HR 1.86; 95% CI 1.52 to 2.27)
Bleeding | 1 (54,636) | Observational/Moderate | NA | Direct | Precise | SOE=Moderate Similar between therapies (HR 1.06; 95% CI 0.87 to 1.29)

Abbreviations: CI=confidence interval; HR=hazard ratio; NA=not applicable; SOE=strength of evidence

#### Clopidogrel+Aspirin Versus Warfarin

Two studies compared clopidogrel+aspirin with warfarin in ITT analyses.153,163 One study was a good-quality retrospective analysis involving 2,859 patients on clopidogrel+aspirin treatment and 50,919 patients on warfarin monotherapy.153 The other study was a good-quality RCT involving 6,706 patients which was stopped early because of the clear evidence of superiority of the warfarin strategy.163

##### Stroke or Systemic Embolism

In both studies, treatment with clopidogrel+aspirin was associated with increased risk of non-fatal and fatal ischemic stroke when compared with warfarin (HR 1.56; 95% CI 1.17 to 2.10;^153^ and HR 1.72; 95% CI 1.24 to 2.37; p=0.001^163^) (high strength of evidence).

##### Hemorrhagic Stroke

The RCT involving 6,706 patients reported rates of hemorrhagic stroke, which were higher in the warfarin group (0.12% per year vs. 0.36% per year for clopidogrel+aspirin and warfarin, respectively; HR 0.34; 95% CI 0.12 to 0.93; p=0.036).163 (moderate strength of evidence).

##### Major Bleeding

The RCT reported no differences in major bleeding rates, including severe and fatal bleeding (2.42% per year vs. 2.21% per year for clopidogrel+aspirin and warfarin, respectively; HR 1.10; 95% CI 0.83 to 1.45; p=0.53).163 The other large retrospective study reported that the risk of non-fatal and fatal bleeding was higher in the clopidogrel+aspirin group (HR 1.66; 95% CI 1.34 to 2.04).153 Given the inconsistent findings, but the similar rates found in the RCT, there was low strength of evidence of similar rates of major bleeding between therapies.

##### Minor Bleeding

Only the RCT study reported rates of minor bleeding, which were higher in the clopidogrel+aspirin group (13.58% per year vs. 11.45% per year for clopidogrel+aspirin and warfarin, respectively; HR 1.23; 95% CI 1.09 to 1.39; p=0.0009)163 (high strength of evidence).

##### Intracranial Bleeding

Intracranial bleeding, including subdural hematoma, was reported by the RCT and was more common with warfarin therapy; however, this difference did not reach statistical significance (p=0.08)163 (insufficient strength of evidence).

##### All-Cause Mortality

All-cause mortality was reported by the RCT, and there was no difference between the two therapies (3.8% per year vs. 3.76% per year for clopidogrel+aspirin and warfarin, respectively; HR 1.01; 95% CI 0.81 to 1.26; p=0.91)163 (high strength of evidence).

##### Death From Vascular Causes

Death from vascular causes was reported by the RCT. Rates were slightly higher with clopidogrel+aspirin; however, the difference did not reach statistical significance (2.87% per year vs. 2.52% per year for clopidogrel+aspirin and warfarin, respectively; HR 1.14; 95% CI 0.88 to 1.48; p=0.34)163 (moderate strength of evidence).

##### Myocardial Infarction

Within the RCT,163 MI occurred at rates of less than one percent per year in both groups and was not significantly different between the treatments. Rates of MI were not reported in the other study153 (moderate strength of evidence).

##### Strength of Evidence

Table 24 summarizes the strength of evidence for outcomes of interest for this comparison.

Table 24 Strength of evidence domains for preventing thromboembolic events—clopidogrel+aspirin vs. warfarin

Outcome | Number of Studies (Subjects) | Domains Pertaining to SOE | | | | SOE and Magnitude of Effect (95% CI)
Outcome | Number of Studies (Subjects) | Risk of Bias | Consistency | Directness | Precision | SOE and Magnitude of Effect (95% CI)
Stroke or systemic embolism | 2 (60,484) | RCT+ Observational/Low | Consistent | Direct | Precise | SOE=High Increased risk with clopidogrel+ASA in both studies (HR 1.56 [95% CI 1.17 to 2.10] in one study; HR 1.72 [95% CI 1.24 to 2.37] in other study)
Hemorrhagic stroke | 1 (6,706) | RCT/Low | NA | Direct | Imprecise | SOE=Moderate Increased risk with warfarin (HR 0.34 [95% CI 0.12 to 0.93])
Major bleeding | 2 (60,484) | RCT+ Observational/Low | Inconsistent | Direct | Imprecise | SOE=Low Similar rates between therapies (HR 1.10; 95% CI 0.83 to 1.45),
Minor bleeding | 1 (6,706) | RCT/Low | NA | Direct | Precise | SOE=High Increased risk with clopidogrel+ASA (HR 1.23; 95% CI 1.09 to 1.39)
Intracranial bleeding | 1 (6,706) | RCT/Low | NA | Direct | Imprecise | SOE=Insufficient
All-cause mortality | 1 (6,706) | RCT/Low | NA | Direct | Precise | SOE=High No difference (HR 1.01; 95% CI 0.81 to 1.26)
Death from vascular causes | 1 (6,706) | RCT/Low | NA | Direct | Imprecise | SOE=Moderate No difference (HR 1.14; 95% CI 0.88 to 1.48)
Myocardial infarction | 1 (6,706) | RCT/Low | NA | Direct | Imprecise | SOE=Moderate No difference (myocardial infarction occurred at rates of <1% per year with both therapies)

Abbreviations: ASA=aspirin; CI=confidence interval; HR=hazard ratio; NA=not applicable; RCT=randomized controlled trial; SOE=strength of evidence

#### Warfarin+Clopidogrel Versus Warfarin Alone

One good-quality retrospective study compared warfarin+clopidogrel (1,430 patients) with warfarin monotherapy (50,919 patients).153 While the risk of ischemic stroke was similar across the two treatments, the risk of bleeding was greatly increased in patients receiving clopidogrel+warfarin compared with those receiving warfarin monotherapy.

##### Ischemic Stroke

In the one included study, there was a trend toward benefit of warfarin+clopidogrel for non-fatal and fatal ischemic stroke (HR 0.70; 95% CI 0.35 to 1.40) (low strength of evidence).

##### Bleeding

The risk of non-fatal and fatal bleeding was three-fold higher for patients receiving warfarin+clopidogrel as compared with patients receiving warfarin monotherapy (HR 3.08; 95% CI 2.32 to 3.91) (moderate strength of evidence).

##### Strength of Evidence

Table 25 summarizes the strength of evidence for outcomes of interest for this comparison.

Table 25 Strength of evidence domains for preventing thromboembolic events—warfarin+clopidogrel vs. warfarin alone

Outcome | Number of Studies (Subjects) | Domains Pertaining to SOE | | | | SOE and Magnitude of Effect (95% CI)
Outcome | Number of Studies (Subjects) | Risk of Bias | Consistency | Directness | Precision | SOE and Magnitude of Effect (95% CI)
Ischemic stroke | 1 (52,349) | Observational/Moderate | NA | Direct | Imprecise | SOE=Low Trend toward benefit of warfarin+ clopidogrel (HR 0.70; 95% CI 0.35 to 1.40)
Bleeding | 1 (52,349) | Observational/Moderate | NA | Direct | Precise | SOE=Moderate Higher for patients on warfarin+ clopidogrel (HR 3.08; 95% CI 2.32 to 3.91)

Abbreviations: CI=confidence interval; HR=hazard ratio; NA=not applicable; SOE=strength of evidence

#### Warfarin Alone Versus Warfarin+Aspirin+Clopidogrel

One good-quality retrospective study compared warfarin monotherapy (50,919 patients) with the triple therapy of warfarin+aspirin+clopidogrel (1,261 patients).153

##### Ischemic Stroke

The rates of non-fatal and fatal ischemic stroke were similar between groups (HR 1.45; 95% CI 0.84 to 2.52), although there was a trend toward an increase in the triple therapy arm (low strength of evidence).

##### Bleeding

Triple therapy was associated with a large and statistically significant increased risk of non-fatal and fatal bleeding (HR 3.70; 95% CI 2.89 to 4.76) (moderate strength of evidence).

##### Strength of Evidence

Table 26 summarizes the strength of evidence for outcomes of interest for this comparison.

Table 26 Strength of evidence domains for preventing thromboembolic events—warfarin alone vs. warfarin+aspirin+clopidogrel

Outcome | Number of Studies (Subjects) | Domains Pertaining to SOE | | | | SOE and Magnitude of Effect (95% CI)
Outcome | Number of Studies (Subjects) | Risk of Bias | Consistency | Directness | Precision | SOE and Magnitude of Effect (95% CI)
Ischemic stroke | 1 (52,180) | Observational/Moderate | NA | Direct | Imprecise | SOE=Low Trend toward being higher for patients on triple therapy (HR 1.45; 95% CI 0.84 to 2.52)
Bleeding | 1 (52,180) | Observational/Moderate | NA | Direct | Precise | SOE=Moderate Higher for patients on triple therapy (HR 3.70; 95% CI 2.89 to 4.76)

Abbreviations: CI=confidence interval; HR=hazard ratio; NA=not applicable; SOE=strength of evidence

#### Factor IIa Inhibitor (Dabigatran 150 mg and 110 mg) Versus Warfarin

One large, good-quality, noninferiority RCT of 18,113 patients (RE-LY) compared a Factor IIa inhibitor (dabigatran) with warfarin in nonvalvular AF patients in ITT analyses.27 Patients receiving dabigatran were randomized to one of two doses (110 mg and 150 mg). Patients receiving the 110 mg dose had rates of stroke and systemic embolism that were similar to those associated with warfarin, but lower rates of major hemorrhage. Patients who received 150 mg of dabigatran had lower rates of stroke and systemic embolism than patients in the warfarin group, but similar rates of major hemorrhage.

##### Stroke or Systemic Embolism

Dabigatran at a 110 mg dose was noninferior to warfarin in preventing stroke and systemic embolism (1.53% per year vs. 1.69% per year for dabigatran and warfarin, respectively; relative risk [RR] 0.91; 95% CI 0.74 to 1.11; p<0.001 for noninferiority and 0.34 for superiority) (high strength of evidence for no difference). Dabigatran at 150 mg was superior to warfarin in reducing the incidence of stroke (including hemorrhagic stroke) and systemic embolism by 34 percent (1.11% per year vs. 1.69% per year; RR 0.66; 95% CI 0.53 to 0.82; p<0.001) (high strength of evidence that dabigatran reduced risk).

##### Ischemic or Uncertain Stroke

The rates of ischemic or uncertain stroke were not different between dabigatran 110 mg and warfarin (1.34% per year for dabigatran 110 mg vs. 1.20% per year for warfarin; RR 1.11; 95% CI 0.89 to 1.40; p=0.35) (moderate strength of evidence). Dabigatran 150 mg was associated with lower rates of ischemic or uncertain stroke when compared with warfarin (0.92% per year for dabigatran 150 mg vs. 1.20% per year for warfarin; RR 0.76; 95% CI 0.60 to 0.98; p=0.03) (moderate strength of evidence).

##### Hemorrhagic Stroke

Both doses of dabigatran were associated with lower rates of hemorrhagic stroke when compared with warfarin (0.12% per year for dabigatran 110 mg vs. 0.38% per year for warfarin; RR 0.31; 95% CI 0.17 to 0.56; p<0.001; 0.10% per year for dabigatran 150 mg versus 0.38% per year for warfarin; RR 0.26; 95% CI 0.14 to 0.49; p<0.001) (high strength of evidence that dabigatran reduced risk with both doses).

##### Major Bleeding

Dabigatran 110 mg was associated with a 20 percent relative risk reduction in major bleeding when compared with warfarin (2.71% per year for dabigatran 110 mg vs. 3.36% per year for warfarin; RR 0.80; 95% CI 0.69 to 0.93; p=0.003) (high strength of evidence), while no difference was seen between dabigatran 150 mg and warfarin in regards to major bleeding (3.11% per year for dabigatran 150 mg vs. 3.36% per year for warfarin; RR 0.93; 95% CI 0.81 to 1.07; p=0.31) (high strength of evidence).

##### Minor Bleeding

Overall, the rates of minor bleeding were higher in the warfarin group compared with both doses of dabigatran (13.16% per year for dabigatran 110 mg vs. 16.37% per year for warfarin; RR 0.79; 95% CI 0.74 to 0.84; p<0.001; and 14.84% per year for dabigatran 150 mg vs. 16.37% per year for warfarin; RR 0.91; 95% CI 0.85 to 0.97; p=0.005) (moderate strength of evidence that dabigatran reduced risk with the 150 mg dose and high strength of evidence that dabigatran reduced risk at the lower 110 mg dose). Gastrointestinal bleeding was more common with higher dose dabigatran than with warfarin.

##### Intracranial Bleeding

Both doses of dabigatran were associated with lower rates of intracranial bleeding (0.23% per year for dabigatran 110 mg vs. 0.74% per year for warfarin; RR 0.31; 95% CI 0.20 to 0.47; p<0.001; 0.30% per year for dabigatran 150 mg vs. 0.74% per year for warfarin; RR 0.40; 95% CI 0.27 to 0.60; p<0.001) (high strength of evidence that dabigatran reduced risk with both doses).

A substudy201 of the RE-LY trial27 analyzed intracranial hemorrhages occurring during anticoagulation in all three groups (warfarin, dabigatran 110 mg, and dabigatran 150 mg). During a mean of 2.0 years of followup, 154 intracranial hemorrhages occurred in 153 participants, with a 30-day mortality of 36 percent. Intracranial hemorrhages included: 46 percent intracerebral (49% mortality), 45 percent subdural (24% mortality), and 8 percent subarachnoid (31% mortality). The rates of intracranial hemorrhage were 0.76 percent, 0.31 percent, and 0.23 percent per year among those assigned to warfarin, dabigatran 150 mg, and dabigatran 110 mg, respectively (p<0.001 for either dabigatran dose versus warfarin). There were no statistically significant differences in mortality rates of intracranial hemorrhages comparing warfarin with either dose of dabigatran for any site (mortality associated with intracranial hemorrhage was 36% warfarin, 35% dabigatran 150 mg, and 41% dabigatran 110 mg). Fewer fatal intracranial hemorrhages occurred among those assigned to dabigatran 150 mg and 110 mg (n=13 and n=11, respectively) versus warfarin (n=32; P <0.01 for both). Fewer traumatic intracranial hemorrhages occurred among those assigned to dabigatran (11 patients with each dose) compared with warfarin (24 patients; p<0.05 for both dabigatran doses versus warfarin). Fatal traumatic intracranial hemorrhages occurred in 5 patients, 3 patients, and 3 patients assigned to warfarin, dabigatran 150 mg, and dabigatran 110 mg, respectively. The rate of spontaneous intracerebral hemorrhage was 0.36% per year (n=42) among those assigned to warfarin and was substantially lower for those assigned to dabigatran 150 mg (0.09% per year, n=11; RR, 0.26; 95% CI 0.13 to 0.50) and dabigatran 110 mg (0.08% per year, n=10; RR, 0.23; 95% CI 0.12 to 0.47). The mortality associated with spontaneous intracerebral hemorrhage averaged 52 percent, with no significant differences between treatment arms. Fatal spontaneous intracerebral bleeding occurred in 19 patients assigned to warfarin versus 7 patients each with dabigatran 150 mg and 110 mg (p<0.01 for both comparisons with warfarin). Subdural hematomas accounted for 45 percent of intracranial hemorrhages and were associated with trauma in 44 percent of warfarin-assigned (16/36) and dabigatran-assigned (15/34) participants. The rate of subdural hematoma was 0.31, 0.20, and 0.08 percent per year among those assigned to warfarin, dabigatran 150 mg (RR, 0.65; 95% CI 0.39 to 1.1; P=0.10) and dabigatran 110 mg (RR, 0.27; 95% CI 0.12 to 0.55; p<0.001), respectively. The rate of subdural hematomas was significantly higher with dabigatran 150 mg compared with the 110 mg dosage (RR, 2.4; 95% CI 1.1 to 5.0; P=0.02). Fatal subdural bleeding occurred in 10, 5, and 2 patients assigned to warfarin, dabigatran 150 mg, and dabigatran 110 mg respectively (p<0.05 for dabigatran 110 mg compared with warfarin).

##### All-Cause Mortality

All-cause mortality did not differ between warfarin and either dose of dabigatran (3.75% per year for dabigatran 110 mg vs. 4.13% per year for warfarin; RR 0.91; 95% CI 0.80 to 1.03; p=0.13; 3.64% per year for dabigatran 150 mg vs. 4.13% per year for warfarin; RR 0.88; 95% CI 0.77 to 1.00; p=0.051) (moderate strength of evidence of no difference with both doses).

##### Death From Vascular Causes

Death from vascular causes was lower with the higher dose of dabigatran (moderate strength of evidence) but there was no difference at the lower dose (moderate strength of evidence) (2.43% per year for dabigatran 110 mg vs. 2.69% per year for warfarin; RR 0.90; 95% CI 0.77 to 1.06; p=0.21; 2.28% per year for dabigatran 150 mg vs. 2.69% per year for warfarin; RR 0.85; 95% CI 0.72 to 0.99; p=0.04).

##### Myocardial Infarction

The rates of MI were higher with both dabigatran doses as compared with warfarin, although these results did not reach statistical significance with the lower dose (0.72% per year for dabigatran 110 mg vs. 0.53% per year for warfarin; RR 1.35; 95% CI 0.98 to 1.87; p=0.07; 0.74% per year for dabigatran 150 mg vs. 0.53% per year for warfarin; RR 1.38; 95% CI 1.00 to 1.91; p=0.048) (moderate strength of evidence of increased risk with 150 mg dabigatran and low strength of evidence at the 110 mg dose).

##### Hospitalization

Hospitalization rates were lower with dabigatran 110 mg (high strength of evidence), and there was no difference between the higher dose and warfarin (19.4% per year for dabigatran 110 mg vs. 20.8% per year for warfarin; RR 0.92; 95% CI 0.87 to 0.97; p=0.003; 20.2% per year for dabigatran 150 mg vs. 20.8% per year for warfarin; RR 0.97; 95% CI 0.92 to 1.03; p=0.34) (high strength of evidence).

##### Adverse Events

Dyspepsia was more common with dabigatran (11.8% patients with 110 mg, 11.3% patients with 150 mg compared with 5.8% with warfarin; p <0.001 for both) (moderate strength of evidence with both doses). No differences in liver function or other adverse events were seen between the groups.

##### Strength of Evidence

Table 27 summarizes the strength of evidence for outcomes of interest for these comparisons.

Table 27 Strength of evidence domains for preventing thromboembolic events—Factor IIa inhibitor (dabigatran 150 mg and 110 mg) vs. warfarin

Outcome | Number of Studies (Subjects) | Domains Pertaining to SOE | | | | SOE and Magnitude of Effect (95% CI)
Outcome | Number of Studies (Subjects) | Risk of Bias | Consistency | Directness | Precision | SOE and Magnitude of Effect (95% CI)
Factor IIa Inhibitor (Dabigatran 150 mg) vs. Warfarin
Stroke or systemic embolism | 1 (12,098) | RCT/Low | NA | Direct | Precise | SOE=High Dabigatran reduced risk (RR 0.66; 95% CI 0.53 to 0.82)
Ischemic or uncertain stroke | 1 (12,098) | RCT/Low | NA | Direct | Imprecise | SOE=Moderate Dabigatran reduced risk (RR 0.76; 95% CI 0.60 to 0.98)
Hemorrhagic stroke | 1 (12,098) | RCT/Low | NA | Direct | Precise | SOE=High Dabigatran reduced risk (RR 0.26; 95% CI 0.14 to 0.49)
Major bleeding | 1 (12,098) | RCT/Low | NA | Direct | Precise | SOE=High No difference (RR 0.93; 95% CI 0.81 to 1.07)
Minor bleeding | 1 (12,098) | RCT/Low | NA | Direct | Imprecise | SOE=Moderate Dabigatran reduced risk (RR 0.91; 95% CI 0.85 to 0.97)
Intracranial bleeding | 1 (12,098) | RCT/Low | NA | Direct | Precise | SOE=High Dabigatran reduced risk (RR 0.40; 95% CI 0.27 to 0.60)
All-cause mortality | 1 (12,098) | RCT/Low | NA | Direct | Imprecise | SOE=Moderate No difference (RR 0.88; 95% CI 0.77 to 1.00)
Death from vascular causes | 1 (12,098) | RCT/Low | NA | Direct | Imprecise | SOE=Moderate Dabigatran reduced risk (RR 0.85; 95% CI 0.72 to 0.99)
Myocardial infarction | 1 (12,098) | RCT/Low | NA | Direct | Imprecise | SOE=Moderate Dabigatran increased risk (RR 1.38; 95% CI 1.00 to 1.91)
Hospitalization | 1 (12,098) | RCT/Low | NA | Direct | Precise | SOE=High No difference (RR 0.97; 95% CI 0.92 to 1.03)
Adverse events | 1 (12,098) | RCT/Low | NA | Direct | Imprecise | SOE=Moderate Dyspepsia more common with dabigatran (11.3% of patients with dabigatran 150 mg vs. 5.8% with warfarin, p<0.001). No differences in liver function or other adverse events between therapies.
Factor IIa Inhibitor (Dabigatran 110 mg) vs. Warfarin
Stroke or systemic embolism | 1 (12,037) | RCT/Low | NA | Direct | Precise | SOE=High No difference (RR 0.91; 95% CI 0.74 to 1.11)
Ischemic or uncertain stroke | 1 (12,037) | RCT/Low | NA | Direct | Imprecise | SOE=Moderate No difference (RR 1.11; 95% CI 0.89 to 1.40)
Hemorrhagic stroke | 1 (12,037) | RCT/Low | NA | Direct | Precise | SOE=High Dabigatran reduced risk (RR 0.31; 95% CI 0.17 to 0.56)
Major bleeding | 1 (12,037) | RCT/Low | NA | Direct | Precise | SOE=High Dabigatran reduced risk (RR 0.80; 95% CI 0.69 to 0.93)
Minor bleeding | 1 (12,037) | RCT/Low | NA | Direct | Precise | SOE=High Dabigatran reduced risk (RR 0.79; 95% CI 0.74 to 0.84)
Intracranial bleeding | 1 (12,037) | RCT/Low | NA | Direct | Precise | SOE=High Dabigatran reduced risk (RR 0.31; 95% CI 0.20 to 0.47)
All-cause mortality | 1 (12,037) | RCT/Low | NA | Direct | Imprecise | SOE=Moderate No difference (RR 0.91; 95% CI 0.80 to 1.03)
Death from vascular causes | 1 (12,037) | RCT/Low | NA | Direct | Imprecise | SOE=Moderate No difference (RR 0.90; 95% CI 0.77 to 1.06)
Myocardial infarction | 1 (12,037) | RCT/Low | NA | Direct | Imprecise | SOE=Low Dabigatran increased risk, although the difference did not reach statistical significance (RR 1.35; 95% CI 0.98 to 1.87)
Hospitalization | 1 (12,037) | RCT/Low | NA | Direct | Precise | SOE=High Dabigatran reduced risk (RR 0.92; 95% CI 0.87 to 0.97)
Adverse events | 1 (12,037) | RCT/Low | NA | Direct | Imprecise | SOE=Moderate Dyspepsia more common with dabigatran (11.8% of patients with dabigatran 110 mg vs. 5.8% with warfarin, p<0.001). No differences in liver function or other adverse events between therapies.

Abbreviations: CI=confidence interval; NA=not applicable; RCT=randomized controlled trial; RR=relative risk; SOE=strength of evidence

#### Factor IIa Inhibitor (Dabigatran) ± Aspirin Versus Warfarin

One good-quality RCT (PETRO) involving 502 patients evaluated different doses of the Factor IIa inhibitor dabigatran with and without concomitant aspirin at different doses and compared with warfarin alone.160

##### Thromboembolic Events

Thromboembolic events were limited to the 50 mg dabigatran dose groups (there were 2 patients with systemic thromboembolic events, both of whom received 50 mg dabigatran twice daily [1.96%]).

##### Major Bleeding

Major hemorrhages were limited to the group treated with 300 mg dabigatran twice daily+aspirin (4 of 64), and the rate was statistically different compared with the group treated with dabigatran 300 mg twice daily without aspirin (0 of 105; p<0.02). There was a significant difference in major and clinically relevant bleeding episodes (11 of 64 vs. 6 of 105; p=0.03) and total bleeding episodes (25 of 64 versus 14 of 105; p=0.0003) between 300 mg dabigatran twice daily+aspirin and 300 mg dabigatran twice daily without aspirin. The frequency of bleeding in the group treated with 50 mg dabigatran twice daily was significantly lower than that in the warfarin group (7 of 107 vs. 12 of 70; p=0.044). When the doses of dabigatran were compared with each other, irrespective of aspirin assignment, there were differences in total bleeding episodes in the 300 mg twice daily and 150 mg twice daily groups versus the 50 mg twice daily group (37 of 169 and 30 of 169 vs. 7 of 107; p=0.0002 and p=0.01, respectively). Total bleeding events were more frequent in the 300 mg (23%) and 150 mg (18%) dabigatran groups compared with the 50 mg groups (7%).

##### Myocardial Infarction

Seven patients reported angina, of which two were classified as having acute coronary syndrome, one treated with 50 mg dabigatran twice daily+81 mg aspirin and the other treated with 300 mg dabigatran twice daily+81 mg aspirin.

##### Adverse Events

Adverse events were more frequent in the dabigatran groups than in warfarin-treated patients. The most commonly reported adverse events were gastrointestinal disorders such as diarrhea, nausea, or vomiting (26%), followed by general system disorders such as fatigue or edema (12%), dizziness and headache (12%), and infections. Most of these were mild and required no change in treatment.

#### Xa Inhibitors (Apixaban and Rivaroxaban) Versus Warfarin

Seven studies compared various factor Xa inhibitors with warfarin. One good-quality RCT (ARISTOTLE) involving 18,201 patients compared apixaban with warfarin;150 one good-quality RCT involving 1,146 patients compared edoxaban with warfarin;154 another good-quality RCT including 536 Japanese patients172 compared different edoxaban doses with warfarin; one good-quality RCT (ROCKET-AF) involving 14,264 patients compared rivaroxaban (20 mg once daily) with warfarin;28 another good-quality RCT (J-ROCKET AF) involving 1,280 Japanese patients compared a lower dose of rivaroxaban (15 mg once daily) with warfarin;171 one good-quality RCT (AMADEUS) involving 4,576 patients compared idraparinux with warfarin;159 and one fair-quality RCT (ARISTOTLE-J) compared apixaban (either 2.5 mg twice daily or 5.0 mg twice daily) with warfarin in 222 Japanese patients.151.

Although each of these RCTs compared a novel Xa inhibitor with warfarin, they differed in significant ways, making a quantitative synthesis of the findings inappropriate. Specifically, the ROCKET AF and ARISTOTLE studies were both Phase III trials of oral anticoagulants. The study by Wietz and colleagues,154 however, was a Phase II trial. The corresponding Phase III study (ENGAGE-AF) will be completed in early 2013,^204^ and at that time a synthesis of its findings with the ROCKET AF and ARISTOTLE studies would be appropriate. Also, in the AMADAEUS trial, treatment was given subcutaneously and once a week, having a very different pharmacokinetics and pharmacodynamics profile from the oral anticoagulants. Another difference between these larger trials, preventing direct comparisons of results, is the time in therapeutic range (TTR) for the participants in the warfarin arms of the study. TTRs for those on warfarin were, in general, greater for participants in the ARISTOTLE trial. TTRs for participants in the ROCKET trial were reported as lower than other trials; however, compared to “real-world” settings, TTRs for those on warfarin in the ROCKET trial were comparable and therefore relevant to clinical practice. We therefore do not combine the data from these four trials through meta-analysis, but instead describe their impact on the outcomes of interest qualitatively below.

##### Stroke or Systemic Embolism

Five studies explored the impact of Xa inhibitors versus warfarin on stroke or systemic embolism. In one study,150 in the ITT population, apixaban was shown to be superior to warfarin in preventing stroke and systemic embolism (1.27% per year vs. 1.60% per year for apixaban and warfarin, respectively; HR 0.79; 95% CI 0.66 to 0.95; p=0.01). In a second study, 28 among all randomized patients in the ITT analysis, primary events occurred in 2.1 percent per year in the rivaroxaban group and in 2.4 percent per year in the warfarin group (HR 0.88; 95% CI 0.74 to 1.03; p<0.001 for noninferiority; p=0.12 for superiority). However, in the per-protocol population, a prespecified secondary analysis, rivaroxaban was shown to be noninferior to warfarin in preventing stroke and systemic embolism (1.7% per year vs. 2.2% per year for rivaroxaban and warfarin, respectively; HR 0.79; 95% CI 0.66 to 0.96; p<0.001 for noninferiority; 1.7% per year vs. 2.2% per year for rivaroxaban and warfarin, respectively; HR 0.79; 95% CI 0.65 to 0.95; p=0.01 for superiority). Similar to the ITT analysis of the ROCKET trial,28 the ITT results of the J ROCKET-AF trial171 did not show a significant difference in primary efficacy outcome of stroke or non-CNS systemic embolism between rivaroxaban and warfarin. In the ITT population analysis including 30-day followup, the primary efficacy outcome occurred at a rate of 2.38 percent per year and 2.91 percent per year in patients receiving rivaroxaban and warfarin, respectively (HR 0.82; 95% CI 0.46 to 1.45). In the on-treatment analysis of the ITT population, the primary efficacy outcome occurred at a rate of 1.26 percent per year and 2.60 percent per year in patients receiving rivaroxaban and warfarin, respectively (HR 0.48; 95% CI 0.23 to 1.00). However, prespecified per-protocol analyses showed a strong trend for a reduction in the rate of stroke/systemic embolism with lower dose of rivaroxaban (15 mg once daily) compared to warfarin in Japanese patients in the primary per-protocol population analysis (HR, 0.49; 95% CI 0.24 to 1.00; p=0.050). In the on-treatment analysis, there were no statistically significant differences in the composite of adjudicated stroke, non-CNS systemic embolism, and vascular death (HR 0.65; 95% CI 0.34 to 1.22), or of the composite of adjudicated stroke, non-CNS systemic embolism, MI, and vascular death (HR 0.74; 95% CI 0.41 to 1.34). All-cause stroke occurred at a lower rate in patients treated with rivaroxaban than with warfarin (HR 0.46; 95% CI 0.22 to 0.98), as did primary ischemic stroke (HR 0.40; 95% CI 0.17 to 0.96). In the fourth study,159 idraparinux was noninferior to warfarin in preventing stroke and systemic embolism (0.9% and 1.3% in the idraparinux and warfarin groups, respectively; HR 0.71; 95% CI 0.39 to 1.30; p=0.007 for noninferiority in the ITT population). Idraparinux was also noninferior to warfarin in the per-protocol analysis (HR 0.74; 95% CI 0.38 to 1.43; p=0.018 for noninferiority). Finally, in the ARISTOTLE-J study,151 there were no strokes or systemic embolisms in either apixaban dose group, but the warfarin group had two ischemic strokes and one subarachnoid hemorrhage in the ITT population.

There was high strength of evidence that apixaban reduced risk of stroke or systemic embolism compared with warfarin. There was moderate strength of evidence that there was no difference in stroke risk between rivaroxaban and warfarin.

##### Ischemic or Uncertain Stroke

One study150 reported rates of ischemic or uncertain stroke that were not different between apixaban and warfarin (0.97% per year for apixaban vs. 1.05% per year for warfarin; HR 0.92; 95% CI 0.74 to 1.13; p=0.42) (high strength of evidence). One other study reported this outcome in the on-treatment population for rivaroxaban compared to warfarin;28 it showed no difference in the rate of ischemic stroke between treatment groups. In this study, those on rivaroxaban had an event rate for ischemic stroke of 1.34/100 patient-years compared with 1.42/100 patient-years for those on warfarin (HR 0.94; 95% CI 0.75 to 1.17; p=0.581). Given the on-treatment analysis, the finding that there was no difference between rivaroxaban and warfarin was rated to have moderate strength of evidence.

##### Hemorrhagic Stroke

Four studies evaluated rates of hemorrhagic stroke.28,150,159,171 In one study,150 apixaban was associated with lower rates of hemorrhagic stroke (0.24% per year for apixaban vs. 0.47% per year for warfarin; HR 0.51; 95% CI 0.35 to 0.75; p<0.001). In the second study,159 hemorrhagic stroke occurred in 0.2 percent of patients in both the idraparinux and warfarin groups. In the ROCKET AF trial,28 there was a reduced rate of hemorrhagic stroke for those on rivaroxaban compared to warfarin among those in the on-treatment population. The event rate for hemorrhagic stroke was 0.26/100 patient-years for those on rivaroxaban compared to 0.44/100 patient-years for those on warfarin (HR 0.59; 95% CI 0.37 to 0.93; p=0.024). In the J-ROCKET AF study,171 the occurrence of primary hemorrhagic stroke was similar in both treatment arms in the per-protocol analyses (HR 0.73; 95% CI 0.16 to 3.25). There was high strength of evidence that apixaban reduced risk of hemorrhagic stroke compared with warfarin. Given on-treatment (rather than intention-to-treat) and imprecise findings, there was low strength of evidence of a benefit of rivaroxaban in reducing hemorrhagic stroke.

##### Any Stroke or TIA

In one study,154 any stroke or TIA were observed in 0.4, 0.8, 0.4, 1.1, and 1.6 percent of patients in the edoxaban 30 mg daily, 30 mg twice daily, 60 mg daily, 60 mg twice daily, and warfarin treatment groups, respectively.

##### Systemic Embolism

Four studies specifically reported the impact of therapy on systematic embolism separated out from stroke. In one study,150 the rates of systemic embolism did not differ between groups (0.09% per year for apixaban vs. 0.10% per year for warfarin; HR 0.87; 95% CI 0.44 to 1.75; p=0.70.) Similar findings were seen in two other studies. In one, systemic embolism was observed in 0.4, 0.4, 0, 0, and 0 percent of patients in the edoxaban 30 mg daily, 30 mg twice daily, 60 mg daily, 60 mg twice daily, and warfarin treatment groups, respectively,154 and in the other, there was no difference between the groups (0% of patients in the idraparinux group vs. 0.1% in the warfarin group).159 Among those in the on-treatment population of the ROCKET trial,28 there was a reduced rate of non-CNS systemic embolism for those on rivaroxaban compared with warfarin. Participants on rivaroxaban had an event rate for non-CNS systemic embolism of 0.04/100 patient-years compared with 0.19/100 patient-years for those on warfarin (HR 0.23; 95% CI 0.09 to 0.61; p=0.003). There was moderate strength of evidence that there was no difference between apixaban and warfarin arms. There was moderate strength of evidence that rivaroxaban reduced risk.

##### Major Bleeding

Five studies reported on the impact of Xa inhibitors versus warfarin on the outcome of major bleeding. In one study,150 which evaluated bleeding for events for all patients who received at least one dose of a study drug, apixaban was associated with lower rates of major bleeding when compared with warfarin (2.13% per year for apixaban vs. 3.09% per year for warfarin; HR 0.69; 95% CI 0.60 to 0.80; p<0.001). In another study, in the safety, as-treated population,28 there was no difference in rates of any major bleeding between the two groups (3.6% per year for rivaroxaban vs. 3.4% per year and warfarin; HR 1.04; 95% CI 0.90 to 1.20; p=0.58). Decreases in hemoglobin levels of 2 g/dL or more and transfusions were more common among patients in the rivaroxaban group, whereas fatal bleeding and bleeding at critical anatomical sites were less frequent. Major bleeding from a gastrointestinal site was more common in the rivaroxaban group (3.2% vs. 2.2%; p<0.001). The observed rate of major bleeding events in the J-ROCKET AF study171 in the on-treatment population was 3.00 percent per year in the rivaroxaban arm compared with 3.59 percent per year in the warfarin arm (HR 0.85; 95% CI 0.50 to 1.43), and observed rates also tended to be lower with rivaroxaban for all individual components of the major bleeding outcome, although none of the differences was statistically significant. By contrast, in a fourth study,154 major bleeding events were observed in 0, 2.0, 0.4, 3.3, and 0.4 percent of patients in the edoxaban 30 mg daily, 30 mg twice daily, 60 mg daily, 60 mg twice daily, and warfarin treatment groups, respectively. Compared with warfarin, the incidence of major bleeding was significantly higher with edoxaban doses of 30 mg twice daily or 60 mg twice daily. With the 30 mg or 60 mg daily edoxaban regimens, the incidence of major bleeding was similar to that in patients randomized to warfarin. Finally, in the fifth study159 rates of major bleeding in the ITT population were significantly higher in the idraparinux group when compared with warfarin (3.9% vs. 1.4%). Fatal bleeding was also more frequent with idraparinux (0.7% vs. <0.1%). Major bleeding other than intracranial hemorrhage occurred in 2.8 percent of patient-years in the idraparinux group and in 0.9 percent patient-years in the warfarin group. A separate post hoc analysis of this study showed that patients receiving combination antithrombotic therapy had a 2.5 fold increase risk of major bleeding events compared with those receiving anticoagulation therapy only.191 There was high strength of evidence that apixaban reduced risk of major bleeding compared with warfarin, and there was moderate strength of evidence that there was no difference between rivaroxaban and warfarin.

##### Major, Nonmajor Clinically Relevant, and Minor Bleeding

In one study,172 the mean incidence of all bleeding events in patients who received at least one dose of the study drug for edoxaban 30, 45, and 60 mg, and warfarin was 18.5, 22.4, 27.7, and 20.0 percent, respectively. There were no statistically significant differences among the edoxaban groups and no significant differences from the warfarin group.

The J-ROCKET AF Study171 confirmed the noninferiority of rivaroxaban to warfarin in respect to the composite of major bleeding and nonmajor clinically relevant bleeding events in the on-treatment group (18.04% patients per year in the rivaroxaban group compared with 16.42% patients per year in the warfarin group; HR 1.11; 95% CI 0.87 to 1.42). Nonmajor clinically relevant bleeding event rates were 15.42 percent per year in rivaroxaban-treated patients compared with 12.99 percent per year in warfarin-treated patients (HR 1.20; 95% CI 0.92 to 1.56), and this difference was also not statistically significant.

##### Intracranial Bleeding

Four studies assessed intracranial bleeding, with three of these evaluating this outcome in a safety population. In two, the use of apixaban and rivaroxaban lowered such bleeding (apixaban: HR 0.42; 95% CI 0.30 to 0.58; p<0.001;^150^ rivaroxaban: HR 0.67; 95% CI 0.47 to 0.93; p=0.02^28^). In the J-ROCKET AF study,171 intracranial hemorrhages were observed in 0.8 percent of patients in the rivaroxaban group and in 1.6 percent of patients in the warfarin group. These results were not tested for statistical significance. In the fourth study,159 rates of intracranial bleeding were higher with idraparinux than with warfarin in its ITT population (1.1% vs. 0.4%; HR 2.58; 95% CI 1.18 to 5.64; p=0.014). There was high strength of evidence that apixaban reduced risk of intracranial bleeding compared with warfarin, and moderate strength of evidence that rivaroxaban did the same.

##### All-Cause Mortality

Four studies reported all-cause mortality. In one,150 apixaban was associated with lower rates of death from any cause (3.52% per year for apixaban vs. 3.94% per year for warfarin; HR 0.89; 95% CI 0.80 to 0.998; p=0.047). In the ARISTOTLE-J study151 there were no deaths in any of the treatment arms. In the other two studies, evaluating rivaroxaban and idraparinux, mortality rates were also similar between the Xa inhibitor and warfarin groups. Specifically, in one study,28 in the ITT analysis, the rates of death from any cause were similar between groups and occurred in 4.5 percent and 4.9 percent per year in the rivaroxaban and warfarin groups, respectively (HR 0.92; 95% CI 0.82 to 1.03; p=0.15). This was similar to the prespecified per-protocol analysis (1.9% per year for rivaroxaban vs. 2.2% per year for warfarin; HR 0.85; 95% CI 0.70 to 1.02; p=0.07). In the fourth study,159 there was no difference in mortality between treatment groups in the ITT population (3.2% per year in the idraparinux group vs. 2.9% per year in the warfarin group; p=0.49). There was moderate strength of evidence that apixaban reduced risk of all-cause mortality, and high strength of evidence that there was no difference between rivaroxaban and warfarin for this outcome.

##### Death From Cardiovascular Causes

Three studies assessed death from cardiovascular causes.28,150,154 All three studies showed similar rates of cardiovascular deaths across treatment arms (1.80% per year for apixaban vs. 2.02% per year for warfarin; HR 0.89; 95% CI 0.76 to 1.04;^150^ and death from cardiovascular causes occurring in 0.9, 1.6, 0, 0, and 0.8 percent of patients in the edoxaban 30 mg daily, 30 mg twice daily, 60 mg daily, 60 mg twice daily, and warfarin treatment groups, respectively154). In the on-treatment population of the ROCKET trial, the event rate for vascular death was 1.53/100 patient-years among those on rivaroxaban compared with 1.71/100 patient-years for those on warfarin (HR 0.89; 95% CI 0.73 to 1.10; p=0.289). There was high strength of evidence of no difference between treatment arms for apixaban and edoxaban, and moderate strength of evidence for of no difference between treatment arms for rivaroxaban based on the on-treatment findings.

##### Myocardial Infarction

Four studies reported rates of MI across therapies. There were no significant differences across treatment groups in any of the four studies. Specifically, in one study,150 the rates of MI were lower in the apixaban group, but this difference was not statistically significant (0.53% per year for apixaban vs. 0.61% per year for warfarin; HR 0.88; 95% CI 0.66 to 1.17; p=0.37). In the second study,154 MI occurred in 0.9, 0.4, 0.9, 0, and 0 percent of patients in the edoxaban 30 mg daily, 30 mg twice daily, 60 mg daily, 60 mg twice daily, and warfarin treatment groups, respectively. In the third study,28 in the as-treated population, rates of MI were similar between groups (0.9% and 1.1% per year for rivaroxaban and warfarin, respectively; HR 0.81; 95% CI 0.63 to 1.06; p=0.12). And similarly, in the fourth study,159 the rates of MI were similar between groups (0.8% for idraparinux vs. 0.6% for warfarin). There was moderate strength of evidence that there was no difference between apixaban or rivaroxaban and warfarin in rates of MI.

##### Hospitalization

One study154 assessed hospitalization rates and found these to be similar between treatment arms: 0.9, 0.8, 3.0, 0, and 0.4 percent of patients in the edoxaban 30 mg daily, 30 mg twice daily, 60 mg daily, 60 mg twice daily, and warfarin treatment groups, respectively.

##### Adverse Events

Studies evaluating apixaban, edoxaban, and rivaroxaban specifically looked at adverse events.150,154,171 In one,150 adverse events occurred in almost equal proportions of patients in the apixaban group and the warfarin group (81.5% and 83.1%, respectively). The rates of abnormalities on liver function testing and liver-related serious adverse events were also similar in the two groups. In another study,154 there were 11.1, 13.5, 11.5, 22.2, and 18.4 percent drug-related treatment-emergent adverse events in the edoxaban 30 mg daily, 30 mg twice daily, 60 mg daily, 60 mg twice daily, and warfarin treatment groups, respectively. Of these, the percentage of subjects with serious treatment-emergent adverse events was similar in the edoxaban (5.9%) and warfarin (4.4%) treatment groups. There were no differences in the incidence of abnormal hepatic function tests across treatment groups. In the J-ROCKET AF Study,171 elevations of hepatic enzyme activity and total bilirubin during the study were similar in the rivaroxaban and warfarin treatment groups, and there was no indication of severe liver damage. There was moderate strength of evidence that there was no difference between apixaban and warfarin for adverse events.

##### Strength of Evidence

Table 28 summarizes the strength of evidence for outcomes of interest for these comparisons.

Table 28 Strength of evidence domains for preventing thromboembolic events—Xa inhibitors (apixaban and rivaroxaban) vs. warfarin

Outcome | Number of Studies (Subjects) | Domains Pertaining to SOE | | | | SOE and Magnitude of Effect (95% CI)
Outcome | Number of Studies (Subjects) | Risk of Bias | Consistency | Directness | Precision | SOE and Magnitude of Effect (95% CI)
Xa Inhibitor (Apixaban) vs. Warfarin
Stroke or systemic embolism | 2 (18,423) | RCT/Low | Consistent | Direct | Precise | SOE=High Apixaban reduced risk (HR 0.79; 95% CI 0.66 to 0.95)
Ischemic stroke | 1 (18,201) | RCT/Low | NA | Direct | Precise | SOE=High No difference (HR 0.92; 95% CI 0.74 to 1.13)
Hemorrhagic stroke | 1 (18,201) | RCT/Low | NA | Direct | Precise | SOE=High Apixaban reduced risk (HR 0.51; 95% CI 0.35 to 0.75)
Systemic embolism | 2 (18,423) | RCT/Low | Consistent | Direct | Imprecise | SOE=Moderate No difference (HR 0.87; 95% CI 0.44 to 1.75)
Major bleeding | 2 (18,423) | RCT/Low | Consistent | Direct | Precise | SOE=High Apixaban reduced risk (HR 0.69; 95% CI 0.60 to 0.80)
Intracranial bleeding | 1 (18,201) | RCT/Low | NA | Direct | Precise | SOE=High Apixaban reduced risk (HR 0.42; 95% CI 0.30 to 0.58)
All-cause mortality | 2 (18,423) | RCT/Low | Consistent | Direct | Precise | SOE=Moderate Apixaban reduced risk (HR 0.89; 95% CI 0.80 to 0.998)
Death from cardiovascular causes | 1 (18,201) | RCT/Low | NA | Direct | Precise | SOE=High No difference (HR 0.89; 95% CI 0.76 to 1.04)
Myocardial infarction | 1 (18,201) | RCT/Low | NA | Direct | Imprecise | SOE=Moderate No difference (HR 0.88; 95% CI 0.66 to 1.17)
Adverse events | 2 (18,423) | RCT/Low | Consistent | Direct | Imprecise | SOE=Moderate Adverse events occurred in almost equal proportions of patients in the apixaban and the warfarin therapy arms
Xa Inhibitor (Rivaroxaban) vs. Warfarin
Stroke or systemic embolism | 2 (15,544) | RCT/Low | Inconsistent | Direct | Precise | SOE=Moderate No difference (HR 0.88; 95% CI 0.74 to 1.03)
Ischemic stroke | 1 (14,264) | RCT/Low | NA | Direct | Precise | SOE=Moderate No difference in on-treatment analyses (HR 0.94; 95% CI 0.75 to 1.17)
Hemorrhagic stroke | 2 (15,544) | RCT/Low | Inconsistent | Direct | Imprecise | SOE=Low In on-treatment analyses, one large RCT demonstrated benefit of rivaroxaban (HR 0.59; 95% CI 0.37 to 0.93); a smaller study showed a trend toward no difference (HR 0.73; 95% CI 0.16 to 3.25)
Systemic embolism | 1 (14,264) | RCT/Low | NA | Direct | Precise | SOE=Moderate Rivaroxaban reduced risk in on-treatment analyses (HR 0.23; 95% CI 0.09 to 0.61)
Major bleeding | 2 (15,544) | RCT/Low | Consistent | Direct | Precise | SOE=Moderate No difference in 2 studies in on-treatment analyses (HR 1.04 [95% CI 0.90 to 1.20] in one study; HR 0.85 [95% CI 0.50 to 1.43] in other study)
Intracranial bleeding | 2 (15,544) | RCT/Low | Consistent | Direct | Precise | SOE=Moderate Rivaroxaban reduced risk in on-treatment analyses (HR 0.67; 95% CI 0.47 to 0.93)
All-cause mortality | 1 (14,264) | RCT/Low | NA | Direct | Precise | SOE=High No difference (HR 0.92; 95% CI 0.82 to 1.03)
Death from cardiovascular causes | 1 (14,264) | RCT/Low | NA | Direct | Precise | SOE=Moderate No difference in on-treatment analyses (HR 0.89; 95% CI 0.73 to 1.10)
Myocardial infarction | 1 (14,264) | RCT/Low | NA | Direct | Precise | SOE=Moderate No difference in on-treatment analyses (HR 0.81; 95% CI 0.63 to 1.06)

Abbreviations: CI=confidence interval; HR=hazard ratio; NA=not applicable; RCT=randomized controlled trial; SOE=strength of evidence

#### Xa Inhibitor (Apixaban) Versus Aspirin

One good-quality RCT involving 5,599 patients compared the efficacy and safety of the direct Xa inhibitor apixaban with aspirin in AF patients in whom warfarin therapy was unsuitable.152 This study demonstrated that in the ITT population, apixaban reduced the risk of stroke or systemic embolism without significantly increasing the risk of major bleeding or intracranial hemorrhage.

##### Stroke or Systemic Embolism

Apixaban was superior to aspirin in reducing the incidence of stroke or systemic embolism (1.6% per year vs. 3.7% per year; HR 0.45; 95% CI 0.32 to 0.62; p<0.001). Systemic embolism was more frequent in the aspirin group (0.1% per year for apixaban vs. 0.4% per year for aspirin; HR 0.16; 95% CI 0.03 to 0.68; p=0.01) (high strength of evidence).

##### Ischemic Stroke

The rates of ischemic stroke were lower in the apixaban group (1.1% per year for apixaban vs. 3.0% per year for aspirin; HR 0.37; 95% CI 0.25 to 0.55; p<0.001) (high strength of evidence).

##### Hemorrhagic Stroke

There was a trend toward a benefit of apixaban reducing hemorrhagic stroke (0.2% per year for apixaban vs. 0.3% per year for aspirin; HR 0.67; 95% CI 0.24 to 1.88; p=0.45) (moderate strength of evidence).

##### Major Bleeding

There were no significant differences in major bleeding rates between the groups (1.4% per year for apixaban vs. 1.2% per year for aspirin; HR 1.13; 95% CI 0.74 to 1.75; p=0.57) (high strength of evidence).

##### Minor Bleeding

There was an increased risk of minor bleeding in patients on apixaban (6.3% per year for apixaban vs. 5.0% per year for aspirin; HR 1.24; 95% CI 1.00 to 1.53; p=0.05) (moderate strength of evidence).

##### Intracranial Bleeding

There was a trend toward a reduction in risk of intracranial bleeding for patients on apixaban (HR 0.85; 95% CI 0.38 to 1.90; p=0.69) (low strength of evidence).

##### All-Cause Mortality

Although not reaching statistical significance, there was a trend toward a reduction in all-cause mortality for patients on apixaban (3.5% per year for apixaban vs. 4.4% per year for aspirin; HR 0.79; 95% CI 0.62 to 1.02; p=0.07) (low strength of evidence).

##### Death From Vascular Causes

Death from vascular causes was similar between groups (2.7% per year for apixaban vs. 3.1% per year for aspirin; HR 0.87; 95% CI 0.66 to 1.17; p=0.37) (moderate strength of evidence).

##### Myocardial Infarction

There were no significant differences in MI rates (0.8% per year for apixaban vs. 0.9% per year for aspirin; HR 0.86; 95% CI 0.50 to 1.48; p=0.59) (moderate strength of evidence).

##### Hospitalization

Hospitalization for cardiovascular cause was lower in the apixaban group (12.6% per year for apixaban vs. 15.9% per year for aspirin; HR 0.79; 95% CI 0.69 to 0.91; p <0.001) (high strength of evidence).

##### Adverse Events

No differences in liver function or other adverse events were seen between the groups (moderate strength of evidence).

##### Strength of Evidence

Table 29 summarizes the strength of evidence for outcomes of interest for this comparison.

Table 29 Strength of evidence domains for preventing thromboembolic events—Xa inhibitor (apixaban) vs. aspirin

Outcome | Number of Studies (Subjects) | Domains Pertaining to SOE | | | | SOE and Magnitude of Effect (95% CI)
Outcome | Number of Studies (Subjects) | Risk of Bias | Consistency | Directness | Precision | SOE and Magnitude of Effect (95% CI)
Stroke or systemic embolism | 1 (5,599) | RCT/Low | NA | Direct | Precise | SOE=High Apixaban reduced risk (HR 0.45; 95% CI 0.32 to 0.62)
Ischemic stroke | 1 (5,599) | RCT/Low | NA | Direct | Precise | SOE=High Apixaban reduced risk (HR 0.37; 95% CI 0.25 to 0.55)
Hemorrhagic stroke | 1 (5,599) | RCT/Low | NA | Direct | Imprecise | SOE=Moderate Trend toward a reduction in risk with apixaban (HR 0.67; 95% CI 0.24 to 1.88)
Major bleeding | 1 (5,599) | RCT/Low | NA | Direct | Precise | SOE=High No difference (HR 1.13; 95% CI 0.74 to 1.75)
Minor bleeding | 1 (5,599) | RCT/Low | NA | Direct | Precise | SOE=Moderate Apixaban increased risk (HR 1.20; 95% CI 1.00 to 1.53)
Intracranial bleeding | 1 (5,599) | RCT/Low | NA | Direct | Imprecise | SOE=Low Trend toward a reduction in risk with apixaban (HR 0.85; 95% CI 0.38 to 1.90)
All-cause mortality | 1 (5,599) | RCT/Low | NA | Direct | Imprecise | SOE=Low Trend toward a reduction in risk with apixaban (HR 0.79; 95% CI 0.62 to 1.02)
Death from vascular causes | 1 (5,599) | RCT/Low | NA | Direct | Imprecise | SOE=Moderate No difference (HR 0.87; 95% CI 0.66 to 1.17)
Myocardial infarction | 1 (5,599) | RCT/Low | NA | Direct | Imprecise | SOE=Moderate No difference (HR 0.86; 95% CI 0.50 to 1.48)
Hospitalization | 1 (5,599) | RCT/Low | NA | Direct | Precise | SOE=High Apixaban reduced risk (HR 0.79; 95% CI 0.69 to 0.91)
Adverse events | 1 (5,599) | RCT/Low | NA | Direct | Imprecise | SOE=Moderate No differences in liver function or other adverse events between therapies

Abbreviations: ASA=aspirin; CI=confidence interval; HR=hazard ratio; NA=not applicable; RCT=randomized controlled trial; SOE=strength of evidence

#### Percutaneous Left Atrial Appendage (LAA) Closure Versus Warfarin

One good-quality RCT (PROTECT AF) involving 707 patients compared the safety and efficacy of percutaneous left atrial appendage (LAA) closure to warfarin in patients with nonvalvular AF.155

##### Composite of Stroke, Cardiovascular Death, and Systemic Embolism

The primary outcome in the trial was a composite of stroke, cardiovascular death, and systemic embolism in the ITT population. This composite outcome was lower in the LAA group (3 per 100 patient-years vs. 4.9 per 100 patient-years; rate ratio 0.62; 95% CI 0.35 to 1.25), which reached the noninferiority criteria. At 2 years of followup, the cumulative composite event rate for the LAA group was 5.9 percent compared with 8.3 percent within the warfarin group. The efficacy results were consistent across all subgroups except for sex with men having a lower HR than women (p=0.03).

##### Ischemic Stroke

After the periprocedural timeframe, 9 patients in the LAA group (1.3 events per 100 patient-years) and 6 patients in the warfarin group had ischemic stroke (1.6 events per 100 patient-years). There was low strength of evidence that there was no difference between treatment arms.

##### All Strokes

The rate of all strokes was lower in the LAA group, although the difference did not reach statistical significance (RR 0.71; 95% CI 0.35 to 1.64). There was low strength of evidence that there was toward a benefit of LAA.

##### Major Bleeding

Major bleeding was less frequent in the LAA group than in the warfarin group (3.5% vs. 4.1%) (low strength of evidence).

##### All-Cause Mortality

The cumulative mortality rates were similar between the groups in the first year (3% in the LAA group and 3.1% in the warfarin group) and lower in the LAA group at 2 years (9.1% vs. 5.9%; RR 0.62; 95% CI 0.34 to 1.24) demonstrating a trend toward a benefit of LAA (low strength of evidence).

##### Adverse Events

The primary composite outcome for safety consisted of excessive bleeding or procedure-related complications. This outcome was more frequent in the LAA group (RR 1.69; 95% CI 1.01 to 3.19). At 2 years the cumulative primary safety rate was 10.2 percent and 6.8 percent for the LAA and warfarin groups, respectively. This was driven by two procedure-related complications: pericardial effusion (4.8% in the LAA group and none in the warfarin group) and device embolization (0.6% in the LAA group and none in the warfarin group) (moderate strength of evidence).

##### Strength of Evidence

Table 30 summarizes the strength of evidence for outcomes of interest for this comparison.

Table 30 Strength of evidence domains for preventing thromboembolic events—percutaneous LAA closure vs. warfarin

Outcome | Number of Studies (Subjects) | Domains Pertaining to SOE | | | | SOE and Magnitude of Effect (95% CI)
Outcome | Number of Studies (Subjects) | Risk of Bias | Consistency | Directness | Precision | SOE and Magnitude of Effect (95% CI)
Ischemic stroke | 1 (707) | RCT/Low | NA | Direct | Imprecise | SOE=Low 9 LAA patients (1.3 events per 100 patient-years) and 6 warfarin patients (1.6 events per 100 patient-years) had ischemic stroke, demonstrating no difference between therapies
All strokes | 1 (707) | RCT/Low | NA | Direct | Imprecise | SOE=Low Trend toward a benefit of LAA (RR 0.71; 95% CI 0.35 to 1.64)
Major bleeding | 1 (707) | RCT/Low | NA | Direct | Imprecise | SOE=Low Less frequent with LAA (3.5% vs. 4.1%)
All-cause mortality | 1 (707) | RCT/Low | NA | Direct | Imprecise | SOE=Low Trend toward a benefit of LAA (RR 0.62; 95% CI 0.34 to 1.24)
Adverse events | 1 (707) | RCT/Low | NA | Direct | Imprecise | SOE=Moderate Higher rate with LAA (RR 1.69; 95% CI 1.01 to 3.19)

Abbreviations: CI=confidence interval; LAA=left atrial appendage; NA=not applicable; RCT=randomized controlled trial; RR=relative risk; SOE=strength of evidence

#### Results in Specific Subgroups of Interest

Thirty-three of our included studies focused on the comparative safety and effectiveness of specific anticoagulation therapies, antiplatelet therapies, and procedural interventions for preventing thromboembolic events in specific subgroups of interest within patients with nonvalvular AF. Below we describe these studies and the qualitative synthesis of their findings.

##### Patients Not Eligible for Warfarin Use

Only two studies have specifically looked at effectiveness of therapy in patients who were considered unsuitable for warfarin therapy.152,156 The ACTIVE-A trial156 was designed to determine whether the combination of clopidogrel (75 mg daily) plus aspirin (75 to 100 mg daily) was better than aspirin alone for prevention of stroke and cardiovascular events (non-CNS embolism, MI, or vascular death) in patients with AF and at least one additional risk factor for vascular events who were considered unsuitable for warfarin therapy. A total of 7,554 patients were enrolled in a double-blind fashion from 580 centers in 33 countries, and the median followup was 3.6 years. In the ITT analyses, the combination of clopidogrel plus aspirin compared with aspirin alone significantly reduced the primary outcome by 11 percent, primarily due to a 28 percent reduction in stroke (ischemic or unknown origin) (RR 0.72; 95% CI 0.62 to 0.83; p<0.001). MI occurred in 90 patients in the clopidogrel group (0.7% per year) and in 115 in the placebo group (0.9% per year; RR 0.78; 95% CI 0.59 to 1.03; p=0.08). Importantly, clopidogrel plus aspirin compared with aspirin alone significantly increased the rate of major bleeding, including intracranial and extracranial bleeding, from 1.3 percent to 2.0 percent per year (RR 1.57; 95% CI 1.29 to 1.92; p<0.001). The rates of bleeding in the clopidogrel plus aspirin group were very similar to those observed in the warfarin arm from the ACTIVE-W study. One should also keep in mind that among the reasons for enrolling in this trial, 50 percent of the time this was due to physician assessment that the patient was inappropriate for warfarin and therefore could be in the study, which is a subjective decision. On the other hand, it is known that this subjective decision from physicians is common in clinical practice, and the results of this trial might be applicable to daily practice. In summary, if we treat 1,000 AF patients that “cannot be put on warfarin” during 3 years, clopidogrel plus aspirin would prevent 28 strokes and 6 MIs, but it would cause 20 major bleeding events, 3 of them fatal. Thus, caution is warranted when considering clopidogrel plus aspirin for patients with AF for stroke prevention.

In the light of the ACTIVE-A results, another recent study deserves special attention. In patients with AF who failed, or were unsuitable for VKA treatment, apixaban (5 mg orally twice daily) was compared with aspirin (81–324 mg daily) in the AVERROES trial, a randomized, double-blind, and multicenter study.152 This trial enrolled about 5,600 patients. The primary efficacy outcome was the composite of stroke or systemic embolism, and secondary outcomes included the composite of: stroke, systemic embolism, MI, or vascular death (major vascular events). The study was terminated early by the data safety and monitoring board (DSMB) due to the superiority of apixaban over aspirin. This finding was more or less expected, since an oral anticoagulant was compared with aspirin, which is known to be less effective than VKAs for the prevention of stroke in patients with AF. However, the most impressive results were the similar rates of bleeding between aspirin and apixaban, which illustrates that often times the risk of bleeding associated with aspirin is underestimated. Finally, apixaban was better tolerated than aspirin, leading to a lower rate of drug discontinuation than aspirin during the course of the trial. This finding also highlights that aspirin has side effects which are sometimes underappreciated in clinical practice.

In summary, despite the established rules, risk scores, and formal contraindications that exist to guide oral anticoagulation therapy in patients with AF, decisionmaking on VKA’s eligibility in clinical practice seems to be very complex and does not necessarily rely on known factors or on data collected in clinical trials. Thus, there are a substantial number of AF patients who are not considered to be eligible to VKAs, but who are at high risk for ischemic events, and for whom an alternative strategy for stroke prevention is needed.

##### Patients With AF and Renal Impairment

One substudy188 of the ROCKET AF study28 analyzed the efficacy results using rivaroxaban compared with warfarin in patients with renal impairment. ITT analysis showed that both medications had similar results with similar rates of stroke or systemic embolism (HR 0.86; 95% CI 0.63 to 1.17). In the per-protocol population, there were 2,950 patients (20.7%) with renal impairment (creatinine clearance 30–49 mL/min) using rivaroxaban 15 mg/d (n=1,434) or warfarin (n=1,462). Among those patients, the primary outcome of stroke or systemic embolism occurred in 2.32 per 100 patient-years using rivaroxaban versus 2.77 per 100 patient-years with warfarin (HR 0.84; 95% CI 0.57 to 1.23). Rates of the principal safety outcome in the safety population (major and clinically relevant non-major bleeding: 17.82 vs. 18.28 per 100 patient-years; p=0.76) and intracranial bleeding (0.71 vs. 0.88 per 100 patient-years; p=0.54) were similar with rivaroxaban or warfarin. Fatal bleeding (0.28 vs. 0.74% per 100 patient-years; p=0.047) occurred less often with rivaroxaban. This study suggested that patients with AF and moderate renal insufficiency have higher rates of stroke and bleeding than those with normal renal function. Rivaroxaban preserved the benefit of warfarin in preventing stroke and systemic embolus and produced lower rates while on treatment. Bleeding rates with the reduced dose of rivaroxaban were similar to those on warfarin therapy, and there were fewer fatal bleeds with rivaroxaban.

One substudy200 of the AVERROES trial152 compared apixaban 5 mg twice daily (2.5 mg twice daily in selected patients) with aspirin 81–324 mg daily in 1,697 patients with stage III chronic kidney disease (CKD). Apixaban significantly reduced primary events (stroke and systemic embolism) by 68 percent (5.6% per year on aspirin vs. 1.8% per year on apixaban; HR 0.32; 95% CI 0.18 to 0.55; p<001) for stage III CKD participants and by 43 percent (2.8% per year on aspirin vs. 1.6% per year on apixaban; HR 0.57; 95% CI 0.37 to 0.87; p=.009) for patients with an estimated glomerular filtration rate (eGFR) ≥60 mL/min per 1.73m^2^ (p value for interaction=0.10) in the ITT population. There was no significant difference in major bleeding in stage III CKD patients by treatment (2.2% per year with aspirin vs. 2.5% per year with apixaban; HR 1.20; 95% CI 0.65 to 2.1).

A substudy203 of the ARISTOTLE trial150 compared apixaban 5 mg twice daily with warfarin (target INR 2·0–3·0) in different levels of GFR. According to baseline Cockcroft–Gault, there were 7,518 patients (42%) with an eGFR >80 mL/min, 7,587 (42%) with an eGFR between 50 and 80 mL/min, and 3,017 (15%) with an eGFR ≤50 mL/min. In the ITT population, rates of cardiovascular events and bleeding were higher at impaired renal function levels (eGFR ≤80 mL/min). Apixaban was more effective than warfarin in preventing stroke or systemic embolism and in reducing mortality irrespective of renal function, with no significant interaction between the treatment effect and the level of renal dysfunction. These results were consistent regardless of methods for GFR estimation, achieving statistical significance on the subgroup ≤50 mL/min by Chronic Kidney Disease Epidemiology Collaboration (CKD-EPI) (all-cause mortality and stroke/systemic embolism), subgroup Cockcroft–Gault 50–80 mL/min (stroke/systemic embolism), and subgroup cystatin C >80 mL/min (stroke/systemic embolism). Apixaban was associated with fewer major bleeding events across all ranges of eGFRs. The relative risk reduction in major bleeding was greater in patients with an eGFR ≤50 mL/min using Cockcroft–Gault (HR 0.50; 95% CI 0.38 to 0.66; p value for interaction=0.005) or CKD-EPI equations (HR 0.48; 95% CI 0.37 to 0.64; p value for interaction=0.003]. When cystatin C was used to estimate GFR, apixaban was associated with fewer bleeding events across all ranges of eGFR, but without any significant interaction with the treatment effect on major bleeding (p value for interaction=0.54).

In sensitivity analyses, trial investigators examined whether the reduction in bleeding in patients with impaired renal function was due to the more frequent use of the lower apixaban dose (2.5 mg twice daily). In both sensitivity analyses, the interaction between treatment and renal function remained statistically significant for major bleeding.

##### Patients With Paroxysmal Versus Sustained AF

One substudy195 of the ACTIVE W RCT163 analyzed the results in patients with paroxysmal AF (n=1,202) as compared with those who had sustained (persistent or permanent) AF (n=5,495). Patients with paroxysmal AF were younger, had a shorter AF history, more hypertension, and less valvular disease, heart failure, and diabetes mellitus than patients with sustained AF. Irrespective of type of AF, the incidence of stroke and non-CNS embolism was lower for patients treated with oral anticoagulation. There were more bleedings of any type in patients receiving clopidogrel plus aspirin, irrespective of the type of AF, but major bleeding events were similar in all groups (paroxysmal vs. sustained, and oral anticoagulants vs. clopidogrel+aspirin).

##### Patients With AF Undergoing Cardioversion

Four studies (including a subgroup analysis192 of the RE-LY trial27) explored stroke prevention in AF patients undergoing cardioversion.166,180,181,192 One very small study180 compared aspirin plus clopidogrel versus warfarin in the prevention of thromboembolic events in a group of patients with non-high-risk AF. Thirty patients (11 women, 45 to 75 years of age) with non-high-risk permanent (n=12) or persistent AF awaiting cardioversion (n=18) underwent transesophageal echocardiography to exclude left heart thrombi and were then randomly assigned to receive warfarin (INR 2–3 for 3 weeks) or aspirin (100 mg/day alone for 1 week) plus clopidogrel (75 mg/day added to aspirin for 3 weeks). Seven of nine patients receiving warfarin and seven of nine patients receiving aspirin+clopidogrel and undergoing electrical cardioversion achieved sinus rhythm. No thromboembolic or hemorrhagic events occurred in either arm throughout the 3-week treatment and a further 3-month followup.

A second study166 was an RCT comparing the safety and efficacy of enoxaparin administered subcutaneously with intravenous unfractionated heparin (UFH) followed by the oral anticoagulant phenprocoumon in 496 patients scheduled for cardioversion of AF of >48 hours and ≤1 year’s duration. Patients were stratified to cardioversion with (n=431) and without (n=65) guidance by transesophageal echocardiogram (TEE). The study aimed to demonstrate noninferiority of enoxaparin compared with UFH+phenprocoumon with regard to the incidence of embolic events, all-cause death, and major bleeding complications. Of 496 randomized patients, 428 were analyzed per protocol. Enoxaparin was noninferior to UFH+phenprocoumon with regard to the incidence of the composite primary outcome in an intention-to-treat analysis (7 of 248 patients vs. 12 of 248 patients, respectively; p=0.013) and in a per-protocol analysis (7 of 216 patients vs. 12 of 212 patients, respectively; p=0.016). Analyzing the events separately, none of them (cerebral embolic infarct, minor and major hemorrhagic events, and death) were statistically different between the groups. There was also no significant difference between the two groups in the number of patients reverted to sinus rhythm.

A third study181 was an RCT comparing the difference in the rate of thromboembolic events of TEE-guided early cardioversion with short-term low molecular weight heparin (LMWH) use in patients with nonvalvular persistent AF. The study group consisted of 172 consecutive patients with nonvalvular AF. Before TEE, 90 patients received LMWH (dalteparin 2 × 5,000 U) and 82 patients received standard heparin (UFH; 5,000 U bolus followed by infusion to raise APTT to 1.5 times control). TEE was performed, and the left atrium and LAA were examined thoroughly for the presence of thrombus. One patient from each group was excluded due to detection of a left atrial thrombus by TEE. Immediately after TEE, cardioversion was attempted and warfarin was initiated. All patients received warfarin for one month after cardioversion. In the LMWH group, 89 of 90 patients (98.9%) were successfully cardioverted. Cardioversion was successful in 97.5 percent of the patients in the UFH group. None of the patients experienced thromboembolic events during the 4 weeks after cardioversion.

The fourth study192 was a subgroup analysis of the RE-LY trial27 evaluating patients that were submitted to cardioversion therapy during the trial. Data from before, during, and 30 days after cardioversion were analyzed. A total of 1,983 cardioversions were performed in 1,270 patients: 647, 672, and 664 in the dabigatran 110 mg, dabigatran 150 mg, and warfarin groups, respectively. For dabigatran 110 mg, dabigatran 150 mg, and warfarin, TEE was performed before 25.5, 24.1, and 13.3 percent of cardioversions, respectively, of which 1.8, 1.2, and 1.1 percent, respectively, were positive for left atrial thrombi. Continuous treatment with study drug for ≥3 weeks before cardioversion was lower in dabigatran 110 mg (76.4%) and dabigatran 150 mg (79.2%) compared with warfarin (85.5%; p<0.01 for both). Stroke and systemic embolism rates at 30 days were 0.77, 0.3, and 0.6 percent in dabigatran 110 mg, dabigatran 150 mg, and warfarin, respectively (dabigatran 110 mg vs. warfarin, p=0.71; dabigatran 150 mg vs., p=0.40) and similar in patients with and without TEE. Major bleeding rates were 1.7, 0.6, and 0.6 percent, respectively (dabigatran 110 mg vs. warfarin, p=0.06; dabigatran 150 mg vs. warfarin, p=0.99).

##### Patients With AF After Stroke

Seven studies explored stroke prevention treatment in patients with AF who had previously suffered a stroke164,168,178,193,197–199

The Heparin in Acute Embolic Stroke Trial (HAEST)168 was a multicenter RCT on the effect of LMWH (dalteparin 100 IU/kg subcutaneously twice a day) or aspirin (160 mg every day) for the treatment of 449 patients with acute ischemic stroke and AF. The primary aim was to test whether treatment with LMWH, started within 30 hours of stroke onset, is superior to aspirin for the prevention of recurrent stroke during the first 14 days. The frequency of recurrent ischemic stroke during the first 14 days was 19/244 (8·5%) in dalteparin-allocated patients versus 17/225 (7·5%) in aspirin-allocated patients (OR 1·13; 95% CI 0·57 to 2·24). In the ITT analyses, the OR remained unchanged after adjusting for sex in logistic-regression analysis (1·19; 95% CI 0·60 to 2·36). The secondary events during the first 14 days also revealed no benefit of dalteparin compared with aspirin. There were no significant differences in functional outcome or death at 14 days or 3 months.

A prespecified subgroup analysis197 of the ROCKET AF study28 investigated whether the efficacy and safety of rivaroxaban compared with warfarin was consistent among patients with and without previous stroke or TIA. A total of 14,264 patients from 1,178 centers in 45 countries were included. Patients with AF who were at increased risk of stroke (CHADS_2_ score >2) were randomly assigned (1:1) in a double-blind manner to rivaroxaban 20 mg daily or adjusted dose warfarin (to maintain INR 2.0–3.0). Patients and investigators were masked to treatment allocation. The primary outcome was the composite of stroke or non-CNS systemic embolism as a safety outcome. The treatment effects of rivaroxaban and warfarin were compared among patients with and without previous stroke or TIA. The safety analyses were done in the on-treatment population. Efficacy analyses were analyzed by ITT, and 7,468 (52%) patients had a previous stroke (n=4,907) or TIA (n=2,561). The number of events per 100 person-years for the primary outcome in patients treated with rivaroxaban compared with warfarin was consistent among patients with previous stroke or TIA (2.79% rivaroxaban vs. 2.96% warfarin; HR 0.94; 95% CI 0.77 to 1.16) and those without (1.44% vs. 1.88%; HR 0.77; 95% CI 0.58 to 1.01; comparison interaction p=0.23). Similarly, the number of major and non-major clinically relevant bleeding events per 100 person-years in patients treated with rivaroxaban compared with warfarin was consistent among patients with previous stroke or TIA (13.31% rivaroxaban vs. 13.87% warfarin; HR 0.96; 95% CI 0.87 to 1.07) and those without (16.69% vs. 15.19%; HR 1.10; 95% CI 0.99 to 1.21; comparison interaction p=0.08).

One observational study178 followed a consecutive series of AF patients with first-ever ischemic stroke and evaluated prospectively those with moderate to severe disability (grade 4–5 on the modified Rankin Scale) who were treated during a 5-year followup period with either warfarin or aspirin. Death and recurrent vascular events were documented. Out of a pool of 438 AF patients, 191 were prospectively assessed. During a mean followup of 50.4 months, the cumulative 5-year mortality was 76.7% (95% CI 69.0 to 84.3), and the 5-year recurrence rate was 33.7% (95% CI 23.3 to 44.1). Additionally, two non-cerebral major bleeding events requiring hospital admission and blood transfusion were recorded in the warfarin group. Only one non-cerebral bleeding event was documented in the aspirin group. The annual event rates for all major bleeding complications in aspirin and warfarin groups were 0.7 and 3.3 percent, respectively. Aspirin versus warfarin was an independent predictor of mortality. Prior TIA and aspirin versus warfarin were predictors of vascular recurrence. Anticoagulation was associated with a decreased risk of death (HR 0.44; 95% CI 0.27 to 0.70; p<0.001) and recurrent thromboembolism (HR 0.36; 95% CI 0.17 to 0.77; p<0.01). The results of this observational study suggest that chronic anticoagulation therapy may be effective in lengthening survival and preventing recurrent thromboembolism in AF patients who have suffered a severely disabling ischemic stroke.

An observational study164 analyzed recurrent cerebral and non-cerebral ischemic vascular events, major intracerebral and extracerebral bleeding, and vascular death in 401 consecutive patients with ischemic stroke or TIA and AF who were discharged with oral anticoagulation, antiplatelet agents, or heparin only in a clinical routine setting. Patients on oral anticoagulation at time of discharge were significantly younger and had suffered a major stroke less often than patients who received antiplatelet agents or heparin at discharge. One year after discharge, adherence to therapy was higher in patients discharged on oral anticoagulation (72%) than in those on antiplatelet agents (46%; p<0.001). The majority of patients discharged on heparin were subsequently treated with oral anticoagulation. During a median followup of 25 months (IQR, 15–38), 103 (26%) patients experienced a complication: 91 (88%) patients an ischemic complication and 12 (12%) a bleeding complication. The rate of ischemic complications and the overall rate of complications were lowest in patients discharged on oral anticoagulation. Patients on antiplatelet agents at discharge suffered from ischemic complications significantly more often during the follow-up period than patients on oral anticoagulation or heparin at discharge (30% vs. 16% vs. 23%; p=0.031). Patients on antiplatelet agents suffered their first vascular complication significantly sooner after discharge than patients on oral anticoagulation. Safety outcomes showed that three percent of the patients on antiplatelet agents and four percent of those on oral anticoagulation suffered from major bleeding complications during follow-up (p=0.028). The rate of intracranial bleeding was higher in patients on oral anticoagulation (3% vs. 1%), but the total numbers were too small to allow a valid statistical comparison. Total mortality was lowest in patients discharged on oral anticoagulation, and vascular mortality also seemed somewhat lower in this group but the difference was not significant.

A predefined analysis193 was conducted of the outcomes of the RE-LY trial27 in subgroups of patients with or without previous stroke or transient ischemic attack. The primary efficacy outcome was stroke or systemic embolism, and the primary safety outcome was major hemorrhage. Within the subgroup of patients with previous stroke or TIA, 1,195 patients were from the 110 mg dabigatran group, 1,233 from the 150 mg dabigatran group, and 1,195 from the warfarin group. Stroke or systemic embolism occurred in 65 patients (2.78% per year) on warfarin compared with 55 (2.32% per year) on 110 mg dabigatran (relative risk [RR] 0.84; 95% CI 0.58 to 1.20) and 51 (2.07% per year) on 150 mg dabigatran (RR 0.75, 95% CI 0.52 to 1.08). The rate of major bleeding was significantly lower in patients on 110 mg dabigatran (RR 0.66; 95% CI 0.48 to 0.90) and similar in those on 150 mg dabigatran (RR 1.01; 95% CI 0.77 to 1.34) compared with those on warfarin. The effects of both doses of dabigatran compared with warfarin were not significantly different between patients with previous stroke or TIA and those without for any of the outcomes from RE-LY apart from vascular death (110 mg group compared with warfarin group, interaction p=0.038). By these results, the effects of 110 mg dabigatran and 150 mg dabigatran twice daily in patients with previous stroke or TIA are consistent with those of other patients in RE-LY, for whom, compared with warfarin, 150 mg dabigatran reduced stroke or systemic embolism and 110 mg dabigatran was noninferior.

A prespecified subgroup analysis198 of AVERROES152 included 5,599 patients (mean age 70 years) with AF who were at increased risk of stroke and unsuitable for warfarin therapy. These patients were randomly assigned to receive apixaban 5 mg twice daily (n=2,808) or aspirin 81–324 mg per day (n=2,791). The primary efficacy outcome was stroke or systemic embolism in the ITT population; the primary safety outcome was major bleeding. In this subanalysis of patients with previous stroke or TIA, the effects of apixaban in patients with and without previous stroke or TIA were compared. The cumulative HR for stroke or systemic embolism at 1 year was 5.73% (95% CI 4.10 to 8.02) in patients with previous stroke or TIA and 2.36% (1.93 to 2.89) in those without. In patients with previous stroke or TIA treated with apixaban, the rates of stroke or systemic embolism, ischemic stroke, and disabling or fatal stroke were consistently lower than those in patients treated with aspirin. In patients with previous stroke or TIA, 10 events of stroke or systemic embolism occurred in the apixaban group (n=390), cumulative hazard 2.39% per year) compared with 33 in the aspirin group (n=374). This resulted in a cumulative hazard of 2.39 percent in the apixaban group and 9.16 percent per year in the aspirin group (HR 0.29; 95% CI 0.15 to 0.60). In those without previous stroke or TIA, 41 events (n=2,417, 1.68% per year) and 80 events (n=2,415, 3.06% per year) occurred in the apixaban and aspirin groups, respectively (HR 0.51; 95% CI 0.35 to 0.74). Compared with those treated with aspirin, the 1-year risk of stroke or systemic embolism decreased by 73 percent in patients treated with apixaban and with previous stroke or TIA (1-year absolute risk reduction of 6.4%; 95% CI 2.8 to 10.0) and by 45 percent in patients treated with apixaban and without previous stroke or TIA (1-year absolute risk reduction of 1.4%, 95% CI 0.4 to 2.3). The p values for interaction between history of previous stroke or TIA and treatment were not significant, indicating that the results in the subgroups were consistent with the overall result of the study. Major bleeding, the primary safety outcome, was more frequent in patients with history of previous stroke or TIA than in patients without this history (HR 2.88; 95% CI 1.77 to 4.55), but risk of this event did not differ between treatment groups. The effect of apixaban versus aspirin for bleeding complications was consistent in the two subgroups, with nonsignificant interaction p values.

A prespecified subgroup analysis199 from the ARISTOTLE trial150 evaluated the efficacy and safety of apixaban compared with warfarin in subgroups of patients with and without previous stroke or TIA. The primary efficacy outcome was stroke or systemic embolism, analyzed by intention to treat. The primary safety outcome was major bleeding in the on-treatment population. Outcomes in patients with and without previous stroke or TIA were compared. Of the trial population, 3,436 (19%) had a previous stroke or TIA. In the subgroup of patients with previous stroke or TIA, the rate of stroke or systemic embolism was 2.46 per 100 patient-years of followup in the apixaban group and 3.24 in the warfarin group (HR 0.76; 95% CI 0.56 to 1.03); in the subgroup of patients without previous stroke or TIA, the rate of stroke or systemic embolism was 1.01 per 100 patient-years of followup with apixaban and 1.23 with warfarin (HR 0.82; 95% CI 0.65 to 1.03). The relative risk reduction of stroke or systemic embolism with apixaban versus warfarin was similar among patients with and those without previous stroke or TIA (p for interaction=0.71). The reduction in rates of cardiovascular death, disabling or fatal stroke, and all-cause mortality with apixaban versus warfarin was similar in patients with and without previous stroke or TIA (p for interaction=0.53, 0.18, and 0.89, respectively). Compared with patients without previous stroke or TIA, patients with previous stroke or TIA were more likely to have major bleeding (HR 1.37; 95% CI 1.17 to 1.62) and intracranial bleeding (2.15, 95% CI 1.57 to 2.96). The relative risk reductions in major bleeding and total bleeding with apixaban versus warfarin were similar in both groups (p for interaction=0.69 and 0·.0, respectively). Intracranial bleeding was reduced in the apixaban groups from 1.49 per 100 patient-years of followup on warfarin to 0.55 per 100 patient-years on apixaban in those with previous stroke or TIA (HR 0.37; 95% CI 0.21 to 0.67) and from 0.65 per 100 patient-years of followup on warfarin to 0.29 per 100 patient-years on apixaban in those without previous stroke or TIA (0.44, 95% CI 0.30 to 0.66). Based on these results, the effects of apixaban versus warfarin were consistent in patients with AF with and without previous stroke or TIA.

##### Patients With AF and Different Thromboembolic Risks

Eight studies explored the comparative safety and effectiveness of stroke prevention therapy in patients with different thromboembolic risks.14,102,110,174,183,187,194,202

An observational study102 sought to determine the efficacy and safety of warfarin and aspirin in patients with nonvalvular AF, with separate analyses according to predicted thromboembolic and bleeding risk. Nationwide registries allowed the identification of all patients discharged with nonvalvular AF in Denmark (n=132,372). For every patient, the risk of stroke and bleeding was calculated by CHADS_2_, CHA_2_DS_2_-VASc, and HAS-BLED. In different groups according to thromboembolic risks, warfarin consistently lowered the risk of thromboembolism compared with aspirin; the combination of warfarin+aspirin did not yield any additional benefit. In patients at high thromboembolic risk, HRs (95% CIs) for thromboembolism were (adjusted for all baseline characteristics): CHA_2_DS_2_-VASc ≥2: HR 1.81 (1.73 to 1.90), 1.14 (1.06 to 1.23) for aspirin and warfarin+aspirin, respectively, compared with warfarin; CHADS_2_ ≥2: HR 1.73 (1.64 to 1.83), 1.05 (0.96 to 1.15), for aspirin and warfarin+aspirin, respectively, compared with warfarin. The risk of bleeding was increased with warfarin, aspirin, and warfarin+aspirin compared with no treatment; the HRs were 1.0 (warfarin; reference), 0.93 (aspirin; 0.89–0.97), 1.64 (warfarin+aspirin; 1.55–1.74), and 0.84 (no treatment; 0.81–0.88), respectively. This large cohort study corroborates the effectiveness of warfarin and no effect of aspirin treatment on the risk of stroke/thromboembolism. Also, the risk of bleeding was increased with both warfarin and aspirin treatment, but the net clinical benefit was clearly positive, in favor of warfarin in patients with increased risk of stroke/thromboembolism.

A post hoc analysis14 was performed to determine the relationship of risk levels (quantified using the CHADS_2_) and thromboembolic events in patients with nonvalvular AF. A total of 509 patients with nonvalvular AF were analyzed, and the CHADS_2_ score of 0 was classified as low risk, 1–2 a moderate risk, and ≥3 high risk. Warfarin was given to 263 patients (mean INR at enrollment, 1.86), antiplatelets (aspirin or ticlopidine) to 163 patients, and no antithrombotic therapy to 83. The event rate increased as the risk level estimated with CHADS_2_ score increased in patients in the non-warfarin group, although the difference did not reach the significance level (p=0.11). In contrast, the event rate differed significantly between the three different risk level groups of patients receiving warfarin (p=0.015), but paradoxically the event rate of the low-risk group was higher than that of the moderate-risk group (3.9% vs. 1.9%). Surprisingly, the event rate was 7.7 percent per year for high-risk patients receiving warfarin. INR levels at the time of enrollment did not differ among the three groups of warfarin-treated patients (low risk, 1.82 ± 0.81; moderate risk, 1.92 ± 0.87; high risk, 1.78 ± 0.70). The unpredictable results shown above could be attributed to the fact that patients with hypertrophic cardiomyopathy but without any clinical risk factors for thromboembolism were defined as low risk, but they actually experienced thromboembolic events frequently. When patients with hypertrophic cardiomyopathy were excluded from the analyses, the event rates increased in patients receiving warfarin as the risk level increased (p=0.033).

A prospective cohort study110 analyzed the effectiveness and safety of oral anticoagulants in 796 outpatients with nonvalvular AF in daily clinical practice, according to embolic risk evaluated by means of CHADS_2_ score. Oral anticoagulation was prescribed to 564 (71%) patients. After 2.4 ± 1.9 years of followup, the embolic event (TIA, ischemic stroke, peripheral embolism) rates (per 100 patient-years) for each stratum of the CHADS_2_ score for patients with/without oral anticoagulants were: 1/4.1, p=0.23 (CHADS_2_=0); 0.6/7.1, p=0.0018 (CHADS_2_=1); 0.5/5.1, p=0.0014 (CHADS_2_=2); 2.4/12.5, p=0.0017 (CHADS_2_=3) and 2.9/20, p=0.013 (CHADS_2_≥4). The severe bleeding rates for the same CHADS_2_ score strata were 3/0.8, 0.8/0.7, 1.3/0.7, 0.4/0, and 2.9/5 in patients with/without oral anticoagulants (non-significant.). This study demonstrated that oral anticoagulants appeared safe and effective in patients with CHADS_2_≥1.

Another observational study174 compared warfarin versus aspirin therapy for the prevention of stroke in AF patients with CHADS_2_ score=1. Among 1,502 patients (mean 62.4 ± 13.8 years old, male 65.4%) who were treated for nonvalvular AF without previous stroke, the number of patients with CHADS_2_ score=1 was 422 (62.9 ± 10.7 years old, male 290 [68.7%]) and their antithrombotic therapies were as follows: warfarin (n=143), aspirin (n=124), other antiplatelet (n=45), and no antithrombotic therapy (none: n=110). During followup, the incidence of ischemic stroke was significantly lower in warfarin (6 patients, 4.2%) than in aspirin (16 patients, 12.9%, p=0.008) than none (23 patients, 20.9%, p <0.001) without differences in all-cause mortality. There was no difference in the incidence of major bleeding between patients on warfarin (2.1%) and aspirin (0.8%, p=NS), but minor bleeding was more common in patients on warfarin (10.5%) than in on aspirin (2.4%, p=0.007).

In ACTIVE W,163 oral anticoagulation was more efficacious than combined clopidogrel plus aspirin in preventing vascular events in patients with AF. A subanalysis of ACTIVE W194 evaluated the findings according to risk stratification using the CHADS_2_ score. Treatment-specific rates of stroke and major bleeding were calculated for patients with a CHADS_2_=1 and compared with those with a CHADS_2_ >1. The ACTIVE W primary outcome (stroke, noncentral nervous system systemic embolism, all-cause mortality, and MI) occurred more frequently in patients on clopidogrel+aspirin, both with CHADS_2_=1 (3.28% per year versus 1.92% per year, RR=1.72, p=0.01) and with CHADS_2_ >1 (7.14% per year versus 5.18% per year, RR 1.40, p=0.0035). CHADS_2_ status did not significantly affect the relative benefit of oral anticoagulants for this outcome (P for interaction=0.41). Observed stroke rates for those with a CHADS_2_=1 were 1.25 percent per year on clopidogrel+aspirin and 0.43 percent per year on oral anticoagulants (RR 2.96; 95% CI 1.26 to 6.98; p=0.01). Among patients with a CHADS_2_>1, the stroke rates were 3.15 percent per year on clopidogrel+aspirin and 2.01 percent per year on oral anticoagulants (RR 1.58; 95% CI 1.11 to 2.24; p=0.01; p for interaction between stroke risk category and efficacy of oral anticoagulants=0.19). The risk of major bleeding during oral anticoagulants was significantly lower among patients with CHADS_2_=1 (1.36% per year) compared with CHADS_2_>1 (2.75% per year) (RR 0.49; 95% CI 0.30 to 0.79; p=0.003). For patients with CHADS_2_=1, the rate of major bleeding was 2.09 percent per year on clopidogrel+aspirin, which was higher than the rate of 1.36 percent per year on oral anticoagulants (RR 1.55; 95% CI 0.91 to 2.64; p=0.11). For patients with CHADS_2_>1, major bleeding occurred at a rate of 2.63 percent per year on clopidogrel+aspirin and 2.75 percent per year on oral anticoagulants (RR 0.97; 95% CI 0.69 to 1.35; p=0.84). The relative risk of major bleeding with clopidogrel+aspirin, compared with oral anticoagulants was not significantly different between patients with high and low CHADS_2_ scores (p for interaction=0.15); however, the absolute risk of major bleeding on oral anticoagulants was significantly lower among patients with CHADS_2_=1 compared with CHADS_2_>1 (RR=0.49; 95% CI 0.30 to 0.79; p=0.0003). Based on these results, patients with a CHADS_2_=1 had a low risk of stroke, yet still derived a modest (<1% per year) but statistically significant absolute reduction in stroke with oral anticoagulants compared with clopidogrel+aspirin and had low rates of major hemorrhage on oral anticoagulants.

A subgroup analysis187 of the RE-LY trial27 evaluated the prognostic importance of CHADS_2_ risk score in patients with AF receiving oral anticoagulants, including warfarin and the direct thrombin inhibitor dabigatran. Of the18,112 patients, the distribution of CHADS_2_ scores were as follows: 0–1, 5,775 patients; 2, 6,455 patients; and 3–6, 5,882 patients. Annual rates of the primary outcome of stroke or systemic embolism among all participants were 0.93, 1.22, and 2.24 percent in patients with a CHADS_2_ score of 0–1, 2, and 3–6 respectively. Annual rates of other outcomes among all participants with CHADS_2_ scores of 0–1, 2, and 3–6, respectively, were 2.26, 3.11, and 4.42 percent (major bleeding); 0.31, 0.40, and 0.61 percent (intracranial bleeding); and 1.35, 2.39, and 3.68 percent (vascular mortality) (p <0.001 for all comparisons). Rates of stroke or systemic embolism, major and intracranial bleeding, and vascular and total mortality each increased in the warfarin and dabigatran groups with increasing CHADS_2_ score. The reduction in stroke or systemic embolism with dabigatran 150 mg twice daily versus warfarin was consistent across the CHADS_2_ risk groups. Across CHADS_2_ risk groups, the rates of stroke or systemic embolism were similar with dabigatran 110 mg twice daily and warfarin. The rates of intracranial bleeding with dabigatran 150 mg or 110 mg twice daily were lower than those with warfarin; there was no significant heterogeneity in subgroups defined by CHADS_2_ scores.

A fair-quality observational study183 that included 8,962 patients with AF and a CHA_2_DS_2_-VASc score=0 showed that among untreated patients, the rates of stroke/thromboembolism, major bleeding, and mortality were 0.64 percent, 1.12 percent, and 1.08 percent per year, respectively. Use of oral anticoagulation and/or antiplatelet therapy was not associated with a reduction in stroke/thromboembolism (RR 0.99; 95% CI 0.25 to 3.99; p=0.99) and was not associated with a different prognosis in terms of bleeding events, improved survival, or a composite outcome of stroke/thromboembolism, bleeding, and death (RR 0.80; 95% CI 0.40 to1.61; p=0.53).

Finally, a secondary analysis202 of the ARISTOTLE trial150 compared apixaban 5 mg twice daily versus warfarin (target INR 2·0–3·0) in patients with different levels of risk of stroke and of bleeding in AF, according to patients’ CHADS_2_,, CHA_2_DS_2_-VASc, and HAS-BLED scores. Irrespective of CHADS_2_ score, patients assigned to apixaban had significantly lower rates of stroke or systemic embolism, mortality, International Society on Thrombosis and Haemostasis (ISTH) major bleeding, intracranial bleeding, and any bleeding than did those assigned warfarin, with no evidence of statistical heterogeneity. The benefits of apixaban compared with warfarin for all outcomes (including events during treatment only) across CHA_2_DS_2_-VASccategories were similar to those seen across CHADS_2_ score categories. No difference was recorded for MI. Irrespective of HAS-BLED score, patients assigned to apixaban had lower rates of stroke or systemic embolism, mortality, ISTH major bleeding, Thrombolysis in Myocardial Infarction (TIMI) major or minor bleeding, Global Use of Strategies to Open Occluded Coronary Arteries (GUSTO) severe or moderate bleeding, and any bleeding, including events during treatment only, than did those assigned to warfarin. The reduction in intracranial bleeding with apixaban compared with warfarin was greater in patients with a HAS-BLED score of 3 or higher (HR 0·22; 95% CI 0·10 to 0·48) than was the reduction seen in those with a HAS-BLED score of 0–1 (HR 0·66; 95% CI 0·39 to 1·12), but not significantly so (p value for interaction=0·0604). Finally, regardless of CHADS_2_, CHA_2_DS_2_-VASc, and HAS-BLED score, patients who received apixaban had fewer events than did patients who received warfarin, with lower rates of the composite of stroke, systemic embolism, ISTH major bleeding, and all-cause mortality.

##### Patients With AF According to INR Control

Four studies evaluated treatment safety and effectiveness according to center-based INR control.121,167,169,184 In the first study,121 incident ischemic strokes were evaluated in a cohort of 13,559 patients with nonvalvular AF. Of 596 ischemic strokes, 32 percent occurred during warfarin therapy, 27 percent during aspirin therapy, and 42 percent during neither type of therapy. Among patients who were taking warfarin, an INR of <2.0 at admission, as compared with an INR of ≥2.0, independently increased the odds of a severe stroke in a proportional odds logistic-regression model (OR 1.9; 95% CI 1.1 to 3.4) across three severity categories of stroke and the risk of death within 30 days (HR 3.4; 95% CI 1.1 to 10.1). The proportion of patients who had a severe or fatal stroke did not differ significantly between those with an admission INR of 1.5–1.9 and those with an INR of <1.5. After adjustment for potential confounders in the proportional odds model, the medication group remained an independent risk factor for the severity of stroke when patients who had an INR ≥2.0 were compared with those who had an INR of <2.0 or those who were taking neither aspirin nor warfarin. An INR of 1.5–1.9 at admission was associated with a mortality rate similar to that for an INR of <1.5 (18% and 15%, respectively). The 30-day mortality rate among patients who were taking aspirin at the time of the stroke was similar to that among patients who were taking warfarin and who had an INR <2.0. The rate of ischemic stroke was highest at INR values <2.0, especially values <1.5. By contrast, there was no marked absolute increase in the rate of intracranial hemorrhage at INR values <4.0. Based on these results, anticoagulation that results in an INR ≥2.0 in patients with nonvalvular AF reduces the frequency of ischemic stroke, its severity, and the risk of death from stroke.

A second study167 analyzed the efficacy and safety of conventional and low-intensity warfarin therapy in a prospective, randomized, multicenter trial. The study population consisted of patients with nonvalvular AF who had a stroke or TIA. The patients were randomly allocated into a conventional-intensity group (INR 2.2–3.5) and a low-intensity group (INR 1.5–2.1). A total of 115 patients were enrolled (mean age 66.7/66.5 years): Fifty-five and 60 patients were allocated into the conventional- and low-intensity groups, respectively. The trial was stopped when major hemorrhagic complications occurred in 6 patients of the conventional-intensity group and the frequency (6.6% per year) was significantly higher than that in the low-intensity group (0% per year, p=0.01, Fisher’s exact test). All of the 6 patients with major bleeding were elderly (mean age 74 years, mean INR before the major hemorrhage 2.8). The annual rate of ischemic stroke was low in both groups and similar (1.1% per year in the conventional-intensity group vs. 1.7% per year in the low-intensity groups, p=NS).

A third observational study included an analysis of warfarin subgroups according to INR control compared with no therapy.169 Ischemic stroke rate relative risk (RR) was 0.93 (95% CI 0.71 to1.22) in patients below therapeutic range (INR<2), 0.69 (0.57 to0.83) in the group within therapeutic range (INR 2–3), 0.82 (0.57 to 1.20) in patients above therapeutic range (INR >3), and 0.62 (0.56 to 0.69) in the group with unknown therapeutic range. Intracranial hemorrhage RR was 1.16 (95% CI 0.62 to 2.16) in patients below therapeutic range (INR <2), 1.13 (0.74 to 1.72) in the group within therapeutic range (INR 2–3), 3.26 (1.67 to 6.38) in patients above therapeutic range (INR >3), and 1.29 (0.98 to 1.69) in the group of unknown therapeutic range.

Another observational study of fair quality184 including 815 patients compared the effects of two different intensities of warfarin therapy (INR values <2 versus INR >2) and showed higher bleeding rates in the group with INR >2 (p<0.001), with no significant differences in the frequencies of ischemic stroke between the two groups (HR 1.93; 95% CI 0.80 to 4.70; p=0.146).

##### Elderly Patients With AF

Eleven studies specifically explored the safety and effectiveness of stroke prevention therapies in the elderly.157,161,165,175–177,179,182,185,189,190

A single-center, retrospective, observational study175 included data from patients aged ≥65 years with chronic nonvalvular AF treated at an urban academic geriatrics practice over a 1-year period. Eligible patients were receiving noninvasive management of AF with warfarin or aspirin. A total of 112 patients (mean age, 82 years) were identified; 106 were included in this analysis (80 women, 26 men). Warfarin was prescribed in 85 percent (90 patients); aspirin in 15 percent (16). The distributions of both the CHADS_2_ and Outpatient Bleeding Risk Index scores were not significantly different between the warfarin and aspirin groups. The proportions of patients treated with warfarin were not significantly different between the groups with a high risk for hemorrhage and the groups at lower risk. At 12 months in the 90 patients initially treated with warfarin, the rate of stroke was 2 percent (2 patients); major hemorrhage, 6 percent (5); and death, 20 percent (18). The number of patients who received aspirin was too small to provide sufficient power to detect significant treatment differences.

A prospective clinical study157 of four clinical services of geriatric medicine included 209 inpatients, (mean age 84.7±7 years; women 60.8%) with chronic AF. The patients were distributed into two groups (anticoagulant or aspirin) according to medical decision. The evolution of the patients was recorded after 3 months. One hundred and two patients (48.8%) received anticoagulant and 107 patients received aspirin. Patients in the aspirin group were significantly older (86.5±6.5 vs. 82.9±7.1 years), had more frequent social isolation, had higher systolic blood pressure, and had more important subjective bleeding risk and risk of falls. After 3 months, the two groups did not significantly differ for death, bleeding, or ischemic events.

A prospective RCT161 included 973 patients aged 75 years or over (mean age 81·5 years, SD 4·2) with AF from primary care who were randomly assigned to warfarin (target INR 2–3) or aspirin (75 mg per day). The primary outcome was fatal or disabling stroke (ischemic or hemorrhagic), intracranial hemorrhage, or clinically significant arterial embolism. Analysis was by intention to treat. There were 24 primary events (21 strokes, 2 other intracranial hemorrhages, and 1 systemic embolus) in people assigned to warfarin, and 48 primary events (44 strokes, 1 other intracranial hemorrhage, and 3 systemic emboli) in people assigned to aspirin in the ITT population (yearly risk 1.8% vs. 3.8%, relative risk 0.48; 95% CI 0.28 to 0.80; p=0·003). Yearly risk of extracranial hemorrhage was 1.4 percent (warfarin) versus 1.6 percent (aspirin) (relative risk 0.87, 95% CI 0.43 to 1.73).

An RCT176 of primary thromboprophylaxis for AF included patients aged >80 and <90 randomized to receive dose-adjusted warfarin (INR 2.0–3.0) or aspirin 300 mg. The primary outcome measure was a comparative frequency of combined outcomes comprising death, thromboembolism, serious bleeding, and withdrawal from the study. Seventy-five patients (aspirin 39; warfarin 36) were entered (mean age 83.9, 47% male). Patients on aspirin had significantly more adverse events (13/39; 33%) than patients on warfarin (2/36; 6%; p=0.002). Ten of 13 aspirin adverse events were caused by side effects and serious bleeding; there were three deaths (two aspirin, one warfarin).

Another RCT177 recruited patients over 75 years of age without previous stroke or systemic embolism. Patients were randomized into three groups, (A) aspirin 100 mg/day, (B) fixed-dose warfarin 1 mg/day; and (C) adjusted-dose warfarin with a target range of INR between 1.6 and 2.5. The study was discontinued 6 months after the enrollment of the first patient for safety reasons. Over a mean followup period of 3.7 months, two patients from group B (n=14) developed a dangerous prolongation of the INR (7.0 and 4.2), which led to the discontinuation of fixed-dose warfarin. Another patient from the same group experienced a major bleeding event 1 month after enrollment in the study (INR 5.5). The percentage of INR measurements within the target range was significantly lower in group B (48.7%) than in group C (83.7%) (p<0.001).

A prospective observational study179 included 207 older people (>75 years) with AF and first ever ischemic stroke. During the followup period (mean 88.4 months, range 3–120), the study population was under either oral anticoagulants (n=72) or aspirin (n=135). The cumulative 10-year mortality and recurrence rates were 92.5 percent (95% CI 85.7 to 99.3) and 66.1 percent (95% CI 43.1 to 89.1), respectively. Increasing age, functional dependency at hospital discharge, and antiplatelet versus anticoagulation therapy were independent determinants of mortality. Antiplatelet versus anticoagulation therapy was the sole determinant of vascular recurrence. Anticoagulation was associated with decreased risk of death (HR 0.47; 95% CI 0.31 to 0.72; p=0.001)) and recurrent thromboembolism (HR 0.31; 95% CI 0.16 to 0.62; p=0.002). These results suggest that the benefits of anticoagulation for secondary stroke prevention in AF patients extend to elderly.

A retrospective cohort analysis165 evaluated persons discharged on warfarin after an AF admission using data from Medicare’s National Stroke Project. It examined antiplatelet therapy among warfarin users and the impact on major bleeding rates. Prediction of concurrent antiplatelet use and hospitalization with a major acute bleed within 90 days after discharge from the index AF admission was assessed. A total of 10,093 warfarin patients met inclusion criteria with a mean age of 77 years; 19.4 percent received antiplatelet therapy. Antiplatelet use was less common among women, older persons, and persons with cancer, terminal diagnoses, dementia, and bleeding history. Persons with coronary disease were more likely to receive an antiplatelet agent. Antiplatelets increased major bleeding rates from 1.3 percent to 1.9 percent (P=0.052). In the multivariate analysis, factors associated with bleeding events included age (OR, 1.03; 95% CI 1.002 to 1.05), anemia (OR, 2.52; 95% CI 1.64 to 3.88), a history of bleeding (OR, 2.40; 95% CI 1.71 to 3.38), and concurrent antiplatelet therapy (OR, 1.53; 95% CI 1.05 to 2.22).

A substudy189 of the BAFTA trial161 evaluated 665 patients aged 75 or over with AF based in the community who were randomized within the BAFTA trial and were not taking warfarin throughout or for part of the study period. A total of 54 (8%) patients had an ischemic stroke, four (0.6%) had a systemic embolism, and 13 (2%) had a TIA. Based on this single trial population, current risk stratification schemes in older people with AF have only limited ability to predict the risk of stroke.

Another study182 examined the effectiveness of oral anticoagulation on risk of stroke of any nature (fatal and nonfatal ischemic and/or hemorrhagic stroke) in patients with nonvalvular AF or flutter living in the County of North Jutland, Denmark. This study used the Hospital Discharge Registry covering the county (490,000 inhabitants) from 1991 to 1998 to identify 2,699 men and 2,425 women with AF or flutter, aged 60–89 years. The risk of stroke associated with use of oral anticoagulation compared with no use was estimated, after adjustment for age, diabetes and underlying cardiovascular diseases. A total of 838 of 2,699 men (31%) and 552 of 2,425 women (23%) with AF had one or more recorded prescriptions of oral anticoagulation. The incidence rates of stroke were 31 per 1000 person-years of followup in men, and 30 per 1000 person-years of followup in women. The adjusted relative risks of stroke during anticoagulation were 0.6 (95% CI 0.4 to 1.0) in men, and 1.0 (95% CI 0.7 to 1.6) in women compared with nonuse periods. The adjusted relative risks of stroke associated with use of oral anticoagulation compared with no use varied by age in men, but not in women. In men aged 60–74 years the adjusted relative risk associated with use of oral anticoagulation compared with no use was 0.5 (95% CI 0.3 to 0.9), and in men aged 75–89 years the adjusted relative risk of stroke associated with oral anticoagulation compared with no use was 0.9 (95% CI 0.4 to 1.8). The adjusted relative risk of stroke increased with age. In men and women, the risk of stroke amongst patients aged 80–89 years was increased by a factor of 2.0 and 2.9 relative to the stroke risk amongst patients aged 60–69 years.

The RE-LY trial27 randomized 18,113 patients to receive dabigatran 110 or 150 mg twice a day or warfarin dose adjusted to an INR of 2.0–3.0 for a median followup of 2.0 years. A substudy of this trial190 assessed the impact of age on the findings and found that there was a significant treatment-by-age interaction, such that dabigatran 110 mg twice a day compared with warfarin was associated with a lower risk of major bleeding in patients aged <75 years (1.89% vs. 3.04%; p<0.001) and a similar risk in those aged ≥75 years (4.43% vs. 4.37%; P=0.89; P for interaction <0.001), whereas dabigatran 150 mg twice a day compared with warfarin was associated with a lower risk of major bleeding in those aged <75 years (2.12% vs. 3.04%; p<0.001) and a trend toward higher risk of major bleeding in those aged ≥75 years (5.10% vs. 4.37%; p=0.07; p for interaction <0.001). The interaction with age was evident for extracranial bleeding, but not for intracranial bleeding, with the risk of the latter being consistently reduced with dabigatran compared with warfarin irrespective of age. Based on these results, patients with AF at risk for stroke, both doses of dabigatran compared with warfarin have lower risks of both intracranial and extracranial bleeding in patients aged <75 years. In those aged ≥75 years, intracranial bleeding risk is lower but extracranial bleeding risk is similar or higher with both doses of dabigatran compared with warfarin.

Finally, a retrospective study of 233 patients aged 80 years or older with AF evaluated the efficacy and safety of oral anticoagulation therapy with low (2.0) versus standard (2.5) INR targets. Hemorrhages and thromboses occurred only in the group with standard INR.185.

##### Patients With AF Undergoing Drug-Eluting Stent Implantation

One prospective cohort study173 analyzed outcomes in 622 AF patients who underwent drug-eluting stent (DES) implantation. Among them, 142 patients (TT group) continued triple antithrombotic therapy comprising aspirin, clopidogrel, and warfarin after discharge; 355 patients (DT group) had dual antiplatelet therapy; 125 patients (WS group) were discharged with warfarin and a single antiplatelet agent. Primary outcome was defined as the occurrence of major adverse cardiac and cerebral events (MACCE) including death, MI, target vessel revascularization, stent thrombosis, or stroke at 12 months. The TT group had a significant reduction in stroke and MACCE (8.8% vs. 20.1% vs. 14.9%; p=0.010) as compared with either the DT or WS group. Warfarin use (HR 0.49; 95% CI 0.31 to 0.77; p=0.002) and baseline CHADS_2_ score ≥2 (HR 2.09; 95% CI 1.27 to 3.45; p=0.004) were independent predictors of MACCE. Importantly, the incidence of major bleeding was comparable among the three groups (2.9% vs. 1.8% vs.2.5%; p=0.725), although the overall bleeding rate was increased in the TT group. Analyzing the events separately in two ways of comparison (all three therapies and therapies with warfarin versus therapy without warfarin), the only event that achieved statistically significance was stroke in the comparison of therapy with warfarin (DT and TT) versus dual antiplatelet therapy without warfarin (less stroke in warfarin group).

##### Patients With AF and Myocardial Infarction

One substudy of the RE-LY trial27 evaluated the use of therapies for stroke prevention in AF patients with MI.196 In this analysis, the relative effects of dabigatran versus warfarin on myocardial ischemic events were consistent in patients with or without a baseline history of MI or coronary artery disease. Patients with a baseline history of coronary artery disease (CAD) or previous MI are at risk for recurrent ischemic events. There were 1,886 (31%) CAD/MI patients in the dabigatran 110 mg group, 1,915 (31%) in the dabigatran 150 mg group, and 1,849 (31%) in the warfarin group. The relative effects of dabigatran compared with warfarin were highly consistent between patients with prior CAD/MI compared with those without (all probability values for interaction were nonsignificant).

##### Elderly Patients With AF and Myocardial Infarction

One observational study170 evaluated the effects of a combination of antithrombotics in 7,619 NSTEMI patients aged ≥65 years with AF. Relative to aspirin alone, antithrombotics were associated with increased bleeding risk (adjusted HR 1.22; 95% CI 1.03 to 1.46 for aspirin+clopidogrel vs. aspirin alone; adjusted HR 1.46; 95% CI 1.21 to 1.80 for warfarin+aspirin vs. aspirin alone). Patients treated with triple therapy of aspirin+clopidogrel+warfarin had the greatest bleeding risk (HR 1.65; 95% CI 1.30 to2.10). The rates of major cardiac outcomes (death, readmission for MI, or stroke) were similar between groups, although relative to aspirin alone, there was a trend toward lower risk for the warfarin+aspirin group (HR 0.88; 95% CI 0.78 to 1.00).

## Key Question 4 Anticoagulation Strategies in Patients Undergoing Invasive Procedures

KQ 4. What are the comparative safety and effectiveness of available strategies for anticoagulation in patients with nonvalvular AF who are undergoing invasive procedures?

### Key Points

- The included studies of oral anticoagulation after percutaneous coronary intervention (PCI) with stenting (3 good-quality retrospective studies; 689 patients) were relatively small and reached different conclusions regarding the effectiveness of triple therapy (warfarin+aspirin+clopidogrel) compared with other combinations of therapies for both bleeding and ischemic outcomes (insufficient strength of evidence for all outcomes assessed).
- Studies of bridging therapies (7 retrospective studies; 2 good quality, 4 fair quality, 1 poor quality; 2,797 patients) were hampered by the variety of procedures (radiofrequency ablation [RFA], other surgeries) and strategies assessed and provided inconclusive findings (insufficient strength of evidence for all outcomes assessed).
- Two studies investigating the safety of dabigatran versus warfarin in the periprocedural period (RFA) reported higher bleeding rates among patients using dabigatran, while the single study comparing dabigatran with warfarin in patients undergoing PCI found no differences in bleeding or ischemic complications (3 studies; 2 good quality, 1 poor quality; 5,037 patients; insufficient strength of evidence).

### Description of Included Studies

Thirteen studies were included in our analysis (Appendix Table F-4),205–217 of which seven were prospective cohort studies,205,208–211,213,214 five were retrospective cohort studies,206,207,212,215,216 and one was a prospective observational study within an RCT.217 These studies assessed oral anticoagulation after PCI with stenting,205–207 bridging therapies,208–214 or dabigatran in the periprocedural setting.215–217 We analyze each of these groups separately in the “Detailed Synthesis” section, below.

The numbers of patients analyzed varied from 104–4,591, although all studies but one217 enrolled fewer than 703 patients. Seven studies were single-center,205,206,208–210,212,215 five were multicenter,207,213,214,216,217 and one did not report the number of sites.211 Studies were conducted in the United States,211,212,215,216 South America,208 Asia,209 and Europe;205–207,210,213,214 one study was conducted in multiple continents.217 Studies were conducted between the years 1999 and 2011. Seven were rated as good quality,205–207,209,211,216,217 four as fair quality,208,210,213,214 and two as poor quality.212,215 Two studies were government funded,209,214 two were sponsored by industry,210,217 one received funding from both government and industry,213 and eight received no funding or the funding source was unclear or not reported.205–208,211,212,215,216 Subjects ranged in age from a mean of 55–78.6 years; a total of 8,523 subjects were enrolled.

### Detailed Synthesis

#### Overview

Our analysis was limited by the small number of included studies, the variability of the clinical context studied, and the variability of the anticoagulation strategies employed. For the purposes of this analysis, the studies are grouped according to indication studied, in particular according to whether they assessed anticoagulation post-PCI with stenting, bridging therapies, or dabigatran in the periprocedural setting. The main findings are summarized in Table 31.

Table 31 Summary of findings for KQ 4

Study | N | Comparators | Outcomes | Results
OAC After PCI With Stenting
Maegdefessel, 2008^205^ | 159 | Clopidogrel+ASA (n=103) Clopidogrel+ASA+LMWH (n=42) Clopidogrel+ASA+OAC (n=14) | Followup: 1.4 years Major bleeding MI Ischemic stroke CV mortality | Major bleeding: 2 vs. 0 vs. 0 events MI: 4 vs. 0 vs. 0 events Ischemic stroke: 9 vs. 4 vs. 0 CV mortality: 3 vs. 5 vs. 1
Manzano-Fernandez, 2008^206^ | 104 | Clopidogrel+ASA (n=53) Clopidogrel+ASA+OAC (n=51) | Followup: 12 months Early major bleeding (within 48 hours post-PCI) Late major bleeding (after 48 hours post-PCI) Composite outcome: MACE (CV mortality, MI, revascularization, stent thrombosis) | Early major bleeding: 5.3% vs. 11.3% (p=0.33) Late major bleeding: 3.8% vs. 21.6% (p=0.006); HR 7.1 (95% CI 1.5 to 32.4) Composite: 21.0% vs. 25.5% (p=0.53)
Ruiz-Nodar, 2008^207^ | 426 | Antipplatelet agents only (n=184) Antiplatelet therapy+OAC (n=242) | Followup: 594 days Composite outcome: MACE (death, MI, TVR) Composite outcome: MACE+major bleeding+stroke Major bleeding Minor bleeding Death MI | Composite (MACE): 38.7% vs. 26.5% (p=0.01) Composite (MACE+major bleeding+stroke): 39.2% vs. 26.8% (p=0.014) Major bleeding: 9.0 vs. 14.9%( p=0.19) Minor bleeding: 9.0% vs. 12.6% (p=0.32) Death: 27.8% vs. 17.8% (p=0.02) MI: 10.4% vs. 6.5% (p=0.14)
Bridging Therapies
Kiviniemi, 2012^214^ | 414 | Uninterrupted OAC without additional anticoagulation (n=196) Uninterrupted OAC with additional anticoagulation (n=218) | Followup: In-hospital Composite: MACCE (death, MI, TVR, stent thrombosis, stroke) Death MI TVR Stent thrombosis Stroke TIMI major bleeding Access site complications | Composite: 4.1% vs. 3.2% (p=0.79) Death: 1.0% vs. 1.8% (p=0.69) MI: 1.5% vs. 1.4% (p=1.0) TVR: 1.5% vs. 0.5% (p=0.35) Stent thrombosis: 1.5% vs. 0.5% (p=0.35) Stroke: 0.5% vs. 0% (p=0.47) TIMI major bleeding 1.0% vs. 3.7% (p=0.11) Access site complications: 5.1% vs. 11% (p=0.032)
Lahtela, 2012^213^ | 451 | Uninterrupted OAC (n=290) Stop OAC and add bridging therapy with LMWH (n=161) | Followup: 30 days Composite outcome: MACCE (death, MI, TVR, stent thrombosis, stroke) Death MI Re-revascularization Stent thrombosis Stroke All bleeding events Major bleeding Access site bleeding | Composite: 3.8% vs. 6.2% (p=0.25) Death: 2.1% vs. 2.5% (p=0.73) MI: 1.0% vs. 1.9% (p=0.67) Re-revascularization: 0.7% vs. 2.5% (p=0.19) Stent thrombosis: 2.1% vs. 1.2% (p=0.72) Stroke: 0.3% vs. 0% (p=1.0) All bleeding: 12.% vs. 18.6% (p=0.07) Major bleeding: 1.4% vs. 2.5% (p=0.25) Access site bleeding: 5.5% vs. 11.2% (p=0.030)
Saad, 2011^208^ | 140 | Enoxaparin 1 mg/kg (n=55) Warfarin (n=49) | Followup: 16 months Minor bleeding Major bleeding CV mortality All-cause mortality Systemic embolism | Minor bleeding: 4(5.7%) vs. 2 (2.8%) Major bleeding: 1 (1.4%) vs. 1 (1.4%) CV mortality: None All-cause mortality: None Systemic embolism: None
Kwak, 2010^209^ | 104 | Enoxaparin 1 mg/kg (n=70) Warfarin (n=70) | Followup: In-hospital Major bleeding Minor bleeding Ischemic stroke | Major bleeding: 2 (3.6%) vs. 6 (12.2%) events (p=0.14) Minor bleeding: 8 (14.5%) vs. 3 (6.1%) (p=0.28) Ischemic stroke: None
Bunch, 2009^212^ | 630 | Aspirin (n=123) Warfarin (n=507) | Followup: 12 months Death Stroke TIA | Death: 0 vs. 5 (1.0%; p=0.59) Stroke: 0 vs. 4 (0.8%; p=0.24) TIA: None
Hammerstingl, 2009^210^ | 703 | Patients at low risk of thromboembolic events: Enoxaparin 1 mg/kg once a day (n=345) Patients at high risk of thromboembolic events: Enoxaparin 1 mg/kg twice daily (n=358) | Followup: 30 days Composite outcome: stroke/TIA, arterial embolism Major bleeding Minor bleeding | Composite: No events Major bleeding: 1 (0.29%) vs. 2 (0.56%) Minor bleeding: 25 (7.25%) vs. 35 (9.78%)
Wazni, 2007^211^ | 355 | Enoxaparin 1 mg/kg twice daily (n=105) Enoxaparin 0.5 mg/kg twice daily (n=100) Warfarin (INR 2–3.5) (n=150) | Followup: 3 months Ischemic stroke Minor bleeding Major bleeding | Ischemic stroke: 1 (1.0%) vs. 2 (2.0%) vs. 0 (p=0.12) Minor bleeding: 23 (21.9%) vs. 19 (19.0%) vs. 8 (5.3%) (p<0.001) Major bleeding: 9 (8.6%) vs. 0 vs. 0 (p<0.001)
Dabigatran in the Periprocedural Setting
Healey, 2012^217^ | 4,591 | Dabigatran 110 mg twice daily (n=1,487) Dabigatran 150 mg twice daily (n=1,546) Warfarin (n=1,558) | Followup: 30 days Minor bleeding Major bleeding Fatal bleeding Transfusion CV death Stroke Systemic embolism MI Composite outcome: CV death, ischemic stroke, non-CNS embolism, and pulmonary embolism | Minor bleeding: 8.1% vs. 9.0% vs. 7.8% Major bleeding: 3.8% vs. 5.1% vs. 4.6% Fatal bleeding: 0.2% vs. 0.1% vs. 0.1% Transfusion: 3.3% vs. 3.5% vs. 4.0% CV death: 0.6% vs. 0.5% vs. 0.5% Stroke: 0.5% vs. 0.5% vs. 0.6% Systemic embolism: 0.1% vs. 0.1% vs. 0.1% MI: 0.1% vs. 0.5% vs. 0.3% Composite: 1.2% vs. 1.5% vs. 1.2% All comparisons p=NS
Lakkireddy, 2012^216^ | 290 | Dabigatran 150 twice daily withheld morning of procedure (n=145) Uninterrupted warfarin (n=145) | Followup: 30 days Major bleeding Minor bleeding Groin hematoma Total bleeding Embolic complications (CVA/TIA) Composite outcome: Total bleeding+embolic complications | Major bleeding: 6% vs. 1% (p=0.019) Minor bleeding: 8% vs. 6% (p=0.35) Groin hematoma: 4% vs. 3% (p=0.75) Total bleeding: 14% vs. 6% (p=0.031) Embolic complications: 2% vs. 0% (p=0.25) Composite: 16% vs. 6% (p=0.009)
Snipelisky, 2012^215^ | 156 | Dabigatran (n=31) Warfarin (n=125) | Followup: 1 week Major complications Minor complications | Major complications: 0% vs. 0% Minor complications: 19.4% vs. 16.8% (p=0.74)

Abbreviations: ASA=aspirin; CI=confidence interval; CNS=central nervous system; CV=cardiovascular; CVA=cerebrovascular accident; HR=hazard ratio; INR=international normalized ratio; KQ=Key Question; LMWH=low molecular weight heparin; MACCE=major adverse cardiac and cerebrovascular events; MACE=major adverse cardiac events; MI=myocardial infarction; N=number of participants; NS=not statistically significant; OAC=oral anticoagulation; PCI=percutaneous coronary intervention; TIA=transient ischemic attack; TIMI=Thrombolysis In Myocardial Infarction trial; TVR=target vessel revascularization

#### Oral Anticoagulation After PCI With Stenting

Three studies compared antiplatelet therapy plus oral anticoagulation with antiplatelet therapy alone after PCI with stenting.205–207 All were cohort studies subject to the biases inherent in the clinical decision of anticoagulation strategy implemented at the discretion of the physician. The strategies compared differed across studies, making cross-study analysis difficult. One study compared dual therapy with aspirin plus clopidogrel with “triple therapy,” defined as either aspirin plus clopidogrel plus LMWH, or as aspirin plus clopidogrel plus oral anticoagulation.205 A second study compared triple therapy (dual antiplatelet therapy plus warfarin) with dual therapy (clopidogrel plus aspirin).206 Finally, the third study compared a strategy of antiplatelet agents alone with antiplatelet agents plus oral anticoagulation;207 however, the antiplatelet agents used were not consistent. Given the known association of both bleeding and protection against thromboembolic events with each of the agents considered, it was deemed inappropriate to combine any of these treatment strategies for analysis.

In general, these studies enrolled an older patient population (mean age 69–71) with a high proportion of patients with diabetes (33–54%), hypertension (82–91%), and hyperlipidemia (>50%), reflecting the demographics of a patient population with AF and coronary disease. The median CHADS_2_ score was 2, with an IQR of 2–3, indicating that a vast majority of patients had a CHADS_2_ score of at least 2.

##### Major Bleeding

One study206 reported major bleeding within 48 hours of PCI and found no significant difference in the occurrence of early major bleeding between the two treatment arms (5.8% for triple therapy vs. 11.3% for dual therapy, p=0.33). In the same study, triple therapy was associated with a significantly higher rate of major bleeding (21.6% for triple therapy vs. 3.8% for dual therapy, p=0.006) during the first 6 months of followup.

At followup at 1.4 years, one study205 reported two major bleeding events in the dual antiplatelet therapy group and none in the triple therapy arms. The third study207 reported a nonsignificant increase of major (14.9% vs. 9.0%, p=0.19) and minor (12.6% vs. 9.0%) bleeding among patients discharged on triple therapy compared with those on dual antiplatelet therapy (insufficient strength of evidence).

##### Mortality

Two studies compared the effect of triple therapy versus dual antiplatelet therapy on mortality.205,207 One205 reported three cardiovascular deaths in the dual antiplatelet therapy group, five cardiovascular deaths among patients receiving triple therapy with LMWH, and one cardiovascular death among patients receiving triple therapy with oral anticoagulant. The second study207 reported a statistically significantly higher rate of all-cause mortality among patients discharged on dual antiplatelet therapy compared with those on triple therapy (10.4% vs. 6.5%; HR 3.43; 95% CI 1.61 to 7.54; p=0.002) (insufficient strength of evidence).

##### Myocardial Infarction

Two studies compared the effect of triple therapy versus dual antiplatelet therapy on myocardial infarction.205,207 One205 reported four myocardial infarction events in the dual antiplatelet therapy group and none in the triple therapy arms. The other207 reported a nonsignificant increase in the rate of myocardial infarction events (10.4% vs. 6.5%) among patients discharged on dual antiplatelet therapy compared with those on triple therapy (insufficient strength of evidence).

##### Composite Outcomes

Two studies compared the effect of triple therapy versus dual antiplatelet therapy on the composite outcome of death, myocardial infarction, and revascularization or stent thrombosis.206,207 One206 found no significant difference in the rate of the composite endpoint between the two treatment arms (25.5% triple therapy vs. 21.0% dual therapy, p=0.53). The other207 reported a statistically significantly higher rate of the composite outcome among patients discharged on dual antiplatelet therapy compared with those on triple therapy (38.7% vs. 26.5%; HR 4.9; 95% CI 2.17 to 11.1; p=0.01). Similarly, in this same study, a significant increase in the secondary safety endpoint (any major adverse cardiovascular event, major bleeding, and/or stroke) was observed among patients treated with dual therapy compared with triple therapy (39.2% vs. 26.8%, p=0.014).

#### Bridging Therapies

Seven studies assessed bridging therapies during cardiac and non-cardiac procedures.208–214 Three studies compared a bridging strategy involving LMWH with a strategy not employing LMWH;208,209,211 Across the studies, the surgical procedures (RFA,208,209,211,212 minor and major surgery210 and PCI213,214) varied, as did the comparator arms. These studies reported on shorter term, periprocedural outcomes.

Two trials compared a strategy of “bridging” peri-RFA with enoxaparin versus continuous oral anticoagulation.208,209 The only demographic data available for both studies were on the age of the population, which appears to have differed significantly across the two studies (mean age 73–76 years in one study208 and 55–56 years in the other209) and sex (~83% male in one study,208 74% male in the other209). Other risk factors for thromboembolism and bleeding were inconsistently reported between the two studies.

Two studies compared performance of PCI on uninterrupted oral anticoagulation versus using a variety of bridging strategies. In the first,213 comparison was made between those undergoing PCI with continuous oral anticoagulation, including those who received additional periprocedural heparin, versus those in whom oral anticoagulation was stopped. There were trends toward lower bleeding events in those maintained on uninterrupted oral anticoagulation; however, the use of radial procedures was markedly higher in this arm (43.4% vs. 13.7%; p<0.0001), which may have accounted for this observation. Interestingly, once propensity matching was performed, no differences were observed in any bleeding or ischemic endpoint, suggesting that these treatment strategies appeared to be equivalent in this small, underpowered study.

A second study assessed the impact of giving additional anticoagulation to patients undergoing PCI while already therapeutic on oral anticoagulants.214 This study suggested that additional anticoagulation administered during the procedure may increase risk of bleeding (3.7% vs. 1.0%; p=0.11) while not impacting ischemic events (3.2 vs. 4.1%; p=0.79). Major access site complications were lower (5.1% vs. 11.0%; p=0.032) in patients who did not receive additional anticoagulation.

These two studies should be interpreted with caution. Decisions about anticoagulation were not randomized, and therefore the findings are potentially confounded by the multiple differences between the populations in the comparison groups. Furthermore, given the small number of ischemic events, the safety of this approach to minimizing ischemic events remains to be established and would require studies of a different order of magnitude.

##### Major and Minor Bleeding

Major and minor bleeding events were reported by six of the seven bridging studies. In one study,208 one patient experienced a major bleeding complication (1.4%) in the LMWH group versus none in the oral anticoagulation group at 16±8 months followup. In the same study, minor bleeding complications occurred at a higher rate in the LMWH group than in the oral anticoagulation group (5.7% vs. 2.8%). Similarly, in another study211 patients in the LMWH group exhibited higher rates of major bleeding than those in the oral anticoagulation group (9 vs. 0 patients, p <0.001). In another study,209 the in-hospital bleeding complication rate was not statistically different in the oral anticoagulation group than in the LMWH group (18.4% vs. 18.2%, p=1.000), and the major bleeding rate was higher in the oral anticoagulation group (12.2%) than in the LMWH group (3.6%) but did not reach statistical significance (p=0.1444). In contrast, when bridging therapy was compared with uninterrupted oral anticoagulation in the setting of PCI213 bleeding trended higher with the bridging strategy (18.6% vs. 12.1%, p=0.07). In the study that assessed bridging anticoagulation during other operative procedures, only three major bleeding events were reported in the entire cohort (n=703).210 As described above, in the study assessing the impact of giving additional anticoagulation to patients undergoing PCI while already therapeutic on oral anticoagulants,214 additional anticoagulation administered during the procedure increased the risk of bleeding (3.7% vs. 1.0%, p=0.11).

Despite these commonalities, the differences in procedures and bleeding definitions in these trials, as well as the relative rarity of serious bleeding and ischemic complications, make definitive conclusions premature and point to the need for much larger studies powered to detect differences in the risk of relatively rare events (insufficient strength of evidence).

##### Mortality

There were no deaths reported in one report.208 Two reports failed to comment on death explicitly,209,210 although one indicated no post-discharge thrombotic or bleeding complications.209 One study reported five deaths in patients treated with warfarin post-RFA compared with none in those treated with aspirin; however, there was no attempt to correct for preprocedural differences in these patients, and the difference was not statistically significant (p=0.59).212 Finally, in one study,213 there were six and four deaths in the oral anticoagulation and bridging therapy arms, respectively; the difference between the two arms was not statistically significant (insufficient strength of evidence).

##### Myocardial Infarction

Myocardial infarction events were not reported as an outcome in any of the included studies except in the PCI setting, in which case the rate was identical for the two strategies evaluated (oral anticoagulation vs. bridging therapy, 1.0% vs. 1.9%)213 (insufficient strength of evidence).

##### Other Thromboembolic Outcomes

In three studies,208–210 none of the patients experienced ischemic stroke, peripheral embolism, or other thromboembolic complications during followup. In one study,211 one patient in the LMWH full-dose group and two patients in the LMWH lower dose group developed ischemic stroke, but no patient developed ischemic stroke in the oral anticoagulation group (p=0.12). In another study,212 there were four CVA/TIA events in patients treated with warfarin compared with aspirin; however, there were multiple baseline differences between groups for which no statistical modeling/correction was attempted.

#### Use of Dabigatran in the Periprocedural Setting

More recently, three studies have investigated the safety of dabigatran in the periprocedural period in patients with AF.215–217 Two of these evaluated the use of dabigatran versus warfarin during RFA.215,216 While one of these reported no major complications,215 both studies report higher major and minor bleeding rates in patients receiving dabigatran (16.8% warfarin vs. 19.4% dabigatran,215 and 6% warfarin vs. 14% dabigatran216). In a subanalysis (n=4,951) of a larger study (RE-LY) of patients undergoing a variety of invasive procedures, Healey et al.217 reported no significant differences in the incidence of bleeding or ischemic complications in patients treated with either 110 or 150 mg twice daily of dabigatran compared with warfarin.

#### Strength of Evidence

Table 32 summarizes the strength of evidence for the various comparisons and outcomes of interest.

Table 32 Strength of evidence domains for anticoagulation strategies in patients undergoing invasive procedures

Outcome | Number of Studies (Subjects) | Domains Pertaining to SOE | | | | SOE and Magnitude of Effect (95% CI)
Outcome | Number of Studies (Subjects) | Risk of Bias | Consistency | Directness | Precision | SOE and Magnitude of Effect (95% CI)
OAC After PCI With Stenting
Major bleeding | 3 (689) | Observational/Moderate | Inconsistent | Direct | Imprecise | SOE=Insufficient
Mortality | 2 (585) | Observational/Moderate | Inconsistent | Direct | Imprecise | SOE=Insufficient
Myocardial Infarction | 2 (585) | Observational/Moderate | Inconsistent | Direct | Imprecise | SOE=Insufficient
Bridging Therapies
Major and minor bleeding | 6 (2,167) | Observational/High | Inconsistent | Direct | Imprecise | SOE=Insufficient
Mortality | 5 (1,932) | Observational/High | Inconsistent | Direct | Imprecise | SOE=Insufficient
Other thomboembolic outcomes | 5 (1,932) | Observational/High | Inconsistent | Direct | Imprecise | SOE=Insufficient
Use of Dabigatran in Periprocedural Setting
Major and minor bleeding | 3 (5,037) | Observational/High | Inconsistent | Direct | Imprecise | SOE=Insufficient

Abbreviations: CI=confidence interval; OAC=oral anticoagulation; PCI=percutaneous coronary intervention; SOE=strength of evidence

## Key Question 5 Strategies for Switching Between Warfarin and Novel Oral Anticoagulants

KQ 5. What are the comparative safety and effectiveness of available strategies for switching between warfarin and other novel oral anticoagulants, in patients with nonvalvular AF?

### Key Points

- There is currently no safety or effectiveness evidence to answer this question based on the absence of any peer-reviewed published studies in this area (insufficient strength of evidence for all outcomes of interest).

### Description of Included Studies

There is no independent, peer-reviewed, published evidence that answers this question. In lieu of such evidence, we describe briefly below:

- Guidance given on this topic in the study protocol for one major RCT;
- Relevant information from package inserts for rivaroxaban and dabigatran; and
- Four unpublished trials that may provide evidence soon.

### Detailed Synthesis

The RE-LY study protocol218 advised providers to stop warfarin on the day of randomization and begin the assigned drug (dabigatran) when the INR fell below 2.0 (if randomized to dabigatran) or below 3.0 (if randomized to warfarin).

Manufacturers (Janessen/Bayer, Boehringer Ingelheim) have included the following information in their package inserts for rivaroxaban and dabigatran:

- “Discontinue warfarin and start Xarelto^®^ [rivaroxaban] as soon as the INR is below 3.0 to avoid periods of inadequate anticoagulation.”219
- “Discontinue warfarin and start Pradaxa^®^ [dabigatran] when the INR is below 2.0.”220

These statements do not reference any published evidence.

Finally, although we did not identify any relevant studies within the published literature, our search of ClinicalTrials.gov identified four clinical trials (two ongoing, two recently completed) that may provide data regarding optimal switching strategies between warfarin and other novel oral anticoagulants for patients with AF. These are described briefly in Table 33.

Table 33 Ongoing and recently completed trials relevant to KQ 5

ClinicalTrials.gov Identifier | Brief Description
NCT01578044 | Scheduled to be completed in January 2013 and funded by the Department of Veterans Affairs, targets an enrollment of 50 patients. This study includes qualitative interviews with patients (n~30) and pharmacists (n~20) to better understand reasons that patients are not compliant with the drug. This study also proposes to develop interventions for patient adherence to dabigatran based on the qualitative data obtained.
NCT0159082 | Seeks to determine the proper dabigatran drug dosing in hemodialysis patients with atrial fibrillation through evaluating pharmacokinetics in 10 patients. This study opens for enrollment July 2012 with an estimated completion date of December 2012, and is funded by the Canadian Capital District Health Authority. All participants will receive a single dose of dabigatran etexilate 100 mg at the start of their 4-hour dialysis session. Blood sampling will be conducted during and up to 48 hours after hemodialysis.
NCT01507051 | Funded by Bayer Pharmaceuticals, had a target enrollment of 96 patients and was completed in November 2009. The study objective was to investigate the pharmacodynamics when switching from warfarin to rivaroxaban in a randomized, parallel-group (Treatments A, B, and C), placebo-controlled (Treatment B), and single-blind (Treatments A and B) design. The first two groups (A, B) received warfarin for approximately 1 week to maintain an INR of 2.0–3.0. The first group (A) then received rivaroxaban for 4 days, the second group (B) received placebo. On the last day, all subjects in groups A and B received vitamin K to neutralize the effects of warfarin. The third group (C) did not undergo prior treatment with warfarin but received rivaroxaban for 4 days. Although completed in 2009, we did not identify publications based on the findings of this study.
NCT01400646 | Sponsored by Janssen Research & Development, LLC was completed in May 2012 with an enrollment of 46 subjects. This was a single-center, open-label, sequential, two-treatment period study in healthy adult volunteers to explore the pharmacodynamic changes specifically in regard to blood coagulation in healthy volunteers taking oral rivaroxaban followed by warfarin. Subjects transitioned from rivaroxaban 20 mg once daily to warfarin dosed to a therapeutic level as measured by the INR range of 2.0–3.0. Subjects were given rivaroxaban 20 mg/day for 5 days followed by rivaroxaban 20 mg/day + warfarin 10 mg/day for ≥2 to ≤4 days of concomitant therapy, then warfarin 0–15 mg/day for 4 days (Treatment Period 1). A 14-day washout period separated Treatment Periods 1 and 2. Treatment Period 2 consisted of warfarin 10 mg/day for ≥2 to ≤4days, then warfarin 0–15 mg/day for 4 days.

Abbreviations: INR=international normalized ratio; KQ=Key Question

## Key Question 6 Stroke Prevention After a Hemorrhagic Event

KQ 6. What are the comparative safety and effectiveness of available strategies for resuming anticoagulation therapy or performing a procedural intervention as a stroke prevention strategy following a hemorrhagic event (stroke, major bleed, or minor bleed) in patients with nonvalvular AF?

### Key Points

- There is currently no safety or effectiveness evidence to answer this question based on the absence of any peer-reviewed published studies in this area (insufficient strength of evidence for all outcomes of interest).

### Description of Included Studies

There is no evidence to describe that answers this question.

### Detailed Synthesis

Although we did not identify any relevant studies within the published literature, future substudy analyses likely to be reported from three major RCTs (RE-LY,27 ROCKET-AF,28,197 and ARISTOLE150) may provide data regarding optimal anticoagulation management strategies for patients with AF who have had prior bleeding events.