# Methods

The methods for this Comparative Effectiveness Review (CER) follow those suggested in the Agency for Healthcare Research and Quality (AHRQ) “Methods Guide for Effectiveness and Comparative Effectiveness Reviews” (hereafter referred to as the Methods Guide)35 and “Methods Guide for Medical Test Reviews” (hereafter referred to as the Medical Test Guide).36 The main sections in this chapter reflect the elements of the protocol established for the CER; certain methods map to the Preferred Reporting Items for Systematic Reviews and Meta-Analyses (PRISMA) checklist.37

## Topic Refinement and Review Protocol

During the topic refinement stage, we solicited input from Key Informants representing medical professional societies/clinicians in the areas of general internal medicine, cardiology, cardiothoracic surgery, neurology, electrophysiology, and primary care; patients, scientific experts; and payers, to help define the Key Questions (KQs). The KQs were then posted for public comment for 4 weeks from September 19 to October 17, 2011, and the comments received were considered in the development of the research protocol. We next convened a Technical Expert Panel (TEP) comprising clinical, content, and methodological experts to provide input to the draft protocol in defining populations, interventions, comparisons, and outcomes, and in identifying particular studies or databases to search. The final review protocol was posted for public access on the AHRQ Effective Health Care Web site.38 Before involvement in the CER process, the Key Informants and members of the TEP were required to disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts. Any potential conflicts of interest were balanced or mitigated. Key Informants and members of the TEP did not perform analysis of any kind, and did not contribute to the writing of this report.

## Literature Search Strategy

### Search Strategy

To identify relevant published literature, we searched PubMed^®^, Embase^®^, and the Cochrane Database of Systematic Reviews (CDSR), limiting the search to studies published from January 1, 2000, to August 14, 2012. We applied a date limitation of 2000 forward because we believe that the evidence published from 2000 on represents the current standard of care for patients with AF and relevant comorbidities. We acknowledge that this criterion eliminates several valuable older studies published prior to 2000 that offer data comparing warfarin and aspirin, and thus provide additional context for these older studies in an introductory section of KQ 3. Where possible in our search strategies, we used existing validated search filters (such as the Clinical Queries Filters in PubMed). An experienced search librarian guided all searches. Exact search strings are included in Appendix A. We supplemented the electronic searches with a manual search of citations from a set of key primary and systematic review articles.19,33,39–94 We also considered studies identified through suggestions from external peer and public reviewers. Final updating of all database searches was performed during the review period. All citations were imported into an electronic database (EndNote^®^ X4; Thomson Reuters, Philadelphia, PA).

We used several approaches to identify relevant gray literature; these included requests to drug and device manufacturers for scientific information packets and searches of trial registries and conference abstracts for relevant articles from completed studies. Gray literature databases searched included ClinicalTrials.gov (final search date August 22, 2012); the World Health Organization International Clinical Trials Registry Platform search portal (final search date August 17, 2012); and ProQuest COS Conference Papers Index (final search date August 14, 2012). Search terms used for these sources are provided in Appendix A.

### Inclusion and Exclusion Criteria

The PICOTS (Populations, Interventions, Comparators, Outcomes, Timings, and Settings of interest) criteria used to screen articles for inclusion/exclusion at both the title-and-abstract and full-text screening stages are detailed in Table 1.

Table 1 Inclusion and exclusion criteria

PICOTS Element | Inclusion Criteria | Exclusion Criteria
Populations | - Humans; - Adults (age ≥18 years of age); - Patients with nonvalvular AF (including atrial flutter):; ○ Paroxysmal AF (recurrent episodes that self-terminate in less than 7 days); ○ Persistent AF (recurrent episodes that last more than 7 days); ○ Permanent AF (an ongoing, long-term episode); ○ Patients with AF who experience acute coronary syndrome; - Subgroups of potential interest include:; ○ Patients who have comorbid conditions such as, dementia, or renal or hepatic failure; ○ Patients with multiple coexisting conditions (e.g., combinations of hypertension, diabetes, congestive heart failure, coronary artery disease, and high cholesterol); ○ Patients with prior stroke (by type of event); ○ Patients with prior bleed (by type of bleed); ○ Patients in the therapeutic range (versus those not in range); ○ Type of AF (paroxysmal, persistent, and permanent); ○ Patients stratified by age; ○ Pregnant patients; ○ Patients stratified by race/ethnicity; ○ Patients who are noncompliant with treatment. | - Patients who have known reversible causes of AF (including but not limited to postoperative, hyperthyroidism); - All subjects are <18 years of age, or some subjects are under <18 years of age but results are not broken down by age
Interventions | - Clinical and imaging tools for assessment/evaluation of thromboembolic risk:; ○ Clinical:; ■ CHADS_2_ score; ■ CHA_2_DS_2_-VASc score; ■ Framingham risk score; ○ Imaging:; ■ Transthoracic echo (TTE); ■ Transesophageal echo (TEE); ■ CT scans; ■ Cardiac MRIs; - Clinical tools and individual risk factors for assessment/evaluation of intracranial hemorrhage bleeding risk:; ○ Patient age; ○ Prior stroke; ○ Type of AF (paroxysmal, persistent, permanent); ○ International normalized ratio (INR); ○ Dementia/cognitive impairment; ○ Falls risk; ○ HAS-BLED score; ○ CHADS2 score; ○ CHA_2_S_2_-VASc score; ○ Framingham risk score; ○ HEMORR_2_HAGES score; ○ ATRIA score; ○ Bleeding Risk Index (BRI); - Anticoagulation therapy (all oral anticoagulants):; ○ Warfarin (Coumadin^®^); ○ Vitamin K antagonists (VKAs); ○ Dabigatran (Pradaxa^®^); ○ Rivaroxaban (Xarelto^®^); ○ Apixaban (Eliquis^®^); ○ Edoxaban (DU-176b); - Procedural interventions:; ○ Surgical procedures (surgical resection/removal of left atrial appendage [LAA]); ○ Minimally invasive procedures (Atriclip device); ○ Transcatheter procedures (WATCHMAN device, AMPLATZER cardiac plug, PLAATO device); - Antiplatelet therapy:; ○ Clopidogrel (Plavix^®^); ○ Aspirin (ASA); ○ ASA + dipyridamole (Aggrenox^®^); ○ Dipyridamole (Persantine^®^); ○ Combinations of antiplatelets; - Anticoagulation bridging therapies:; ○ FDA-approved low molecular weight heparins (e.g., bemiparin, certoparin, dalteparin, enoxaparin, nadroparin, parnaparin, reviparin, tinzaparin); ○ IV heparin; ○ Dabigatran (off-label usage) | None
Comparators | - KQ 1: Other clinical or imaging tools listed for assessing thromboembolic risk; - KQ 2: Other clinical tools listed for assessing bleeding risk; - KQ 3: Other anticoagulation therapies, antiplatelet therapies, or procedural interventions for preventing thromboembolic events; - KQ 4: Other anticoagulation therapies; - KQ 5: Other anticoagulation bridging strategies; - KQ 6: Other strategies for resuming anticoagulation therapy following a hemorrhagic event | For KQs 3 and 4, studies that did not include an active comparator
Outcomes | Study assesses a patient-centered outcome of interest:; - Assessment of thromboembolic outcomes:; ○ Cerebrovascular infarction; ○ Transient ischemic attack (TIA); ○ Systemic embolism (note: excludes pulmonary embolism and deep vein thrombosis); - Prevention of bleeding outcomes:; ○ Hemorrhagic stroke; ○ Intracranial hemorrhage (intracerebral hemorrhage, subdural hematoma); ○ Major bleed (stratified by type and location); ○ Minor bleed (stratified by type and location); - Occurrence of other clinical outcomes:; ○ Mortality; ○ Myocardial infarction; ○ Infection; ○ Heart block; ○ Esophageal fistula; ○ Tamponade; ○ Dyspepsia (upset stomach); ○ Health-related quality of life and functional capacity; ○ Health services utilization (hospital admissions, office visits, prescription drug use); ○ Long-term adherence to therapy; - Assessment of clinical and imaging tool efficacy for predicting thromboembolic risk and bleeding events:; ○ Diagnostic accuracy efficacy; ○ Diagnostic thinking efficacy; ○ Therapeutic efficacy; ○ Patient outcome efficacy | Study does not include any outcomes of interest
Timing | - Timing of followup not limited | None
Settings | - Inpatient and outpatient | None
Study design | - Original data; - All sample sizes; - RCTs, prospective and retrospective observational studies, or registries | - Not a clinical study (e.g., editorial, nonsystematic review, letter to the editor, case series)
Publications | - English-language publications only; - Relevant systematic reviews, meta-analyses, or methods articles (used for background only)^a^; - Published on or after January 1, 2000 | - Non-English-language publications b

a Systematic reviews and meta-analyses were excluded from direct abstraction; those representing key sources were hand-searched as potential sources of additional citations to consider in the review. Articles providing methods information only (i.e., not reporting data) were not considered among the formal set of included articles, but were used to supplement the abstractions of the studies they referenced.

b Given the high volume of literature available in English-language publications (including the majority of known important studies), and concerns about the applicability of non-English publication studies to settings in the United States, non-English articles were excluded.

Abbreviations: AF=atrial fibrillation; ASA=aspirin; ATRIA=Anticoagulation and Risk Factors in Atrial Fibrillation; BRI=Bleeding Risk Index; CHADS_2_=Congestive heart failure, Hypertension, Age ≥75, Diabetes mellitus, prior Stroke/transient ischemic attack (2 points); CHA_2_DS_2_-VASc=Congestive heart failure/left ventricular ejection fraction ≤ 40%, Hypertension, Age ≥ 75 (2 points), Diabetes mellitus, prior Stroke/transient ischemic attack/thromboembolism (2 points), Vascular disease, Age 65–74, Sex category female; CT=computed tomography; FDA=U.S. Food and Drug Administration; HAS-BLED=Hypertension, Abnormal renal/liver function, Stroke, Bleeding history or predisposition, Labile international normalized ratio, Elderly (> 65 years), Drugs/alcohol concomitantly; HEMORR_2_HAGES=Hepatic or renal disease, Ethanol abuse, Malignancy, Older (age >75 years), Reduced platelet count or function, Re-bleeding risk (2 points), Hypertension (uncontrolled), Anemia, Genetic factors, Excessive fall risk, Stroke; INR=international normalized ratio; IV=intravenous; KQ=Key Question; LAA=left atrial appendage; MRI=magnetic resonance imaging; PICOTS=Populations, Interventions, Comparators, Outcomes, Timings, and Settings of interest; RCTs=randomized controlled trials; TIA=transient ischemic attack; TEE=transesophageal echocardiography; TTE=transthoracic echocardiography; VKAs=vitamin K antagonists

### Study Selection

Using the prespecified inclusion and exclusion criteria described in Table 1, two investigators independently reviewed titles and abstracts for potential relevance to the KQs. Articles included by either reviewer underwent full-text screening. At the full-text review stage, paired researchers independently reviewed the articles and indicated a decision to “include” or “exclude” the article for data abstraction. When the two reviewers arrived at different decisions about whether to include or exclude an article, they reconciled the difference through review and discussion, or through a third-party arbitrator if needed.

Relevant systematic review articles, meta-analyses, and methods articles were flagged for manual searching of references and cross-referencing against the library of citations identified through electronic database searching.

For citations retrieved by searching the gray literature, the above-described procedures were modified such that a single screener initially reviewed all search results; final eligibility of citations for data abstraction was determined by duplicate screening review. All screening decisions were made and tracked in a Distiller SR database (Evidence Partners Inc, Manotick, ON, Canada).

### Data Extraction

The research team created data abstraction forms and evidence table templates for abstracting data for each KQ. Based on clinical and methodological expertise, a pair of investigators was assigned to abstract data from each eligible article. One investigator abstracted the data, and the second reviewed the completed abstraction form alongside the original article to check for accuracy and completeness. Disagreements were resolved by consensus, or by obtaining a third reviewer’s opinion if consensus could not be reached. To aid in both reproducibility and standardization of data collection, researchers received data abstraction instructions directly on each form created specifically for this project within the DistillerSR database.

We designed the data abstraction forms to collect the data required to evaluate the specified eligibility criteria for inclusion in this review, as well as demographic and other data needed for determining outcomes (intermediate, final, and adverse events outcomes). We paid particular attention to describing the details of the treatment (e.g., pharmacotherapy dosing, methods of procedural therapies), patient characteristics (e.g., etiology of AF, history of prior bleed or stroke), and study design (e.g., randomized controlled trial [RCT] versus observational) that may be related to outcomes. In addition, we described comparators carefully, as treatment standards may have changed during the period covered by this review. Data necessary for assessing quality and applicability, as described in the Methods Guide,35 were abstracted. Before the data abstraction form templates were used, they were pilot-tested with a sample of included articles to ensure that all relevant data elements were captured and that there was consistency/reproducibility between abstractors. Forms were revised as necessary before full abstraction of all included articles. Some outcomes were reported only in figures. In these instances, we used the web-based software, EnGauge Digitizer (http://digitizer.sourceforge.net/) to convert graphical displays to numerical data. Appendix B provides a detailed listing of the elements included in the data abstraction forms.

## Quality (Risk of Bias) Assessment of Individual Studies

We evaluated the quality of individual studies using the approach described in the Methods Guide.35 To assess quality, we used the following strategy: (1) classify the study design, (2) apply predefined criteria for quality and critical appraisal, and (3) arrive at a summary judgment of the study’s quality. We applied criteria for each study type derived from core elements described in the Methods Guide. Criteria of interest for all studies included similarity of groups at baseline, extent to which outcomes were described, blinding of subjects and providers, blinded assessment of the outcome(s), intention-to-treat analysis, differential loss to followup between the compared groups or overall high loss to followup, and conflicts of interest. Criteria specific to RCTs included methods of randomization and allocation concealment. For observational studies, additional elements such as methods for selection of participants, measurement of interventions/exposures, addressing any design-specific issues, and controlling confounding were considered. To indicate the summary judgment of the quality of individual studies, we used the summary ratings of good, fair, or poor based on the classification scheme presented in Table 2.

Table 2 Definitions of overall quality ratings

Quality Rating | Description
Good | A study with the least bias; results are considered valid. A good study has a clear description of the population, setting, interventions, and comparison groups; uses a valid approach to allocate patients to alternative treatments; has a low dropout rate; and uses appropriate means to prevent bias, measure outcomes, and analyze and report results.
Fair | A study that is susceptible to some bias but probably not enough to invalidate the results. The study may be missing information, making it difficult to assess limitations and potential problems. As the fair-quality category is broad, studies with this rating vary in their strengths and weaknesses. The results of some fair-quality studies are possibly valid, while others are probably valid.
Poor | A study with significant bias that may invalidate the results. These studies have serious errors in design, analysis, or reporting; have large amounts of missing information; or have discrepancies in reporting. The results of a poor-quality study are at least as likely to reflect flaws in the study design as to indicate true differences between the compared interventions.

For studies of diagnostic tests (KQs 1 and 2), we used the QUality Assessment tool for Diagnostic Accuracy Studies (QUADAS)-2^95^ to assess quality. QUADAS-2 describes risk of bias in four key domains: patient selection, index test(s), reference standard, and flow and timing. The questions in each domain are rated in terms of risk of bias and concerns regarding applicability, with associated signaling questions to help with these bias and applicability judgments.

Studies of different designs were graded within the context of their respective designs. Thus, RCTs were graded as good, fair, or poor, and observational studies were separately graded as good, fair, or poor.

## Data Synthesis

We determined the feasibility of completing a quantitative synthesis (i.e., meta-analysis based on the volume of relevant literature, conceptual homogeneity of the studies in terms of study population and outcomes, and completeness of the reporting of results. We grouped interventions by prediction tool (KQs 1–2) and drug class or procedure (KQs 3–6), when appropriate.

When at least three comparable studies reported the same outcome, we used the random-effects model analysis option in Comprehensive Meta-Analysis software (Version 2.2057; Biostat, Englewood, NJ) and the DerSimonian and Laird method.96 to synthesize the available evidence quantitatively. We explored heterogeneity using graphical displays and test statistics (Q and I^2^ statistics), while recognizing that the ability of statistical methods to detect heterogeneity may be limited. When we were able to calculate hazard ratios (HRs), we assumed that a HR between 0.8 and 1.2 with a narrow confidence interval that also crossed 1.0 suggested no clinically significant difference between treatment strategies; in such cases, we describe the treatment strategies being compared as having “comparable efficacy.” For some outcomes, study quality or other factors affected comparability; these exceptions are explained on a case-by-case basis.

For KQ 1 and KQ 2, we synthesized available c-statistics which quantify the discrimination ability of the studied tools. Since these tools are not binary, summary receiver operating characteristic (ROC) curves were not considered as would have been possible for binary diagnostic tests. The c-statistics were pooled by considering their estimated values (point estimates) and confidence intervals, and the “Generic point estimates” effect specification option in the Comprehensive Meta-Analysis software. For a clinical prediction rule, we assumed that a c-statistic <0.6 had no clinical value, 0.6–0.7 had limited value, 0.7–0.8 had modest value, and >0.8 has discrimination adequate for genuine clinical utility.97 Of note, a risk score may have a statistically significant association with a clinical outcome, but the relationship may not be discriminated enough to allow clinicians to accurately and reproducibly separate patients who will and will not have the outcome. In addition, the c-statistic value is almost always higher when assessing discrimination accuracy in the patient data set used to develop the model than in independent sets of patients; we therefore indicate when studies being discussed were actually used to develop the models they describe.

We hypothesized that the methodological quality of individual studies, study type, the characteristics of the comparator, and patients’ underlying clinical presentation would be associated with the intervention effects, causing heterogeneity in the outcomes. Where there were sufficient studies, we performed subgroup analyses and/or meta-regression analyses to examine these hypotheses.

## Strength of the Body of Evidence

We rated the strength of evidence for each KQ and outcome using the approach described in the Methods Guide.35,98 and Medical Test Guide.36 We assessed four domains: risk of bias, consistency, directness, and precision (Table 3).

Table 3 Strength of evidence—required domains

Domain | Rating | How Assessed
Risk of bias | Low Medium High | Assessed primarily through study design (RCT versus observational study) and aggregate study quality
Consistency | Consistent Inconsistent Unknown/not applicable | Assessed primarily through whether included studies appear to have the same direction of effect or the same magnitude of effect
Directness | Direct Indirect | Assessed by whether the evidence links interventions directly to health outcomes of specific importance for the review, and for comparative effectiveness studies, whether the comparisons have been done in head-to-head studies
Precision | Precise Imprecise | Based primarily on the size of the confidence intervals of effect estimates and highlighting the degree of certainty surrounding an effect estimate with respect to a given outcome, based on the sufficiency of sample size and number of events

Abbreviation: RCT=randomized controlled trial

We also assessed publication bias. These domains were considered qualitatively, and a summary rating of “high,” “moderate,” or “low” strength of evidence was assigned after discussion by two reviewers. In some cases, high, moderate, or low ratings were impossible or imprudent to make—for example, when no evidence was available or when evidence on the outcome was too weak, sparse, or inconsistent to permit any conclusion to be drawn. In these situations, a grade of “insufficient” was assigned. Outcomes based on evidence from RCTs or observational studies started with a “high” or “low” strength of evidence rating, respectively, and were downgraded for inconsistency, indirectness, or imprecision. Studies of risk prediction outcomes started with moderate strength of evidence.99 We assumed that outcomes based on only 1 study should not be downgraded for lack of consistency if the study included more than 1,000 patients. Intention-to-treat findings were evaluated when available and form the basis of our strength of evidence ratings. When only on-treatment findings were available, our confidence in the stability of our findings was reduced, and therefore the related strength-of-evidence rating was lowered. Finally, when outcomes were assessed by large RCTs and smaller studies, we focused our strength of evidence rating on the findings from the large RCTs and then increased or decreased the strength of evidence rating depending on whether findings from the smaller studies were consistent or inconsistent with those from the large RCTs.

This four-level rating scale consists of the following definitions:

- High—High confidence that the evidence reflects the true effect. Further research is very unlikely to change our confidence in the estimate of effect.
- Moderate—Moderate confidence that the evidence reflects the true effect. Further research may change our confidence in the estimate of effect and may change the estimate.
- Low—Low confidence that the evidence reflects the true effect. Further research is likely to change the confidence in the estimate of effect and is likely to change the estimate.
- Insufficient—Evidence either is unavailable or does not permit estimation of an effect.

## Applicability

We assessed applicability across the KQs using the method described in the Methods Guide.35,100 In brief, we used the PICOTS format to organize information relevant to applicability. The most important applicability concern is whether the outcomes observed for any individual study, with its specific patient population and methods of implementing interventions, can be confidently extrapolated to a broader context. Differences in intervention methods or study population characteristics (e.g., age, comorbidities) can affect the rates of events observed in both control and intervention groups, and may limit the generalizability of the findings. Specific criteria considered in applicability assessments are listed in Appendix B. We used these data to evaluate applicability to clinical practice, paying special attention to study eligibility criteria, demographic features of the enrolled population in comparison to the target population, characteristics of the intervention used in comparison with care models currently in use, and clinical relevance and timing of the outcome measures. We summarized issues of applicability qualitatively.

## Peer Review and Public Commentary

The peer review process is our principal external quality-monitoring device. Nominations for peer reviewers were solicited from several sources, including the TEP and interested Federal agencies. Experts in general cardiology, heart failure, electrophysiology, neurology, internal medicine, stroke prophylaxis, pharmacological treatments for AF, geriatrics, primary care, health services research, epidemiology, and biostatistics, along with individuals representing stakeholder and user communities, were invited to provide external peer review of the draft report. AHRQ, an associate editor, and members of the TEP also provided comments. In addition, the draft report was posted on the AHRQ Web site for public comment for 4 weeks, from August 31 to September 28, 2012. We have addressed all reviewer comments, revising the text as appropriate, and have documented our responses in a disposition of comments report that will be made available 3 months after the Agency posts the final report on the AHRQ Web site. A list of peer reviewers who submitted comments on the draft report is provided in the front matter of this document.