# Peer Reviewers

Prior to publication of the final report, the EPC sought input from independent Peer Reviewers without financial conflicts of interest. However, the conclusions and synthesis of the scientific literature presented in this report do not necessarily represent the views of individual peer reviewers.

Peer Reviewers must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential nonfinancial conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential nonfinancial conflicts of interest identified.

The list of Peer Reviewers follows:

- Wilbert S. Aronow, M.D.
  Professor of Medicine
  New York Medical College
  Valhalla, NY
- David A. Garcia, M.D.
  Associate Professor, Department of Internal Medicine
  University of New Mexico
  Albuquerque, NM
- Mark H. Eckman, M.D., M.S.
  Professor of Medicine
  Director, Division of General Internal Medicine
  Director, Center for Clinical Effectiveness
  University of Cincinnati
  Cincinnati, OH
- Mark A. Hlatky, M.D.
  Professor of Health Research and Policy
  Professor of Medicine (Cardiovascular Medicine)
  Stanford University School of Medicine
  Stanford, CA
- Elaine M. Hylek, M.D., M.P.H.
  Professor of Medicine
  Boston University
  Boston, MA
- Ralph L. Sacco, M.D., M.S.
  Professor and Olemberg Chair of Neurology
  Executive Director, McKnight Brain Institute
  Chief of Neurology, Jackson Memorial Hospital
  Miller School of Medicine
  University of Miami
  Miami, FL
  Past President
  American Heart Association
  Dallas, TX