# Technical Expert Panel

In designing the study questions and methodology at the outset of this report, the EPC consulted several technical and content experts. Broad expertise and perspectives were sought. Divergent and conflicted opinions are common and perceived as healthy scientific discourse that results in a thoughtful, relevant systematic review. Therefore, in the end, study questions, design, methodologic approaches, and/or conclusions do not necessarily represent the views of individual technical and content experts.

Technical Experts must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential conflicts of interest identified.

The list of Technical Experts who participated in developing this report follows:

- Hussein Rashid Al-Khalidi, Ph.D.
  Associate Professor of Biostatistics and Bioinformatics
  Duke University
  Durham, NC
- G. Hossein Almassi, M.D.
  Professor of Cardiothoracic Surgery
  Medical College of Wisconsin
  Milwaukee, WI
- Javed Butler, M.P.H., M.D.
  Director, Heart Failure Research
  Professor of Medicine
  Emory University
  Atlanta, GA
- Douglas E. Campos-Outcalt, M.D., M.P.A.
  Associate Head, Clinical Professor
  University of Arizona
  Phoenix, AZ
- Roger Chou, M.D.
  Oregon Health & Science University
  Portland, OR
- Walter Koroshetz, M.D.
  Deputy Director
  National Institute of Neurological Disorders and Stroke
  National Institutes of Health
  Bethesda, MD
- Gregory Y.H. Lip, M.D.
  Professor of Cardiovascular Medicine
  University of Birmingham Centre for Cardiovascular Sciences
  City Hospital
  Birmingham, United Kingdom
- Eric N. Prystowsky, M.D.
  Director of the Clinical Electrophysiology Laboratory
  St. Vincent Medical Group
  Indianapolis, IN
- Eric Smith, M.D., M.P.H.
  Associate Professor of Neurology
  Department of Clinical Neurosciences
  Hotchkiss Brain Institute
  University of Calgary
  Calgary, Alberta, Canada
- Paul Varosy, M.D.
  Director of Cardiac Electrophysiology
  VA Eastern Colorado Health Care System
  Denver, CO
  Assistant Professor of Medicine
  University of Colorado
  Aurora, CO