# Key Informants

In designing the study questions, the EPC consulted several Key Informants who represent the end-users of research. The EPC sought the Key Informants’ input on the priority areas for research and synthesis. Key Informants are not involved in the analysis of the evidence or the writing of the report. Therefore, in the end, study questions, design, methodological approaches, and/or conclusions do not necessarily represent the views of individual Key Informants.

Key Informants must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their role as end-users, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any conflicts of interest.

The list of Key Informants who participated in developing this report follows:

- Javed Butler, M.P.H., M.D.
  Director, Heart Failure Research
  Professor of Medicine
  Emory University
  Atlanta, GA
- Douglas E. Campos-Outcalt, M.D., M.P.A.
  Associate Head, Clinical Professor
  University of Arizona
  Phoenix, AZ
- Roger Chou, M.D.
  Oregon Health & Science University
  Portland, OR
- David A. Garcia, M.D.
  Associate Professor, Department of Internal Medicine
  University of New Mexico
  Albuquerque, NM
- Neil C. Jensen, M.H.A., M.B.A.
  Director, Cardiology Networks
  United Healthcare
  Minneapolis-St. Paul, MN
- Eugenie M. Komives, M.D.
  Family Practitioner
  Chapel Hill, NC
- Eric N. Prystowsky, M.D.
  Director of the Clinical Electrophysiology Laboratory
  St. Vincent Medical Group
  Indianapolis, IN
- Mellanie True Hills
  Patient Advocate
  True Hills, Inc.
  Dallas-Ft.Worth, TX