# Acknowledgments

The authors thank Connie Schardt, M.L.S., and Megan von Isenburg, M.S.L.S., for help with the literature search and retrieval, and R. Julian Irvine, M.C.M., and Michael D. Musty, B.A., for assistance with project coordination.