# Discussion

## Key Findings and Strength of Evidence

In this comparative effectiveness review (CER), we reviewed 92 unique studies represented by 122 publications and involving over 1,164,900 patients that evaluated stroke and bleeding prediction tools and stroke prevention strategies in patients with nonvalvular atrial fibrillation (AF). The current evidence base was greatest for the comparative safety and effectiveness of stroke prevention therapies and tools for predicting thromboembolic and bleeding risk; however, the evidence was very limited or nonexistent regarding AF patients undergoing invasive procedures, switching among anticoagulant therapies, and starting or restarting anticoagulant therapy in patients with previous major bleeding events.

### KQ 1 Predicting Thromboembolic Risk

Our review included 37 studies comparing the diagnostic accuracy and impact on clinical decisionmaking of available clinical and imaging tools for predicting thromboembolic risk. The clinical tools assessed for this question included the CHADS_2_ score (Congestive heart failure, Hypertension, Age ≥75, Diabetes mellitus, prior Stroke/transient ischemic attack [2 points]), CHA_2_DS_2_-VASc score (Congestive heart failure/left ventricular ejection fraction ≤ 40%, Hypertension, Age ≥75 [2 points], Diabetes mellitus, prior Stroke/transient ischemic attack/thromboembolism [2 points], Vascular disease, Age 65–74, Sex category female), Framingham risk score, and imaging tools, as well as international normalized ratio (INR) monitoring for patients treated with warfarin. Current guidelines recommend that oral anticoagulation be considered in patients with CHADS_2_ or CHA_2_DS_2_-VASc score ≥2.

The reviewed studies had varying categorical arrangements of risk scores with patients receiving antiplatelet therapy and/or anticoagulant therapy or not, making direct comparisons across studies examining these tools difficult. The CHADS_2_ and CHA_2_DS_2_-VASc continuous scores had the best prediction abilities given available evidence, but this advantage was incremental on an absolute basis. Imaging risk tools found conflicting results when the presence of left atrial thrombus was assessed, and only one advanced imaging study utilizing magnetic resonance angiography (MRA)/magnetic resonance imaging (MRI) was reviewed and therefore was insufficient evidence to support conclusions.

Our conclusions may be limited by the limitations in the development and validation of risk scores. Specifically, although many of the studies use clinical data sources to derive or validate these risk scores, some studies relied on billing data and institutional electronic medical records to identify patients with AF and comorbidity information. Since few of these administrative studies used a formal clinical adjudication process to validate the occurrence of a clinical event and may suffer from insufficient coding, the risk scores could underestimate stroke risk, particularly in patients incorrectly identified as having few or no comorbidities. Likewise, lack of validated results or common event definitions for the endpoints of thromboembolism and bleeding could have underestimated the performance of these risk scores. Additionally, lack of standard definitions for comorbidities such as heart failure, diabetes mellitus, hypertension, etc. could also lead to discrepancies across studies validating the various risk scores. Moreover, our review included both ambulatory and hospitalized patients, which inherently introduces bias in comparing studies and results give the heterogeneity with regards to stability of covariates, concomitant medications, stroke inducing procedures, etc.

Table 34 summarizes the strength of evidence for the thromboembolic risk discrimination abilities of the included tools. This summary table represents only those studies that evaluated the risk discrimination abilities of the tools using a c-statistic. Details about the specific components of these ratings (risk of bias, consistency, directness, and precision) are available in the Results section.

Table 34 Summary of strength of evidence and c-statistic estimates for KQ 1 (discrimination of thromboembolic risk)

Tool | Number of Studies (Subjects) | Strength of Evidence and Effect Estimate^a^
CHADS_2_ (Categorical) | 8 (380,669) | SOE=Insufficient
CHADS_2_ (Continuous) | 8 (379,755) | SOE=Low Modest risk discrimination ability (c-statistic=0.71; 95% CI 0.66 to 0.75)
CHA_2_DS_2_-VASc (Categorical) | 6 (332,009) | SOE=Insufficient
CHA_2_DS_2_-VASc (Continuous) | 5 (371,911) | SOE=Low Modest risk discrimination ability (c-statistic=0.70; 95% CI 0.66 to 0.75)
Framingham (Categorical) | 5 (259,253) | SOE=Moderate Limited risk discrimination ability (c-statistic=0.63; 95% CI 0.62 to 0.65)
Framingham (Continuous) | 4 (262,151) | SOE=Low Limited risk discrimination ability (c-statistic ranges between 0.64 and 0.69 across studies)
Imaging | 0 | SOE=Insufficient
INR | 0 | SOE=Insufficient

a All strength of evidence ratings of “Insufficient” are shaded.

Abbreviations: CHADS_2_=Congestive heart failure, Hypertension, Age ≥75, Diabetes mellitus, prior Stroke/transient ischemic attack (2 points); CHA_2_DS_2_-VASc=Congestive heart failure/left ventricular ejection fraction ≤ 40%, Hypertension, Age ≥75 (2 points), Diabetes mellitus, prior Stroke/transient ischemic attack/thromboembolism (2 points), Vascular disease, Age 65–74, Sex category female; CI=confidence interval; INR=international normalized ratio; SOE=strength of evidence

### KQ 2 Predicting Bleeding Events

Seventeen studies were included in our analyses comparing the diagnostic accuracy and impact on clinical decisionmaking of clinical tools and associated risk factors for predicting bleeding events. Four different bleeding risk scores were evaluated in these studies, all based on clinical parameters, including ATRIA, Bleeding Risk Index, HAS-BLED, and HEMORR_2_HAGES.

Of note, many included studies used administrative data sources to identify patients with AF, as well as comorbidity information. As a result, many of the included studies used different approaches to calculating the risk scores of interest due to unavailable data, particularly for the HEMORR_2_HAGES and HAS-BLED scores. For example, in HEMORR_2_HAGES, due to unavailability of information on genetic factors, multiple database studies left out the “genetic factors” component of the score. To further complicate this issue, not all studies described in detail whether certain factors were omitted from their calculations of these scores. Inter-study differences in approach to calculating some of the bleeding risk scores limited comparison of bleeding risk scores across populations and precluded meta-analysis. Similarly, use of administrative data in some cases prevented validation of clinical bleeding events, and this could have affected studies’ estimates of the performance of these risk scores.

Among the tools for predicting risk of major bleeding and ICH, there was a suggestion that HAS-BLED is the most accurate for predicting major bleeds in patients on warfarin, but the majority of studies for other patient scenarios showed no statistically significant differences in predictive accuracy among tools. Evaluating these bleeding risk prediction scores was complicated by the fact that, though studies consistently reported event rates and c-statistics, measures of calibration, strength of association, and diagnostic accuracy were inconsistently reported.

Table 35 summarizes the strength of evidence for the bleeding risk discrimination abilities of the included tools. This summary table represents only those studies that evaluated the risk discrimination abilities of the tools using a c-statistic. Details about the specific components of these ratings (risk of bias, consistency, directness, and precision) are available in the Results section.

Table 35 Summary of strength of evidence and c-statistic estimates for KQ 2 (discrimination of bleeding risk)

Tool | Number of Studies (Subjects) | Strength of Evidence and Effect Estimate^a^
Summary c-statistic
BRI | 5 (47,684) | SOE=Moderate Limited risk discrimination ability (c-statistic ranging from 0.56 to 0.65)
HEMORR_2_HAGES | 8 (318,246) | SOE=Moderate Limited risk discrimination ability (c-statistic ranging from 0.53 to 0.78)
HAS-BLED | 8 (313,294) | SOE=Moderate Modest risk discrimination ability (c-statistic ranging from 0.58 to 0.80)
ATRIA | 4 (15,732) | SOE=Insufficient
Comparative Risk Discrimination Abilities
Major bleeding events among patients with AF on warfarin | 9 (319,183) | SOE=Low Favors HAS-BLED
Intracranial hemorrhage among patients with AF on warfarin | 1 (48,599) | SOE=Low No difference
Major bleeding events among patients with AF on aspirin alone | 3 (177,538) | SOE=Low No difference
Major bleeding events among patients with AF not on antithrombotic therapy | 6 (310,607) | SOE=Low No difference

a All strength of evidence ratings of “Insufficient” are shaded.

Abbreviations: AF=atrial fibrillation; ATRIA=Anticoagulation and Risk Factors in Atrial Fibrillation; BRI=Bleeding Risk Index; CI=confidence interval; HAS-BLED=Hypertension, Abnormal renal/liver function, Stroke, Bleeding history or predisposition, Labile international normalized ratio, Elderly (> 65 years), Drugs/alcohol concomitantly; HEMORR_2_HAGES=Hepatic or renal disease, Ethanol abuse, Malignancy, Older (age >75 years), Reduced platelet count or function, Re-bleeding risk (2 points), Hypertension (uncontrolled), Anemia, Genetic factors, Excessive fall risk, Stroke; KQ=Key Question; SOE=strength of evidence

### KQ 3 Interventions for Preventing Thromboembolic Events

Our review included 43 studies comparing the safety and effectiveness of specific anticoagulation therapies, antiplatelet therapies, and procedural interventions for preventing thromboembolic events. Among these studies, several new agents were evaluated including Factor IIa inhibitors (dabigatran) and novel Xa inhibitors (apixaban, edoxaban, rivaroxaban, idraparinux). Dabigatran, apixaban, and rivaroxaban have been approved by the FDA; edoxaban and idraparinux are currently investigational. Of the dabigatran doses discussed in this report, the 150 mg dose is FDA-approved and marketed in the United States; the 110 mg dose is not. Although the number of studies for any specific comparison of interest was limited, the included RCTs were often very large, of good quality, and considered definitive in the field. These trials were, however, limited to comparing novel therapies with warfarin or aspirin and have not involved head-to-head comparison among the newer agents. Based on these trials though, it has been determined that these newer agents are better than the prior lone treatment of warfarin in terms of stroke prevention, side effects, and risk of bleeding.

In comparative effectiveness analyses, warfarin was found to be superior to aspirin for stroke prevention, and the combination of aspirin and clopidogrel was found to be superior to aspirin alone in patients with warfarin contraindications. Triple therapy with aspirin, clopidogrel, and warfarin did not provide any additional stroke protection beyond warfarin alone, but increased bleeding events significantly. Percutaneous left atrial appendage (LAA) closure is non-inferior to warfarin, while novel antithrombotics (apixaban, rivaroxaban, dabigatran) were non-inferior or superior to warfarin for stroke prevention. LAA occlusion devices are currently investigational, pending FDA approval.

Based on these recent studies, these novel antithrombotics have been incorporated into the stroke prevention guidelines in Europe. In these guidelines, there has been a shift away from both warfarin and aspirin, particularly for those patients with lower risk of stroke, for whom aspirin is becoming less favored. In these European guidelines, for those patients with low to moderate risk (CHA2DS2-VASc=1) of thromboembolic event, these novel anticoagulants are recommended or aspirin; and for those with an even lower risk of thromboembolic event (CHA2DS2-VASc=0), it is recommended that these patients receive no anticoagulants or aspirin, with no anticoagulants recommended over aspirin.17

While novel antithrombotics have shown significant benefit for prevention of thromboembolic complications of atrial fibrillation, they are not without risk. Dabigatran with or without aspirin has been associated with a higher risk of MI than warfarin. Further study is needed to determine if dabigatran itself leads to increased risk, or if warfarin is somehow protective against MI. Dabigatran has also been associated with a higher rate of dyspepsia and other GI symptoms than warfarin.

Table 36 summarizes the strength of evidence for the various comparisons and outcomes of interest. Details about the specific components of these ratings (risk of bias, consistency, directness, and precision) are available in the Results section.

Table 36 Summary of strength of evidence and effect estimates for KQ 3 (interventions for preventing thromboembolic events)

Outcome | Number of Studies (Subjects) | SOE and Magnitude of Effect^a^ (95% CI)
ASA vs. Warfarin
Ischemic stroke | 4 (170,642) | SOE=Moderate 4 retrospective studies showing consistent reduction in stroke with warfarin
Bleeding | 3 (99,876) | SOE=Moderate Warfarin associated with increased rates of bleeding
All-cause mortality | 1 (601) | SOE=Insufficient
Warfarin+ASA vs. Warfarin Alone
Ischemic stroke | 1 (69,264) | SOE=Moderate Increased with warfarin + ASA (HR 1.27; 95% CI 1.14 to 1.40)
Bleeding | 1 (69,264) | SOE=Moderate Increased with warfarin + ASA (HR 1.83; 95% CI 1.72 to 1.96)
Clopidogrel+ASA vs. ASA Alone
Any stroke | 2 (8,147) | SOE=Moderate Lower rates with combined therapy (HR 0.72; 95% CI 0.62 to 0.83)
Ischemic stroke | 2 (8,147) | SOE=Low Lower rates with combined therapy (HR 0.68; 95% CI 0.57 to 0.80)
Hemorrhagic stroke | 2 (8,147) | SOE=Moderate Similar between therapies in both studies
Systemic embolism | 1 (7,554) | SOE=Moderate Similar between therapies (HR 0.96; 95% CI 0.66 to 1.40)
Major bleeding | 1 (7,554) | SOE=High Clopidogrel+ASA associated with higher rates (HR 1.57; 95% CI 1.29 to 1.92)
Minor bleeding | 1 (7,554) | SOE=High Clopidogrel+ASA associated with higher rates (HR 2.42; 95% CI 2.03 to 2.89)
Intracranial bleeding | 2 (8,147) | SOE=Low Higher rates with clopidogrel+ASA (HR 1.87; 95% CI 1.19 to 2.94)
Extracranial bleeding | 2 (8,147) | SOE=High Higher rates with clopidogrel+ASA (HR 1.51; 95% CI 1.21 to 1.88)
All-cause mortality | 2 (8,147) | SOE=Moderate No difference (HR 0.98 [95% CI 0.89 to 1.08] in one study; HR 1.12 [95% CI 0.65 to 1.90] in other study)
Death from vascular causes | 2 (8,147) | SOE=Low No difference based on large RCT (HR 1.00; 95% CI 0.89 to 1.12), although a smaller study showed a trend toward a benefit of ASA alone (HR 1.68; 95% CI 0.83 to 3.42)
Myocardial infarction | 2 (8,147) | SOE=Low No difference based on large RCT (HR 0.78; 95% CI 0.59 to 1.03), although a smaller study showed a trend toward a benefit of ASA alone (HR 1.43; 95% CI 0.51 to 4.01)
Hospitalization | 1 (593) | SOE=Insufficient
Clopidogrel vs. Warfarin
Ischemic stroke | 1 (54,636) | SOE=Moderate Increased risk with clopidogrel (HR 1.86; 95% CI 1.52 to 2.27)
Bleeding | 1 (54,636) | SOE=Moderate Similar between therapies (HR 1.06; 95% CI 0.87 to 1.29)
Clopidogrel+ASA vs. Warfarin
Stroke or systemic embolism | 2 (60,484) | SOE=High Increased risk with clopidogrel+ASA in both studies (HR 1.56 [95% CI 1.17 to 2.10] in one study; HR 1.72 [95% CI 1.24 to 2.37] in other study)
Hemorrhagic stroke | 1 (6,706) | SOE=Moderate Increased risk with warfarin (HR 0.34 [95% CI 0.12 to 0.93])
Major bleeding | 2 (60,484) | SOE=Low Similar rates between therapies (HR 1.10; 95% CI 0.83 to 1.45),
Minor bleeding | 1 (6,706) | SOE=High Increased risk with clopidogrel+ASA (HR 1.23; 95% CI 1.09 to 1.39)
Intracranial bleeding | 1 (6,706) | SOE=Insufficient
All-cause mortality | 1 (6,706) | SOE=High No difference (HR 1.01; 95% CI 0.81 to 1.26)
Death from vascular causes | 1 (6,706) | SOE=Moderate No difference (HR 1.14; 95% CI 0.88 to 1.48)
Myocardial infarction | 1 (6,706) | SOE=Moderate No difference (myocardial infarction occurred at rates of <1% per year with both therapies)
Warfarin+Clopidogrel vs. Warfarin Alone
Ischemic stroke | 1 (52,349) | SOE=Low Trend toward benefit of warfarin+clopidogrel (HR 0.70; 95% CI 0.35 to 1.40)
Bleeding | 1 (52,349) | SOE=Moderate Higher for patients on warfarin+clopidogrel (HR 3.08; 95% CI 2.32 to 3.91)
Warfarin Alone vs. Warfarin+ASA+Clopidogrel
Ischemic stroke | 1 (52,180) | SOE=Low Trend toward being higher for patients on triple therapy (HR 1.45; 95% CI 0.84 to 2.52)
Bleeding | 1 (52,180) | SOE=Moderate Higher for patients on triple therapy (HR 3.70; 95% CI 2.89 to 4.76)
Factor IIa Inhibitor (Dabigatran 150 mg) vs. Warfarin
Stroke or systemic embolism | 1 (12,098) | SOE=High Dabigatran reduced risk (RR 0.66; 95% CI 0.53 to 0.82)
Ischemic or uncertain stroke | 1 (12,098) | SOE=Moderate Dabigatran reduced risk (RR 0.76; 95% CI 0.60 to 0.98)
Hemorrhagic stroke | 1 (12,098) | SOE=High Dabigatran reduced risk (RR 0.26; 95% CI 0.14 to 0.49)
Major bleeding | 1 (12,098) | SOE=High No difference (RR 0.93; 95% CI 0.81 to 1.07)
Minor bleeding | 1 (12,098) | SOE=Moderate Dabigatran reduced risk (RR 0.91; 95% CI 0.85 to 0.97)
Intracranial bleeding | 1 (12,098) | SOE=High Dabigatran reduced risk (RR 0.40; 95% CI 0.27 to 0.60)
All-cause mortality | 1 (12,098) | SOE=Moderate No difference (RR 0.88; 95% CI 0.77 to 1.00)
Death from vascular causes | 1 (12,098) | SOE=Moderate Dabigatran reduced risk (RR 0.85; 95% CI 0.72 to 0.99)
Myocardial infarction | 1 (12,098) | SOE=Moderate Dabigatran increased risk (RR 1.38; 95% CI 1.00 to 1.91)
Hospitalization | 1 (12,098) | SOE=High No difference (RR 0.97; 95% CI 0.92 to 1.03)
Adverse events | 1 (12,098) | SOE=Moderate Dyspepsia more common with dabigatran (11.3% of patients with dabigatran 150 mg vs. 5.8% with warfarin, p<0.001). No differences in liver function or other adverse events between therapies.
Factor IIa Inhibitor (Dabigatran 110 mg) vs. Warfarin
Stroke or systemic embolism | 1 (12,037) | SOE=High No difference (RR 0.91; 95% CI 0.74 to 1.11)
Ischemic or uncertain stroke | 1 (12,037) | SOE=Moderate No difference (RR 1.11; 95% CI 0.89 to 1.40)
Hemorrhagic stroke | 1 (12,037) | SOE=High Dabigatran reduced risk (RR 0.31; 95% CI 0.17 to 0.56)
Major bleeding | 1 (12,037) | SOE=High Dabigatran reduced risk (RR 0.80; 95% CI 0.69 to 0.93)
Minor bleeding | 1 (12,037) | SOE=High Dabigatran reduced risk (RR 0.79; 95% CI 0.74 to 0.84)
Intracranial bleeding | 1 (12,037) | SOE=High Dabigatran reduced risk (RR 0.31; 95% CI 0.20 to 0.47)
All-cause mortality | 1 (12,037) | SOE=Moderate No difference (RR 0.91; 95% CI 0.80 to 1.03)
Death from vascular causes | 1 (12,037) | SOE=Moderate No difference (RR 0.90; 95% CI 0.77 to 1.06)
Myocardial infarction | 1 (12,037) | SOE=Low Dabigatran increased risk, although the difference did not reach statistical significance (RR 1.35; 95% CI 0.98 to 1.87)
Hospitalization | 1 (12,037) | SOE=High Dabigatran reduced risk (RR 0.92; 95% CI 0.87 to 0.97)
Adverse events | 1 (12,037) | SOE=Moderate Dyspepsia more common with dabigatran (11.8% of patients with dabigatran 110 mg vs. 5.8% with warfarin, p<0.001). No differences in liver function or other adverse events between therapies.
Xa Inhibitor (Apixaban) vs. Warfarin
Stroke or systemic embolism | 2 (18,423) | SOE=High Apixaban reduced risk (HR 0.79; 95% CI 0.66 to 0.95)
Ischemic stroke | 1 (18,201) | SOE=High No difference (HR 0.92; 95% CI 0.74 to 1.13)
Hemorrhagic stroke | 1 (18,201) | SOE=High Apixaban reduced risk (HR 0.51; 95% CI 0.35 to 0.75)
Systemic embolism | 2 (18,423) | SOE=Moderate No difference (HR 0.87; 95% CI 0.44 to 1.75)
Major bleeding | 2 (18,423) | SOE=High Apixaban reduced risk (HR 0.69; 95% CI 0.60 to 0.80)
Intracranial bleeding | 1 (18,201) | SOE=High Apixaban reduced risk (HR 0.42; 95% CI 0.30 to 0.58)
All-cause mortality | 2 (18,423) | SOE=Moderate Apixaban reduced risk (HR 0.89; 95% CI 0.80 to 0.998)
Death from cardiovascular causes | 1 (18,201) | SOE=High No difference (HR 0.89; 95% CI 0.76 to 1.04)
Myocardial infarction | 1 (18,201) | SOE=Moderate No difference (HR 0.88; 95% CI 0.66 to 1.17)
Adverse events | 2 (18,423) | SOE=Moderate Adverse events occurred in almost equal proportions of patients in the apixaban and the warfarin therapy arms
Xa Inhibitor (Rivaroxaban) vs. Warfarin
Stroke or systemic embolism | 2 (15,544) | SOE=Moderate No difference (HR 0.88; 95% CI 0.74 to 1.03)
Ischemic stroke | 1 (14,264) | SOE=Moderate No difference in on-treatment analyses (HR 0.94; 95% CI 0.75 to 1.17)
Hemorrhagic stroke | 2 (15,544) | SOE=Low In on-treatment analyses, one large RCT demonstrated benefit of rivaroxaban (HR 0.59; 95% CI 0.37 to 0.93); a smaller study showed a trend toward no difference (HR 0.73; 95% CI 0.16 to 3.25)
Systemic embolism | 1 (14,264) | SOE=Moderate Rivaroxaban reduced risk in on-treatment analyses (HR 0.23; 95% CI 0.09 to 0.61)
Major bleeding | 2 (15,544) | SOE=Moderate No difference in 2 studies in on-treatment analyses (HR 1.04 [95% CI 0.90 to 1.20] in one study; HR 0.85 [95% CI 0.50 to 1.43] in other study)
Intracranial bleeding | 2 (15,544) | SOE=Moderate Rivaroxaban reduced risk in on-treatment analyses (HR 0.67; 95% CI 0.47 to 0.93)
All-cause mortality | 1 (14,264) | SOE=High No difference (HR 0.92; 95% CI 0.82 to 1.03)
Death from cardiovascular causes | 1 (14,264) | SOE=Moderate No difference in on-treatment analyses (HR 0.89; 95% CI 0.73 to 1.10)
Myocardial infarction | 1 (14,264) | SOE=Moderate No difference in on-treatment analyses (HR 0.81; 95% CI 0.63 to 1.06)
Xa Inhibitor (Apixaban) vs. ASA
Stroke or systemic embolism | 1 (5,599) | SOE=High Apixaban reduced risk (HR 0.45; 95% CI 0.32 to 0.62)
Ischemic stroke | 1 (5,599) | SOE=High Apixaban reduced risk (HR 0.37; 95% CI 0.25 to 0.55)
Hemorrhagic stroke | 1 (5,599) | SOE=Moderate Trend toward a reduction in risk with apixaban (HR 0.67; 95% CI 0.24 to 1.88)
Major bleeding | 1 (5,599) | SOE=High No difference (HR 1.13; 95% CI 0.74 to 1.75)
Minor bleeding | 1 (5,599) | SOE=Moderate Apixaban increased risk (HR 1.20; 95% CI 1.00 to 1.53)
Intracranial bleeding | 1 (5,599) | SOE=Low Trend toward a reduction in risk with apixaban (HR 0.85; 95% CI 0.38 to 1.90)
All-cause mortality | 1 (5,599) | SOE=Low Trend toward a reduction in risk with apixaban (HR 0.79; 95% CI 0.62 to 1.02)
Death from vascular causes | 1 (5,599) | SOE=Moderate No difference (HR 0.87; 95% CI 0.66 to 1.17)
Myocardial infarction | 1 (5,599) | SOE=Moderate No difference (HR 0.86; 95% CI 0.50 to 1.48)
Hospitalization | 1 (5,599) | SOE=High Apixaban reduced risk (HR 0.79; 95% CI 0.69 to 0.91)
Adverse events | 1 (5,599) | SOE=Moderate No differences in liver function or other adverse events between therapies
Percutaneous LAA Closure vs. Warfarin
Ischemic stroke | 1 (707) | SOE=Low 9 LAA patients (1.3 events per 100 patient-years) and 6 warfarin patients (1.6 events per 100 patient-years) had ischemic stroke, demonstrating no difference between therapies
All strokes | 1 (707) | SOE=Low Trend toward a benefit of LAA (RR 0.71; 95% CI 0.35 to 1.64)
Major bleeding | 1 (707) | SOE=Low Less frequent with LAA (3.5% vs. 4.1%)
All-cause mortality | 1 (707) | SOE=Low Trend toward a benefit of LAA (RR 0.62; 95% CI 0.34 to 1.24)
Adverse events | 1 (707) | SOE=Moderate Higher rate with LAA (RR 1.69; 95% CI 1.01 to 3.19)

a All strength of evidence ratings of “Insufficient” are shaded.

Abbreviations: ASA=aspirin; CI=confidence interval; HR hazard ratio; LAA=left atrial appendage; RCT=randomized controlled trial; RR=relative risk; SOE=strength of evidence

### KQ 4 Anticoagulation Strategies in Patients Undergoing Invasive Procedures

We identified 13 studies that assessed the comparative safety and effectiveness of available strategies for anticoagulation in patients with nonvalvular AF who are undergoing invasive procedures. These studies differed in design and invasive procedure, and they encompassed a wide variety of anticoagulation strategies, making synthesis of the findings difficult. Across the outcomes, the studies were often inconsistent, but given the variability described immediately above, the reasons for these inconsistencies are uncertain. As Table 37 demonstrates, we had insufficient evidence to draw conclusions about any of the outcomes of interest in this KQ. Details about the specific components of these ratings (risk of bias, consistency, directness, and precision) are available in the Results section.

Table 37 Summary of strength of evidence and effect estimates for KQ 4 (anticoagulation therapies for patients undergoing invasive procedures)

Outcome | Number of Studies (Subjects) | Strength of Evidence and Effect Estimate^a^
OAC After PCI With Stenting
Major bleeding | 3 (689) | SOE=Insufficient
Mortality | 2 (585) | SOE=Insufficient
Myocardial infarction | 2 (585) | SOE=Insufficient
Bridging Therapies
Major and minor bleeding | 6 (2,167) | SOE=Insufficient
Mortality | 5 (1,932) | SOE=Insufficient
Other thomboembolic outcomes | 5 (1,932) | SOE=Insufficient
Use of Dabigatran in Periprocedural Setting
Major and minor bleeding | 3 (5,037) | SOE=Insufficient

a All strength of evidence ratings of “Insufficient” are shaded.

Abbreviations: CI=confidence interval; OAC=oral anticoagulation; PCI=percutaneous coronary intervention; SOE=strength of evidence

### KQ 5 Strategies for Switching Between Warfarin and Novel Oral Anticoagulants

We did not identify any relevant studies to assess the comparative safety and effectiveness of available strategies for switching between warfarin and other novel oral anticoagulants, in patients with nonvalvular AF. Although an important clinical question needing future research, the current evidence was insufficient to support any findings concerning this KQ.

### KQ 6 Stroke Prevention After a Hemorrhagic Event

We did not identify any relevant studies to assess the comparative safety and effectiveness of available strategies for resuming anticoagulation therapy or performing a procedural intervention as a stroke prevention strategy following a hemorrhagic event (stroke, major bleed, or minor bleed) in patients with nonvalvular AF. Although an important clinical question needing future research, the current evidence was insufficient to support any findings concerning this KQ.

### Findings in Relationship to What Is Already Known

The need to ensure adequate benefit given the known bleeding risks of warfarin has led to the development of risk scores for thromboembolism and bleeding in patients with AF to help inform therapeutic decisions. Risk scores for prediction of these events have been touted as a way of guiding antithrombotic therapy in patients with AF. In the current CER, we found that of the available risk scores, the CHADS_2_ and CHA_2_DS_2_VASc scores are the most commonly studied. A bleeding score, HAS-BLED, has recently been developed and was also reviewed. Although the CHADS_2_, CHA_2_DS_2_VASc, and HAS-BLED scores aid in estimating the risk of stroke and bleeding in patients with AF and help guide decisions regarding the use of warfarin, the value of these scores in guiding decisionmaking in patients with AF receiving other novel agents is still emerging, with evidence so far based solely on patients in RCTs rather than on actual clinical practice. Further improvement in the tools and methods for risk stratification of both stroke and bleeding will be important to better individualize treatment using novel oral anticoagulants in patients with AF.

With more available treatments, our review suggests that not only do risk algorithms need to be updated, but physician decisionmaking about when to use which agent does as well. When anticoagulating a patient with an acute coronary syndrome, for example, physicians have an extensive array of effective parenteral and oral agents from which to choose. However, until very recently, there was only one established oral anticoagulant available for stroke prophylaxis in patients with AF. This single agent—warfarin—while effective when compared with placebo or antiplatelet agents such as aspirin, is associated with significant limitations from both the health system and patient perspectives. Historically, this fundamental lack of choices in oral anticoagulation in AF was particularly challenging, given the significant heterogeneity present in the increasingly elderly AF population. In the setting of multiple limitations of current treatment with warfarin or other vitamin K antagonists (VKAs), several new oral anticoagulants have been developed for stroke prevention in nonvalvular AF. Trials of dabigatran, rivaroxaban, and apixaban have demonstrated favorable efficacy and safety results compared with warfarin, but conclusions about the comparative efficacy and safety of the newer oral anticoagulants cannot be drawn because these medications have not been directly compared with one another, and indirect (cross-trial) comparisons may not be reliable. In addition, the trials of these newer agents used different dosing strategies, were performed in different health systems, used varying event definitions, and recruited populations at varying risk for stroke and bleeding. The newer oral anticoagulants do, however, have different attributes and important advantages over warfarin. After many years without options, they offer new alternatives for the treatment of patients with nonvalvular AF who are at risk for stroke. Specifically, our review adds the following to what is already known within the field of stroke prevention for patients with AF:

- New oral anticoagulants preserve the benefits of warfarin for stroke prevention, and two of them (apixaban and higher dose dabigatran) have been demonstrated in large RCTs to be more effective than warfarin.
- In addition to these stroke prevention benefits, the new oral anticoagulants appear to be safer than warfarin in that:
  ○ All of them caused less intracranial bleeding than warfarin.
  ○ Two of them (apixaban or lower dose dabigatran) caused less major bleeding, including gastrointestinal bleeding, than warfarin.
- For patients not suitable for oral anticoagulation, apixaban was more effective than aspirin in stroke prevention. In addition, apixaban was better tolerated than and as safe as aspirin.
- All the new oral anticoagulants tested in a blinded fashion were better tolerated than warfarin, and rates of study drug discontinuation were lower with the new agents than with warfarin.
- Apixaban reduced all-cause mortality in patients with AF. Dabigatran and rivaroxaban appear to have similar all-cause mortality as warfarin.

Despite all the potential advantages of the new drugs demonstrated in the clinical trials when compared with warfarin, the new drugs still do not have a well-validated and studied immediate antidote. Similarly, although there are data showing that fresh frozen plasma or vitamin K can help in normalizing INRs for warfarin-treated patients, there are not good data on actually stopping or reversing bleeding events for them. Once a bleed occurs, the event has happened, and regardless of the original treatment strategy, it is not clear that any reversal or antidote will alter patient outcomes. Therefore, a focus should be on preventing bleeds—in particular, fatal bleeds. The shorter half-life of the novel drugs may help in the management of bleeding episodes in patients receiving these drugs and should provide comfort that bleeding can be controlled without an antidote. This half-life is similar to the time needed to reverse INR (not bleeding) of patients on warfarin with vitamin K. The shorter half-life of these novel agents may, however, be a disadvantage in poorly compliant patients, emphasizing the need for additional evidence outside of RCTs and within actual clinical practice.

### Applicability

Efficacy of interventions as determined in RCTs does not always translate to usual practice, where patient characteristics, provider clinical training, and available resources may differ from trial conditions. Additionally, the availability and/or specific features of interventions studied in our review may differ from those available to patients within the United States.

Nearly all the studies were conducted in Europe, the United States or Canada, suggesting that the level of care and co-medications were roughly similar to those available to the U.S. population. Table 38 illustrates the specific issues with the applicability of our included evidence base by KQ.

Table 38 Potential issues with applicability of included studies

Issues | Key Question
Issues | KQ 1 N=37 | KQ 2 N=17 | KQ 3 N=43 | KQ 4 N=13 | KQ 5 N=0 | KQ 6 N=0 | Total^a^ N=92
Population (P)
Narrow eligibility criteria and exclusion of those with comorbidities | 0 | 0 | 2 | 0 | 0 | 0 | 2
Large differences between demographics of study population and community patients | 2 | 0 | 2 | 0 | 0 | 0 | 4
Narrow or unrepresentative severity, stage of illness, or comorbidities | 0 | 0 | 0 | 0 | 0 | 0 | 0
Run-in period with high exclusion rate for nonadherence or side effects | 0 | 0 | 1 | 0 | 0 | 0 | 1
Event rates much higher or lower than observed in population-based studies | 0 | 0 | 1 | 0 | 0 | 0 | 1
Intervention (I)
Doses or schedules not reflected in current practice | 0 | 0 | 1 | 0 | 0 | 0 | 1
Monitoring practices or visit frequency not used in typical practice | 1 | 1 | 0 | 0 | 0 | 0 | 1
Older versions of an intervention no longer in common use | 2 | 1 | 1 | 0 | 0 | 0 | 3
Cointerventions that are likely to modify effectiveness of therapy | 0 | 0 | 1 | 0 | 0 | 0 | 1
Highly selected intervention team or level of training/proficiency not widely available | 0 | 0 | 0 | 0 | 0 | 0 | 0
Comparator (C)
Inadequate comparison therapy | 1 | 2 | 1 | 1 | 0 | 0 | 5
Use of substandard alternative therapy | 0 | 0 | 0 | 0 | 0 | 0 | 0
Outcomes (O)
Composite outcomes that mix outcomes of different significance | 2 | 1 | 2 | 0 | 0 | 0 | 4
Short-term or surrogate outcomes | 1 | 0 | 7 | 0 | 0 | 0 | 8
Setting (S)
Standards of care differ markedly from setting of interest | 0 | 0 | 0 | 0 | 0 | 0 | 0
Specialty population or level of care differs from that seen in community | 0 | 0 | 0 | 0 | 0 | 0 | 0

a Some studies were relevant to more than one KQ.

Abbreviation: KQ=Key Question

In general, concerns about study applicability were not a major factor for this project’s body of evidence. The main issues related to applicability were concerns about short-term outcomes (9% of studies overall, representing 3%, 0%, 16%, and 0% of KQ 1, KQ 2, KQ 3, and KQ 4 studies, respectively); concerns about large differences between demographics of study populations and community patients in terms of age, renal function, and comorbidities (4% of studies overall, representing 5%, 0%, 5%, and 0% of KQ 1, KQ 2, KQ 3, and KQ 4 studies, respectively); and concerns about use of older versions of an intervention no longer in common use (3% of studies overall, representing 5%, 6%, 2%, and 0% of KQ 1, KQ 2, KQ 3, and KQ 4 studies, respectively).

## Implications for Clinical and Policy Decisionmaking

Stroke prevention in patients with nonvalvular AF in contemporary clinical practice is complex and challenging, but critically important given the morbidity and mortality associated with stroke events. The use of common antiplatelet agents such as aspirin and traditional anticoagulants can significantly reduce the risk of stroke in patients with AF, however, bleeding risks increase with these agents, potentially attenuating their effects. Newer anticoagulants promise improved efficacy with reduction in bleeding events and more predictable pharmacokinetics. However, the long-term effects of these newer agents in broad populations have not been established. Therefore, clinicians are constantly struggling to find the right balance between efficacy and risk in the use of these therapies in this patient population.

Despite the availability and validation of numerous risk tools for both stroke and bleeding risk in patients with nonvalvular AF, evidence has shown that the routine use of these tools is low, and patients are sometimes paradoxically treated (e.g., low-risk patients with anticoagulants and high-risk patients with antiplatelet or no therapy). At the time the current U.S. guidelines for management of AF were developed (2006,1 with a focused update in 2011^62^), the primary focus was on risk stratification and treatment with antiplatelets or VKAs. Since that time, newer anticoagulants have entered the marketplace, but the guidelines have not yet been updated to reflect this new evidence. Furthermore, there have not been any comparative effectiveness studies examining these new agents head-to-head. The task of stroke prevention for busy clinicians is no longer simply risk stratification and deciding between aspirin versus warfarin, but much more complex. Clinicians will have to understand the risk and benefits, indications, side effects, and monitoring of new anticoagulants, further complicating treatment decisions in patients with AF.

In its most recent update in 2012, the ESC has published guidelines that acknowledge the limitation of current risk tools to identify patients at high risk for thromboembolic risk. In fact, the current ESC guidelines recommend a strategy of identifying those individuals with AF who are “truly low risk” for thromboembolic events, i.e., no risk factors for stroke, and thus do not need oral anticoagulant therapy. The current guidelines recommend all other patients should be considered for oral anticoagulant therapy. To provide further guidance, the AFib Optimal Treatment Task Force convened a roundtable of experts to develop a statement on the best practices for assessing stroke and bleeding risk for anticoagulation decision-making using available risk assessment tools. The group proposed a three-step approach to assessing stroke and bleeding risk in AF patients:

1. Assess and record an individual’s stroke risk annually using an established scoring tool. Intermediate or high risk individuals should be place on an anticoagulant. Aspirin was not recommended by the task force for stroke prophylaxis in AF.
2. If the individual requires anticoagulation therapy, then the bleeding risk should be evaluated to estimate the net clinical benefit of anticoagulation. Risk factors for intracranial hemorrhage should be considered although routine screening for these risk factors was not recommended.
3. The decision to start anticoagulation therapy must reflect patient preferences and values. The patient must also understand the relative benefits and risks involved in the discussion and decision surrounding the clinical net benefit of anticoagulation therapy.

In light of these recent recommendations, the current review underscores that further efforts are needed to continue to refine risk prediction tools, particularly in the context of newly available anticoagulants. With the growing prevalence of digitized medical records, there is an opportunity to monitor the real world uptake of the newer anticoagulants. Additionally, with these electronic records, there will be the opportunity to continue to evaluate and modify risk prediction tools to improve their discrimination for stroke and bleeding risk, particularly with these newer anticoagulants diffusing into clinical practice. Also, newer clinical markers, comorbidities (i.e., renal failure, etc.) and biomarkers should be tested and validated with or alongside current risk tools to improve their discrimination of both stroke and bleeding risks. Additionally, more prescriptive guidelines on how to use risk scores and apply necessary therapies, possibly in the form of physician decision support tools, will be important for clinical decisionmaking. Finally, gaps have been identified in the current evidence for increasingly common clinical scenarios for patients on therapies for stroke prevention. Evidence is needed on the best strategies for patients undergoing invasive procedures, switching among anticoagulant therapies, and starting or restarting anticoagulant therapy in patients with previous major bleeding events.

As new drugs are introduced, determining their relative risks and benefits in the overall scheme for stroke prevention in AF is critically important in order to minimize the use of less efficacious, less safe, and more expensive therapies. Even though the ESC 2012 guidelines for AF recommend that the critical assessment necessary in the era of newer oral anticoagulants is the differentiation of “truly low-risk” patients—i.e., those who do not need oral anticoagulation—from those who have one or more risk factors for stroke and should be recommended for oral anticoagulation, appropriate and accurate risk assessment is required, as these newer anticoagulants are still not without bleeding risk. Although the results of the current review are largely consistent with existing guidelines, they do help identify gaps in the evidence base and areas of needed future research, particularly as newer agents are rapidly entering into broader clinical practice.

## Limitations of the Evidence Base and the Comparative Effectiveness Review Process

Our findings have limitations related to the literature and our approach. Important limitations of the literature across the KQs include: (1) few or no studies focusing on stroke prevention for patients undergoing invasive procedures (KQ 4), switching between warfarin and other novel anticoagulants (KQ 5), and determining optimal stroke prevention following a hemorrhagic event (KQ 6); (2) inconsistency across studies that assess prediction tools for thromboembolic or bleeding risk in terms of the methods used and findings reported; (3) few studies which compare specific stroke prevention therapies allowing quantitative synthesis especially involving the newer anticoagulant agents (KQ 3); and (4) inadequate comparison therapies in terms of representing either standard of care of novel alternative therapy.

Our review methods also had limitations. Our study was limited to English-language publications. It was the opinion of the investigators and the Technical Expert Panel (TEP) that the resources required to translate non-English articles would not be justified by the low potential likelihood of identifying relevant data unavailable from English-language sources. We also limited our analysis to studies published since 2000. Given the rapidly changing treatment alternatives for stroke prevention for patients with AF it was the opinion of the investigators and the TEP that this recent literature was the most relevant to today’s clinical and policy uncertainties. Finally, as a comparative effectiveness study, for KQ3 we restricted our analysis to studies that compared two active therapies for AF stroke prevention and did not include placebo (only)-controlled trials. Inclusion of such placebo-controlled trials may have allowed additional quantitative analyses to be performed used mixed treatment meta-analyses. We did not perform meta-analysis using indirect comparisons of treatment given the heterogeneity of study designs, therapies, populations, and concomitant therapies in the included studies. Of note, a recent meta-analysis221 combined 12 studies (3 administering dabigatran, 4 administering rivaroxaban, 2 administering apixaban, and 3 administering edoxaban) involving 54 875 patients and found that these novel oral anticoagulants as a group significantly reduced total mortality (RR, 0.89; 95% CI 0.83 to 0.96), cardiovascular mortality (RR, 0.89; 95% CI 0.82 to 0.98), and stroke/systemic embolism (RR, 0.77; 95% CI 0.70 to 0.86). There was a trend toward reduced major bleeding (RR, 0.86; 95% CI 0.72 to 1.02) and a significant reduction of intracranial hemorrhage (RR, 0.46; 95% CI 0.39 to 0.56). No difference in myocardial infarction was observed. The authors acknowledge the limitation of their analyses given differences in trial design and populations, and given that direct thrombin inhibitors and factor Xa inhibitors have different pharmacodynamic and pharmacokinetic properties.

## Research Gaps

In our analyses, we have identified research gaps for all the Key Questions (KQs) examined. We used the framework recommended by Robinson et al. to identify gaps in evidence and describe why these gaps exist.222 This approach considers PICOTS (Populations, Interventions, Comparators, Outcomes, Timings, and Settings of interest) to identify gaps and classifies gaps as due to (a) insufficient or imprecise information; (b) biased information; (c) inconsistency or unknown consistency; and (d) not the right information. Results are described for each KQ below.

### KQs 1–2 Predicting Thromboembolic and Bleeding Risk

While there are several scores available in clinical practice to predict stroke and bleeding in patients with AF, the major limitation of these scores is the overlap of clinical factors that go into both types of scores. We therefore think that the evidence gaps for these two questions are best addressed together.

Many of the available studies for KQ1 and KQ2 had methodological issues that point to limitations of the current evidence base. Many studies’ utilization of administrative data sources led to different approaches to calculating the risk scores of interest due to unavailable data (notably for the HEMORR_2_HAGES and HAS-BLED scores). Similarly, use of administrative data in some cases prevented validation of clinical stroke/bleeding events, which could have affected studies’ estimates of the performance of these risk scores. Finally, though studies consistently reported c-statistic as a measure of model discrimination, other relevant statistics (including measures of calibration, strength of association and diagnostic accuracy) were inconsistently reported. Further studies are needed that: (1) utilize complete data; (2) use validated clinical outcomes; and (3) compare all available risk scores using consistent and appropriate statistical evaluations.

Additional research is also needed to: (1) refine risk scores to better identify truly “low risk” patients with respect to stroke for whom anticoagulation may not be necessary; (2) gather real-world data on new anticoagulants; and (3) better define biological age, frailty, and specific brain imaging findings as RFs for ICH.

We can identify well patients at risk for stroke, who usually are the same patients at high risk for bleeding. Thus, there is a need for a score that could be used for decisionmaking about antithrombotic therapy in AF patients taking into account both thromboembolic and bleeding risks. Scores that identify only patients at risk for stroke or only those at risk for bleeding are not so helpful since the clinical factors in these scores are usually similar. Another challenge is that both stroke events and bleeding events are on a spectrum of severity. For example, some strokes may have symptoms lasting <24 hours with complete resolution, whereas others can cause death. Additional studies utilizing prospectively constructed databases with longer-term outcomes data that compare all available risk prediction scores would be of great use in better clarifying which risk score system is superior in predicting major bleeding or thromboembolic risk. Specific to bleeding risk, additional prospective comparisons of the standard deviation of transformed international normalized ratio (SDT_INR_) and time in therapeutic range (TTR) are needed to establish which variable has better predictive accuracy for major bleeding.

Another issue was not addressed in this review: in an era of personalized medicine, it may be important to have the “omics” profile (genomics, proteomics, metabolomics) incorporated into the risk scores, which could help to more accurately stratify AF patients according to their thromboembolic and bleeding risks.

Additionally, even assuming that an optimal risk prediction score can be identified, further work is needed to clarify how scores should be used prospectively in clinical practice.

Finally, for future studies of available tools, reporting the raw data rather than c-statistics would allow more informative assessment of the predictive model performance. If we had had such raw data, we could have considered the net reclassification index (NRI) or integrated discrimination index, which summarize the incremental benefit of a score when added to a model with other covariates.

Therefore four specific evidence gaps identified from KQ 1 and KQ 2 are:

1. In patients with nonvalvular AF, what are the comparative diagnostic accuracy and impact on clinical decisionmaking of clinical tools with modest or better predictive value for predicting the overall clinical risk of patients combining both their risk of stroke and their risk of bleeding?
2. In patients with nonvalvular AF, what are the comparative diagnostic accuracy and impact on clinical decisionmaking of imaging tools with modest or better predictive value for predicting the overall clinical risk of patients combining both their risk of stroke and their risk of bleeding?
3. What are the benefits, harms, and costs of incorporating genomics, proteomics, and metabolomics into risk scores for the prediction of thromboembolic and/or bleeding risk?
4. What is the most effective way to prospectively use thromboembolic and/or bleeding risk scores with evidence of modest or better predictive value in clinical practice? Specifically, how can we increase dissemination of point-of-care tools to improve risk assessment and treatment choices for clinicians?

### KQ 3 Interventions for Preventing Thromboembolic Events

Although recent years have been exciting in stroke prevention and development of new agents as alternatives to warfarin, there are several evidence gaps that remain and should inform future research. Given the risks associated with AF, the growing number of patients with AF, and the costs and risks associated with stroke prevention for AF, a better understanding of comparative safety and effectiveness of newer anticoagulant therapies is of paramount importance. There is a need for further study of these newer agents, particularly focusing on methods of monitoring adequacy of anticoagulation, as well as the development of antidotes for severe bleeding events. There is also a need for future studies in special populations and clinical scenarios. In addition, it is important to have new studies with head-to-head comparisons of available prevention strategies. Given variability in patient populations, concomitant therapies, and underlying patient care, cross-trial comparisons in this field should be avoided. Patients with AF usually have comorbidities that require the use of antithrombotic agents other than those used to treat AF. Many antithrombotic agents are available at different doses for different clinical indications. There is a need for studies assessing the safety and effectiveness of different combinations of antithrombotics (anticoagulants and antiplatelet agents) at different doses, as well as their duration. For example, nothing is known about the use of triple therapy in patients with coronary artery disease/acute coronary syndrome and AF in the new era with new antiplatelet (prasugrel and ticagrelor) and new anticoagulant agents (dabigatran, rivaroxaban, apixaban).

There are also many novel invasive treatments for AF. Studies are needed to determine if and how anticoagulation strategies should be modified for patients receiving these procedures. For example, studies are needed to determine the comparative effectiveness and safety of new oral anticoagulants and percutaneous left atrial appendage (LAA) closure for stroke prevention in nonvalvular AF patients. Studies are needed to determine if and when it is safe to discontinue all oral anticoagulants after successful AF ablation. Studies also are needed to determine the thromboembolic and bleeding risk associated with the procedures themselves over the long term.

Therefore, we have identified the following specific evidence gaps related to KQ 3:

1. What are the comparative safety and effectiveness of specific anticoagulation therapies, antiplatelet therapies, and procedural interventions for preventing thromboembolic events?
  a. For the above evidence gap, we suggest focusing specifically on the comparative effectiveness of Factor IIa inhibitors, Xa inhibitors, and other novel anticoagulants and procedural interventions.
  b. Safety issues include reversal of anticoagulant effects for severe bleeding events and monitoring of therapeutic status.
2. What are the comparative safety and effectiveness of specific anticoagulation therapies, antiplatelet therapies, and procedural interventions for preventing thromboembolic events specific to patients who have recently undergone rate or rhythm control procedures for treating their AF?
  a. For the above evidence gap, we suggest focusing on methods of determining the comparative effectiveness and safety of available stroke prevention therapies, and strategies for determining longer term therapy given successful AF treatment.
3. What are the comparative safety and effectiveness of specific anticoagulation therapies, antiplatelet therapies, and procedural interventions for preventing thromboembolic events specific to special subpopulations such as patients with advanced renal failure or on dialysis, elderly patients, and others?
  a. For the above evidence gap, we suggest focusing specifically on the comparative effectiveness of Factor IIa inhibitors, Xa inhibitors, and other novel anticoagulants and procedural interventions

### KQ 4 Anticoagulation Strategies in Patients Undergoing Invasive Procedures

Our review identified limited studies assessing the optimal strategy for anticoagulation either peri-radiofrequency ablation (RFA) or in the setting of other operative procedures. In addition, the few studies available suggest that ischemic event rates are likely to be extremely low; thus, trials powered adequately to assess the impact of different strategies, especially on ischemic events, would have to be large. Given the number of these procedures performed per year, as well as the apparent uncertainty about optimal treatment of the patients undergoing such procedures, RCTs to answer these questions are sorely needed. Trials should be done with traditional anticoagulants as well as the newer antiplatelet and antithrombotic agents. Given the number of treatment strategies available, initial research might be focused on comparing continued anticoagulant therapy versus bridging therapies versus interruption of therapy (i.e., stopping anticoagulant therapy before the procedure). Given the current insufficient evidence pertinent to this KQ, we think that the original KQ represents the remaining evidence gap and need for future research. Perhaps an additional evidence gap, given the need for a large sample size in an RCT addressing this question, would be explore whether study designs other than RCTs would possibly help decrease the evidence gap in this area.

### KQs 5–6 Switching Between Warfarin and Novel Oral Anticoagulants and Stroke Prevention After a Hemorrhagic Event

We found no peer-reviewed published studies for either of these KQs, and so these are both clearly remaining evidence gaps, needing future evidence generation before evidence synthesis is possible.

Due to the increasing popularity of the new Xa agents, RCTs are needed to establish evidence to guide providers in managing patients with AF who are currently on warfarin and being switched to the newer Xa agents. Trials should seek to provide directions for managing patients who may be at different risk levels (as defined by CHADS_2,_ CHA_2_DS_2_VASc, or Framingham risk scores), including type of AF, sex, age, and other co-existing risk factors. Additionally, evidence needs to be published in peer-reviewed journals on how to manage patients being switched off of the newer Xa agents and onto warfarin.

Similarly, trials are needed to determine the comparative safety and effectiveness of available strategies for resuming anticoagulation therapy following a hemorrhagic event. These trials should be evaluated in patients based on type of hemorrhagic event, as well as based on traits that may affect risk of bleeding, such as age, comorbidities, and other medical therapies.

## Conclusions

Overall, we found that CHADS_2_ and CHA_2_DS_2_-VASc scores have the best prediction for stroke events in patients with AF among the risk scores we reviewed, whereas HAS-BLED provides the best prediction for bleeding risk. Imaging tools require further evidence in regard to their appropriate use in clinical decisionmaking. Additionally, simple clinical decision tools are needed that incorporate both stroke risk and bleeding risk to assist providers choosing agents in patients with AF. Additional work will be required to develop risk tools for patients to discriminate those individuals with AF where the bleeding risk may outweigh the stroke prevention benefit. These tools could be embedded into electronic medical record systems for point-of-care decisionmaking, developed into applications for smartphones and tablets, or be delivered via web-based interfaces. Additional evidence of the use of these stroke and bleeding risk scores (and clinical decision tools which balance these risks) among patients on therapy is also required.

Newer anticoagulants show early promise of reducing stroke and bleeding events when compared with warfarin, and apixaban shows safety and efficacy in patients who are not candidates for warfarin. However, further studies are required for key clinical scenarios involving anticoagulation use and procedures, switching or bridging therapies, and when to start anticoagulation after a hemorrhagic event.