# List of Excluded Studies

All studies listed below were reviewed in their full-text version and excluded for the reasons cited. Reasons for exclusion signify only the usefulness of the articles for this study and are not intended as criticisms of the articles.

## Not Available in English

Hu DY, Zhang HP, Sun YH, et al. The randomized study of efficiency and safety of antithrombotic therapy in nonvalvular atrial fibrillation: warfarin compared with aspirin. Zhonghua Xin Xue Guan Bing Za Zhi. 2006;34(4):295-8. [pmid: 16776915].
Perez-Ortega I, Moniche-Alvarez F, Dolores Jimenez-Hernandez M, et al. Cardioembolic stroke in atrial fibrillation and new anticoagulation criteria: A therapeutic dare. ORIGINAL (NON-ENGLISH) TITLE. Ictus cardioembolico por fibrilacion auricular y nuevos criterios de anticoagulacion: Un reto terapeutico. Rev Neurol. 2012;55(2):74-80. [pmid: 22760766].

## Not a Clinical Study

Aalbers J. South Africa’s poor warfarin control raises questions of benefit above other anticoagulant therapies in atrial fibrillation. Cardiovasc J Afr. 2011;22(4):220. [pmid: 21881695].
Bleeding risk with warfarin is high among elderly. J Fam Pract. 2007;56(9):709. [pmid: 17802645].
Warfarin prevents more stroke than clopidogrel and aspirin in afib. J Fam Pract. 2006;55(9):753. [pmid: 17009433].
Warfarin versus aspirin in stroke prevention. Med Today. 2002;3(2):10.
Badar A, Richardson J, Scaife J, et al. Estimation of thromboembolic and bleeding risk in patients with atrial fibrillation undergoing percutaneous coronary intervention for acute coronary syndrome. EuroIntervention. 2010;6.
Banerjee A, Lane DA, Torp-Pedersen C, et al. Net clinical benefit of new oral anticoagulants (dabigatran, rivaroxaban, apixaban) versus no treatment in a ‘real world’ atrial fibrillation population: a modelling analysis based on a nationwide cohort study. Thromb Haemost. 2012;107(3):584-9. [pmid: 22186961].
Benditt DG, Adabag S, Chen LY. An earnest search for atrial fibrillation patients without thromboembolic risk. J Cardiovasc Electrophysiol. 2012;23(7):714-6. [pmid: 22313332].
Bouzin M, Cavaco D, Adragao P, et al. Atrial fibrillation ablation with therapeutic INR: A safe strategy. Europace. 2010;12(Suppl 1):i113.
Butler A, Tait RC. Restarting oral anticoagulation after intracranial hemorrhage. Stroke. 2004;35(1):e5-6. author reply e5–6. [pmid: 14671234].
Ciudici MC, Paul DL, Sloane C, et al. Outpatient atrial Fibrillation ablation on therapeutic warfarin safety, efficacy, and cost savings. Europace. 2010;12:i113.
Crosato M, Calzolari V, Grisolia EF, et al. Perioperative warfarin management in pacing surgery. Europace. 2010;12:i44.
Darby-Stewart A, Dachs R, Graber MA. Rivaroxaban vs. warfarin for stroke prevention in patients with nonvalvular atrial fibrillation. Am Fam Physician. 2012;85(6):577-86. [pmid: 22534269].
DeSilvey DL. Clopidogrel plus aspirin vs oral anticoagulation for atrial fibrillation: the ACTIVE W trial. Am J Geriatr Cardiol. 2006;15(5):326-7. [pmid: 16957455].
Di Biase L, Burkhardt JD, Lakkireddy DJ, et al. Catheter ablation of atrial fibrillation under therapeutic coumadin: Prevalence of pericardial effusion comparing paroxysmal and non paroxysmal atrial fibrillation. Eur Heart J. 2011;32:804.
Dufaitre G, Ederhy S, Lang S, et al. Tee-detected left atrial thrombogenic milieu is associated with increased cardiovascular events in patients with non valvular atrial fibrillation. Arch Cardiovasc Dis. 2011;104(4):288.
Eikelboom JW, Quinlan DJ, Connolly SJ, et al. Dabigatran efficacy-safety assessment for stroke prevention in patients with atrial fibrillation. J Thromb Haemost. 2012;10(5):966-8. [pmid: 22360879].
Engelbertz C, Reinecke H. Atrial fibrillation and oral anticoagulation in chronic kidney disease. J Atrial Fibrillation. 2012;4(6):74-85.
Fang MC, Singer DE. Risk of intracranial hemorrhage in atrial fibrillation. Cardiol Rev. 2005;22(12):24-8.
Gao F, Zhou YJ, Wang ZJ, et al. Comparison of different antithrombotic regime in patients with atrial fibrillation undergoing drug-eluting stent implantation. EuroIntervention. 2010;6.
Gloekler S, Schmid M, Saguner AA, et al. Transcatheter left atrial appendage occlusion in atrial fibrillation: Comparison of non-dedicated versus dedicated amplatzer devices. Eur Heart J. 2011;32:667.
Granger CB, Hanna M, Wallentin L. The authors reply. N Engl J Med. 2012;366(1):89.
Hart RG, Pearce LA, Koudstaal PJ. Transient ischemic attacks in patients with atrial fibrillation: implications for secondary prevention: the European Atrial Fibrillation Trial and Stroke Prevention in Atrial Fibrillation III trial. Stroke. 2004;35(4):948-51. [pmid: 14988571].
Hohnloser S, Yusuf S, Eikelboom J, et al. Apixaban in patients with atrial fibrillation and their risk for cardiovascular hospitalization: Insights from the AVERROES trial. Eur Heart J. 2011;32(Suppl 1):671.
Kakar P, Lane D, Lip GY. Bleeding risk stratification models in deciding on anticoagulation in patients with atrial fibrillation: a useful complement to stroke risk stratification schema. Chest. 2006;130(5):1296-9. [pmid: 17099002].
Kita K, Lyn R, Cortes G, et al. The ARISTOTLE trial: Apixaban versus warfarin in patients with atrial fibrillation. Intervent Cardiol. 2011;3(6):637.
Klein G, Hartung J, Tallone EM, et al. Left atrial appendage occlusion with the watchman-device in patients with atrial fibrillation and warfarin contraindications. Eur Heart J. 2011;32(Suppl 1):556-7.
Lang S, Ederhy S, Dufaitre G, et al. Adding C-reactive protein to the CHADS2 and CHA2DS2-VASc scores improves prediction of cardiovascular events including heart failure in patients with non valvular atrial fibrillation. Eur Heart J. 2011;32(Suppl 1):461.
Lee EH, Kwong WJ, Casciano J, et al. Improving bleeding risk assessment for anticoagulant use in atrial fibrillation. Value Health. 2011;14(3):A37.
Leithauser B, Broemel T, Park JW. Left atrial appendage closure with Amplatzer Cardiac Plug for prevention of stroke in atrial fibrillation: in-vivo imaging. J Cardiovasc Med (Hagerstown). 2011;12(3):209-11. [pmid: 20479656].
Limantoro I, Pisters R. Peri-procedural antithrombotic bridging and the assessment of the associated risk of major bleeding. Thromb Haemost. 2012;108(1):9-10. [pmid: 22688666].
Lip GYH, Frison L, Halperin JL, et al. Comparative analysis of the HAS-BLED score with other bleeding risk scores, Using estimates of net reclassification improvement and integrated discrimination improvement. J Am Coll Cardiol. 2011;58(13):1398-9.
Makosch GA, Griffiths A, Meredith T, et al. Catheter ablation of atrial fibrillation whilst taking therapeutic warfarin: A british experience. Heart. 2010;96(Suppl 1):A79-80.
Malo M, Valle S, Izquierdo I, et al. Clinical experience in combined anti-platelet plus anticoagulant therapy in patients with valvular and non valvular atrial fibrillation. Haematologica. 2009;94(Suppl 2):668.
Mant J, Hobbs R, Fletcher K, et al. Is warfarin a safe alternative to aspirin in elderly patients with atrial fibrillation?. Cardiol Rev. 2008;25(7):32-6.
Meyer JP, Gillatt DA, Lush R, et al. Managing the warfarinized urological patient. BJU Int. 2003;92(4):351-4. [pmid: 12930417].
Mohrs OK, Schraeder R, Petersen SE, et al. Percutaneous left atrial appendage transcatheter occlusion (PLAATO): planning and follow-up using contrast-enhanced MRI. AJR Am J Roentgenol. 2006;186(2):361-4. [pmid: 16423938].
Molina CA, Selim MH. The dilemma of resuming anticoagulation after intracranial hemorrhage little evidence facing big fears. Stroke. 2011;42(12):3665-6. [pmid: 22052525].
Murray RD, Shah A, Jasper SE, et al. Transesophageal echocardiography guided enoxaparin antithrombotic strategy for cardioversion of atrial fibrillation: the ACUTE II pilot study. Am Heart J. 2000;139(6):E1-7. [pmid: 10827367].
Nerella N. A 5-item score predicted risk for warfarin-associated major hemorrhage in patients with atrial fibrillation. Ann Intern Med. 2011;155(10):JC5-13. [pmid: 22084360].
Nicola Tufano N, Attanasio S, Sessa G, et al. Prevention of thromboembolism in paroxysmal atrial fibrillation: from guidelines to daily practice in an emergency department. Eur J Cardiovasc Prev Rehabil. 2011;18(1):S114.
Ohtsuka T, Ninomiya M, Nonaka T. Resection of fibrillated atrial appendage may mitigate a risk of stroke. Innov Technol Tech Cardiothorac Vasc Surg. 2010;5(3):229.
Ostermayer S, Reschke M, Billinger K, et al. Percutaneous closure of the left atrial appendage. J Interv Cardiol. 2003;16(6):553-6. [pmid: 14632953].
Park JW, Bethencour A, Sievert H, et al. Left atrial appendage closure with Amplatzer cardiac plug for prevention of stroke in atrial fibrillation. EuroIntervention. 2010;6.
Park JW, Bethencour A, Sievert H, et al. Left atrial appendage closure with amplatzer cardiac plug for prevention of stroke in atrial fibrillation. Initial european experience. Eur Heart J. 2010;31(Suppl 1):513.
Park JW, Bethencour A, Sievert H, et al. Left atrial appendage closure with amplatzer cardiac plug for prevention of stroke in atrial fibrillation-initial European experience. Eur Heart J Suppl. 2010;12(Suppl A):S14.
Peters DC. Association of left atrial fibrosis detected by delayed enhancement magnetic resonance imaging and risk of stroke in patients with atrial fibrillation. J Atrial Fibrillation. 2011;2(6).
Petrie C. Clopidogrel in atrial fibrillation: Is there any justification now in the era of new anticoagulants?. Am J Cardiol. 2012;110(1):165. [pmid: 22704302].
Pocnulli D, Hartford M, Karlsson T, et al. The role of the CHADS2 score in acute coronary syndromes very long-term risk of death in patients with and without atrial fibrillation. Europace. 2010;12(Suppl 1):i131.
Poli D, Antonucci E, Di Gennaro L, et al. VKA treatment and bleeding rate of patients aged older than 80 years: Results from a prospective collaborative study. Eur Heart J. 2011;32(Suppl 1):671.
Providencia R. Should we rely on risk assessment by the CHADS(2) score in patients with non-valvular atrial fibrillation undergoing direct current cardioversion?. Am J Cardiol. 2012;110(3):468-9. [pmid: 22793001].
Romero-Ortuno R, O’Shea D. Aspirin versus warfarin in atrial fibrillation: decision analysis may help patients’ choice. Age Ageing. 2012;41(2):250-4. [pmid: 22156597].
Ruff CT, Giugliano RP, Antman EM, et al. Evaluation of the novel factor Xa inhibitor edoxaban compared with warfarin in patients with atrial fibrillation: design and rationale for the Effective aNticoaGulation with factor xA next GEneration in Atrial Fibrillation-Thrombolysis In Myocardial Infarction study 48 (ENGAGE AF-TIMI 48). Am Heart J. 2010;160(4):635-41. [pmid: 20934556].
Rutten FH, Van Riet EES, Hollander M, et al. Longterm effects of aspirin and vitamin K antagonists on mortality in patients with atrial fibrillation and heart failure. An observational study. Eur J Heart Fail Suppl. 2011;10(Suppl 1):S120-1.
Sakai T, Kujime S, Moriyama A, et al. Combination therapy with K channel blocker and warfarin in atrial fibrillation might be more effective for prevention of cerebral infarction than with warfarin alone. Europace. 2010;12(Suppl 1):i76.
Salzberg SP, Emmert MY, Gruenenfelder J, et al. Excellent clinical outcome 1 year after left atrial appendage clip occlusion. Eur Heart J. 2010;31(Suppl 1):513.
Sanna T, Di Lazzaro V. Thromboembolic risk management in paroxysmal atrial fibrillation after brain haemorrhage. Int J Stroke. 2011;6(1):92-3. [pmid: 21205251].
Sawaya FJ, Musallam KM, Arnaout S, et al. Switching patients from warfarin to dabigatran therapy: To RE-LY or not to rely. Int J Cardiol. 2012;154(2):e27-8. [pmid: 21624685].
Schulman S, Majeed A. The oral thrombin inhibitor dabigatran: Strengths and weaknesses. Semin Thromb Hemost. 2012;38(1):7-15. [pmid: 22314598].
Schulman S. Resumption of oral anticoagulation after warfarin-associated intracerebral hemorrhage no. Stroke. 2011;42(12):3663-4. [pmid: 22052515].
Smit MD, Van Gelder IC. Risk-benefit ratio assessment for stroke prevention in intermediate risk atrial fibrillation patients: will TEE-based aspirin treatment fill the gap?. Neth Heart J. 2011;19(5):212-3. [pmid: 21487742].
Smoyer-Tomic K, Sander S, Siu K, et al. Anticoagulant use, the prevalence of bridging and relation to length of stay among hospitalized patients with non-valvular atrial fibrillation. Value Health. 2011;14(3):A49.
Spyropoulos AC, Douketis J, Kaatz S, et al. Bridging anticoagulation in patients who require temporary interruption of warfarin for elective surger or procedure-the BRIDGE trial: Design, rationale and clinical implications. Blood. 2011;118(21):A4327.
Steiner T. Resumption of oral anticoagulation after warfarin-associated intracerebral hemorrhage yes. Stroke. 2011;42(12):3661-2. [pmid: 22052514].
Testa L, Agnifili M, Latini RA, et al. Adjusted indirect comparison of new oral anticoagulants for stroke prevention in atrial fibrillation. QJM. 2012;105(10):949-57. [pmid: 22771555].
Vassiliou VS. Apixaban versus warfarin in Atrial Fibrillation [1]. N Engl J Med. 2012;366(1):88. author reply 89. [pmid: 22216849].
Zed PJ, Anthony CJ, Ackroyd-Stolarz S, et al. INTENSITY of anticoagulation with warfarin and risk of adverse events in patients presenting to the emergency department. Can J Emerg Med. 2010;12(3):272.

## Not Original Peer-Reviewed Data/Abstract Only

Abraham JCMM, Wassertheil-Smoller S, Larson J, et al. Stroke risk in post-menopausal women with atrial fibrillation in the women’s health initiative: A validation and comparison of the CHADS2 and CHA2DS2-VASC risk scores. J Am Coll Cardiol. 2012;59(13Suppl 1):E569.
Abu Assi E, Otero Ravina F, Lado A, et al. Validity of the HAS-BLED risk score in a community-based cohort of elderly patients with atrial fibrillation. the AFBAR (Atrial Fibrillation in the BARbanza area) study. Eur Heart J. 2011;32(Suppl 1):463.
Adams C, Ross I, Bainbridge D, et al. The immediate and long term effectiveness of surgical ligation of the left atrial appendage in patients undergoing cardiac surgery. Can J Cardiol. 2010;26(Suppl D):101D.
Alexander JH, Lopes R, McMurray J, et al. Efficacy and safety of apixaban compared with warfarin for stroke prevention in atrial fibrillation in patients taking concomitant aspirin. J Am Coll Cardiol. 2012;59(13Suppl 1):E1697.
Andersen SS, Raunso J, Schmiegelow M, et al. Combination therapy with warfarin and amiodarone increases risk of bleeding in patients with atrial fibrillation - A nationwide study. Eur Heart J. 2011;32(Suppl 1):672.
Andrey A, Evgeny Z, Aleksey K, et al. Comparison of the catheter ablation vs. rate-control strategy in patients with long-lasting persistent atrial fibrillation: Results of 5 years of follow-up. J Interv Card Electrophysiol. 2012;33(3):345.
Andrey A, Evgeny Z, Maksim R, et al. Long-term outcomes of extremely long-lasting persistent atrial fibrillation ablation. J Interv Card Electrophysiol. 2012;33(3):280-1.
Apixaban superior to warfarin in preventing stroke or systemic embolism. Aust J Pharm. 2012;93(1104):93.
Comparison of 12 risk stratification schemes to predict stroke in patients with nonvalvular atrial fibrillation. Stroke. 2008;39(6):1901-10. [pmid: 18420954].
Rivaroxaban-once daily, oral, direct factor Xa inhibition compared with vitamin K antagonism for prevention of stroke and Embolism Trial in Atrial Fibrillation: rationale and design of the ROCKET AF study. Am Heart J. 2010;159(3):340-7 e1. [pmid: 20211293].
Atarashi H, Inoue H, Okumura K, et al. Investigation of optimal anticoagulation strategy for stroke prevention in Japanese patients with atrial fibrillation--the J-RHYTHM Registry study design. J Cardiol. 2011;57(1):95-9. [pmid: 20934857].
Azana Fernandez EH, Da vila Barboza YR, Ribera Casado JM. Acenocoumarol or aspirin for stroke prevention in an elderly population with atrial fibrillation: Complications of treatment. Eur Geriatr Med. 2011;2(Suppl 1):S80-1.
Baker WL, Phung O. Do differences exist between oral anticoagulants in patients with nonvalvular atrial fibrillation? an adjusted indirect comparison meta-analysis. J Am Coll Cardiol. 2012;59(13Suppl 1):E597.
Bassiouny M, Saliba W, Rickard J, et al. Use of dabigatran for peri-procedural anticoagulation in patients undergoing catheter ablation for atrial fibrillation: A new paradigm in peri-procedural anticoagulation. Circulation. 2011;124(21):A13128.
Berge E, Sandercock P. Anticoagulants versus antiplatelet agents for acute ischaemic stroke. Cochrane Database Syst Rev. 2002;(4):CD003242. [pmid: 12519590].
Biase LD, Santangeli P, Anselmino M, et al. Left atrial appendage morphology and risk of stroke in patients with AF and CHADS2 score 0–1: Is there an association. J Interv Card Electrophysiol. 2012;33(3):288-9.
Blustin JM, McBane RD, Grill DE, et al. The association of thromboembolic complications and blood group in patients with atrial fibrillation. Circulation. 2011;124(21):A12072.
Boersma LVA, Swaans M, Post M, et al. Ablation for atrial fibrillation in combination with left atrial appendage closure in patients with high CHADS2-score or incompatibility with oral anticoagulation. Europace. 2011;13(Suppl 3).
Braut A, Neuzil P, Sick P, et al. LAA closure using a next-generation WATCHMAN LAA closure device. Eur Heart J. 2011;32(Suppl 1):467.
Bunch TJ, Crandall BG, Weiss JP, et al. Pradaxa can be safely used as monotherapy or as a bridge to therapeutic warfarin after atrial fibrillation ablation. Circulation. 2011;124(21):A14708.
Burgess S, Crown N, Louzada ML, et al. Clinical performance of bleeding risk scores for predicting major and clinically relevant non-major bleeding events in patients receiving oral anticoagulant therapy. Blood. 2011;118(21):2311.
Chang CH, Yang YHK, Lin LJ. Effectiveness of warfarin among atrial fibrillation patients in Taiwan. Pharmacoepidemiol Drug Saf. 2011;20(Suppl 1):S21.
Chang KC, Ko PY, Sung FC, et al. Atrial fibrillation is a strong predictor of stroke in young taiwanese adults. Circulation. 2011;124(21):A12835.
Connolly S, Yusuf S, Budaj A, et al. Rationale and design of ACTIVE: the atrial fibrillation clopidogrel trial with irbesartan for prevention of vascular events. Am Heart J. 2006;151(6):1187-93. [pmid: 16781218].
Connolly SJ, Ezekowitz MD, Yusuf S, et al. Newly identified events in the RE-LY trial. N Engl J Med. 2010;363(19):1875-6. [pmid: 21047252].
Coutts S, Frayne R, Sevick R, et al. Microbleeding on MRI as a marker for hemorrhage after stroke thrombolysis. Stroke. 2002;33(6):1457-8. [pmid: 12052973].
Cove CL, Cowan AJ, Magnani JW, et al. Distribution of stroke risk factors among trial participants and urban black individuals with atrial fibrillation. Vasc Med. 2011;16(3):227.
De Cuyper A, De Meester A, Descamps O, et al. Left atrial appendage thrombus detection in patients with persistent atrial fi brillation before cardioversion. Comparison between multidetector computed tomography and transesophageal echocardiography. Acta Cardiol. 2012;67(1):111-2.
De Sutter J, Weytjens C, Willems AM, et al. CHA2DS2-VASc score as a complementary tool for the CHADS2 score in patients admitted with acute heart failure and atrial fi brillation. Practical implications and real-life use of warfarin at discharge: A report from the BIO-HF study. Acta Cardiol. 2012;67(1):112.
Deneke T, Krug J, Schade A, et al. Silent cerebral lesions after left atrial ablation procedures. Heart Rhythm. 2012;9(5Suppl 1):S422.
Di Biase L, Gaita F, Anselmino M, et al. Does the left atrial appendage morphology correlates with the risk of stroke in patients with atrial fibrillation? Result from a multicenter study. Circulation. 2011;124:A10879.
Di Biase L, Gaita F, Anselmino M, et al. Does the left atrial appendage morphology correlates with the risk of stroke in patients with atrial fibrillation? Result from a multicenter study. PACE - Pacing Clin Electrophysiol. 2011;34(11):1317.
Di Biase L, Gaita F, Anselmino M, et al. Does the left atrial appendage morphology correlates with the risk of stroke in patients with atrial fibrillation? Results from a multicenter study. G Ital Cardiol. 2011;12(12Suppl 3):e12.
Di Biase L, Santangeli P, Mohanty P, et al. Delayed cardiac tamponade following catheter ablation of atrial fibrillation with and without warfarin discontinuation: Single center experience. Circulation. 2011;124(21):A14189.
Di Biase L, Tschopp D, Sanchez JE, et al. Catheter ablation of atrial fibrillation without dabigratan discontinuation: Preliminary safety and efficacy data. Circulation. 2011;124(21):A14277.
Di Toro DC, Hadid C, Gallino S, et al. CHADS2 and CHA2DS2-VASC risk scores validation in an atrial fibrilation population. Heart Rhythm. 2012;9(5Suppl 1):S172.
Donze J, Rodondi N, Monney P, et al. Prospective comparison of scores and clinical judgment to predict major bleeding in patients receiving oral anticoagulants. J Gen Intern Med. 2011;26(Suppl 1):S77-8.
Eikelboom J, Synhorst D, Wright R, et al. Efficacy and safety of apixaban compared with aspirin in patients with atrial fibrillation who previously used and discontinued warfarin therapy: A secondary analysis of the AVERROES trial. Eur Heart J. 2011;32:465.
Eikelboom JW, O’Donnell M, Yusuf S, et al. Rationale and design of AVERROES: apixaban versus acetylsalicylic acid to prevent stroke in atrial fibrillation patients who have failed or are unsuitable for vitamin K antagonist treatment. Am Heart J. 2010;159(3):348-53.e1. [pmid: 20211294].
Eitel C, Hindricks G, Sommer P, et al. Dabigatran in patients undergoing catheter ablation for atrial fibrillation. Europace. 2011;13(Suppl 3).
Ellis CR, Streur MM, Nagarakanti R. Safety and efficacy of dabigatran versus warfarin in patients undergoing left atrial catheter ablation. Heart Rhythm. 2012;9(5Suppl 1):S421.
Essebag V, Birnie D, Guerra P, et al. Anticoagulation management PRE and post atrial fibrillation ablation: A survey of Canadian centres. Can J Cardiol. 2010;26(Suppl D):112D.
Fang MC, Go AS, Chang Y. A 5-item score predicted risk for warfarin-associated major hemorrhage in patients with atrial fibrillation. Ann Intern Med. 2011;155(10):JC5-13. [pmid: 22084360].
Fauchier L, Olesen JB, Taillandier S, et al. Validation of the CHA2DS2-VASc score for stroke and thromboembolism risk stratification in patients with atrial fibrillation in a community based cohort study: The LVAF project. Eur Heart J. 2011;32(Suppl 1):466.
Fauchier L, Taillandier S, Lagrenade I, et al. Prognosis in patients with atrial fibrillation and CHA2DS2VASc score=0 in a real world community based cohort study: The Loire Valley Atrial Fibrillation project. Eur Heart J. 2011;32(Suppl 1):7. [pmid: 21246770].
Ferreira J, Ezekowitz MD, Connolly SJ, et al. Dabigatran compared with warfarin in patients with atrial fibrillation and symptomatic heart failure: A subgroup analysis of the re-ly trial. Circulation. 2011;124(21):A10956.
Figini F, Latib A, Chieffo A, et al. Managing patients with an indication for anticoagulant therapy after transcatheter aortic valve implantation. J Am Coll Cardiol. 2012;59(13Suppl 1):E1988.
Flaker G, Ezekowitz M, Yusuf S, et al. Efficacy and Safety of Dabigatran Compared to Warfarin in Patients With Paroxysmal, Persistent, and Permanent Atrial Fibrillation: Results From the RE-LY (Randomized Evaluation of Long-Term Anticoagulation Therapy) Study. J Am Coll Cardiol. 2012;59(9):854-5. [pmid: 22361407].
Flynn RWV, MacDonald TM, Choy AM, et al. When should an atrial fibrillation patient receive anticoagulants following intracerebral haemorrhage?. Pharmacoepidemiol Drug Saf. 2011;20(Suppl 1):S129.
Fosbol EL, Wang T, Piccini J, et al. Comparative effectiveness and safety of antithrombotic therapy in older patients with atrial fibrillation and non-st elevation myocardial infarction (NSTEMI) treated with coronary stenting. J Am Coll Cardiol. 2012;59(13Suppl 1):E1866.
Fountain RB, Holmes DR, Chandrasekaran K, et al. The PROTECT AF (WATCHMAN Left Atrial Appendage System for Embolic PROTECTion in Patients with Atrial Fibrillation) trial. Am Heart J. 2006;151(5):956-61. [pmid: 16644311].
Gallagher AM, Murray-Thomas T, Clemens A, et al. Incidence of vascular outcomes in patients with atrial fibrillation. Blood. 2011;118(21):4223.
Gangireddy S, Coffey JO, Calenda BW, et al. The incidence of stroke after atrial fibrillation ablation in patients on dabigatran. Heart Rhythm. 2012;9(5Suppl 1):S472.
Genovesi S, Santoro A, Fabbrini P, et al. Italian survey on hemorrhagic and thromboemolic risk and oral anticoagulant therapy in a large population of hemodalysis patients with atrial fibrillation. Nephrol Dial Transplant. 2012;27(Suppl 2):ii236.
Goodman SG, Wojdyla DM, White HD, et al. Predictors of major bleeding risk: Insights from the rivaroxaban once-daily oral direct factor XA inhibition compared with vitamin K antagonism for prevention of stroke and embolism trial in atrial fibrillation (Rocket AF). Circulation. 2011;124(21):A16903.
Haines DE, Salazar M, Mead-Salley M, et al. Dabigatran versus warfarin for periprocedural anticoagulation at the time of catheter ablation of atrial fibrillation. Heart Rhythm. 2012;9(5Suppl 1):S171-2.
Han JH, Hwang HJ, Pak HN, et al. Preprocedural transesophageal echocardiography was not necessary for the stroke prevention evaluation in af patient on anticoagulation. Heart Rhythm. 2012;9(5Suppl 1):S347.
Hart RG, Eikelboom J, Yusuf S, et al. Efficacy and safety of the novel oral factor Xa inhibitor apixaban in atrial fibrillation (AF) patients with chronic kidney disease (CKD): The AVERROES trial. Eur Heart J. 2011;32(Suppl 1):6.
Healey JS, Eikelboom J, Wallentin L, et al. The risk of peri-operative bleeding with warfarin compared to two doses of dabigatran: Results from the RE-LY trial. Circulation. 2011;124(21):A12041.
Heinzel FR, Forstner H, Lercher P, et al. Re-evaluating thromboembolic risk in cardiomyopathy patients using CHADS-VASc. Europace. 2011;13(Suppl 3).
Hioki M, Matsuo SM, Narui F, et al. Does continuing warfarin therapy during catheter ablation reduce the thromboembolism in patients with atrial fibrillation?. Heart Rhythm. 2012;9(5Suppl 1):S132.
Ho KW, Ivanov J, Seidelin P, et al. Should anticoagulation therapy be combined with dual antiplatelet therapy in patients with nonvalvular atrial fibrillation following percutaneous coronary intervention?. J Am Coll Cardiol. 2012;59(13Suppl 1):E264.
Honig S, Steinwender C, Lambert T, et al. Significant reduction of bleeding complications after pulmonary vein isolation using different types of anticoagulant strategies. Journal fur Kardiologie. 2011;18(5–6):201-2.
Hori M, Matsumoto M, Tanahashi N, et al. J-ROCKET AF: The safety and efficacy of rivaroxaban for prevention of stroke in Japanese patients with non-valvular atrial fibrillation. J Thromb Haemost. 2011;9(Suppl 2):20. [pmid: 21781238].
Janse P, Theuns D, Bhagwandien R, et al. CHADS2 score does not predict left atrial thrombi before pulmonary vein isolation. Heart Rhythm. 2012;9(5Suppl 1):S221.
Kaatz S, Douketis JD, White RH, et al. Can the CHADS2 score predict postoperative stroke risk in patients with chronic atrial fibrillation who are having elective non-cardiac surgery?. J Thromb Haemost. 2011;9(Suppl 2):635.
Kazemimood R, Mirocha J, Shiota T. Clinical and echocardiograohic factors that are associated with left atrial or left atrial appendage thrombus or spontaneous echo contrast in patients with atrial fibrillation. J Am Coll Cardiol. 2012;59(13Suppl 1):E677.
Kefer J, Vermeersch P, De Potter T, et al. Left atrial appendage closure with Amplatzer Cardiac Plug for stroke prevention in atrial fi brillation: Initial Belgian experience. Acta Cardiol. 2012;67(1):130-1.
Konduru SV, Cheema A, Jones P, et al. Heparinization during catheter ablation for atrial fibrillation: A comparison of patients treated with dabigatran vs patients maintained on warfarin. Heart Rhythm. 2012;9(5Suppl 1):S200.
Kosiuk J, Bode K, Kornej J, et al. Left ventricular diastolic dysfunction correlates with thromboembolic risk in atrial fibrillation. Heart Rhythm. 2012;9(5Suppl 1):S462.
Krishnamoorthy S, Khoo C, Lim S, et al. Prognostic role of plasma von willebrand factor and soluble e-selectin levels for future cardiovascular events in a ‘real world’ community cohort of patients with atrial fibrillation. Heart Rhythm. 2012;9(5Suppl 1):S421-2.
Kuwahara T, Takahashi Y, Okubo K, et al. Prevention of periprocedural stroke and management of hemorrhagic complication in atrial fibrillation ablation under continuing warfarin administration. Heart Rhythm. 2012;9(5Suppl 1):S277.
Lamberts M, Hansen M, Olesen J, et al. Risk of major bleeding after initiation of dual or triple antithrombotic drug therapy in atrial fibrillation patients following myocardial infarction and coronary stenting: A nationwide cohort study. J Am Coll Cardiol. 2012;59(13Suppl 1):E512.
Lassila R, Munsterhjelm E, Joutsi-Korhonen L, et al. Laboratory follow-up and clinical management of a patient case with severe bleeding complication on dabigatran for atrial fibrillation. J Thromb Haemost. 2011;9(Suppl 2):840-1.
Lee SJ, Hwang HJ, Pak HN, et al. The safety and efficacy of oral anticoagulation in patients with healed ulcer on vitamin K antagonist treatment. Heart Rhythm. 2012;9(5Suppl 1):S243.
Lip GY, Yusuf S, Eikelboom J, et al. Impact of treatment with apixaban and aspirin in patients with atrial fibrillation in relation to the CHADS2 and CHA2DS2-vasc scores: The averroes study. Circulation. 2011;124(21):A15542.
Lip GYH, Halperin JL, Petersen P, et al. Safety and tolerability of the oral factor Xa inhibitor, YM150 vs. warfarin in 1297 patients with nonvalvular atrial fibrillation: A dose confirmation study (OPAL-2). J Thromb Haemost. 2011;9(Suppl 2):748. [pmid: 21255247].
Lip GYH, Larsen TB, Skjoth F, et al. Indirect Comparisons of New Oral Anticoagulant Drugs for Efficacy and Safety When Used for Stroke Prevention in Atrial Fibrillation. J Am Coll Cardiol. 2012;60(8):738-46. [pmid: 22575324].
Lopes RD, Alexander JH, Al-Khatib SM, et al. Apixaban for reduction in stroke and other ThromboemboLic events in atrial fibrillation (ARISTOTLE) trial: design and rationale. Am Heart J. 2010;159(3):331-9. [pmid: 20211292].
Lopes RD, Al-Khatib S, Wallentin L, et al. Efficacy and safety of apixaban compared with warfarin according to CHADS2 and hasbled risk scores for stroke prevention in atrial fibrillation. J Am Coll Cardiol. 2012;59(13Suppl 1):E574.
Maes F, Almpanis C, Scavee C, et al. Underuse of anticoagulation in older patients with atrial fbrillation. Acta Cardiol. 2011;66(1):95.
Mahaffey KW, White HD, Nessel CC, et al. Ischemic cardiac outcomes in patients with af treated with vitamin k antagonism or factor XA inhibition: Results from the rocket AF Trial. Circulation. 2011;124(21):A13482.
Makino N, Nishino M, Tanaka A, et al. Left atrial appendage morphology determined by computed tomography can predict high risk patient for embolism with atrial fibrillation. Circulation. 2011;124(21):A11570.
Mant JW, Richards SH, Hobbs FD, et al. Protocol for Birmingham Atrial Fibrillation Treatment of the Aged study (BAFTA): a randomised controlled trial of warfarin versus aspirin for stroke prevention in the management of atrial fibrillation in an elderly primary care population [ISRCTN89345269]. BMC Cardiovasc Disord. 2003;3:9. [pmid: 12939169].
Marazzi R, Ponti RD, Doni L, et al. Prevalence of left atrial appendage thrombi onmultidetector computed tomography as compared with transesophageal echocardiography and predisposing factors in candidates for pulmonary vein isolation. J Interv Card Electrophysiol. 2012;33(3):287.
Martinek M, Sigmund E, Lemes C, et al. Asymptomatic cerebral lesions in pulmonary vein isolation under therapeutic anticoagulation. Heart Rhythm. 2012;9(5Suppl 1):S132-3.
Mendoza I, Helguera M, Baez-Escudero J, et al. Atrial fibrillation ablation on uninterrupted anticoagulation with dabigatran versus warfarin. Heart Rhythm. 2012;9(5Suppl 1):S270-1.
Muhammad MIA. Role of video-assisted thoracoscopy in the management of stroke. Heart Surgery Forum. 2012;15(Suppl 1):S45.
Murtaza G, Von Ballmoos MW, Masroor S. Cryomaze for sole-therapy atrial fibrillation. Circulation. 2011;124(21):A18025.
Novakovic-Anucin SL, Gnip S, Povazan L, et al. Efficacy of combined antiplatelet therapy in preventing thromboembolism in patients with atrial fibrillation. J Thromb Haemost. 2011;9(Suppl 2):887.
Oldgren J, Alings M, Darius H. Chads(2) score predicted bleeding and death in atrial fibrillation treated with anticoagulants. Ann Intern Med. 2012;156(8):JC4-13. [pmid: 22508753].
Oldgren J, Hijazi Z, Andersson U, et al. Cystatin c is prognostic for stroke, death and bleeding in atrial fibrillation-a rely substudy. Circulation. 2011;124(21):A12492.
Olesen JB, Lip GYH, Lane DA, et al. Rates of thromboembolism and bleeding with antithrombotic treatment in patients with atrial fibrillation: A nullreal worldnull nationwide cohort study. Eur Heart J. 2011;32(Suppl 1):465.
Page S, Cantor E, Sporton S, et al. Lower heparin doses are required to achieve therapeutic anticoagulation in patients undergoing catheter ablation for atrial fibrillation on uninterrupted warfarin. J Interv Card Electrophysiol. 2012;33(3):339.
Para O, Pieralli F, Lualdi C, et al. Management of oral anticoagulation at discharge in elderly patients with atrial fibrillation hospitalized in an Internal Medicine ward: An observational study. Ital J Med. 2012;6(1Suppl 1):105-6.
Perros N, Schneck M. Resumption of antithrombotic therapy following hemorrhagic stroke in patients with atrial fibrillation. Neurology. 2012;78(1):P02.206.
Piccini JP, Stevens SR, Patel MR, et al. Renal dysfunction is a potent predictor of stroke and systemic embolism among individuals with atrial fibrillation: Results from the Rocket AF trial. Circulation. 2011;124(21):A17137.
Poli D, Antonucci E, Grifoni E, et al. Low bleeding risk of very old atrial fibrillation women on VKA treatment: Results from a prospective collaborative study. on behalf of the ad hoc study group of FCSA. J Thromb Haemost. 2011;9(Suppl 2):886.
Providencia RA, Botelho A, Trigo J, et al. CHADSEcho: A new stroke risk classification for patients with atrial fibrillation. Europace. 2011;13(Suppl 3).
Providencia RA, Botelho A, Trigo J, et al. Decreased left atrial appendage deformation: A new predictor of stroke risk in patients with atrial fibrillation?. Europace. 2011;13(Suppl 3).
Providencia RA, Botelho A, Trigo J, et al. Importance of left ventricle dysfunction quantification for thromboembolic risk prediction in patients with atrial fibrillation. Eur J Heart Fail Suppl. 2011;10(Suppl 1):S15-6.
Providencia RA, Botelho A, Trigo J, et al. Left atrial deformation in atrial fibrillation: Which parameter and segment are the best predictors of thromboembolic risk?. Europace. 2011;13(Suppl 3).
Pump A, Szapary L, Komoly S, et al. Advantages of CHA2DS2-VASC scheme, a novel risk factors score to predict stroke in patients with atrial fibrillation. J Am Coll Cardiol. 2012;59(13Suppl 1):E1698.
Rajdev A, Bradley J, Petrini J, et al. A community experience of the novel anticoagulant pradaxa. J Am Coll Cardiol. 2012;59(13Suppl 1):E601.
Reynolds MW, Fahrbach K, Hauch O, et al. Warfarin anticoagulation and outcomes in patients with atrial fibrillation: a systematic review and metaanalysis. Chest. 2004;126(6):1938-45. [pmid: 15596696].
Roldan V, Gallego P, Marin F, et al. The HAS-BLED score also predicts cardiovascular events and mortality in atrial fibrillation. Eur Heart J. 2011;32(Suppl 1):322.
Roldan V, Marin F, Gallego P, et al. Usefulness for CHA2DS2-VASc score for predicting adverse events in high risk anticoagulated patients with atrial fibrillation. Eur Heart J. 2011;32(Suppl 1):464.
Romanov A, Pokushalov E, Corbucci G, et al. Ablation of paroxysmal and persistent atrial fibrillation: 1-year follow-up through continuous subcutaneous monitoring. Europace. 2011;13(Suppl 3).
Romanov A, Pokushalov E, Corbucci G, et al. Ablation of paroxysmal and persistent atrial fibrillation: 1-year follow-up through implantable ecg recorder. Pacing Clin Electrophysiol. 2011;34(11):1308.
Roversi S, Malavasi V, D’Ascenzo F, et al. Picking the best novel oral anticoagulant for atrial fibrillation: Evidence from a warfarin-controlled network meta-analysis. J Am Coll Cardiol. 2012;59(13Suppl 1):E598.
Rowley CP, Bradford NS, Bernard ML, et al. Complications of atrial fibrillation ablation in patients anticoagulated with dabigatran compared to warfarin. Heart Rhythm. 2012;9(5Suppl 1):S201.
Saxena R, Koudstaal P. Anticoagulants versus antiplatelet therapy for preventing stroke in patients with nonrheumatic atrial fibrillation and a history of stroke or transient ischemic attack. Cochrane Database Syst Rev. 2004;(4):CD000187. [pmid: 15494992].
Saxena R, Koudstaal PJ. Anticoagulants for preventing stroke in patients with nonrheumatic atrial fibrillation and a history of stroke or transient ischaemic attack. Cochrane Database Syst Rev. 2004;(2):CD000185. [pmid: 15106146].
Schade A, Krug J, Stahl C, et al. Left atrial appendage occlusion using the watchman device in a high risk population: Is there a significant risk of periprocedural cerebral stroke or microembolism?. Heart Rhythm. 2012;9(5Suppl 1):S317.
Schlitt A, Rubboli A, Lathela H, et al. AFCAS, a prospective multicenter registry of patients with atrial fibrillation undergoing coronary artery stenting: Comparison of CHADS2-with CHA2DS2-VASc score. Circulation. 2011;124(21):A12001.
Seet R, Rabinstein A, Christianson T, et al. Life-time bleeding events among stroke patients with atrial fibrillation during warfarin treatment: A population-based cohort study. Neurology. 78:PD2.010.
Shim J, Uhm JS, Hwang HJ, et al. Larger left atrial appendage is an independent predictor of stroke in patients with atrial fibrillation. Circulation. 2011;124(21):A16425.
Sick PB, Turi Z, Grube E, et al. Stroke prevention in non-valvular atrial fibrillation: Long-term results after 6 years of the WATCHMAN left atrial appendage occlusion pilot study. Eur Heart J. 2011;32(Suppl 1):468.
Sigmund E, Lemes C, Derndorfer M, et al. Asymptomatic cerebral lesions in pulmonary vein isolation under therapeutic anticoagulation. J Interv Card Electrophysiol. 2012;33(3):286.
Siu CW, Jim MH, Lau CP, et al. Low molecular weight heparin versus unfractionated heparin for thromboprophylaxis in patients with acute atrial fibrillation: a randomized control trial. Acute Card Care. 2011;13(3):196-8. [pmid: 21517667].
Snipelisky D, Kauffman C, Kusumoto F. A comparison of bleeding complications post ablation between warfarin and dabigatran. Heart Rhythm. 2012;9(5Suppl 1):S203.
Sulke AN, Podd S, Sallomi DF, et al. MRI assessed brain abnormality in patients who have undergone pulmonary vein isolation: A randomised comparison of phased multi-electrode radiofrequency ablation (PVAC(trademark)) or conventional lasso guided irrigated radiofrequency ablation techniques. Heart Rhythm. 2012;9(5Suppl 1):S391.
Tamura H, Watanabe T, Nishiyama S, et al. Left atrial appendage wall velocity measured by transthoracic echocardiography is a feasible marker for predicting poor prognosis in patients with cardioembolic stroke. Circulation. 2011;124(21):A12289.
Tamura H, Watanabe T, Nishiyama S, et al. Left atrial appendage wall velocity obtained by transthoracic echocardiography may be a feasible parameter to detect high risk stroke patients despite low CHADS(;2); Score. Circulation. 2011;124(21):A11896.
Timcenko M, Volceka D, Skorodumovs A, et al. Practical aspects of cardioembolic stroke prevention in patients eligible and uneligible for warfarin therapy. Pacing Clin Electrophysiol. 2011;34(11):1384-5.
Toda E, Lip GYH, Uchiyama S, et al. Use of the CHADS2 and CHA2DS2-VASC score in Japanese patients with atrial fibrillation: A sub-analysis of the Japan thrombosis registry for atrial fibrillation, coronary or cerebrovascular events (J-trace). J Am Coll Cardiol. 2012;59(13Suppl 1):E674.
Topinkova E, Novakova M, Chamradova MK, et al. Difficult choices: Antithrombotic treatment for atrial fibrillation in frail geriatric patients. Eur Geriatr Med. 2011;2(Suppl 1):S9-10.
Tsadok MA, Jackevicius C, Rahme E, et al. Sex differences in risk factors, treatment patterns and clinical outcomes of stroke among patients with atrial fibrillation. Circulation. 2011;124(21):A13626.
Underwood JM, Rogers KC, Pham M, et al. Evaluation of bleeding risk using HAS-BLED scoring in patients with atrial fibrillation receiving enoxaparin bridging therapy. Pharmacotherapy. 2011;31(10):409e.
Van Der Zee SA, Reddy VY, Doshi SK. Peri-device flow after percutaneous closure of the left atrial appendage: One-year follow-up in 76 patients. Heart Rhythm. 2012;9(5Suppl 1):S127-8.
van Walraven C, Hart RG, Connolly S, et al. Effect of age on stroke prevention therapy in patients with atrial fibrillation: the atrial fibrillation investigators. Stroke. 2009;40(4):1410-6. [pmid: 19182090].
van Walraven C, Hart RG, Singer DE, et al. Oral anticoagulants vs aspirin in nonvalvular atrial fibrillation: an individual patient meta-analysis. JAMA. 2002;288(19):2441-8. [pmid: 12435257].
Ward MA, Biddle AK. Cost-effectiveness analysis of dabigatran compared to warfarin for stroke prevention in atrial fibrillation in a medicare population. Value Health. 2012;15(4):A121.
Weimar T, Vosseler M, Czesla M, et al. Endoscopic approach for epicardial bipolar radiofrequency ablation in the surgical treatment of lone atrial fibrillation: Towards a revision of treatment strategies. Innovations: Technology and Techniques in Cardiothoracic and Vascular Surgery. 2012;7(2):129.
Wieloch M, Jonsson K, Svensson PJ. Correlations between estimated glomerular filtration rate, major bleeding and thromboembolic complications in patients on anticoagulation treatment with warfarin. Circulation. 2011;124(21):A15529.
Willens HJ, Nelson K, De Nicco A, et al. A comparison of the correlation of CHADS(2) and CHA(2)DS(2)-VASc risk score and category with transesophageal echocardiography risk factors for thromboembolism. J Am Soc Echocardiogr. 2012;25(6):B63.
Wilson WW, Wilson W. Enoxaparin bridge therapy in patients with nonvalvular atrial fibrillation: A ten year retrospective analysis. J Am Coll Cardiol. 2012;59(13Suppl 1):E605.
Yamaji H, Murakami T, Kawamura H, et al. Safety of dabigatran for atrial fibrillation ablation as a periprocedural anticoagulation strategy. Heart Rhythm. 2012;9(5Suppl 1):S170.
Yamashita E, Sasaki T, Tsukada N, et al. CHA2DS2-VASc score for screening of thromboembolic risk prior to atrial fibrillation ablation: Comparison to CHADS2 scoring system. J Am Soc Echocardiogr. 2012;25(6):B64.
Yamashita E, Sasaki T, Tsukada N, et al. Left atrial appendage dysfunction in female patients prior to catheter ablation for atrial fibrillation. J Am Soc Echocardiogr. 2012;25(6):B65.
Yang F, Xu X, Winkelmayer W, et al. Warfarin use and bleeding risk in veterans with incident atrial fibrillation and severe chronic kidney disease: The treat-AF study. Heart Rhythm. 2012;9(5Suppl 1):S312.
You JH, Tsui KK, Wong RS, et al. Improve warfarin therapy or use dabigatran for patients with atrial fibrillation - A cost-effectiveness analysis. J Clin Pharmacol. 2011;51(9):1334.
Zecchin M, Bardari S, Vitali Serdoz L, et al. Anticoagulant therapy in patients with atrial fibrillation according to CHA2DS2 VASc score: What will change?. Europace. 2011;13(Suppl 3).

## Population Is Not Patients With Nonvalvular Atrial Fibrillation

al-Khadra AS. Implantation of pacemakers and implantable cardioverter defibrillators in orally anticoagulated patients. Pacing Clin Electrophysiol. 2003;26(1Pt2):511-4. [pmid: 12687880].
Alonso A, Tang W, Agarwal SK, et al. Hemostatic markers are associated with the risk and prognosis of atrial fibrillation: The ARIC study. Int J Cardiol. 2012;155(2):217-22. [pmid: 20965585].
Andersen KK, Olsen TS. Reduced poststroke mortality in patients with stroke and atrial fibrillation treated with anticoagulants: results from a Danish quality-control registry of 22,179 patients with ischemic stroke. Stroke. 2007;38(2):259-63. [pmid: 17194876].
Bande D, Hossain S, Newman W, et al. Incidence of thromboembolic and bleeding complications in anticoagulated patients undergoing colonoscopy - A retrospective study. Am J Gastroenterol. 2011;106(Suppl 2):S523-4.
Blacker DJ, Wijdicks EF, McClelland RL. Stroke risk in anticoagulated patients with atrial fibrillation undergoing endoscopy. Neurology. 2003;61(7):964-8. [pmid: 14557569].
Brandt RR, Neumann T, Neuzner J, et al. Transcatheter closure of atrial septal defect and patent foramen ovale in adult patients using the Amplatzer occlusion device: no evidence for thrombus deposition with antiplatelet agents. J Am Soc Echocardiogr. 2002;15(10Pt1):1094-8. [pmid: 12373252].
Cano O, Munoz B, Tejada D, et al. Evaluation of a new standardized protocol for the perioperative management of chronically anticoagulated patients receiving implantable cardiac arrhythmia devices. Heart Rhythm. 2012;9(3):361-7. [pmid: 22001709].
Chan TY, Miu KY. Hemorrhagic complications of anticoagulant therapy in Chinese patients. J Chin Med Assoc. 2004;67(2):55-62. [pmid: 15146899].
Chandratheva A, Geraghty OC, Luengo-Fernandez R, et al. ABCD2 score predicts severity rather than risk of early recurrent events after transient ischemic attack. Stroke. 2010;41(5):851-6. [pmid: 20299668].
Cheng A, Nazarian S, Brinker JA, et al. Continuation of warfarin during pacemaker or implantable cardioverter-defibrillator implantation: a randomized clinical trial. Heart Rhythm. 2011;8(4):536-40. [pmid: 21147261].
Chung N, Jeon HK, Lien LM, et al. Safety of edoxaban, an oral factor Xa inhibitor, in Asian patients with non-valvular atrial fibrillation. Thromb Haemost. 2011;105(3):535-44. [pmid: 21136011].
Constans M, Santamaria A, Mateo J, et al. Low-molecular-weight heparin as bridging therapy during interruption of oral anticoagulation in patients undergoing colonoscopy or gastroscopy. Int J Clin Pract. 2007;61(2):212-7. [pmid: 17263709].
Corrado G, Sgalambro A, Mantero A, et al. Thromboembolic risk in atrial flutter. The FLASIEC (FLutter Atriale Societa Italiana di Ecografia Cardiovascolare) multicentre study. Eur Heart J. 2001;22(12):1042-51. [pmid: 11428839].
Dayani PN, Grand MG. Maintenance of warfarin anticoagulation for patients undergoing vitreoretinal surgery. Arch Ophthalmol. 2006;124(11):1558-65. [pmid: 17102002].
de Souza MV, Duarte MM, Coeli CM, et al. Atrial fibrillation & hyperthyroidism: relation between transesophageal markers of a thrombogenic milieu and clinical risk factors for thromboembolism. Clin Endocrinol (Oxf). 2011;76(3):448-53. [pmid: 21950838].
Deerhake JP, Merz JC, Cooper JV, et al. The duration of anticoagulation bridging therapy in clinical practice may significantly exceed that observed in clinical trials. J Thromb Thrombolysis. 2007;23(2):107-13. [pmid: 17221327].
Dotan ZA, Mor Y, Leibovitch I, et al. The efficacy and safety of perioperative low molecular weight heparin substitution in patients on chronic oral anticoagulant therapy undergoing transurethral prostatectomy for bladder outlet obstruction. J Urol. 2002;168(2):610-3. discussion 614. [pmid: 12131319].
Douketis JD, Johnson JA, Turpie AG. Low-molecular-weight heparin as bridging anticoagulation during interruption of warfarin: assessment of a standardized periprocedural anticoagulation regimen. Arch Intern Med. 2004;164(12):1319-26. [pmid: 15226166].
Eisele R, Melzer N, Englert C, et al. Bridging with the Low molecular weight heparin certoparin in patients requiring temporary discontinuation of oral anticoagulation - the non-interventional, retrospective REMEMBER study. Thromb Res. 2012;130(5):788-92. [pmid: 22281069].
Evans A, Perez I, Yu G, et al. Secondary stroke prevention in atrial fibrillation: lessons from clinical practice. Stroke. 2000;31(9):2106-11. [pmid: 10978038].
Finlay M, Sawhney V, Schilling R, et al. Uninterrupted warfarin for periprocedural anticoagulation in catheter ablation of typical atrial flutter: a safe and cost-effective strategy. J Cardiovasc Electrophysiol. 2010;21(2):150-4. [pmid: 19793142].
Fjeldheim R, Welch J, Koo J. A retrospective review of short-term outcomes after switching patients from clopidogrel to alternative antiplatelet therapy. Hosp Pharm. 2009;44(12):1103-11.
Flanigan DC, Muchow R, Orwin J, et al. Arthroscopy on anticoagulated patients: A retrospective evaluation of postoperative complications. Orthopedics. 2010;33(2):82-6. [pmid: 20192141].
Fu AD, McDonald HR, Williams DF, et al. Anticoagulation with warfarin in vitreoretinal surgery. Retina. 2007;27(3):290-5. [pmid: 17460583].
Fukuda Y, Yoshida T, Inage T, et al. Long-term results of the maze procedure on left ventricular function for persistent atrial fibrillation associated with mitral valve disease. Heart Vessels. 2012;27(1):53-7. [pmid: 21331619].
Gronefeld GC, Wegener F, Israel CW, et al. Thromboembolic risk of patients referred for radiofrequency catheter ablation of typical atrial flutter without prior appropriate anticoagulation therapy. Pacing Clin Electrophysiol. 2003;26(1Pt2):323-7. [pmid: 12687838].
Halbritter KM, Wawer A, Beyer J, et al. Bridging anticoagulation for patients on long-term vitamin-K-antagonists. A prospective 1 year registry of 311 episodes. J Thromb Haemost. 2005;3(12):2823-5. [pmid: 16359528].
Halkes PH, van Gijn J, Kappelle LJ, et al. Medium intensity oral anticoagulants versus aspirin after cerebral ischaemia of arterial origin (ESPRIT): a randomised controlled trial. Lancet Neurol. 2007;6(2):115-24. [pmid: 17239798].
Hallevi H, Albright KC, Martin-Schild S, et al. Anticoagulation after cardioembolic stroke: to bridge or not to bridge?. Arch Neurol. 2008;65(9):1169-73. [pmid: 18625852].
Handke M, Harloff A, Hetzel A, et al. Left atrial appendage flow velocity as a quantitative surrogate parameter for thromboembolic risk: determinants and relationship to spontaneous echocontrast and thrombus formation--a transesophageal echocardiographic study in 500 patients with cerebral ischemia. J Am Soc Echocardiogr. 2005;18(12):1366-72. [pmid: 16376768].
Inatomi Y, Kimura K, Yonehara T, et al. DWI abnormalities and clinical characteristics in TIA patients. Neurology. 2004;62(3):376-80. [pmid: 14872016].
Jessup DB, Coletti AT, Muhlestein JB, et al. Elective coronary angiography and percutaneous coronary intervention during uninterrupted warfarin therapy. Catheter Cardiovasc Interv. 2003;60(2):180-4. [pmid: 14517922].
Kagansky N, Knobler H, Rimon E, et al. Safety of anticoagulation therapy in well-informed older patients. Arch Intern Med. 2004;164(18):2044-50. [pmid: 15477441].
Kanderian AS, Gillinov AM, Pettersson GB, et al. Success of surgical left atrial appendage closure: assessment by transesophageal echocardiography. J Am Coll Cardiol. 2008;52(11):924-9. [pmid: 18772063].
Karjalainen PP, Porela P, Ylitalo A, et al. Safety and efficacy of combined antiplatelet-warfarin therapy after coronary stenting. Eur Heart J. 2007;28(6):726-32. [pmid: 17267456].
Khositseth A, Cabalka AK, Sweeney JP, et al. Transcatheter Amplatzer device closure of atrial septal defect and patent foramen ovale in patients with presumed paradoxical embolism. Mayo Clin Proc. 2004;79(1):35-41. [pmid: 14708946].
Khurram Z, Chou E, Minutello R, et al. Combination therapy with aspirin, clopidogrel and warfarin following coronary stenting is associated with a significant risk of bleeding. J Invasive Cardiol. 2006;18(4):162-4. [pmid: 16729401].
Krane LS, Laungani R, Satyanarayana R, et al. Robotic-assisted radical prostatectomy in patients receiving chronic anticoagulation therapy: role of perioperative bridging. Urology. 2008;72(6):1351-5. [pmid: 19041033].
Krumsdorf U, Ostermayer S, Billinger K, et al. Incidence and clinical course of thrombus formation on atrial septal defect and patient foramen ovale closure devices in 1,000 consecutive patients. J Am Coll Cardiol. 2004;43(2):302-9. [pmid: 14736453].
Lamberts M, Olesen JB, Ruwald MH, et al. Bleeding after Initiation of Multiple Antithrombotic Drugs, Including Triple Therapy, in Atrial Fibrillation Patients Following Myocardial Infarction and Coronary Intervention: A Nationwide Cohort Study. Circulation. 2012;126(10):1185-93. [pmid: 22869839].
de Lavitola PL, Spina GS, Sampaio RO, et al. Bleeding during oral anticoagulant therapy: warning against a greater hazard. Arq Bras Cardiol. 2009;93(2):174-9. [pmid: 19838496].
Lawrentschuk N, Kariappa S, Kaye AH. Spontaneous intracerebral haemorrhages-warfarin as a risk factor. J Clin Neurosci. 2003;10(5):550-2. [pmid: 12948457].
Leitman M, Sidenko S, Peleg E, et al. Improved detection of spontaneous echo contrast in the aorta with tissue Doppler imaging. Echocardiography. 2004;21(6):503-8. [pmid: 15298685].
Leung CS, Tam KM. Antithrombotic treatment of atrial fibrillation in a regional hospital in Hong Kong. Hong Kong Med J. 2003;9(3):179-85. [pmid: 12777653].
Long AL, Bendz L, Horvath MM, et al. Characteristics of ambulatory anticoagulant adverse drug events: A descriptive study. Thromb J. 2010;8:5. [pmid: 20167114].
Lopes RD, Elliott LE, White HD, et al. Antithrombotic therapy and outcomes of patients with atrial fibrillation following primary percutaneous coronary intervention: results from the APEX-AMI trial. Eur Heart J. 2009;30(16):2019-28. [pmid: 19502623].
MacDonald LA, Meyers S, Bennett CL, et al. Post-cardiac catheterization access site complications and low-molecular -weight heparin following cardiac catheterization. J Invasive Cardiol. 2003;15(2):60-2. [pmid: 12556615].
Malato A, Saccullo G, Lo Coco L, et al. Patients requiring interruption of long-term oral anticoagulant therapy: the use of fixed sub-therapeutic doses of low-molecular-weight heparin. J Thromb Haemost. 2010;8(1):107-13. [pmid: 19817996].
Matchar DB, Jacobson A, Dolor R, et al. Effect of home testing of international normalized ratio on clinical events. N Engl J Med. 2010;363(17):1608-20. [pmid: 20961244].
Mattichak SJ, Reed PS, Gallagher MJ, et al. Evaluation of safety of warfarin in combination with antiplatelet therapy for patients treated with coronary stents for acute myocardial infarction. J Interv Cardiol. 2005;18(3):163-6. [pmid: 15966919].
McGrath ER, Kapral MK, Fang J, et al. Which Risk Factors Are More Associated With Ischemic Stroke Than Intracerebral Hemorrhage in Patients With Atrial Fibrillation?. Stroke. 2012;43(8):2048-54. [pmid: 22618379].
Nguyen MC, Lim YL, Walton A, et al. Combining warfarin and antiplatelet therapy after coronary stenting in the Global Registry of Acute Coronary Events: is it safe and effective to use just one antiplatelet agent?. Eur Heart J. 2007;28(14):1717-22. [pmid: 17562671].
Nikolsky E, Mehran R, Dangas GD, et al. Outcomes of patients treated with triple antithrombotic therapy after primary percutaneous coronary intervention for ST-elevation myocardial infarction (from the Harmonizing Outcomes With Revascularization and Stents in Acute Myocardial Infarction [HORIZONS-AMI] trial). Am J Cardiol. 2012;109(6):831-8. [pmid: 22196778].
Omran H, Bauersachs R, Rubenacker S, et al. The HAS-BLED score predicts bleedings during bridging of chronic oral anticoagulation. Results from the national multicentre BNK Online bRiDging REgistRy (BORDER). Thromb Haemost. 2012;108(1):65-73. [pmid: 22534746].
Ono A, Fujita T. Low-intensity anticoagulation for stroke prevention in elderly patients with atrial fibrillation: efficacy and safety in actual clinical practice. J Clin Neurosci. 2005;12(8):891-4. [pmid: 16271478].
Orford JL, Fasseas P, Melby S, et al. Safety and efficacy of aspirin, clopidogrel, and warfarin after coronary stent placement in patients with an indication for anticoagulation. Am Heart J. 2004;147(3):463-7. [pmid: 14999195].
Parvathaneni L, Mahenthiran J, Jacob S, et al. Comparison of tissue Doppler dynamics to Doppler flow in evaluating left atrial appendage function by transesophageal echocardiography. Am J Cardiol. 2005;95(8):1011-4. [pmid: 15820180].
Perez-Gomez F, Alegria E, Berjon J, et al. Comparative effects of antiplatelet, anticoagulant, or combined therapy in patients with valvular and nonvalvular atrial fibrillation: a randomized multicenter study. J Am Coll Cardiol. 2004;44(8):1557-66. [pmid: 15489085].
Perez-Gomez F, Iriarte JA, Zumalde J, et al. Antithrombotic therapy in elderly patients with atrial fibrillation: effects and bleeding complications: a stratified analysis of the NASPEAF randomized trial. Eur Heart J. 2007;28(8):996-1003. [pmid: 17158523].
Phan TG, Koh M, Wijdicks EF. Safety of discontinuation of anticoagulation in patients with intracranial hemorrhage at high thromboembolic risk. Arch Neurol. 2000;57(12):1710-3. [pmid: 11115236].
Poci D, Hartford M, Karlsson T, et al. Role of the CHADS2 score in acute coronary syndromes - risk of subsequent death or stroke in patients with and without atrial fibrillation. Chest. 2012;141(6):1431-40. [pmid: 22016485].
Pozzoli M, Selva A, Skouse D, et al. Visualization of left atrial appendage and assessment of its function by transthoracic second harmonic imaging and contrast-enhanced pulsed Doppler. Eur J Echocardiogr. 2002;3(1):13-23. [pmid: 12067529].
Rossini R, Musumeci G, Lettieri C, et al. Long-term outcomes in patients undergoing coronary stenting on dual oral antiplatelet treatment requiring oral anticoagulant therapy. Am J Cardiol. 2008;102(12):1618-23. [pmid: 19064015].
Rubboli A, Magnavacchi P, Guastaroba P, et al. Antithrombotic management and 1-year outcome of patients on oral anticoagulation undergoing coronary stent implantation (from the Registro Regionale Angioplastiche Emilia-Romagna Registry). Am J Cardiol. 2012;109(10):1411-7. [pmid: 22342850].
Saccullo G, Malato A, Raso S, et al. Cancer patients requiring interruption of long-term warfarin because of surgery or chemotherapy induced thrombocytopenia: the use of fixed sub-therapeutic doses of low-molecular weight heparin. Am J Hematol. 2012;87(4):388-91. [pmid: 22374861].
Saokaew S, Sapoo U, Nathisuwan S, et al. Anticoagulation control of pharmacist-managed collaborative care versus usual care in Thailand. Int J Clin Pharm. 2012;34(1):105-12. [pmid: 22203442].
Sarafoff N, Ndrepepa G, Mehilli J, et al. Aspirin and clopidogrel with or without phenprocoumon after drug eluting coronary stent placement in patients on chronic oral anticoagulation. J Intern Med. 2008;264(5):472-80. [pmid: 18624903].
Saxena R, Lewis S, Berge E, et al. Risk of early death and recurrent stroke and effect of heparin in 3169 patients with acute ischemic stroke and atrial fibrillation in the International Stroke Trial. Stroke. 2001;32(10):2333-7. [pmid: 11588322].
Silverman IE, Kiernan FJ, Kelsey AM, et al. Initial experience with a transcatheter septal closure system for secondary stroke prevention in patients with interatrial septal defects. Conn Med. 2003;67(3):135-44. [pmid: 12687787].
Sorescu D, Turk RJ, Cain M, et al. Clinical and transthoracic echocardiographic predictors of abnormal transesophageal findings in patients with suspected cardiac source of embolism. Am J Med Sci. 2003;326(1):31-4. [pmid: 12861123].
Spyropoulos AC, Frost FJ, Hurley JS, et al. Costs and clinical outcomes associated with low-molecular-weight heparin vs unfractionated heparin for perioperative bridging in patients receiving long-term oral anticoagulant therapy. Chest. 2004;125(5):1642-50. [pmid: 15136371].
Spyropoulos AC, Turpie AG, Dunn AS, et al. Clinical outcomes with unfractionated heparin or low-molecular-weight heparin as bridging therapy in patients on long-term oral anticoagulants: the REGIMEN registry. J Thromb Haemost. 2006;4(6):1246-52. [pmid: 16706967].
Stahrenberg R, Edelmann F, Haase B, et al. Transthoracic echocardiography to rule out paroxysmal atrial fibrillation as a cause of stroke or transient ischemic attack. Stroke. 2011;42(12):3643-5. [pmid: 21998056].
Udell JA, Wang JT, Gladstone DJ, et al. Anticoagulation after anterior myocardial infarction and the risk of stroke. PLoS One. 2010;5(8):e12150. [pmid: 20730096].
Vincelj J, Sokol I, Jaksic O. Prevalence and clinical significance of left atrial spontaneous echo contrast detected by transesophageal echocardiography. Echocardiography. 2002;19(4):319-24. [pmid: 12047783].
Yarmohammadi H, Varr BC, Puwanant S, et al. Role of CHADS(2) Score in Evaluation of Thromboembolic Risk and Mortality in Patients With Atrial Fibrillation Undergoing Direct Current Cardioversion (from the ACUTE Trial Substudy). Am J Cardiol. 2012;110(2):222-6. [pmid: 22503581].
Zanetti G, Kartalas-Goumas I, Montanari E, et al. Extracorporeal shockwave lithotripsy in patients treated with antithrombotic agents. J Endourol. 2001;15(3):237-41. [pmid: 11339387].

## No Intervention/Comparator of Interest

Abdelhafiz AH, Wheeldon NM. Results of an open-label, prospective study of anticoagulant therapy for atrial fibrillation in an outpatient anticoagulation clinic. Clin Ther. 2004;26(9):1470-8. [pmid: 15531009].
Abdelhafiz AH, Wheeldon NM. Risk factors for bleeding during anticoagulation of atrial fibrillation in older and younger patients in clinical practice. Am J Geriatr Pharmacother. 2008;6(1):1-11. [pmid: 18396243].
Ad N, Henry L, Hunt S, et al. Do we increase the operative risk by adding the Cox Maze III procedure to aortic valve replacement and coronary artery bypass surgery?. J Thorac Cardiovasc Surg. 2012;143(4):936-43. [pmid: 22244503].
Ahmed I, Gertner E, Nelson WB, et al. Continuing warfarin therapy is superior to interrupting warfarin with or without bridging anticoagulation therapy in patients undergoing pacemaker and defibrillator implantation. Heart Rhythm. 2010;7(6):745-9. [pmid: 20176137].
Akdeniz B, Turker S, Ozturk V, et al. Cardioversion under the guidance of transesophageal echochardiograhy in persistent atrial fibrillation: results with low molecular weight heparin. Int J Cardiol. 2005;98(1):49-55. [pmid: 15676166].
Albers GW, Diener HC, Frison L, et al. Ximelagatran vs warfarin for stroke prevention in patients with nonvalvular atrial fibrillation: a randomized trial. JAMA. 2005;293(6):690-8. [pmid: 15701910].
Alcalay J. Cutaneous surgery in patients receiving warfarin therapy. Dermatol Surg. 2001;27(8):756-8. [pmid: 11493301].
Angeloni G, Alberti S, Romagnoli E, et al. Low molecular weight heparin (parnaparin) for cardioembolic events prevention in patients with atrial fibrillation undergoing elective electrical cardioversion: a prospective cohort study. Intern Emerg Med. 2011;6(2):117-23. [pmid: 21082292].
Asbach S, Biermann J, Bode C, et al. Early Heparin Administration Reduces Risk for Left Atrial Thrombus Formation during Atrial Fibrillation Ablation Procedures. Cardiol Res Pract. 2011;2011:615087. [pmid: 21747989].
Attaran S, Saleh HZ, Shaw M, et al. Does the outcome improve after radiofrequency ablation for atrial fibrillation in patients undergoing cardiac surgery? A propensity-matched comparison. Eur J Cardiothorac Surg. 2012;41(4):806-10. discussion 810–1. [pmid: 22219413].
Azoulay L, Dell’aniello S, Simon T, et al. Warfarin and the risk of major bleeding events in patients with atrial fibrillation: A population-based study. Eur Heart J. 2011;32(Suppl 1):671-2.
Bai R, Horton RP, DIB L, et al. Intraprocedural and Long-Term Incomplete Occlusion of the Left Atrial Appendage Following Placement of the WATCHMAN Device: A Single Center Experience. J Cardiovasc Electrophysiol. 2012;23(5):455-61. [pmid: 22082312].
Bai R, Horton RP, DIB L, et al. Intraprocedural and long-term incomplete occlusion of the left atrial appendage following placement of the WATCHMAN device: a single center experience. J Cardiovasc Electrophysiol. 2012;23(5):455-61. [pmid: 22082312].
Bayard YL, Omran H, Neuzil P, et al. PLAATO (Percutaneous Left Atrial Appendage Transcatheter Occlusion) for prevention of cardioembolic stroke in non-anticoagulation eligible atrial fibrillation patients: results from the European PLAATO study. EuroIntervention. 2010;6(2):220-6. [pmid: 20562072].
Bechtold H, Gunzenhauser D, Sawitzki H, et al. Anticoagulation with the low-molecular-weight heparin dalteparin (Fragmin) in atrial fibrillation and TEE-guided cardioversion. Z Kardiol. 2003;92(7):532-9. [pmid: 12883837].
Bernhardt P, Schmidt H, Hammerstingl C, et al. Patients at high risk with atrial fibrillation: a prospective and serial follow-up during 12 months with transesophageal echocardiography and cerebral magnetic resonance imaging. J Am Soc Echocardiogr. 2005;18(9):919-24. [pmid: 16153514].
Bernhardt P, Schmidt H, Sommer T, et al. Atrial fibrillation - patients at high risk for cerebral embolism. Clin Res Cardiol. 2006;95(3):148-53. [pmid: 16598527].
Berwaerts J, Webster J. Analysis of risk factors involved in oral-anticoagulant-related intracranial haemorrhages. QJM. 2000;93(8):513-21. [pmid: 10924533].
Beyth RJ, Quinn L, Landefeld CS. A multicomponent intervention to prevent major bleeding complications in older patients receiving warfarin. A randomized, controlled trial. Ann Intern Med. 2000;133(9):687-95. [pmid: 11074901].
Billett HH, Scorziello BA, Giannattasio ER, et al. Low molecular weight heparin bridging for atrial fibrillation: is VTE thromboprophylaxis the major benefit?. J Thromb Thrombolysis. 2010;30(4):479-85. [pmid: 20405168].
Birman-Deych E, Radford MJ, Nilasena DS, et al. Use and effectiveness of warfarin in Medicare beneficiaries with atrial fibrillation. Stroke. 2006;37(4):1070-4. [pmid: 16528001].
Blackshear JL, Johnson WD, Odell JA, et al. Thoracoscopic extracardiac obliteration of the left atrial appendage for stroke risk reduction in atrial fibrillation. J Am Coll Cardiol. 2003;42(7):1249-52. [pmid: 14522490].
Block PC, Burstein S, Casale PN, et al. Percutaneous left atrial appendage occlusion for patients in atrial fibrillation suboptimal for warfarin therapy: 5-year results of the PLAATO (Percutaneous Left Atrial Appendage Transcatheter Occlusion) Study. JACC Cardiovasc Interv. 2009;2(7):594-600. [pmid: 19628179].
Bollmann A, Husser D, Lindgren A, et al. Atrial fibrillatory rate and risk of stroke in atrial fibrillation. Europace. 2009;11(5):582-6. [pmid: 19287016].
Boriani G, Botto GL, Padeletti L, et al. Improving stroke risk stratification using the CHADS2 and CHA2DS2-VASc risk scores in patients with paroxysmal atrial fibrillation by continuous arrhythmia burden monitoring. Stroke. 2011;42(6):1768-70. [pmid: 21493904].
Boulanger L, Hauch O, Friedman M, et al. Warfarin exposure and the risk of thromboembolic and major bleeding events among medicaid patients with atrial fibrillation. Ann Pharmacother. 2006;40(6):1024-9. [pmid: 16735649].
Bover R, Perez-Gomez F, Maluenda MP, et al. Long-term follow-up of atrial fibrillation patients in the NASPEAF study. Prospective evaluation of different antiplatelet treatments. Rev Esp Cardiol. 2009;62(9):992-1000. [pmid: 19712620].
Cha MJ, Oh GC, Hahn S, et al. Thromboembolic risk evaluation in patients with atrial fibrillation using a modified CHADS(2) scoring system. J Cardiovasc Electrophysiol. 2012;23(2):155-62. [pmid: 21955174].
Chae SH, Froehlich J, Morady F, et al. Prevalence and predictors of warfarin use in patients with atrial fibrillation at low or intermediate risk and relation to thromboembolic events. Clin Cardiol. 2011;34(10):640-4. [pmid: 21994084].
Chan KE, Lazarus JM, Thadhani R, et al. Warfarin use associates with increased risk for stroke in hemodialysis patients with atrial fibrillation. J Am Soc Nephrol. 2009;20(10):2223-33. [pmid: 19713308].
Connolly SJ, Eikelboom JW, Ng J, et al. Net clinical benefit of adding clopidogrel to aspirin therapy in patients with atrial fibrillation for whom vitamin K antagonists are unsuitable. Ann Intern Med. 2011;155(9):579-86. [pmid: 22041946].
Conway DS, Pearce LA, Chin BS, et al. Prognostic value of plasma von Willebrand factor and soluble P-selectin as indices of endothelial damage and platelet activation in 994 patients with nonvalvular atrial fibrillation. Circulation. 2003;107(25):3141-5. [pmid: 12796127].
Copland M, Walker ID, Tait RC. Oral anticoagulation and hemorrhagic complications in an elderly population with atrial fibrillation. Arch Intern Med. 2001;161(17):2125-8. [pmid: 11570942].
Corbi IS, Dantas RA, Pelegrino FM, et al. Health related quality of life of patients undergoing oral anticoagulation therapy. Rev Lat Am Enfermagem. 2011;19(4):865-73. [pmid: 21876937].
Corrado G, Beretta S, Sormani L, et al. Prevalence of atrial thrombi in patients with atrial fibrillation/flutter and subtherapeutic anticoagulation prior to cardioversion. Eur J Echocardiogr. 2004;5(4):257-61. [pmid: 15219540].
Corrado G, Santarone M, Beretta S, et al. Early cardioversion of atrial fibrillation and atrial flutter guided by transoesophageal echocardiography: a single centre 8.5-year experience. Europace. 2000;2(2):119-26. [pmid: 11225938].
Currie CJ, Jones M, Goodfellow J, et al. Evaluation of survival and ischaemic and thromboembolic event rates in patients with non-valvar atrial fibrillation in the general population when treated and untreated with warfarin. Heart. 2006;92(2):196-200. [pmid: 15883133].
Currie CJ, McEwan P, Emmas C, et al. Anticoagulation in patients with non-valvular atrial fibrillation: an evaluation of stability and early factors that predict longer-term stability on warfarin in a large UK population. Curr Med Res Opin. 2005;21(12):1905-13. [pmid: 16368039].
Damonte AA, Costantini C, Montenegro M, et al. Percutaneous closure of the left atrial appendage with the Amplatzer Cardiac Plug: Initial Latin American experience. J Am Coll Cardiol. 2011;58(20):B192.
Darkow T, Vanderplas AM, Lew KH, et al. Treatment patterns and real-world effectiveness of warfarin in nonvalvular atrial fibrillation within a managed care system. Curr Med Res Opin. 2005;21(10):1583-94. [pmid: 16238898].
Das AK, Willcoxson PD, Corrado OJ, et al. The impact of long-term warfarin on the quality of life of elderly people with atrial fibrillation. Age Ageing. 2007;36(1):95-7. [pmid: 16799180].
De Caterina R, Connolly SJ, Pogue J, et al. Mortality predictors and effects of antithrombotic therapies in atrial fibrillation: insights from ACTIVE-W. Eur Heart J. 2010;31(17):2133-40. [pmid: 20685676].
Di Biase L, Burkhardt JD, Mohanty P, et al. Periprocedural stroke and management of major bleeding complications in patients undergoing catheter ablation of atrial fibrillation: the impact of periprocedural therapeutic international normalized ratio. Circulation. 2010;121(23):2550-6. [pmid: 20516376].
DiMarco JP, Flaker G, Waldo AL, et al. Factors affecting bleeding risk during anticoagulant therapy in patients with atrial fibrillation: observations from the Atrial Fibrillation Follow-up Investigation of Rhythm Management (AFFIRM) study. Am Heart J. 2005;149(4):650-6. [pmid: 15990748].
Douketis JD, Arneklev K, Goldhaber SZ, et al. Comparison of bleeding in patients with nonvalvular atrial fibrillation treated with ximelagatran or warfarin: assessment of incidence, case-fatality rate, time course and sites of bleeding, and risk factors for bleeding. Arch Intern Med. 2006;166(8):853-9. [pmid: 16636210].
Dunn AS, Spyropoulos AC, Turpie AG. Bridging therapy in patients on long-term oral anticoagulants who require surgery: the Prospective Peri-operative Enoxaparin Cohort Trial (PROSPECT). J Thromb Haemost. 2007;5(11):2211-8. [pmid: 17697140].
Ederhy S, Di Angelantonio E, Dufaitre G, et al. C-reactive protein and transesophageal echocardiographic markers of thromboembolism in patients with atrial fibrillation. Int J Cardiol. 2012;159(1):40-6. [pmid: 21402418].
Edvardsson N, Juul-Moller S, Omblus R, et al. Effects of low-dose warfarin and aspirin versus no treatment on stroke in a medium-risk patient population with atrial fibrillation. J Intern Med. 2003;254(1):95-101. [pmid: 12823646].
Elliott DJ, Zhao L, Jasper SE, et al. Health status outcomes after cardioversion for atrial fibrillation: results from the Assessment of Cardioversion Using Transesophageal Echocardiography (ACUTE) II Trial. Am Heart J. 2008;156(2):374.e1-6. [pmid: 18657673].
Evans A, Perez I, Yu G, et al. Should stroke subtype influence anticoagulation decisions to prevent recurrence in stroke patients with atrial fibrillation?. Stroke. 2001;32(12):2828-32. [pmid: 11739981].
Ezekowitz MD, Wallentin L, Connolly SJ, et al. Dabigatran and warfarin in vitamin K antagonist-naive and -experienced cohorts with atrial fibrillation. Circulation. 2010;122(22):2246-53. [pmid: 21147728].
Fang MC, Chang Y, Hylek EM, et al. Advanced age, anticoagulation intensity, and risk for intracranial hemorrhage among patients taking warfarin for atrial fibrillation. Ann Intern Med. 2004;141(10):745-52. [pmid: 15545674].
Fang MC, Go AS, Chang Y, et al. Thirty-day mortality after ischemic stroke and intracranial hemorrhage in patients with atrial fibrillation on and off anticoagulants. Stroke. 2012;43(7):1795-9. [pmid: 22539546].
Fang MC, Go AS, Hylek EM, et al. Age and the risk of warfarin-associated hemorrhage: the anticoagulation and risk factors in atrial fibrillation study. J Am Geriatr Soc. 2006;54(8):1231-6. [pmid: 16913990].
Fang MC, Singer DE, Chang Y, et al. Gender differences in the risk of ischemic stroke and peripheral embolism in atrial fibrillation: the AnTicoagulation and Risk factors In Atrial fibrillation (ATRIA) study. Circulation. 2005;112(12):1687-91. [pmid: 16157766].
Flaker GC, Gruber M, Connolly SJ, et al. Risks and benefits of combining aspirin with anticoagulant therapy in patients with atrial fibrillation: an exploratory analysis of stroke prevention using an oral thrombin inhibitor in atrial fibrillation (SPORTIF) trials. Am Heart J. 2006;152(5):967-73. [pmid: 17070169].
Flaker GC, Pogue J, Yusuf S, et al. Cognitive function and anticoagulation control in patients with atrial fibrillation. Circ Cardiovasc Qual Outcomes. 2010;3(3):277-83. [pmid: 20233976].
Friberg L, Benson L, Rosenqvist M, et al. Assessment of female sex as a risk factor in atrial fibrillation in Sweden: nationwide retrospective cohort study. BMJ. 2012;344:e3522. [pmid: 22653980].
Friberg L, Benson L, Rosenqvist M, et al. Assessment of female sex as a risk factor in atrial fibrillation in Sweden: Nationwide retrospective cohort study. BMJ. 2012;344:e3522. [pmid: 22653980].
Gallagher AM, Setakis E, Plumb JM, et al. Risks of stroke and mortality associated with suboptimal anticoagulation in atrial fibrillation patients. Thromb Haemost. 2011;106(5):968-77. [pmid: 21901239].
Gautam S, John RM, Stevenson WG, et al. Effect of therapeutic INR on activated clotting times, heparin dosage, and bleeding risk during ablation of atrial fibrillation. J Cardiovasc Electrophysiol. 2011;22(3):248-54. [pmid: 20812929].
Go AS, Hylek EM, Chang Y, et al. Anticoagulation therapy for stroke prevention in atrial fibrillation: how well do randomized trials translate into clinical practice?. JAMA. 2003;290(20):2685-92. [pmid: 14645310].
Gomberg-Maitland M, Wenger NK, Feyzi J, et al. Anticoagulation in women with non-valvular atrial fibrillation in the stroke prevention using an oral thrombin inhibitor (SPORTIF) trials. Eur Heart J. 2006;27(16):1947-53. [pmid: 16774980].
Gorin L, Fauchier L, Nonin E, et al. Antithrombotic treatment and the risk of death and stroke in patients with atrial fibrillation and a CHADS2 score=1. Thromb Haemost. 2010;103(4):833-40. [pmid: 20135077].
Guerin A, Lin J, Jhaveri M, et al. Outcomes in atrial fibrillation patients on combined warfarin & antiarrhythmic therapy. Int J Cardiol. 2012. [pmid: 22336254].
Guerios EE, Schmid M, Gloekler S, et al. Left atrial appendage closure with the Amplatzer Cardiac Plug in patients with atrial fibrillation. Arq Bras Cardiol. 2012;98(6):528-36. [pmid: 22584492].
Guiot A, Jongnarangsin K, Chugh A, et al. Anticoagulant Therapy and Risk of Cerebrovascular Events After Catheter Ablation of Atrial Fibrillation in the Elderly. J Cardiovasc Electrophysiol. 2011;23(1):36-43. [pmid: 21806701].
Guo Y, Wu Q, Zhang L, et al. Antithrombotic therapy in very elderly patients with atrial fibrillation: is it enough to assess thromboembolic risk?. Clin Interv Aging. 2010;5:157-62. [pmid: 20517485].
Ha SI, Choi DH, Ki YJ, et al. Stroke prediction using mean platelet volume in patients with atrial fibrillation. Platelets. 2011;22(6):408-14. [pmid: 21599611].
Hakalahti A, Uusimaa P, Ylitalo K, et al. Catheter ablation of atrial fibrillation in patients with therapeutic oral anticoagulation treatment. Europace. 2011;13(5):640-5. [pmid: 21398311].
Halbfass P, Janko S, Dorwarth U, et al. Dilemma of antithrombotic therapy in anticoagulated atrial fibrillation patients squeezed between thrombosis and bleeding events: a single-centre experience. Europace. 2009;11(7):957-60. [pmid: 19493910].
Harley CR, Riedel AA, Hauch O, et al. Anticoagulation therapy in patients with chronic atrial fibrillation: a retrospective claims data analysis. Curr Med Res Opin. 2005;21(2):215-22. [pmid: 15801992].
Hart RG, Pearce LA, Rothbart RM, et al. Stroke with intermittent atrial fibrillation: incidence and predictors during aspirin therapy. Stroke Prevention in Atrial Fibrillation Investigators. J Am Coll Cardiol. 2000;35(1):183-7. [pmid: 10636278].
He H, Kang J, Tao H, et al. Conventional oral anticoagulation may not replace prior transesophageal echocardiography for the patients with planned catheter ablation for atrial fibrillation. J Interv Card Electrophysiol. 2009;24(1):19-26. [pmid: 18982437].
Hijazi Z, Oldgren J, Andersson U, et al. Cardiac biomarkers are associated with an increased risk of stroke and death in patients with atrial fibrillation: a Randomized Evaluation of Long-term Anticoagulation Therapy (RE-LY) substudy. Circulation. 2012;125(13):1605-16. [pmid: 22374183].
Hori M, Connolly SJ, Ezekowitz MD, et al. Efficacy and safety of dabigatran vs. warfarin in patients with atrial fibrillation--sub-analysis in Japanese population in RE-LY trial. Circ J. 2011;75(4):800-5. [pmid: 21436594].
Humphries J, Phillips K. First 12 months experience and clinical outcomes after Watchman® left atrial appendage occlusion procedure: Case series in a single centre. Heart Lung Circul. 2011;20(Suppl 2):S126.
Hussein AA, Martin DO, Saliba W, et al. Radiofrequency ablation of atrial fibrillation under therapeutic international normalized ratio: a safe and efficacious periprocedural anticoagulation strategy. Heart Rhythm. 2009;6(10):1425-9. [pmid: 19968920].
Hylek EM, Evans-Molina C, Shea C, et al. Major hemorrhage and tolerability of warfarin in the first year of therapy among elderly patients with atrial fibrillation. Circulation. 2007;115(21):2689-96. [pmid: 17515465].
Hylek EM, Frison L, Henault LE, et al. Disparate stroke rates on warfarin among contemporaneous cohorts with atrial fibrillation: potential insights into risk from a comparative analysis of SPORTIF III versus SPORTIF V. Stroke. 2008;39(11):3009-14. [pmid: 18703812].
Indredavik B, Rohweder G, Lydersen S. Frequency and effect of optimal anticoagulation before onset of ischaemic stroke in patients with known atrial fibrillation. J Intern Med. 2005;258(2):133-44. [pmid: 16018790].
Jaffer AK, Ahmed M, Brotman DJ, et al. Low-molecular-weight-heparins as periprocedural anticoagulation for patients on long-term warfarin therapy: a standardized bridging therapy protocol. J Thromb Thrombolysis. 2005;20(1):11-6. [pmid: 16133889].
Jang SW, Rho TH, Kim DB, et al. Optimal antithrombotic strategy in patients with atrial fibrillation after coronary stent implantation. Korean Circ J. 2011;41(10):578-82. [pmid: 22125556].
Joffe HV, Goldhaber SZ. Effectiveness and safety of long-term anticoagulation of patients >/=90 years of age with atrial fibrillation. Am J Cardiol. 2002;90(12):1397-8. [pmid: 12480055].
Johnson CE, Lim WK, Workman BS. People aged over 75 in atrial fibrillation on warfarin: the rate of major hemorrhage and stroke in more than 500 patient-years of follow-up. J Am Geriatr Soc. 2005;53(4):655-9. [pmid: 15817013].
Jones M, McEwan P, Morgan CL, et al. Evaluation of the pattern of treatment, level of anticoagulation control, and outcome of treatment with warfarin in patients with non-valvar atrial fibrillation: a record linkage study in a large British population. Heart. 2005;91(4):472-7. [pmid: 15772203].
Kalra L, Yu G, Perez I, et al. Prospective cohort study to determine if trial efficacy of anticoagulation for stroke prevention in atrial fibrillation translates into clinical effectiveness. BMJ. 2000;320(7244):1236-9. [pmid: 10797031].
Klein AL, Grimm RA, Murray RD, et al. Use of transesophageal echocardiography to guide cardioversion in patients with atrial fibrillation. N Engl J Med. 2001;344(19):1411-20. [pmid: 11346805].
Klem I, Wehinger C, Schneider B, et al. Diabetic atrial fibrillation patients: mortality and risk for stroke or embolism during a 10-year follow-up. Diabetes Metab Res Rev. 2003;19(4):320-8. [pmid: 12879410].
Kovacs MJ, Kearon C, Rodger M, et al. Single-arm study of bridging therapy with low-molecular-weight heparin for patients at risk of arterial embolism who require temporary interruption of warfarin. Circulation. 2004;110(12):1658-63. [pmid: 15364803].
Kukula K, Klopotowski M, Konka M, et al. Left atrial appendage occlusion using the PLAATO system in high-risk patients with atrial fibrillation - Long-term follow-up. Postepy Kardiol Interwencyjnej. 2009;5(2):51-7.
Lai HM, Aronow WS, Kalen P, et al. Incidence of thromboembolic stroke and of major bleeding in patients with atrial fibrillation and chronic kidney disease treated with and without warfarin. Int J Nephrol Renovasc Dis. 2009;2:33-7. [pmid: 21694919].
Lam YY, Yip GW, Yu CM, et al. Left atrial appendage closure with Amplatzer cardiac plug for stroke prevention in atrial fibrillation: Initial Asia-Pacific experience. Catheter Cardiovasc Interv. 2011;78(1):S173. [pmid: 21542102].
Lee SJ, Shin DH, Hwang HJ, et al. Bleeding risk and major adverse events in patients with previous ulcer on oral anticoagulation therapy. Am J Cardiol. 2012;110(3):373-7. [pmid: 22516526].
Leiria TLL, Pellanda L, Miglioranza MH, et al. Warfarin and phenprocoumon: Experience of an Outpatient Anticoagulation Clinic. Arq Bras Cardiol. 2010;94(1):40-3.
Lip GY, Rasmussen LH, Olsson SB, et al. Oral direct thrombin inhibitor AZD0837 for the prevention of stroke and systemic embolism in patients with non-valvular atrial fibrillation: a Phase II study of AZD0837 in patients who are appropriate for but unable or unwilling to take vitamin K antagonist therapy. Thromb Res. 2011;127(2):91-9. [pmid: 21172721].
Lip GY, Rasmussen LH, Olsson SB, et al. Oral direct thrombin inhibitor AZD0837 for the prevention of stroke and systemic embolism in patients with non-valvular atrial fibrillation: a randomized dose-guiding, safety, and tolerability study of four doses of AZD0837 vs. vitamin K antagonists. Eur Heart J. 2009;30(23):2897-907. [pmid: 19690349].
Lorgat F, Pudney E, Van Deventer H, et al. Robotically controlled ablation for atrial fibrillation: The first real-world experience in Africa with the Hansen robotic system. Cardiovasc J Afr. 2012;23(5):274-80. [pmid: 22447186].
Mahe I, Bergmann JF, Chassany O, et al. A multicentric prospective study in usual care: D-dimer and cardiovascular events in patients with atrial fibrillation. Thromb Res. 2012;129(6):693-9. [pmid: 21917302].
Mahe I, Grenard AS, Joyeux N, et al. Management of oral anticoagulant in clinical practice: a retrospective study of 187 patients. J Gerontol A Biol Sci Med Sci. 2004;59(12):1339-42. [pmid: 15699536].
Majunke N, Daehnert I, Sick P, et al. Long-term outcome of percutaneous closure of the left atrial appendage with the watchman device. Eur Heart J. 2011;32(Suppl 1):467-8.
Masaki N, Suzuki M, Matsumura A, et al. Quality of warfarin control affects the incidence of stroke in elderly patients with atrial fibrillation. Intern Med. 2010;49(16):1711-6. [pmid: 20720347].
Mendell J, Basavapathrisni R, Swcaringen D, et al. Thorough qtiqtc study with edoxaban to evaluate effect of therapeutic and supratherapeutic exposure on QTC interval duration en healthy subjects. J Clin Pharmacol. 2009;49(9):1122.
Mendell J, Basavapathruni R, Swearingen D, et al. Thorough QT/QTc study eith edoxaban to evaluate effect of therapeutic and supratherapeutic exposure on QTc interval duration in healthy subjects. Basic Clin Pharmacol Toxicol. 2009;105(Suppl 1):53.
Naganuma M, Shiga T, Sato K, et al. Clinical outcome in Japanese elderly patients with non-valvular atrial fibrillation taking warfarin: A single-center observational study. Thromb Res. 2012;130(1):21-6. [pmid: 22137743].
Nakagawa K, Hirai T, Takashima S, et al. Chronic kidney disease and CHADS(2) score independently predict cardiovascular events and mortality in patients with nonvalvular atrial fibrillation. Am J Cardiol. 2011;107(6):912-6. [pmid: 21247518].
Njaastad AM, Abildgaard U, Lassen JF. Gains and losses of warfarin therapy as performed in an anticoagulation clinic. J Intern Med. 2006;259(3):296-304. [pmid: 16476107].
Nozawa T, Asanoi H, Inoue H. Instability of anticoagulation intensity contributes to occurrence of ischemic stroke in patients with non-rheumatic atrial fibrillation. Jpn Circ J. 2001;65(5):404-8. [pmid: 11357868].
Nozawa T, Inoue H, Hirai T, et al. D-dimer level influences thromboembolic events in patients with atrial fibrillation. Int J Cardiol. 2006;109(1):59-65. [pmid: 15992948].
O’Hara GE, Charbonneau L, Chandler M, et al. Comparison of management patterns and clinical outcomes in patients with atrial fibrillation in Canada and the United States (from the analysis of the Atrial Fibrillation Follow-up Investigation of Rhythm Management [AFFIRM] database). Am J Cardiol. 2005;96(6):815-21. [pmid: 16169368].
Olsson SB, Rasmussen LH, Tveit A, et al. Safety and tolerability of an immediate-release formulation of theoral direct thrombin inhibitor AZD0837 in the prevention of stroke and systemic embolism in patients with atrial fibrillation. Thromb Haemost. 2010;103(3):604-12. [pmid: 20076850].
Olsson SB. Stroke prevention with the oral direct thrombin inhibitor ximelagatran compared with warfarin in patients with non-valvular atrial fibrillation (SPORTIF III): randomised controlled trial. Lancet. 2003;362(9397):1691-8. [pmid: 14643116].
Ostermayer SH, Reisman M, Kramer PH, et al. Percutaneous left atrial appendage transcatheter occlusion (PLAATO system) to prevent stroke in high-risk patients with non-rheumatic atrial fibrillation: results from the international multi-center feasibility trials. J Am Coll Cardiol. 2005;46(1):9-14. [pmid: 15992628].
Oude Velthuis B, Stevenhagen J, van Opstal JM, et al. Continuation of vitamin K antagonists as acceptable anticoagulation regimen in patients undergoing pulmonary vein isolation. Neth Heart J. 2012;20(1):12-5. [pmid: 22161077].
Paciaroni M, Agnelli G, Ageno W, et al. Risk factors for cerebral ischemic events in patients with atrial fibrillation on warfarin for stroke prevention. Atherosclerosis. 2010;212(2):564-6. [pmid: 20599199].
Park JW, Leithauser B, Gerk U, et al. Percutaneous left atrial appendage transcatheter occlusion (PLAATO) for stroke prevention in atrial fibrillation: 2-year outcomes. J Invasive Cardiol. 2009;21(9):446-50. [pmid: 19726815].
Park JW, Sievert H, Schillinger W, et al. Interim data from AMPLATZER® Cardiac Plug registry. J Am Coll Cardiol. 2011;58(20):B33.
Parkash R, Wee V, Gardner MJ, et al. The impact of warfarin use on clinical outcomes in atrial fibrillation: a population-based study. Can J Cardiol. 2007;23(6):457-61. [pmid: 17487290].
Pearce LA, Hart RG, Halperin JL. Assessment of three schemes for stratifying stroke risk in patients with nonvalvular atrial fibrillation. Am J Med. 2000;109(1):45-51. [pmid: 10936477].
Penado S, Cano M, Acha O, et al. Atrial fibrillation as a risk factor for stroke recurrence. Am J Med. 2003;114(3):206-10. [pmid: 12637135].
Pengo V, Cucchini U, Denas G, et al. Lower versus standard intensity oral anticoagulant therapy (OAT) in elderly warfarin-experienced patients with non-valvular atrial fibrillation. Thromb Haemost. 2010;103(2):442-9. [pmid: 20076843].
Perera V, Bajorek BV, Matthews S, et al. The impact of frailty on the utilisation of antithrombotic therapy in older patients with atrial fibrillation. Age Ageing. 2009;38(2):156-62. [pmid: 19151165].
Pet M, Robertson JO, Bailey M, et al. The impact of CHADS(2) score on late stroke after the Cox maze procedure. J Thorac Cardiovasc Surg. 2012. [pmid: 22818126].
Pichette M, Stevens LM, Noiseux N, et al. Effectiveness of warfarin therapy for atrial fibrillation in a real world population. Can J Cardiol. 2011;27(5):S122.
Poli D, Antonucci E, Grifoni E, et al. Bleeding risk during oral anticoagulation in atrial fibrillation patients older than 80 years. J Am Coll Cardiol. 2009;54(11):999-1002. [pmid: 19729116].
Poli D, Antonucci E, Grifoni E, et al. Low bleeding risk of very old atrial fibrillation women on VKA treatment: Results from a prospective collaborative study. on behalf of the ad hoc Study Group of FCSA. Eur Heart J. 2011;32(Suppl 1):8.
Poli D, Antonucci E, Grifoni E, et al. Risk of bleeding in low-risk atrial fibrillation patients on warfarin waiting for elective cardioversion. Thromb Res. 2012;129(5):588-90. [pmid: 21975030].
Poli D, Antonucci E, Lombardi A, et al. Low incidence of hemorrhagic complications of oral anticoagulant therapy in patients with atrial fibrillation in the daily practice of an anticoagulation clinic. Ital Heart J. 2003;4(1):44-7. [pmid: 12690920].
Poli D, Antonucci E, Lombardi A, et al. Management of oral anticoagulant therapy in the real practice of an anticoagulation clinic: focus on atrial fibrillation. Blood Coagul Fibrinolysis. 2005;16(7):491-4. [pmid: 16175008].
Rasmussen LH, Larsen TB, Due KM, et al. Impact of vascular disease in predicting stroke and death in patients with atrial fibrillation: The Danish Diet, Cancer and Health Cohort study. J Thromb Haemost. 2011;9(7):1301-7. [pmid: 21535388].
Raunso J, Selmer C, Olesen JB, et al. Increased short-term risk of thrombo-embolism or death after interruption of warfarin treatment in patients with atrial fibrillation. Eur Heart J. 2012;33(15):1886-92. [pmid: 22199117].
Raunsoe J, Andersen SS, Lamberts M, et al. Increased risk of bleeding during combination therapy with warfarin and ibuprofen in a large population with atrial fibrillation. Eur Heart J. 2011;32(Suppl 1):264-5. [pmid: 20729544].
Reynolds MR, Gunnarsson CL, Hunter TD, et al. Health outcomes with catheter ablation or antiarrhythmic drug therapy in atrial fibrillation results of a propensity-matched analysis. Circ Cardiovasc Qual Outcomes. 2012;5(2):171-81. [pmid: 22373904].
Rodes-Cabau J, Champagne J, Bernier M, et al. Transcatheter left atrial appendage closure in high-risk patients with atrial fibrillation who are not eligible for long-term anticoagulation therapy: Initial experience with the amplatzer cardiac plug. Can J Cardiol. 2011;27(5):S160.
Roijer A, Eskilsson J, Olsson B. Transoesophageal echocardiography-guided cardioversion of atrial fibrillation or flutter. Selection of a low-risk group for immediate cardioversion. Eur Heart J. 2000;21(10):837-47. [pmid: 10781356].
Rossillo A, Bonso A, Themistoclakis S, et al. Role of anticoagulation therapy after pulmonary vein antrum isolation for atrial fibrillation treatment. J Cardiovasc Med (Hagerstown). 2008;9(1):51-5. [pmid: 18268419].
Roy B, Desai RV, Mujib M, et al. Effect of Warfarin on Outcomes in Septuagenarian Patients With Atrial Fibrillation. Am J Cardiol. 2012;109(3):370-7. [pmid: 22118824].
Ruigomez A, Garcia Rodriguez LA, Johansson S, et al. Risk of cerebrovascular accident after a first diagnosis of atrial fibrillation. Clin Cardiol. 2007;30(12):624-8. [pmid: 18069679].
Ruiz Ortiz M, Romo E, Mesa D, et al. Outcomes and safety of antithrombotic treatment in patients aged 80 years or older with nonvalvular atrial fibrillation. Am J Cardiol. 2011;107(10):1489-93. [pmid: 21420049].
Saad EB, d’Avila A, Costa IP, et al. Very low risk of thromboembolic events in patients undergoing successful catheter ablation of atrial fibrillation with a CHADS2 score </=3: a long-term outcome study. Circ Arrhythm Electrophysiol. 2011;4(5):615-21. [pmid: 21841192].
Sadanaga T, Kohsaka S, Mitamura H, et al. Elevated B-type natriuretic peptide level as a marker of subsequent thromboembolic events in patients with atrial fibrillation. Heart Vessels. 2011;26(5):530-5. [pmid: 21188387].
Sandhu RK, Bakal JA, Ezekowitz JA, et al. Risk stratification schemes, anticoagulation use and outcomes: The risk - Treatment paradox in patients with newly diagnosed non-valvular atrial fibrillation. Heart. 2011;97(24):2046-50. [pmid: 22076011].
Sato H, Ishikawa K, Kitabatake A, et al. Low-dose aspirin for prevention of stroke in low-risk patients with atrial fibrillation: Japan Atrial Fibrillation Stroke Trial. Stroke. 2006;37(2):447-51. [pmid: 16385088].
Scaglione M, Blandino A, Raimondo C, et al. Impact of Ablation Catheter Irrigation Design on Silent Cerebral Embolism After Radiofrequency Catheter Ablation of Atrial Fibrillation:Results from a Pilot Study. J Cardiovasc Electrophysiol. 2012;23(8):801-5. [pmid: 22494043].
Scherr D, Dalal D, Spragg D, et al. Incidence and predictors of periprocedural cerebrovascular accident in patients undergoing catheter ablation of atrial fibrillation. Eur Heart J. 2011;32(Suppl 1):805.
Schultz KT, Bungard TJ. Dosing options for decreasing the time to achieve therapeutic anticoagulation when reinitiating warfarin: A case series. Pharmacotherapy. 2011;31(8):793-805. [pmid: 21923606].
Seidl K, Rameken M, Drogemuller A, et al. Embolic events in patients with atrial fibrillation and effective anticoagulation: value of transesophageal echocardiography to guide direct-current cardioversion. Final results of the Ludwigshafen Observational Cardioversion Study. J Am Coll Cardiol. 2002;39(9):1436-42. [pmid: 11985904].
Shen AY, Yao JF, Brar SS, et al. Racial/Ethnic differences in ischemic stroke rates and the efficacy of warfarin among patients with atrial fibrillation. Stroke. 2008;39(10):2736-43. [pmid: 18635860].
Shen AY, Yao JF, Brar SS, et al. Racial/ethnic differences in the risk of intracranial hemorrhage among patients with atrial fibrillation. J Am Coll Cardiol. 2007;50(4):309-15. [pmid: 17659197].
Sherman DG, Kim SG, Boop BS, et al. Occurrence and characteristics of stroke events in the Atrial Fibrillation Follow-up Investigation of Sinus Rhythm Management (AFFIRM) study. Arch Intern Med. 2005;165(10):1185-91. [pmid: 15911734].
Shin HW, Kim H, Son J, et al. Tissue Doppler imaging as a prognostic marker for cardiovascular events in heart failure with preserved ejection fraction and atrial fibrillation. J Am Soc Echocardiogr. 2010;23(7):755-61. [pmid: 20620861].
Sick PB, Schuler G, Hauptmann KE, et al. Initial worldwide experience with the WATCHMAN left atrial appendage system for stroke prevention in atrial fibrillation. J Am Coll Cardiol. 2007;49(13):1490-5. [pmid: 17397680].
Singer DE, Chang Y, Fang MC, et al. The net clinical benefit of warfarin anticoagulation in atrial fibrillation. Ann Intern Med. 2009;151(5):297-305. [pmid: 19721017].
Sorino M, Colonna P, De Luca L, et al. Post-cardioversion transesophageal echocardiography (POSTEC) strategy with the use of enoxaparin for brief anticoagulation in atrial fibrillation patients: the multicenter POSTEC trial (a pilot study). J Cardiovasc Med (Hagerstown). 2007;8(12):1034-42. [pmid: 18163016].
Stenestrand U, Lindback J, Wallentin L. Anticoagulation therapy in atrial fibrillation in combination with acute myocardial infarction influences long-term outcome: a prospective cohort study from the Register of Information and Knowledge About Swedish Heart Intensive Care Admissions (RIKS-HIA). Circulation. 2005;112(21):3225-31. [pmid: 16301355].
Sun Y, Hu D, Li K, et al. Predictors of stroke risk in native Chinese with nonrheumatic atrial fibrillation: retrospective investigation of hospitalized patients. Clin Cardiol. 2009;32(2):76-81. [pmid: 19215006].
Suzuki S, Yamashita T, Kato T, et al. Incidence of major bleeding complication of warfarin therapy in Japanese patients with atrial fibrillation. Circ J. 2007;71(5):761-5. [pmid: 17457005].
Tangelder MJ, Frison L, Weaver D, et al. Effect of ximelagatran on ischemic events and death in patients with atrial fibrillation after acute myocardial infarction in the efficacy and safety of the oral direct thrombin inhibitor ximelagatran in patients with recent myocardial damage (ESTEEM) trial. Am Heart J. 2008;155(2):382-7. [pmid: 18215612].
Tebbe U, Oeckinghaus R, Appel KF, et al. AFFECT: a prospective, open-label, multicenter trial to evaluate the feasibility and safety of a short-term treatment with subcutaneous certoparin in patients with persistent non-valvular atrial fibrillation. Clin Res Cardiol. 2008;97(6):389-96. [pmid: 18322636].
Thambidorai SK, Murray RD, Parakh K, et al. Utility of transesophageal echocardiography in identification of thrombogenic milieu in patients with atrial fibrillation (an ACUTE ancillary study). Am J Cardiol. 2005;96(7):935-41. [pmid: 16188520].
Themistoclakis S, Corrado A, Marchlinski FE, et al. The risk of thromboembolism and need for oral anticoagulation after successful atrial fibrillation ablation. J Am Coll Cardiol. 2010;55(8):735-43. [pmid: 20170810].
Tincani E, Baldini P, Crowther MA, et al. Bleeding rates in patients older than 90 years of age on vitamin K antagonist therapy for nonvalvular atrial fibrillation. Blood Coagul Fibrinolysis. 2009;20(1):47-51. [pmid: 20523164].
Tinkler K, Cullinane M, Kaposzta Z, et al. Asymptomatic embolisation in non-valvular atrial fibrillation and its relationship to anticoagulation therapy. Eur J Ultrasound. 2002;15(1–2):21-7. [pmid: 12044849].
Tinmouth AH, Morrow BH, Cruickshank MK, et al. Dalteparin as periprocedure anticoagulation for patients on warfarin and at high risk of thrombosis. Ann Pharmacother. 2001;35(6):669-74. [pmid: 11408982].
Torn M, Cannegieter SC, Bollen WL, et al. Optimal level of oral anticoagulant therapy for the prevention of arterial thrombosis in patients with mechanical heart valve prostheses, atrial fibrillation, or myocardial infarction: a prospective study of 4202 patients. Arch Intern Med. 2009;169(13):1203-9. [pmid: 19597069].
Toumanides S, Sideris EB, Agricola T, et al. Transcatheter patch occlusion of the left atrial appendage using surgical adhesives in high-risk patients with atrial fibrillation. J Am Coll Cardiol. 2011;58(21):2236-40. [pmid: 22078431].
Trullas-Vila JC, Bisbe-Company J, Freitas-Ramirez A, et al. Ten-year experience with acenocoumarol treatment in an ambulatory cohort of Spanish patients. J Thromb Thrombolysis. 2009;28(4):436-43. [pmid: 19225864].
Ussia GP, Mule M, Cammalleri V, et al. Percutaneous closure of left atrial appendage to prevent embolic events in high-risk patients with chronic atrial fibrillation. Catheter Cardiovasc Interv. 2009;74(2):217-22. [pmid: 19472361].
Vazquez E, Sanchez-Perales C, Garcia-Cortes MJ, et al. Ought dialysis patients with atrial fibrillation be treated with oral anticoagulants?. Int J Cardiol. 2003;87(2–3):135-9. discussion 139–41. [pmid: 12559531].
Viles-Gonzalez JF, Reddy VY, Petru J, et al. Incomplete occlusion of the left atrial appendage with the percutaneous left atrial appendage transcatheter occlusion device is not associated with increased risk of stroke. J Interv Card Electrophysiol. 2012;33(1):69-75. [pmid: 21947786].
Wallentin L, Yusuf S, Ezekowitz MD, et al. Efficacy and safety of dabigatran compared with warfarin at different levels of international normalised ratio control for stroke prevention in atrial fibrillation: an analysis of the RE-LY trial. Lancet. 2010;376(9745):975-83. [pmid: 20801496].
Weigner MJ, Thomas LR, Patel U, et al. Early cardioversion of atrial fibrillation facilitated by transesophageal echocardiography: short-term safety and impact on maintenance of sinus rhythm at 1 year. Am J Med. 2001;110(9):694-702. [pmid: 11403753].
White HD, Gruber M, Feyzi J, et al. Comparison of outcomes among patients randomized to warfarin therapy according to anticoagulant control: results from SPORTIF III and V. Arch Intern Med. 2007;167(3):239-45. [pmid: 17296878].
Wieloch M, Sjalander A, Frykman V, et al. Anticoagulation control in Sweden: reports of time in therapeutic range, major bleeding, and thrombo-embolic complications from the national quality registry AuriculA. Eur Heart J. 2011;32(18):2282-9. [pmid: 21616951].
Wiesholzer M, Harm F, Tomasec G, et al. Incidence of stroke among chronic hemodialysis patients with nonrheumatic atrial fibrillation. Am J Nephrol. 2001;21(1):35-9. [pmid: 11275630].
Winkelmayer WC, Liu J, Setoguchi S, et al. Effectiveness and safety of warfarin initiation in older hemodialysis patients with incident atrial fibrillation. Clin J Am Soc Nephrol. 2011;6(11):2662-8. [pmid: 21959598].
Winkle RA, Mead RH, Engel G, et al. The Use of Dabigatran Immediately After Atrial Fibrillation Ablation. J Cardiovasc Electrophysiol. 2012;23(3):264-8. [pmid: 21955008].
Wysokinski WE, McBane RD, Daniels PR, et al. Periprocedural anticoagulation management of patients with nonvalvular atrial fibrillation. Mayo Clin Proc. 2008;83(6):639-45. [pmid: 18533080].
Yasaka M, Minematsu K, Yamaguchi T. Optimal intensity of international normalized ratio in warfarin therapy for secondary prevention of stroke in patients with non-valvular atrial fibrillation. Intern Med. 2001;40(12):1183-8. [pmid: 11813841].

## No Outcomes of Interest

Abe Y, Asakura T, Gotou J, et al. Prediction of embolism in atrial fibrillation: classification of left atrial thrombi by transesophageal echocardiography. Jpn Circ J. 2000;64(6):411-5. [pmid: 10875730].
Alessandri N, Mariani S, Ciccaglioni A, et al. Thrombus formation in the left atrial appendage in the course of atrial fibrillation. Eur Rev Med Pharmacol Sci. 2003;7(3):65-73. [pmid: 14650642].
Ali A, Bailey C, Abdelhafiz AH. Stroke prophylaxis with warfarin or dabigatran for patients with non-valvular atrial fibrillation-cost analysis. Age Ageing. 2012;41(5):681-4. [pmid: 22378612].
Determinants of warfarin use and international normalized ratio levels in atrial fibrillation patients in Japan. - Subanalysis of the J-RHYTHM Registry. Circ J. 2011;75(10):2357-62. [pmid: 21791869].
Audebert HJ, Schenk B, Schenkel J, et al. Impact of prestroke oral anticoagulation on severity and outcome of ischemic and hemorrhagic stroke in patients with atrial fibrillation. Cerebrovasc Dis. 2010;29(5):476-83. [pmid: 20299787].
Berisha B, Gashi M, Krasniqi X, et al. Limitations of CHADS2 scoring system in predicting stroke risk--need to change the age criteria. Med Arh. 2011;65(1):27-9. [pmid: 21534448].
Bernhardt P, Schmidt H, Hammerstingl C, et al. Patients with atrial fibrillation and dense spontaneous echo contrast at high risk a prospective and serial follow-up over 12 months with transesophageal echocardiography and cerebral magnetic resonance imaging. J Am Coll Cardiol. 2005;45(11):1807-12. [pmid: 15936610].
Bernhardt P, Schmidt H, Hammerstingl C, et al. Fate of left atrial thrombi in patients with atrial fibrillation determined by transesophageal echocardiography and cerebral magnetic resonance imaging. Am J Cardiol. 2004;94(6):801-4. [pmid: 15374795].
Cemri M, Timurkaynak T, Ozdemir M, et al. Effects of left ventricular systolic dysfunction on left atrial appendage and left atrial functions in patients with chronic nonvalvular atrial fibrillation. Acta Cardiol. 2002;57(2):101-5. [pmid: 12003255].
Chan PS, Maddox TM, Tang F, et al. Practice-level variation in warfarin use among outpatients with atrial fibrillation (from the NCDR PINNACLE program). Am J Cardiol. 2011;108(8):1136-40. [pmid: 21798501].
Chao TF, Liu CJ, Chen SJ, et al. Atrial fibrillation and the risk of ischemic stroke: Does it still matter in patients with a CHA2DS2-VASc score of 0 or 1?. Stroke. 2012;43(10):2551-5. [pmid: 22871677].
Chilukuri K, Mayer SA, Scherr D, et al. Transoesophageal echocardiography predictors of periprocedural cerebrovascular accident in patients undergoing catheter ablation of atrial fibrillation. Europace. 2010;12(11):1543-9. [pmid: 20682553].
Connolly SJ, Pogue J, Eikelboom J, et al. Benefit of oral anticoagulant over antiplatelet therapy in atrial fibrillation depends on the quality of international normalized ratio control achieved by centers and countries as measured by time in therapeutic range. Circulation. 2008;118(20):2029-37. [pmid: 18955670].
Conway DS, Buggins P, Hughes E, et al. Relation of interleukin-6, C-reactive protein, and the prothrombotic state to transesophageal echocardiographic findings in atrial fibrillation. Am J Cardiol. 2004;93(11):1368-73. A6. [pmid: 15165916].
Daccarett M, Badger TJ, Akoum N, et al. Association of left atrial fibrosis detected by delayed-enhancement magnetic resonance imaging and the risk of stroke in patients with atrial fibrillation. J Am Coll Cardiol. 2011;57(7):831-8. [pmid: 21310320].
Di Angelantonio E, Ederhy S, Benyounes N, et al. Comparison of transesophageal echocardiographic identification of embolic risk markers in patients with lone versus non-lone atrial fibrillation. Am J Cardiol. 2005;95(5):592-6. [pmid: 15721097].
Di Biase L, Gaita F, Salvetti I, et al. Left atrial appendage morphology correlates with a reduced risk for stroke in patients with AF. Eur Heart J. 2011;32(Suppl 1):7. [pmid: 21246770].
Di Biase L, Santangeli P, Anselmino M, et al. Does the left atrial appendage morphology correlate with the risk of stroke in patients with atrial fibrillation?: results from a multicenter study. J Am Coll Cardiol. 2012;60(6):531-8. [pmid: 22858289].
Dinh T, Baur LH, Pisters R, et al. Feasibility of TEE-guided stroke risk assessment in atrial fibrillation-background, aims, design and baseline data of the TIARA pilot study. Neth Heart J. 2011;19(5):214-22. [pmid: 21541835].
Dores H, Cardiga R, Ferreira R, et al. Atrial fibrillation and thromboembolic risk: what is the extent of adherence to guidelines in clinical practice?. Rev Port Cardiol. 2011;30(2):171-80. [pmid: 21553610].
Ellis DJ, Usman MH, Milner PG, et al. The first evaluation of a novel vitamin K antagonist, tecarfarin (ATI-5923), in patients with atrial fibrillation. Circulation. 2009;120(12):1029-35. 2 p following 1035. [pmid: 19738136].
Ezekowitz MD, Connolly S, Parekh A, et al. Rationale and design of RE-LY: randomized evaluation of long-term anticoagulant therapy, warfarin, compared with dabigatran. Am Heart J. 2009;157(5):805-10. 810 e1. 2. [pmid: 19376304].
Fonseca N, Caetano F, Santos J, et al. Transesophageal echocardiography-guided cardioversion of atrial fibrillation. Selection of a low-risk group for immediate cardioversion. Rev Port Cardiol. 2004;23(3):365-75. [pmid: 15185562].
Friberg L, Rosenqvist M, Lip GY. Net clinical benefit of warfarin in patients with atrial fibrillation: a report from the Swedish atrial fibrillation cohort study. Circulation. 2012;125(19):2298-307. [pmid: 22514252].
Fukuda S, Watanabe H, Shimada K, et al. Left atrial thrombus and prognosis after anticoagulation therapy in patients with atrial fibrillation. J Cardiol. 2011;58(3):266-77. [pmid: 21824749].
Gage BF, van Walraven C, Pearce L, et al. Selecting patients with atrial fibrillation for anticoagulation: stroke risk stratification in patients taking aspirin. Circulation. 2004;110(16):2287-92. [pmid: 15477396].
Gaita F, Caponi D, Pianelli M, et al. Radiofrequency catheter ablation of atrial fibrillation: a cause of silent thromboembolism? Magnetic resonance imaging assessment of cerebral thromboembolism in patients undergoing ablation of atrial fibrillation. Circulation. 2010;122(17):1667-73. [pmid: 20937975].
Ghate SR, Biskupiak JE, Ye X, et al. Hemorrhagic and thrombotic events associated with generic substitution of warfarin in patients with atrial fibrillation: a retrospective analysis. Ann Pharmacother. 2011;45(6):701-12. [pmid: 21666081].
Giralt-Steinhauer E, Cuadrado-Godia E, Ois A, et al. Comparison between CHADS (2) and CHA (2) DS (2)-VASc score in a stroke cohort with atrial fibrillation. Eur J Neurol. 2012. [pmid: 22834861].
Go AS, Hylek EM, Phillips KA, et al. Implications of stroke risk criteria on the anticoagulation decision in nonvalvular atrial fibrillation: the Anticoagulation and Risk Factors in Atrial Fibrillation (ATRIA) study. Circulation. 2000;102(1):11-3. [pmid: 10880408].
Gupta S, Wagner JS, Goren A, et al. The risk of stroke and preventative steps among patients diagnosed with atrial fibrillation in the United States. Value Health. 2011;14(3):A45.
Haeusler KG, Konieczny M, Endres M, et al. Impact of anticoagulation before stroke on stroke severity and long-term survival. Int J Stroke. 2011. [pmid: 22111868].
Hanna IR, Kolm P, Martin R, et al. Left atrial structure and function after percutaneous left atrial appendage transcatheter occlusion (PLAATO): six-month echocardiographic follow-up. J Am Coll Cardiol. 2004;43(10):1868-72. [pmid: 15145113].
Ho LY, Siu CW, Yue WS, et al. Safety and efficacy of oral anticoagulation therapy in Chinese patients with concomitant atrial fibrillation and hypertension. J Hum Hypertens. 2011;25(5):304-10. [pmid: 20596062].
Hoppensteadt D, Fareed J, Klein AL, et al. Comparison of anticoagulant and anti-inflammatory responses using enoxaparin versus unfractionated heparin for transesophageal echocardiography-guided cardioversion of atrial fibrillation. Am J Cardiol. 2008;102(7):842-6. [pmid: 18805108].
Igarashi Y, Kasai H, Yamashita F, et al. Lipoprotein(a), left atrial appendage function and thromboembolic risk in patients with chronic nonvalvular atrial fibrillation. Jpn Circ J. 2000;64(2):93-8. [pmid: 10716521].
Ilercil A, Kondapaneni J, Hla A, et al. Influence of age on left atrial appendage function in patients with nonvalvular atrial fibrillation. Clin Cardiol. 2001;24(1):39-44. [pmid: 11195605].
Ilic LM, Goldenberg EM. CHADS2 score predicts time interval free of atrial fibrillation in patients with symptomatic paroxysmal atrial fibrillation. Int J Cardiol. 2010;145(3):576-7. [pmid: 20580106].
Inoue H, Atarashi H. Risk factors for thromboembolism in patients with paroxysmal atrial fibrillation. Am J Cardiol. 2000;86(8):852-5. [pmid: 11024400].
Inoue H, Nozawa T, Hirai T, et al. Sex-related differences in the risk factor profile and medications of patients with atrial fibrillation recruited in J-TRACE. Circ J. 2010;74(4):650-4. [pmid: 20173301].
Ito T, Suwa M, Kobashi A, et al. Integrated backscatter assessment of left atrial spontaneous echo contrast in chronic nonvalvular atrial fibrillation: relation with clinical and echocardiographic parameters. J Am Soc Echocardiogr. 2000;13(7):666-73. [pmid: 10887351].
Ito T, Suwa M, Nakamura T, et al. Quantification of left atrial appendage spontaneous echo contrast in patients with chronic nonalvular atrial fibrillation. J Cardiol. 2001;37(6):325-33. [pmid: 11433808].
Jorge E, Pereira FS, Baptista R, et al. Anticoagulation in elderly patients with atrial fibrillation from the guidelines to the daily medical practice ORIGINAL (NON-ENGLISH) TITLE Terapeutica anti trombotica no idoso com fibrilhacao auricular das guidelines a pratica clinica. Acta Med Port. 2011;24(Suppl 2):293-300. [pmid: 22849915].
Kamath S, Blann AD, Chin BS, et al. A prospective randomized trial of aspirin-clopidogrel combination therapy and dose-adjusted warfarin on indices of thrombogenesis and platelet activation in atrial fibrillation. J Am Coll Cardiol. 2002;40(3):484-90. [pmid: 12142115].
Kaneko K, Hirono O, Fatema K, et al. Direct evidence that sustained dysfunction of left atrial appendage contributes to the occurrence of cardiogenic brain embolism in patients with paroxysmal atrial fibrillation. Intern Med. 2003;42(11):1077-83. [pmid: 14686745].
Kawabata H, Pan X, Simon T, et al. Examining the association between discontinuation of warfarin and preceding bleeding, during or resulting in hospitalization, in patients with atrial fibrillation. Eur Heart J. 2011;32(Suppl 1):466.
Khumri TM, Idupulapati M, Rader VJ, et al. Clinical and echocardiographic markers of mortality risk in patients with atrial fibrillation. Am J Cardiol. 2007;99(12):1733-6. [pmid: 17560884].
King A. Atrial fibrillation: Is dabigatran cost-effective compared with warfarin in patients with AF?. Nat Rev Cardiol. 2011;9(1):3. [pmid: 22124320].
Kleemann T, Becker T, Strauss M, et al. Prevalence and clinical impact of left atrial thrombus and dense spontaneous echo contrast in patients with atrial fibrillation and low CHADS2 score. Eur J Echocardiogr. 2009;10(3):383-8. [pmid: 18835820].
Klein AL, Murray RD, Grimm RA, et al. Bleeding complications in patients with atrial fibrillation undergoing cardioversion randomized to transesophageal echocardiographically guided and conventional anticoagulation therapies. Am J Cardiol. 2003;92(2):161-5. [pmid: 12860217].
Laguna P, Martin A, Del Arco C, et al. Differences among clinical classification schemes for predicting stroke in atrial fibrillation: implications for therapy in daily practice. Acad Emerg Med. 2005;12(9):828-34. [pmid: 16141016].
Lam YY, Yip GW, Yu CM, et al. Left atrial appendage closure with AMPLATZER cardiac plug for stroke prevention in atrial fibrillation: initial Asia-Pacific experience. Catheter Cardiovasc Interv. 2012;79(5):794-800. [pmid: 21542102].
Li-Saw-Hee FL, Blann AD, Lip GY. Effects of fixed low-dose warfarin, aspirin-warfarin combination therapy, and dose-adjusted warfarin on thrombogenesis in chronic atrial fibrillation. Stroke. 2000;31(4):828-33. [pmid: 10753983].
Lidell C, Svedberg LE, Lindell P, et al. Clopidogrel and warfarin: absence of interaction in patients receiving long-term anticoagulant therapy for non-valvular atrial fibrillation. Thromb Haemost. 2003;89(5):842-6. [pmid: 12719782].
Lin LY, Lee CH, Yu CC, et al. Risk factors and incidence of ischemic stroke in Taiwanese with nonvalvular atrial fibrillation-- a nation wide database analysis. Atherosclerosis. 2011;217(1):292-5. [pmid: 21513938].
Maehama T, Okura H, Imai K, et al. Usefulness of CHADS2 score to predict C-reactive protein, left atrial blood stasis, and prognosis in patients with nonrheumatic atrial fibrillation. Am J Cardiol. 2010;106(4):535-8. [pmid: 20691312].
Maltagliati A, Pepi M, Tamborini G, et al. Usefulness of multiplane transesophageal echocardiography in the recognition of artifacts and normal anatomical variants that may mimic left atrial thrombi in patients with atrial fibrillation. Ital Heart J. 2003;4(11):797-802. [pmid: 14699710].
Mason PK, Lake DE, DiMarco JP, et al. Impact of the CHA2DS2-VASc score on anticoagulation recommendations for atrial fibrillation. Am J Med. 2012;125(6):603.e1-6. [pmid: 22502952].
McBane RD, Hodge DO, Wysokinski WE. Clinical and echocardiographic measures governing thromboembolism destination in atrial fibrillation. Thromb Haemost. 2008;99(5):951-5. [pmid: 18449427].
Meier B, Palacios I, Windecker S, et al. Transcatheter left atrial appendage occlusion with Amplatzer devices to obviate anticoagulation in patients with atrial fibrillation. Catheter Cardiovasc Interv. 2003;60(3):417-22. [pmid: 14571497].
Mortada ME, Chandrasekaran K, Nangia V, et al. Periprocedural anticoagulation for atrial fibrillation ablation. J Cardiovasc Electrophysiol. 2008;19(4):362-6. [pmid: 18284509].
Muller I, Massberg S, Zierhut W, et al. Effects of aspirin and clopidogrel versus oral anticoagulation on platelet function and on coagulation in patients with nonvalvular atrial fibrillation (CLAFIB). Pathophysiol Haemost Thromb. 2002;32(1):16-24. [pmid: 12214159].
Naccarelli GV, Panaccio MP, Cummins G, et al. CHADS2 and CHA2DS2-VASc risk factors to predict first cardiovascular hospitalization among atrial fibrillation/atrial flutter patients. Am J Cardiol. 2012;109(10):1526-33. [pmid: 22360819].
Nakagawa K, Hirai T, Shinokawa N, et al. Aortic spontaneous echocardiographic contrast and hemostatic markers in patients with nonrheumatic atrial fibrillation. Chest. 2002;121(2):500-5. [pmid: 11834664].
Ohyama H, Hosomi N, Takahashi T, et al. Comparison of magnetic resonance imaging and transesophageal echocardiography in detection of thrombus in the left atrial appendage. Stroke. 2003;34(10):2436-9. [pmid: 12970519].
Okada Y, Shibazaki K, Kimura K, et al. Brain natriuretic peptide is a marker associated with thrombus in stroke patients with atrial fibrillation. J Neurol Sci. 2011;301(1–2):86-9. [pmid: 21094497].
Olshansky B, Heller EN, Mitchell LB, et al. Are transthoracic echocardiographic parameters associated with atrial fibrillation recurrence or stroke? Results from the Atrial Fibrillation Follow-Up Investigation of Rhythm Management (AFFIRM) study. J Am Coll Cardiol. 2005;45(12):2026-33. [pmid: 15963405].
Olsson LG, Swedberg K, Lappas G, et al. Trends in stroke incidence after hospitalization for atrial fibrillation in Sweden 1987 to 2006. Int J Cardiol. 2012. [pmid: 22464487].
Omran H, Hardung D, Schmidt H, et al. Mechanical occlusion of the left atrial appendage. J Cardiovasc Electrophysiol. 2003;14(9 Suppl):S56-9. [pmid: 12950520].
Ozer N, Tokgozoglu L, Ovunc K, et al. Left atrial appendage function in patients with cardioembolic stroke in sinus rhythm and atrial fibrillation. J Am Soc Echocardiogr. 2000;13(7):661-5. [pmid: 10887350].
Palm F, Kleemann T, Dos Santos M, et al. Stroke due to atrial fibrillation in a population-based stroke registry (Ludwigshafen Stroke Study) CHADS(2), CHA(2) DS(2) -VASc score, underuse of oral anticoagulation, and implications for preventive measures. Eur J Neurol. 2012. [pmid: 22788384].
Parikh MG, Aziz Z, Krishnan K, et al. Usefulness of Transesophageal Echocardiography to Confirm Clinical Utility of CHA2DS2-VASc and CHADS2 Scores in Atrial Flutter. Am J Cardiol. 2012;109(4):550-5. [pmid: 22133753].
Pengo V, Legnani C, Noventa F, et al. Oral anticoagulant therapy in patients with nonrheumatic atrial fibrillation and risk of bleeding. A Multicenter Inception Cohort Study. Thromb Haemost. 2001;85(3):418-22. [pmid: 11307807].
Pink J, Lane S, Pirmohamed M, et al. Dabigatran etexilate versus warfarin in management of non-valvular atrial fibrillation in UK context: Quantitative benefit-harm and economic analyses. BMJ. 2011;343:d6333. [pmid: 22042753].
Poli D, Antonucci E, Marcucci R, et al. Risk of bleeding in very old atrial fibrillation patients on warfarin: relationship with ageing and CHADS2 score. Thromb Res. 2007;121(3):347-52. [pmid: 17597186].
Poli D, Antonucci E, Marcucci R, et al. The quality of anticoagulation on functional outcome and mortality for TIA/stroke in atrial fibrillation patients. Int J Cardiol. 2009;132(1):109-13. [pmid: 18180057].
Providencia R, Botelho A, Trigo J, et al. Possible refinement of clinical thromboembolism assessment in patients with atrial fibrillation using echocardiographic parameters. Europace. 2012;14(1):36-45. [pmid: 21868410].
Providencia R, Paiva L, Faustino A, et al. Cardiac troponin I: Prothrombotic risk marker in non-valvular atrial fibrillation. Int J Cardiol. 2012. [pmid: 22353438].
Providencia RA, Botelho A, Trigo J, et al. May echocardiographic data improve CHADS2 risk score?. Eur Heart J. 2011;32(Suppl 1):322.
Providencia RA, Trigo J, Botelho A, et al. Left atrial deformation for stroke risk prediction in atrial fibrillation: How and where?. Eur Heart J. 2011;32(Suppl 1):562-3.
Puwanant S, Varr BC, Shrestha K, et al. Role of the CHADS2 score in the evaluation of thromboembolic risk in patients with atrial fibrillation undergoing transesophageal echocardiography before pulmonary vein isolation. J Am Coll Cardiol. 2009;54(22):2032-9. [pmid: 19926009].
Rader VJ, Khumri TM, Idupulapati M, et al. Clinical predictors of left atrial thrombus and spontaneous echocardiographic contrast in patients with atrial fibrillation. J Am Soc Echocardiogr. 2007;20(10):1181-5. [pmid: 17566700].
Ren JF, Marchlinski FE, Callans DJ. Left atrial thrombus associated with ablation for atrial fibrillation: identification with intracardiac echocardiography. J Am Coll Cardiol. 2004;43(10):1861-7. [pmid: 15145112].
Ren JF, Marchlinski FE, Callans DJ, et al. Increased intensity of anticoagulation may reduce risk of thrombus during atrial fibrillation ablation procedures in patients with spontaneous echo contrast. J Cardiovasc Electrophysiol. 2005;16(5):474-7. [pmid: 15877616].
Rodriguez-Manero M, Cordero A, Bertomeu-Gonzalez V, et al. Impact of new criteria for anticoagulant treatment in atrial fibrillation. Rev Esp Cardiol. 2011;64(8):649-53. [pmid: 21652133].
Roldan V, Marin F, Diaz J, et al. High sensitivity cardiac troponin T and interleukin-6 predict adverse cardiovascular events and mortality in anticoagulated patients with atrial fibrillation. J Thromb Haemost. 2012;10(8):1500-7. [pmid: 22681487].
Saha SK, Anderson PL, Caracciolo G, et al. Global left atrial strain correlates with CHADS2 risk score in patients with atrial fibrillation. J Am Soc Echocardiogr. 2011;24(5):506-12. [pmid: 21477990].
Salazar DE, Mendell J, Kastrissios H, et al. Modelling and simulation of edoxaban exposure and response relationships in patients with atrial fibrillation. Thromb Haemost. 2012;107(5):925-34. [pmid: 22398655].
Salzberg SP, Plass A, Emmert MY, et al. Left atrial appendage clip occlusion: early clinical results. J Thorac Cardiovasc Surg. 2010;139(5):1269-74. [pmid: 19880144].
Sato S, Yazawa Y, Itabashi R, et al. Pre-admission CHADS2 score is related to severity and outcome of stroke. J Neurol Sci. 2011;307(1–2):149-52. [pmid: 21570092].
Schmidt H, von der Recke G, Illien S, et al. Prevalence of left atrial chamber and appendage thrombi in patients with atrial flutter and its clinical significance. J Am Coll Cardiol. 2001;38(3):778-84. [pmid: 11527633].
Schrickel JW, Lickfett L, Lewalter T, et al. Incidence and predictors of silent cerebral embolism during pulmonary vein catheter ablation for atrial fibrillation. Europace. 2010;12(1):52-7. [pmid: 19933517].
Shinokawa N, Hirai T, Takashima S, et al. A transesophageal echocardiographic study on risk factors for stroke in elderly patients with atrial fibrillation: a comparison with younger patients. Chest. 2001;120(3):840-6. [pmid: 11555518].
Shinokawa N, Hirai T, Takashima S, et al. Relation of transesophageal echocardiographic findings to subtypes of cerebral infarction in patients with atrial fibrillation. Clin Cardiol. 2000;23(7):517-22. [pmid: 10894440].
Sievert H, Lesh MD, Trepels T, et al. Percutaneous left atrial appendage transcatheter occlusion to prevent stroke in high-risk patients with atrial fibrillation: early clinical experience. Circulation. 2002;105(16):1887-9. [pmid: 11997272].
Singer DE, Chang Y, Fang MC, et al. Should patient characteristics influence target anticoagulation intensity for stroke prevention in nonvalvular atrial fibrillation?: the ATRIA study. Circ Cardiovasc Qual Outcomes. 2009;2(4):297-304. [pmid: 20031854].
Siracuse JJ, Robich MP, Gautam S, et al. Antiplatelet agents, warfarin, and epidemic intracranial hemorrhage. Surgery. 2010;148(4):724-9. discussion 729–30. [pmid: 20727562].
Smith SA, Binkley PF, Foraker RE, et al. The Role of Repeat Transesophageal Echocardiography in Patients without Atrial Thrombus Prior to Cardioversion or Ablation. J Am Soc Echocardiogr. 2012;25(10):1106-12. [pmid: 22749434].
Somme D, Corvol A, Lazarovici C, et al. Clinical usefulness in geriatric patients of combining CHADS2 and HEMORR2HAGES scores to guide antithrombotic prophylaxis in atrial fibrillation. Aging Clin Exp Res. 2010;22(4):289-94. [pmid: 19996707].
Tafur AJ, McBane R 2nd, Wysokinski WE, et al. Predictors of Major Bleeding in Peri-Procedural Anticoagulation Management. J Thromb Haemost. 2012;10(2):261-7. [pmid: 22123000].
Takada T, Yasaka M, Nagatsuka K, et al. Blood flow in the left atrial appendage and embolic stroke in nonvalvular atrial fibrillation. Eur Neurol. 2001;46(3):148-52. [pmid: 11598333].
Thomson R, Eccles M, Wood R, et al. A cautionary note on data sources for evidence-based clinical decisions: warfarin and stroke prevention. Med Decis Making. 2007;27(4):438-47. [pmid: 17641140].
Valocik G, Kamp O, Mihciokur M, et al. Assessment of the left atrial appendage mechanical function by three-dimensional echocardiography. Eur J Echocardiogr. 2002;3(3):207-13. [pmid: 12144840].
van Walraven C, Hart RG, Wells GA, et al. A clinical prediction rule to identify patients with atrial fibrillation and a low risk for stroke while taking aspirin. Arch Intern Med. 2003;163(8):936-43. [pmid: 12719203].
Vazquez E, Sanchez-Perales C, Borrego F, et al. Influence of atrial fibrillation on the morbido-mortality of patients on hemodialysis. Am Heart J. 2000;140(6):886-90. [pmid: 11099992].
Vene N, Mavri A, Kosmelj K, et al. High D-dimer levels predict cardiovascular events in patients with chronic atrial fibrillation during oral anticoagulant therapy. Thromb Haemost. 2003;90(6):1163-72. [pmid: 14652652].
Viles-Gonzalez JF, Kar S, Douglas P, et al. The clinical impact of incomplete left atrial appendage closure with the Watchman Device in patients with atrial fibrillation: a PROTECT AF (Percutaneous Closure of the Left Atrial Appendage Versus Warfarin Therapy for Prevention of Stroke in Patients With Atrial Fibrillation) substudy. J Am Coll Cardiol. 2012;59(10):923-9. [pmid: 22381428].
von der Recke G, Schmidt H, Illien S, et al. Use of transesophageal contrast echocardiography for excluding left atrial appendage thrombi in patients with atrial fibrillation before cardioversion. J Am Soc Echocardiogr. 2002;15(10 Pt 2):1256-61. [pmid: 12411914].
Wallvik J, Sjalander A, Johansson L, et al. Bleeding complications during warfarin treatment in primary healthcare centres compared with anticoagulation clinics. Scand J Prim Health Care. 2007;25(2):123-8. [pmid: 17497491].
Wang TD, Chen WJ, Su SS, et al. Increased levels of tissue plasminogen activator antigen and factor VIII activity in nonvalvular atrial fibrillation: relation to predictors of thromboembolism. J Cardiovasc Electrophysiol. 2001;12(8):877-84. [pmid: 11523531].
Weber R, Weimar C, Wanke I, et al. Risk of recurrent stroke in patients with silent brain infarction in the Prevention Regimen for Effectively Avoiding Second Strokes (PRoFESS) imaging substudy. Stroke. 2012;43(2):350-5. [pmid: 22267825].
Wehinger C, Stollberger C, Langer T, et al. Evaluation of risk factors for stroke/embolism and of complications due to anticoagulant therapy in atrial fibrillation. Stroke. 2001;32(10):2246-52. [pmid: 11588308].
Wilke T, Groth A, Mueller S, et al. Oral anticoagulation use by patients with atrial fibrillation in Germany. Adherence to guidelines, causes of anticoagulation under-use and its clinical outcomes, based on claims-data of 183,448 patients. Thromb Haemost. 2012;107(6):1053-65. [pmid: 22398417].
Wysokinski WE, Ammash N, Sobande F, et al. Predicting left atrial thrombi in atrial fibrillation. Am Heart J. 2010;159(4):665-71. [pmid: 20362727].
Zoppo F, Brandolino G, Berton A, et al. Predictors of left atrium appendage clot detection despite on-target warfarin prevention for atrial fibrillation. J Interv Card Electrophysiol. 2012;35(2):151-8. [pmid: 22869388].