# Exact Search Strings

## PubMed^®^ Search Strategy (August 14, 2012)

KQ1: In patients with nonvalvular atrial fibrillation, what are the comparative diagnostic accuracy and impact on clinical decisionmaking (diagnostic thinking, therapeutic, and patient outcome efficacy) of available clinical and imaging tools for predicting thromboembolic risk?

#1 | “Atrial Fibrillation”[Mesh] OR “atrial fibrillation”[tiab] OR (atrial[tiab] AND fibrillation[tiab]) OR afib[tiab] OR “atrial flutter”[MeSH Terms] OR “atrial flutter”[tiab]
#2 | chads2[tw] OR chads2-vasc[tw] OR “Magnetic Resonance Imaging”[Mesh] OR MRI[tw] OR “Cardiac Imaging Techniques”[Mesh] OR “Tomography, X-Ray Computed”[Mesh] OR “Echocardiography”[Mesh] OR ((transthoracic[tw] OR transesophageal[tw]) AND echo[tw]) OR TTE[tw] OR TEE[tw] OR CT-scan[tw]
#3 | “Stroke”[Mesh] OR stroke[tw] OR thromboembolism[tw] OR “Thromboembolism”[Mesh] OR thromboembolic[tw] OR “brain ischemia”[MeSH Terms] OR (brain[tw] AND ischemia[tw]) OR (brain[tw] AND ischaemia[tw]) OR (transient[tw] AND (ischemic[tw] OR ischaemic[tw] OR ischaemia[tw] OR ischemia[tw]) AND attack[tw]) OR TIA[tw]
#4 | #1 AND #2 AND #3
#5 | ((“diagnosis”[Subheading] OR “diagnosis”[tiab] OR “diagnosis”[MeSH Terms]) OR “treatment outcome”[MeSH Terms] OR outcome[tiab] OR outcomes[tiab]) OR (reliability[tw] OR accuracy[tw] OR accurate[tw] OR Sensitivity[tw] OR specificity[tw] OR “Sensitivity and Specificity”[Mesh] OR valid[tw] OR validity[tw] OR validation[tw] OR decision[tw] OR decisions[tw] OR “decision making”[MeSH Terms] OR assessment[tw])
#6 | #5 AND #4
#7 | #6 NOT (animals[mh] NOT humans[mh]), Limits: English, Publication Date from 2000 to present

KQ2: In patients with nonvalvular atrial fibrillation, what are the comparative diagnostic accuracy and impact on clinical decisionmaking (diagnostic thinking, therapeutic, and patient outcome efficacy) of clinical tools and associated risk factors for predicting bleeding events?

#1 | “Atrial Fibrillation”[Mesh] OR “atrial fibrillation”[tiab] OR (atrial[tiab] AND fibrillation[tiab]) OR afib[tiab] OR “atrial flutter”[MeSH Terms] OR “atrial flutter”[tiab]
#2 | “Age Factors”[Mesh] OR “Dementia”[Mesh] OR “Accidental Falls”[Mesh] OR “International Normalized Ratio”[Mesh] OR age[tiab] OR dementia[tiab] OR INR[tiab] OR fall[tiab] OR falls[tiab] OR “international normalized ratio”[tiab] OR paroxysmal[tiab] OR persistent[tiab] OR permanent[tiab] OR stratification[tiab] OR classification[tiab] OR schema[tiab] OR has-bled[tiab] OR (cognitive[tw] AND impairment[tw]) OR cognition[tw] OR ((prior[tiab] OR previous[tiab] OR first[tiab]) AND stroke[tiab])
#3 | “Intracranial Hemorrhages”[Mesh] OR “Hemorrhage”[Mesh:noexp] OR hemorrhage[tw] OR hemorrhaging[tw] OR bleeding[tw] OR bleed[tw] OR hemorrhagic[tw] OR haemorrhage[tw] OR haemorrhaging[tw] OR haemorrhagic[tw]
#4 | #1 AND #2 AND #3
#5 | ((“diagnosis”[Subheading] OR “diagnosis”[tiab] OR “diagnosis”[MeSH Terms]) OR “treatment outcome”[MeSH Terms] OR outcome[tiab] OR outcomes[tiab]) OR (reliability[tw] OR accuracy[tw] OR accurate[tw] OR Sensitivity[tw] OR specificity[tw] OR “Sensitivity and Specificity”[Mesh] OR valid[tw] OR validity[tw] OR validation[tw] OR decision[tw] OR decisions[tw] OR “decision making”[MeSH Terms] OR assessment[tw])
#6 | #5 AND #4
#7 | #6 NOT (animals[mh] NOT humans[mh]), Limits: English, Publication Date from 2000 to present

KQ3: What are the comparative safety and effectiveness of specific anticoagulation therapies, antiplatelet therapies, and procedural interventions for preventing thromboembolic events:

a. In patients with nonvalvular atrial fibrillation?
b. In specific subpopulations of patients with nonvalvular atrial fibrillation?

#1 | “Atrial Fibrillation”[Mesh] OR “atrial fibrillation”[tiab] OR (atrial[tiab] AND fibrillation[tiab]) OR afib[tiab] OR “atrial flutter”[MeSH Terms] OR “atrial flutter”[tiab]
#2 | “Anticoagulants”[Mesh] OR “Anticoagulants”[Pharmacological Action] OR warfarin[tw] OR “Warfarin”[Mesh] OR coumadin[tw] OR “Vitamin K/antagonists and inhibitors”[Mesh] OR vitamin k[tw] OR “Heparin”[Mesh] OR “Enoxaparin”[Mesh] OR enoxaparin[tw] OR lovenox[tw] OR “rivaroxaban” [Supplementary Concept] OR rivaroxaban[tw] OR xarelto[tw] OR “dabigatran etexilate” [Supplementary Concept] OR dabigatran[tw] OR pradaxa[tw] OR heparin[tw] OR “apixaban” [Supplementary Concept] OR apixaban[tw] OR eliquis[tw] OR “edoxaban” [Supplementary Concept] OR edoxaban[tw] OR lixiana[tw]
#3 | “Platelet Aggregation Inhibitors”[Mesh] OR “Platelet Aggregation Inhibitors”[Pharmacological Action] OR “clopidogrel” [Supplementary Concept]OR clopidogrel[tw] OR plavix[tw] OR “Aspirin”[Mesh] OR aspirin[tw] OR “Dipyridamole”[Mesh] OR dipyridamole[tw] OR aggrenox[tw] OR persantine[tw] OR antiplatelet[tw] OR anti-platelet[tw] OR antiplatelets[tw] OR anti-platelets[tw]
#4 | Atrial Appendage/surgery[mesh] OR atrial appendage[tw] OR LAA[tw] OR occluder[tw] OR AMPLATZER[tw] OR AtriClip[tw] OR PLAATO[tw] OR Watchman[tw] OR (atrial[tw] AND modification[tw]) OR “atriacure isolator”[tw]
#5 | “Stroke”[Mesh] OR stroke[tw] OR thromboembolism[tw] OR “Thromboembolism”[Mesh] OR thromboembolic[tw] OR “brain ischemia”[MeSH Terms] OR (brain[tw] AND ischemia[tw]) OR (brain[tw] AND ischaemia[tw]) OR (transient[tw] AND (ischemic[tw] OR ischaemic[tw] OR ischaemia[tw] OR ischemia[tw]) AND attack[tw]) OR TIA[tw]
#6 | #1 AND (#2 OR #3 OR #4) AND #5
#7 | “evaluation studies”[Publication Type] OR “evaluation studies as topic”[MeSH Terms] OR “evaluation study”[tw] OR evaluation studies[tw] OR “intervention studies”[MeSH Terms] OR “intervention study”[tw] OR “intervention studies”[tw] OR “case-control studies”[MeSH Terms] OR “case-control”[tw] OR “cohort studies”[MeSH Terms] OR cohort[tw] OR “longitudinal studies”[MeSH Terms] OR “longitudinal”[tw] OR longitudinally[tw] OR “prospective”[tw] OR prospectively[tw] OR “retrospective studies”[MeSH Terms] OR “retrospective”[tw] OR “follow up”[tw] OR “comparative study”[Publication Type] OR “comparative study”[tw] OR systematic[subset] OR “meta-analysis”[Publication Type] OR “meta-analysis as topic”[MeSH Terms] OR “meta-analysis”[tw] OR “meta-analyses”[tw] OR randomized controlled trial[pt] OR controlled clinical trial[pt] OR randomized[tiab] OR randomised[tiab] OR randomization[tiab] OR randomisation[tiab] OR placebo[tiab] OR “drug therapy”[Subheading] OR randomly[tiab] OR trial[tiab] OR groups[tiab] OR Clinical trial[pt] OR “clinical trial”[tw] OR “clinical trials”[tw] NOT (Editorial[ptyp] OR Letter[ptyp] OR Case Reports[ptyp] OR Comment[ptyp])
#8 | #7 AND #6
#9 | #8 NOT (animals[mh] NOT humans[mh]), Limits: English, Publication Date from 2000 to present

KQ4: What are the comparative safety and effectiveness of available strategies for anticoagulation in patients with nonvalvular atrial fibrillation who are undergoing invasive procedures?

#1 | “Atrial Fibrillation”[Mesh] OR “atrial fibrillation”[tiab] OR (atrial[tiab] AND fibrillation[tiab]) OR afib[tiab] OR “atrial flutter”[MeSH Terms] OR “atrial flutter”[tiab]
#2 | “Anticoagulants”[Mesh] OR “Anticoagulants”[Pharmacological Action] OR warfarin[tw] OR “Warfarin”[Mesh] OR coumadin[tw] OR “Vitamin K/antagonists and inhibitors”[Mesh] OR vitamin k[tw] OR “Heparin”[Mesh] OR “Enoxaparin”[Mesh] OR enoxaparin[tw] OR lovenox[tw] OR “rivaroxaban” [Supplementary Concept] OR rivaroxaban[tw] OR xarelto[tw] OR “dabigatran etexilate” [Supplementary Concept] OR dabigatran[tw] OR pradaxa[tw] OR heparin[tw] OR “apixaban” [Supplementary Concept] OR apixaban[tw] OR eliquis[tw] OR “edoxaban” [Supplementary Concept] OR edoxaban[tw] OR lixiana[tw]
#3 | “Surgical Procedures, Operative”[Mesh] OR/surgery[mesh] OR ((surgical[tw] OR invasive[tw]) AND (procedure[tw] OR procedures[tw])) OR “dental care”[MeSH Terms] OR (dental[tw] AND (procedure[tw] OR procedures[tw])) OR surgery[tw] OR procedures[tiab] OR procedure[tiab]
#4 | #1 AND #2 AND #3
#5 | “evaluation studies”[Publication Type] OR “evaluation studies as topic”[MeSH Terms] OR “evaluation study”[tw] OR evaluation studies[tw] OR “intervention studies”[MeSH Terms] OR “intervention study”[tw] OR “intervention studies”[tw] OR “case-control studies”[MeSH Terms] OR “case-control”[tw] OR “cohort studies”[MeSH Terms] OR cohort[tw] OR “longitudinal studies”[MeSH Terms] OR “longitudinal”[tw] OR longitudinally[tw] OR “prospective”[tw] OR prospectively[tw] OR “retrospective studies”[MeSH Terms] OR “retrospective”[tw] OR “follow up”[tw] OR “comparative study”[Publication Type] OR “comparative study”[tw] OR systematic[subset] OR “meta-analysis”[Publication Type] OR “meta-analysis as topic”[MeSH Terms] OR “meta-analysis”[tw] OR “meta-analyses”[tw] OR randomized controlled trial[pt] OR controlled clinical trial[pt] OR randomized[tiab] OR randomised[tiab] OR randomization[tiab] OR randomisation[tiab] OR placebo[tiab] OR “drug therapy”[Subheading] OR randomly[tiab] OR trial[tiab] OR groups[tiab] OR Clinical trial[pt] OR “clinical trial”[tw] OR “clinical trials”[tw] NOT (Editorial[ptyp] OR Letter[ptyp] OR Case Reports[ptyp] OR Comment[ptyp])
#6 | #5 AND #4
#7 | #7 NOT (animals[mh] NOT humans[mh]), Limits: English, Publication Date from 2000 to present

KQ5: What are the comparative safety and effectiveness of available strategies for switching between warfarin and other novel oral anticoagulants, in patients with nonvalvular atrial fibrillation?

#1 | “Atrial Fibrillation”[Mesh] OR “atrial fibrillation”[tiab] OR (atrial[tiab] AND fibrillation[tiab]) OR afib[tiab] OR “atrial flutter”[MeSH Terms] OR “atrial flutter”[tiab]
#2 | “warfarin”[MeSH Terms] OR warfarin[tw] OR coumadin[tw]
#3 | “antithrombins”[MeSH Terms] OR “antithrombins”[tiab] OR (“direct”[tiab] AND “thrombin”[tiab] AND “inhibitors”[tiab]) OR “direct thrombin inhibitors”[tiab] OR “antithrombins”[Pharmacological Action]
#4 | “Anticoagulants”[Mesh] OR “Anticoagulants” [Pharmacological Action] OR anticoagulant[tiab] OR anticoagulants[tiab]
#5 | “evaluation studies”[Publication Type] OR “evaluation studies as topic”[MeSH Terms] OR “evaluation study”[tw] OR evaluation studies[tw] OR “intervention studies”[MeSH Terms] OR “intervention study”[tw] OR “intervention studies”[tw] OR “case-control studies”[MeSH Terms] OR “case-control”[tw] OR “cohort studies”[MeSH Terms] OR cohort[tw] OR “longitudinal studies”[MeSH Terms] OR “longitudinal”[tw] OR longitudinally[tw] OR “prospective”[tw] OR prospectively[tw] OR “retrospective studies”[MeSH Terms] OR “retrospective”[tw] OR “follow up”[tw] OR “comparative study”[Publication Type] OR “comparative study”[tw] OR systematic[subset] OR “meta-analysis”[Publication Type] OR “meta-analysis as topic”[MeSH Terms] OR “meta-analysis”[tw] OR “meta-analyses”[tw] OR randomized controlled trial[pt] OR controlled clinical trial[pt] OR randomized[tiab] OR randomised[tiab] OR randomization[tiab] OR randomisation[tiab] OR placebo[tiab] OR “drug therapy”[Subheading] OR randomly[tiab] OR trial[tiab] OR groups[tiab] OR Clinical trial[pt] OR “clinical trial”[tw] OR “clinical trials”[tw] NOT (Editorial[ptyp] OR Letter[ptyp] OR Case Reports[ptyp] OR Comment[ptyp])
#6 | #1 AND #2 AND (#3 OR #4) AND #5
#7 | #6 NOT (animals[mh] NOT humans[mh]), Limits: English, Publication Date from 2000 to present

KQ6: What are the comparative safety and effectiveness of available strategies for resuming anticoagulation therapy or performing a procedural intervention as a stroke prevention strategy following a hemorrhagic event (stroke, major bleed, or minor bleed) in patients with nonvalvular atrial fibrillation?

#1 | “Atrial Fibrillation”[Mesh] OR “atrial fibrillation”[tiab] OR (atrial[tiab] AND fibrillation[tiab]) OR afib[tiab] OR “atrial flutter”[MeSH Terms] OR “atrial flutter”[tiab]
#2 | “Anticoagulants”[Mesh] OR “Anticoagulants”[Pharmacological Action] OR warfarin[tw] OR “Warfarin”[Mesh] OR coumadin[tw] OR “Vitamin K/antagonists and inhibitors”[Mesh] OR vitamin k[tw] OR “Heparin”[Mesh] OR “Enoxaparin”[Mesh] OR enoxaparin[tw] OR lovenox[tw] OR “rivaroxaban” [Supplementary Concept] OR rivaroxaban[tw] OR xarelto[tw] OR “dabigatran etexilate” [Supplementary Concept] OR dabigatran[tw] OR pradaxa[tw] OR heparin[tw] OR “apixaban” [Supplementary Concept] OR apixaban[tw] OR eliquis[tw] OR “edoxaban” [Supplementary Concept] OR edoxaban[tw] OR lixiana[tw]
#3 | “Intracranial Hemorrhages”[Mesh] OR “Hemorrhage”[Mesh:noexp] OR hemorrhage[tw] OR hemorrhaging[tw] OR bleeding[tw] OR bleed[tw] OR hemorrhagic[tw] OR haemorrhage[tw] OR haemorrhaging[tw] OR haemorrhagic[tw]
#4 | Resume[tiab] OR resumed[tiab] OR restart[tiab] OR restarted[tiab] OR restarting[tiab] OR re-initiate[tiab] OR reinitiate[tiab] OR continue[tiab] OR continued[tiab] OR start[tiab] OR “time factors”[MeSH Terms] OR resumption[tiab] OR reinitiating[tiab] OR resuming[tiab] OR continuing[tiab]
#5 | #1 AND #2 AND #3 AND #4
#6 | “evaluation studies”[Publication Type] OR “evaluation studies as topic”[MeSH Terms] OR “evaluation study”[tw] OR evaluation studies[tw] OR “intervention studies”[MeSH Terms] OR “intervention study”[tw] OR “intervention studies”[tw] OR “case-control studies”[MeSH Terms] OR “case-control”[tw] OR “cohort studies”[MeSH Terms] OR cohort[tw] OR “longitudinal studies”[MeSH Terms] OR “longitudinal”[tw] OR longitudinally[tw] OR “prospective”[tw] OR prospectively[tw] OR “retrospective studies”[MeSH Terms] OR “retrospective”[tw] OR “follow up”[tw] OR “comparative study”[Publication Type] OR “comparative study”[tw] OR systematic[subset] OR “meta-analysis”[Publication Type] OR “meta-analysis as topic”[MeSH Terms] OR “meta-analysis”[tw] OR “meta-analyses”[tw] OR randomized controlled trial[pt] OR controlled clinical trial[pt] OR randomized[tiab] OR randomised[tiab] OR randomization[tiab] OR randomisation[tiab] OR placebo[tiab] OR “drug therapy”[Subheading] OR randomly[tiab] OR trial[tiab] OR groups[tiab] OR Clinical trial[pt] OR “clinical trial”[tw] OR “clinical trials”[tw] NOT (Editorial[ptyp] OR Letter[ptyp] OR Case Reports[ptyp] OR Comment[ptyp])
#7 | #5 AND #6
#8 | #7 NOT (animals[mh] NOT humans[mh]), Limits: English, Publication Date from 2000 to present

## Embase^®^ Search Strategy (August 14, 2012)

Platform: Embase.com

KQ1: In patients with nonvalvular atrial fibrillation, what are the comparative diagnostic accuracy and impact on clinical decisionmaking (diagnostic thinking, therapeutic, and patient outcome efficacy) of available clinical and imaging tools for predicting thromboembolic risk?

#1 | ‘heart atrium fibrillation’/exp OR ‘heart atrium flutter’/exp OR “atrial fibrillation”:ab,ti OR (atrial:ab,ti AND fibrillation:ab,ti) OR afib:ab,ti OR “atrial flutter”:ab,ti
#2 | ‘nuclear magnetic resonance imaging’/exp OR ‘cardiac imaging’/exp OR ‘computer assisted tomography’/exp OR ‘echocardiography’/exp OR chads2:ab,ti OR ‘chads2 vasc’:ab,ti OR (transthoracic:ab,ti AND echo:ab,ti) OR (transesophageal:ab,ti AND echo:ab,ti) OR tte:ab,ti OR tee:ab,ti OR ‘ct scan’:ab,ti
#3 | ‘stroke’/exp OR ‘thromboembolism’/exp OR ‘brain ischemia’/exp OR stroke:ab,ti OR thromboembolism:ab,ti OR thromboembolic:ab,ti OR (brain:ab,ti AND ischemia:ab,ti) OR (brain:ab,ti AND ischaemia:ab,ti) OR (transient:ab,ti AND (ischemic:ab,ti OR ischaemic:ab,ti OR ischaemia:ab,ti OR ischemia:ab,ti) AND attack:ab,ti) OR TIA:ab,ti
#4 | #1 AND #2 AND #3
#5 | ‘diagnosis’/exp OR ‘treatment outcome’/exp OR ‘sensitivity and specificity’/exp OR ‘clinical decision making’/exp OR ‘decision making’/exp OR diagnosis:ab,ti OR outcome:ab,ti OR outcomes:ab,ti OR reliability:ab,ti OR accuracy:ab,ti OR accurate:ab,ti OR Sensitivity:ab,ti OR specificity:ab,ti OR valid:ab,ti OR validity:ab,ti OR validation:ab,ti OR decision:ab,ti OR decisions:ab,ti OR assessment:ab,ti
#6 | #5 AND #4
#7 | #6 Limits: Humans, English, 2000 - present
#8 | #7 AND [embase]/lim NOT [medline]/lim

KQ2: In patients with nonvalvular atrial fibrillation, what are the comparative diagnostic accuracy and impact on clinical decisionmaking (diagnostic thinking, therapeutic, and patient outcome efficacy) of clinical tools and associated risk factors for predicting bleeding events?

#1 | ‘heart atrium fibrillation’/exp OR ‘heart atrium flutter’/exp OR “atrial fibrillation”:ab,ti OR (atrial:ab,ti AND fibrillation:ab,ti) OR afib:ab,ti OR “atrial flutter”:ab,ti
#2 | ‘age’/exp OR ‘dementia’/exp OR ‘falling’/exp OR ‘international normalized ratio’/exp OR “age factors”:ab,ti OR “age factor”:ab,ti OR age:ab,ti OR dementia:ab,ti OR INR:ab,ti OR fall:ab,ti OR falls:ab,ti OR “international normalized ratio”:ab,ti OR paroxysmal:ab,ti OR persistent:ab,ti OR permanent:ab,ti OR stratification:ab,ti OR classification:ab,ti OR schema:ab,ti OR has-bled:ab,ti OR (cognitive:ab,ti AND impairment:ab,ti) OR cognition:ab,ti OR ((prior:ab,ti OR previous:ab,ti OR first:ab,ti) AND stroke:ab,ti)
#3 | ‘brain hemorrhage’/exp OR ‘bleeding’/exp OR hemorrhage:ab,ti OR hemorrhaging:ab,ti OR bleeding:ab,ti OR bleed:ab,ti OR hemorrhagic:ab,ti OR haemorrhage:ab,ti OR haemorrhaging:ab,ti OR haemorrhagic:ab,ti
#4 | #1 AND #2 AND #3
#5 | ‘diagnosis’/exp OR ‘treatment outcome’/exp OR ‘sensitivity and specificity’/exp OR ‘clinical decision making’/exp OR ‘decision making’/exp OR diagnosis:ab,ti OR outcome:ab,ti OR outcomes:ab,ti OR reliability:ab,ti OR accuracy:ab,ti OR accurate:ab,ti OR Sensitivity:ab,ti OR specificity:ab,ti OR valid:ab,ti OR validity:ab,ti OR validation:ab,ti OR decision:ab,ti OR decisions:ab,ti OR assessment:ab,ti
#6 | #5 AND #4
#7 | #6 Limits: Humans, English, 2000 - present
#8 | #7 AND [embase]/lim NOT [medline]/lim

KQ3: What are the comparative safety and effectiveness of specific anticoagulation therapies, antiplatelet therapies, and procedural interventions for preventing thromboembolic events:

a. In patients with nonvalvular atrial fibrillation?
b. In specific subpopulations of patients with nonvalvular atrial fibrillation?

#1 | ‘heart atrium fibrillation’/exp OR ‘heart atrium flutter’/exp OR “atrial fibrillation”:ab,ti OR (atrial:ab,ti AND fibrillation:ab,ti) OR afib:ab,ti OR “atrial flutter”:ab,ti
#2 | ‘anticoagulant agent’/exp OR ‘warfarin’/exp OR ‘vitamin K group’/exp OR ‘heparin’/exp OR ‘enoxaparin’/exp OR ‘rivaroxaban’/exp OR ‘dabigatran etexilate’/exp OR ‘apixaban’/exp OR ‘edoxaban’/exp
#3 | warfarin:ab,ti OR coumadin:ab,ti OR vitamin k:ab,ti OR enoxaparin:ab,ti OR lovenox:ab,ti OR rivaroxaban:ab,ti OR xarelto:ab,ti OR dabigatran:ab,ti OR pradaxa:ab,ti OR heparin:ab,ti OR apixaban:ab,ti OR eliquis:ab,ti OR edoxaban:ab,ti OR lixiana:ab,ti
#4 | #2 OR #3
#5 | ‘antithrombocytic agent’/exp OR ‘clopidogrel’/exp OR ‘acetylsalicylic acid’/exp OR ‘dipyridamole’/exp OR clopidogrel:ab,ti OR plavix:ab,ti OR aspirin:ab,ti OR dipyridamole:ab,ti OR aggrenox:ab,ti OR persantine:ab,ti OR antiplatelet:ab,ti OR anti-platelet:ab,ti OR antiplatelets:ab,ti OR anti-platelets:ab,ti
#6 | ‘heart atrium appendage’/exp OR atrial appendage:ab,ti OR LAA:ab,ti OR occluder:ab,ti OR AMPLATZER:ab,ti OR AtriClip:ab,ti OR PLAATO:ab,ti OR Watchman:ab,ti OR (atrial:ab,ti AND modification:ab,ti) OR “atriacure isolator”:ab,ti
#7 | ‘stroke’/exp OR ‘thromboembolism’/exp OR ‘brain ischemia’/exp OR stroke:ab,ti OR thromboembolism:ab,ti OR thromboembolic:ab,ti OR (brain:ab,ti AND ischemia:ab,ti) OR (brain:ab,ti AND ischaemia:ab,ti) OR (transient:ab,ti AND (ischemic:ab,ti OR ischaemic:ab,ti OR ischaemia:ab,ti OR ischemia:ab,ti) AND attack:ab,ti) OR TIA:ab,ti
#8 | #1 AND (#4 OR #5 OR #6) AND #7
#9 | (‘randomized controlled trial’/exp OR ‘crossover procedure’/exp OR ‘double blind procedure’/exp OR ‘single blind procedure’/exp OR random*:ab,ti OR factorial*:ab,ti OR crossover*:ab,ti OR (cross NEAR/1 over*):ab,ti OR placebo*:ab,ti OR (doubl* NEAR/1 blind*):ab,ti OR (singl* NEAR/1 blind*):ab,ti OR assign*:ab,ti OR allocat*:ab,ti OR volunteer*:ab,ti OR ‘clinical study’/exp OR “clinical trial”:ti,ab OR “clinical trials”:ti,ab OR ‘controlled study’/exp OR ‘evaluation’/exp OR “evaluation study”:ab,ti OR “evaluation studies”:ab,ti OR “intervention study”:ab,ti OR “intervention studies”:ab,ti OR “case control”:ab,ti OR ‘cohort analysis’/exp OR cohort:ab,ti OR longitudinal*:ab,ti OR prospective:ab,ti OR prospectively:ab,ti OR retrospective:ab,ti OR ‘follow up’/exp OR “follow up”:ab,ti OR ‘comparative effectiveness’/exp OR ‘comparative study’/exp OR “comparative study”:ab,ti OR “comparative studies”:ab,ti OR ‘evidence based medicine’/exp OR “systematic review”:ab,ti OR “meta-analysis”:ab,ti OR “meta-analyses”:ab,ti) NOT (‘editorial’/exp OR ‘letter’/exp OR ‘case report’/exp)
#10 | #8 AND #9
#11 | #10 Limits: Humans, English, 2000 - present
#12 | #11 AND [embase]/lim NOT [medline]/lim

KQ4: What are the comparative safety and effectiveness of available strategies for anticoagulation in patients with nonvalvular atrial fibrillation who are undergoing invasive procedures?

#1 | ‘heart atrium fibrillation’/exp OR ‘heart atrium flutter’/exp OR “atrial fibrillation”:ab,ti OR (atrial:ab,ti AND fibrillation:ab,ti) OR afib:ab,ti OR “atrial flutter”:ab,ti
#2 | ‘anticoagulant agent’/exp OR ‘warfarin’/exp OR ‘vitamin K group’/exp OR ‘heparin’/exp OR ‘enoxaparin’/exp OR ‘rivaroxaban’/exp OR ‘dabigatran etexilate’/exp OR ‘apixaban’/exp OR ‘edoxaban’/exp
#3 | warfarin:ab,ti OR coumadin:ab,ti OR vitamin k:ab,ti OR enoxaparin:ab,ti OR lovenox:ab,ti OR rivaroxaban:ab,ti OR xarelto:ab,ti OR dabigatran:ab,ti OR pradaxa:ab,ti OR heparin:ab,ti OR apixaban:ab,ti OR eliquis:ab,ti OR edoxaban:ab,ti OR lixiana:ab,ti
#4 | #2 OR #3
#5 | ‘surgery’/exp OR ‘dental care’/exp OR ((surgical:ab,ti OR invasive:ab,ti) AND (procedure:ab,ti OR procedures:ab,ti)) OR (dental:ab,ti AND (procedure:ab,ti OR procedures:ab,ti)) OR surgery:ab,ti OR procedures:ab,ti OR procedure:ab,ti
#6 | #1 AND #4 AND #5
#7 | (‘randomized controlled trial’/exp OR ‘crossover procedure’/exp OR ‘double blind procedure’/exp OR ‘single blind procedure’/exp OR random*:ab,ti OR factorial*:ab,ti OR crossover*:ab,ti OR (cross NEAR/1 over*):ab,ti OR placebo*:ab,ti OR (doubl* NEAR/1 blind*):ab,ti OR (singl* NEAR/1 blind*):ab,ti OR assign*:ab,ti OR allocat*:ab,ti OR volunteer*:ab,ti OR ‘clinical study’/exp OR “clinical trial”:ti,ab OR “clinical trials”:ti,ab OR ‘controlled study’/exp OR ‘evaluation’/exp OR “evaluation study”:ab,ti OR “evaluation studies”:ab,ti OR “intervention study”:ab,ti OR “intervention studies”:ab,ti OR “case control”:ab,ti OR ‘cohort analysis’/exp OR cohort:ab,ti OR longitudinal*:ab,ti OR prospective:ab,ti OR prospectively:ab,ti OR retrospective:ab,ti OR ‘follow up’/exp OR “follow up”:ab,ti OR ‘comparative effectiveness’/exp OR ‘comparative study’/exp OR “comparative study”:ab,ti OR “comparative studies”:ab,ti OR ‘evidence based medicine’/exp OR “systematic review”:ab,ti OR “meta-analysis”:ab,ti OR “meta-analyses”:ab,ti) NOT (‘editorial’/exp OR ‘letter’/exp OR ‘case report’/exp)
#8 | #6 AND #7
#9 | #8 Limits: Humans, English, 2000 - present
#10 | #9 AND [embase]/lim NOT [medline]/lim

KQ5: What are the comparative safety and effectiveness of available strategies for switching between warfarin and other novel oral anticoagulants, in patients with nonvalvular atrial fibrillation?

#1 | ‘heart atrium fibrillation’/exp OR ‘heart atrium flutter’/exp OR “atrial fibrillation”:ab,ti OR (atrial:ab,ti AND fibrillation:ab,ti) OR afib:ab,ti OR “atrial flutter”:ab,ti
#2 | ‘warfarin’/exp OR warfarin:ab,ti OR coumadin:ab,ti
#3 | antithrombins:ab,ti OR (direct:ab,ti AND thrombin:ab,ti AND inhibitors:ab,ti) OR (direct:ab,ti AND thrombin:ab,ti AND inhibitor:ab,ti) OR “direct thrombin inhibitors”:ab,ti OR “Antithrombin III”:ab,ti OR “Antithrombin Proteins”:ab,ti OR argatroban:ab,ti OR bivalirudin:ab,ti OR “Heparin Cofactor II”:ab,ti OR Hirudins:ab,ti OR inogatran:ab,ti OR lepirudin:ab,ti OR melagatran:ab,ti OR “SDZ MTH 958”:ab,ti OR ximelagatran:ab,ti
#4 | ‘anticoagulant agent’/exp OR anticoagulant:ab,ti OR anticoagulants:ab,ti
#5 | (‘randomized controlled trial’/exp OR ‘crossover procedure’/exp OR ‘double blind procedure’/exp OR ‘single blind procedure’/exp OR random*:ab,ti OR factorial*:ab,ti OR crossover*:ab,ti OR (cross NEAR/1 over*):ab,ti OR placebo*:ab,ti OR (doubl* NEAR/1 blind*):ab,ti OR (singl* NEAR/1 blind*):ab,ti OR assign*:ab,ti OR allocat*:ab,ti OR volunteer*:ab,ti OR ‘clinical study’/exp OR “clinical trial”:ti,ab OR “clinical trials”:ti,ab OR ‘controlled study’/exp OR ‘evaluation’/exp OR “evaluation study”:ab,ti OR “evaluation studies”:ab,ti OR “intervention study”:ab,ti OR “intervention studies”:ab,ti OR “case control”:ab,ti OR ‘cohort analysis’/exp OR cohort:ab,ti OR longitudinal*:ab,ti OR prospective:ab,ti OR prospectively:ab,ti OR retrospective:ab,ti OR ‘follow up’/exp OR “follow up”:ab,ti OR ‘comparative effectiveness’/exp OR ‘comparative study’/exp OR “comparative study”:ab,ti OR “comparative studies”:ab,ti OR ‘evidence based medicine’/exp OR “systematic review”:ab,ti OR “meta-analysis”:ab,ti OR “meta-analyses”:ab,ti) NOT (‘editorial’/exp OR ‘letter’/exp OR ‘case report’/exp)
#6 | #1 AND #2 AND (#3 OR #4) AND #5
#7 | #6 Limits: Humans, English, 2000 - present
#8 | #7 AND [embase]/lim NOT [medline]/lim

KQ6: What are the comparative safety and effectiveness of available strategies for resuming anticoagulation therapy or performing a procedural intervention as a stroke prevention strategy following a hemorrhagic event (stroke, major bleed, or minor bleed) in patients with nonvalvular atrial fibrillation?

#1 | ‘heart atrium fibrillation’/exp OR ‘heart atrium flutter’/exp OR “atrial fibrillation”:ab,ti OR (atrial:ab,ti AND fibrillation:ab,ti) OR afib:ab,ti OR “atrial flutter”:ab,ti
#2 | ‘anticoagulant agent’/exp OR ‘warfarin’/exp OR ‘vitamin K group’/exp OR ‘heparin’/exp OR ‘enoxaparin’/exp OR ‘rivaroxaban’/exp OR ‘dabigatran etexilate’/exp OR ‘apixaban’/exp OR ‘edoxaban’/exp
#3 | warfarin:ab,ti OR coumadin:ab,ti OR vitamin k:ab,ti OR enoxaparin:ab,ti OR lovenox:ab,ti OR rivaroxaban:ab,ti OR xarelto:ab,ti OR dabigatran:ab,ti OR pradaxa:ab,ti OR heparin:ab,ti OR apixaban:ab,ti OR eliquis:ab,ti OR edoxaban:ab,ti OR lixiana:ab,ti
#4 | #2 OR #3
#5 | ‘brain hemorrhage’/exp OR ‘bleeding’/exp OR hemorrhage:ab,ti OR hemorrhaging:ab,ti OR bleeding:ab,ti OR bleed:ab,ti OR hemorrhagic:ab,ti OR haemorrhage:ab,ti OR haemorrhaging:ab,ti OR haemorrhagic:ab,ti
#6 | ‘time’/exp OR resume:ab,ti OR resumed:ab,ti OR restart:ab,ti OR restarted:ab,ti OR restarting:ab,ti OR re-initiate:ab,ti OR reinitiate:ab,ti OR continue:ab,ti OR continued:ab,ti OR start:ab,ti OR resumption:ab,ti OR reinitiating:ab,ti OR resuming:ab,ti OR continuing:ab,ti
#7 | #1 AND #4 AND #5 AND #6
#8 | (‘randomized controlled trial’/exp OR ‘crossover procedure’/exp OR ‘double blind procedure’/exp OR ‘single blind procedure’/exp OR random*:ab,ti OR factorial*:ab,ti OR crossover*:ab,ti OR (cross NEAR/1 over*):ab,ti OR placebo*:ab,ti OR (doubl* NEAR/1 blind*):ab,ti OR (singl* NEAR/1 blind*):ab,ti OR assign*:ab,ti OR allocat*:ab,ti OR volunteer*:ab,ti OR ‘clinical study’/exp OR “clinical trial”:ti,ab OR “clinical trials”:ti,ab OR ‘controlled study’/exp OR ‘evaluation’/exp OR “evaluation study”:ab,ti OR “evaluation studies”:ab,ti OR “intervention study”:ab,ti OR “intervention studies”:ab,ti OR “case control”:ab,ti OR ‘cohort analysis’/exp OR cohort:ab,ti OR longitudinal*:ab,ti OR prospective:ab,ti OR prospectively:ab,ti OR retrospective:ab,ti OR ‘follow up’/exp OR “follow up”:ab,ti OR ‘comparative effectiveness’/exp OR ‘comparative study’/exp OR “comparative study”:ab,ti OR “comparative studies”:ab,ti OR ‘evidence based medicine’/exp OR “systematic review”:ab,ti OR “meta-analysis”:ab,ti OR “meta-analyses”:ab,ti) NOT (‘editorial’/exp OR ‘letter’/exp OR ‘case report’/exp)
#9 | #7 AND #8
#10 | #9 Limits: Humans, English, 2000 - present
#11 | #10 AND [embase]/lim NOT [medline]/lim

## Cochrane Search Strategy (August 14, 2012)

Platform: Wiley

Database searched: Cochrane Database of Systematic Reviews

KQ1: In patients with nonvalvular atrial fibrillation, what are the comparative diagnostic accuracy and impact on clinical decisionmaking (diagnostic thinking, therapeutic, and patient outcome efficacy) of available clinical and imaging tools for predicting thromboembolic risk?

#1 | (atrial fibrillation OR atrial flutter):ti,ab,kw
#2 | Magnetic Resonance Imaging explode all trees OR MeSH descriptor Cardiac Imaging Techniques explode all trees OR MeSH descriptor Tomography, X-Ray Computed explode all trees OR MeSH descriptor Echocardiography explode all trees OR (chads2 OR chads2-vasc OR TEE OR TTE OR ct-scan OR transthoracic echo OR transesophageal echo):ti,ab,kw
#3 | MeSH descriptor Stroke explode all trees OR MeSH descriptor Thromboembolism explode all trees OR MeSH descriptor Brain Ischemia explode all trees OR (thromboembolism OR thromboembolic OR brain ischemia OR brain ischaemia OR tia):ti,ab,kw OR (transient ischemic attack):ti,ab,kw or (transient ischaemic attack):ti,ab,kw or (transient ischemia attack):ti,ab,kw or (transient ischaemic attack):ti,ab,kw
#4 | #1 AND #2 AND #3
#5 | #4, Limits: Cochrane Reviews, 2000 to 2012

KQ2: In patients with nonvalvular atrial fibrillation, what are the comparative diagnostic accuracy and impact on clinical decisionmaking (diagnostic thinking, therapeutic, and patient outcome efficacy) of clinical tools and associated risk factors for predicting bleeding events?

#1 | (atrial fibrillation OR atrial flutter):ti,ab,kw
#2 | MeSH descriptor Age Factors explode all trees OR MeSH descriptor Dementia explode all trees OR MeSH descriptor Accidental Falls explode all trees OR MeSH descriptor International Normalized Ratio explode all trees OR age:ti,ab,kw OR dementia:ti,ab,kw OR INR:ti,ab,kw OR fall:ti,ab,kw OR falls:ti,ab,kw OR “international normalized ratio”:ti,ab,kw OR paroxysmal:ti,ab,kw OR persistent:ti,ab,kw OR permanent:ti,ab,kw OR stratification:ti,ab,kw OR classification:ti,ab,kw OR schema:ti,ab,kw OR has-bled:ti,ab,kw OR cognitive impairment:ti,ab,kw OR cognition:ti,ab,kw OR ((prior:ti,ab,kw OR previous:ti,ab,kw OR first:ti,ab,kw) AND stroke:ti,ab,kw)
#3 | MeSH descriptor Intracranial Hemorrhages explode all trees OR MeSH descriptor Hemorrhage explode all trees OR hemorrhage:ti,ab,kw OR hemorrhaging:ti,ab,kw OR bleeding:ti,ab,kw OR bleed:ti,ab,kw OR hemorrhagic:ti,ab,kw OR haemorrhage:ti,ab,kw OR haemorrhaging:ti,ab,kw OR haemorrhagic:ti,ab,kw
#4 | #1 AND #2 AND #3
#5 | MeSH descriptor Diagnosis explode all trees OR MeSH descriptor Treatment Outcome explode all trees OR MeSH descriptor Sensitivity and Specificity explode all trees OR MeSH descriptor Decision Making explode all trees OR diagnosis:ti,ab,kw OR outcome:ti,ab,kw OR outcomes:ti,ab,kw OR reliability:ti,ab,kw OR accuracy:ti,ab,kw OR accurate:ti,ab,kw OR Sensitivity:ti,ab,kw OR specificity:ti,ab,kw OR valid:ti,ab,kw OR validity:ti,ab,kw OR validation:ti,ab,kw OR decision:ti,ab,kw OR decisions:ti,ab,kw OR assessment:ti,ab,kw
#6 | #4 AND #5
#7 | #6, Limits: Cochrane Reviews, 2000 to 2012

KQ3: What are the comparative safety and effectiveness of specific anticoagulation therapies, antiplatelet therapies, and procedural interventions for preventing thromboembolic events:

a. In patients with nonvalvular atrial fibrillation?
b. In specific subpopulations of patients with nonvalvular atrial fibrillation?

#1 | (atrial fibrillation OR atrial flutter):ti,ab,kw
#2 | MeSH descriptor Anticoagulants explode all trees OR warfarin:ti,ab,kw OR coumadin:ti,ab,kw OR vitamin k:ti,ab,kw OR enoxaparin:ti,ab,kw OR lovenox:ti,ab,kw OR rivaroxaban:ti,ab,kw OR xarelto:ti,ab,kw OR dabigatran:ti,ab,kw OR pradaxa:ti,ab,kw OR heparin:ti,ab,kw OR apixaban:ti,ab,kw OR eliquis:ti,ab,kw OR edoxaban:ti,ab,kw OR lixiana:ti,ab,kw OR anticoagulants:ti,ab,kw OR OR anticoagulant:ti,ab,kw
#3 | MeSH descriptor Platelet Aggregation Inhibitors explode all trees OR clopidogrel:ti,ab,kw OR plavix:ti,ab,kw OR aspirin:ti,ab,kw OR dipyridamole:ti,ab,kw OR aggrenox:ti,ab,kw OR persantine:ti,ab,kw OR antiplatelet:ti,ab,kw OR anti-platelet:ti,ab,kw OR antiplatelets:ti,ab,kw OR anti-platelets:ti,ab,kw
#4 | MeSH descriptor Atrial Appendage explode all trees OR atrial appendage:ti,ab,kw OR LAA:ti,ab,kw OR occluder:ti,ab,kw OR AMPLATZER:ti,ab,kw OR AtriClip:ti,ab,kw OR PLAATO:ti,ab,kw OR Watchman:ti,ab,kw OR (atrial:ti,ab,kw AND modification:ti,ab,kw) OR “atriacure isolator”:ti,ab,kw
#5 | MeSH descriptor Stroke explode all trees OR MeSH descriptor Thromboembolism explode all trees OR MeSH descriptor Brain Ischemia explode all trees OR (thromboembolism OR thromboembolic OR brain ischemia OR brain ischaemia OR tia):ti,ab,kw OR (transient ischemic attack):ti,ab,kw or (transient ischaemic attack):ti,ab,kw or (transient ischemia attack):ti,ab,kw or (transient ischaemic attack):ti,ab,kw
#6 | #1 AND (#2 OR #3 OR #4) AND #5
#7 | #6, Limits: Cochrane Reviews, 2000 to 2012

KQ4: What are the comparative safety and effectiveness of available strategies for anticoagulation in patients with nonvalvular atrial fibrillation who are undergoing invasive procedures?

#1 | (atrial fibrillation OR atrial flutter):ti,ab,kw
#2 | MeSH descriptor Anticoagulants explode all trees OR warfarin:ti,ab,kw OR coumadin:ti,ab,kw OR vitamin k:ti,ab,kw OR enoxaparin:ti,ab,kw OR lovenox:ti,ab,kw OR rivaroxaban:ti,ab,kw OR xarelto:ti,ab,kw OR dabigatran:ti,ab,kw OR pradaxa:ti,ab,kw OR heparin:ti,ab,kw OR apixaban:ti,ab,kw OR eliquis:ti,ab,kw OR edoxaban:ti,ab,kw OR lixiana:ti,ab,kw OR anticoagulants:ti,ab,kw OR OR anticoagulant:ti,ab,kw
#3 | MeSH descriptor Surgical Procedures, Operative explode all trees OR MeSH descriptor Dental Care explode all trees OR surgical:ti,ab,kw OR invasive:ti,ab,kw OR procedures:ti,ab,kw OR surgery:ti,ab,kw OR procedure:ti,ab,kw
#4 | #1 AND #2 AND #3
#5 | #4, Limits: Cochrane Reviews, 2000 to 2012

KQ5: What are the comparative safety and effectiveness of available strategies for switching between warfarin and other novel oral anticoagulants, in patients with nonvalvular atrial fibrillation?

#1 | (atrial fibrillation OR atrial flutter):ti,ab,kw
#2 | warfarin:ti,ab,kw OR coumadin:ti,ab,kw
#3 | MeSH descriptor Antithrombins explode all trees OR antithrombins:ti,ab,kw OR (direct:ti,ab,kw AND thrombin:ti,ab,kw AND inhibitors:ti,ab,kw) OR “direct thrombin inhibitors”:ti,ab,kw OR “direct thrombin inhibitor”:ti,ab,kw
#4 | MeSH descriptor Anticoagulants explode all trees OR anticoagulant:ti,ab,kw OR anticoagulants:ti,ab,kw OR vitamin k:ti,ab,kw OR enoxaparin:ti,ab,kw OR lovenox:ti,ab,kw OR rivaroxaban:ti,ab,kw OR xarelto:ti,ab,kw OR dabigatran:ti,ab,kw OR pradaxa:ti,ab,kw OR heparin:ti,ab,kw OR apixaban:ti,ab,kw OR eliquis:ti,ab,kw OR edoxaban:ti,ab,kw OR lixiana:ti,ab,kw
#5 | #1 AND #2 AND (#3 OR #4)
#6 | #5, Limits: Cochrane Reviews, 2000 to 2012

KQ6: What are the comparative safety and effectiveness of available strategies for resuming anticoagulation therapy or performing a procedural intervention as a stroke prevention strategy following a hemorrhagic event (stroke, major bleed, or minor bleed) in patients with nonvalvular atrial fibrillation?

#1 | (atrial fibrillation OR atrial flutter):ti,ab,kw
#2 | MeSH descriptor Anticoagulants explode all trees OR warfarin:ti,ab,kw OR coumadin:ti,ab,kw OR vitamin k:ti,ab,kw OR enoxaparin:ti,ab,kw OR lovenox:ti,ab,kw OR rivaroxaban:ti,ab,kw OR xarelto:ti,ab,kw OR dabigatran:ti,ab,kw OR pradaxa:ti,ab,kw OR heparin:ti,ab,kw OR apixaban:ti,ab,kw OR eliquis:ti,ab,kw OR edoxaban:ti,ab,kw OR lixiana:ti,ab,kw OR anticoagulant:ti,ab,kw OR anticoagulants:ti,ab,kw
#3 | MeSH descriptor Intracranial Hemorrhages explode all trees OR MeSH descriptor Hemorrhage explode all trees OR hemorrhage:ti,ab,kw OR hemorrhaging:ti,ab,kw OR bleeding:ti,ab,kw OR bleed:ti,ab,kw OR hemorrhagic:ti,ab,kw OR haemorrhage:ti,ab,kw OR haemorrhaging:ti,ab,kw OR haemorrhagic:ti,ab,kw
#4 | MeSH descriptor Time Factors explode all trees OR Resume:ti,ab,kw OR resumed:ti,ab,kw OR restart:ti,ab,kw OR restarted:ti,ab,kw OR restarting:ti,ab,kw OR re-initiate:ti,ab,kw OR reinitiate:ti,ab,kw OR continue:ti,ab,kw OR continued:ti,ab,kw OR start:ti,ab,kw OR resumption:ti,ab,kw OR reinitiating:ti,ab,kw OR resuming:ti,ab,kw OR continuing:ti,ab,kw
#5 | #1 AND #2 AND #3 AND #4
#6 | #5, Limits: Cochrane Reviews, 2000 to 2012

## Grey Literature Searches

### ClinicalTrials.gov (August 22, 2012)

KQ1, KQ2, KQ3, KQ6
Condition | atrial fibrillation OR afib OR atrial flutter
Outcome | stroke OR thromboembolism OR thromboembolic OR “brain ischemia” OR “brain ischaemia” OR (transient AND ischemic AND attack) OR TIA OR hemorrhage OR hemorrhaging OR bleeding OR bleed OR hemorrhagic OR haemorrhage OR haemorrhaging OR haemorrhagic

KQ4
Condition | atrial fibrillation OR afib OR atrial flutter
Intervention | Anticoagulants OR anticoagulation OR warfarin OR coumadin OR vitamin k OR Heparin OR enoxaparin OR lovenox OR rivaroxaban OR xarelto OR dabigatran OR pradaxa OR apixaban OR eliquis OR edoxaban OR lixiana
Search Terms | Surgery OR procedures OR procedure

KQ5
Condition | atrial fibrillation OR afib OR atrial flutter
Intervention | (warfarin OR Coumadin) AND (Antithrombins OR antithrombin OR (direct AND thrombin AND (inhibitors OR inhibitor)) OR anticoagulant OR anticoagulants)

Total number of results: 186

### WHO: International Clinical Trials Registry Platform Search Portal (August 17, 2012)

KQs 1–6
Condition | atrial fibrillation OR afib OR atrial flutter
Recruiting status | ALL

Total number of results: 858

### ProQuest COS Conference Papers Index (August 14, 2012)

KQ1, KQ2, KQ3, KQ6
#1 | All (atrial fibrillation OR afib OR atrial flutter)
#3 | All (stroke OR thromboembolism OR thromboembolic OR “brain ischemia” OR “brain ischaemia” OR (transient AND (ischemic OR ischaemic) AND attack) OR TIA OR hemorrhage OR hemorrhaging OR bleeding OR bleed OR hemorrhagic OR haemorrhage OR haemorrhaging OR haemorrhagic)
#4 | #1 AND #2 AND #3

KQ4
#1 | All (atrial fibrillation OR afib OR atrial flutter)
#2 | All (Anticoagulants OR anticoagulation OR warfarin OR coumadin OR vitamin k OR Heparin OR enoxaparin OR lovenox OR rivaroxaban OR xarelto OR dabigatran OR pradaxa OR apixaban OR eliquis OR edoxaban OR lixiana)
#3 | All (Surgery OR procedures OR procedure)
#4 | #1 AND #2 AND #3

KQ5
#1 | All (atrial fibrillation OR afib OR atrial flutter)
#2 | All (warfarin OR Coumadin)
#3 | All (Antithrombins OR antithrombin OR (direct AND thrombin AND (inhibitors OR inhibitor)) OR anticoagulant OR anticoagulants)
#6 | #1 AND #2 AND #3

Total number of results: 352