# Abbreviations

AF: atrial fibrillation
AHRQ: Agency for Healthcare Research and Quality
ARISTOTLE: Apixaban for Reduction in Stroke and Other Thromboembolic Events in Atrial Fibrillation
ASA: aspirin
ATRIA: Anticoagulation and Risk Factors in Atrial Fibrillation
AVERROES: Apixaban Versus Acetylsalicylic acid (ASA) to Prevent Stroke in Atrial Fibrillation Patients Who Have Failed or Are Unsuitable for Vitamin K Antagonist Treatment
BRI: Bleeding Risk Index
BRIDGE: Bridging Anticoagulation in Patients who Require Temporary Interruption of Warfarin Therapy for an Elective Invasive Procedure or Surgery
CDSR: Cochrane Database of Systematic Reviews
CER: Comparative Effectiveness Review
CHADS_2_: Congestive heart failure, Hypertension, Age ≥75, Diabetes mellitus, prior Stroke/transient ischemic attack (2 points)
CHA_2_DS_2_-VASc: Congestive heart failure/left ventricular ejection fraction ≤ 40%, Hypertension, Age ≥75 (2 points), Diabetes mellitus, prior Stroke/transient ischemic attack/thromboembolism (2 points), Vascular disease, Age 65–74, Sex category female
CI: confidence interval
CT: computed tomography
eGFR: estimated glomerular filtration rate
ESC: European Society of Cardiology
FDA: U.S. Food and Drug Administration
GUSTO: Global Use of Strategies to Open Occluded Coronary Arteries
GWTG: Get With The Guidelines
HAS-BLED: Hypertension, Abnormal renal/liver function, Stroke, Bleeding history or predisposition, Labile international normalized ratio, Elderly (>65 years), Drugs/alcohol concomitantly
HEMORR_2_HAGES: Hepatic or renal disease, Ethanol abuse, Malignancy, Older (age >75 years), Reduced platelet count or function, Re-bleeding risk (2 points), Hypertension (uncontrolled), Anemia, Genetic factors, Excessive fall risk, Stroke
HR: hazard ratio
ICH: intracranial hemorrhage
INR: international normalized ratio
ISTH: International Society on Thrombosis and Haemostasis
ITT: intention-to-treat
IV: intravenous
KQ: Key Question
LAA: left atrial appendage
LMWH: low molecular weight heparin
MI: myocardial infarction
MRA: magnetic resonance angiography
MRI: magnetic resonance imaging
NIH: National Institutes of Health
NRI: net reclassification improvement
OR: odds ratio
PCI: percutaneous coronary intervention
PICOTS: Populations, Interventions, Comparators, Outcomes, Timings, and Settings of interest
PRISMA: Preferred Reporting Items for Systematic Reviews and Meta-Analyses
QUADAS-2: QUality Assessment tool for Diagnostic Accuracy Studies-2
RCT: randomized controlled trial
RE-LY: Randomized Evaluation of Long-Term Anticoagulation Therapy
RFA: radiofrequency ablation
ROCKET AF: Rivaroxaban Once-daily, oral, direct factor Xa inhibition compared with vitamin K antagonism for prevention of stroke and Embolism Trial in Atrial Fibrillation
RR: relative risk
SDT_INR_: standard deviation of transformed international normalized ratio
SE: standard error
TEE: transesophageal echocardiography
TEP: Technical Expert Panel
TIA: transient ischemic attack
TIMI: Thrombolysis in Myocardial Infarction
TTE: transthoracic echo
TTR: time in therapeutic range
VKA: vitamin K antagonist