# Results

Figure 2 provides details of the flow of studies and the final papers for review for the Key Questions (KQ).80 The search yielded 9,725 unique citations. This includes five citations added as a result of the grey literature search (one from the Scientific Information Packages (SIPs) that were received, (two from clinical trial registries and two from conference abstracts). During two levels of title and abstract screening, 8,891 articles were excluded. A total of 834 citations proceeded to full text screening. After the final eligibility screening, 73 publications passed through full text screening. From these, 52 publications (51 studies) were eligible for data extraction for KQ2. Appendix C contains the list of studies excluded at full text screening.

Figure 2 Flow diagram of citations in the Comparative Effectiveness Review of tinnitus

Figure 2 is a flow diagram indicating the numbers of citations included and excluded at each level of screening. In addition the reasons for exclusion at full text screening and sorting are included. The literature search yielded 9,725 unique citations. In total, 8,891 citations were excluded from further review following two levels of title and abstract screening. Out of the 834 citations promoted to full text screening, 761 were excluded. This left 52 articles (51 studies) that passed full text screening and proceeded to data extraction and quality assessment.

Not included in the results, 22 reports (21 studies) did not present measures of variance123–139 or they presented results as proportions.140–144 Details of these studies may be found in Appendix D.

## KQ1 In patients with symptoms of tinnitus (e.g., ringing in the ears, whooshing sounds, etc.) what is the comparative effectiveness of methods used to identify patients for further evaluation or treatment?

No studies addressing this question were identified in the literature search.

## KQ2 In adults with subjective idiopathic (nonpulsatile) tinnitus, what is the comparative effectiveness (and/or potential harms) of medical/surgical, sound treatment/technological, or psychological/behavioral interventions, including combinations of interventions?

A total of 51 studies (52 included publications)10,17,18,28,35,53,57,61,62,64,81–122 address KQ2. We organized the eligible studies based on intervention groupings suggested by the Technical Expert Panel. Results for this comparative effectiveness review (CER) are organized by type of intervention (i.e., pharmacological/food supplement; medical; sound technologies; and, psychological/behavioral). Within each intervention section, the discussion of the data is then organized by the primary outcomes: tinnitus-specific quality of life (TSQoL), perceived loudness, sleep disturbance, anxiety symptoms, depression symptoms, and global quality of life.

From the 51 eligible studies (52 publications), 21 studies (and one companion publication123) were not included in the results because they did not present measures of variance123–139 or they presented results as proportions.140–144 Where possible, forest plots were created for each outcome within the four groups of interventions showing the different treatments relative to inactive control. Forest plots for head-to-head trials were not generated as none of the active comparators were similar.

### Pharmacological or Food Supplement Interventions

#### Key Messages

Thirteen of 16^28,82,85,86,90,93,106,107,109,111,113–115,117,119,122^ studies had sample sizes less than 100 and most did not contain sample size calculations. Authors did not specify minimum clinically worthwhile differences on outcome measurement instruments. The ability of the instruments used to discriminate between treatment effects across study groups was questionable.

##### Tinnitus-Specific Quality of Life

- Nortriptyline, sertraline, acamprosate, and Deanxit were shown to produce some improvement in TSQoL. All comparisons were against placebo (participants in the Deanxit study received 1 mg clonazepam in addition to Deanxit or placebo).
- However, strength of evidence (SOE) was insufficient for all comparisons because of medium risk of bias and inconsistent and imprecise effect estimates.

##### Subjective Loudness

- Neurotransmitter drugs showed improvement in subjective loudness versus placebo; however SOE was low because risk of bias was medium and effect estimates were imprecise.
- SOE was insufficient for the anti-depressant, other drug, and food supplement groups (single studies in each of these groups evaluated the outcome).

##### Sleep Disturbance

- Paroxetine and vardenafil showed improvement in sleep disturbance versus placebo; no improvement was observed with Deanxit.
- However, SOE was insufficient because only one study for each intervention considered this outcome.

##### Depression Symptoms

- Sertraline, paroxetine, and nortriptyline showed improvements in depression symptoms versus placebo; however, SOE was insufficient because the risk of bias was moderate and effects were inconsistent and imprecise.
- Improvements were also seen in honeybee larvae versus hydrogenated dextrin; however, SOE was insufficient because only one honeybee larvae study evaluated this outcome.

##### Global Quality of Life

- Only sertraline showed improved global quality of life versus placebo; however, SOE was insufficient for all anti-depressants (sertraline, paroxetine, trazodone) versus placebo because the risk of bias was moderate and effects were inconsistent and imprecise.
- SOE was insufficient for acamprosate, vardenafil, and ginkgo biloba versus placebo because only one study for each intervention considered this outcome.

#### Characteristics of Included Studies

A total of 17 articles28,82,85,86,90,93,99,106,107,109,111,113–115,117,119,122 reported on 16 unique studies that evaluated interventions in the pharmacological or food supplement domain (Table 3; Appendix E, Table E1). Two articles99,122 pertained to the same study, with the followup publication99 containing additional data on global quality-of-life (QoL) as an outcome.

Table 3 Interventions and comparators used in studies that evaluate pharmacological and food supplement interventions and outcomes

Pharma/Food Intervention | # | Specific Intervention | Sleep | Anxiety Symptoms | Depression Symptoms | Loudness | Global QoL | Tinnitus-Specific QoL | Adverse Effects
Anti-depressant drugs | | INACTIVE COMPARATOR
Anti-depressant drugs | 1 | Sertraline (SSRI antidepressant) vs. placebo Zoger,122 2006 and Holgers,99 2011 | | HAS^*^, CPRS-S-A, PGWB-sub | HDS^*^, CPRS-S-A, PGWB-sub | VAS | PGWB | TSQ^*^ VAS | Yes
Anti-depressant drugs | 2 | Paroxetine (SSRI antidepressant) vs. placebo Robinson,113 2005 | PSQI | HADS-A, BAI^*^ | HADS-D, BDI^*^ | | QWB | THQ^*^, Likert-scale | Yes
Anti-depressant drugs | 3 | Trazodone (SARI antidepressant) vs. placebo Dib,90 2007 | | | | | VAS | VAS-s^*^ VAS-d | Yes
Anti-depressant drugs | 4 | Nortriptyline (2^nd^ gen tricyclic antidepressant) vs. placebo Sullivan,115 1993 | | Sheehan’s Disability | HDS | | | IOWA^*^, Likert-scale | Yes
Neuro-transmitter drugs | | INACTIVE COMPARATOR
Neuro-transmitter drugs | 1 | Gabapentin (GABA analogue – GABAergic) vs. placebo Piccirillo,109 2007 | | | | | | THI | Yes
Neuro-transmitter drugs | 2 | Baclofen (selective GABAB1 receptor agonist) vs. placebo Westerberg,119 1996 | | | | Subjective | | THI | Yes
Neuro-transmitter drugs | 3 | Alprazolam (benzodiazepine – anxiolytic) vs. placebo Johnson,28 1993 | | | | VAS | | | Yes
Neuro-transmitter drugs | 4 | Acamprosate (glutamate antagonist & GABA agonist) vs. placebo Sharma,114 2012 | | | | VAS | Subjective | | None
Neuro-transmitter drugs | 5 | Acamprosate vs. placebo Azevedo 2005,^82^ 2005 | | | | | | Subjective | Yes
Other drugs | | INACTIVE COMPARATOR
Other drugs | 1 | Methylprednisolone (intratympanic injection) vs. placebo Topak,117 2009 | | | | Self-rated | | TSI | Yes
Other drugs | 2 | Vardenafil (PDE5 inhibitor) vs. placebo Mazurek,106 2009 | TQ-sub | | | | SF-36 | TQ | Yes
Other drugs | 3 | Deanxit vs. placebo Meeus,107 2011 | TQ-sub | | BDI | VAS | | TQ VAS-Ann | None
Food supplements | | INACTIVE COMPARATOR
Food supplements | 1 | Gingko Biloba vs. placebo Rejali,111 2004 | | | | | GHSI | THI | Yes
Food supplements | 2 | Gingko vs. Placebo: only effect size reported Drew,93 2001 | | | | VAS | | TSQ (21-item) | Yes
Food supplements | 3 | Enzymolyzed honey bee larvae vs. placebo, Aoiki,85 2012 | | | THI-subscale | | | THI, VAS | Yes
Food supplements | 4 | Zinc vs. placebo Arda,86 2003 | | | | Subjective | | | Yes

Abbreviations: Ann = annoyance; BAI = Beck Anxiety Inventory; BDI = Beck Depression Inventory; CPRS-S-A = Comprehensive Psychopathological Rating Scale – Anxiety subscale; GABAB1 = gamma-aminobutyric acid B1; gen = generation; GHSI = Glasgow Health Status Inventory; HADS = Hospital Anxiety and Depression Scale; HADS-A = Hospital Anxiety and Depression Scale – Anxiety subscale; HADS-D = Hospital Anxiety and Depression Scale – Depression subscale; HAS = Hamilton Anxiety Rating Scale; HDS = Hamilton Depression Rating Scale; IOWA = IOWA disability scale for Tinnitus; HDS = Hospital Depression Scale; PDE5 = phosphodiesterase type 5; Pharma = Pharmacological; PGWB = Psychological General Well-Being index; PSQI = Pittsburg Sleep Quality Index; QoL = Quality of Life; QWB = Quality of Well-being Scale; SARI = serotonin antagonist reuptake inhibitor; SF-36 = Medical Outcomes Study 36-Item Short-Form Health Survey; SSRI = selective serotonin reuptake inhibitor; THI = Tinnitus Handicap Inventory; THQ = Tinnitus Handicapped Questionnaire; TQ = Tinnitus Questionnaire; TSI = Tinnitus Severity Index; TSQ = Tinnitus Severity Questionnaire; VAS = visual analogue scale; vs. = versus

* Indicates the test used to measure outcomes which were selected to represent the domain in the forest plots (and subsequent SOE decisions)

##### Population Duration and Severity

In ten studies,82,93,106,107,111,113,115,117,119,122 the majority of participants were male. The percentages of male participants in these studies ranged from 52 percent115 to 89 percent.107 Females formed the majority of participants in four studies,85,86,90,109 ranging from 59 percent86 to 79 percent.85 One article117 reported a male:female ratio of 2:1 in the active treatment group and 1.5:1 in the placebo group. Two publications28,114 did not report the percentages of males and females in the study populations.

All of the studies were conducted in primarily middle-age populations. Mean ages in 14 studies ranged from 42^122^ to 63.^85^ One study90 reported that 53 percent of participants were at least 60 years of age; another indicated that all participants fell within an age range of 18 to 65 years.28

The largest study analyzed data for 708 participants at the end of followup.93 The remaining 15 studies contained a mean of 62 participants, ranging in size from 28 persons107 to 95 persons.109

##### Intervention

Four studies (five publications)90,99,113,115,122 investigated anti-depressant drugs versus placebo. These drugs included sertraline,99,122 paroxetine,113 trazodone,90 and nortriptyline.115 Dosage levels in the sertraline, paroxetine, and nortriptyline articles were at the recommended levels for treating depression. However, the dosage level in the trazodone study was below the recommended dose for depression; the dosage level was instead suitable for use as a sleep aid. Five publications28,82,109,114,119 involving placebo comparators examined neurotransmitter drugs that enhance or stimulate γ-aminobutyric acid (GABA). The neurotransmitter drugs were gabapentin,109 baclofen,119 alprazolam,28 and acamprosate.82,114 Three studies investigated other drugs, including methylprednisolone versus placebo,117 vardenafil versus placebo,106 and Deanxit versus placebo (all participants received 1 mg clonazepam in addition to Deanxit or placebo).107 Four papers evaluated food supplements, with two93,111 focused on gingko biloba, one86 on zinc, and one85 on honeybee larvae. All food supplements were compared to placebo (which was hydrogenated dextrin in the larvae study).

Mean length of followup was 11 weeks. The shortest followup period was 3 weeks119 and the longest was 16 weeks.122

##### Comparators

Table 3 shows the interventions and comparators for studies in this grouping.

##### Outcomes

Of the six outcomes of interest, tinnitus-specific QoL was evaluated in 13 studies,82,85,90,93,106,107,109,111,113,115,117,119,122 subjective loudness in eight studies,28,86,93,107,114,117,119,122 sleep disturbance in three studies,106,107,113 anxiety symptoms in three studies,113,115,122 depression symptoms in five studies,85,107,113,115,122 and global QoL in six studies (Table 4).90,106,111,113,114,122 Adverse effects were reported in all except two studies.107,114 See Table 3 and Appendix E, Table E1.

Table 4 Outcome measurements used in pharmacological and food supplement intervention studies

Outcome | Outcome Measurement Used
Sleep disturbance | PSQI (Pittsburg Sleep Quality Index)113 TQ-subscale (Tinnitus Questionnaire subscale – sleep disturbance)106,107
Anxiety symptoms | HADS-A (Hospital Anxiety and Depression Scale – Anxiety subscale)99,113 CPRS-S-A (Comprehensive Psychopathological Rating Scale – Anxiety subscale)99 PGWB-subscale (Psychological General Well-being Index)99 BAI (Beck Anxiety Inventory)113 Sheehan’s Disability Scale115
Depression symptoms | HADS-D (Hospital Anxiety and Depression Scale – Depression subscale)99,113 HDS (Hospital Depression Scale)115 CPRS-S-A (Comprehensive Psychopathological Rating Scale – Anxiety subscale)99 PGWB-subscale (Psychological General Well-being Index)99 BDI (Beck Depression Inventory)107,113 THI-subscale (Tinnitus Handicap Inventory subscale)85
Subjective loudness | VAS (Visual Analogue Scale)28,93,99,107,114 Self-rated/subjective86,117,119
Global quality of life | PGWB (Psychological General Well-being Index)99,122 QWB (Quality of Well-being Scale)113 VAS (Visual Analogue Scale)90 SF-36^106^ GHSI (Glasgow Health Status Inventory)111 Subjective/self-rated114
Tinnitus-specific quality of life | TSQ (Tinnitus Severity Questionnaire)93,99 THQ (Tinnitus Handicapped Questionnaire)113 TQ (Tinnitus Questionnaire)106,107 VAS (Visual Analogue Scale)85,90,99,107 IOWA (IOWA disability scale)115 THI (Tinnitus Handicap Inventory)85,109,111,119 TSI (Tinnitus Severity Index)117 Likert-scale113,115 Subjective/self-rated82

##### Setting

Twelve studies28,86,106,107,109,111,113–115,117,119,122 were set in specialty clinics (i.e., ear-nose-throat). Three studies82,85,109 recruited participants through a university hospital, and another93 through advertisements in the national press or a tinnitus publication. One study90 did not report its setting.

##### Country

The studies were carried out in several different countries: Sweden;122 the United States;28,109,113,115,119 Brazil;82,90 India;114 Germany;106 Belgium;107 United Kingdom;93,111 Japan;85 and Turkey.86,117

##### Sources of Funding

Sources of funding were not reported in seven publications.28,82,86,90,111,114,117 In one of these studies, the author holds a patent for the use of the drug in Tinnitus.82 Ten publications received funding from research councils, foundations, and government departments and non-profit associations.85,93,106,107,109,113,115,119,122

#### Risk of Bias for Pharmacological and Food Supplement Interventions

The risk of bias, taken across all of the studies, was low to medium (Figure 3). Most of the major issues related to bias, assessed via the Jadad scale and supplemental questions on allocation concealment, intention-to-treat analysis, and justification of sample size, were related to reporting. All of the studies were RCTs, yet the authors of 9 publications did not describe the randomization procedure. In only one instance85 could we ascertain that the randomization method was inappropriate, i.e., the authors described it as an ‘alternating sequence’ based on 1:1 assignment into groups. Randomization procedures were appropriate in 6 studies.93,106,109,111,113,122

Figure 3 Distribution of methodological risk of bias criteria of randomized controlled trials for the pharmacological and food supplement interventions

Figure 3 depicts the risk of bias for pharmacological and food supplementation interventions. All of the studies were RCTs; yet in only 38% of cases the randomization process was deemed appropriate. Eighty-seven percent of articles reported using double blinding techniques, with only 62% of these being assessed as appropriate. Seventy-five percent of studies reported withdrawals by number and reason per arm, while only half reported the methods used to assess adverse effects. All studies reported inclusion and/or exclusion criteria, and most (94%) described the statistical analysis used. Forty-four percent of articles reported that the intervention/drug allocation was concealed. Only 31% reported that the analysis was based on “intention to treat” and only 38% justified their sample size.

Related to randomization is the issue of allocation concealment, i.e., the method(s) used to ensure that the randomization sequence remains hidden from the person(s) responsible for recruiting participants into studies. Nine studies85,86,90,93,106,109,113,117,122 reported, and seven28,82,107,111,114,115,119 did not report, the methods of allocation concealment. The methods in two studies were judged to be inappropriate.86,117

Fourteen studies contained specific mention of double-blinding. In four of these studies,82,107,111,114 the authors did not provide sufficient detail for us to assess whether the methods of double-blinding were appropriate. The two studies without double-blinding included the methylprednisolone trial117 (single-blinded) and one of the zinc studies86 (no blinding reported whatsoever).

Only half the studies28,93,106,109,113,117,119,122 reported the methods used to assess adverse effects. Since knowledge of adverse effects is necessary to support clinical decision making, which requires the consideration of benefits and harms,145 researchers must pay careful attention to how they ascertain these effects. Failure to report the methods in this regard raises the possibility that adverse effects were assessed in an ad hoc or unsystematic fashion, or not at all. Six studies82,85,86,90,107,111,115 that did not delineate methods for assessing adverse effects did actually report such effects. Two studies stated that there were no adverse effects reported.107,114

Five studies106,109,113,119,122 reported that participants were analyzed according to an intention-to-treat principle. Many of the other studies appeared to follow an intention-to-treat principle as well. RCTs should be analyzed using this principle to promote the unbiased assessment of efficacy in light of the extent to which study participants adhere to treatment.146 Given the added potential for bias when RCTs are not analyzed according to the intention-to-treat principle, authors should be clear about the methods they have used to analyze trial data.

Ten trials28,82,86,90,106,107,114,115,117,119 did not contain a justification for sample size. Since all except three studies contained samples of less than 100 persons, readers could legitimately raise the question of whether the studies had sufficient power to detect clinically important effects.

#### Results for Pharmacological or Food Supplement Interventions by Outcome

##### Tinnitus-Specific Quality of Life

Four studies82,107,115,122 assessed tinnitus-specific QoL by measuring discomfort, disturbance, or annoyance. Eleven studies85,93,106,107,109,111,113,115,117,119,122 examined tinnitus-specific QoL by measuring severity. One study used both.90 See Table 3 and Appendix E, Table E1.

All five studies82,90,107,115,122 examining discomfort, disturbance, or annoyance used some form of visual analogue or Likert-type scale to measure the outcome. The sertraline study122 used a 100 mm visual analogue scale (VAS) and found no statistically significant difference between groups. The trazodone study90 employed a 0- to 10-point scale and also found no difference between groups. Conversely, a paper82 describing results in 41 persons given acamprosate (333 mg taken 3 times daily) or placebo reported that 86.9 percent of participants receiving the active medication showed improvement (any reduction in score) on a 1- to 10-point ‘disturbance’ scale, which compared favorably to the 44.4 percent of participants in the placebo group who showed improvement (p=0.004). If improvement was defined as a 50 percent or greater reduction in score, then 47.8 percent in the acamprosate group and 11.1 percent in the placebo group were improved over followup (p=0.012). Note that two of the study authors hold the patent on use of acamprosate for tinnitus.

In the Deanxit crossover trial,107 discomfort was measured on a 0 to 100 VAS scale. Persons who received Deanxit after placebo (instead of placebo after Deanxit) showed improvement on the VAS at the end of followup (mean difference in score from baseline=9.5; p=0.024) (Figure 4). This study107 also used a Hyperacusis Questionnaire to assess annoyance and the authors reported that they did not find any significant between-group differences on this scale (no statistics presented in the publication).

Figure 4 Studies with inactive comparators that evaluate pharmacological and food supplement interventions and report tinnitus-specific quality of life outcomes

Note: A decrease in score indicates improvement.

This figure shows the effect size (standardized mean difference ‘SMD’) with 95% confidence interval for each study in a forest plot for pharmacological and food supplement interventions for the outcome of tinnitus specific quality of life. Eight studies show a SMD with 95% confidence interval that crosses 0 (no difference) between groups, while three studies show a SMD with 95% confidence interval less than 0 (Favors treatment group as compared to control group).

The nortriptyline study115 used a battery of instruments to measure discomfort. These instruments included the Multidimensional Pain Inventory (MPI) self and spouse evaluations, two VAS which measure life disruptions due to tinnitus (one examining ‘internally referred’ disruptions, another ‘externally referred’ disruptions), and a 5-point overall tinnitus disruption scale. The active treatment group had lower (better) mean scores on all instruments except the MPI spouse evaluation, with mean differences in score being significant on the MPI self-evaluation (mean difference=0.6; p<0.01) and VAS internal disruption (mean difference=0.9; p<0.05) (Figure 4).

Turning to the 12 studies85,90,93,106,107,109,111,113,115,117,119,122 that measured tinnitus-specific QoL as severity, a multitude of different instruments were used to assess the outcome. In 10 studies, between group differences were not statistically significant at the 5 percent level on the following instruments: Tinnitus Handicap Questionnaire (and a supplemental 8-point Likert scale, as well as the Disability Inventory),113 10-point VAS,85,90 Iowa Disability Scale,115 Tinnitus Handicap Inventory,109,111,119 Tinnitus Severity Index,117 Tinnitus Questionnaire,106 and a 21-item severity questionnaire based on existing instruments.93

In the sertraline study,122 the treated group experienced greater reductions in severity over 16 weeks of followup relative to the placebo group, as evidenced by larger mean changes in score on the Tinnitus Severity Questionnaire (i.e., 4.69 vs. 2.12; p=0.024).

In the Deanxit crossover trial,107 the authors subtracted mean scores on the Tinnitus Questionnaire after 7 weeks of followup from baseline scores. They reported that mean changes in score were higher in the group that received placebo followed by Deanxit (mean score change=11.0; p<0.001), compared to the group that received Deanxit followed by placebo (mean score change=7.9; p=0.001). However, conclusions about efficacy from this study are limited because the authors were investigating the sequence of treatment rather than a direct comparison of the effects of Deanxit versus placebo.

###### Strength of Evidence—Tinnitus-Specific Quality of Life

Strength of evidence was insufficient for tinnitus-specific QoL in the case of each intervention group (antidepressants, neurotransmitter drugs acting on GABA, other drugs and food supplements) relative to placebo comparators. Only honeybee larvae (versus hydrogenated dextrin) had other than a placebo comparator and SOE was also insufficient (Table 5). Effect sizes were inconsistent regarding direction of effect; included studies, when taken together, had medium risk of bias. Each intervention group was rated ‘imprecise’ under the precision domain because of small sample sizes and a lack of power calculations in the majority of included studies, as well as the heterogeneity of the interventions. Additionally, the published reports presented no evidence for dose response and the risk of publication bias was high given the small sample sizes.

Table 5 Strength of evidence: Studies that evaluate pharmacological and food supplement interventions compared to inactive control and report tinnitus-specific quality of life outcomes

Intervention Group | Specifics | # of Studies (n) | Risk of Bias | Consistency | Directness | Precision | Magnitude of the Effect SMD Range (CI) | SOE
Anti-depressants | Nortriptyline Paroxetine Sertraline Trazodone | 4^*,90,99,113,115,122^ | Medium | Inconsistent | Direct | Imprecise | −0.61 (−1.03 to −0.19) to 0.12 (−0.31 to 0.54) | Insufficient
Neuro-transmitter drugs | Acamprosate Baclofen Gabapentin | 3^82,109,119^ | Medium | Inconsistent | Direct | Imprecise | −1.57 (−2.28 to −0.86) to −0.01 (−0.38 to 0.35) | Insufficient
Other drugs | Deanxit, MEP, vardenafil | 3^106,107,117^ | Medium | Inconsistent | Direct | Imprecise | −0.68 (−1.21 to −0.16) to 0.35 (−0.26 to 0.86) | Insufficient
Food supplement | Gingko biloba Honeybee larvae | 3^85,93,111^ | Medium | Inconsistent | Direct | Imprecise | −0.21 (−0.72 to 0.30) to −0.21 (−0.72 to 0.30) | Insufficient

Abbreviations: CI = confidence interval; n = number; SOE = strength of evidence; SMD = standard mean difference

Note: all drugs were compared to placebo except honeybee larvae (versus hydrogeneated dextrin); Deanxit comparison was a crossover trial of Deanxit versus placebo, with each participant given 1 mg clonazapam in addition to Deanxit or placebo.

* four studies, five publications

##### Subjective Loudness

Eight publications28,86,93,107,114,117,119,122 examined loudness, primarily using subjective VAS-type scales (Tables 3 and 4). In two studies,86,122 active treatments had more impact on loudness than comparators. A group receiving sertraline had a greater mean reduction in score over the course of followup, measured on a 100 mm VAS, than placebo (15.21 vs. 5.15; p=0.014).122 A study comparing zinc (50 mg/day for 8 weeks) to placebo in 41 persons seen at ear-nose-throat clinics found the mean score to be 1.41 points lower in the zinc group (p<0.05) after 8 weeks of followup, as measured using a 7-item subjective loudness questionnaire (higher scores indicated more loudness).86

Four studies failed to find any differences (p>0.05) in loudness between treatment arms. These studies included baclofen (10 to 30 mg/day twice daily for 3 weeks) vs. placebo in 58 persons recruited from a tinnitus referral center (subjective 10-point scale),119 methylprednisolone solution (0.3 to 0.4 ml intratympanic injection of 62.5 mg/ml methylprednisolone) vs. saline in 59 persons recruited from an unreported setting (subjective 10-point scale),117 Deanxit vs. placebo (0 to 100 VAS),107 and ginkgo biloba (50 mg given 3 times daily) vs. placebo in persons who were recruited through advertisements placed in the national press and a tinnitus publication (6-point loudness scale) (Figure 5).93

Figure 5 Studies with inactive comparators that evaluate pharmacological and food supplement interventions and report subjective loudness outcomes

Note: A decrease in score indicates improvement.

This figure shows the effect size (standardized mean difference ‘SMD’) with 95% confidence interval for each study in a forest plot for pharmacological and food supplement interventions for the outcome of subjective loudness. Three studies show a SMD with 95% confidence interval that crosses 0 (no difference) between groups, while three studies show a SMD with 95% less than 0 (Favors treatment group as compared to control group).

In a study28 of alprazolam (25 to 50 mg/day) versus placebo in 36 persons recruited from a tinnitus registry and followed for 12 weeks, loudness was measured using a 10-point VAS and Norwest SG-1 tinnitus synthesizer. The authors did not provide between-group comparisons on each outcome; however, they stated that four of 17 persons in the alprazolam group, and 18 of 19 persons in the placebo group, experienced stable or increased loudness on either the VAS or synthesizer. Using these data, one may compute a relative risk of 0.25 (95% CI, 0.10 to 0.59), which means that the risk of stable or increased loudness was 75 percent less in the alprazolam group compared to the placebo group.

A crossover trial114 of acamprosate (333 mg twice daily for 45 days) versus placebo in 40 persons who were outpatients at an ear-nose-throat hospital measured loudness on a 10 cm VAS. The authors only present within-group comparisons in the text, but do mention that 92.5 percent of the treated group, and 12.5 percent of the placebo group, displayed improvement over the course of followup. However, the authors do not define improvement, which appears to be an amalgam of the loudness and global QoL outcomes. Nor do the authors conduct a statistical test to compare improvement between the two groups.

###### Strength of Evidence—Subjective Loudness

The SOE is insufficient for the anti-depressant, other drug, and food supplement groups because only use one study in each group could be used to make judgments about SOE. In the neurotransmitter drugs group, SOE is low, despite the fact that consistency across the results in three studies suggests benefits for these drugs. Risk of bias for the neurotransmitter drugs is medium and effect estimates are imprecise due to small sample sizes, a lack of power calculations, and the heterogeneity of the interventions. Additionally, all eight published reports presented no evidence for dose response and the risk of publication bias was high given the small sample sizes (Table 6).

Table 6 Strength of evidence: Studies that evaluate pharmacological and food supplement interventions compared to inactive control and report subjective loudness outcomes

Intervention Group | Specifics | # of Studies (n) | Risk of Bias | Consistency | Directness | Precision | Magnitude of the Effect SMD Range (CI) | SOE
Anti-depressants | Sertraline | 1^*,99,122^ | Low | Unknown (single study) | Direct | Imprecise | −0.45 (−0.95 to 0.05) | Insufficient
Neuro-transmitter drugs | Baclofen, alprazolam acamprosate | 3^28,114,119^ | Medium | Consistent | Direct | Imprecise | −2.08 (−2.87 to −1.30) to −0.29 (−0.79 to 0.22) | Low
Other drugs | MEP, Deanxit | 2^107,117^ | Medium | Unknown (single study) (Cannot calculate SMD in Deanxit study107) | Direct | Imprecise | −0.07 (−0.58 to 0.44) | Insufficient
Food supplement | Gingko biloba Zinc | 2^86,93^ | Medium | Unknown (single study) (Cannot calculate SMD in zinc study86) | Direct | Imprecise | −0.91 (−1.60 to −0.22) | Insufficient

Abbreviations: CI = confidence interval; MEP = methylprednisolone injections; n = number; SOE = strength of evidence; SMD = standard mean difference

Note: all drugs were compared to placebo; Deanxit comparison was a crossover trial of Deanxit versus placebo, with each participant given 1 mg clonazapam in addition to Deanxit or placebo.

* one study, two publications

##### Sleep Disturbance

Three studies looked at the outcome of sleep disturbance (Tables 3 and 4). One study113 investigating sleep compared paroxetine (50 mg/day) and placebo in 115 persons over 14 weeks of followup. Between-group differences in sleep quality, measured using the Pittsburg Sleep Quality Index (PSQI), were not statistically significantly different at the end of followup. Two studies106,107 examined sleep using the sleep disturbance subscale of the Tinnitus Questionnaire (TQ). The first106 of these two studies compared vardenafil (10 mg taken twice daily) against placebo and found no between-group differences (p=0.88) on the sleep disturbance subscale. The second of these two studies, a crossover trial107 of Deanxit (flupentixol 0.5 mg and melitracen 10 mg) and clonazepam (1 mg), compared to placebo and clonazepam, reported decreases in score following the first treatment phase, and increases in score following the second treatment phase, regardless of whether Deanxit or placebo was received first. However, the authors do not report a statistical comparison of these subscale results (Figure 6).

Figure 6 Studies with inactive comparators that evaluate pharmacological and food supplement interventions and report sleep disturbances outcomes

Note: A decrease in score indicates improvement.

This figure shows the effect size (standardized mean difference ‘SMD’) with 95% confidence interval for each study in a forest plot for pharmacological and food supplement interventions for the outcome of sleep disturbances. All studies show a SMD with 95% confidence interval that crosses 0 (no difference) between groups.

###### Strength of Evidence—Sleep Disturbance

The SOE is insufficient for sleep disturbance because we could only use one study in each of the two relevant intervention groups to make judgments about SOE (Table 7). In the other drug intervention group, studies of vardenafil106 and Deanxit107 were included in the review. However, the Deanxit study could not be used to assess SOE because the authors compared baseline scores to treatment order, i.e., whether participants received Deanxit before or after placebo. Thus, the comparison did not evaluate the efficacy of Deanxit versus placebo.

Table 7 Strength of evidence: Studies that evaluate pharmacological and food supplement interventions compared to inactive control and report sleep disturbance outcomes

Intervention Group | Specifics | # of Studies (n) | Risk of Bias | Consistency | Directness | Precision | Magnitude of the Effect SMD Range (CI) | SOE
Anti-depressant | Paroxetine | 1^113^ | Low | Unknown (single study) | Direct | Imprecise | 0.31 (−0.06 to 0.67) | Insufficient
Other drugs | Vardenafil, Deanxit | 2^106,107^ | Medium | Unknown (single study) (Cannot calculate SMD in Deanxit study107) | Direct | Imprecise | −0.09 (−0.69 to 0.52) | Insufficient

Abbreviations: CI = confidence interval; n = number; SOE = strength of evidence; SMD = standard mean difference

Note: all drugs were compared to placebo; Deanxit comparison was a crossover trial of Deanxit versus placebo, with each participant given 1 mg clonazapam in addition to Deanxit or placebo.

##### Anxiety Symptoms

Three placebo-controlled studies113,115,122 included anxiety as an outcome (Tables 3 and 4). Two studies (sertraline,122 paroxetine113) measured anxiety with the Hamilton Anxiety Rating Scale (HAS); one study113 also utilized the Beck Anxiety Inventory (BAI). The third study,115 of nortriptyline (50 to 150 mg/mL for 6 weeks) versus placebo, used Sheehan’s Disability Scales (SDS). The paroxetine study113 found greater improvements in score for the placebo group on the HAS and BAI, although the differences were not statistically significant. Conversely, a study122 of sertraline (50 mg/day) versus placebo in 63 persons found the mean score change over followup on the HADS to be larger in the treated group compared to the placebo group (8.51 vs. 4.09; p=0.04). On the SDS,115 the nortriptyline group showed slight improvement relative to the placebo group, but the difference was not statistically significant.

The sertraline study122 also measured anxiety using the Comprehensive Psychopathological Rating Scale (CPRS) anxiety subscale and in a companion paper,99 the Psychological General Well-being Index (PGWB), which contains an anxiety subindex. Over the course of followup, the sertraline group displayed a larger mean score change on the CPRS relative to the placebo group (4.38 vs. 0.73; p=0.013), which indicates a greater reduction in anxiety for persons receiving the active treatment. Likewise, the sertraline group also showed a larger mean score change versus the placebo group on the PGWB (4.59 vs. 0.61; p=0.002) (Figure 7).

Figure 7 Studies with inactive comparators that evaluate pharmacological and food supplement interventions and report anxiety symptom outcomes

Note: A decrease in score indicates improvement.

This figure shows the effect size (standardized mean difference ‘SMD’) with 95% confidence interval for each study in a forest plot for pharmacological and food supplement interventions for the outcome of anxiety symptoms. Two studies show a SMD with 95% confidence interval that crosses 0 (no difference) between groups, while only one study shows a SMD with 95% confidence interval less than 0 (Favors treatment group as compared to control group).

###### Strength of Evidence—Anxiety Symptoms

The SOE is insufficient with regard to suggesting whether anti-depressants are more efficacious than placebo in reducing anxiety in persons with tinnitus. Risk of bias is medium, direction of effect estimates is inconsistent, and the certainty around effect estimates is imprecise due to small sample sizes and the heterogeneity of the interventions. Additionally, all three published reports presented no evidence for dose response and the risk of publication bias was high given the small sample sizes (Table 8).

Table 8 Strength of evidence: Studies that evaluate pharmacological and food supplement interventions compared to inactive control and report anxiety symptoms outcomes

Intervention Group | Specifics | # of Studies (n) | Risk of Bias | Consistency | Directness | Precision | Magnitude of the Effect SMD Range (CI) | SOE
Anti-depressants | Sertraline Paroxetine Nortriptyline | 3^113,115,122^ | Medium | Inconsistent | Direct | Imprecise | −1.13 (−1.57 to −0.69) to 0.28 (−0.09 to 0.64) | Insufficient

Abbreviations: CI = confidence interval; n = number; SOE = strength of evidence; SMD = standard mean difference; SSRI = serotonin reuptake inhibitors

Note: all drugs were compared to placebo

##### Depression Symptoms

Five studies considered depression, with two113,122 utilizing more than one outcome measure (Tables 3 and 4). Three113,115,122 of the five trials measured depression with the Hamilton Depression Rating Scale (HAM-D), two107,113 with the Beck Depression Inventory (BDI), one with the CPRS depression subscale and PGWB depression subindex,99,122 and one85 with the depression question on the Tinnitus Handicap Inventory (THI). On the HAM-D, treated groups showed greater improvement than placebo when treated with sertraline (difference not significant)122 and nortriptyline (difference in mean score change over followup=3.7; p<0.05).115 In the sertraline study,99,122 the mean changes in score over followup on the CPRS depression subscale and PGWB depression subindex favored the treated group (CPRS: difference in mean change score=5.88, p=0.002; PGWB: difference in mean change score=2.22, p=0.002). For the paroxetine-placebo comparison,113 changes in score on the HAM-D and BDI were greater in the placebo group over the course of followup, although the differences were not statistically significant relative to the treated group. The authors of the Deanxit crossover107 wrote that they did not find between-group differences on the BDI; however, they did not report any numerical results or statistical calculations.

The final study in this outcome domain85 compared lyophilized powder of enzymolyzed honeybee larvae (720 mg given 4 times daily) to hydrogenated dextrin over 12 weeks of followup. The authors administered the THI to the 58 study participants and found only one between-group difference after conducting subgroup analyses for each of the THI’s 25 questions. On the depression question, the mean score difference at week 12 favored the honeybee larvae group (MSD=0.08; p<0.05) (Figure 8).

Figure 8 Studies with inactive comparators that evaluate the pharmacological and food supplement interventions and report depression symptoms outcomes

Note: A decrease in score indicates improvement.

This figure shows the effect size (standardized mean difference ‘SMD’) with 95% confidence interval for each study in a forest plot for pharmacological and food supplement interventions for the outcome of depression symptoms. Three studies show a SMD with 95% confidence interval that crosses 0 (no difference) between groups, while only one study shows a SMD with 95% confidence interval less than 0 (Favors treatment group as compared to control group).

###### Strength of Evidence—Depression Symptoms

The SOE is insufficient that anti-depressants99,113,115,122 (Table 9) improve depression symptoms relative to placebo because the risk of bias was moderate, effects were inconsistent and imprecise, no evidence was reported about dose response relations, and the small sample sizes could have led to publication bias. SOE is insufficient for Deanxit107 and honeybee larvae85 because only one study evaluated each of these interventions.

Table 9 Strength of evidence: Studies that evaluate pharmacological and food supplement interventions compared to inactive control and report depression symptoms outcomes

Intervention Group | Specifics | # of Studies (n) | Risk of Bias | Consistency | Directness | Precision | Magnitude of the Effect SMD Range (CI) | SOE
Anti-depressants | Sertraline Paroxetine Nortriptyline | 3^113,115,122^ | Medium | Inconsistent | Direct | Imprecise | −1.13 (−1.57 to −0.69) to 0.21 (−0.16 to 0.57) | Insufficient
Other drugs | Deanxit | 1^107^ | Medium | Unknown (single study) (Cannot calculate SMD in Deanxit study107) | Direct | Imprecise | | Insufficient
Food supplement | Honeybee larvae | 1^85^ | Medium | Unknown (single study) | Direct | Imprecise | −0.49 (−1.01 to 0.04) | Insufficient

Abbreviations: CI = confidence interval; n = number; SOE = strength of evidence; SMD = standard mean difference; SSRI = serotonin reuptake inhibitors

Note: all drugs were compared to placebo except honeybee larvae (versus hydrogeneated dextrin); Deanxit comparison was a crossover trial of Deanxit versus placebo, with each participant given 1 mg clonazapam in addition to Deanxit or placebo

##### Global Quality-of-Life

Six studies examined global QoL (Tables 3 and 4)90,106,111,113,114,122 and only one study (sertraline122) showed improvement versus placebo. The sertraline trial122 reported QoL results, measured using the PGWB, in a companion paper:99 after 16 weeks of followup, the improvement in mean score compared to baseline was greater in the treated group relative to the placebo group (20.83 vs. 2.79; p=0.001). In four other studies, global QoL was assessed using the Quality of Well-being Scale,113 a 10-point VAS,90 Short Form 36,^106^ or Glasgow Health Status Inventory.111 In these four studies, between-group differences in mean score changes over followup were extremely minimal and not suggestive of any particular direction of effect (Figure 9).

Figure 9 Studies with inactive comparators that evaluate pharmacological and food supplement interventions and report global quality of life outcomes

Note: A decrease in score indicates improvement.

This figure shows the effect size (standardized mean difference ‘SMD’) with 95% confidence interval for each study in a forest plot for pharmacological and food supplement interventions for the outcome of global quality of life. Four studies show a SMD with 95% confidence interval that crosses 0 (no difference) between groups, while two studies show a SMD with 95% confidence interval greater than 0 (Favors treatment group as compared to control group).

The acamprosate study114 utilized an unspecified QoL instrument that was linked to an incorrect citation. The authors combined outcomes and reported 92.5 percent improvement in the treated group and 12.5 percent improvement in the placebo group, although the paper does not indicate the portion of this improvement attributable to QoL.

###### Strength of Evidence—Global Quality-of-Life

The SOE is insufficient for anti-depressants versus placebo in global QoL, for the same reasons as outlined in the depression symptoms section above (Table 10). SOE is insufficient for acamprosate,114 vardenafil,106 and ginkgo biloba111 because only one study evaluated each of these interventions.

Table 10 Strength of evidence: Studies that evaluate pharmacological and food supplement interventions compared to inactive control and report global quality of life outcomes

Intervention Group | Specifics | # of Studies (n) | Risk of Bias | Consistency | Directness | Precision | Magnitude of the Effect SMD Range (CI) | SOE
Anti-depressants | Sertraline Paroxetine Trazodone | 3^90,113,122^ | Medium | Inconsistent | Direct | Imprecise | −0.24 (−0.60 to 0.13) to 1.06 (0.53 to 1.59) | Insufficient
Neuro-transmitter drugs | Acamprosate | 1^114^ | Medium | Unknown (single study) | Direct | Imprecise | 1.53 (0.82 to 2.25) | Insufficient
Other drugs | Vardenafil | 1^106^ | Low | Unknown (single study) | Direct | Imprecise | −0.22 (−0.83 to 0.38) | Insufficient
Food supplement | Ginkgo biloba | 1^111^ | Medium | Unknown (single study) | Direct | Imprecise | −0.07 (−0.58 to 0.44) | Insufficient

Abbreviations: CI = confidence interval; n = number; SOE = strength of evidence; SMD = standard mean difference; SSRI = serotonin reuptake inhibitors

Note: all drugs were compared to placebo

##### Adverse Effects

Adverse effects spanned a range of clinical severity, from dry or sour mouth90,113 to confusion,119 but generally subsided after discontinuation of treatment (Table 11). Incidence of adverse effects varied from 3 percent122 to 67 percent.117 One study114 did not report adverse effects and one trial85 only reported that 2 persons withdrew due to ‘discomfort’.

Table 11 Treatment emergent adverse effects reported in studies evaluating pharmacological and food supplement interventions

Pharmacological Intervention Category | Specific Intervention | Dropouts Eue to AE (% of dropouts) Reason(s) | AE Info Collected | Treatment Emergent AE (did not drop out of study) Reason(s)
Antidepressant drugs | Sertraline (SSRI antidepressant) vs. placebo99,122 | NR | Yes | NR
Antidepressant drugs
Antidepressant drugs | Paroxetine (SSRI antidepressant) vs. placebo113 | 22/26 (84.6%) Sexual dysfunction Tx n=17(29.8%) Pl n=4 (6.9%) p=0.001 Drowsiness Tx n=11(19.3%) Pl n=2 (3.4%) p=0.007 Dry mouth Tx n=8(14.0%) Pl n=1 (1.7%) p=0.015 NS results: Sweat (11), Insomnia (11), GI distress (7), Tremor (1), Headache (5) | Yes | NR
Antidepressant drugs
Antidepressant drugs | Trazodone (SARI antidepressant) vs. placebo90 | 0 | NR | Sleepiness Tx n=3 (7%) Pl n=1 (2.4%)
Antidepressant drugs
Antidepressant drugs | Nortriptyline (2^nd^ gen tricyclic antidepressant) vs. placebo115 | 14/25 (56.0%) Anticholinergic side effects and sedation (11) | NR | NR
Neurotransmitter drugs | Gabapentin(GABA analogue – GABAergic) vs. placebo109 | 9/20 (45.0%) Nausea n=3 Weight gain n=2 Sleep disturbance n=2 Dizziness n=1 | Yes | NR
Neurotransmitter drugs
Neurotransmitter drugs | Baclofen (selective GABAB1 receptor agonist) vs. placebo119 | 8/11 (72.7%) All withdrew because of side effects (not specified) | Yes | Confusion Tx n=8 (26.7%) Pl n=0 <0.005 Dizziness Tx n=12 (40.0%) Pl n=1 (3.4%) <0.001 Drowsiness Tx n=15 (50.0%) Pl n=3 (10.3%) <0.001
Neurotransmitter drugs
Neurotransmitter drugs | Alprazolam (benzodiazepine – anxiolytic) vs. placebo28 | 2/4 (50%) Excessive drowsiness | Yes | Excessive drowsiness 7/17 (41%)
Neurotransmitter drugs
Neurotransmitter drugs | Acamprosate vs. placebo114 | NR | NR | NR
Neurotransmitter drugs
Neurotransmitter drugs | Acamprosate vs. placebo82 | 9/50 (18%) 2 in Tx group and 7 in Pl group (AEs included epigastralgia, choking, depression (n=1); authors did not break down AEs by group or percentage) | Yes | Epigastralgia and choking were reported in 12% of Tx group and 20% of Pl group, including 9 participants who withdrew
Other Drugs | Methylprednisolone (intratympanic injection) vs. placebo117 | 0 | NR | Pain during injection Tx: 67% Pl 52% NS Burning sensation: Tx 57% Pl 17% p=0.002 Vertigo Tx 57%, Pl 38% NS Bitter taste Tx 40%, Pl 7% p=0.003
Other Drugs
Other Drugs | Deanxit + clonazepam vs. placebo + clonazepam107 | NR | NR | NR
Other Drugs
Other Drugs | Vardenafil (PDE5 inhibitor) vs. placebo106 | 5/7 (71.4%) | NR | Headache Tx n=1; Pl n=2 Diarrhea Tx n=2; Pl n=0 Nasal congestion Tx n=2; Pl n=0 Prolonged penile erection Tx n=1; Pl n=0
Food Supplements | Gingko biloba vs. placebo111 | 0 | NR | Diarrhea Tx n=1 (3%) Pl n=2(6%) Headache Tx n=1 (3%) Pl n=1 (3%)
Food Supplements
Food Supplements | Zinc vs. placebo86 | NR | Yes | Minor gastric disturbances Tx n=2 (6%); Pl n=0
Food Supplements
Food Supplements | Honeybee larvae vs. hydrogenated dextrin85 | Discomfort (term not further defined by authors) Tx n=1; Comparator n=1 | Yes | Authors specifically report that no AEs occurred besides ‘discomfort’ (n=2) leading to drop-out
Food Supplements
Food Supplements | Gingko biloba vs. placebo93 | NR | Yes | Gastrointestinal Tx n=15; Pl n=15 Ear pressure/blocking Tx n=10 ; Pl n=4 Dizziness/nausea Tx n=6; Pl n=7 Headache Tx n=4; Pl n=4 Mouth ulcer/dryness/bad taste Tx n=3 ; Pl n=6 Worsening sleep/dreams Tx n=4 ; Pl n=3 Flushing/redness in face Tx n=1; Pl n=4 Skin problems Tx n=2 ; Pl n=3 Awareness of heartbeat Tx n=3 ; Pl n=3 Worsening hearing Tx n=1; Pl n=1 Hyperacusis Tx n=2; Pl n=2 Miscellaneous Tx n=8 ; Pl n=8

Abbreviations: AE = adverse effects; gen = generation; n = sample size; NR = not reported; NS = not significant; PDE5 = phosphodiesterase type 5; Pl= placebo; SARI = serotonin antagonist reuptake inhibitor; SSRI = selective serotonin reuptake inhibitor; Tx = treatment; vs. = versus

Among the anti-depressant trials, adverse effects were minimal in one trial,122 with one sertraline participant reporting sexual dysfunction and one placebo participant reporting an unspecified problem. Eighty-eight percent of participants in the trazodone study90 were free of adverse effects with seven reported effects in the treated group, the most serious being hypertensive crisis, and three in the placebo group: sour mouth, insomnia, sleepiness. For paroxetine,113 eight different effects occurred during followup: sexual dysfunction, drowsiness, dry mouth, sweating, insomnia, gastrointestinal distress, tremor, and headache. The incidence of sexual dysfunction, drowsiness, and dry mouth were statistically significantly greater in the paroxetine group relative to the placebo group. One study115 reported anticholinergic effects and sedation.

Turning to neurotransmitter drugs, nine persons withdrew from the gabapentin study109 due to nausea (n=3), weight gain (n=2), sleep disturbance (n=2), or dizziness (n=1). These persons were assigned to the active treatment group. The baclofen trial119 saw higher incidences (p<0.05) of confusion, dizziness, and drowsiness in the treated group, with no differences (p>0.05) between treatment and placebo groups in terms of gastrointestinal problems, weakness, or worsening tinnitus. Twelve of 17 persons who received alprazolam28 reported side effects, including drowsiness (n=7), insomnia (n=1), difficulty functioning at work (n=1), or more dreams during sleep (n=4). The authors of the acamprosate trial82 indicated that 12 percent of the acamprosate group and 20 percent of the placebo group reported adverse effects (p=0.35), which included epigastralgia and choking (no specific numbers reported).

In the methylprednisolone vs. saline study,117 the authors reported percentage incidences of four types of adverse effects, with higher percentages in the treated vs. placebo group: pain (67 vs. 52 percent; p>0.05); burning sensation (57 vs. 17 percent; p=0.002); vertigo (57 vs. 38 percent; p>0.05); and bitter taste (40 vs. 7 percent; p=0.003). Turning to the vardenafil study,106 six persons in the vardenafil group and two persons in the placebo group experienced adverse effects, which included headache, diarrhea, nasal congestion, and priapism.

The authors of the two ginkgo biloba trials reported side effects. In the smaller study (n=60),111 the authors noted that diarrhea occurred in 6 percent of placebo and 3 percent of treated participants, while headaches occurred in 3 percent of the persons in each group. In the larger study,93 the authors reported numerous adverse effects, with the highest incidence observed for gastrointestinal effects (3.1 percent in both study groups) and the lowest for hyperacusis (0 percent in the treated group, 0.4 percent in the placebo group). Overall, the between-group differences in incidence were not statistically significant for any adverse effect in the larger trial. In the zinc trial,86 two patients in the intervention group reported minor gastric disturbances. Similarly, two patients in the honeybee larvae RCT85 dropped out due to ‘discomfort’ (one patient in each study group).

###### Strength of Evidence—Adverse Effects

The study protocol identified surgical outcomes, sedation, and worsening symptoms as adverse effects of primary interest. There were four studies reporting symptoms of sedation (sleepiness, drowsiness) and this was reported in studies using antidepressants (trazodone and paroxetine) and neurotransmitter drugs (baclofen, alprazolam). Table 12 shows the ratings across the four domains for the adverse effect of sedation. The findings for sedation were inconsistent and deemed imprecise as estimates of affected patients were poorly characterized; the SOE for the outcome of sedation was judged to be insufficient in patients with tinnitus.

Table 12 Strength of evidence: Studies that evaluate pharmacological and food supplement interventions compared to inactive control and report on the adverse effect of sedation

Intervention Group | Specifics | # of Studies (n) | Risk of Bias | Consistency | Directness | Precision | Magnitude of the Effect SMD Range (CI) | SOE
Pharmacological Drowsiness or excessive sleepiness | Anti-depressant vs. placebo | 2^90,113^ | Low | Inconsistent | Direct | Imprecise | N/A | Insufficient
Pharmacological Drowsiness or excessive sleepiness | Neuro-transmitter Drugs (Baclofen, Alprazolam) vs. placebo | 2^28,119^ | Low | Inconsistent | Direct | Imprecise | N/A | Insufficient

Abbreviations: CI = confidence interval; n = number; SOE = strength of evidence; SMD = standard mean difference

### Medical Interventions

#### Key Messages

Eleven studies were included for medical interventions in KQ2:^35,83,88,89,94,103,105,108,110,116,118^

- Six evaluated Repetitive Transcranial Magnetic Stimulation (rTMS) or electromagnetic stimulation83,88,94,103,105,110
- Three evaluated low level laser therapy (LLLT)35,89,108
- One evaluated acupuncture118
- One evaluated acoustic coordinated reset neuromodulation (ACRN) therapy116

All the studies in the medical intervention grouping have relatively small sample sizes (less than 60 subjects total).

The risk of bias in the 11 studies evaluating medical interventions was generally fair (n=9 fair,35,83,89,94,103,105,108,116,118 n=1 poor,88 n=1 good110).

##### Tinnitus-Specific Quality of Life

- This outcome was evaluated in nine studies with inactive controls using different types of instruments. The SOE was insufficient for studies evaluating rTMS (n=4) (high risk of bias, variability in dose and areas treated), and for those interventions that had single studies (high frequency pulsed electrical stimulation (n=1), LLLT (n=2) (different types of LLLT), ACRN (n=1) and acupuncture (n= 1)).

##### Subjective Loudness

- This outcome was evaluated in four studies. The SOE was insufficient for studies evaluating LLLT (n=2), ACRN (n=1) and acupuncture (n=1) because of high risk of bias and imprecise estimates.

##### Sleep Disturbance

- No studies evaluated this outcome.

##### Anxiety Symptoms

- A single study evaluating LLLT evaluated this outcome and the SOE was deemed insufficient.

##### Depression Symptoms

- A single study evaluating LLLT evaluated this outcome and the SOE was deemed insufficient.

##### Global Quality of Life

- No studies evaluated this outcome

#### Characteristics of Included Studies

Eleven studies were included for medical interventions in KQ2. Six83,88,94,103,105,110 of these evaluated repetitive transcranial magnetic stimulation (rTMS) or electromagnetic stimulation, three evaluated low level laser therapy (LLLT)35,89,108 and one each evaluating acupuncture118 and acoustic coordination reset neuromodulation (ACRN) therapy.116 See Appendix E for the Characteristics of Included Studies Evidence Tables.

##### Population—Duration and Severity of Tinnitus

The subjects in the majority of studies were from the general population of those experiencing subjective idiopathic tinnitus. Two studies focused on specific sub-populations (some tinnitus presenting with sensorineural hearing loss or from Ménière’s disease35 or tinnitus that was treatment resistant for one year).118

For some studies, the duration of time participants had been bothered by their tinnitus before being eligible for the intervention study was a minimum of 3 months,89,105 6 months,83,94,116 1 year,118 or less than 5 years.110 Other studies did not specify a minimum threshold for duration in order to be eligible for study participation. Two studies also required subjects to be right handed83,88 and had symptoms that had not resolved following pharmacological interventions after 3 months83 or any following any other type of treatment.88 Other studies did not specify a time period.

The severity of the tinnitus was not consistently identified prior to treatment, but studies reported recruiting patients with tinnitus described as disturbing,103 disabling chronic,108 and chronic.116 Other papers enrolled patients with treatment resistant tinnitus,88,118 and three did not report on severity of tinnitus at enrollment.35,105,110 Some studies included a pre-study assessment by an otolaryngologist (ENT),88,89 and audiologist or audiology tests.83,94,103,108

In the rTMS and electromagnetic stimulation studies, the subjects were identified as having a range of tinnitus symptom duration from 7 months to 60 years,94 less than 5 years,110 and 6 months to 20 years.88 One study provided only mean duration of tinnitus (11.7 and 10.7 years).103 Two studies did not report duration of symptoms of included subjects.83,105

The study evaluating ACRN116 did not report any information regarding duration of tinnitus. In the LLLT studies, subjects were identified as having a range of duration of tinnitus symptoms from 3 months to 25/26 years35,108 and 6 months to 45 years.89 The acupuncture study118 reported only the average duration (from 7.4 and 9.4 years).

##### Interventions and Role of Device Manufacturers

###### Repetitive Transcranial Magnetic Stimulation (rTMS) and Electromagnetic Stimulation

Five studies focused on rTMS83,88,103,105,110 and one on high-frequency pulsed electromagnetic energy.94Table 13 shows the specifics of the rTMS and electromagnetic stimulation devices, dose and placement on the head. One study94 appears to use a markedly different approach to electromagnetic stimulation and is not classified as rTMS. The five studies evaluating the use of rTMS appeared to stimulate the cortex most commonly associated with auditory function and only two studies83,103 used additional devices (stereotaxy and MRI) to locate the cortical areas of interest. The electromagnetic stimulation parameters markedly varied with respect to number of session (5 sessions over two weeks)83 to 20 consecutive sessions over 4 weeks.110 Similarly, the dose of electromagnetic stimulation varied across studies from 1,500 stimulations at 1 Hz83 to 900 bursts at 5 Hz.110

Table 13 Details of the devices, dose and placement of rTMS and electromagnetic stimulation interventions

Study | Device | Dose and Duration | Information About the Location and Method of Treatment Application as Specified Within the Studies
Ghossaini,94 2004 | Device: Diapulse (model D103); Diapulse Corporation of America | Electromagnetic energy group: High-Frequency Pulsed Electromagnetic Energy (Diapulse) set to produce pulsed electromagnetic energy at 27.12 MHz in 65 μs burst with repetition of 600 pulses per second at 975 W peak. Patients received 30-minute treatments with the Diapulse device (model D103) 3 times per wk for 1 month. Sham rTMS group: deactivated machine but same protocol. | Treatment was accomplished by placing the center of the head of the Diapulse unit approximately 1 inch lateral to the auricle. Treatment was placed only on one side of the skull. Patients with bilateral tinnitus received treatment to the ear with louder tinnitus.
Anders,83 2010 | Device: Magstim SuperRapid; (The Magstim Company Ltd., Whitland, UK). Coil: Figure-eight-shaped coil | rTMS 1500 stimulations per session occurring over 2 intervals within a session at 1 Hz. In total 5 sessions over 2 weeks. Sham rTMS: coil was tilted 45 degrees away from skull with only one wing touching the skull. | Navigation of the coil on the surface of the skull Frameless neuro-navigation system (Magstim Co. Ltd, Whiteland, UK) over the auditory cortex (Brodman area 41 and 42) according to individual structural MRI data (T1 weighted 1.5 system Gyroscan NT. Phillips, Medical Systems, Shelton CT). Coil was positioned over the primary auditory cortex marked by water resistant pen during stereotaxy navigation session.
Marcondes,105 2010 | Device: Dantec Stimulator (Medtronic, Minneapolis, MN, USA) Coil: Figure 8 coil 7 cm | rTMS group: 17 minutes at 110% intensity if motor threshold (1020 stimuli) at a frequency of 1 Hz. Treatment administered for 5 consecutive days.. Sham rTMS group: Performed with the sham coil system. | Applied over the left temporoparietal cortex in accordance with previous studies. Coil was centered at the midline between the electroencephalographic electrode positions T3 and P3 with the handle of the coil angled backward of about 45 degrees away from the midline TMS. All subjects were given earplugs.
Chung,88 2012 | Device: Magstim SuperRapid; (The Magstim Company Ltd., Whitland, UK). Coil: Figure-eight-shaped coil | rTMS group: -Intensity setting at 80% of the resting motor threshold (RMT) as per previous methods. Continuous theta-burst rTMS (cTBS) was delivered at a burst frequency of 5 Hz (the theta rhythm in the EEG); each burst consisted of 3 pulses repeated at 50 Hz. 900 pulses (300 bursts) of stimulation once daily for 10 consecutive business days. Sham group: Received an identical protocol to the active-stimulation group, but with the sham coil tilted away from the skull. | Coil was placed over the auditory cortex (temporoparietal lobes): the distance between electrodes on the scalp and cortex is calculated on average as 23.8 mm.
Plewnia,110 2012 | Device: Magstim SuperRapid; (The Magstim Company Ltd., Whitland, UK). Coil: Figure-eight-shaped coil (diameter of each winding 70 mm, biphasic stimuli of 250 us) | rTMS group. Continuous theta burst stimulation (cTBS) which was standardized to 80% individual active motor threshold. cTBS was applied to each hemisphere in alternating order. Each stimulation train (40s) consisted of 600 stimuli applied in burst of 3 pulses at 50 Hz given every 200 msec (i.e.,5 Hz). Fifteen minutes after the first 2 trains, a second pair of cTBS trains was given (a total of 2,400 stimuli per day). Applying a second train 15 minutes later has previously been shown to prolong the inhibitory effects. Patients received daily cTBS for 4 weeks (20 sessions). Sham group: for adequate masking of the patients, sham stimulation was performed as per cTBS but behind the mastoid. | Because the primary auditory cortex cannot be reached adequately by rTMS and in order to compare the effects of cTBS to secondary and higher order processing areas, the 10–20 EEG electrode placement system was used to localize. Temporal cortex (Brodmann area 39 (TAC: halfway between T5/P3 and T6/P4)) and Temporoparietal cortex (Brodmann area 42/22 [SAC: halfway between T3/C3 and T4/C4]). Sham (behind the mastoid) The coil was hand-held during stimulation trains to allow for optimal fixation. All patients were seated in a comfortable chair while they were receiving 4 × 40 s of cTBS. There was no other input to or activity of the patients during stimulation. Disposable earplugs (ColorPlux^®^; noise reduction rating 35 decibels) were used while cTBS was applied.
Langguth,103 2008 | Medtronic (90 mm outer diameter, Medtronic, Minneapolis, MN, USA) Figure 8 coil | The study aimed to investigate whether priming stimulation enhances the efficacy of low-frequency rTMS Intervention: Priming protocol (960 stimuli; 6 Hz) preceded rTMS (1,040 stimuli; 1 Hz and an intensity of 90% motor threshold (16 trains lasting 10 s separated by 20 s). Stimulation was provided over 10 consecutive days. Comparator: standard protocol rTMS: (2,000 stimuli; 1 Hz and 110% motor threshold) | A neuronavigational system (Brainvision, Brainlab) based on frameless stereotaxy and adapted for magnetic stimulation allowed for navigation of the coil on the surface of the skull over the auditory cortex according to the individual MRI data. The handle of the coil was pointing upwards. Treatment over the left auditory cortex (independent of right or left handedness).

Abbreviations: cm = centimeter; cTBS = continuous theta burst stimulation; EEG = electroencephalogram; Hz = Hertz; Mhz = megahertz; Mnth = month; MRI = Magnetic resonance imaging RMT = registered massage therapist rTMS = repetitive transcranial magnetic stimulation; SAC = secondary auditory cortex; TAC = temporoparietal association cortex; TMS = Transcranial magnetic stimulation; wk = week

###### Acoustic Coordinated Reset Neuromodulation

One study116 evaluated the use of acoustic coordinated reset neuromodulation (ACRN). As described by the study authors, “the concept of ACRN comprises a spatial and temporal coordination of the applied stimuli to induce desynchronization leading to anti-kindling” and is applied to the primary auditory cortex, where short sinusoidal tones of different frequencies (f1 to f4) induce a soft reset in different target areas grouped around the tinnitus focus. Three ACRN cycles, each comprising a randomized sequence of four tones, are followed by two silent cycles. That pattern is repeated periodically. The random variation of the tone sequences and the 3:2 “on and off” pattern optimizes the desynchronizing ACRN effect.

In this study, four different stimulation groups and one placebo group were evaluated. Groups 1, 3, and 4 (G1, G3, G4) used four tones grouped around the tinnitus frequency for each patient (ft); G3 differed only in repetition rate being adapted to the individual EEG (i.e., band peak). For group 2 (G2) each ACRN cycle was formed by a varying composition of four tones chosen out of twelve tones from the surrounding frequencies. Placebo stimulation or group 5 (G5) was formed similar to G1 using a down-shifted stimulation-frequency (fp) (fp=0.7071·ft/(2n), fp within (300 Hz, 600 Hz)) outside the synchronized tinnitus focus. Note that a readjustment of stimulation parameters could be undertaken if the matched tinnitus frequency had changed relative to baseline.

Treatment in G1, G2, and G3 was applied for 4 to 6 hours per day and applied continuously or split into several sessions not less than 1 hour. In contrast, G4 and G5 received stimulation for only 1 hour daily. Patients were stimulated for 12 weeks using portable acoustic device and comfortable earphones; this 3 month treatment was followed by an additional off stimulation period of 4 weeks and an optional 24 week off-label extension period. Although not specified, it is likely that the stimulation was administered by the patient (as the device was portable) but it is not clear what role if any the neurologist had in administering the treatment (but EEG was used to optimize the frequencies selected for individual patients and thus specialized professional expertise was required in the initial assessment of tinnitus frequency for the purposes of selecting the characteristics of the acoustic stimulation). The primary authors of the study have a contractual relationship with the manufacturer or hold shares within the company of the device and the study was funded by the manufacturers.

###### Low Level Laser Treatment

Two studies reviewed the effects of low level laser treatment (LLLT)35,108 relative to sham laser and one study used LLLT in combination with counseling relative to sham LLLT and counseling.89 Note that the role of the manufacturers of the LLLT devices was not specified in the studies; similarly, potential conflict of interest by the study authors with regards to payment from the manufacturer was not reported in any of these three studies.

One study108 used gallium-aluminium-arsenade (Ga-Al-As) diode laser (Uni-laser 301P, type 301.000, 3B) with a maximum output power of 140 mW and a wavelength of 830 nm with invisible radiation (probe beam 670 nm with less than 1mW output power); the frequency spectrum for the laser was in the range of 10–1500 Hz. The tip of the laser probe was inserted in the external acoustic meatus, pointing the beam towards the tympanic membrane and the promontory of the affected ear. Each of the 15 treatment settings lasted 10 min. Power of 50 mW with a continuous wave resulted in a total application of 30 J in each session. Only one ear was treated even if the subject had bilateral tinnitus. Although not explicitly, stated it is likely that the laser was administered by a technician in a clinical setting.

Two studies35,89 used a similar laser device (see website for this device: www.tinnitool.com/en/therapie_moeglichkeiten/index.php) where the patient administered the laser using a headset or ear attachment to ensure consistency in the administration of the laser. One study35 used the TinniTool (Adisma^©^) and a second study89 used the LLLT (TinniTool EarLaser, DisMark GmbH, Maur, Switzerland) which may be very similar devices. These devices are diode lasers with a wavelength of 650 nm and absolute power output of 5 mW with a continuous wave. One study35 describes the laser probe inserted into a special fixation material in a specifically designed headset to facilitate positioning in the auditory meatus; the laser beam is projected onto the tympanic membrane through a 17-degree diverging lens, creating a spot size of 1 cm. Duration of irradiation was 20 min a day resulting in an energy density of about 6 J at the tympanic membrane; the treatment lasted 3 months. All subjects had unilateral tinnitus and although not reported in the study, it is assumed that only one ear was treated. Note that the laser was administered by the patient at their home. The second study89 using the TinniTool EarLaser, describes the system as one composed of a laser probe that was placed at the entrance of the external auditory canal, from where the laser ray was directed toward the eardrum. The laser probe was to be used with a wearable ear hook. Patients were trained to use the device for 20 minutes per day, for 3 months. In this study, although the largest proportion of subjects had bilateral tinnitus (63 percent), it is not clear if the study subjects were instructed to treat both ears.

This second study89 using the TinniTool EarLaser also combined counseling (10 sessions of 40 minutes, distributed over the 3 month treatment period) with both the active LLLT and the sham LLLT groups. The counseling intervention included a multi-modal approach and combined tinnitus retraining therapy principles and psychosomatic approaches (both hypnotic and relaxation techniques) over the 10 sessions.

###### Acupuncture

One study reviewed the effects of Chinese acupuncture relative to sham acupuncture.118 Treatments were given over 2 months where subjects received three blocks of treatments (10, 5, and 10, separated by 1 week) for a total of 25 sessions. The treatment was administered daily for 30 minutes. All subjects were treated over five different points (SI -19, G 2, SJ 17, SJ 19, DU 20); however, distal points and the “methods of manipulation” varied with individual patients. Bilateral treatment was administered irrespective of whether the patient suffered with unilateral or bilateral tinnitus. A non-penetrating Japanese acupuncture needle was used as the sham acupuncture. The sham needles were inserted superficially into the skin over random non-acupuncture sites for 30 minutes.

##### Comparators

Table 14 shows the types of comparators in the included in the studies. Description of the sham interventions are described in the interventions section.

Table 14 Interventions and comparators used in studies that evaluate medical interventions and outcomes

Medical Intervention | | Specific Intervention | Sleep | Anxiety Symptoms | Depression Symptoms | Loudness | Global QoL | Tinnitus-Specific QoL | Adverse Effects
RTMS | | INACTIVE COMPARATOR
RTMS | 1 | rTMS vs. sham Anders,83 2012 | | | | | | THI^*^, TQ-modified, VAS | Yes
RTMS | 2 | rTMS vs. sham Marcondes,105 2010 | | | | | | THI | None
RTMS | 3 | rTMS vs. sham, Chung,88 2012 | | | | VAS | | THI^*^ TQ | None
RTMS | 4 | rTMS (cTBS) secondary auditory cortex vs. sham, Plewnia,110 2012 | | | | | | TQ | Yes
RTMS | | rTMS (cTBS) temporoparietal cortex vs. sham, Plewnia,110 2012 | | | | | | TQ | Yes
RTMS | 5 | High-Frequency Pulsed Electromagnetic Energy vs. sham Ghossaini,94 2004 | | | | | | THI^*^, TMR | Yes
RTMS | | HEAD-TO-HEAD
RTMS | 1 | rTMS Standard protocol (2000 stimuli; 1 Hz) vs. rTMS Priming protocol (960 stimuli; 6 Hz+1040 stimuli;1 Hz) Langguth,103 2007 | | | | | | TQ | None
RTMS | 2 | rTMS (cTBS) secondary auditory cortex vs. rTMS (cTBS) temporoparietal cortex, Plewnia,110 2012 | | | | | | TQ | Yes
Acupuncture | | INACTIVE COMPARATOR
Acupuncture | 1 | Acupuncture vs. sham Vilholm,118 1998 | | | | VAS | | VAS-Ann^*^, VAS-Awr | NR
Laser | | INACTIVE COMPARATOR
Laser | 1 | Laser Therapy vs. sham Mirz,108 1999 | | STAI | BDI | VAS | | THI^*^, VAS-Ann, VAS-Att | None
Laser | 2 | Laser Therapy vs. sham Teggi,35 2009 | | | | VAS | | THI | Yes
Laser | | HEAD-TO-HEAD
Laser | 1 | Experimental (LLS+): low level laser + counseling Control (LLS−): same counseling as LLS+ plus faked stimulation device Cuda,89 2008 | | | | | | THI | NR
Neuromodulation | | INACTIVE COMPARATOR
Neuromodulation | 1 | ACRN G1 vs. placebo Tass,116 2012 | | | | VAS | | TQ^*^ VAS | Yes
Neuromodulation | | ACRN G2 vs. placebo Tass,116 2012 | | | | VAS | | TQ^*^ VAS | Yes
Neuromodulation | | ACRN G3 vs. placebo Tass,116 2012 | | | | VAS | | TQ^*^ VAS | Yes
Neuromodulation | | ACRN G4 vs. placebo Tass,116 2012 | | | | VAS | | TQ^*^ VAS | Yes
Neuromodulation | | Head-to-head
Neuromodulation | 1 | ACRN G1 vs. G2, Tass,116 2012 | | | | VAS | | TQ^*^ VAS | Yes
Neuromodulation | | ACRN G2 vs. G3, Tass,116 2012 | | | | VAS | | TQ^*^ VAS | Yes
Neuromodulation | | ACRN G3 vs. G4, Tass,116 2012 | | | | VAS | | TQ^*^ VAS | Yes
Neuromodulation | | ACRN G1 vs. G3, Tass,116 2012 | | | | VAS | | TQ^*^ VAS | Yes
Neuromodulation | | ACRN G1 vs. G4, Tass,116 2012 | | | | VAS | | TQ^*^ VAS | Yes
Neuromodulation | | ACRN G2 vs. G4, Tass,116 2012 | | | | VAS | | TQ^*^ VAS | Yes

Abbreviations: ACRN = acoustic coordinated reset neuromodulation; Ann = annoyance; Att = attention; Awr = awareness; BDI = Beck Depression Inventory; cTBS = continuous Theta Burst Stimulation; G(1, 2, 3, 4) = group (1, 2, 3, 4); Hz = hertz; LLS = low level laser; NR = not reported; QoL = quality of life; rTMS = repetitive transcranial magnetic stimulation; STAI = State-Trait Anxiety Inventory; THI = Tinnitus Handicap Inventory; TMR = Tinnitus Magnitude Rating; TQ = Tinnitus Questionnaire; VAS = visual analogue scale; vs. = versus

* Indicates the test used to measure outcomes which were selected to represent the domain in the forest plots (and subsequent SOE decisions)

##### Outcomes

Most studies reported data on more than one outcome (Table 14, and Appendix E, Table E2.). The outcome measurement instruments used varied for the same outcomes (Table 15). For example, nine different instruments were used to measure the outcome of severity of tinnitus.

Table 15 Outcome measurements used in medical intervention studies

Outcome | Outcome Measurement Used
Tinnitus-specific QoL | THI (Tinnitus Handicap Inventory)35,83,88,89,94,105,108 TQ (Tinnitus Questionnaire)83,88,103,110,116 VAS (Visual Analogue Scale)83,108,116,118 TMR (Tinnitus Magnitude Rating)94
Sleep Disturbance | No study evaluated this outcome
Anxiety Symptoms | STAI (State-Trait Anxiety Inventory)108
Depression Symptoms | BDI (Beck Depression Inventory)108
Subjective loudness | VAS (Visual Analogue Scale)35,88,108,116,118
Global Quality of Life | No study evaluated this outcome

##### Setting

The research settings were in departments of Otolaryngology/Otorhinolaryngology,83,89,105,108 Audiology,118 Otorhinolaryngology and Psychiatry,110 Psychiatry,103 and Ear, nose and throat.35 Other settings included tinnitus clinics116 and a university medical hospital.88 One paper did not report on the research setting.94

##### Country

The studies were carried out in seven different countries: the United States;94 China;88 Germany;103,110,116 Denmark;108,118 Italy;35,89 Spain;105 and the Czech Republic.83 See Appendix E, Table E2.

##### Sources of Funding

Sources of funding were not reported in six studies.35,89,105,108,110,118 One study reported industry funding,116 and one received a loan of the equipment being tested.94 The remaining studies received funding from research councils, foundations, and government departments and non-profit associations.83,88,103

#### Risk of Bias for Medical Interventions

The risk of bias in the 11 studies evaluating medical interventions was generally fair risk of bias (n=9 fair,35,83,89,94,103,105,108,116,118 n=1 poor,88 n=1 good110). All authors reported their studies as randomized, with appropriate randomization in 36 percent (n= 4) of articles.35,103,110,116 Method of randomization was not described in seven papers (64%).83,88,89,94,105,108,118 Some articles reported using double-blinding techniques,35,83,89,94,105,108,118 and in all but one case118 it was deemed appropriate. Seventy three percent of articles (n=8) reported the inclusion/exclusion criteria,83,88,89,103,105,110,116,118 and all described the statistical methods used (Figure 10).

Figure 10 Proportion of medical intervention studies achieving criteria for risk of bias

Figure 10 depicts the risk of bias for medical intervention studies. All of the studies were RCTs; yet in only 36% of cases the randomization process was deemed appropriate. Sixty-four percent of articles reported using double blinding techniques, with only 55% of these being assessed as appropriate. Forty-five percent of studies reported withdrawals by number and reason per arm, while only 9% reported the methods used to assess adverse effects. Seventy-three percent of studies reported inclusion and/or exclusion criteria, and all described the statistical analysis used. Forty-five percent of articles reported that the intervention/drug allocation was concealed. Only 9% reported that the analysis was based on “intention to treat” and only 27% justified their sample size.

Issues with risk of bias in the RCTs included a lack of reporting on withdrawals (n=6, 55%),88,94,105,108,116,118 no description of methods to assess adverse effects (n=4, 36%),88,103,116,118 inadequate concealment of allocation (n=10, 91%),35,83,88,89,94,103,105,108,116,118 analysis not based on intention-to-treat principle (n=9, 82%),35,83,88,94,103,105,108,116,118 and inadequate justification of sample size (n=8, 73%).35,83,88,89,94,105,108,118

#### Results for Medical Interventions by Outcome

##### Tinnitus-Specific Quality of Life

###### Repeated Transcranial Magnetic Stimulation (rTMS )

Figure 11 shows the studies evaluating rTMS83,88,105,110 or electromagnetic stimulation94 relative to an inactive control (see also Table 14). Most of these studies used the TQ or the THQ to evaluate tinnitus-specific QoL. Two studies83,105 at high risk of bias investigated low frequency (1 Hz) rTMS relative to sham stimulation and measured the outcome using the THI. Although the dose of rTMS differed (5 sessions over 2 weeks and 5 consecutive days), the changes immediately following treatment showed no significant benefit relative to sham rTMS. However, both studies seemed to report that a time effect was present. There was some worsening of symptoms at week 6 (relative to week 2) on the THI.83 There were statistically significantly reductions relative to baseline in the active treatment groups at 26 weeks83 and 6 months.105 However, active treatment appeared not to confer any further reductions in score after 6 weeks83 or at 1 month.105 In both studies, the groups receiving placebo stimulation did not experience statistically significant changes in THI scores over the course of followup. It is noteworthy that one of these studies105 selected subjects with lower THI scores at baseline relative to other studies, suggesting that they had less severe tinnitus.

Figure 11 Studies with inactive comparators that evaluate medical interventions and report tinnitus-specific quality of life outcomes

Note: A decrease in score indicates improvement.

** Represent studies with multiple intervention groups.

This figure shows the effect size (standardized mean difference ‘SMD’) with 95% confidence interval for each study in a forest plot for medical interventions for the outcome of tinnitus specific quality of life. Twelve studies show a SMD with 95% confidence interval that crosses 0 (no difference) between groups, while only one study shows a SMD with 95% confidence interval less than 0 (Favors treatment group as compared to control group).

Two studies88,110 investigated higher frequency (5 Hz) rTMS relative to sham stimulation and measured the outcome using the THI. One of these studies88 was at high risk of bias, and administered treatment for 10 consecutive days. Significant differences on TQ and THI scores showed at 1 week post treatment (p <0.01), but not at 1 month. The second study110 was at low risk of bias, and administered treatment for 20 consecutive days but showed no significant differences between treatment and sham groups immediately post treatment using the THI; this study also showed no differences at 2, 4 and 12 weeks post treatment.

One study94 at high risk of bias examined high-frequency (27.2 MHz) electromagnetic energy using the THI as the outcome measure. The high frequency study94 failed to detect any differences between groups. The shape of the electromagnetic stimulator appears to be encased in a round head; all other studies in this group used a figure eight coil; it is not clear how the properties of generating an electromagnetic field differ as a result of the different shaped stimulator.

###### Acoustic Coordination Reset Neuromodulation

The single study evaluating ACRN interventions demonstrated improvement on the Tinnitus Questionnaire (TQ) scores in all treatment groups (G1 to G4) and statistical differences relative to baseline were shown in these groups but not in placebo (G5).116 However, none showed a significant effect favoring treatment relative to placebo (Figure 11). VAS scores for annoyance were statistically significant and favoring treatment at 12 weeks for the G1 vs. G5 groups only.

###### Laser

Two studies at high risk of bias35,108 evaluated LLLT compared to an inactive control, and one study89 comparing LLLT plus counseling to sham LLLT and counseling (also at high risk of bias). All of these three studies measured Tinnitus-specific quality of life using the THI.89,108,118 All studies showed no statistical differences between the treatment and comparator groups using the THI. It is noteworthy that one study108 used a markedly different form of LLLT relative to the other two studies35,89 which used a self-administered applied for a minimum of 3 months. One study108 evaluated 100 mm VAS for annoyance and found no between-group differences (p=0.81). Similarly, a VAS for attention to symptoms was evaluated and showed no statistical differences 1 month post treatment (p=0.52).

###### Acupuncture

A single trial118 compared traditional Chinese acupuncture to sham acupuncture over 2 months of treatment and evaluated up to 4 months of followup. Results on an unspecified VAS were not statistically significantly different at the 5 percent level for either annoyance or awareness (no p-values reported in trial publication). This trial was at high risk of bias and had only 54 subjects in total included in the study. Adverse effects were not systematically evaluated and none were reported.

###### Strength of Evidence—Tinnitus-Specific Quality of Life

There is insufficient evidence (four studies, 147 participants) that rTMS improves TSQoL when compared with sham treatment for idiopathic tinnitus immediately post treatment or after short term followup. The sample sizes were small (less than 30 per group), power calculations were not undertaken, and the effect estimates had wide confidence intervals; all these factors contributed to the rating of imprecision. The direction of effect was judged to be inconsistent across studies; high frequency rTMS studies88,110 showed differing directions of effect (statistically significant differences favoring treatment or no difference between groups) and low frequency rTMS studies83,105 favoring treatment but were not statistically significant. With respect to the magnitude of the treatment effects, studies were inconsistent in that effect sizes varied from small to large (0.02 to −1.23). With respect to risk of bias, the studies were categorized as high risk of bias and only one study110 achieved a score greater than 7 from 12. No dose response pattern was observed; there was a trend that longer term effects (improvement in THI scores) occurred with low frequency rTMS (1 Hz) up to 6 months followup. Risk of publication bias is high given the small sample sizes of the studies. The SOE for rTMS alone for the outcome of TSQoL is rated as insufficient as the criteria for more than three of the domains were not met (Table 16).

Table 16 Strength of evidence by medical interventions in the treatment of tinnitus for the outcome of tinnitus-specific quality of life in studies with inactive comparators

Intervention Group | Specifics | # of Studies (n) | Risk of Bias | Consistency | Directness | Precision | Magnitude of the Effect SMD Range (CI) | SOE
rTMS vs. sham | N/A | 4^83,88,105,110^ | High | Inconsistent | Direct | Imprecise | −1.23 (−2.16, −0.30) to −0.02 (−0.67, 0.72) | Insufficient
Hi-frequency electromagnetic energy vs. sham | N/A | 1^94^ | High | Unknown | Direct | Imprecise | −0.13 (−0.86, 0.60) | Insufficient
ACRN vs. sham | N/A | 1^116^ | High | Unknown | Direct | Imprecise | −0.50 (−1.56, 0.56) to −0.03 (−1.07, 1.02) | Insufficient
Laser therapy vs. sham | N/A | 2^35,108^ | High | Inconsistent | Direct | Imprecise | −0.00 (−0.54, 0.53) to 0.33 (−0.29, 0.94) | Insufficient
Acupuncture vs. placebo | N/A | 1^118^ | High | Unknown | Direct | Imprecise | −0.10 (−0.63, 0.10) | Insufficient

Abbreviations: ACRN = acoustic coordinated reset neuromodulation; RCT = randomized controlled trial; rTMS = repetitive transcranial magnetic stimulation; SMD = standard mean difference; SOE = strength of evidence; vs. = versus; WLC = wait list control

For LLLT studies, there is insufficient evidence (two studies, 95 participants) that TSQoL improves when compared with sham treatment for idiopathic tinnitus immediately post treatment or after short term followup. Both studies were rated as high risk of bias. One study showed no difference between groups and the other favored control but was not statistically significant; the effect sizes varied from small to moderate (−0.0 to 0.33) and were deemed inconsistent (Table 16). Although the confidence intervals overlapped substantially, the small sample sizes (less than 30 per group), and lack of power calculations were factors that led to a rating of imprecise. Additionally, the types of LLLT (frequency and treatment intensity and duration) can be considered to be very different types of laser energy administration. Risk of publication bias is high given the small sample sizes of the study and limited to single publications. There is insufficient evidence for LLLT affecting TSQoL, as the criteria for more than three domains were not met.

There is insufficient evidence that high frequency electromagnetic stimulation, ACRN, or acupuncture interventions, improve TSQoL relative to inactive controls. All of these studies were at high risk of bias, had unknown consistency, and small sample sizes (less than 30 per group). Risk of publication bias is high for these interventions represented in a single study. The SOE was judged as insufficient for these interventions, as three or more of the criteria for domains were not met.

##### Subjective Loudness

Four studies with high risk of bias,35,108,116,118 (summary risk of bias score did not exceed 7 from 12) examined loudness as an outcome in persons given medical interventions including LLLT, ACRN, and acupuncture (Table 15). Figure 12 shows the standardized mean difference for the studies that measured this outcome. All studies used VAS for subjective loudness (see Appendix E, Table E2, for full study details for this outcome).

Figure 12 Studies with inactive comparators that evaluate medical interventions and report subjective loudness outcomes

Note: A decrease in score indicates improvement.

** Represent studies with multiple intervention groups.

This figure shows the effect size (standardized mean difference ‘SMD’) with 95% confidence interval for each study in a forest plot for medical interventions for the outcome of subjective loudness. Six studies show a SMD with 95% confidence interval that crosses 0 (no difference) between groups, while only one study shows a SMD with 95% confidence interval less than 0 (Favors treatment group as compared to control group).

One study116 evaluated the impact of ACRN on subjective loudness (VAS) measured after 12 weeks of treatment, and all groups except placebo (G5) had statistically significant changes relative to baseline scores (within group) for the on stimulation condition; for the off stimulation condition, only G1 and G3 groups showed significant differences relative to baseline. The estimates of effect size based on the standardized mean difference (see Figure 12) would suggest that G1 treatment protocol was favored relative to G5 placebo. However, the study reports that there were no differences for a matched subgroup from G1 (subgroup n=5), relative to placebo group G5 (n=5).

Two studies involved LLLT versus sham LLLT, with one article35 finding no statistical difference in self-reported loudness (measured on a 10 cm VAS, with 0 indicating no tinnitus and 100 indicating the highest loudness level) in the treatment group after 3 months of patient-administered daily treatment (p=0.69). Similarly, the second LLLT study,108 using Ga-Al-As diode laser administered by a clinician, no differences between groups were found on a 100 mm VAS after 3 weeks of treatment and at the 1 month of followup (mean difference=4.1 favoring placebo; p=0.53).

In the acupuncture study,118 the authors found no differences between groups on active versus sham acupuncture, measured using an undefined VAS, over 5 weeks of followup (mean difference=5.0 favoring active acupuncture; p>0.05).

###### Strength of Evidence—Self Reported Loudness

There is insufficient evidence that ACRN (one study, 65 participants), LLLT (two studies, 102 participants), and acupuncture (one study, 54 participants) improves self-reported loudness when compared with inactive treatment for idiopathic tinnitus immediately post treatment or after short term followup (Table 17). All the studies measuring this outcome consistently showed no statistical differences between treatment and inactive control groups; however the studies had small sample sizes (less than 30 per group) and it is not clear if this is a factor in the results and as such the studies are considered imprecise. Both LLLT studies showed that the point estimates favored control, but were not statistically significant between groups; the effect sizes were generally small. The study evaluating ACRN consistently favored treatment but only one dose was statistically significant. Risk of bias was high in all studies. Publication bias is assumed as the sample sizes of the studies were small. There is insufficient evidence that ACRN, LLLT, and acupuncture improve subjective loudness, as the criteria for three or more domains were not met.

Table 17 Strength of evidence by medical interventions in the treatment of tinnitus for the outcome of loudness for studies with inactive comparators

Intervention Group | Specifics | # of Studies (n) | Risk of Bias | Consistency | Directness | Precision | Magnitude of the Effect SMD Range (CI) | SOE
ACRN vs. sham | N/A | 1^116^ | High | Unknown | Direct | Imprecise | −1.15 (−2.18, −0.12) to −0.41 (−1.47, 0.64) | Insufficient
Laser therapy vs. sham | N/A | 2^35,108^ | High | Consistent | Direct | Imprecise | 0.23 (−0.34, 0.80) to 13 (−0.40, 0.66) | Insufficient
Acupuncture vs. placebo | N/A | 1^118^ | High | Unknown | Direct | Imprecise | −0.27 (−0.81, 0.27) | Insufficient

Abbreviations: CI = confidence interval; n = number; SOE = strength of evidence; SMD = standard mean difference; vs. = versus

##### Sleep Disturbance

None of the studies evaluating medical interventions measured the impact on sleep disturbance.

##### Anxiety Symptoms

One study at high risk of bias108 evaluated active versus sham LLLT (Ga-Al-As, diode laser) administered by a clinician (Table 15). The State Trait Anxiety Inventory (STAI) was evaluated at baseline and 1 month following treatment. For laser,108 mean score on the STAI was lower in the LLLT group yet not statistically significant (p=0.74).

###### Strength of Evidence—Anxiety Symptoms

There is insufficient evidence that LLLT (one study, 50 participants) improves anxiety symptoms relative to sham control in idiopathic tinnitus patients in the short term (Table 18). The study was at high risk of bias, had a small sample size, and had a wide confidence interval (imprecise). The SOE for LLLT for the outcome of anxiety symptoms is insufficient, as the criteria for three or more domains is not met.

Table 18 Strength of evidence by medical interventions in the treatment of tinnitus for the outcome of anxiety symptoms for studies with inactive comparators

Intervention Group | Specifics | # of Studies (n) | Risk of Bias | Consistency | Directness | Precision | Magnitude of the Effect SMD Range (CI) | SOE
Laser therapy vs. sham | N/A | 1^108^ | High | Unknown | Direct | Imprecise | 0.39 (−0.18, 0.95) | Insufficient

Abbreviations: CI = confidence interval; n = number; SOE = strength of evidence; SMD = standard mean difference; vs. = versus

##### Depression Symptoms

A single study at high risk of bias108 evaluated depression symptoms following the use of LLLT (Ga-Al-As, diode laser) administered by a clinician (Table 14). The Beck Depression Inventory (BDI) was evaluated at baseline and 1 month following treatment. After one month of followup, the difference on the BDI, while favoring the active LLLT group, was small and non-significant (mean difference=0.2; p=0.58).

###### Strength of Evidence—Depression Symptoms

The evidence is insufficient for the single study that evaluated LLLT (one study, 50 participants) improving depression symptoms relative to sham LLLT in the short term. The study was at high risk of bias, small sample size, and a wide confidence interval (imprecise). The SOE for this single study which used LLLT and reported impact on depression symptoms (using the STAI) was rated as insufficient (Table 19) because the criteria for three or more domains were not met.

Table 19 Strength of evidence by medical interventions in the treatment of tinnitus for the outcome of depression symptoms for studies with inactive comparators

Intervention Group | Specifics | # of Studies (n) | Risk of Bias | Consistency | Directness | Precision | Magnitude of the Effect SMD Range (CI) | SOE
Laser therapy vs. sham | N/A | 1^108^ | High | Unknown | Direct | Imprecise | 0.33 (−0.24, 0.89) | Insufficient

Abbreviations: CI = confidence interval; n = number; SOE = strength of evidence; SMD = standard mean difference; vs. = versus

##### Global Quality of Life

None of the studies evaluating medical interventions measured the impact on global QoL (Table 14).

##### Adverse Effects—Medical Interventions

Adverse effects (AE) addressing unintended effects other than worsening tinnitus symptoms (which are considered in the outcomes of severity, loudness, and discomfort), were considered in this report. In general, AE were not consistently reported, and not specified in the methods of the studies. Table 20 shows the percentage of subjects who dropped out because of AE, whether the study methods specifies the mode of collection of AE, and any treatment emergent events that were reported.

Table 20 Description of reported adverse effects in the medical intervention studies

Medical Intervention Category | Specific Intervention | Dropouts Due to AE | AE Info Collected | Treatment Emergent AE (did not drop out of study) Reason(s)
rTMS and electromagnetic Stimulation | rTMS vs. sham83 | 0 | NR | Worsening of Tinnitus symptoms (n=2)
rTMS and electromagnetic Stimulation | rTMS vs. sham105 | 0 | NR | All patients tolerated rTMS without relevant side effects
rTMS and electromagnetic Stimulation | rTMS vs. sham88 | 0 | NR | Transient jaw soreness (n=5) Temporary orbital twitching (n=3) Facial myalgia (n=1)
rTMS and electromagnetic Stimulation | rTMS vs. sham110 | 0 | Yes^*^ | Headache (SAC 2, TAC 2, PLC 3), worsening tinnitus (SAC 1, TAC 2, PLC 3), increased sensitivity to noise (TAC 1, PLC 1), painful local sensation (SAC 1), sleep disturbance (SAC 1)
rTMS and electromagnetic Stimulation | rTMS vs. rTMS103 | 0 | NR | Treatment was well tolerated. No serious A/E were observed.
rTMS and electromagnetic Stimulation | High-Frequency Pulsed Electromagnetic Energy vs. sham94 | 0 | NR | Worsening of Tinnitus symptoms Tx n=4 (26.6%); Pl n=5 (35.7%)
ACRN | ACRN vs. sham116 | 0 | NR | 15 AEs occurred in total: 13 AEs during blinded phase, 2 AEs in LTE. Two SAEs (an abdominal pregnancy and avascular necrosis of the femoral head, not associated with treatment) were reported. All other AEs were of mild to moderate intensity and none was permanent. 8 AEs were judged to be treatment related of which 3 AEs were associated with a transient increase of tinnitus loudness; all 3 patients continued treatment into the LTE.
LLLT | LLLT vs. sham108 | 0 | NR | Some experienced warmth inside the ear canal No serious untoward AE noticed
LLLT | LLLT vs. sham35 | 2/4 (50%) | NR | Increase in tinnitus loudness n=2
LLLT | Laser + counseling vs. sham + counseling89 | 0 | NR | NR
Acupuncture | Acupuncture vs. sham118 | 0 | NR | NR

Abbreviations: ACRN = acoustic coordinate reset neuromodulationl; AE = adverse effect(s); CBT = cognitive behavioral training; CI = confidence interval; LLLT = low level laser treatment; LTE = longterm evaluation; med/surg = medical/surgical; n = sample size; NR = not reported; NS = not significant; Pl = placebo; PLC = placebo; psych/beh = psychological/behavioral; RCT = randomized controlled trial; rTMS = repetitive transcranial magnetic stimulation; SAC = secondary auditory cortex; SARI serotonin antagonist reuptake inhibitor; SMD = standard mean difference; SOE = strength of evidence; SSRI = selective serotonin reuptake inhibitor; TAC = temporoparietal association cortex; Tx = treatment; vs. = versus; WLC = wait list control

* All patients underwent a standard otolaryngologicalphysical examination as a safety assessment. At every treatment visit, tolerability and safety was assessed by spontaneous adverse effect reports. At baseline and after 2 and 4 weeks of treatment audiologic testing was performed, including subjective tinnitus matching, puretone audiometry, and speech audiometry in quiet using the Freiburg speech test and in noise with the Oldenburg sentence test.

None of the studies in the medical interventions group reported drop-outs related to AE. A single study110 reported a priori methods used to collect AE and employed both passive and active approaches to capture potential events and reported events per treatment group. In general, it would appear that AE were transient and mild in nature; however, it is difficult to report any trends related to specific medical interventions, given that all but one study did not report the methods used to capture AE.

### Sound Technology Interventions

#### Key Messages

Four head-to-head studies (with sample sizes per group less than 50) evaluated five different interventions alone and/or in combination with other forms of treatment.53,61,92,98

The interventions compared were:

- TRT with either hearing aids or sound generators,
- information only, with relaxation training, with long-term low-level white noise masking (LTWN), with both relaxation and LTWN
- CBT only, tinnitus education (TE) only, NG with CBT, NG with TE
- Neuromonics with one stage or two stages of stimulus conditions.

All studies had insufficient SOE. No study demonstrated a significant difference between the technologies used in the treatments evaluated on any measure.

##### Tinnitus-Specific Quality of Life

All studies measured this outcome, but using a variety of measures.

There were no significant differences between treatments in any of the studies, although benefits were reported for both TRT treatments and for both Neuromonics treatments. However, the SOE was insufficient for studies evaluating the effects on sound technology interventions on TSQoL.

##### Subjective Loudness

All but one study53 evaluated this outcome.

There were no significant differences between treatments in the three studies in which this outcome was measured, although benefits were reported for both TRT treatments. However, the SOE was insufficient for studies evaluating the effects on sound technology interventions on subjective loudness.

##### Sleep Disturbance

No study in this category evaluated this outcome.

##### Anxiety

One study98 evaluated this outcome.

All groups in the study demonstrated improvement, but adding NG to TE or CBT did not increase benefit and may even have decreased it. However, the SOE was insufficient for studies evaluating the effects on sound technology interventions on anxiety.

##### Depression

One study98 evaluated this outcome, but only for the groups receiving CBT and not for the groups receiving TE because few participants had clinically significant results pre-treatment.

There was no benefit from CBT with or without NG. However, the SOE was insufficient for studies evaluating the effects on sound technology interventions on depression.

##### Global Quality of Life

Three studies61,92,98 evaluated this outcome using a variety of different measures.

Benefit was reported for all interventions involving TRT, but there were no differences depending on the technology used.61 No benefits were reported in the other two studies. However, the SOE was insufficient for studies evaluating the effects on sound technology interventions on global QoL.

#### Characteristics of Included Studies

Five publications (four head-to-head studies) were included for KQ2 and were classified into the sound treatment/technology intervention category (Table 21).53,61,91,92,98 Two articles reported on the same results91,92 and only one92 will be discussed in this section. As well, two different interventions were presented in one article and they will be described separately in the intervention section (described as STUDY A and STUDY B).98 See Appendix E for the Characteristics of Included Studies Evidence Tables.

Table 21 Interventions and comparators used in studies that evaluate sound treatment/technology interventions and outcomes

Sound Treat Intervention | | Specific Intervention | Sleep | Anxiety Symptoms | Depression Symptoms | Loudness | Global QoL | Tinnitus-Specific QoL | Adverse Effects
| | HEAD-TO-HEAD
| 1 | Hearing aids vs. SG Parazzini,61 2011 | | | | subjective | VAS | THI | NR
| 2 | Neuromonics Tinnitus Treatment – 2^nd^ study One-stage: Intermittent perception Two-stage: complete covering of perception initially, then intermittent Davis,53 2007 | | | | VAS | | TRQ VAS | NR
| 3 | Group I: Information Only Group IR: information plus relaxation training Group ID: information plus LTWN Group IDR: information plus relaxation plus LTWN Dineen,91,92 1997,1999 | | | | VAS | DSP (total stress) | TRQ, VAS VAS (coping), change in awareness | NR
| 4 | CBT with NG CBT alone Hiller,98 2004 STUDY A | | WI | | VAS | | TQ, T-cog | NR
| | TE plus NG TE no NG Hiller,98 2004 STUDY B | | WI | | VAS | SCL-90R, PSDI | TQ, T-cog, VAS, Diary of symptoms | NR

Abbreviations: DSP=Derogatis Stress Profile; LTWN = long-term low level white noise; med/surg = medical/surgical; NG = noise generator; NR = not reported; PDPSDI = Positive Symptom Distress Index; QoL = Quality of Life; SG = sound generator; T-cog = Tinnitus Cognition Scale; TE = tinnitus education; THI = Tinnitus Handicap Inventory; TQ = Tinnitus Questionnaire; VAS = visual analogue scale; WI = Whiteley Index

##### Population—Duration and Severity of Tinnitus

The subjects in all of studies were from the general population of those experiencing subjective idiopathic tinnitus. For one study, the duration of time participants had been bothered by their tinnitus before being eligible for the intervention study was a minimum of 6 months.98 In other papers, the majority of the participants were identified as having tinnitus for 11 years,53 and 69.5 months.61 One study did not report on the duration of tinnitus prior to the intervention.92

The severity of the tinnitus was not consistently identified prior to treatment among subjects in the four studies. One article included patients with moderate to severe tinnitus53 while one included individuals with chronic tinnitus.98 Two articles did not report on the severity of tinnitus.61,92 The presumed etiologies of tinnitus were described as hearing loss,98 and bilateral hearing loss.61 Presumed etiology was not reported in two studies.53,92 Audiological factors at study enrollment included decreased sound tolerance,53 and borderline between category 1 and category 2 according to the Jastreboff classification with hearing loss (HL) ≤ 25 dB HL at 2 kilohertz (kHz) and HL ≥ 25 dB HL at frequencies higher than 2 kHz.61 Two articles did not report on audiological factors at enrollment.92,98

##### Head-to-Head Interventions

All four studies53,61,92,98 categorized under the sound treatments/technology category (Table 21, and Appendix E, Table E3.) focused on head-to-head comparison including: hearing aids versus sound generators;61 one stage intermittent perception plus two stage complete covering of perception initially, then intermittent;53 information only, information plus relaxation training, information plus long-term low level white noise (LTWN), information plus relaxation training plus LTWN;92 and cognitive behavioral therapy (CBT) with noise generator (NG), CBT alone, tinnitus education (TE) plus NG, and TE with no NG.98

##### Outcomes

Most studies reported data on more than one outcome (Table 21, also Appendix E, Table E3.). The outcome measurement instruments used varied for the same outcomes (Table 22). For example, four different instruments were used to measure the outcome of TSQoL. Upon discussion with clinical experts, the following decisions regarding outcomes were made. All results that addressed the outcomes of interest were extracted. However, when a clinical outcome was measured using multiple scales within the same study, the outcome was reported once for that study. Data was extracted for the most widely used scale for that outcome, even if both scales were validated. This approach was implemented to facilitate better comparability between studies. The results of any studies that used the terms ‘annoyance’ or ‘distress’ were included to describe outcomes in the category of ‘discomfort.’

Table 22 Outcome measurements used in sound technology intervention studies

Outcome | Outcome Measurement Used
Anxiety Symptoms | WI (Whiteley Index)98
Subjective loudness | VAS (Visual Analogue Scale)53,92,98 Subjective61
Global Quality of Life | VAS (Visual Analogue Scale)61 DSP(The Derogates Stress Profile)92 SCL-90R (Symptom Checklist, general psychopathology98
Tinnitus-Specific Quality of Life | TRQ (The Tinnitus Reaction Questionnaire)53,92 TQ (Tinnitus Questionnaire)98 VAS (Visual Analogue Scale)53,92,98 TRSS (Tinnitus-Related Self-Statements Scale)18

##### Setting

The research settings were a tinnitus clinic,61 a university hearing clinic,92 and an outpatient department.98 One paper did not report the setting (Appendix E, Table E3).53

##### Country

The studies were carried out in Australia53,92 the United States and Italy,61 and Germany.98

##### Sources of Funding

Sources of funding included the Australian Commonwealth Government via a Biotechnology Innovation Fund,53 grants from a Tinnitus Research Initiative,61 and financial support from the German Tinnitus Association.98 One paper did not reveal the source of funding.92

#### Risk of Bias for Sound Technologies

The risk of bias in the four studies was mixed (n=3 fair; n=1 poor).53,61,92,98 All authors reported their studies as randomized, with appropriate randomization in 50 percent (n=2) of articles53,61 and not described in two.92,98 All articles did not involve double-blinding due to the nature of the interventions. Three (75 percent) articles reported the inclusion/exclusion criteria,53,61,98 and all described the statistical methods used (Figure 13).

Figure 13 Distribution of methodological risk of bias criteria of randomized controlled trials for the sound technology interventions

Figure 13 depicts the risk of bias for sound technology interventions. All of the studies were RCTs; yet in only 50% of cases the randomization process was deemed appropriate. None of the articles reported using appropriate double blinding techniques. Twenty-five percent of studies reported withdrawals by number and reason per arm, while none reported the methods used to assess adverse effects. Seventy-five reported inclusion and/or exclusion criteria, and all described the statistical analysis used. None of the articles reported that the intervention/drug allocation was concealed. None of the articles reported that the analysis was based on “intention to treat” and none justified their sample size.

Issues with risk of bias in the RCTs included a lack of reporting on withdrawals (n=3, 75 percent),53,61,92 no description of methods to assess adverse effects (n=4, 100%),53,61,92,98 inadequate concealment of allocation (n=4, 100%),53,61,92,98 analysis not based on intention-to-treat principle (n=3, 75%),61,92,98 and inadequate justification of sample size (n=4, 100%).53,61,92,98

#### Results for Sound Technologies by Outcome

##### Tinnitus-Specific Quality of Life

All studies measured the effectiveness of treatment using a tinnitus-specific measure; however, a variety of different measures were used in each study, including the TRQ and a single-item VAS,53,92 the TQ and VAS,98 and the THI.61 A significant reduction in tinnitus severity on the THI was found for the TRT treatment delivered with either sound generators or open ear hearing aids, but no difference between treatments was found.61 A significant reduction in tinnitus disturbance on the TRQ was reported for a one-stage version and a two-stage version of Neuromonics tinnitus treatment; however, there was no significant difference in the reduction found for the two versions of the treatment which differed in terms of when and to what extent tinnitus perception was totally covered up or intermittent.53 Note that the author of this study developed Neuromonics and continues to work for the company. In a study comparing four treatments offering information, white noise, relaxation or combinations of these components, no differences between treatments was found on the TRQ.92 No significant effect of intervention was found on the TQ or the Tinnitus Cognition Scale (T-Cog) in a study98 investigating whether use of a low level white-noise generator (NG) would enhance the effects of CBT, or tinnitus education (TE), with the degree of tinnitus-related stress determined using the Structured Tinnitus Interview (STI).

Overall, significant benefits of treatment in terms of TSQoL measures were reported in half of the studies, but there were no significant differences between the treatments that were compared using such measures.

##### Subjective Loudness

All but one of the studies61,92,98 evaluated the effects of intervention on the subjective loudness of the tinnitus.61,92,98 Significant reductions in subjective loudness were reported in one study61 in which TRT was delivered with either sound generators or open ear hearing aids; however, there was no difference between treatments on this outcome measure. In a study comparing four treatments with information, white noise, relaxation or combinations of these components, no change in subjective loudness was found for any of the treatments.92 No significant differences between treatments in reduction of subjective loudness were reported in a study comparing the benefit of combining the use of NG with either CBT or TE.98

Overall, it seems that the effects of intervention on subjective loudness did not differentiate the interventions that were compared.

##### Sleep Disturbance

No studies evaluated the effects of the interventions on sleep.

##### Anxiety

Only one study98 evaluated the effects of intervention on anxiety. In one study98 that sought to determine if the addition of sound stimulation provided by the use of low level white-noise generators would enhance the effects of CBT or TE, the Whiteley Index (WI) was used to measure health-related anxieties. All groups demonstrated improvement on the WI, but no statistically significant additional benefit due to NG was observed when it was combined with either TE or CBT and in fact, adding NG seemed to have a deleterious effect on the WI outcome measure.98

##### Depression

Only one study reported the effects of the interventions on depression symptoms. No significant effect of CBT treatment either with or without NG was found when the SCL-90R was used to measure depression,98 but changes due to the TE with or without NG were not reported because not all participants had clinically significant conditions pre-treatment.

##### Global Quality of Life

Global quality of life was measured in three studies,61,92,98 using a number of different measurement tools. A significant reduction in tinnitus severity on the single item “effect on life” VAS was found for the TRT treatment delivered with either sound generators or open ear hearing aids, but no difference between treatments was found.61 In a study comparing four treatments with information, white noise, relaxation or combinations of these components, no differences between treatments were found on the DSP measure of life stress.92 The SCL-90R of the Positive Symptom Distress Index (PSDI) and the Dysfunctional Analysis Questionnaire (DAQ) were used to measure psychopathology and psychosocial functioning, respectively,98 with no significant effects of treatment being found for the CBT intervention with or without NG, while changes due to treatment were not reported for the TE intervention with or without NG because not all participants had clinically significant conditions pre-treatment.

Overall, although benefits of treatment were reported for TRT, no benefits were reported for the other interventions and no differences between treatments were discernible using this outcome.

##### Strength of Evidence—Sound Technologies

The types of sound technologies and comparator groups within each study were markedly diverse. For this reason we did not prepare formal SOE tables as all would have a similar rating of insufficient irrespective of the outcome being measured. All the studies evaluating sound technologies relative to different active comparators were considered to be at high risk of bias and unknown consistency. The very small sample sizes within the studies is a factor contributing to the rating of ‘imprecise’. Overall, there is insufficient information to judge the SOE for the head-to-head studies evaluating sound technologies.

### Psychological and Behavioral Interventions

#### Key Messages

Nineteen studies were included as psychological and behavioral interventions for KQ2. They were organized into four general sub-categories: CBT, TRT, relaxation, and other.

- Ten compared some form of CBT to an inactive control and six compared CBT to another treatment.
- Two compared TRT to an inactive control and three compared TRT to another treatment,
- Three compared some form of relaxation therapy to an inactive control and one compared relaxation to another treatment.
- Six studies evaluated some other type of psychological/behavioral therapy compared to an inactive control and one involved head-to-head comparisons between treatments.

The research settings were varied; some studies recruited patients from ENT, audiology or psychology clinics at hospitals or universities and others recruited volunteers using newspapers or the internet.

Most studies recruited participants from the general population of middle-aged or older adults experiencing subjective idiopathic tinnitus. Three studies focused on specific subpopulations: veterans,97 industrial workers,81 and older adults.84

Eligibility criteria in terms of duration and severity of tinnitus varied.

Some studies restricted participation to those without significant depression or anxiety.

Nine studies in the psychological/behavioral grouping have sample sizes greater than 20 subjects per group and most had less than 50 subjects per group.

##### Subjective Loudness

Eight RCT studies with WLCs investigated the effects of 16 interventions on subjective loudness. Although benefits in subjective loudness were suggested by two CBT interventions, CBT combined with biofeedback18 and a self-help book with telephone therapy,100 overall, there was low SOE for no effect in subjective loudness from CBT.

SOE was insufficient for other interventions.

##### Sleep Disturbance

Five RCT studies with WLCs investigated the effects of nine interventions on sleep. Although benefits in sleep were suggested by two studies in the CBT sub-category, biofeedback-based CBT,18 and self-help book with telephone therapy,100 overall, there was low SOE for no effect in sleep from CBT.

SOE was insufficient for other interventions.

##### Anxiety Symptoms

Five RCT studies with WLCs investigated anxiety symptoms in nine interventions as one of the main outcomes57,62,84 or as a secondary outcome100,120 that was compared to a WLC group. Although benefits in anxiety were noted in one study in the CBT sub-category: self-help book with telephone therapy,100 overall, there was low SOE for no effect in anxiety from CBT.

SOE was insufficient for other interventions.

##### Depression Symptoms

Eleven RCT studies with WLCs investigated the effects of 22 interventions on depression symptoms, but depression was a primary outcome in only two studies57,62 and a secondary outcome in the others. Although benefits in depression were suggested for four interventions in the CBT sub-category: self-help with telephone therapy,100 CR with or without ACI,96 and biofeedback-based CBT18 and benefit was also suggested for two interventions using relaxation and distraction,10,62 overall, there was low SOE for no effect in depression symptoms from CBT.

SOE was insufficient for other interventions.

##### Global Quality of Life

Six RCT studies with WLCs investigated the effects of 11 interventions on global quality of life. Although benefits in global quality of life were suggested for biofeedback-based CBT18 and bibliotherapy,104 and marginally for psycho-physiologic therapy,112 overall, there was low SOE for no effect in global QoL from CBT and bibliotherapy.104

SOE was insufficient for other interventions.

#### Characteristics of Included Studies

A total of 19 RCT articles10,17,18,57,62,64,81,84,87,95–97,100–102,104,112,120,121 evaluated interventions in the psychological and behavioral domain (Table 23, Appendix E, Table E4). The interventions in this domain are organized in four sub-categories, including those involving primarily some form of cognitive behavioral therapy (CBT), a version of tinnitus retraining therapy (TRT), relaxation, or other therapies (e.g., education, Qigong, yoga).

Table 23 Interventions and comparators used in studies that evaluate psychological and behavioral interventions and outcomes

Psych/Beh Intervention | | Specific Intervention | Sleep | Anxiety Symptoms | Depression Symptoms | Loudness | Global QoL | Tinnitus-Specific QoL | Adverse Effects
CBT/CBT Combination | | INACTIVE COMPARISONS
CBT/CBT Combination | 1 | CBT vs. no treatment Andersson,84 2005 | | HADS-A^*^, ASI | HADS-D | | | TRQ | NR
CBT/CBT Combination | 2 | CBT via the internet vs. WLC Andersson,57 2002 | VAS | HADS-A^*^, ASI | HADS-D | VAS | | TRQ^*^, VAS-Ann, VAS-Ctrl | NR
CBT/CBT Combination | 3 | CR vs. WLC Henry JL and Wilson PH,96 1998 | | | BDI | | | TRQ^*^, TEQ, THQ (handicap), TCSQ (coping) TCQ | NR
CBT/CBT Combination | | CR combined with ACI vs. WLC Henry JL and Wilson PH,96 1998 | | | BDI | | | TRQ^*^, TEQ, THQ (handicap), TCSQ (coping) TCQ | NR
CBT/CBT Combination | | ACI vs. WLC, Henry JL and Wilson PH,96 1998 | | | BDI | | | TRQ^*^, TEQ, THQ (handicap), TCSQ (coping) TCQ | NR
CBT/CBT Combination | 4 | CBT & Education vs. WLC Henry JL and Wilson PH,95 1996 | | | BDI | Self-report | | TRQ^*^, TEQ, THQ (handicap), TCSQ (coping), TCQ (Awareness) | NR
CBT/CBT Combination | 5 | CBT-biofeedback-based vs. WLC Weise,18 2008 | VAS^*^, TQ-sub | | BDI | VAS | GSI SCL-90R | TQ^*^, VAS TRSS (catastrophizing), TRCS (helplessness) | NR
CBT/CBT Combination | 6 | TCT1 vs. WLC Kroner-Herwig,102 1995 | Diary, TQ subs^*^ | | Dep-Skala | Diary | Bef-Skala Bes-Liste^*^ | TQ Diary | NR
CBT/CBT Combination | | TCT2 vs. WLC Kroner-Herwig,102 1995 | Diary, TQ subs^*^ | | Dep-Skala | Diary | Bef-Skala Bes-Liste^*^ | TQ Diary | NR
CBT/CBT Combination | 7 | TCT vs. WLC Kroner-Herwig,17 2003 | | | ADS | Diary | SCL-90R GSI | TDI TQ^*^ TC (COPE subscales) | NR
CBT/CBT Combination | 8 | Psychophysiological therapy vs. WLC, Rief,112 2005 | | | | Diary | HRLS^*^ GSI SCL-90R | TQ^*^, emotional cognitive distress | None
CBT/CBT Combination | 9 | Self-help book and brief phone therapy vs. WLC Kaldo,100 2007 | ISI | HADS-A | HADS-D | VAS | | THI (handicap) TRQ^*^, VAS | NR
CBT/CBT Combination | 10 | ACT vs. WLC, Westin,120 2011 | ISI | HADS-A | HADS-D | | QoLI | THI (Tinnitus Impact) | None
CBT/CBT Combination | | HEAD-TO-HEAD COMPARISONS
CBT/CBT Combination | 1 | CBT vs. Information only Abbott,81 2009 | VAS | DASS-A | DASS-D | VAS | WHO-QoL | X TRQ, VAS, OSI-R (occupational) | None
CBT/CBT Combination | 2 | Intervention: Internet based self help Control (usual care) vs. Standard group CBT Kaldo,101 2008 | ISI | HADS-A | HADS-D | VAS | | THI TRQ, VAS | NR
CBT/CBT Combination | 3 | CBT vs. ACI Henry JL and Wilson PH,96 1998 | | | BDI | | | TRQ^*^, TEQ, THQ (handicap), TCSQ (coping) TCQ | NR
CBT/CBT Combination | | CBT vs. CBT combined with ACI Henry JL and Wilson PH,96 1998 | | | BDI | | | TRQ^*^, TEQ, THQ (handicap), TCSQ (coping) TCQ | NR
CBT/CBT Combination | | ACI vs. CBT combined with ACI Henry JL and Wilson PH,96 1998 | | | BDI | | | TRQ^*^, TEQ, THQ (handicap), TCSQ (coping) TCQ | NR
CBT/CBT Combination | 4 | CBT & Education vs. Education WLC Henry JL and Wilson PH,95 1996 | | | BDI | Self-report | | TRQ, TEQ, TCSQ(coping), TCQ | NR
CBT/CBT Combination | 5 | TCT1 vs. TCT2 Kroner-Herwig,102 1995 | Diary TQ | | Dep-Skala | Diary | Bef-Skala Bes-Liste^*^ | TQ Diary | NR
CBT/CBT Combination | | TCT2 vs. yoga Kroner-Herwig,102 1995 | Diary TQ | | Dep-Skala | Diary | Bef-Skala Bes-Liste^*^ | TQ Diary | NR
CBT/CBT Combination | 7 | TCT vs. EDU Zachriat,121 2004 | | | | Diary | VEV | TQ, TCQ, JQ, Diary (awareness) | NR
CBT/CBT Combination | | TCT vs. HT Zachriat,121 2004 | | | | Diary | VEV | TQ, TCQ, JQ, Diary (awareness) | NR
TRT | | INACTIVE CONTROL
TRT | 1 | Group education counseling (TRT principles) vs. no treatment Henry,97 2007 | | | | | | TSI | None
TRT | 2 | TRT vs. WLC, Westin,120 2011 | ISI | HADS-A | HADS-D | | QoLI | THI (Tinnitus Impact) | None
TRT | | HEAD-TO-HEAD
TRT | 1 | CBT with TRT vs. usual care or no treatment Cima,64 2012 | | | HADS | | HUI | TQ THI (impairment) | None
TRT | 2 | TRT vs. ACT, Westin,120 2011 | ISI | HADS-A | HADS-D | | QoLI | THI (Tinnitus Impact) | None
TRT | 3 | Group education counseling (TRT principles) vs. Traditional support group Henry,97 2007 | | | | | | TSI | None
Relaxation | | INACTIVE COMPARATOR
Relaxation | 1 | Relaxation therapy vs. WLC Scott,10 1985 | | | Self-report-R | Self-report-D | | Self-report-D | Yes
Relaxation | 2 | Relaxation therapy Counter-demand vs. WLC Ireland,62 1985 | | STAI | BDI | Self-report | | Tinnitus interference (self-report) | NR
Relaxation | | Relaxation therapy Neutral-demand. vs. WLC Ireland,62 1985 | | STAI | BDI | Self-report | | Tinnitus interference (self-report) | NR
Relaxation | | Relaxation therapy Counter-demand -2vs. WLC Ireland,62 1985 | | STAI | BDI | Self-report | | Tinnitus interference (self-report) | NR
Relaxation | | Relaxation therapy Neutral-demand -2vs. WLC Ireland,62 1985 | | STAI | BDI | Self-report | | Tinnitus interference (self-report) | NR
Relaxation | 3 | Relaxation vs. WLC Kroner-Herwig,17 2003 | | | ADS | Diary | GSI SCL-90R | TDI (disability), TQ^*^ TC (COPE-subscales) | NR
Relaxation | | HEAD-TO-HEAD
Relaxation | 1 | Relaxation therapy Counter-demand vs. Neutral Demand Ireland,62 1985 | | STAI | BDI | Self-report | | Tinnitus interference (self-report) | NR
Relaxation | 2 | Relaxation therapy-2 vs. Neutral-demand-2 Ireland,62 1985 | | STAI | BDI | Self-report | | Tinnitus interference (self-report) | NR
Other | | INACTIVE COMPARATOR
Other | 1 | Education vs. WLC Kroner-Herwig,17 2003 | | | ADS | Diary | GSI SCL-90R | TDI (disability), TQ^*^ TC (COPE- subscales) | NR
Other | 2 | Education alone vs. WLC Henry JL and Wilson PH,95 1996 | | | BDI | Self-report | | TRQ, TEQ THQ (handicap), TCSQ (coping), TCQ (Awareness) | NR
Other | 3 | Traditional support group vs. no treatment Henry,97 2007 | | | | | | TSI | None
Other | 4 | Bibliotherapy vs. WLC Malouff,104 2010 | | | | | GHQ-12 | TRQ | None
Other | 5 | Qigong therapy vs. WLC Biesinger,87 2010 | | | | | | TBF-12^*^, VAS | None
Other | 6 | Yoga vs. WLC Kroner-Herwig,102 1995 | Diary TQ | | Dep-Skala | Diary | Bef-Skala Bes-Liste | TQ | NR
Other | | HEAD-TO-HEAD
Other | 1 | EDU vs. HT Zachriat,121 2004 | | | | Diary | VEV | TQ, TCQ, JQ, Diary(awareness) | NR

Abbreviations: ACI = attention control and imagery traiing; ACT = acceptance and commitment therapy; ADS = A Depression Scale, The German version of CES-D “Center for Epidemiologic Studies Depression scale”; Ann = annoyance; ASI = Anxiety Sensitivity Index; BDI = Beck Depression Inventory; CBT = cognitive behavioral training; CR = cognitive restructuring; DASS-A = Depression and Anxiety Stress Scale; DASS-D = Depression and Anxiety Stress Scale; EDU = educational control-group; EDU = education; GHQ = general health questionnaire; HADS = Hospital Anxiety and Depression Scale; HADS-A = Hospital Anxiety and Depression Scale – Anxiety subscale; HADS-D = Hospital Anxiety and Depression Scale – Depression subscale; HRLS = health-related life satisfaction; HT = habituation-based treatment; ISI = Insomnia Severity Index; JQ = Jastreboff Questionnaire; NR = not reported; OSI-R = Occupational Stress Inventory–Revised; psych/beh = psychological/behavioral; QoL = Quality of Life; QoLI = Quality of Life Questionnaire Instrument; SCL-90R = Symptom Checklist, general psychopathology; STAI = State-Trait Anxiety Inventory; TBF-12 = Tinnitus Questionnaire; TCT = tinnitus coping therapy; TCQ = Tinnitus Cognitions Questionnaire; TCSQ = Tinnitus Coping Strategies Questionnaire; TDI = Tinnitus Disability Questionnaire; THI = Tinnitus Handicap Inventory; THQ = Tinnitus Handicapped Questionnaire; TQ = Tinnitus Questionnaire; TRCS = The Tinnitus-Related Control Scale; TRQ = The Tinnitus Reaction Questionnaire; TRSS = Tinnitus-Related Self-Statements Scale; TRT = tinnitus retraining therapy; TSI = Tinnitus Severity Index; VAS = visual analogue scale; VEV = changes in wellbeing and adaptive behavior; vs. = versus; WLC = wait list control.

* Indicates the test used to measure outcomes which were selected to represent the domain in the forest plots (and subsequent SOE decisions)

##### Population—Duration and Severity of Tinnitus

The subjects in the majority of studies were from the general population of those experiencing subjective idiopathic tinnitus. Three studies focused on specific subpopulations of veterans,97 individuals from various industrial organizations,81 and older adults.84

For some studies, the duration of time participants had been bothered by their tinnitus before being eligible for the intervention study was a minimum of 3 months.87 In other studies tinnitus had to have been bothersome for greater than 3 months,81,101,121 and at least 6 months.18,57,95,96,100,112 In other papers, the majority of the participants were identified as having tinnitus for 3 years or more,97 8.3 years,120 9.4 years,10 and 13 years.84 Other publications did not report on the duration of tinnitus prior to the intervention.10,17,62,64,104

The severity of the tinnitus was not consistently identified prior to treatment among subjects in the 19 publications. Some studies included an assessment by an otolaryngologist (ENT), audiologist or a physician being consulted about tinnitus;57,95,96,100 one study included only persons who had not received treatment elsewhere, or persons for whom previous treatments had failed.62 In the inclusion criteria, tinnitus was identified as having to be a ‘main’ or ‘major’ complaint,87 perceived as constant,10 ‘sufficiently bothersome to warrant intervention’,97 and as ‘disabling chronic uni- or bi-lateral.’108 Some studies required specific scores on tinnitus severity scales to meet study inclusion criteria. These include: a score of 10 or greater on the Tinnitus Reaction Questionnaire (TRQ);100,101 a distress score greater than 17 points on the TRQ;95,96 a score greater than 46 (high annoyance) on the Tinnitus Questionnaire (TQ) Modified version;18 a score of greater than 40 on nine scales assessing the disruptive effects of tinnitus;17 a Visual Analogue Scale (VAS) score (range=0 to 10) of greater than 3;^112^ ≥30 on the Tinnitus Handicap Inventory (THI) scale;120 and a tinnitus of grade 2 or 3.^10,147^

##### Interventions

There is considerable heterogeneity among the treatments categorized as Psychological and Behavioral Interventions and also within each of the four sub-categories of CBT, TRT, relaxation and other. For the purposes of the present review, general characteristics of the therapies rather than the specific details of the therapeutic protocols guided the placement of studies in the sub-categories (Table 23).

CBT does not exist as a distinct therapeutic technique and has no strict definition. It is a form of psychotherapy that emphasizes the important role of thinking in how we feel and what we do. Insofar as it involves psychotherapy, it features an interaction between a clinician and patient, but the format could be individual or group, and it could be delivered in person or at a distance with telephone or internet contact. Studies were considered to be in the CBT subcategory if the author described the intervention as CBT or as being CBT-based or involving tinnitus coping training (TCT) or a cognitive approach such as attention control and imagery (ACI), cognitive restructuring (CR), or acceptance and commitment therapy (ACT). CBT for the elderly84 was compared to no treatment, and internet CBT57 and TCT17 were compared to an inactive control. CBT combined with biofeedback18 and a psychophysiological-oriented intervention combining CBT and relaxation components112 were compared to WLCs. In one study,102 comparisons were made between four conditions: a WLC, the same CBT intervention administered by two different clinicians (TCT1 and TCT2), and yoga. In another study,96 comparisons were made between three conditions: a WLC and two types of cognitive intervention, ACI and CR provided alone or in combination. In another study,95 comparisons were made between three conditions: a WLC, CBT with education and education alone. An additional two studies compared CBT to other treatments: an information only intervention81 or to internet-based self-help.101 A final study121 compared TCT to two other interventions, habituation-based treatment (HT) and education.

TRT is a well-known intervention that features both the use of sound and a particular type of structured directive counseling. Studies were placed in the TRT category if the intervention was described as TRT or included a component based on TRT principles, and it was compared to either an inactive control or in a head-to-head comparison to another psychological/behavioral intervention. Three articles64,97,120 evaluated forms of TRT with an emphasis on the behavioral aspect of TRT (note that one other article61 focused on comparing the sound technology aspect of TRT and it was included in the section on Sound Technology Interventions). In one study, interventions in which TRT principles were applied to either a traditional support group or to group education and counseling were compared to a WLC or each other.97 In the other study,120 TRT was compared to a WLC and to ACT. A final additional study compared a combination of CBT and TRT to usual care.64

Relaxation may be incorporated into the protocols of many interventions, but studies evaluating interventions in which relaxation was the main approach were allocated to the relaxation sub-category. Three articles10,17,62 compared interventions focused on relaxation to WLCs. In one of the studies,62 the relaxation therapy was administered in the same way to four groups, with instructions that were either neutral or counter-demand (participants were told not to expect improvements until after five weeks) and with two groups recruited for each instruction condition; thus, comparisons between the four groups and the WLC could be made as well as comparisons between groups receiving the same or different instructions.

The “other” sub-category was used to group studies evaluating psychological/behavioral interventions not assigned to the CBT, TRT or relaxation sub-categories. Some of the studies involving CBT, TRT and relaxation interventions listed above also included comparisons between other treatments and a WLC, including: education,17 bibliotherapy,104 Qigong therapy,87 and yoga.102 Finally, one study121 included a head-to-head comparison between HT and education.

##### Comparators

Ten articles17,18,57,84,95,96,100,102,112,120 had an inactive control, with either no treatment84 or a WLC (WLC)17,18,57,95,96,100,102,112,120 compared to various forms CBT administered either alone or in combination with other treatments. These, along with the head-to-head comparisons are detailed in Table 23.

Comparators for the articles assessing TRT included no treatment97 and WLC.120 The comparators for relaxation therapy10,17,62 and for other interventions were also all WLC.17,87,102,104

##### Outcomes

Most studies reported data on more than one outcome (Table 23). The outcome measurement instruments used varied for the same outcomes (Table 24). For example, 19 different instruments were used to measure the outcome of TSQoL. Upon discussion with clinical experts, the following decisions regarding outcomes were made. All results that addressed the outcomes of interest were extracted. However, when a clinical outcome was measured using multiple scales within the same study; the outcome was reported once for that study. Data was extracted for the most widely used scale for that outcome, even if both scales were validated. This approach was implemented to facilitate better comparability between studies. The results of any studies that used the terms “annoyance” or “distress” were included to describe outcomes in the category of “discomfort.”

Table 24 Outcome measurements used in psychological and behavioral intervention studies

Outcome | Outcome Measurement Used
Tinnitus-Specific Quality of Life | TRQ (The Tinnitus Reaction Questionnaire)57,81,84,95,96,100,101,104 TEO (Tinnitus Effects Questionnaire)95,96 THQ (Tinnitus Handicapped Questionnaire)95,96 TCSQ (Tinnitus Coping Strategies Questionnaire)95,96 TCQ (Tinnitus Cognitions Questionnaire)95,96,121 TQ (Tinnitus Questionnaire)17,18,64,112,121 VAS (Visual Analogue Scale)18,57,81,87,100,101 TRSS (Tinnitus-Related Self-Statements Scale)18 TRCS (The Tinnitus-Related Control Scale)18 TCT (Tinnitus Coping Training)17 OSI-R (Occupational Stress Inventory–Revised)81 THI (Tinnitus Handicap Inventory)64,100,101,120 TSI (Tinnitus Severity Index)97 Self-report Direct and Retrospect10,62 TDI (Tinnitus Disability Questionnaire)17 JQ (Jastreboff Questionnaire)121 Diary (awareness)121 TBF-12 (Tinnitus Questionnaire)87 Diary-D,I,C,TQPQ, TQSC102,121
Subjective loudness | VAS (Visual Analogue Scale)18,57,81,100,101 Self-rated/reported scale/score10,62,95 Diary17,102,112,121
Sleep Disturbance | VAS (Visual Analog Scale)18,57,81 ISI (Insomnia Severity Index)100,101,120 TQ (Tinnitus Questionnaire subscale – sleep disturbance)18,102 Diary102
Anxiety Symptoms | HADS-A (Hospital Anxiety and Depression Scale – Anxiety subscale)57,84,100,101,120 DASS-A (Depression and Anxiety Stress Scale)81 STAI (State-Trait Anxiety Inventory)62 ASI (Arabic Scale of Insomnia)57,84
Depression Symptoms | HADS-D (Hospital Anxiety and Depression Scale – Depression subscale)57,84,100,101,120 BDI (Beck Depression Inventory)18,62,95,96 DASS-D (Depression and Anxiety Stress Scale )81 ADS (A Depression Scale, The German version of CES-D “Center for Epidemiologic Studies Depression scale”)17 Self-report Retrospect10 HADS (Hospital Anxiety and Depression Scale - Depression and Anxiety composite)64 Depressivitats-Skala102
Global Quality of Life | HUI-3 (Health Utilities Index-3)64 GSI (Global Severity Index – Symptom Checklist self-rating questionnaire)18 WHO-Social (Quality of Life Questionnaire)81 QoLI (Quality of Life Questionnaire Instrument)120 SLR-90R (Symptom Checklist self-rating questionnaire)17 HRLS (psychological symptoms short form of SCL-90R)112 GSI (General Symptomatic Index)112 GPD104 VEV (Changes in wellbeing and adaptive behavior induced by treatment which go beyond modification of tinnitus related illness)121 Befindlichkeits-Skala, Beschwerden liste102 TQ102

##### Setting

The research settings were in departments of audiology,10,102,120 psychology,121 psychology outpatient,18 psychotherapy outpatient,112 university clinic,62 hospital (department not reported),97 clinic,62,64,101 phone/mail,100 newspaper and radio advertisements,96 and the internet.57,81,84,101,104 Three papers did not report the research setting.17,87,95

##### Country

The studies were carried out in several different countries: Sweden;10,57,84,100,101,120 the United States;97 Australia;62,81,95,96,104 Germany;17,18,87,102,112,121 and the Netherlands.64

##### Sources of Funding

Sources of funding were not reported in seven studies.62,87,95,96,101,102,112 Twelve publications received funding from research councils, foundations, and government departments and non-profit associations.10,17,18,57,64,81,84,97,100,104,120,121

#### Risk of Bias for Psychological/Behavioral Interventions

The risk of bias in the 19 RCTs evaluating psych/behavioral interventions was mixed (n=9 fair;18,81,87,96,97,100,112,120,121 n=8 poor;10,17,62,84,95,101,102,104 and n=2 good.57,64 All authors reported their studies as randomized, with appropriate randomization in 53 percent (n= 10) of articles18,57,64,81,87,97,100,112,120,121 and inappropriate randomization in three (16%).17,101,104 The randomization method was not described in six articles (32%).10,62,84,95,96,102 Double-blinding was not possible due to the nature of the interventions. All articles reported the inclusion/exclusion criteria, and all but three (84%)17,102,104 described the statistical methods used (Figure 14).

Figure 14 Distribution of risk of bias scores of randomized controlled trials for the psychological and behavioral category (n=19)

Figure 14 depicts the risk of bias for psychological and behavioral interventions. All of the studies were RCTs; yet in only 53% of cses the randomization process was deemed appropriate. None of the articles reported using appropriate double blinding techniques. Thirty-two percent of studies reported withdrawals by number and reason per arm, with only 5% reporting the methods used to assess adverse effects. All studies reported inclusion and/or exclusion criteria, and most (84%) described the statistical analysis used. Only 16% of articles reported that the intervention/drug allocation was concealed. Only 42% reported that the analysis was based on “intention to treat” and only 26% justified their sample size.

Issues with risk of bias in the RCTs included: a lack of reporting on withdrawals: (n=13, 68%),10,17,18,62,84,95,97,101,102,104,112,120,121 no description of methods to assess adverse effects (n=18, 95%);10,17,18,57,62,81,84,87,95–97,100–102,104,112,120,121 inadequate concealment of allocation (n=13, 68%);10,17,62,84,87,95–97,100,101,104,112,120 analysis not based on intention-to-treat principle (n=9, 47%);10,17,62,84,87,95–97,112 and inadequate justification of sample size (n=13, 68%).10,17,62,81,84,87,95–97,100,102,104,121

#### Results for Psychological/Behavioral Interventions by Outcome

##### Tinnitus-Specific Quality of Life

Fifteen RCT studies with WLCs investigated the effects of 27 interventions on tinnitus-specific measures related to quality of life (TSQoL).10,17,18,57,62,84,87,95–97,100,102,104,112,120 See Table 23 and Table 24, and Appendix E, Table E4.

The primary measures used to evaluate this outcome included: TRQ,57,84,95,96,100,104 TQ,17,18,112 THI,120 TSI,97 TBF-12,^87^ TQ-PI,102 and other single self-report items.10,62 A variety of measures were also tested in addition to these primary measures.

Ten RCT studies with inactive controls evaluated the effect of 13 interventions in the CBT category on TSQoL outcome measures. The TRQ questionnaire was used to measure tinnitus-specific outcomes in five studies in the CBT category which investigated six interventions.57,84,95,96,100 A significant reduction in distress due to tinnitus was reported in a study in which CBT was delivered by internet57 (group effect on pre- vs. post-treatment change score: t(70)=3.99, p=0.002); however, when drop-outs were included in an intention-to-treat analysis there was no longer a significant effect. A significant effect in favor of treatment was also reported in a study in which elderly people received six weekly 2-hour group CBT sessions (F(1,21)=6.4, p=0.02).84 A study of two types of cognitive intervention, CR and ACI delivered either alone or together96 reported significant reductions in tinnitus distress for the CR, ACI and combined CR plus ACI interventions compared to the WLC (F(1,46)=6.11, p <0.05), but significantly more benefit was found when the intervention components were combined than when they were delivered alone. A study comparing a wait list group to two treatments, a cognitive coping training combined with education and an education alone treatment,95 reported a significant reduction in tinnitus distress which was significantly greater when the cognitive coping training was combined with education than when education alone was provided (F(1,57)=16.19, p <0.01). Finally, a significant reduction in tinnitus distress measured with the TRQ was found for the treatment involving a self-help book and telephone therapy100 (group × time interaction: (F(1,70)=12.4, p <0.001). The TQ was used as the outcome measure in four studies17,18,102,112 of five interventions in the CBT category. A study102 comparing a WLC group to those who received TCT (TCT1 and TCT2 were delivered by different clinicians) reported that TCT significantly reduced psychological impairment due to tinnitus as measured with a German version of the TQ (F(1,32)=4.43, p ≤0.04)). In another study comparing TQ outcomes for a WLC group to a group receiving cognitive behavioral TCT intervention,17 significant effects in favor of treatment were reported (F(1,34)=9.22, p <0.01). A psychophysiological CBT intervention112 yielded a significant reduction in tinnitus distress on the TQ in comparison to the WLC group (group × time interaction: F(1,41)=6.74, p <0.05, g=0.64), as did a biofeedback-based CBT intervention18 (F(1,109)=55.40, p <0.001, g=1.15). A significant reduction in tinnitus handicap as measured using the THI was reported in a study in which ACT was compared to a WLC group120 (group × time interaction: F(1,42)=12.16, p=0.001).

Two RCT studies with inactive controls evaluated the effect of three interventions involving TRT on tinnitus-specific handicap using the THI or severity using the TSI. Compared to a WLC group, TRT did not yield a significant improvement on the THI immediately post-treatment in one study.120 In the other study,97 a group counseling intervention based on TRT principles was compared to a WLC and to traditional group support using the TSI;97 significant group effects were not found at the 1-month followup, but the study reported a significant pre- vs. post-treatment improvement on the TSI for the counseling intervention based on TRT and at the 6-month and 1-year followup the counseling intervention yielded significantly greater improvements compared to either the WLC or the support group.

Three RCT studies evaluated the effect on TSQoL for six interventions involving relaxation.10,17,62 A significant effect of treatment on the TDI was reported for a minimal contact relaxation intervention compared to the WLC group (F(1,34)=6.79, p <0.01), but not on the TQ.17 For the other interventions involving relaxation, tinnitus-specific outcomes were measured by a single self-report item. In one study,10 a VAS ‘direct’ form (10-cm line with end-points labeled ‘none’ and ‘maximum’) was completed four times each day with a tinnitus discomfort/annoyance rating item pertaining to the last half-hour and a second retrospective form completed in the evening with a discomfort/annoyance rating item pertaining to the participant’s experience over the course of the day (with end points labeled ‘absent/very weak’ and ‘very loud/maximal’). A significant effect on both direct (group × time interaction: F(1,21)=6.01, p <0.05) and retrospective measures (group × time interaction: F(1,21)=7.92, p <0.01) was reported for a 10-week treatment consisting of training in relaxation, self-control by distraction, and how to apply these methods in everyday situations.10 In another study,62 no effect of a relaxation intervention, delivered with either neutral or counter-demand instructions to two different groups, was found when the extent to which tinnitus interfered with daily activities was measured using one item with a 4-point scale on a monitoring form that was completed daily for a 2-week period.62

Six RCT studies evaluated the effect of other psychological behavioral interventions compared to an inactive control on TSQoL.17,87,95,97,102,104 One study87 reported that Qigong (mindful exercise) significantly reduced tinnitus handicap as measured using the TBF-12 (a German version of the THI) (group × time interaction: F(3,66)=3.7, p=0.015). In another study,102 psychological impairment due to tinnitus measured with a German version of the TQ was not reduced by a yoga intervention. In a study comparing the TQ scores for a WLC group to a group receiving a minimal educational intervention,17 no significant effect in favor of treatment were reported. As mentioned above, one study95 evaluated the effect of CBT combined with education and an education alone intervention compared to a WLC on TRQ score and did not find a significant effect of the education alone treatment. One study evaluated the effect of treatment on tinnitus distress using the TRQ comparing a WLC to bibliotherapy104 and a significant reduction in tinnitus distress was found (F(1,122)=6.23, p =.01, d=0.28), but there was no significant effect when an intention-to-treat analysis was conducted for the bibliotherapy intervention.104 Finally, a traditional support group did not differ from the inactive control.97

As seen in the forest plots (Figure 15), almost all of the interventions tended to result in mean effects in favor of treatment. However, only the studies that had group sample sizes greater than 20^17,18,57,97,100,104,112,120^ showed results that could be considered to be significantly in favor of treatment in comparison to an inactive control group. Such positive effects were observed for a number of interventions in the CBT sub-category, including biofeedback-based CBT,18 psycho-physiologic CBT,112 internet CBT,57 cognitive TCT,17 self-help book with telephone therapy,100 and ACT,120 as well as one intervention in each of the other sub-categories, including group education with TRT principles,97 minimal contact relaxation17 and bibliotherapy.104

Figure 15 Studies with inactive comparators that evaluate psychological and behavioral interventions and report tinnitus-specific quality of life outcomes

This figure shows the effect size (standardized mean difference ‘SMD’) with 95% confidence interval for each study in a forest plot for psychological and behavioral interventions for the outcome of tinnitus specific quality of life. Nineteen studies show a SMD with 95% confidence interval that crosses 0 (no difference) between groups, while eight studies show a SMD with 95% confidence interval less than 0 (Favors treatment group as compared to control group).

###### Strength of Evidence—Tinnitus-Specific Quality of Life

There is low quality evidence (10 studies, 498 participants)17,18,57,84,95,96,100,102,112,120 that CBT interventions improve TSQoL when compared with inactive controls for patients with idiopathic tinnitus in the immediate or short term followup. Only two studies had a sample size greater than 30 subjects per group and as such, the majority of studies had small sample sizes and lack of power calculations; these studies were judged to be relatively imprecise for this reason. The direction of effect was judged to be consistent across studies showing that the findings favored the CBT treatments; half the studies18,57,100,112,120 showed statistically significantly differences relative to inactive controls. The confidence intervals had substantial overlap across studies and the magnitude of the effect size was generally greater than 0.5 (medium to large effect) with the exception of three studies.95,96,102 Although we judged the directness of these studies to be acceptable, we note that there was marked differences in the types of CBT interventions with respect to the different components and dose administered. Risk of bias was categorized as high, as few studies achieved a score greater than 7 from 12. No dose response pattern was observed. Risk of publication bias is assumed to be high given the small sample sizes of the studies. The SOE for CBT interventions for the outcome of TSQoL is rated as low quality, as the criteria for two domains were not met (Table 25).

Table 25 Strength of evidence by psychological and behavioral interventions in the treatment of tinnitus for the outcome of tinnitus-specific quality of life

Intervention Group | Specifics | # of Studies (n) | Risk of Bias | Consistency | Directness | Precision | Magnitude of the Effect SMD Range (CI) | SOE
CBT/CBT combination vs. WLC or no treatment | N/A | 10^17,18,57,84,95,96,100,102,112,120^ | High | Consistent | Direct | Imprecise | −1.56 (−1.98, −1.13) to −0.13 (−0.93, 0.67) | Low
TRT vs. WLC or no treatment | N/A | 2^97,120^ | High | Inconsistent | Direct | Imprecise | −0.60 (0−0.93, −0.26) to −0.12 (−0.46, 0.23) | Insufficient
Relaxation vs. WLC | N/A | 3^10,17,62^ | High | Inconsistent | Direct | Imprecise | −1.02 (−2.20, 0.17) to 0.17 (−1.02, 1.36) | Insufficient
Other psych/behavioral | MC-E vs. WLC | 1^17^ | High | Unknown | Direct | Imprecise | −0.38 (−1.05, 0.28) | Insufficient
Other psych/behavioral | BLT vs. WLC | 1^104^ | High | Unknown | Direct | Imprecise | −0.33 (−0.68, 0.02) | Insufficient
Other psych/behavioral | Qigong training vs. WLC | 1^87^ | High | Unknown | Direct | Imprecise | −0.14 (−0.82, 0.54) | Insufficient
Other psych/behavioral | Yoga vs. WLC | 1^102^ | High | Unknown | Direct | Imprecise | −0.17 (−0.96, 0.63) | Insufficient

Abbreviations: ACT = acceptance and commitment therapy; BLT = bibliotherapy; BPT = brief phone therapy; CBT = cognitive behavioral training; CI = confidence interval; MC-E = minimal contact education; n = sample size; psych = psychological; SMD = standard mean difference; SOE = strength of evidence; vs. = versus; TRT = Tinnitus Retraining Therapy; WLC = wait list control

There is insufficient evidence (two studies, 182 participants) that TRT related interventions improve TSQoL when compared with inactive controls for patients with idiopathic tinnitus in the immediate or short term followup. Both TRT therapy studies favored treatment, but only one was statistically significant; in this study, the sample size exceeded 30 subjects per group. The confidence intervals overlapped to a large degree, but the magnitude of the effect varied from small to medium. Given the difference in effect sizes these few studies were considered inconsistent. One study had a small sample size120 and given the lack of power calculations, these studies were considered imprecise. No dose response pattern was observed. Risk of publication bias was rated as high for both studies. The SOE for TRT interventions for the outcome of TSQoL is rated as insufficient as the criteria for three or more domains were not met.

There is insufficient evidence (three studies, 104 participants) that relaxation therapy interventions improve TSQoL when compared with inactive controls for patients with idiopathic tinnitus in the immediate or short term followup. The studies were at high risk of bias and showed wide confidence intervals suggesting imprecision (none of the studies had greater than 30 subjects per group). All but one study favored relaxation therapy relative to inactive control, but only one study was statistically significant. The effect size magnitude varied from small to large and as such, these studies were rated as inconsistent. No dose response pattern was observed. Risk of publication bias is high given the small sample sizes of the studies. The SOE for relaxation therapy for the outcome of TSQoL is rated as insufficient, as the criteria for three domains were not met.

When considering the interventions grouped in the ‘other’ category (six studies, 398 participants, six different interventions), the evidence was deemed insufficient given the heterogeneity of the interventions, the high risk of bias, and small sample sizes. Risk of publication bias is high for these interventions given the small sample sizes within the single studies for each intervention type.

Overall, it seems that there is low quality evidence that CBT interventions have a beneficial effect on TSQoL relative to inactive controls as the criteria for two domains were not met. The other interventions are rated as insufficient SOE as the criteria for at least three domains were not met (Table 26).

Table 26 Strength of evidence by psychological and behavioral interventions in the treatment of tinnitus for the outcome of subjective loudness

Intervention Group | Specifics | # of Studies (n) | Risk of Bias | Consistency | Directness | Precision | Magnitude of the Effect SMD Range (CI) | SOE
CBT/CBT combination vs. WLC or no treatment | N/A | 7^17,18,57,95,100,102,112^ | High | Consistent | Direct | Imprecise | −0.72 (−1.10, −0.33) to 0.01 (−0.61, 0.63) | Low
Relaxation vs. WLC | N/A | 3^10,17,62^ | High | Inconsistent | Direct | Imprecise | −1.16 (−2.65, 0.34) to 0.21 (−0.45, 0.87) | Insufficient
Other psychological | MC-E vs. WLC | 1^17^ | High | Unknown | Direct | Imprecise | 0.21 (−0.45, 0.87) | Insufficient
Other psychological | Education vs. WLC | 1^95^ | High | Unknown | Direct | Imprecise | −0.27 (−0.89, 0.35) | Insufficient
Other psychological | Yoga vs. WLC | 1^102^ | High | Unknown | Direct | Imprecise | −0.06 (−0.86, 0.73) | Insufficient

Abbreviations: ACT = acceptance and commitment therapy; BLT = bibliotherapy; BPT = brief phone therapy; CBT = cognitive behavioral training; CI = confidence interval; MC-E = minimal contact education; n = sample size; psych/behav = psychological/behavioral; SMD = standard mean difference; SOE = strength of evidence; vs. = versus; TRT = Tinnitus Retraining Therapy; WLC = wait list control

##### Subjective Loudness

Eight RCT studies with WLCs investigated the effects of 16 interventions on the subjective loudness of tinnitus.10,17,18,62,95,100,102,112 See Table 23.

In all studies, subjective loudness was measured on a single item presented using a variety of self-report measures that were administered over a number of days during pre- and post-treatment monitoring periods. These measures included a daily diary entry for 1 week using a 10-point VAS to rate loudness,18,100,112 a loudness rating item with a 4-point scale on a monitoring form that was completed daily for a 1-week period95 or a 2-week period,62 a daily diary entry (scale unspecified) completed over a two-week period,17 a VAS ‘direct’ form (10-cm line with end-points labeled ‘none’ and ‘maximum’) that was completed four times each day with an loudness rating item pertaining to the immediate moment and a second retrospective form completed in the evening with a loudness rating item pertaining to the participant’s experience over the course of the day (with end points labeled ‘absent/very weak’ and ‘very loud/maximal’),10 and a VAS 10-point scale with a loudness rating item that was completed three times per day over a 2-week monitoring period.102

The effect on loudness was evaluated for seven interventions in the CBT category. A significant beneficial effect of biofeedback-based CBT18 was reported (group × time interaction: F(1,109) = 10.83, p <0.001) and a significant effect of treatment on subjective loudness was reported for an intervention using a self-help book with telephone therapy (group × time interaction: F(1,69) = 6.7, p=0.012). No significant effects of treatment on subjective loudness were reported for the other interventions in this category, including internet CBT,57 psychophysiological therapy,112 a CBT plus education intervention,95 a CBT plus TCT intervention,17 and a TCT intervention delivered by two different clinicians.102

The effect on loudness was evaluated for six interventions involving relaxation that were investigated in three studies with sample sizes of less than 20 per group.10,17,62 A significant effect on subjective loudness on both direct (group × time interaction: F(1,21) = 7.03, p <0.01) and retrospective measures (group × time interaction: F(1,21) = 5.35, p <0.05) was reported for a 10-week treatment consisting training in relaxation, self-control by distraction, and how to apply these methods in everyday situations.10 No significant effect of treatment on subjective loudness was reported for the other treatments in this category, including a minimal contact relaxation intervention,17 and relaxation delivered with either neutral or counter-demand instructions to two different groups.62

The effect of loudness on three other psychological behavioral interventions was examined.17,95,112 No significant effects of treatment were reported for education interventions17,95 or for yoga.102

The forest plot (Figure 16) for subjective loudness as an outcome of treatment indicates that biofeedback-based CBT18 and intervention using a self-help book with telephone therapy100 show beneficial effects of treatment. However, the other interventions, all of which were evaluated in treatment groups with a sample size below 30, did not significantly reduce subjective loudness.

Figure 16 Studies with inactive comparators that evaluate psychological and behavioral interventions and report subjective loudness outcomes

Note: A decrease in score indicates improvement.

** Represent studies with multiple intervention arms

This figure shows the effect size (standardized mean difference ‘SMD’) with 95% confidence interval for each study in a forest plot for psychological and behavioral interventions for the outcome of subjective loudness. Fifteen studies show a SMD with 95% confidence interval that crosses 0 (no difference) between groups, while two studies show a SMD with 95% confidence interval less than 0 (Favors treatment group as compared to control group).

###### Strength of Evidence—Subjective Loudness

There is low quality evidence (seven studies, 462 participants) that CBT interventions had no effect on subjective loudness when compared with inactive controls for patients with idiopathic tinnitus in the immediate or short term followup. For these CBT interventions, only two studies had a sample size greater than 30 subjects per group. Since the majority of studies had small sample sizes and lack of power calculations, these studies were judged to be relatively imprecise. The direction of effect was judged to be consistent as the point estimates in five studies were on the line of no effect. Two studies favored CBT intervention and were statistically significant.18,100 With the exception of these two studies, which had large effect sizes, the magnitude of effect was small. Overall these seven studies were judged relatively consistent (overlap of confidence intervals) for subjective loudness. The studies were categorized as high risk of bias with few studies achieving a score greater than 7 from 12. No dose response pattern was observed. Risk of publication bias is high given the small sample sizes of the studies. The SOE for CBT interventions for the outcome of loudness is rated as low SOE as the criteria for two of the domains were not met (Table 26).

There is insufficient evidence (three studies, 104 participants) that relaxation therapy interventions improve subjective loudness when compared with inactive controls for patients with idiopathic tinnitus in the immediate or short term followup. All of the studies were at high risk of bias. The sample sizes were less than 30 per group, and the effect size estimates showed wider confidence intervals suggesting imprecision. All but one study favored relaxation therapy relative to inactive control and one study favored control; none of the studies showed statistically significant differences between groups. The effect size magnitude varied from small to large, as such, this evidence was rated as inconsistent. No dose response pattern was observed. Risk of publication bias is high given the small sample sizes of the studies. The SOE for relaxation therapy for the outcome of loudness is rated as insufficient as the criteria for three domains were not met.

When considering the interventions grouped in the “other category”, the evidence was deemed insufficient given the diversity of interventions, the high risk of bias, and the small sample sizes. Risk of publication bias is high for these interventions given the small sample sizes of the study and the single studies for each intervention type.

Overall, it seems that there is low quality evidence that CBT interventions have no effect on subjective loudness relative to inactive controls as the criteria for two domains were not met. The other interventions are rated as insufficient SOE as the criteria for at least three domains were not met (Table 26).

##### Sleep Disturbance

Five RCT studies with WLCs investigated the effects of interventions on sleep as a secondary outcome measure.18,57,100,102,120 See Table 23 and Appendix E, Table E4.

In one study,18 the effect of a biofeedback-based CBT on sleep was measured using a diary VAS measure as well as the sleep subscale of the TQ; there were 52 participants in the intervention group and 52 participants in the WLC group who later underwent treatment and completed post-treatment evaluation. Significant improvements due to biofeedback-based CBT were reported (time × group interaction F(1,109) = 9.93, p=0.01 on the VAS diary measure and F(1,109) = 13.78, p=0.001 on the TQ subscale). Another study of CBT delivered by internet57 reported no significant effect of intervention on sleep.

A third study in the CBT sub-category102 which had a very small sample size (less than 10 per group), the sleep subscale of the TQ was used to evaluate the effectiveness of two treatments compared to a WLC: cognitive behavioral tinnitus coping training (TCT) administered by two clinicians and yoga. There was no significant effect of these treatments on sleep.

In two other studies with small sample sizes (30 or less per group), one investigating TRT and ACT120 and the other100 investigating a self-help book and telephone therapy, the effects of the interventions on sleep were evaluated using the ISI. The studies reported a significant beneficial effect of the self-help book and telephone therapy100 on sleep (time × group interaction F(1,69) = 11.2, p <0.001), as well as a significant beneficial effect of ACT120 on sleep (time × group interaction F(1,41) = 5.67, p=0.022), but no significant effect of TRT.

The findings reported in these studies are in general agreement with moderate heterogeneity among outcomes shown in the forest plot (Figure 17). A significant beneficial effect on the VAS measure in favor of treatment for the biofeedback-based CBT18 and a significant beneficial effect on the ISI of the self-help book with telephone therapy100 can be seen in the forest plot, as well as a mean effect in favor of treatment for ACT.120 No benefit from internet CBT,57 TCT,102 TRT,120 or yoga102 is evident in the forest plots; however, the sample sizes are smaller and the confidence intervals are larger for these treatments than for the biofeedback-based CBT treatment where benefit from treatment is most apparent.

Figure 17 Studies with inactive comparators that evaluate psychological and behavioral interventions and report sleep disturbance outcomes

Note: A decrease in score indicates improvement.

** Represent studies with multiple intervention arms.

This figure shows the effect size (standardized mean difference ‘SMD’) with 95% confidence interval for each study in a forest plot for psychological and behavioral interventions for the outcome of sleep disturbances. Six studies show a SMD with 95% confidence interval that crosses 0 (no difference) between groups, while two studies show a SMD with 95% confidence interval less than 0 (Favors treatment group as compared to control group).

###### Strength of Evidence—Sleep Disturbance

There is low quality evidence (five studies, 362 participants) that CBT interventions have no effect on sleep disturbance when compared with inactive controls for patients with idiopathic tinnitus in the immediate or short term followup. Only two of these studies have sample sizes greater than 30 subjects per group and both showed statistically significant differences between groups and had relatively smaller confidence intervals. The remaining studies had large confidence intervals and very small sample sizes. Overall, these studies were judged to be imprecise. The direction of effect is generally consistent in that all except one study favor treatment; one study arm favors control but is not statistically significant. The CIs have significant overlap and the magnitude of the effect size are small to moderate (−0.20 and −0.70) suggesting large variation in effect size but the direction of effect is consistent in showing benefit; for this reason the studies were judge to be consistent. The studies were categorized as medium risk of bias and only one study57 achieved a score greater than 7 from 12. No dose response pattern was observed. Risk of publication bias is high given the small sample sizes of the studies. The SOE for CBT interventions for the outcome of sleep disturbance is rated as low quality as the criteria for two of the domains were not met (Table 27).

Table 27 Strength of evidence by psychological and behavioral interventions in the treatment of tinnitus for the outcome of sleep disturbance

Intervention Group | Specifics | # of Studies (n) | Risk of Bias | Consistency | Directness | Precision | Magnitude of the Effect SMD Range (CI) | SOE
CBT/CBT combination vs. WLC or no treatment | N/A | 5^18,57,100,102,120^ | High | Consistent | Direct | Imprecise | −0.70 (−1.08, −0.31) to 0.61 (−0.23, 1.46) | Low
TRT vs. WLC or no treatment | N/A | 1^120^ | High | Unknown | Direct | Imprecise | 0.12 (−0.49, 0.72) | Insufficient
Other psych/behavioral | Yoga vs. WLC | 1^102^ | High | unknown | Direct | Imprecise | 0.10 (−0.70, 0.89) | Insufficient

Abbreviations: CBT = cognitive behavioral training; CI = confidence interval; n = sample size; psych = psychological; SMD = standard mean difference; SOE = strength of evidence; vs. = versus; TRT = Tinnitus Retraining Therapy; WLC = wait list control

There is insufficient evidence that TRT interventions (one study, 44 participants) or yoga (one study, 28 participants) improve sleep disturbance when compared with inactive controls for patients with idiopathic tinnitus in the immediate or short term followup. For either intervention, the studies show a point estimate favoring control but this was not statistically significant. The study sample sizes are small and both studies were judged as imprecise. These single studies are at high risk of bias and consistency is unknown. No dose response pattern can be assessed and risk of publication bias is high given the small sample sizes. The SOE for TRT and yoga for the outcome sleep disturbance is rated as insufficient, as the criteria for three domains were not met.

##### Anxiety

Five RCT studies57,62,84,100,120 evaluated anxiety symptoms as one of the main outcomes57,62,84 or as a secondary outcome100,120 that was compared to a WLC group (Table 23). The group mean pre-treatment scores on the STAI suggest that the participants had mild levels of anxiety62 and results on the HADS-A57,84,100,120 suggest that anxiety symptoms were minimal. Indeed, the HADS-A score was used in one study100 as an eligibility criterion to rule out anxiety as a major problem. Two studies57,84 used the ASI as a second measure of anxiety.

No significant improvement due to group CBT was found using either the HADS-A or ASI in a study with a very small sample size.84 However, in another study,57 significant effects of CBT delivered by internet to a larger sample size were reported when the change scores for the treatment and wait list groups were compared on both the HADS-A and ASI measures (t(70) = 3.05, p = 0.004 on HADS-A and t(70) = 2.48, p = 0.015 on ASI). In another study,100 a significant reduction in anxiety on the HADS-A was reported when the treatment was a self-help book with telephone therapy (time × group interaction: F(1,70) = 10.1, p = 0.002). Significant improvement on the HADS-A immediately post-treatment was reported in one study for ACT (time × group interaction: F(1,41) = 4.40, p = 0.042; Cohen’s d effect size = 0.80, 95% CI (0.14–1.42)), but there was no significant effect of TRT on anxiety.120 When relaxation therapy was provided with either neutral or counter-demand instructions, no significant effect of treatment on anxiety was found using the STAI.62

As shown in the forest plot (Figure 18), a clear beneficial effect on anxiety was found for the self-help book and telephone therapy,100 although this study is considered to have a high risk of bias. There also seems to be a moderate beneficial effect of ACT on anxiety,120 but this study also has a high risk of bias. CBT delivered over the internet57 and CBT delivered to a small group84 have mean beneficial effects on anxiety, but these effects are not significant and the studies have moderate risk of bias. Relaxation62 and TRT120 seem to have little or no beneficial effect on anxiety.

Figure 18 Studies with inactive comparators that evaluate psychological and behavioral interventions and report anxiety symptoms outcomes

Note: A decrease in score indicates improvement improvement.

** Represent studies with multiple intervention arms.

This figure shows the effect size (standardized mean difference ‘SMD’) with 95% confidence interval for each study in a forest plot for psychological and behavioral interventions for the outcome of anxiety symptoms. Eight studies show a SMD with 95% confidence interval that crosses 0 (no difference) between groups, while only one study shows a SMD with 95% confidence interval less than 0 (Favors treatment group as compared to control group).

###### Strength of Evidence–Anxiety Symptoms

Overall, there is low quality evidence (four studies, 211 participants) that CBT interventions have an effect on anxiety symptoms when compared with inactive controls for patients with idiopathic tinnitus in the immediate or short term followup. Given that these studies were of small sample size, with wide confidence intervals, they were judged as imprecise. All studies showed that the point estimates favored treatment, but only one study100 was statistically significant; this was the only study with a sample size of greater than 30 subjects per group. The magnitude of the effect size is moderate in all studies and the confidence intervals overlapped substantively; as such, these studies were rated as having a consistent effect. No dose response pattern was observed. Risk of publication bias is high given the small sample sizes of the studies. The SOE for CBT interventions for the outcome of anxiety symptoms is rated as low because the criteria for two domains were not met (Table 28).

Table 28 Strength of evidence by psychological and behavioral interventions in the treatment of tinnitus for the outcome of anxiety symptoms

Intervention Group | Specifics | # of Studies (n) | Risk of Bias | Consistency | Directness | Precision | Magnitude of the Effect SMD Range (CI) | SOE
CBT/CBT combination vs. WLC or no treatment | N/A | 4^57,84,100,120^ | High | Consistent | Direct | Imprecise | −0.61 (−1.08, −0.14) to −0.27 (−0.76, 0.22) | Low
TRT vs. WLC or no treatment | N/A | 1^120^ | High | Unknown | Direct | Imprecise | −0.19 (−0.80, 0.41) | Insufficient
Relaxation vs. WLC | N/A | 1^62^ | High | Unknown | Direct | Imprecise | −0.08 (−1.26, 1.11) to 0.46 (−0.65, 1.57) | Insufficient

Abbreviations: CBT = cognitive behavioral training; CI = confidence interval; n = sample size; psych = psychological; SMD = standard mean difference; SOE = strength of evidence; vs. = versus; TRT = Tinnitus Retraining Therapy; WLC = wait list control

There is insufficient evidence that TRT interventions (one study, 42 participants) or relaxation therapy (one study, 44 participants) improve anxiety symptoms when compared with inactive controls for patients with idiopathic tinnitus in the immediate or short term followup. For these single studies the consistency for each intervention is unknown. The studies have wide confidence intervals and very small sample sizes (less than 30 per group) and are the effect estimate is judged as imprecise. Dose response cannot be assessed and risk of publication bias is high for these interventions given the small sample sizes. The SOE for TRT and Relaxation therapy interventions for affecting anxiety symptoms is rated as insufficient because the criteria for three domains were not met (Table 28).

##### Depression Symptoms

Eleven RCT studies10,17,18,57,62,84,95,96,100,102,120 investigated the effects of treatments on depression symptoms by comparing treatments to WLCs (Table 23). The BDI was used to measure depression symptoms in four studies,18,62,95,96 the HADS-D was used in four studies,57,84,100,120 the ADS was used in one study,17 a retrospective measure was used in one study10 and the Depressivitäts Skala was used in one study.102 As well, the ATQ was used as a second measure of depression symptoms in one study.96 Note that depression was used as a primary outcome measure in some studies,57,62 but in most studies10,17,18,84,95,96,100,102,120 it was considered to be only a secondary or general outcome measure not specifically related to tinnitus. Also note that the eligibility criteria for some studies selected for participants who did not have major problems with depression100 and the mean pre-treatment scores on standardized measures of depression indicated no more than mild depression.

Nine studies tested treatments in the CBT sub-category,17,18,57,84,95,96,100,102,120 four using the HADS-D,57,84,100,120 three using the BDI,18,95,96 one using the ADS17 and one using the Depressivitäts Skala to evaluate the same treatment administered by two different clinicians.102 Some beneficial effects of treatment were reported in five studies18,57,96,100,102 and no significant effects were reported in the other four.17,84,95,120

The four CBT interventions that evaluated depression using the HADS-D included one CBT intervention with six weekly group sessions for adults 65 years of age and older that was compared to a WLC group who later received a shorter version of the treatment,84 and an internet-based CBT intervention with six self-help modules that was compared to a WLC.57 For the treatment provided to older adults,84 there was no effect on depression measured, whereas for the internet intervention,57 there was significantly greater improvement for the treatment group compared to the control group for pre-post (t(70)=3.14, p =0.002) and for pre-followup at 1 year (F(1,94)=5.4, p=0.02). One study100 used the HADS-D to investigate the effect on depression symptoms of a treatment involving a self-help book and telephone therapy and a significant beneficial effect was found (time × group interaction; F(1,70)=5.3, p=0.024). Finally, one study used the HADS-D to evaluate the effect of ACT and found no significant benefit of treatment.120

The effects on depression as measured with the BDI were studied in three studies in the CBT sub-category:18,95,96 one CBT intervention consisted of eight weekly sessions involving attention control and imagery and cognitive restructuring (ACI + CR) compared to an ACI-only treatment, a CR-only treatment and a WLC,96 another CBT intervention was a 12-session biofeedback-based CBT delivered over 3 months compared to a WLC,18 and a third CBT intervention was an 6-week intervention involving cognitive coping skills training (attention diversion, imagery training and thought management) that was compared to an education only treatment and a WLC.95 In the study comparing ACI and CR treatments alone and in combination, it was reported that those who received treatment improved more than the WLC group (F(1,46)=7.28, p <0.01);96 as seen in the forest plot, the benefits of treatment reached significance for the CR plus ACI treatment and the CR alone treatment, but not for the ACI treatment alone. Biofeedback-based CBT resulted in medium pre-post, but only small pre-followup effect sizes and the small improvements in BDI compared to the WLC did not reach significance in the intention-to-treat analysis.18 There was no significant effect on depression of the cognitive coping skills or education treatments on depression symptoms.95

The ADS, a German version of the CES-D designed to evaluate the effect on depression symptoms of an 11-session CBT Tinnitus Coping Training (TCT) group intervention was compared to a WLC as well as two minimal contact (MC) interventions, one entailing two group sessions focused on education about tinnitus (MC-E) and the other group sessions focused on education and music-supported relaxation.17 There was no effect of treatment on depression and the absence of an effect was attributed to the low levels of depression found at baseline.

The Depressivitäts Skala was used to evaluate the effect on depression when TCT was delivered by two different clinicians compared to a WLC and to yoga.102 Although one of the TCT groups showed a significant reduction in depression, there was no significant effect on depression reported for the second TCT group or for the yoga group.

The effect of TRT on depression symptoms was evaluated in one study,120 and no significant effects were found.

Three interventions focused on relaxation were evaluated: one treatment was the music-supported relaxation intervention that was compared to CBT,17 one involved relaxation with neutral or counter-demand instructions with each version of the treatment delivered to two groups or stages,62 and the third was a treatment emphasizing coping through the use of relaxation and distraction techniques.10 There was no significant effect of the music-supported relaxation as measured with the ADS.17 For the relaxation intervention with different instructions, the only significant effect reported was pre- to post-treatment improvement on BDI (overall pre-treatment mean 12.2 to overall post-treatment mean 8.3), but each group has less than ten participants and this small difference was observed for both the treatment and WLC groups. For the study using relaxation and distraction to enable coping,10 depression symptoms were measured using a VAS whereby participants marked a 10cm line (from ‘none’ to ‘maximal’) at the end of the day for periods of 4 weeks pre- and post-treatment. A statistically significant difference between pre- and post-treatment was reported (t(20)=2.90, p <0.01) as well as a small difference between the treatment and control groups that favored the treatment group (F(1,21)=4.76, p <0.05).

Three studies17,95,102 investigated the effects of other treatments on depression symptoms. The study already mentioned that investigated the effects of TCT using the ADS also evaluated the effects of education (ME-E) on depression symptoms, with no significant benefit reported.17 The study already mentioned that used the BDI to investigate the effects on depression symptoms of CBT with education also evaluated the effects of education alone and found no significant benefit.95 As mentioned above, no significant effect of yoga on depression symptoms was reported.102 The forest plots (see Figure 19) are consistent with the findings reported in the studies regarding the effect of the treatments on depression symptoms. Overall, less than half of the treatments yielded a significant effect in favor of the treatment in comparison to a WLC.

Figure 19 Studies with inactive comparators that evaluate psychological and behavioral interventions and report depression symptoms outcomes

Note: A decrease in score indicates improvement.

** Represent studies with multiple intervention arms

This figure shows the effect size (standardized mean difference ‘SMD’) with 95% confidence interval for each study in a forest plot for psychological and behavioral interventions for the outcome of depression symptoms. Seventeen studies show a SMD with 95% confidence interval that crosses 0 (no difference) between groups, while five studies show a SMD with 95% confidence interval less than 0 (Favors treatment group as compared to control group).

###### Strength of Evidence—Depression Symptoms

There is low quality evidence (ten studies, 550 participants) that CBT interventions had no effect on depression symptoms when compared with inactive controls for patients with idiopathic tinnitus in the immediate or short term followup. Only two studies had a sample size greater than 30 subjects per group. As such, the majority of studies had small sample sizes and lack of power calculations, and were judged to be imprecise. The direction of effect was consistent across studies showing that the findings favored the CBT treatment in all studies; however, only two studies96,100 showed statistically significant differences. The confidence intervals had substantive overlap and the magnitude of the effect size varied. With respect to risk of bias, the studies were categorized as high risk of bias with few studies achieving a score greater than 7 from 12. No dose response pattern was observed. Risk of publication bias is high given the small sample sizes of the studies. The SOE for CBT interventions for the outcome of depression symptoms is rated as low quality evidence as the criteria for two domains were not met (Table 29).

Table 29 Strength of evidence by psychological and behavioral interventions in the treatment of tinnitus for the outcome of depression symptoms

Intervention Group | Specifics | # of Studies (n) | Risk of Bias | Consistency | Directness | Precision | Magnitude of the Effect SMD Range (CI) | SOE
CBT/CBT combination vs. WLC or no treatment | N/A | 9^17,18,57,84,95,96,100,102,120^ | High | Consistent | Direct | Imprecise | −1.05 (−1.92, −0.19) to −0.04 (−0.57, 0.49) | Low
TRT vs. WLC or no treatment | N/A | 1^120^ | High | Unknown | Direct | Imprecise | 0.05 (−0.55, 0.66) | Insufficient
Relaxation vs. WLC | N/A | 3^10,17,62^ | High | Inconsistent | Direct | Imprecise | −1.85 (−3.59, −0.11) to −0.06 (−1.24, 1.13) | Insufficient
Relaxation vs. WLC | MC-E vs. WLC | 1^17^ | High | Unknown | Direct | Imprecise | −0.31 (−0.97, 0.35) | Insufficient
Relaxation vs. WLC | Education vs. WLC | 1^95^ | High | Unknown | Direct | Imprecise | 0.08 (−0.54, 0.70) | Insufficient
Relaxation vs. WLC | Yoga vs. WLC | 1^102^ | High | Unknown | Direct | Imprecise | −0.32 (−1.12, 0.48) | Insufficient

Abbreviations: CBT = cognitive behavioral training; CI = confidence interval; MC-E = minimal contact education; n = sample size; psych = psychological; SMD = standard mean difference; SOE = strength of evidence; vs. = versus; TRT = Tinnitus Retraining Therapy; WLC = wait list control

There is insufficient evidence that TRT interventions (one study, 42 participants) improve depression symptoms when compared with inactive controls for patients with idiopathic tinnitus in the immediate or short term followup. This single study is at high risk of bias and the consistency is unknown. The study had a small sample size (less than 30 per group) and was considered imprecise. Dose response cannot be assessed and risk of publication bias is high for these interventions given the small sample sizes. The SOE for TRT interventions for affecting depression symptoms is rated as insufficient because the criteria for three domains were not met (Table 28).

There is insufficient evidence that relaxation therapies (three studies, 104 participants) improve depression symptoms when compared with inactive controls for patients with idiopathic tinnitus in the immediate or short term followup. All three studies favored treatment but none were statistically significant. The confidence intervals overlapped to a large degree but the magnitude of the effect varied from small to large; as such these studies were judged to be inconsistent. The confidence intervals were widely varying and the sample sizes were very small in these studies, earning a rating of imprecise. All the studies were at high risk of bias. No dose response pattern was observed. Risk of publication bias is high given the small sample sizes of the studies. The SOE for relaxation interventions for the outcome of depression symptoms is rated as insufficient as the criteria for three domains were not met.

There is insufficient evidence that MC education (one study, 36 participants), education (one study, 40 participants), or yoga (one study, 28 participants) improves depression symptoms when compared with inactive controls for patients with idiopathic tinnitus in the immediate or short term followup. When considering the three interventions grouped in the “other category”, the evidence was deemed insufficient given the high risk of bias for the studies, unknown consistency, and small sample sizes of less than 30 per group (imprecision). Risk of publication bias is high for these interventions given the small sample sizes and the single studies within this group. The SOE for MC education, education and yoga interventions for the outcome of depression symptoms is rated as insufficient as the criteria for three domains were not met.

##### Global Quality of Life

Six RCT studies17,18,102,104,112,120 investigated the effects of treatments on non-tinnitus-specific global QoL by comparing treatments to WLCs (Tables 23 and 30, Appendix E, Table E4). A number of different measurement tools were employed across the studies, with some measures being more focused on psychological distress and psychopathology, whereas other measures tapped health-related well-being more broadly. The SCL-90-R was used in two studies to measure ‘general psychopathology’17,18 and it was listed as a secondary outcome measure in one of those studies;18 the GHQ-12 was used in one study104 to measure general psychological distress; the German Beschwerden-Liste was used to measure various symptoms of well-being in one study;102 the QoLI was used in one study120 as a secondary outcome measure of quality of life based on responses in six domains; the HRLS was used in one study112 as a secondary measure to assess the importance of and satisfaction with eight health-related issues, with a composite index for health-related life satisfaction.

The effect on global QoL was evaluated for six interventions in the CBT category (Figure 20). A significant effect favoring CBT was found for an intervention using biofeedback-based CBT18 which was evaluated with the SCL-90-R (group × time interaction: F(1,109)=7.61, p <0.01). No significant effect of treatment was reported for CBT using a psychophysiological approach evaluated with the HRLS.112 CBT with TCT and TCT were evaluated in two studies, one using the SCL-90-R17 and the other using the Beschwerden-Liste;102 no significant immediate post-treatment effects between the WLC and the treatment groups were reported in either study. ACT120 was evaluated with the QoLI and no benefit was found,

Figure 20 Studies with inactive comparators that evaluate psychological and behavioral interventions and report global quality of life outcomes

Note: A decrease in score indicates improvement.

** Represent studies with multiple intervention arms

This figure shows the effect size (standardized mean difference ‘SMD’) with 95% confidence interval for each study in a forest plot for psychological and behavioral interventions for the outcome of global quality of life. Eight studies show a SMD with 95% confidence interval that crosses 0 (no difference) between groups, while three studies show a SMD with 95% confidence interval greater than 0 (Favors treatment group as compared to control group).

The effect on global quality of life by TRT was evaluated in one study120 using the QoLI, but no significant effect of treatment was reported.

The effect on global QoL by a relaxation intervention with minimal contact was evaluated in one study17 using the SCL-90-R, but no significant effect of treatment was reported.

The effect on global QoL was evaluated for three other psychological behavioral treatments: bibliotherapy with the GHQ-12,^104^ education with minimal contact with the SCL-90-R,17 and yoga with the Beshwerden-Liste.102 No significant effects of treatment on global QoL were reported for education,17 or yoga.102 However, a significant reduction in general stress measured with the GHQ-12 with a small effect size was reported for bibliotherapy.104

As seen in the forest plot (Figure 20), the two most promising interventions are biofeedback-based CBT and bibliotherapy; however, these were the only two studies with sample sizes greater than 50.^18,104^

###### Strength of Evidence—Global QoL

There is low quality evidence (six studies, 313 participants) that CBT interventions had no effect on global QoL when compared with inactive controls for patients with idiopathic tinnitus in the immediate or short term followup. All studies were at high risk of bias. Only one study had a size greater than 30 subjects per group.18 The majority of studies had small sample sizes and lack of power calculations; these studies were judged to be relatively imprecise for this reason. The direction of effect across studies showed that the findings favored the treatment group (point estimate) except for one study (Figure 20). The confidence intervals had significant overlap and the magnitude of the effect size varied from small to moderate; we rated these studies as consistent. No dose response pattern was observed. Risk of publication bias is high given the small sample sizes of the studies. The SOE for CBT interventions for the outcome of global QoL is rated as low quality evidence, as two the criteria for two domains were not met (Table 30).

Table 30 Strength of evidence by psychological and behavioral interventions in the treatment of tinnitus for the outcome of global quality of life

Intervention Group | Specifics | # of Studies (n) | Risk of Bias | Consistency | Directness | Precision | Magnitude of the Effect SMD Range (CI) | SOE
CBT/CBT combination vs. WLC or no treatment | N/A | 5^17,18,102,112,120^ | High | Consistent | Direct | Imprecise | 0.64 (0.02, 1.26) to −0.06 (−0.59, 0.47) | Low
TRT vs. WLC or no treatment | N/A | 1^120^ | High | Unknown | Direct | Imprecise | 0.06 (−0.55, 0.66) | Insufficient
Other | BLT vs. WLC | 1^104^ | High | Unknown | Direct | Precise | 0.45 (0.1, 0.81) | Low
Other | MC-E vs. WLC | 1^17^ | High | Unknown | Direct | Imprecise | 0.32 (−0.35, 0.98) | Insufficient
Other | Yoga vs. WLC | 1^102^ | High | Unknown | Direct | Imprecise | 0.26 (−0.54, 1.05) | Insufficient

Abbreviations: ACT = acceptance and commitment therapy; BLT = bibliotherapy; BPT = brief phone therapy; CBT = cognitive behavioral training; CI = confidence interval; MC-E = minimal contact education; n = sample size; psych/behav = psychological/behavioral; SMD = standard mean difference; SOE = strength of evidence; vs. = versus; TRT = Tinnitus Retraining Therapy; WLC = wait list control

There is insufficient evidence for TRT interventions (one study, 42 participants), relaxation therapy (one study, 36 participants), and “other category” interventions (bibliotherapy (one study, 127 participants), MC education (one study, 36 participants), yoga (one study, 28 participants)) to assess if global QoL is improved relative to inactive control immediately post treatment or in the short term. All studies were at high risk of bias, had unknown consistency, small sample sizes, and wide confidence intervals, except for one study (127 participants)104 on bibliotherapy in which the SOE was considered low as it was judged to be precise. Risk of publication bias is high for these studies given the small sample sizes of the study and the single studies within each intervention group (Table 30).

## KQ3 For adults with subjective idiopathic tinnitus, what prognostic factors, patient characteristics, and/or symptom characteristics affect final treatment outcomes?

No data addressing this question were identified in the literature search.