# References

1 2013 ICD-10-CM Diagnosis Code H93.1. 2013. www.icd10data.com/ICD10CM/Codes/H60-H95/H90-H94/H93-/H93.1. Accessed April 11, 20013.
2 American Tinnitus Association. Top 10 most frequently asked questions. www.ata.org/for-patients/faqs. Accessed April 11, 2013.
3 Davis A, El Rafaie A. Epidemiology of tinnitus. Tyler RS, editor. Epidemiology of Tinnitus. San Diego, CA. Singular Publishing Group. 2000;1:1-24.
4 Davis A, Smith P, Ferguson M, et al. Acceptability, benefit and costs of early screening for hearing disability: A study of potential screening tests and models. Health Technol Assess. 2007;11(42):iii-xii. 1. 154. [pmid: 17311734].
5 Press release: Two ATA Scientific Advisory Committee members receive Department of Defense grant. www.ata.org/about-ata/news-pubs/press-releases#DoDGrant. Accessed April 11, 2013.
6 Holgers KM, Juul J. The suffering of tinnitus in childhood and adolescence. Int J Audiol. 2006;45(5):267-72. [pmid: 16717016].
7 Savage J, Waddell A. Tinnitus. Clin Evid. 2012. Feb. 3. [pmid: 22331367].
8 Shargorodsky J, Curhan GC, Farwell WR. Prevalence and characteristics of tinnitus among US adults. Am J Med. 2010;123(8):711-8. [pmid: 20670725].
9 Zoger S, Erlandsson S, Svedlund J, et al. Benefits from group psychotherapy in the treatment of severe refractory tinnitus. Audiol Med. 2008;6(1):62-72.
10 Scott B, Lindberg P, Lyttkens L, et al. Psychological treatment of tinnitus. Scand Audiol. 1985;14(4):223-30. [pmid: 3912955].
11 Brunnberg E, Linden-Bostrom M, Berglund M. Tinnitus and hearing loss in 15–16-year-old students:Mmental health symptoms, substance use, and exposure in school. Int J Audiol. 2008;47(11):688-94. [pmid: 19031227].
12 Weber C, Arck P, Mazurek B, et al. Impact of a relaxation training on psychometric and immunologic parameters in tinnitus sufferers. J Psychosom Res. 2002;52(1):29-33. [pmid: 11801262].
13 Henry JA. 2011. Jul. 26. Key informant interview.
14 Henry JA, Zaugg TL, Myers PJ, et al. A triage guide for tinnitus. J Fam Pract. 2010;59(7):389-93. [pmid: 20625568].
15 British Tinnitus Association. Tinnitus: Guidelines for primary care. www.tinnitus.org.uk/ten-top-tinnitus-tips-for-gps. Accessed April 11, 2013.
16 Holgers K-M. Mechanisms and classification of tinnitus: A discussion paper. Audiol Med. 2003;1(4):238-41.
17 Kroner-Herwig B, Frenzel A, Fritsche G, et al. The management of chronic tinnitus: Comparison of an outpatient cognitive-behavioral group training to minimal-contact interventions. J Psychosom Res. 2003;54(4):381-9. [pmid: 12670617].
18 Weise C, Heinecke K, Rief W. Biofeedback-based behavioral treatment for chronic tinnitus: Results of a randomized controlled trial. J Consult Clin Psychol. 2008;76(6):1046-57. [pmid: 19045972].
19 Dobie RA. A review of randomized clinical trials in tinnitus. Laryngoscope. 1999;109(8):1202-11. [pmid: 10443820].
20 McCombe A, Baguley D, Coles R, et al. Guidelines for the grading of tinnitus severity: The results of a working group commissioned by the British Association of Otolaryngologists, Head and Neck Surgeons, 1999. Clin Otolaryngol Allied Sci. 2001;26(5):388-93. [pmid: 11678946].
21 Erlandsson S. Psychological profiles of tinnitus in patients. Tinnitus Handbook. Tyler RS, editor. San Diego, CA. Singular Publishing Group. 2000;2:25-58.
22 Figueiredo RR, Azevedo AA, Oliveira PM. Correlation analysis of the visual-analogue scale and the Tinnitus Handicap Inventory in tinnitus patients. Revista Brasil Otorrinolaringol. 2009;75(1):76-9. [pmid: 19488564].
23 Kamalski DM, Hoekstra CE, van Zanten BG, et al. Measuring disease-specific health-related quality of life to evaluate treatment outcomes in tinnitus patients: A systematic review. Otolaryngol Head Neck Surg. 2010;143(2):181-5. [pmid: 20647116].
24 Lipsey MW. Design sensitivity: Statistical power for experimental research. Newburry Park, CA. Sage Publications, Inc. 1990.
25 Kazdin AE. Research design in clinical psychology. 4th. Needham Heights, MA. Allyn & Bacon. 2003.
26 Meikle M, Henry JA, Griest S, et al. The Tinnitus Functional Index: Development of a new clinical measure for chronic, intrusive tinnitus. Ear Hear. 2012;33(2):153-76. [pmid: 22156949].
27 Baldo P, Doree C, Lazzarini R, et al. Antidepressants for patients with tinnitus. Cochrane Database Syst Rev. 2006;(4):CD003853. [pmid: 17054188].
28 Johnson RM, Brummett R, Schleuning A. Use of alprazolam for relief of tinnitus. A double-blind study. Arch Otolaryngol Head Neck Surg. 1993;119(8):842-5. [pmid: 8343245].
29 Jalali MM, Kousha A, Naghavi SE, et al. The effects of alprazolam on tinnitus: A cross-over randomized clinical trial. Med Sci Mon. 2009;15(11):I55-I60 P. [pmid: 19865063].
30 Kalcioglu MT, Bayindir T, Erdem T, et al. Objective evaluation of the effects of intravenous lidocaine on tinnitus. Hear Res. 2005;199(1–2):81-8. [pmid: 15574302].
31 Agarwal L, Pothier DD. Vasodilators and vasoactive substances for idiopathic sudden sensorineural hearing loss. Cochrane Database Syst Rev. 2009;(4):CD003422. [pmid: 19821308].
32 Noble W. Treatments for tinnitus. Trends Amplification. 2008;12(3):236-41. [pmid: 18635586].
33 Sziklai I, Szilvassy J, Szilvassy Z. Tinnitus control by dopamine agonist pramipexole in presbycusis patients: A randomized, placebo-controlled, double-blind study. Laryngoscope. 2011;121(4):888-93. [pmid: 21433025].
34 Hilton M, Stuart E. Ginkgo biloba for tinnitus. Cochrane Database Syst Rev. 2004;(2):CD003852. [pmid: 15106224].
35 Teggi R, Bellini C, Piccioni LO, et al. Transmeatal low-level laser therapy for chronic tinnitus with cochlear dysfunction. Audiol Neuro Otol. 2009;14(2):115-20. [pmid: 18843180].
36 Tuz HH, Onder EM, Kisnisci RS. Prevalence of otologic complaints in patients with temporomandibular disorder. Am J Orthod Dentofacial Orthop. 2003;123(6):620-3. [pmid: 12806339].
37 Wright EF, Syms CA III, Bifano SL. Tinnitus, dizziness, and nonotologic otalgia improvement through temporomandibular disorder therapy. Milit Med. 2000;165(10):733-6. [pmid: 11050868].
38 Ash CM, Pinto OF. The TMJ and the middle ear: Structural and functional correlates for aural symptoms associated with temporomandibular joint dysfunction. Int J Prosthodont. 1991;4(1):51-7. [pmid: 2012671].
39 Langguth B, Hajak G, Kleinjung T, et al. Repetitive transcranial magnetic stimulation and chronic tinnitus. Acta Otolaryngol Suppl. 2006;(556):102-5. [pmid: 17114153].
40 Henry JA, Dennis KC, Schechter MA. General review of tinnitus: Prevalence, mechanisms, effects, and management. J Speech Lang Hear Res. 2005;48(5):1204-35. [pmid: 16411806].
41 Bennett M, Kertesz T, Yeung P. Hyperbaric oxygen therapy for idiopathic sudden sensorineural hearing loss and tinnitus: A systematic review of randomized controlled trials. J Laryngol Otol. 2005;119(10):791-8. [pmid: 16259656].
42 Keate B. Diet and tinnitus: What to eat … and what not to eat. Tinnitus Library. www.tinnitusformula.com/infocenter/articles/treatments/diet.aspx. Accessed April 11, 2013.
43 New Tinnitus Treatments Blog. Tinnitus and your diet. www.tinnitustreatments.org/tinnitus-and-your-diet.html. Accessed April 11, 2013.
44 Tinnitus Remedies Web Site. Tinnitus relief through diet - Foods to avoid to relieve tinnitus. www.thetinnitussite.info/tinnitus-relief-2/tinnitus-relief-through-diet-foods-to-avoid-to-relieve-tinnitus. Accessed April 11, 2013.
45 National Center for Complementary and Alternative Medicine (NCCAM). What is Complementary and Alternative Medicine?. www.nccam.nih.gov/health/whatiscam. Accessed April 11, 2013.
46 Henry JA, Zaugg TL, Myers PJ, et al. Progressive audiologic tinnitus management. ASHA Leader. 2008;13(8):14-7. www.asha.org/Publications/leader/2008/080617/f080617b.htm.
47 Punte AK, Vermeire K, Hofkens A, et al. Cochlear implantation as a durable tinnitus treatment in single-sided deafness. Cochlear Implants International. 2011;12(Suppl 1):S26-S29 P. [pmid: 21756468].
48 Amoodi HA, Mick PT, Shipp DB, et al. The effects of unilateral cochlear implantation on the tinnitus handicap inventory and the influence on quality of life. Laryngoscope. 2011;121(7):1536-40. [pmid: 21647911].
49 Arts RA, George EL, Stokroos RJ, et al. Review: Cochlear implants as a treatment of tinnitus in single-sided deafness. Curr Opin Otolaryngol Head Neck Surg. 2012;20(5):398-403. [pmid: 22931903].
50 Hobson J, Chisholm E, El RA. Sound therapy (masking) in the management of tinnitus in adults. Cochrane Database Syst Rev. 2010;12:CD006371. [pmid: 21154366].
51 CIGNA medical coverage policy No. 0220. Tinnitus treatment services and devices. www.cigna.com/assets/docs/health-care-professionals/coverage_positions/mm_0220_coveragepositioncriteria_tinnitus_instr_devices_retraining_ther.pdf. Accessed April 11, 2013.
52 Davis PB, Wilde RA, Steed LG, et al. Treatment of tinnitus with a customized acoustic neural stimulus: A controlled clinical study. Ear Nose Throat J. 2008;87(6):330-9. [pmid: 18561116].
53 Davis PB, Paki B, Hanley PJ. Neuromonics tinnitus treatment: Third clinical trial. Ear Hear. 2007;28(2):242-59. [pmid: 17496674].
54 Langguth B, Kleinjung T, Landgrebe M. Tinnitus: The complexity of standardization. Eval Health Prof. 2011;34(4):429-33. [pmid: 21224265].
55 Martinez-Devesa P, Perera R, Theodoulou M, et al. Cognitive behavioural therapy for tinnitus. Cochrane Database Syst Rev. 2010;(9):CD005233. [pmid: 20824844].
56 Department of Health. Provision of services for adults with tinnitus: A good practice guide. London. Central Office of Information. 2009.
57 Andersson G, Stromgren T, Strom L, et al. Randomized controlled trial of internet-based cognitive behavior therapy for distress associated with tinnitus. Psychosom Med. 2002;64(5):810-6. [pmid: 12271112].
58 Hesser H, Weise C, Westin VZ, et al. A systematic review and meta-analysis of randomized controlled trials of cognitive-behavioral therapy for tinnitus distress. Clinical Psychology Review. 2011;31(4):545-53. [pmid: 21237544].
59 Phillips JS, McFerran D. Tinnitus Retraining Therapy (TRT) for tinnitus. Cochrane Database Syst Rev. 2010;(3):CD007330. [pmid: 20238353].
60 Jastreboff PJ, Hazell JW. A neurophysiological approach to tinnitus: Clinical implications. Br J Audiol. 1993;27(1):7-17. [pmid: 8339063].
61 Parazzini M, Del Bo L, Jastreboff M, et al. Open ear hearing aids in tinnitus therapy: An efficacy comparison with sound generators. Int J Audiol. 2011;50(8):548-53. [pmid: 21595527].
62 Ireland CE, Wilson PH, Tonkin JP, et al. An evaluation of relaxation training in the treatment of tinnitus. Behav Res Ther. 1985;23(4):423-30. [pmid: 3896227].
63 Henry JA, Zaugg TL, Myers PJ, et al. The role of audiologic evaluation in progressive audiologic tinnitus management. Trends Amplification. 2008;12(3):170-87. [pmid: 18628281].
64 Cima RF, Maes IH, Joore MA, et al. Specialised treatment based on cognitive behaviour therapy versus usual care for tinnitus: A randomised controlled trial. Lancet. 2012;379(9830):1951-9. [pmid: 22633033].
65 Humphrey C, Herbst KG, Faurqi S. Some characteristics of the hearing-impaired elderly who do not present themselves for rehabilitation. Br J Audiol. 1981;15(1):25-30. [pmid: 7214067].
66 Searchfield G. A commentary on the complexity of tinnitus management: Clinical guidelines provide a path through the fog. Eval Health Prof. 2011;34(4):421-8. [pmid: 21224266].
67 Hoare DJ, Gander PE, Collins L, et al. Management of tinnitus in English NHS audiology departments: An evaluation of current practice. J Eval Clin Pract. 2010;18(2):326-34. [pmid: 21087449].
68 Henry JA, Schechter MA, Loovis CL, et al. Clinical management of tinnitus using a “progressive intervention” approach. J Rehabil Res Dev. 2005;42(4:Suppl 2):95-116. [pmid: 16470467].
69 Juni P, Holenstein F, Sterne J, et al. Direction and impact of language bias in meta-analyses of controlled trials: Empirical study. Int J Epidemiol. 2002;31(1):115-23. [pmid: 11914306].
70 Moher D, Pham B, Klassen T, et al. What contributions do languages other than English make on the results of meta-analysis?. J Clin Epidemiol. 2000;53(9):964-72. [pmid: 11004423].
71 Agency for Healthcare Research and Quality. Methods guide for effectiveness and comparative effectiveness reviews. Rockville, MD. Agency for Healthcare Research and Quality. 2011.
72 Wells GA, Shea B, O’Connell D, et al. The Newcastle-Ottawa Scale (NOS) for assessing the quality of nonrandomised studies in meta-analyses. www.ohri.ca/programs/clinical_epidemiology/oxford.asp. Accessed April 11, 2013.
73 Jadad AR, Moore RA, Carroll D, et al. Assessing the quality of reports of randomized clinical trials: Is blinding necessary?. Control Clin Trials. 1996;17(1):1-12. [pmid: 8721797].
74 Atkins D, Chang S, Gartlehner G, et al. Assessing applicability when comparing medical interventions: AHRQ and the Effective Health Care Program. J Clin Epidemiol. 2011;64(11):1198-207. [pmid: 21463926].
75 Guyatt GH, Oxman AD, Kunz R, et al. GRADE guidelines: 7. Rating the quality of evidence--inconsistency. J Clin Epidemiol. 2011;64(12):1294-302. [pmid: 21803546].
76 Owens DK, Lohr KN, Atkins D, et al. AHRQ series paper 5: Grading the strength of a body of evidence when comparing medical interventions--Agency for Healthcare Research and Quality and the Effective Health-care program. J Clin Epidemiol. 2010;63(5):513-23. [pmid: 19595577].
77 Grading the strength of a body of evidence when assessing health care interventions: An update. [Draft]. Rockville, MD. Agency for Healthcare Research and Quality. 2012.
78 Hayden JA, Cote P, Bombardier C. Evaluation of the quality of prognosis studies in systematic reviews. Ann Intern Med. 2006;144(6):427-37. [pmid: 16549855].
79 Guyatt GH, Oxman AD, Montori V, et al. GRADE guidelines: 5. Rating the quality of evidence--publication bias. J Clin Epidemiol. 2011;64(12):1277-82. [pmid: 21802904].
80 Moher D, Liberati A, Tetzlaff J, et al. Preferred reporting items for systematic reviews and meta-analyses: The PRISMA statement. Ann Intern Med. 2009;151(4):264-9. W64. [pmid: 19622511].
81 Abbott JA, Kaldo V, Klein B, et al. A cluster randomised trial of an internet-based intervention program for tinnitus distress in an industrial setting. Cognit Behav Ther. 2009;38(3):162-73. [pmid: 19675959].
82 Azevedo AA, Figueiredo RR. Tinnitus treatment with acamprosate: Double-blind study. Revista Brasil Otorrinolaringol. 2005;71(5):618-23. [pmid: 16612523].
83 Anders M, Dvorakova J, Rathova L, et al. Efficacy of repetitive transcranial magnetic stimulation for the treatment of refractory chronic tinnitus: A randomized, placebo controlled study. Neuroendocrinol Lett. 2010;31(2):238-49. [pmid: 20424590].
84 Andersson G, Porsaeus D, Wiklund M, et al. Treatment of tinnitus in the elderly: A controlled trial of cognitive behavior therapy. Int J Audiol. 2005;44(11):671-5. [pmid: 16379495].
85 Aoki M, Wakaoka Y, Hayashi H, et al. Effect of lyophilized powder made from enzymolyzed honeybee larvae on tinnitus-related symptoms, hearing levels, and hypothalamus-pituitary-adrenal axis-related hormones. Ear Hear. 2012;33(3):430-6. [pmid: 21971082].
86 Arda HN, Tuncel U, Akdogan O, et al. The role of zinc in the treatment of tinnitus. Otol Neurotol. 2003;24(1):86-9. [pmid: 12544035].
87 Biesinger E, Kipman U, Schatz S, et al. Qigong for the treatment of tinnitus: A prospective randomized controlled study. J Psychosom Res. 2010;69(3):299-304. [pmid: 20708452].
88 Chung HK, Tsai CH, Lin YC, et al. Effectiveness of theta-burst repetitive transcranial magnetic stimulation for treating chronic tinnitus. Audiol Neuro Otol. 2012;17(2):112-20. [pmid: 21865723].
89 Cuda D, De CA. Effectiveness of combined counseling and low-level laser stimulation in the treatment of disturbing chronic tinnitus. Int Tinnitus J. 2008;14(2):175-80. [pmid: 19205171].
90 Dib GC, Kasse CA, Alves de AT, et al. Tinnitus treatment with Trazodone. Revista Brasil Otorrinolaringol. 2007;73(3):390-7. [pmid: 17684661].
91 Dineen R, Doyle J, Bench J. Managing tinnitus: A comparison of different approaches to tinnitus management training. Br J Audiol. 1997;31(5):331-44. [pmid: 9373742].
92 Dineen R, Doyle J, Bench J, et al. The influence of training on tinnitus perception: An evaluation 12 months after tinnitus management training. Br J Audiol. 1999;33(1):29-51. [pmid: 10219721].
93 Drew S, Davies E. Effectiveness of Ginkgo biloba in treating tinnitus: Double blind, placebo controlled trial. BMJ. 2001;322(7278):73. [pmid: 11154618].
94 Ghossaini SN, Spitzer JB, Mackins CC, et al. High-frequency pulsed electromagnetic energy in tinnitus treatment. Laryngoscope. 2004;114(3):495-500. [pmid: 15091224].
95 Henry JL, Wilson PH. The psychological management of tinnitus: Comparison of a combined cognitive educational program, education alone and a waiting list control. Int Tinnitus J. 1996;2:9-20. [pmid: 10753339].
96 Henry JL, Wilson PH. An evaluation of two types of cognitive intervention in the management of chronic tinnitus. Scand J Behav Ther. 1998;27(4):156-66.
97 Henry JA, Loovis C, Montero M, et al. Randomized clinical trial: Group counseling based on tinnitus retraining therapy. J Rehabil Res Dev. 2007;44(1):21-32. [pmid: 17551855].
98 Hiller W, Haerkotter C. Does sound stimulation have additive effects on cognitive-behavioral treatment of chronic tinnitus?. Behav Res Ther. 2005;43(5):595-612. [pmid: 15865915].
99 Holgers K-M, Zoger S, Svedlund J. The impact of sertraline on health-related quality of life in severe refractory tinnitus: A double-blind, randomized, placebo-controlled study. Audiol Med. 2011;9(2):67-72.
100 Kaldo V, Cars S, Rahnert M, et al. Use of a self-help book with weekly therapist contact to reduce tinnitus distress: A randomized controlled trial. J Psychosom Res. 2007;63(2):195-202. [pmid: 17662757].
101 Kaldo V, Levin S, Widarsson J, et al. Internet versus group cognitive-behavioral treatment of distress associated with tinnitus: A randomized controlled trial. Behav Ther. 2008;39(4):348-59. [pmid: 19027431].
102 Kroner-Herwig B, Hebing G, van Rijn-Kalkmann U, et al. The management of chronic tinnitus--Comparison of a cognitive-behavioural group training with yoga. J Psychosom Res. 1995;39(2):153-65. [pmid: 7595873].
103 Langguth B, Kleinjung T, Frank E, et al. High-frequency priming stimulation does not enhance the effect of low-frequency rTMS in the treatment of tinnitus. Exp Brain Res. 2008;184(4):587-91. [pmid: 18066684].
104 Malouff JM, Noble W, Schutte NS, et al. The effectiveness of bibliotherapy in alleviating tinnitus-related distress. J Psychosom Res. 2010;68(3):245-51. [pmid: 20159209].
105 Marcondes RA, Sanchez TG, Kii MA, et al. Repetitive transcranial magnetic stimulation improve tinnitus in normal hearing patients: A double-blind controlled, clinical and neuroimaging outcome study. Eur J Neurol. 2010;17(1):38-44. [pmid: 19614962].
106 Mazurek B, Haupt H, Szczepek AJ, et al. Evaluation of vardenafil for the treatment of subjective tinnitus: A controlled pilot study. J Negative Results Biomed. 2009;8:3. [pmid: 19222841].
107 Meeus O, De RD, Van de Heyning P. Administration of the combination clonazepam-Deanxit as treatment for tinnitus. Otol Neurotol. 2011;32(4):701-9. [pmid: 21358561].
108 Mirz F, Zachariae R, Andersen SE, et al. The low-power laser in the treatment of tinnitus. Clin Otolaryngol Allied Sci. 1999;24(4):346-54. [pmid: 10472473].
109 Piccirillo JF, Finnell J, Vlahiotis A, et al. Relief of idiopathic subjective tinnitus: Is gabapentin effective?. Arch Otolaryngol Head Neck Surg. 2007;133(4):390-7. [pmid: 17438255].
110 Plewnia C, Vonthein R, Wasserka B, et al. Treatment of chronic tinnitus with theta burst stimulation: A randomized controlled trial. Neurology. 2012;78(21):1628-34. [pmid: 22539568].
111 Rejali D, Sivakumar A, Balaji N. Ginkgo biloba does not benefit patients with tinnitus: A randomized placebo-controlled double-blind trial and meta-analysis of randomized trials. Clin Otolaryngol Allied Sci. 2004;29(3):226-31. [pmid: 15142066].
112 Rief W, Weise C, Kley N, et al. Psychophysiologic treatment of chronic tinnitus: A randomized clinical trial. Psychosom Med. 2005;67(5):833-8. [pmid: 16204446].
113 Robinson SK, Viirre ES, Bailey KA, et al. Randomized placebo-controlled trial of a selective serotonin reuptake inhibitor in the treatment of nondepressed tinnitus subjects. Psychosom Med. 2005;67(6):981-8. [pmid: 16314604].
114 Sharma DK, Kaur S, Singh J, et al. Role of acamprosate in sensorineural tinnitus. Indian J Pharmacol. 2012;44(1):93-6. [pmid: 22345878].
115 Sullivan M, Katon W, Russo J, et al. A randomized trial of nortriptyline for severe chronic tinnitus. Effects on depression, disability, and tinnitus symptoms. Arch Intern Med. 1993;153(19):2251-9. [pmid: 8215728].
116 Tass PA, Adamchic I, Freund H-J, et al. Counteracting tinnitus by acoustic coordinated reset neuromodulation. Restor Neurol Neurosci. 2012;30(2):137-59. [pmid: 22414611].
117 Topak M, Sahin-Yilmaz A, Ozdoganoglu T, et al. Intratympanic methylprednisolone injections for subjective tinnitus. J Laryngol Otol. 2009;123(11):1221-5. [pmid: 19640315].
118 Vilholm OJ, Moller K, Jorgensen K. Effect of traditional Chinese acupuncture on severe tinnitus: A double-blind, placebo-controlled, clinical investigation with open therapeutic control. Br J Audiol. 1998;32(3):197-204. [pmid: 9710337].
119 Westerberg BD, Roberson JB Jr, Stach BA. A double-blind placebo-controlled trial of baclofen in the treatment of tinnitus. Am J Otol. 1996;17(6):896-903. [pmid: 8915419].
120 Westin VZ, Schulin M, Hesser H, et al. Acceptance and commitment therapy versus tinnitus retraining therapy in the treatment of tinnitus: A randomised controlled trial. Behav Res Ther. 2011;49(11):737-47. [pmid: 21864830].
121 Zachriat C, Kroner-Herwig B. Treating chronic tinnitus: Comparison of cognitive-behavioural and habituation-based treatments. Cognit Behav Ther. 2004;33(4):187-98. [pmid: 15625793].
122 Zoger S, Svedlund J, Holgers KM. The effects of sertraline on severe tinnitus suffering—A randomized, double-blind, placebo-controlled study. J Clin Psychopharmacol. 2006;26(1):32-9. [pmid: 16415703].
123 Neri G, De SA, Baffa C, et al. Treatment of central and sensorineural tinnitus with orally administered Melatonin and Sulodexide: Personal experience from a randomized controlled study. Acta Otorhinolaryngol Ital. 2009;29(2):86-91. [pmid: 20111618].
124 Figueiredo RR, Langguth B, Mello de OP, et al. Tinnitus treatment with memantine. Otolaryngol Head Neck Surg. 2008;138(4):492-6. [pmid: 18359360].
125 Akkuzu B, Yilmaz I, Cakmak O, et al. Efficacy of misoprostol in the treatment of tinnitus in patients with diabetes and/or hypertension. Auris Nasus Larynx. 2004;31(3):226-32. [pmid: 15364356].
126 Bayar N, Boke B, Turan E, et al. Efficacy of amitriptyline in the treatment of subjective tinnitus. J Otolaryngol. 2001;30(5):300-3. [pmid: 11771024].
127 Dobie RA, Sakai CS, Sullivan MD, et al. Antidepressant treatment of tinnitus patients: Report of a randomized clinical trial and clinical prediction of benefit. Am J Otol. 1993;14(1):18-23. [pmid: 8424470].
128 Suckfüll M, Althaus M, Ellers-Lenz B, et al. A randomized, double-blind, placebo-controlled clinical trial to evaluate the efficacy and safety of neramexane in patients with moderate to severe subjective tinnitus. BMC Ear Nose Throat Disord. 2011;11(1):1. [pmid: 21223542].
129 Dehkordi MA, Abolbashari S, Taheri R, et al. Efficacy of gabapentin on subjective idiopathic tinnitus: A randomized, double-blind, placebo-controlled trial. Ear Nose Throat J. 2011;90(4):150-8. [pmid: 21500166].
130 Jakes SC, Hallam RS, McKenna L, et al. Group cognitive therapy for medical patients: An application to tinnitus. Cognit Ther Res. 1992;16(1):67-82.
131 Herraiz C, Diges I, Cobo P, et al. Auditory discrimination training for tinnitus treatment: The effect of different paradigms. Eur Arch Otorhinolaryngol. 2010;267(7):1067-74. [pmid: 20044759].
132 Olzowy B, Canis M, Hempel JM, et al. Effect of atorvastatin on progression of sensorineural hearing loss and tinnitus in the elderly: Results of a prospective, randomized, double-blind clinical trial. Otol Neurotol. 2007;28(4):455-8. [pmid: 17529847].
133 Searchfield GD, Kaur M, Martin WH. Hearing aids as an adjunct to counseling: Tinnitus patients who choose amplification do better than those that don’t. Int J Audiol. 2010;49(8):574-9. [pmid: 20500032].
134 Mason JD, Rogerson DR, Butler JD. Client centred hypnotherapy in the management of tinnitus—Is it better than counselling?. J Laryngol Otol. 1996;110(2):117-20. [pmid: 8729491].
135 Pandey S, Mahato NK, Navale R. Role of self-induced sound therapy: Bhramari Pranayama in Tinnitus. Audiol Med. 2010;8(3):137-41.
136 Erlandsson SI, Rubinstein B, Carlsson SG. Tinnitus: Evaluation of biofeedback and stomatognathic treatment. Br J Audiol. 1991;25(3):151-61. [pmid: 1873582].
137 Bonaconsa A, Mazzoli MM, Antonia M, et al. Posturography measures and efficacy of different physical treatments in somatic tinnitus. Int Tinnitus J. 2010;16(1):44-50. [pmid: 21609913].
138 Neri G, Baffa C, De SA, et al. Management of tinnitus: Oral treatment with melatonin and sulodexide. Journal of Biological Regulators & Homeostatic Agents. 2009;23(2):103-10. [pmid: 19589291].
139 Lindberg P, Scott B, Melin L, et al. The psychological treatment of tinnitus: An experimental evaluation. Behav Res Ther. 1989;27(6):593-603. [pmid: 2692553].
140 Gungor A, Dogru S, Cincik H, et al. Effectiveness of transmeatal low power laser irradiation for chronic tinnitus. J Laryngol Otol. 2008;122(5):447-51. [pmid: 17625032].
141 Roland NJ, Hughes JB, Daley MB, et al. Electromagnetic stimulation as a treatment of tinnitus: A pilot study. Clin Otolaryngol Allied Sci. 1993;18(4):278-81. [pmid: 8877185].
142 Khedr EM, Rothwell JC, Ahmed MA, et al. Effect of daily repetitive transcranial magnetic stimulation for treatment of tinnitus: Comparison of different stimulus frequencies. J Neurol Neurosurg Psychiatry. 2008;79(2):212-5. [pmid: 18202212].
143 Podoshin L, Ben-David Y, Fradis M, et al. Idiopathic subjective tinnitus treated by biofeedback, acupuncture and drug therapy. Ear Nose Throat J. 1991;70(5):284-9. [pmid: 1914952].
144 Muehlmeier G, Biesinger E, Maier H. Safety of intratympanic injection of AM-101 in patients with acute inner ear tinnitus. Audiol Neuro Otol. 2011;16(6):388-97. [pmid: 21252501].
145 Loke YK, Price D, Herxheimer A. Systematic reviews of adverse effects: Framework for a structured approach. BMC Med Res Methodol. 2007;7:32. [pmid: 17615054].
146 Montori VM, Guyatt GH. Intention-to-treat principle. CMAJ. 2001;165(10):1339-41. [pmid: 11760981].
147 Klockhoff I, Lindblom U. Meniere’s disease and hydrochlorothiazide (Dichlotride)--A critical analysis of symptoms and therapeutic effects. Acta Otolaryngol. 1967;63(4):347-65. [pmid: 6033658].
148 Geyh S, Cieza A, Schouten J, et al. ICF Core Sets for stroke. J Rehabil Med. 2004;(44 Suppl):135-41. [pmid: 15370761].
149 Meng Z, Liu S, Zheng Y, et al. Repetitive transcranial magnetic stimulation for tinnitus. Cochrane Database Syst Rev. 2011;(10):CD007946. [pmid: 21975776].
150 Hoare DJ, Kowalkowski VL, Kang S, et al. Systematic review and meta-analyses of randomized controlled trials examining tinnitus management. Laryngoscope. 2011;121(7):1555-64. [pmid: 21671234].
151 Hesser H, Gustafsson T, Lunden C, et al. A randomized controlled trial of Internet-delivered cognitive behavior therapy and acceptance and commitment therapy in the treatment of tinnitus. J Consult Clin Psychol. 2012;80(4):649-61. [pmid: 22250855].
152 Philippot P, Nef F, Clauw L, et al. A randomized controlled trial of mindfulness-based cognitive therapy for treating tinnitus. Clin Psychol Psychother. 2012;19(5):411-9. [pmid: 21567655].
153 Kochkin S, Tyler R, Born J. MarkeTrak VIII: The prevalence of tinnitus in the United States and the self-reported efficacy of various treatments. Hear Rev. 2011;18(12):10-27.
154 Nondahl DM, Cruickshanks KJ, Huang GH, et al. Generational differences in the reporting of tinnitus. Ear Hear. 2012;33(5):640-4. [pmid: 22588269].
155 Hoekstra CE, Rynja SP, van Zanten GA, et al. Anticonvulsants for tinnitus. Cochrane Database Syst Rev. 2011;(7):CD007960. [pmid: 21735419].
156 Karkos PD, Leong SC, Arya AK, et al. ‘Complementary ENT’: A systematic review of commonly used supplements. J Laryngol Otol. 2007;121(8):779-82. [pmid: 17125579].
157 Hilton M, Malcolm P, Stuart, et al. Ginkgo biloba for tinnitus. Cochrane Database Syst Rev. 2010;(3):CD003852.
158 Baldo P, Doree C, Molin P, et al. Antidepressants for patients with tinnitus. Cochrane Database Syst Rev. 2009;(1):CD003853.
159 Landgrebe M, Azevedo A, Baguley D, et al. Methodological aspects of clinical trials in tinnitus: A proposal for an international standard. J Psychosom Res. 2012;73(2):112-21. [pmid: 22789414].
160 Hesser H. Methodological considerations in treatment evaluations of tinnitus distress: a call for guidelines. J Psychosom Res. 2010;69(3):305-7. [pmid: 20708453].
161 Jenkins PA, Carroll JD. How to report low-level laser therapy (LLLT)/photomedicine dose and beam parameters in clinical and laboratory studies. Photomed Laser Surg. 2011;29(12):785-7. [pmid: 22107486].
162 Hesser H, Weise C, Rief W, et al. The effect of waiting: A meta-analysis of wait-list control groups in trials for tinnitus distress. J Psychosom Res. 2011;70(4):378-84. [pmid: 21414459].
163 Ioannidis JPA, Evans SJW, Gotzsche PC, et al. Better reporting of harms in randomized trials: An extension of the CONSORT statement. Ann Intern Med. 2004;141(10):781-8. [pmid: 15545678].